# Chapter 4 Discussion

## Summary of Evidence

We identified only one trial that provided direct evidence on the benefits and harms of screening for cognitive impairment. As such, our review primarily answers two questions: 1) How well does screening detect dementia or MCI in primary care? and 2) How effective are interventions to improve patient or caregiver outcomes in persons with mild to moderate dementia or MCI? We identified more than 260 studies that addressed these questions, more than a quarter of which were identified as part of this update. Despite the accumulation of new data, we believe that the conclusions are concordant with the findings of the previous review.^105,^ ^106^

Table 22 presents our summary of findings for all KQs as well as our assessment of the strength of evidence for each body of evidence.

Table 22 Summary of Evidence

Key Question Instrument or Treatment | Studies (k) Study Designs, Observations (n) | Summary of Findings | Consistency and Precision^*^ | Other Limitations | Strength of Evidence^*^ | Applicability
KQ 1 | k=1 RCT; n=4,005 | No evidence of a difference in health related QOL at 1, 6, and 12 months between those randomized to screening versus no screening as well as no difference in healthcare utilization and advanced planning at 12 months. | NA | High rate of missing data for all outcomes at all time points given attrition and data quality issues (42% missing data at 12 months for primary outcome). | Low evidence of no benefit | Mean age of participants within the one trial was 74.2 years and the majority were female (66%) and white (67%). Over one-third of primary care eligible older adults declined participation in the study and 66% of those who screened positive refused further diagnostic assessment.
KQ 2; Very brief instruments | k=31 cross sectional studies (6 new); n=22,359 | 25 instruments.; To detect dementia sensitivity was usually at 0.75 or higher and specificity at 0.80 or higher.; Across all very brief instruments, the detection of MCI was less consistent, with a wide range in sensitivity and specificity. | Reasonably consistent and precise (dementia); Inconsistent and imprecise (MCI) | Large number of instruments with little replication. | Moderate evidence of adequate sensitivity and specificity | Broad inclusion of older adult populations with a wide range of underlying dementia and MCI
KQ 2; Brief instruments | k=48 cross sectional studies (7 new); n=29,950 | 20 instruments.; For the MMSE, to detect dementia, 15 studies (n=12,796) resulted in a pooled sensitivity of 0.89 (95% CI, 0.85 to 0.92) and a specificity of 0.89 (95% CI, 0.85 to 0.93).; For other brief instruments reported in more than one study, sensitivity ranged from 0.74 to 1.0 and specificity ranged from 0.65 to 0.96.; Across all brief instruments, the detection of MCI was less consistent, with a wide range in sensitivity and specificity. | Reasonably consistent and precise (dementia); Inconsistent and imprecise (MCI) | Large number of instruments with little replication, except for the MMSE. | Moderate evidence of adequate sensitivity and specificity | Broad inclusion of older adult populations with a wide range of underlying dementia and MCI. Administration time less useful for primary care screening.
KQ 2; Longer, self-administered instruments | k=8 cross sectional studies (0 new); n=2,271 | 4 instruments.; Only the IQCODE was assessed in more than one study, with sensitivity to detect dementia ranging from 0.80 to 0.88 and specificity ranging from 0.51 to 0.91.; To detect MCI, sensitivity ranged from 0.71 to 0.82 and specificity ranged from 0.69 to 0.92. | Reasonably consistent (dementia and MCI); Precise (dementia and MCI) | Few instruments, little replication. | Moderate evidence of adequate sensitivity and specificity | Broad inclusion of older adult populations with a wide range of underlying dementia and MCI
KQ 3 | k=1 RCT; n=4,005 | No evidence of a difference in symptoms of depression or anxiety between those in the screening versus no screening arm at 1, 6, and 12 months followup. | NA | High rate of missing data for all outcomes at all time points given attrition and data quality issues (42% missing data at 12 months for primary outcome). | Low evidence of no harm | Mean age of participants within the one trial was 74.2 years and the majority were female (66%) and white (67%). Over one-third of primary care eligible older adults declined participation in the study and 66% of those who screened positive refused further diagnostic assessment.
KQ 4; AChEIs and memantine | k=48 RCTs (6 new); n=22,431 | Medications may improve measures of global cognitive function in short-term, but magnitude of differences between drug versus placebo groups was small. Pooled results indicate differences in change ranging from approximately 1 to 2.5 points in favor of drug groups on the ADAS-Cog-11 (range 0–70). For donepezil: MD, −2.13 95% CI: −0.94 to −3.32, k=6, n=1,981, I^2^=64.4%). For galantamine: MD, −2.13 (95% CI, −1.32 to −2.94, k=9, n=3,786, I=65.9). For rivastigmine: −2.43 (95% CI: −0.75 to −4.10, k=5, n=2,618, I^2^=81.9%). For memantine: −0.88 (95% CI: −0.11 to −1.65, k=8, n=2,609, I2=78.1%). Using accepted thresholds of clinical benefit, the average benefit across patients is not clinically significant.; AChEIs and memantine increased the likelihood of improving or maintaining patient’s global function (e.g., using a CIBIC+) by 15 percent (for memantine) to 50 percent (for rivastigmine) in the short-term (pooled 95% CI range, 0.49 to 2.69). Pooled continuous change found small effect sizes (SMDs ranging from 0.14 to 0.46).; Other important measures such as mental health and neuropsychiatric symptoms and rates of institutionalization were rarely reported; no trials included measures of QOL. | Reasonably consistent; Precise | Evidence of a small studies effect for the pooled result for global cognitive function measured by the MMSE for donepezil, indicating the possibility of publication bias.; Few trials included followup longer than 6 months. | Moderate evidence of a small benefit | Older adults with dementia (mainly AD), particularly among those with moderate versus mild forms. Unclear representation of ethnic minorities and those of varying education levels. Doses of medications applicable to common use.
KQ 4; Other medications and supplements | k=29 RCTs (5 new); n=6,489 | No evidence that antihypertensives, vitamins or omega-3 fatty acids, gonadal steroids, HMG-CoA reductase inhibitors, or NSAIDS are beneficial for any cognitive, functional or other outcome at 3 months to 4 years of followup. | Reasonably consistent; Imprecise | Small trials often with differential attrition between groups.; Lack of consistency in formulations and dosages of agents used. | Low evidence of no benefit | Older adults with mild to moderate dementia.; Unclear representation of ethnic minorities and those of varying education levels.
KQ 4; Nonpharmacologic patient-level interventions | k=61 RCTs (39 new); n=7,847 | No clear benefit of cognitive stimulation, training, or rehabilitation, exercise interventions, multicomponent interventions, and other interventions on global and domain-specific cognitive function compared with controls at 3 months to 2 years followup among persons with MCI or dementia. Effect estimates generally favored intervention groups, but the magnitude of effects was inconsistent across trials and represented very wide CIs. Measures related to physical function, QOL, and mental and neuropsychiatric symptoms were only reported by half or less of the trials for each intervention group and few found robust differences between groups. | Reasonably consistent; Imprecise | Small studies of limited duration. Types of outcomes, specific measures, and duration of followup was highly variable across trials. | Low evidence of small to no benefit | Broad range of older adults with MCI and mild and moderate dementia. Very sparse reporting of clinical characteristics of the included patients such as race/ethnicity and education. Virtually no data on effect modification by important clinical differences. Many complex interventions may not be widely available in the U.S.
KQ 4; Caregiver and caregiver-patient dyad interventions | k=88 RCTs (33 new); n=14,880 | Consistent benefit of psychoeducation and care and case management interventions on caregiver burden and depression outcomes. However, effect sizes were mostly small and are of unclear clinical significance. For caregiver burden, the standardized pooled effect was −0.24 (95% CI, −0.36 to −0.13]; I^2^=50.2%; k=27; n=2,776) for psychoeducation interventions and −0.54 (95% CI, −0.85 to −0.22); k=8; n=1,215; I^2^=82.9%) for care and case management interventions.; Other outcomes such as caregiver or patient QOL, rates or time to institutionalization, patient mental health and neuropsychiatric symptoms, and patient functional ability were sparsely reported across the trials with no consistent evidence of a benefit. Decision-making and preparation for meeting dementia-related needs were only reported by one trial each with neither finding statistically significant benefit of the interventions versus control conditions on overall scores for these measures. | Reasonably consistent; Precise | Little evidence of longer-term effects; inconsistency in outcomes and specific measures across trials with many providing little data on precise scales used. | Moderate evidence of small benefit | Generally applicable to caregivers of persons with moderate dementia. Many complex interventions may not be widely available in the U.S.
KQ 5; AChEIs and memantine | k=48 RCTs (6 new) n=22,431; k=3 obs. studies (1 new) n=190,076 | Side effects from medications were common. Withdrawal or discontinuation was more common with AChEIs (13% withdrawing for donepezil and rivastigmine, 14% for galantamine) than placebo (8%). Memantine appeared to be better tolerated, with no difference in withdrawal rates (8%) compared with placebo (8%). In total, there did not appear to be a difference in total SAEs for these medications across trials with limited duration of followup. However, individual studies, including observational evidence, reported increased rates of bradycardia, and relatedly, of syncope, falls and need for pacemaker placement among those exposed versus unexposed to AChEIs. | Reasonably consistent; Precise | The definitions of serious adverse events, which likely vary, were rarely described in the included studies. | Moderate evidence of harm | Mostly represented patients with moderate dementia.
KQ 5; Other medications and supplements | k=21 RCTs (4 new); n=5,688 | Across interventions, harms were not clearly significantly increased in intervention vs. control groups. | Reasonably consistent; Precise | Small trials often with differential attrition between groups. Lack of consistency in formulations and dosages of agents used. | Low evidence of no harm | Older adults with mild to moderate dementia. Unclear representation of ethnic minorities and those of varying education levels.
KQ 5; Nonpharmacologic patient-level interventions | k=12 RCTs (11 new); n=2,370 | Little evidence of harms from good quality studies. Evidence of greater musculoskeletal problems among persons taking part in exercise interventions versus comparators. One trial reported one case of atrial fibrillation among one patient during an exercise session. | Reasonably consistent; Precise | Sparse reporting of harms. Trials of exercise interventions more likely to report monitoring harms than cognitive training or other interventions | Low evidence of no harm^†^ | Applicable to patients with mild-to-moderate dementia and MCI.
KQ 5; Caregiver and caregiver-patient dyad interventions | k=4 RCTs (3 new); n=486 | No harms evident. | NA | Sparse reporting of harms for patients or caregivers. | Low evidence of no harm^†^ | Generally applicable to caregivers of persons with moderate dementia.

* For KQ 4, consistency, precision, and strength of evidence, assessments were based on primary outcomes within each body of evidence. For AChEIs and memantine, assessments were for cognitive function and global function outcomes. For, other medications and supplements assessments were for cognitive function. For nonpharmacologic patient-level interventions, assessments were for cognitive function, physical function, and neuropsychiatric symptoms. For caregiver and caregiver-patient dyad interventions, assessments were for caregiver burden and depression outcomes.

† No hypothesized serious harms of nonpharmacologic patient or caregiver interventions. Thus, despite few trials reporting this outcome, we have low confidence that the finding of no harm in these two trials reflects this body of evidence.

Abbreviations: AChEIs = acetylcholinesterase inhibitors AD = Alzheimer’s disease; CI = confidence interval; CIBIC+ = Clinicians’ Interview-Based Impression of Change plus informant input; CG = control group; HMG-CoA = 3-hydroxy-3-methyl-glutaryl-CoA reductase; IG = intervention group; K = number of trials; MCI = mild cognitive impairment; N = population size; n = sample size; NA = not applicable; NR = not reported; NSAIDs = Nonsteroidal Anti-inflammatory Drugs; obs = observational; QOL = quality of life; RCT = randomized controlled trial; SAE = serious adverse events; vs = versus

### Screening

Our review identified a very large body of well-conducted test-accuracy studies that evaluated brief screening instruments in unselected, community-dwelling older adults. In general, these instruments have adequate sensitivity (mostly ≥75%) and specificity (mostly ≥80%) to detect dementia, although estimates vary and the optimal diagnostic thresholds or cutoffs for many of these instruments are unclear. Across all instruments, sensitivity was generally higher in the detection of dementia than in the detection of cognitive impairment (inclusive of MCI alone or MCI and dementia diagnoses), although the confidence intervals often overlapped and the cutoffs were not always adjusted to identify a lower level of impairment. Because many instruments focus preferentially on memory dysfunction (as opposed to other domains of cognitive function), it is thought that some instruments may perform better (or more consistently) for different types of dementia. For instance, memory loss is the hallmark of AD dementia but is not necessarily impaired at an early stage with other types of dementia. Unfortunately, most studies did not specify what types of dementia were identified, although most cases are presumed to be AD.

Even though this is a large body of evidence, only a handful of instruments have been evaluated in more than one study and few are very brief instruments that may be more applicable to primary care. The MMSE is the most thoroughly studied instrument, but it has a relatively long administration time (~7 to 10 minutes) and is not available for use without cost. Our bivariate pooled analysis for the MMSE at a cutoff of 23 or less or 24 or less (≤23 is the recommended cutoff) resulted in 89 percent sensitivity (95% CI, 0.85 to 0.92; I^2^=58.7%) and 90 percent specificity (95% CI, 0.86 to 0.93; I^2^=97.4%) (k=14; n=11,972) to identify dementia. Among the other instruments examined in at least two studies with adequate test performance to detect dementia among primary care–relevant populations, are: very brief instruments such as the Clock Drawing Test, the MIS, which includes the Memory Impairment Screen Telephone and Mental State Questionnaire, the Mini-Cog, verbal fluency tests, the AD8, and the Functional Activities Questionnaire; brief instruments such as the Abbreviated Mental Test, Montreal Cognitive Assessment, 7-Minute Screen, and Saint Louis University Mental Status Examination; and the longer, self-administered IQCODE short and long forms. Four of these instruments (the Mini-Cog, MIS, AD8, and short IQCODE) and the GPCOG are endorsed by the Alzheimer’s Association, Gerontological Society of America, or NIA for use in primary care. In all cases, administration of these structured screening instruments is advised if signs or symptoms of cognitive impairment are present upon review of a health risk assessment or through clinical observation or if concerns are raised by the patient or informant.^103,^ ^104,^ ^415^

Only one trial has examined the potential benefits and harms of screening (vs. no screening) on patient-reported outcomes and measures of health care utilization and future planning. In that one trial, there was no evidence of harm (i.e., no greater increase in symptoms of depression or anxiety) nor benefit (i.e., no difference in health-related QOL, health care utilization, or advanced planning) at 1, 6, and 12 months following screening. Importantly, more than a third of primary care patients age 65 years and older eligible for the trial agreed to participate and of those in the screening arm who screened positive (7.7%), two-thirds refused to go on for further diagnostic assessment and followup care.

#### Hypothesized Benefits and Harms of Screening

Hypothesized benefits of screening for, or early detection of, cognitive impairment include the ability to: 1) optimize current medical management (e.g., search for potentially treatable or reversible disorders such as medication interactions, depression, and thyroid disease), factor in patient comprehension of and compliance with treatment plans and other conditions, avoid medications with anticholinergic effects, and better manage related symptoms, such as depression and irritability; 2) enhance understanding of the disease, including its symptoms and course and thereby help caregivers and patients better adapt to and manage the diagnosis; 3) help ensure appropriate access to programs and services for patients and families; and 4) ensure risk reduction (e.g., consider strategies to prevent delirium, motor vehicle accidents, medication errors, and financial difficulties).^416^ Perhaps the best rationale to routinely screen for cognitive impairment in older adults is that early diagnosis can positively influence decision making that leads to improved patient outcomes and reduced future costs. This may include facilitating involvement of patient and caregivers in planning medical, educational, and psychosocial interventions to suit their needs; starting early so the patient can still participate in medical, legal, and financial decisions; and making proxy plans.^416^ While these are all logical arguments, there is currently little or no empirical evidence, including qualitative evidence, to support them.^417^

Screening for cognitive impairment may also have direct or indirect harms as a result of diagnostic inaccuracy (false-positives and false-negatives) and because of the negative emotions and stigmatization that may arise once the patient is diagnosed.^418,^ ^419^ We only found one trial however, to substantiate or refute concerns about harms of screening. Recent systematic reviews regarding patients’ attitudes and preferences about screening for dementia found mixed evidence. Some studies suggested that patients have no concerns and welcome having their memory evaluated, whereas others suggested that few persons would agree to routine screening for memory problems for reasons such as stigma.^417,^ ^420^ Additional cross-sectional evidence in this review suggested that caregivers and the general public believe they will benefit from being screened for dementia, in part because there are effective treatments and financial benefits.^417,^ ^421,^ ^422^ However, a few studies suggest that a high proportion (48% to 67%) of patients who screen positive for cognitive impairment refuse a diagnostic evaluation.^423,^ ^424^

Some studies suggest that a dementia diagnosis can be difficult for patients, whereas others find no deleterious associations. One recent study found that patients experienced higher stress, greater depression, and lower QOL with awareness of their diagnosis of MCI or early-stage AD vs. those who were unaware of their condition.^425^ Similarly, another study found that older adults who knew they were ApoE4 carriers reported more symptoms of cognitive decline and performed more poorly on measures of memory than adults who were ApoE4 carriers but had no information about their genetic risk.^426^ Other studies, however, have found no association between a formal dementia diagnosis and poor psychological health outcomes.^427–431^ Given the cross-sectional nature of the data, these studies have many limitations, and none provided a comprehensive look at the harms (or benefits) of routine screening.

### Treatment

Our review was not a comprehensive synthesis of all treatment and management options for persons with cognitive impairment; instead, we focused on selected interventions aimed at persons with mild to moderate dementia or MCI (i.e., those populations more representative of screen-detected older adults with cognitive impairment). We reviewed available pharmacologic interventions in the United States, including FDA-approved medications for use in AD such as AChEIs and memantine, potentially disease-modifying medications (i.e., antihypertension therapy, HMG Co-A reductase inhibitors, NSAIDs, and gonadal steroids), and vitamins and supplements. Nonpharmacologic interventions represented in this review included focused and complex interventions aimed at the patient (i.e., cognitive-focused interventions, exercise interventions, and multicomponent interventions) and focused and complex interventions aimed at the caregiver or caregiver-patient dyad, including psychoeducation and care management or care coordination interventions.

Overall, based on the large body of evidence, AChEIs (donepezil, galantamine, and rivastigmine) and memantine can improve global cognitive function in the short term. The improvements seen, however, are small and may not be clinically important. On average, differences between persons taking these medications and those receiving placebo favored the medications by only about 1 to 2.5 points on the ADAS-Cog and 0.50 to 1.25 points on the MMSE. The values commonly accepted as clinically important are an ADAS-Cog change of 4 points or more (on a scale of 0–70) or an MMSE change of 3 points or more (on a scale of 0–30).^107^ Given the consistency in the effect estimates across trials and precision in these estimates over time, we are moderately confident that our pooled estimates and the results of the body of evidence lie close to true effects. While measures of global function were less commonly reported, they were still reported in most medication trials. AChEIs and memantine increased the likelihood of improving or maintaining patients’ global function by 15 percent (for memantine) to 50 percent (for rivastigmine) in the short term (generally 6 months or less) compared with placebo. There was limited evidence about the effects of these medications on measures of physical function and other important patient-reported outcomes, and the measures showed mixed results when they were reported. None of the trials of medications reported QOL outcome measures. Almost all available evidence is from trials in persons with dementia, particularly those with AD and those with moderate as opposed to mild forms of dementia. Evidence for these medications in persons with MCI is much more limited. Trials of donepezil and memantine in patients with MCI showed no benefit on global cognitive function or in the rate of conversion from MCI to AD.

Side effects are common with all these medications and discontinuation due to AEs from AChEIs, but not memantine, was higher in treatment groups than in control groups. While there did not appear to be an increase in SAEs in the medication trials of limited duration, some of the individual studies, including observational evidence, reported increased rates of bradycardia, and relatedly, of syncope, falls, and need for pacemaker placement among those exposed vs. unexposed to AChEIs. We did not abstract and analyze common adverse reactions, but the types and relative frequencies are well-described.^432^ The most common side effects for AChEIs include gastrointestinal symptoms (i.e., nausea, vomiting, diarrhea, anorexia, and abdominal discomfort), central nervous system symptoms (i.e., dizziness, headaches, sleep disturbance, somnolence, confusion, fatigue, depression, and other mood or neuropsychiatric disturbances), and cardiovascular signs/symptoms (i.e., bradycardia, hypertension, syncope, and chest pain). The most common adverse reactions for memantine include gastrointestinal symptoms (i.e., constipation, vomiting), central nervous system symptoms (i.e., dizziness, headaches, somnolence, confusion, fatigue), and cardiovascular signs (i.e., hypertension).

We have limited confidence in the evidence regarding effects of other medications, vitamins, and supplements on important functional outcomes. Although some individual trials reported promising effects particularly for vitamin E supplementation, in general, there was no consistent benefit on cognitive or physical function among those with mild to moderate dementia or MCI within each class of therapy. Harms of these agents were not clearly higher in intervention groups than in control groups.

Most of the new evidence in this review is related to nonpharmacologic patient interventions, namely cognition-focused interventions and exercise interventions among those with mild to moderate dementia (not identified through screening). While there was a relatively large number of studies, most of the individual trials were small (<100 participants). There was no overall evidence that cognitive stimulation, training, or rehabilitation improved global or domain-specific measures of cognitive function at 3 to 12 months followup. Effect estimates generally favored the intervention groups over control groups, but the magnitude of effect was inconsistent in trials and represented very wide confidence intervals (ranging from no effect to a large effect). While a pooled analysis of cognitive training, stimulation, and rehabilitation intervention trials found a small, statistically significant mean difference of about 1.5 points on the MMSE, there was substantial clinical and statistical heterogeneity. Furthermore, there was no overall pooled difference between groups when looking specifically at measures on the ADAS-Cog. There was also no evidence that the effect of the interventions was modified based on study, population, or intervention characteristics and no evidence of longer-term effects on cognitive function. Only about half of the trials evaluating cognition-focused interventions reported other important patient outcomes such as measures of ADLs and IADLs, neuropsychiatric symptoms, or QOL, with most finding very little change over time in both intervention and control participants or small and relatively equal decline in these measures over time. Though the scales range considerably, the majority of between-group differences did not exceed a 1-point difference in favor of either group on any of these measures. Similarly, trials of exercise interventions resulted in no marked improvement in measures of global or domain-specific cognitive function compared with no intervention or usual care. There was a favorable pattern, however, for the effect of exercise interventions on measures of physical function, with those taking part in exercise interventions experiencing small improvements of unclear clinical significance (e.g., by approximately 1 point), whereas control groups reported worsening function over 3 months to 1 year. This evidence is limited by possible selective reporting (only half of the exercise trials reported this outcome) and considerable heterogeneity in the instruments used to measure these outcomes. Likewise, there was a pattern of effect favoring the exercise groups compared with the control groups for measures of global cognitive function and neuropsychiatric and behavioral symptoms, but differences between groups were small and of unclear clinical magnitude. There were no clear benefits of multicomponent or other patient-level nonpharmacologic interventions on any important patient-reported outcome. Even those trials that specifically targeted improvements in patients’ well-being and QOL found no differences between groups on these measures. Regarding all types of patient-level interventions, potential harms were rarely reported. Given the considerable heterogeneity both in the clinical characteristics of these trials and the lack of consistency and precision in the effect sizes across trials, we have low confidence that the pooled effects and patterns of effects we report in this review reflect true average effects. The heterogeneity in each individual intervention arm and differences in the populations, settings, and trial quality made it difficult to disentangle what variables might be driving larger effects, even within subgroups of interventions.

The largest body of evidence in our review included trials evaluating interventions targeting caregivers of those with dementia or the caregiver-patient dyad. Almost all the included evidence pertained to patients (or their caregivers) with dementia; very few included any patients with MCI. Further, most trials represented patients with moderate as opposed to mild dementia and none of the interventions were linked with a standard screening program. In general, these individual trials were larger and longer in duration than the other nonpharmacologic studies (likely due to the younger age and relative health of caregivers compared with patients and therefore, a greater ability to minimize loss to followup). Among trials evaluating a psychoeducation intervention for caregivers, we found that these interventions can reduce caregiver burden and depression more so than no intervention, usual care, or other brief interventions, but the average effects for both outcomes were small. Interpretation of the pooled standardized effect sizes and their 95 percent confidence intervals ranged from very small (about 0.1) to small (about 0.3), representing between-group differences of approximately 0.5 to 3.5 points on the Zarit-22 (88-point scale) or 1.5 to 4 points on the CES-D (60-point scale). In most cases, caregivers in the intervention groups reported experiencing fewer depressive symptoms or a reduced burden over time, whereas caregivers in the control groups reported slightly more symptoms or little change over time. Slightly larger effects on caregiver burden were seen among trials evaluating comprehensive care or case management interventions. The pooled effects of care management interventions vs. usual care or other brief interventions on caregiver burden indicated small (0.2) to large (0.8) effects, translating to a between-group difference of approximately 3.5 to 4 points on the Zarit-22. While effects trended toward a benefit of care management interventions on caregiver depression, the effects were small, and pooling all available data indicated no association. Regarding both outcomes and trials, the 95 percent confidence intervals of the study-level between-group differences were often wide, suggesting a range in benefit (or lack thereof) across participants. There was no evidence in our meta-regressions, however, that one type of intervention (psychoeducation vs. care or case management vs. other caregiver or caregiver-patient dyad interventions) was more effective than the others regarding measures of caregiver burden or caregiver depression. Likewise, there were no study, population, or intervention characteristics that consistently and robustly predicted larger effects on caregiver burden or depression outcomes.

Many of these interventions, particularly those employing care management programs, had explicit goals to maximize the ability of both patients and caregivers to keep patients at home or in assisted living settings and out of skilled nursing facilities. There was a pattern of benefit where fewer persons in the intervention group were placed in nursing homes (or experienced delayed time to institutionalization) compared with those in usual care, but very few trials found these differences to be statistically significant. While delay of institutionalization may be one of the most clinically important outcomes to examine within this field, it is potentially inappropriate if it is accompanied by increased stress or negative mental and physical health on the part of family caregivers.^433,^ ^434^ Few studies, however, have examined this relationship. Other outcomes such as caregiver or patient QOL, patient mental health and neuropsychiatric symptoms, and patient functional ability were sparsely reported across the trials, with no consistent evidence of a benefit. Decision making and preparation for meeting dementia-related needs were only reported by one trial each, with neither finding statistically significant benefit of the interventions vs. control conditions on overall scores for these measures. Only two trials reported monitoring harms related to the caregiver interventions and no harms were evident.

## Comparison With Other Existing Systematic Reviews

The findings of our review are consistent with the conclusions of other recent systematic reviews that have examined the test performance of instruments to detect dementia or MCI.^435,^ ^436^ Even with the expansion of scope in these other systematic reviews (e.g., inclusion of any clinical setting, case-control studies), these other reviews also concluded the MMSE is the most-studied instrument with test performance similar to what was seen in our review (pooled sensitivity and specificity of 0.71 and 0.74 to detect MCI and 0.81 and 0.89 to detect dementia). They additionally note that several instruments have comparable test performance as the MMSE, such as the Mini-Cog or MoCA.

Likewise, the findings of our review are generally concordant with those other recent systematic reviews that have synthesized the evidence on the benefits and harms of pharmacological and nonpharmacological interventions in persons with MCI and mild to moderate dementia. Similar to our review, most of the identified recent reviews of trials testing the effectiveness of AChEIs and memantine found short-term small statistically significant improvements on global cognitive function and global function, as well as increased risk of adverse events compared with placebo groups.^437–442^ Likewise, our findings on the benefits and harms of other medications, vitamins, and supplements are consistent overall with those of comparable reviews, with primarily null findings across all reported outcome types.^443–446^

Furthermore, recent reviews of trials evaluating patient-level cognitive-focused and physical activity interventions accord with our findings in that there was little to no benefit of the interventions on global and domain-specific cognitive function.^325,^ ^326,^ ^447^ Similar to our review, one review of physical activity interventions found a minor improvement in physical function.^447^ On the contrary, evidence from recent reviews of studies targeting caregivers of persons with dementia was less consistent with our findings.^448–451^ That is, three of the four identified reviews found no benefit for caregiver burden, with inconsistent findings for other outcomes (e.g., depression, QOL, anxiety) associated with counseling, case management, and mindfulness-based stress reduction interventions. These discordant findings are primarily due to key differences in scope resulting in lesser evidence bases in each of the respective reviews.

## Implementation of Screening

Our review included an examination of brief screening instruments that could be administered in primary care (i.e., before, during, or after visits) by a clinician or primary care staff with minimal training or self-administered by the patient or a close informant. Most of the included instruments are available in the public domain, although the MMSE (which remains the best-studied instrument) is a notable exception. The opportunity cost of screening can be minimized by choosing very brief instruments or those that can be self-administered. However, we acknowledge that there are implications for the subsequent workup of persons with screen-detected cognitive impairment, including issues regarding guidance on best practices for satisfactory diagnostic workup, resources and capacity for neuropsychological testing or referral to neurology, psychiatry, or geriatric specialty services (if needed), and the potential for refusal of diagnostic workup and issues around acceptability of further testing and the diagnosis itself.

### Routine Screening vs. Case Finding

There is disagreement about the best approach to detect cognitive impairment. Many believe the best approach is to routinely administer a brief cognitive test to all older adults or older adults older than a specified age, then provide a diagnostic evaluation or referral for those whose scores are consistent with possible dementia. Also recommended is a stepwise approach of administering a brief cognitive test only to persons at high risk for or who have suspected cognitive impairment based on clinician observation, self- (or informant-) reported concerns, or review of a health risk assessment or single item indicating subjective cognitive complaints or concerns related to one’s everyday function. This approach can be viewed as a two-step screening process or a case-finding approach: screening with a question on cognitive complaints and an assessment of ADLs/IADLs, followed by administration of a brief instrument designed to assess cognitive impairment. We found no evidence to support or refute this proposed method. We did, however, find one study that used electronic medical record data to identify patients at increased likelihood of having undiagnosed dementia based on their history of stroke and emergency department visits and found a higher likelihood of dementia diagnoses among that group vs. controls.^452^ Our review focused on screening among older adults without known cognitive impairment and therefore did not address the use of brief cognitive instruments in persons with observed deficits (i.e., case-finding). We did, however, include studies that enrolled patients with subjective memory complaints, given the high prevalence of memory complaints in general among older adults. No pattern was seen in the test performance or prevalence of dementia for these studies compared with those that did not have a subjective memory complaint requirement. Further research comparing which criteria (e.g., age, comorbid conditions, functional status, self-reported memory complaint) should lead primary care clinicians to conduct cognitive screening, and perhaps how often screening should be conducted, is needed.

### Age at Which to Start (and Stop) Screening

Age is the biggest risk factor for cognitive impairment. Therefore, if screening is advisable, using age to target cognitive screening is a reasonable strategy. While population estimates vary, the best estimates for dementia prevalence in North America are generally low (<5%) before age 75 years and rises to approximately 10 percent among 75- to 84-year-olds and nearly 30 percent among those age 85 years and older.^4,^ ^23^

The prevalence of dementia greatly affects the positive predictive value (PPV) of testing and therefore can be used to infer reasonable ages at which to start screening for cognitive impairment or possibly target subpopulations in which it could be reasonable to start earlier screening. Looking across a range of sensitivities and specificities representative of currently available brief cognitive screening instruments based on our review, it appears that the PPV is greater than 60 percent if the prevalence of underlying dementia approximates 30 percent (Table 23). The general prevalence is much lower in populations younger than age 85 years, as are the PPVs across a range of sensitivities and specificities. If screening is advisable, there is no compelling rationale to stop screening based on increasing prevalence with age. Therefore, the rationale for stopping screening should be based on evidence that intervening in the oldest old (age 85 years and older) does not improve important outcomes or the harms of intervening outweigh the potential benefit. Our review does not support or refute this idea. Arguably, cognitive screening in the oldest old may be considered case-finding as opposed to true screening, as the prevalence of memory complaints is extremely high in this group.

Table 23 Positive and Negative Predictive Values for Various Sensitivity and Specificity Values, by Age Group Screening

| Age Group, years | Dementia prevalence, percent^*^ | PPV, percent | NPV, percent
Sensitivity 70; Specificity 80 | 65–74 | 3 | 10 | 99
Sensitivity 70; Specificity 80 | 75–84 | 10 | 28 | 96
Sensitivity 70; Specificity 80 | 85+ | 30 | 60 | 86
Sensitivity 80; Specificity 90 | 65–74 | 3 | 20 | 99
Sensitivity 80; Specificity 90 | 75–84 | 10 | 47 | 98
Sensitivity 80; Specificity 90 | 85+ | 30 | 77 | 91
Sensitivity 90; Specificity 90 | 65–74 | 3 | 22 | 100
Sensitivity 90; Specificity 90 | 75–84 | 10 | 50 | 99
Sensitivity 90; Specificity 90 | 85+ | 30 | 79 | 95

* Dementia prevalence based on 2012 data reported by Langa and colleagues.^23^

Abbreviations: PPV = positive predictive value; NPV = negative predictive value.

### Screening Interval

Likewise, at a population level, the timing and frequency of rescreening is partly dependent on the incidence of dementia and the test performance of the cognitive screening instrument (i.e., rescreening can improve the sensitivity to detect dementia). Overall, there is a wide range of incidence rates. The incidence rate grows exponentially with age, and the estimated doubling time of AD incidence in North America is 6 years.^27,^ ^453^ Incidence rates from one U.S.-based longitudinal cohort study demonstrated that rates increase with age, from 11.7 cases per 1,000 person-years at younger than age 75 years to 32.0 cases per 1,000 person-years at ages 75 to 79 years, 57.5 cases per 1,000 person-years at ages 80 to 84 years, and 95.9 cases per 1,000 person-years at age 85 years and older.^454^ If screening is advisable, based on incidence alone, it is reasonable to offer repeated screening, such as annually, and it may be reasonable to increase the frequency of repeated screening with increasing age (or other risk factors), such as more frequent screening in the oldest old (age ≥85 years), based on the very high incidence of dementia in this group. Repeated screening will also improve the cumulative sensitivity to detect dementia. Therefore, it may be reasonable to choose an instrument or cutoff for an instrument with very high specificity (e.g., >90%) at the expense of a slightly lower sensitivity, knowing that with repeated screening over time, the cumulative sensitivity will be much higher. Thresholds for acceptable levels of sensitivity and specificity, and therefore choice of instrument and cutoffs, may vary depending on the stakeholder’s resources and preferences.

## Limitations of Our Approach

Our review has several limitations given our primary aim and target audience—the USPSTF. It was relatively narrow in scope and was not meant to be a comprehensive review of all cognitive screening instruments nor all dementia treatments. We focused on the best-quality evidence for the diagnostic accuracy of cognitive screening instruments in community-dwelling older adults relevant to primary care in the United States. Therefore, we excluded case-control studies, instruments with lengthy administration times, and studies among institutionalized adults or among those selected based on cognitive impairment or clinically suspected cognitive impairment. Additionally, we did not address other important aspects of screening test performance, including the psychometric properties of instruments (besides sensitivity and specificity), the comparative performance of screening instruments, and the ability to improve diagnostic performance by combining screening instruments.

Likewise, our review focused on best-quality evidence for interventions applicable to community-dwelling older adults with screen-detected cognitive impairment. We included only evidence among older adults (or their caregivers) with mild to moderate dementia or MCI and excluded studies among institutionalized older adults and those with severe dementia, trials of experimental therapy, and interventions aimed primarily at symptom management. Despite our best efforts, there may have been some inconsistency in operationalizing these inclusion criteria and in categorizing the interventions due to reporting in individual trials. We also did not address the comparative effectiveness of different types of interventions. Given the heterogeneity in the included evidence, even within subgroups of interventions, we were unable to explain important population or intervention characteristics that predicted larger effects or the minimum components of effective interventions.

## Limitations of the Studies and Future Research Needs

Despite such a large body of research on the test accuracy of screening for cognitive impairment, as well as treatment and management of persons with dementia and MCI, there are several important limitations and research gaps in the evidence base. First is the lack of evidence around decision making outcomes. Experts in the field argue that early diagnosis is important because it influences clinical and patient decision making. While this is a reasonable argument, there is currently little to no empirical evidence to support it. Researchers should conduct screening trials or observational studies to demonstrate changes in decision making (at a minimum) and patient or caregiver outcomes (as an ideal). Studies examining how (and whether) earlier identification of cognitive impairment or earlier management of patients with dementia and their caregivers influence clinician decision making (e.g., medical management of comorbid conditions) and patient and family decision making (e.g., advanced planning) are critical to improving management of this rapidly growing health care problem.

Second, the harms of screening are very poorly studied. Some have argued that the harms of screening, other than the opportunity cost, are minimal given the noninvasive nature of screening and subsequent diagnostic workup. Others have argued that the harms of screening and mislabeling persons with dementia are quite real given the variation in practice of diagnostic confirmation of disease. If a broader adoption of screening for cognitive impairment is implemented in primary care, we need a better understanding of what, or whether, harmful tradeoffs exist.

Third, while there are many well-designed diagnostic accuracy studies, there has been very little reproducibility in testing instruments, at consistent cutoffs and for specific conditions, in primary care populations. Well-conducted diagnostic accuracy studies for the most promising instruments or those currently endorsed in national guidance need to be reproduced in relevant populations. These diagnostic accuracy studies should report adequate baseline population characteristics, including age and education (characteristics known to affect normative values of the instrument). These studies should report multiple cut-points if applicable and be explicit about scoring methods or choice of cut-points (if multiple options exist). Furthermore, studies should be explicit in describing which types of dementia were identified and have large enough samples to report the test accuracy of the instrument in detecting different forms of dementia.

Fourth, while our report did not evaluate the role of biomarkers (such as those found in plasma, urine, or cerebrospinal fluid) or imaging in screening for diseases affecting cognition, such as AD (as this field is still developmental), it is an active field of research focused on early (even preclinical) detection of disease.^455^ If these types of tests prove useful in the diagnosis of types of dementia or MCI, they may provide an additional “gold standard” for diagnostic accuracy and calibration. They may also be useful for case-finding or screening purposes, should the eventual discovery of reliable, valid, sensitive, specific, and affordable tests be manifested.^456^

Fifth, a major limitation in the treatment literature is the short followup duration (generally 6 months or less for pharmacologic trials and 1 year or less for nonpharmacologic trials). Dementia is a chronic condition that worsens over time; while 1 year of observation provides time to monitor changes in most outcomes, it does not provide a long enough observation period for more distal outcomes such as nursing home placement or mortality. Indeed, most of the included evidence did not include reports on rates of institutionalization or mortality, nor was it powered to detect differences in such outcomes. We acknowledge, however, that trials in older adult populations with longer duration and followup run the risk of heightened attrition due to institutionalization and mortality in addition to more general tendencies of attrition seen in longer-term studies.

Sixth, there are numerous challenges surrounding measurement within the treatment literature. In general, trials offer little consistency in the specific outcomes reported. Even within specific outcomes, the wide variation in the measures make cross-study comparisons difficult. A strikingly high number of trials do not fully describe the instruments, including the scale range or direction of benefit, used to measure key outcomes. This makes it nearly impossible to determine the magnitude of change reported in individual studies or to combine seemingly “like” outcomes in pooled analyses. In some cases, to be able to combine the most studies possible, we calculated SMDs rather than MDs according to the original scale of the instruments. These standardized effect sizes are generally harder to interpret and give no indication of the meaningfulness of any differences seen. Where we could, we provided an estimate of what the effect would be based on a standardized effect size to add in interpretation. Development of a set of agreed-upon patient and caregiver measures like those being populated in the National Institutes of Health Patient-Reported Outcome Measurement Information System would advance this area of research considerably.^457^

Seventh, the average treatment effects revealed by this body of evidence are disappointingly small. Consequently, it is difficult to interpret the clinical importance of such small changes. It is also possible that outcome measures themselves may have limited responsiveness (sensitivity to detect change) for patients with less pronounced cognitive impairment. For example, the ADAS-Cog and MMSE may have ceiling effects and therefore be unable to show benefit in persons with MCI or even mild dementia. Other important outcomes, such as global function, physical function, QOL, and institutionalization, were inconsistently reported (except for the CIBIC+, as reported in drug trial literature). Inconsistent reporting could be symptomatic of selective reporting or inconsistent use of these outcome measures. Whatever the reason, this limits our ability to interpret effects on these outcomes as a body of literature. Given these challenges in interpreting the clinical significance of benefit (or even lack of benefit) in treatment trials, we suggest that trials should consistently report a constellation of important self-reported and objective outcomes (e.g., emergency visits and institutionalization). This might be difficult given that trials are costly to conduct and followup is limited. For outcome measures with accepted thresholds of clinical significance, consistent and standardized (using same thresholds) reporting of results that is dichotomized into “responders” and “nonresponders” will also be helpful in interpreting the small average effects on continuous outcome measures.

Eighth, the overwhelming majority of evidence is in persons with AD, and additional research is needed on the effectiveness of various interventions in other types of dementia, including VaD, FTD, and DLB.

Finally, while our report did not evaluate the effectiveness of experimental therapies targeted to alter the disease process, disease-modifying therapies (e.g., those targeting amyloid-related mechanisms or tau-related mechanisms) to slow cognitive decline are an extremely active area of research.^455^ If these therapies are found to truly alter the disease process, there may be reason to change the benefit-to-risk ratio, which could have implications for routine screening for cognitive impairment.

## Conclusions

Several brief screening instruments can adequately detect cognitive impairment, especially in populations with a higher prevalence of underlying dementia. There is no little evidence, however, that screening for cognitive impairment or early diagnosis of cognitive impairment improves patient, caregiver, family, or clinician decision making or other important outcomes nor results in harms. There is a robust evidence base studying pharmacologic and nonpharmacologic interventions aimed at improving patient function and caregiver well-being. In general, there is support that AChEIs and memantine and interventions that support caregivers, including those who help coordinate care for patients and caregivers, can result in small improvements in the short term. Unfortunately, the average effects of these benefits are quite small and likely not of clinical significance. Additionally, most of the evidence pointing to positive effects is applicable to persons with moderate—as opposed to mild—dementia. Therefore, the applicability of the treatment evidence to persons with screen-detected cognitive impairment is unclear. Any benefits are further limited by the commonly experienced side effects of medications and the limited availability of complex caregiver interventions. Cognitive stimulation and training, exercise interventions, and other medications and supplements showed some favorable effects on patients’ cognitive and physical function, but trial evidence lacked consistency and the estimates of benefit were imprecise. There is less evidence related to screening for and treating MCI. The test performance of the few instruments evaluated to detect MCI was lower than the sensitivity and specificity to detect dementia, despite more liberal cutoffs, and there is little evidence for any pharmacologic or nonpharmacologic interventions to preserve or improve patient functioning in persons with MCI.