# Chapter 3 Results

We reviewed 11,645 abstracts and 967 articles for all KQs (Appendix B Figure 1). Overall, we included 287 studies representing more than 280,000 older adults. Ninety-two studies were newly identified in this update and 195 were carried forward from the preview review. Only one trial was identified that addressed the benefits and harms of screening (KQs 1 and 3). We included 59 studies (8 of which were new) that addressed the test accuracy of screening instruments (KQ 2) and another 224 trials (82 new) and 3 observational studies (1 new) that addressed the benefits and harms of treatment (KQs 4 and 5).

The lists of included studies and excluded studies (with reasons for exclusion) are available in Appendix C and Appendix D, respectively. Across all KQs, eight studies included in the previous review were excluded for poor quality upon rereview and an additional 36 new studies were excluded for poor quality due to several methodological issues (Appendix D).

## KQs 1–3: Overall Summary of Results for Screening for Cognitive Impairment

We included one trial—IU CHOICE—that examined the direct effect of screening for cognitive impairment on patient outcomes, including potential harms.^124,^ ^125^ This trial was specifically designed and funded to address the lack of empirical data included in the previous USPSTF review.^124,^ ^125^ Primary care patients age 65 years and older were randomized to screening for AD and related dementia (n=2,008) or no screening (n=1997). Patients in the screening arm were screened using the MIS or the Mini-Cog and were referred for a voluntary diagnostic assessment if they screened positive on either or both tests. At 1, 6, and 12 months, measures of health-related QOL (via the Health Utilities Index [HUI]) were similar between the screening and no screening groups, with no statistically significant difference. Likewise, no differences in symptoms of depression or anxiety were seen at 1, 6, or 12 months or in health care utilization or advance care planning at 12 months. The effect of screening (vs. not) on caregiver or other decision making outcomes were not measured.

We identified 59 studies that address the test accuracy of screening for MCI or dementia. Most of these studies were included in the prior USPSTF review; only eight studies were new. To be included in our review, the study had to assess the performance of an instrument that could be administered in less than 10 minutes or self-administered in less than 20 minutes. To facilitate discussion of results, we categorized these instruments as very brief (administered in ≤5 minutes), brief (within 6 to 10 minutes), or longer, self-administered tests (>10 minutes). We included 25 very brief instruments, 20 brief instruments, and 4 longer, self-administered instruments. All these instruments can be administered and scored with minimal training.

Despite a very large body of evidence examining cognitive screening instruments, most instruments have only been tested in a few well-designed studies in populations generalizable to primary care. The tests most relevant to screening in primary care are very brief instruments, with an administration time of 5 minutes or less. Eight very brief instruments were examined in more than one study (CDT, Lawton IADL, MIS, MSQ, Mini-Cog, VF, AD8, and FAQ), with sensitivity to detect dementia usually at 0.75 or higher (range, 0.43 to 1.0) and specificity at 0.80 or higher (range, 0.54 to 1.0). The MMSE, a brief test taking 7 to 10 minutes to complete, remains the most studied instrument (k=32), but the administration time is longer than ideal for a first step of screening for cognitive impairment in primary care. For the MMSE, the most commonly reported cut-points to detect dementia were 23 or lower and 24 or lower, although higher and lower cut-points were evaluated in various studies. Pooled estimates across 15 studies (n=12,796) resulted in a sensitivity of 0.89 (95% CI, 0.85 to 0.92) and a specificity of 0.89 (95% CI, 0.85 to 0.93) at a cut-point of 23 or lower or 24 or lower for the MMSE. The range of sensitivity contributing to the pooled analysis was 0.77 to 1.0, and the range of specificity was 0.71 to 0.99. Even at cutoffs not pooled, the sensitivity remained at 0.75 or higher for all but one study and the specificity was 0.70 or higher for all but one study. The test accuracy of the MMSE to detect MCI was based on a much smaller body of literature (k=13) with a variety of cutoffs, and resulted in less consistent estimates for test accuracy, with a range in sensitivity from 0.20 to 0.93 and range in specificity from 0.48 to 0.93. The test accuracy of five additional brief tests (7MS, AMT, MoCA, SLUMS, and TICS) was reported in more than one study, with sensitivity to detect dementia ranging from 0.74 to 1.0 and specificity ranging from 0.65 to 0.96. For self-administered, longer tests, only one instrument (the IQCODE) was assessed in more than one study, with sensitivity to detect dementia ranging from 0.80 to 0.88 and specificity ranging from 0.51 to 0.91. Across all instruments, test performance was generally higher in the detection of dementia vs. MCI, although confidence intervals overlapped. Brief instruments appear to have slightly better test performance in detecting MCI and dementia than very brief instruments, although this difference is likely not statistically significantly different.

No studies directly addressed the adverse psychological effects of screening or adverse effects from false-positive or false-negative testing, although again, we expect the recently completed CHOICE study to contribute answers to this question.

### KQ 1 Does Screening for Cognitive Impairment in Community-Dwelling Older Adults in Primary Care–Relevant Settings Improve Decision Making, Patient-Family/Caregiver, or Societal Outcomes?

We identified one recently completed fair-quality U.S.-based large trial—Indiana University Cognitive Health Outcomes Investigation of the Comparative Effectiveness of Dementia Screening (IU CHOICE)—that contributes evidence to answer this question.^124,^ ^125^ The trial was funded by the NIA to provide empiric evidence to address a gap in the literature regarding the potential benefits and harms of screening for cognitive impairment, as identified in the previous USPSTF review and recommendation. Within this trial, 4,005 individuals age 65 years and older without a diagnosis of dementia, cognitive impairment, or serious mental illness receiving care at primary care practices within two cities in Indiana were randomized to either screening for dementia using very brief screening tools (MIS or Mini-Cog) or no screening for dementia. Adults who screened positive for dementia were referred for further diagnostic testing. If subsequently found through diagnostic assessment to have dementia, they were referred to the local Aging Brain Care program, which delivers an evidence-based collaborative care model for dementia and depression and is modeled after one of the care management trials included in our review. Participants in the no screening arm continued to receive their usual primary care, including a referral to a local memory care practice if their provider suspected the presence of cognitive impairment at any point throughout the study. Primary outcomes, measured at 1, 6, and 12 months, included patients’ health-related QOL, mood, and anxiety. Measures of health care utilization (i.e., emergency department visits and hospital admissions) and advance care planning information (e.g., having power of attorney for health care and/or financial affairs, having a living will, and having life and additional insurance policies) were also captured.

Measures of health-related QOL using HUI scores (ranging from 0.36 to 1.00, where 0 = dead and 1.00 = no impairment) were similar between groups and across time. Among those in the screening arm, HUI scores were 0.67 (95% CI, 0.65 to 0.68), 0.71 (95% CI, 0.69 to 0.72), 0.69 (95% CI, 0.67 to 0.71), and 0.68 (95% CI, 0.66 to 0.69) at baseline, 1 month, 6 months, and 12 months, respectively. For those in the no screening arm, HUI scores were nearly identical to the screening arm at all four time points: 0.67 (95% CI, 0.66 to 0.69), 0.69 (95% CI, 0.68 to 0.71), 0.70 (95% CI, 0.68 to 0.72), and 0.68 (95% CI, 0.66 to 0.70) at baseline, 1 month, 6 months, and 12 months, respectively. Furthermore, mixed effects models showed no statistical differences between groups at any time point. Scores for depressive and anxiety symptoms were also similar between the groups at all time points (further discussed for KQ 3). Finally, no difference in health care utilization, advance care planning, and dementia recognition by clinicians were detected at 12 months. No measures to examine the effect of screening vs. no screening on caregiver outcomes were included.

There are some limitations to this trial that should be noted, given the lack of other studies contributing direct evidence on screening. IU CHOICE was missing 42 percent of observations at 12 months for the QOL measure due to attrition as well as considerable data quality issues. There was no evidence of substantial differences between groups for observations retained and lost, and multiple robust analyses accounting for the missing data found similar results as the complete case analysis. Thus, it is unlikely that more complete followup data would have led to a different result despite having lower power than anticipated. Additionally, 38 percent of those assessed for eligibility into the trial refused to participate, perhaps compromising the generalizability of the sample. Furthermore, 66 percent of the participants who screened positive in the screening arm refused diagnostic assessment and further followup care. No additional data were provided comparing screen-positives who agreed to or who declined further evaluation.

### KQ 2 What Is the Accuracy of Screening Instruments to Detect Cognitive Impairment in Community-Dwelling Older Adults?

We identified 59 studies (n=38,531) that addressed the accuracy of cognitive impairment screening instruments (Appendix C);^126–182^ eight of these studies were newly identified and the other 51 were included in the previous review (Table 2).

Table 2 Study and Population Characteristics of Included Diagnostic Accuracy Studies (KQ 2)

Author, year Quality | Country; recruitment setting | N Screened | Dem, % | MCI, % | Age, mean (range) | Female, % | Race/Ethnicity, % | SES | Diagnostic Criteria | Reference Standard
Ayalon, 2011^126^; Fair | US; Community-based | 647 | 32 | 29 | 79 (≥70) | 51 | NR | Mean edu, years: 11.8 | Dementia: NA; MCI: Defined as functional impairment per respondent or informant report that did not meet criteria for dementia on neuropsychological measures that was below expectations and ≥1.5 SD below published norms | Neuropsychological battery, self-report depression measure, standardized neurologic examination, physiological testing, and genetic testing
Ball, 2001^127^; Fair | US; Community-based | 170 (53 in analysis) | 9 | NR | 76 (≥65) | 100 | NR | Mean edu, years: 13.6 | Dementia: NINCDS-ADRDA; MCI: NA | Short Blessed Test, clinical examination, and neuropsychological test battery
Borson, 2006^128^; Fair | US; Community-based | 371 | 42 | 21 | NR (NR) | NR | White: 7; Black: 17; Asian: 48; Hispanic: 7; Other: 6 | NR | Dementia: CDR≥1; MCI: CDR=0.5 | Neuropsychological test battery, informant interview, medical history and examination
Brodaty, 2002^*^,^129^; Fair | AUS; Primary care | 283 | 29 | NR | 80 (56–94) | 59 | NR | % ≤8 years edu: 44.2; % >8 years edu: 55.8 | Dementia: DSM-IV; MCI: NA | Neuropsychological testing
Buschke, 1999^130^; Fair | US; Community-based, Primary care | 483 | 10 | NR | 80 (≥65) | 64 | White: 80.7; Black: 16.2; Other: 2.7 | Mean edu, years: 12.1 | Dementia: DSM-III-R; MCI: NA | Neuropsychological test battery
Callahan, 2002^131^; Fair | US; Community-based | 344 | 4 | 22 | 74 (65–99) | 59 | Black: 100 | Mean (range) edu, years: 10.4 (0–16) | Dementia: NR; MCI: NR | Physical examination and neurologic examination
Chan, 2016^132^,^†^; Fair | SGP; Primary care | 309 | 24 | NR | 72 (≥60) | 54 | Asian: 99 | Mean edu, years: 7.93 | Dementia: DSM-IV, CDR; MCI: NA | Clinical assessment and neuropsychological test battery
Cook, 2009^133^,^‡^; Fair | US; Community-based, Other medical | 71 | 0 | 24 | 75 (≥65) | 56 | White: 93 | Mean edu, years: 16.1 | Dementia: NA; MCI: NR | Neuropsychological test battery
Cruz-Orduna, 2012^134^,^‡^; Fair | ESP; Primary care | 160 | 9 | 47 | 72 (>49) | 70 | NR | Edu, %: None/Incomplete: 44.4 | Dementia: Performance <10th percentile in memory and at least one other domain, cognitive deterioration considered the cause of impairment in function, and confusion state not present.; MCI: Performance <10th percentile in at least 1 test | Neuropsychological test battery
Cullen, 2005^135^; Fair | IRL; Primary care | 1115 | 4 | 5 | 75 (≥65) | 68 | NR | Mean edu, years: 9.9 | Dementia: NR; MCI: NR | GMS-AGECAT (diagnostic interview)
Cummings-Vaughn, 2014^136^,^†^; Good | US; Other medical | 136 | 21 | 42 | 79 (66–95) | 2 | NR | Completed HS: 41% | Dementia: CDR; MCI: CDR | CDR
Del Ser, 2006^137^; Fair | ESP; Community-based | 416 | 12 | NR | 79 (>65) | 52 | NR | % No Formal edu: 25 | Dementia: NR; MCI: NA | Neuropsychological test battery
Donnelly, 2008^138^; Fair | US; Primary care | 100 | NR | 20 | 78 (65–89) | 1 | White: 95; Black: 4; AI/AN: 1 | Mean edu, years: 12.9 | Dementia: NA; MCI: ≥1 SD below the normative mean | Dementia Rating Scale
Ehreke, 2009^140^; Fair | DEU; Primary care | 3198 | 0 | 14 | 80 (≥75) | 65 | NR | Level of edu:; % Low: 61.8; % Middle: 27.5; % High: 10.7 | Dementia: NA; MCI: Winblad | SIDAM
Ehreke, 2011^139^; Fair | DEU; Community-based | 428 | 0 | 14 | 83 (≥75) | 73 | NR | % Low edu: 63.5; % Assisted Living/Residential Care: 11.3 in institutional care | Dementia: NA; MCI: International Working Group on MCI (Winblad, 2004) - (a) absence of dementia according to DSM-IV or ICD-10; (b) evidence of cognitive decline: subjective cognitive impairment (measured by self-rating or informant report) | SIDAM
Erkinjuntti, 1987^141^; Fair | FIN; Community-based | 119 | 2 | NR | 73 (65–84) | 65 | NR | % Grade school or less: 85; % Assisted Living/Residential Care: 4 | Dementia: NR; MCI: NA | Neuropsychological test battery and medical history
Fillenbaum, 1990^142^; Fair | US; Community-based | 164 | 16 | NR | NR (≥65) | 58 | White: 49.4; Black: 50.6 | NR | Dementia: DSM-III and NINCDS/ADRDA; MCI: NA | Semi-structured interview, including a modified physical and neurological examination
Fong, 2011^143^; Fair | US; Community-based | 709 | 12 | NR | 79 (≥70) | 60 | White: 91 | NR | Dementia: DSM-III; MCI: NA | Functional status, health information, neuropsychological examination
Fuchs, 2012^144^; Fair | DEU; Primary care | 423 | 5 | NR | 82 (75–89) | 68 | NR | % Low level of edu: 62.2 | Dementia: DSM-IV and NINCDS/ADRDA; MCI: NA | Neuropsychological test battery, medical and family history, drug inventory, SES, lifestyle, and GDS
Gagnon, 1990^145^; Fair | FRA; Community-based | 2730 | 4 | NR | 75 (≥65) | 59 | NR | % No edu/Grade School: 66 | Dementia: DSM-III; MCI: NA | Psychometric tests
Galvin, 2005^146^; Fair | US; Community-based, Primary care, Other medical | 236 | 24 | 29 | 78 (55–102) | 53 | NR | NR | Dementia: DSM-IV and NINCDS/ADRDA; MCI: CDR=0.5 | Semistructured interview
Grut, 1993^147^; Fair | SWE; Community-based | 1810 | 14 | NR | NR (≥75) | 76 | NR | % Elementary edu: 52.9 | Dementia: DSM-III-R; MCI: NA | Clinical examination, family interview, and laboratory tests
Heun, 1998^148^; Fair | DEU; Community-based | 291 | 13 | NR | 77 (60–99) | 60 | NR | Mean edu, years: 9.5 | Dementia: DSM-III-R; MCI: NA | CIDI and SIDAM
Holsinger, 2012^149^; Good | US; Primary care | 639 | 3 | 39 | 75 (≥65) | 7 | White: 73; Black: 26; Hispanic: 1; Other: <1 | Mean edu, years: 13.0 | Dementia: DSM-IV, NINCDS-ADRDA, NINDS-AIREN; MCI: Functional impairment due to cognitive impairment that the participant or informant reported that did not meet criteria for dementia (that was fairly mild), and or performance on neuropsychological measure | Clinical interviews, neuropsychological testing, neurological examination, and review of electronic medical records
Hooijer, 1992^150^; Fair | NLD; Primary care | 358 | 4 | NR | NR | NR | NR | NR | Dementia: GMS, AGECAT; MCI: NA | GMS-AGECAT
Hsu, 2015^151^,^†^; Good | TWN; Community-based | 276 | 6 | NR | 68 (≥60) | 51 | NR | Mean edu, years: 11.4 | Dementia: DSM-IV; MCI: NA | Neurological examination, function, laboratory tests, imaging
Jeong, 2004^152^; Good | KOR; Community-based | 235 | 20 | 23 | 74 (NR) | 66 | NR | Median edu, years: 1 | aDementia: DSM-IV, NINCDS-ADRDA; MCI: DSM-IV (people with cognitive decline who did not meet DSM-IV criteria for dementia) | Clinical exam and neuropsychiatric inventory
Jorm, 1996^153^; Fair | AUS; POWs/ex-servicemen | 144 | NR | NR | 73 (66–83) | 0 | NR | NR | Dementia: ICD-9; MCI: NR | Neuropsychological test battery
Juva, 1997^154^; Fair | FIN; Community-based | 656 | 14 | NR | 80 (75–85) | 73 | NR | Low edu: 74.4% | Dementia: DSM III-R; MCI: NA | CDR followed by a clinical assessment when indicated
Kahle-Wrobleski, 2007^155^; Fair | US; Community-based | 435 | 36 | 28 | 95 (90–104) | 74 | NR | >12 years of formal edu: 73% | Dementia: DSM-IV; MCI: NR | Neurological examination
Kaufer, 2008^156^; Fair | US; Other medical | 146 | 38 | 52 | 83 (≥65) | 79 | White: 90 | 12 years of edu or less: 55% | Dementia: DSM-IV; MCI: DSM-IV | Neuropsychological testing, physical examination, and neurologic examination
Kay, 1985^157^; Fair | AUS; Electoral roll | 274 | 14 | NR | NR (≥70) | 64 | NR | NR | Dementia: DSM-III; MCI: NA | GMS-6
Kirby, 2001^158^; Fair | IRL; Primary care | 648 | 6 | NR | 75 (≥65) | NR | NR | Mean edu, years: 10.8 | Dementia: GMS; MCI: NA | GMS-AGECAT (diagnostic interview)
Kuslansky, 2002^159^; Fair | US; Community-based, Other medical | 240 | 12 | NR | 79 (>70) | 64 | White: 72; Black: 28 | Mean edu, years: 12.5 | Dementia: DSM-III-R; DSM-IV; NINCDS-ADRDA; MCI: NA | Medical and social history, neurological examination, neuropsychological testing
Lam, 2008^160^; Fair | HKG; Community-based | 459 | 10 | 35 | 71 (NR) | 54 | Asian: 100 | Mean edu, years: 4.8 | Dementia: NINCDS-ADRDA; MCI: NR | CDR
Lee, 2008^161^; Fair | KOR; Community-based, Hospital | 196 | 22 | 19 | 70 (≥65) | 65 | Asian: 100 | <6 years edu: 53.1% | Dementia: NR; MCI: NR | Neuropsychological test battery
Lee, 2008^162^; Fair | KOR; Other medical | 465 | 0 | 48 | 71 (≥60) | 63 | NR | Mean edu, years: 6.1 | Dementia: NR; MCI: NR | Medical history, physical and neurologic examinations, neuropsychological testing, and dementia-related blood tests
Lipton, 2003^163^; Fair | US; Community-based, Primary care | 300 | 9 | 10 | 79 (≥65) | 66 | White: 83; Black: 15; Hispanic: 2 | Mean edu, years: 12.8 | Dementia: DSM-III-R; MCI: NR | Clinical assessment and a case conference
Manly, 2011^164^; Fair | US; Insurance list | 377 | 14 | 18 | 81 (≥65) | 68 | White: 30; Black: 35; Hispanic: 34; Other: 1 | Mean edu, years: 10.4 | Dementia: DSM III-R; MCI: NR | Medical history and neurologic and physical examination
Mao, 2018^460^; Good | TWN; Community-based | 10340 | 9 | NR | 76 (NR) | 52 | NR | Elementary school or less: 77% | Dementia: NIA-AA; MCI: NA | Medical history, lifestyle factors, MMSE, AD8, CDR, cognitive and functional status
Markwick, 2012^165^; Good | GBR; Community-based | 107 | 8 | 19 | 76 (NR) | 54 | NR | ≤12 years edu: 23.4% | Dementia: NINCDS-ADRDA, NINCDS-AIREN, Hachinski, DSM-IV; MCI: Petersen criteria | Neuropsychological test battery, informant interview, medical history and examination, imaging, blood tests
McDowell, 1997^166^; Fair | CAN; Community-based | 1600 | 23 | 30 | 80 (65–99) | 59 | NR | Mean edu, years: 8.6 | Dementia: DSM-III-R; MCI: NR | Medical and family history, 3MS, physician’s mental status assessment, and physical and neurological examination
Morales, 1997^167^; Fair | ESP; Community-based | 160 | 13 | NR | 73 (61–96) | 68 | NR | % Low economic level: 74.4 | Dementia: DSM-III-R; MCI: NA | Neurological and neuropsychological assessment
Ozer, 2016^168^,^†^; Fair | GBR; Primary care | 152 | 0 | 26 | 78 (≥75) | NR | NR | Mean edu, years: 11.5 | Dementia: NA; MCI: Petersen criteria | Neuropsychological test battery, ADL, adult reading test
Rait, 2000^169^; Fair | GBR; Primary care | 101 | 11 | NR | 69 (≥60) | 52 | Asian: 100 | Mean edu, years: 9 | Dementia: GMS; MCI: NA | GMS-AGECAT
Rait, 2000^170^; Fair | GBR; Primary care | 96 | 11 | NR | 69 (60–85) | 50 | Black: 100 | Mean edu, years: 9 | Dementia: GMS; MCI: NA | GMS-AGECAT
Ranson, 2018^461^; Good | US; Community-based | 824 | 35 | NR | 82 (70–110) | 58 | White: 72.2; Black: 18.0; Hispanic: 9.8 | Mean edu, years: 10.1 | Dementia: DSM-III-R and DSM-IV; MCI: NA | Neuropsychological test battery, clinical examination, depression screen, and informant interview
Resichies, 1997^171^; Fair | DEU; Community-based | 516 | 20 | NR | NR (≥70) | NR | NR | NR | Dementia: NR; MCI: NA | GMS-A interview and History and Aetiology Schedule interview
Rideaux, 2012^172^; Fair | US; Community-based | 701 | 26 | 32 | 80 (≥70) | 55 | White: 72; Black: 18; Hispanic: 10 | Mean edu, years: 10.3 | Dementia: DSM-IV; MCI: NR | Medical examination and neuropsychological test battery
Saxton, 2009^173^; Good | US; Community-based, Primary care | 524 | 0 | 44 | 73 (≥60) | 65 | White: 94 | Mean edu, years: 13.5 | Dementia: University of Pittsburgh ADRC; MCI: University of Pittsburgh ADRC | Neuropsychological test battery, medical history, depression scale, IADL, subjective memory complaints
Solomon, 2000^174^; Fair | US; Primary care | 137 | 10 | NR | 77 (61–88) | 67 | NR | Mean edu, years: 11.8 | Dementia: NINCDS-ADRDA; MCI: NA | Medical history, history of cognitive complaints, physical examination, and neuropsychological testing
Stein, 2015^175^,^†^; Good | DEU; Primary care | 2657 | 3 | NR | 81 (≥75) | 65 | NR | % Level of edu:; Low=61; Middle=27; High=12 | Dementia: DSM-IV; MCI: NA | SIDAM
Swearer, 2002^176^; Fair | US; Community-based, Primary care | 46 | 17 | NR | 81 (NR) | 65 | NR | Mean edu, years: 14.4 | Dementia: DSM-IV; MCI: NA | Neuropsychological testing
Tariq, 2006^177^; Fair | US; Primary care | 702 | 12 | 26 | 75 (NR) | NR | NR | % HS edu or more: 69.4 | Dementia: DSM-IV; MCI: DSM-IV | Physical examination, laboratory testing, and mental status examination
Tokuhara, 2006^178^; Fair | US; Primary care | 230 | 7 | 10 | 74 (65–96) | 66 | Asian: 100 | Mean edu, years: 12.2 | Dementia: Benson and Cummings; MCI: CASI<74 and CDR>0 | Interview data, cognitive testing, and assessment of function
Vannier-Nitenberg, 2016^179^,^†^; Fair | FRA; Primary care | 585 | 1 | 30 | 71 (≥65) | 47 | NR | No schooling/primary edu: 32%; Social deprivation (EPICES score):; ≥30: 22%; ≤30: 77% | Dementia: NINCDS-ARDA; MCI: NINCDS-ARDA (amnestic MCI) | Neuropsychological test battery
Vercambre, 2010^180^; Fair | FRA; Community-based | 120 | 8 | 15 | 79 (NR) | 100 | NR | NR | Dementia: NR; MCI: NR | Neuropsychological test battery
Waite, 1998^181^; Fair | AUS; Community-based | 630 | 28 | NR | 84 (78–99) | 55 | NR | Mean edu, years: 10 | Dementia: DSM-IV criteria A and B; MCI: NA | Medical history, neuropsychological test battery, and detailed medical and neurological examination
Wolf-Klein, 1989^182^; Good | US; Other medical | 312 | 47 | NR | 77 (58–99) | 70 | NR | NR | Dementia: NINCDS-ADRDA; MCI: NA | History taking and physical examination

* Required memory problems if aged 50–74 years

† New study

‡ Recruited patients with memory concerns

Abbreviations: 3MS = Modified Mini-Mental State Examination; ADL = activities of daily living; ADRC = Aging and Disability Resource Center; AI/AN = American Indian/Alaskan Native; AUS = Australia; CAN = Canada; CASI = Cognitive Abilities Screening Instrument; CDR = Clinical Dementia Rating; Dem = dementia; DEU = Germany; DSM = Diagnostic and Statistical Manual of Mental Disorders; Edu = education; EPICES = Evaluation of Deprivation and Inequalities in Health Examination Centers; ESP = Spain; FIN = Finland; FRA = France; GBR = Great Britain/United Kingdom; GDS = Global Deterioration Scale; GMS-AGECAT = Geriatric Mental State – Automated Geriatric Examination for Computer Assisted Taxonomy; HKG = Hong Kong; IADL = instrumental activities of daily living; ICD-9 = International Statistical Classification of Diseases and Related Health Problems-9th revision; ICD-10 = International Statistical Classification of Diseases and Related Health Problems-10th revision; IRL = Ireland; KOR = Korea; MCI = mild cognitive impairment; N = number of participants; NA = not applicable; NINCDS/ADRDA = National Institute of Neurological and Communicative Diseases and Stroke/Alzheimer’s Disease and Related Disorders Association; NINDS-AIREN = National Institute of Neurological Disorders and Stroke and Association Internationale pour la Recherché et l’Enseignement en Neurosciences; NLD = Netherlands; NR = not reported; SD = standard deviation; SES = socioeconomic status; SGP = Singapore; SIDAM = Structured Interview for the Diagnosis of Dementias of the Alzheimer type and Multi-infarct dementia and dementias of other etiology; SWE = Sweden; TWN = Taiwan

#### Study and Population Characteristics

Approximately half of the studies (k=25) were conducted in the United States. The remainder were conducted in Germany (k=6), Australia (k=4), the United Kingdom (k=4), Spain (k=3), France (k=3), South Korea (k=3), Finland (k=2), Ireland (k=2), Taiwan (k=2), and Canada, the Netherlands, Hong Kong, Singapore, and Sweden (1 each). The number of participants screened ranged from 46 to 8,805. Thirty-four studies recruited fully or partially from the community and 23 recruited partially or fully from primary care. The remaining two studies recruited patients from either an insurance list^164^ or ex-servicemen who were prisoners of war in Japan during World War II.^153^ Forty-seven of the 59 studies reported the test accuracy to detect dementia and 35 reported the test accuracy to detect cognitive impairment (inclusive of MCI as well as MCI and dementia combined). Among the 59 studies, the prevalence of cognitive impairment varied widely; dementia ranged from 1 to 47 percent (k=51), MCI (k=29) ranged from 10 to 52 percent, and the prevalence of cognitive impairment (inclusive of MCI and dementia, k=22) ranged from 17 to 90 percent. Mean age ranged from 68 to 95 years. Percent female ranged from 0 to 100. Race/ethnicity was only reported in 21 studies; six were predominantly or entirely Asian, 11 were predominantly or entirely white, three were predominantly or entirely black, and one was fairly evenly distributed between white, black, and Hispanic populations. Education was reported in 22 studies with a wide range of education levels; mean years of education ranged from 5 to 16 and those with more than a high school education ranged from 4 to 73 percent.

#### Instrument and Reference Standard Characteristics

We categorized the screening tests by administration time: very brief (≤5 minutes), brief (6 to 10 minutes), and longer (>10 minutes, self-administered) (Table 3). Of the 59 included studies, 49 screening tests were evaluated. Very few were evaluated in more than one study. Full names that correspond to instrument abbreviations are provided in Table 3. Most of the tests (25) fall into the very brief (≤5 minutes) category. The very brief tests are: 3-Word, 6-Item Screener, AD8, CDT, CoDEx, Dubois 5-Word, FAQ, GPCOG, HVLT, single-item informant memory report, Katz ADL, Lawton IADL, M@T subtests, MF-2, Mini-Cog, MIS/MIS-T, MSQ/SPMSQ, OMC, self-reported subjective memory impairment, STMS, Sweet 16, TMT, TYM subtests, VAT, and VF. The brief tests (20 tests) are: 7MS, AMT, FCR, FOME-abbreviated, Immediate recall, Kendrick, Labyrinth, M@T, MMblind, MMSE, MoCA, OT, SBT, SLUMS, SMMSE, Storandt, TICS/TICS-M, TYM, Word List Learning, and Word List Recognition. The longer tests (4 tests) are: CAMCI, CAST, CIDS/SCIDS, and IQCODE/Short IQCODE. The tests were typically administered by clinical staff; in a few cases, they were self-administered. Most of the screening instruments directly assessed the cognitive function of the patient (with a few also evaluating physical function), but five queried only the informant (IQCODE, CIDS, FAQ, AD8, and single-item informant memory report), and one collected information from the patient and informant (GPCOG). The cognitive domains assessed varied, but most of the tests addressed memory.

Table 3 Screening Test Characteristics, by Category of Test (KQ 2)

Category | Test name (Target)^*^ | Description | Domains
Very brief (5 minutes or less) | 3-Word | 3-item recall | Memory
Very brief (5 minutes or less) | 6-Item Screener | 3-item recall plus 3 orientation questions | Memory
Very brief (5 minutes or less) | AD8 (informant) | Asks informant about judgment, less interest in hobbies, repeats things, trouble using tools, forgets month or year, finances, trouble remembering appointments or daily things | Memory, Executive Functioning, Apraxia, Agnosia
Very brief (5 minutes or less) | Clock Drawing Test, CDT | Clock draw; variety of scoring methods | Executive Functioning, Apraxia
Very brief (5 minutes or less) | Cognitive Disorders Examination test, CoDEx | 3-word test, simplified clock test and 5 spatial orientation questions from the MMSE | Memory, Executive Functioning, Apraxia
Very brief (5 minutes or less) | Dubois five-word test | Recall of 5 word list | Memory
Very brief (5 minutes or less) | Functional Activities Questionnaire, FAQ (informant) | Activities and independent activities of daily living, ability to remember appointments, ability to keep track of current events, understanding books | Memory, Executive Functioning, Apraxia
Very brief (5 minutes or less) | General Practitioner Assessment of Cognition, GPCOG (patient and informant) | Recall, orientation, recent news recall. Patient questionnaire is paired with an informant questionnaire that asks about memory, finances, wordfinding, ADLs | Memory, Executive Functioning, Aphasia
Very brief (5 minutes or less) | Hopkins Verbal Learning Test, HVLT | Immediate recall of objects | Memory
Very brief (5 minutes or less) | Katz Activities of Daily Living, Katz ADL | Activities of daily living | Executive Functioning, Apraxia, Agnosia
Very brief (5 minutes or less) | Lawton Instrumental Activities of Daily Living, Lawton IADL | Independent activities of daily living | Executive Functioning, Apraxia, Agnosia
Very brief (5 minutes or less) | 2-item functional memory screen, MF-2 (patient and informant) | Subjective memory complaints and trouble with executive function Note: This test can be completed by the informant or the patient | Memory, Executive Functioning
Very brief (5 minutes or less) | Mini-Cog | 3-item recall plus clock draw | Memory, Executive Functioning, Apraxia
Very brief (5 minutes or less) | Memory Impairment Screen, MIS | 4-item recall, either spontaneous or cued recall | Memory
Very brief (5 minutes or less) | Memory Impairment Screen by Telephone, MIS-T | 4-item recall, either spontaneous or cued recall administered by telephone | Memory
Very brief (5 minutes or less) | Mental State Questionnaire, MSQ | Memory, orientation, naming, attention | Memory
Very brief (5 minutes or less) | Orientation Memory Concentration, OMC | Memory, orientation, concentration | Memory
Very brief (5 minutes or less) | Single-item (informant) | Asks about patient memory | Memory
Very brief (5 minutes or less) | Short Portable Mental Status Questionnaire, SPMSQ | Orientation, memory, attention | Memory
Very brief (5 minutes or less) | Short Test of Mental Status, STMS | Orientation, memory, attention | Memory
Very brief (5 minutes or less) | Self-report memory impairment | Yes/No question: Do you feel like your memory is getting worse? | Memory
Very brief (5 minutes or less) | Sweet 16 | Orientation (identification of person, place, time, and situation), registration, digit spans (tests of verbal memory), and recall | Memory
Very brief (5 minutes or less) | Trail Making Tests, TMT | Different versions have patients go to different numbers/letters | Executive Functioning
Very brief (5 minutes or less) | Visual Association Test, VAT | Visual association and recall | Memory, Apraxia
Very brief (5 minutes or less) | Verbal Fluency, VF | Asks participant’s name, and asks them to list as many different animals, first names, or similar objects as possible in 1 min | Memory, Aphasia, Executive Function
Brief (6–10 minutes) | 7-Minute Screen, 7MS | Recall objects from categories, clock, vegetables | Memory, Executive Functioning, Aphasia, Apraxia, Agnosia
Brief (6–10 minutes) | Abbreviated Mental Test, AMT | Orientation, memory, name objects, attention tests | Memory, Agnosia
Brief (6–10 minutes) | Free and Cued Recall, FCR | Controlled learning of a card with 4 pictures; each with a semantic cue; the patient counts backwards by threes for 20 seconds (as interference for working memory) and then has 3 recall trials without then with the semantic cues | Memory
Brief (6–10 minutes) | Abbreviated Fuld Object Memory Evaluation, FOME-abbreviated | Participants attempt to identify 10 common items concealed in a bag and are asked to recall the 10 items 3 different times. Each time after identifying the items, participants receive a semantic fluency distractor task for 60, 30, and 30 seconds, respectively | Memory
Brief (6–10 minutes) | Immediate Recall | Evaluator reads a story, then asks patient to remember as many things from story as possible | Memory
Brief (6–10 minutes) | Kendrick Cognitive Tests | Recall of outline pictures of common items and speed of copying 10 rows of 10 digits each. Scoring guidelines permit 2 determinations: distinction between dementia and normal and distinction between dementia, depression, and normal | Memory
Brief (6–10 minutes) | Labyrinth Test - mistakes | Patient is asked to draw a line that successfully navigates through a maze | Apraxia
Brief (6–10 minutes) | Labyrinth Test - seconds | Patient is asked to draw a line that successfully navigates through a maze | Apraxia
Brief (6–10 minutes) | Memory Alteration Test, M@T | Assesses five cognitive skills: encoding, orientation, semantic memory, free recall, and cued recall | Memory
Brief (6–10 minutes) | MMblind | Excludes items from MMSE requiring vision: naming, reading, comprehension, copying, writing, and instructions to handle a sheet of paper, resulting in a maximum score of 22 | Memory, Aphasia
Brief (6–10 minutes) | Mini-Mental State Examination, MMSE | Orientation, recall, naming, draw figure, repetition, attention, reading, writing | Memory, Aphasia, Apraxia, Agnosia
Brief (6–10 minutes) | Montreal Cognitive Assessment. MoCA | Trails B, copy figure, clock, naming, verbal fluency, 5-word recall, similarities, orientation, attention | Memory, Executive Functioning, Aphasia, Apraxia, Agnosia
Brief (6–10 minutes) | Benton’s Orientation Test, OT | Identify month, date, year, day of the week, and time of day | Memory
Brief (6–10 minutes) | Short Blessed Test, SBT | Temporal orientation, attention, and short-term memory test | Memory
Brief (6–10 minutes) | Saint Louis University Mental Status Examination, SLUMS | Orientation, 5-item recall, math, animals, attention, clock, figures, story | Memory, Executive Functioning, Aphasia, Apraxia, Agnosia
Brief (6–10 minutes) | Storandt Battery | Word fluency and trailmaking | Executive Functioning, Aphasia
Brief (6–10 minutes) | Telephone Instrument for Cognitive Status, TICS | Orientation, repetition, naming, and calculations are some of the items covered | Memory, Executive Functioning
Brief (6–10 minutes) | Modified Telephone Instrument for Cognitive Status, TICS-M | Orientation, repetition, naming, and calculations are some of the items covered | Memory, Executive Functioning
Brief (6–10 minutes) | Test Your Memory, TYM | Orientation, ability to copy a sentence, semantic knowledge, calculation, verbal fluency, similarities, naming, visuospatial abilities, recall of copied sentence | Memory, Executive Functioning, Aphasia, Apraxia
Brief (6–10 minutes) | Word List Learning - immediate recall | Immediate recall and recognition tasks. Recognition task is composed of 8 targets and 8 distractors | Memory
Brief (6–10 minutes) | Word List Learning - immediate recognition hit | Immediate recall and recognition tasks. Recognition task is composed of 8 targets and 8 distractors | Memory
Brief (6–10 minutes) | Word List Recognition | Tests immediate and delayed memory, and learning ability of non-associated verbal material. Patients are asked to recall as many of ten words as possible, immediately after having read them. After 5–10 minutes, patients are again asked to recall as many of the ten words presented before as possible, without seeing them. Finally, patients are asked to recognize the ten words among a list of 20 words. | Memory
Longer, Self-administered | Computer Assessment of Mild Cognitive Impairment, CAMCI | Orientation, figure identification, picture recall, word recall, attention, “virtual environment” (follow directions while driving) | Memory, Executive Functioning, Apraxia
Longer, Self-administered | Cognitive Assessment Screening Test, CAST | Memory, orientation, naming, copy a sentence, copy a figure, addition, fill out a check, clock draw, plus multiple questions about memory complaints, changes in behavior | Memory, Executive Functioning, Aphasia, Apraxia, Agnosia
Longer, Self-administered | Concord Informant Dementia Scale, CIDS (informant) | Asks informant about changes in patient memory, orientation, judgment and problem solving, community affairs, involvement in home and hobbies, personal care, and language | Memory, Executive Functioning, Aphasia, Agnosia
Longer, Self-administered | Informant Questionnaire on Cognitive Decline in the Elderly, IQCODE (informant) | Asks informant about changes in cognitive function, physical function, patient personality and behavior | Memory, Executive Functioning, Apraxia, Agnosia
Longer, Self-administered | Short Informant Questionnaire on Cognitive Decline in the Elderly, IQCODE-Short (informant) | Same as full IQCODE, except has 16 rather than 26 questions | Memory, Executive Functioning, Apraxia, Agnosia
Longer, Self-administered | Short Concord Informant Dementia Scale, SCIDS (informant) | Questions for informant about perceived changes in memory and ability to find their way around | Memory, Executive Functioning, Agnosia

* If not patient

The reference standard used to diagnose dementia or MCI usually consisted of a neuropsychological battery of tests and often was supplemented by a clinical examination, laboratory testing, imaging, assessment of depression and physical function, and/or an informant interview. The reference standard was administered by research staff, neurologists, psychiatrists, psychologists, psychometricians, physicians, and/or nurses, and the diagnosis was usually made by consensus. DSM-IV, DSM-III-R, or DSM-III criteria were most often used to diagnose dementia, sometimes in conjunction with NINCDS-ADRDA^183^ (for AD) and NINDS-AIREN^184^ (for VaD) criteria. No studies used DSM-5 criteria. MCI was more variably diagnosed, with criteria including that from the International Working Group on MCI,^12^ performance of 1 or more or 1.5 or more standard deviations (SDs) below normal, performance in less than the 10th percentile in at least one cognitive test, a CDR rating of 0.5, reported impairment that did not meet the criteria for dementia, criteria developed by Petersen,^185^ criteria developed by a specific AD Research Center, or NINCDS-ADRDA (for amnestic MCI).

We rated 10 studies as good quality and 49 studies as fair quality. Studies that were rated fair quality had a higher risk of bias due to patient selection (volunteers or limited information on how patients were recruited), partial verification (only a subset of participants who screened negative received the full reference standard), incorporation (the screening test was one of the tests included in the reference standard or not independently administered), or disease progression (a lag between the administration of the reference standard and the screening test).

Below we report the test accuracy results grouped by category of screening instrument based on test administration time. Results for all instruments, including those only evaluated in one study, are presented in Tables 4–6. Narrative results are only provided for instruments that were evaluated in more than one study.

Table 4 Test Performance of Very Brief Screening Instruments, by Instrument and Target Condition (KQ 2)

Test name | Target condition | Author, year | Screened group | % (n/N) with condition | Total n | Cutoff | Sens (95% CI) | Spec (95% CI) | PPV (95% CI) | NPV (95% CI) | AUC (95% CI)
3-Word | Dementia | Kuslansky, 2002^159^ | All | 12 (28/240) | 240 | 0 | 0.65 (NR) | 0.85 (NR) | 0.37 (NR) | NR | 0.80 (NR)
6-Item Screener | Dementia | Callahan, 2002^131^ | All | 4 (15/344) | 344 | ≥3 | 0.887 (NR) | 0.880 (NR) | 0.248 (NR) | 0.994 (NR) | 0.95 (NR)
6-Item Screener | Cognitive Impairment | Callahan, 2002^131^ | All | 26 (91/344) | 344 | ≥2 | 0.742 (NR) | 0.802 (NR) | 0.574 (NR) | 0.896 (NR) | 0.86 (NR)
AD8 | Dementia | Chan, 2016^*^,^132^ | 60 years or older | 24 (113/478) | 309 | ≥4 | 0.91 (NR) | 0.91 (NR) | 0.63 (NR) | 0.98 (NR) | 0.97 (0.95, 0.99)
AD8 | Dementia | Chan, 2016^*^,^132^ | 75 years or older | 24 (113/478) | 110 | ≥4 | 0.90 (NR) | 0.88 (NR) | 0.79 (NR) | 0.94 (NR) | 0.95 (0.91, 0.99)
AD8 | Dementia | Chan, 2016^*^,^132^ | 79 years or older | 24 (113/478) | 59 | ≥4 | 0.87 (NR) | 0.82 (NR) | 0.84 (NR) | 0.85 (NR) | 0.90 (0.81, 0.98)
AD8 | Dementia | Mao, 2018 | All | 9 (917/10340) | 8805 | 1.5 | 0.88 (NR) | 0.84 (NR) | NR | NR | 0.90 (0.89, 0.92)
AD8 | Dementia | Mao, 2018 | Edu Elem School | NR | NR | 1.5 | 0.84 (NR) | 0.87 (NR) | NR | NR | 0.90 (0.88, 0.92)
AD8 | Dementia | Mao, 2018 | Edu illiterate | NR | NR | 1.5 | 0.92 (NR) | 0.74 (NR) | NR | NR | 0.89 (0.88, 0.91)
AD8 | Dementia | Mao, 2018 | Edu Jr HS or higher | NR | NR | 1.5 | 0.82 (NR) | 0.92 (NR) | NR | NR | 0.91 (0.88, 0.95)
AD8 | Dementia | Mao, 2018 | Men | NR | NR | 1.5 | 0.87 (NR) | 0.87 (NR) | NR | NR | 0.91 (0.89, 0.93)
AD8 | Dementia | Mao, 2018 | Women | NR | NR | 1.5 | 0.88 (NR) | 0.82 (NR) | NR | NR | 0.90 (0.88, 0.91)
AD8 | MCI | Galvin, 2005^146^ | All | 29 (68/236) | 180 | ≥2 | NR | NR | NR | NR | 0.834 (NR)
AD8 | Cognitive Impairment | Galvin, 2005^146^ | All | 53 (124/236) | 236 | ≥2 | 0.85 (NR) | 0.86 (NR) | 0.76 (NR) | 0.84 (NR) | 0.904 (NR)
CDT | Dementia | Ball, 2001^127^ | All | 9 (10/170) (estimated) | 53 | NR | 0.67 (NR) | 0.69 (NR) | 0.39 (NR) | 0.91 (NR) | NR
CDT | Dementia | Del Ser, 2006^137^ | All | 12 (48/416) | 416 | NR (Freedman) | 0.979 (NR) | 0.807 (NR) | 0.398 (NR) | 0.996 (NR) | 0.927 (NR)
CDT | Dementia | Fuchs, 2012^144^ | All | 5 (21/423) | 423 | ≤7 (Sunderland) | 0.895 (0.757, 1.00) | 0.837 (0.801, 0.873) | 0.207 (0.120, 0.295) | 0.994 (0.986, 1.00) | 0.856 (0.733, 0.978)
CDT | Dementia | Kirby, 2001^158^ | All | 6 (41/648) | 648 | ≤5 (Sunderland) | NR | NR | NR | NR | NR (NR)
CDT | Dementia | Wolf-Klein, 1989^182^ | All | 47 (147/312) | 312 | Abnormal patterns | NR (NR) | NR (NR) | NR (NR) | NR (NR) | NR (NR)
CDT | MCI | Donnelly, 2008^138^ | All | 20 (20/100) | 100 | 1 SD (Freedman) | 0.85 (0.62, 0.97) | 0.44 (0.33, 0.55) | 0.27 (0.17, 0.40) | 0.92 (0.79, 0.98) | 0.73 (NR)
CDT | MCI | Ehreke, 2009^140^ | All-MCI modified | 14 (58/428) | 3198 | ≤9 (Sunderland) | 0.594 (NR) | 0.597 (NR) | NR | NR | 0.616 (NR)
CDT | MCI | Ehreke, 2009^140^ | All-MCI original | 14 (58/428) | 3198 | ≤9 (Sunderland) | 0.582 (NR) | 0.573 (NR) | NR | NR | 0.595 (NR)
CDT | MCI | Ehreke, 2009^140^ | All | 14 (58/428) | 428 | ≤9 (Sunderland) | 0.69 (NR) | 0.63 (NR) | NR | NR | NR
CDT | MCI | Ehreke, 2009^140^ | All | 14 (58/428) | 428 | ≥2 (Shulman) | 0.76 (NR) | 0.58 (NR) | NR (NR) | NR (NR) | NR
CDT | MCI | Lee, 2008^162^ | All | 48 (224/465) | 465 | 1/2 (CERAD) | 0.430 (NR) | 0.853 (NR) | 0.245 (NR) | 0.784 (NR) | 0.656 (0.606, 0.706)
CDT | MCI | Lee, 2008^162^ | All | 48 (224/465) | 465 | 9/10 (Freedman) | 0.407 (NR) | 0.830 (NR) | 0.210 (NR) | 0.748 (NR) | 0.653 (0.604, 0.701)
CDT | MCI | Lee, 2008^162^ | All | 48 (224/465) | 465 | 6/6.5 (Todd) | 0.444 (NR) | 0.813 (NR) | 0.209 (NR) | 0.716 (NR) | 0.661 (0.613, 0.710)
CDT | MCI | Lee, 2008^162^ | All | 48 (224/465) | 465 | 7/8 (Rouleau) | 0.564 (NR) | 0.718 (NR) | 0.182 (NR) | 0.559 (NR) | 0.669 (0.621, 0.717)
CoDEx | Cognitive Impairment | Vannier-Nitenberg, 2016^*^,^179^ | All | 31 (182/585) | 491 | NA | 0.320 (NR) | 0.848 (NR) | 0.480 (NR) | 0.739 (NR) | NR (NR)
Dubois five-word test | Cognitive Impairment | Vannier-Nitenberg, 2016^*^,^179^ | All | 31 (182/585) | 554 | ≤9 | 0.283 (NR) | 0.892 (NR) | 0.544 (NR) | 0.733 (NR) | NR (NR)
FAQ | Dementia | Cruz-Orduna, 2011^134^ | All | 9 (15/160) | 160 | ≥9 | 0.8667 (NR) | 0.8207 (NR) | 0.3333 (NR) | 0.9835 (NR) | 0.91 (0.84, 0.96)
FAQ | Dementia | Juva, 1997^154^ | All | 14 (93/656) | 370 | ≥8 | 0.94 (NR) | 0.84 (NR) | 0.50 (NR) | NR (NR) | 0.96 (0.92, 0.98)
FAQ | Cognitive Impairment | Cruz-Orduna, 2011^134^ | All | 56 (90/160) | 160 | ≥2 | 0.7333 (NR) | 0.7286 (NR) | 0.7765 (NR) | 0.68000 (NR) | 0.77 (0.69, 0.84)
GPCOG | Dementia | Brodaty, 2002^129^ | All | 29 (82/283) | 202 | ≤10 | 0.82 (NR) | 0.83 (NR) | 0.67 (NR) | 0.92 (NR) | 0.91 (0.86, 0.95)
HVLT | MCI | Donnelly, 2008^138^ | All | 20 (20/100) | 100 | 1 SD | 0.55 (0.32, 0.77) | 0.43 (0.32, 0.54) | 0.19 (0.10, 0.32) | 0.79 (0.64, 0.90) | 0.55 (NR)
Informant memory report | Dementia | Ayalon, 2011^126^ | All | 32 (206/647) | 647 | >2 | NR | NR | NR | NR | NR
Informant memory report | MCI | Ayalon, 2011^126^ | All | 29 (185/647) | 441 | >2 | 0.811 (NR) | 0.753 (NR) | 0.246 (NR) | 0.188 (NR) | 0.85 (NR)
Informant memory report | Cognitive Impairment | Ayalon, 2011^126^ | All | 60 (391/647) | 647 | >2 | NR | NR | NR | NR | NR
Katz ADL | Dementia | Juva, 1997^154^ | All | 14 (93/656) | 437 | ≥2 | 0.81 (NR) | 0.83 (NR) | 0.42 (NR) | NR (NR) | 0.90 (0.80, 0.94)
Lawton IADL | Dementia | Juva, 1997^154^ | All | 14 (93/656) | 424 | ≤4 | 0.91 (NR) | 0.86 (NR) | 0.49 (NR) | NR (NR) | 0.95 (0.91, 0.98)
Lawton IADL | Dementia | Mao, 2018^460^ | All | 9 (917/10340) | 8805 | 6.5 | 0.89 (NR) | 0.81 (NR) | NR | NR | 0.925 (0.915, 0.935)
Lawton IADL | Dementia | Mao, 2018^460^ | Edu Elem School | NR | NR | 6.5 | 0.87 (NR) | 0.82 (NR) | NR | NR | 0.916 (0.898, 0.934)
Lawton IADL | Dementia | Mao, 2018^460^ | Edu illiterate | NR | NR | 6.5 | 0.89 (NR) | 0.75 (NR) | NR | NR | 0.913 (0.898, 0.929)
Lawton IADL | Dementia | Mao, 2018^460^ | Edu Jr HS or higher | NR | NR | 6.5 | 0.94 (NR) | 0.88 (NR) | NR | NR | 0.947 (0.917, 0.978)
Lawton IADL | Dementia | Mao, 2018^460^ | Men | NR | NR | 6.5 | 0.93 (NR) | 0.78 (NR) | NR | NR | 0.926 (0.910, 0.942)
Lawton IADL | Dementia | Mao, 2018^460^ | Women | NR | NR | 6.5 | 0.86 (NR) | 0.84 (NR) | NR | NR | 0.928 (0.915, 0.940)
M@T - Cued recall | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <9 | 0.80 (NR) | 0.78 (NR) | 0.29 (NR) | 0.97 (NR) | 0.86 (0.78, 0.93)
M@T - Encoding | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <9 | 0.58 (NR) | 0.88 (NR) | 0.35 (NR) | 0.95 (NR) | 0.79 (0.70, 0.87)
M@T - Free recall | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <6 | 0.90 (NR) | 0.77 (NR) | 0.30 (NR) | 0.99 (NR) | 0.88 (0.82, 0.94)
M@T - Orientation | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <5 | 0.38 (NR) | 0.83 (NR) | 0.20 (NR) | 0.92 (NR) | 0.61 (0.50, 0.71)
M@T - Semantic | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <14 | 0.85 (NR) | 0.54 (NR) | 0.17 (NR) | 0.97 (NR) | 0.74 (0.65, 0.83)
MF-2 | Dementia | Holsinger, 2012^149^ | All | 3 (21/630) | 630 | Both yes | 0.38 (0.20, 0.60) | 0.87 (0.84, 0.89) | NR (NR) | NR (NR) | NR (NR)
MF-2 | Cognitive Impairment | Holsinger, 2012^149^ | All | 42 (268/630) | 630 | Both yes | 0.24 (0.19, 0.29) | 0.93 (0.90, 0.95) | NR (NR) | NR (NR) | NR (NR)
Mini-Cog | Dementia | Borson, 2006^128^ | All | 42 (154/371) | 371 | ≤2 | NR | NR | NR | NR | NR
Mini-Cog | Dementia | Fuchs, 2012^144^ | All | 5 (21/423) | 423 | ≤1 | 1.00 (0.824, 1.00) | 0.852 (0.841, 0.884) | 0.234 (0.153, 0.340) | 1.00 (0.989, 1.00) | 0.956 (0.931, 0.982)
Mini-Cog | Dementia | Holsinger, 2012^149^ | All | 3 (21/630) | 630 | ≤2 | 0.76 (0.54, 0.90) | 0.73 (0.69, 0.76) | NR (NR) | NR (NR) | NR (NR)
Mini-Cog | Dementia | Kaufer, 2008^156^ | All | 38 (55/146) | 146 | 0 | 0.87 (0.76, 0.95) | 0.54 (0.43, 0.64) | 0.53 (NR) | 0.88 (NR) | 0.706 (NR)
Mini-Cog | MCI | Kaufer, 2008^156^ | All | 52 (76/146) | 91 | 0 | 0.50 (0.38, 0.62) | 0.73 (0.45, 0.92) | 0.90 (NR) | 0.22 (NR) | 0.617 (NR)
Mini-Cog | Cognitive Impairment | Borson, 2006^128^ | All | 62 (231/371) | 371 | ≤2 | NR | NR | NR | NR | NR
Mini-Cog | Cognitive Impairment | Holsinger, 2012^149^ | All | 42 (268/630) | 630 | ≤2 | 0.39 (0.34, 0.45) | 0.78 (0.73, 0.82) | NR (NR) | NR (NR) | NR (NR)
Mini-Cog | Cognitive Impairment | Kaufer, 2008^156^ | All | 90 (131/146) | 146 | 0 | NR | NR | NR | NR | NR
MIS | Dementia | Buschke, 1999 | All | 10 (50/483) | 483 | 4 | 0.80 (NR) | 0.96 (NR) | 0.69 (NR) | 0.98 (NR) | 0.94 (NR)
MIS | Dementia | Holsinger, 2012^149^ | All | 3 (21/630) | 630 | ≤4 | 0.43 (0.24, 0.64) | 0.93 (0.90, 0.95) | NR (NR) | NR (NR) | NR (NR)
MIS | Dementia | Kuslansky, 2002^159^ | All | 12 (28/240) | 240 | ≤4 | 0.86 (NR) | 0.97 (NR) | 0.80 (NR) | NR | 0.93 (NR)
MIS | Dementia | Ranson, 2018^461^ | All | 35 (291/824) | 824 | ≤4 | 0.82 (0.77, 0.86) | 0.85 (0.82, 0.88) | 0.48 (0.42, 0.53) | 0.97 (0.96, 0.97) | NR
MIS | Cognitive Impairment | Holsinger, 2012^149^ | All | 42 (268/630) | 630 | ≤4 | 0.17 (0.13, 0.22) | 0.98 (0.96, 0.99) | NR (NR) | NR (NR) | NR (NR)
MIS-T | Dementia | Lipton, 2003^163^ | All-extrapolated | 9 (27/300) | 300 | 4 | 0.78 (NR) | 0.93 (NR) | 0.52 (NR) | NR (NR) | 0.92 (NR)
MSQ | Dementia | Fillenbaum, 1990^142^ | All | 16 (26/159) | 159 | ≤7 | NR | NR | NR | NR | NR
MSQ | Dementia | Hooijer, 1992^150^ | All | 3.6 (13/358) | 358 | ≤7 | 0.923 (NR) | 0.983 (NR) | 0.667 (NR) | NR (NR) | NR (NR)
OMC | Dementia | Fillenbaum, 1990^142^ | All | 16 (26/159) | 159 | ≥11 | NR (NR) | NR (NR) | NR (NR) | NR (NR) | NR
Self-report | Dementia | Fuchs, 2012^144^ | All | 5 (21/423) | 423 | NA | 0.895 (0.757, 1.00) | 0.458 (0.409, 0.506) | 0.073 (0.039, 0.506) | 0.989 (0.974, 1.00) | NR
SPMSQ | Dementia | Del Ser, 2006^137^ | All | 12 (48/416) | 416 | NR | 0.958 (NR) | 0.885 (NR) | 0.522 (NR) | 0.993 (NR) | 0.978 (NR)
SPMSQ | Dementia | Erkinjuntti, 1987^141^ | All | 2 (3/119) | 119 | ≤7 | 1.00 (NR) | 1.00 (NR) | 1.00 (NR) | 1.00 (NR) | NR
SPMSQ | Dementia | Fillenbaum, 1990^142^ | All | 16 (26/159) | 159 | NR | NR (NR) | NR (NR) | NR (NR) | NR (NR) | NR
SPMSQ | Dementia | Hooijer, 1992^150^ | All | 3.6 (13/358) | 358 | ≤7 | 1.0 (NR) | 0.968 (NR) | 0.542 (NR) | NR (NR) | NR (NR)
STMS | MCI | Cummings-Vaughn, 2014^*^,^136^ | All | 42 (57/136) | 108 | ≤32 | 0.68 (NR) | 0.76 (NR) | 0.76 (NR) | 0.68 (NR) | 0.77 (0.68, 0.86)
STMS | Cognitive Impairment | Cummings-Vaughn, 2014^*^,^136^ | All | 62 (85/136) | 136 | ≤32 | 0.78 (NR) | 0.76 (NR) | 0.85 (NR) | 0.67 (NR) | 0.84 (0.77, 0.90)
Sweet 16 | Dementia | Fong, 2011^143^ | All | 1 (86/709) | 729 | <14 | 0.99 (0.97, 1.00) | 0.72 (0.68, 0.77) | 0.33 (0.28, 0.39) | 1.00 (0.99, 1.00) | 0.97 (NR)
TMT | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤40 | 0.81 (NR) | 0.71 (NR) | NR (NR) | NR (NR) | 0.836 (0.756, 0.916)
TMT A | MCI | Donnelly, 2008^138^ | All | 20 (20/100) | 100 | 1 SD | 0.30 (0.12, 0.54) | 0.90 (0.81, 0.96) | 0.43 (0.18, 0.71) | 0.84 (0.74, 0.91) | 0.72 (NR)
TMT B | MCI | Donnelly, 2008^138^ | All | 20 (20/100) | 100 | 1 SD | 0.43 (0.18, 0.71) | 0.86 (0.76, 0.93) | 0.35 (0.14, 0.62) | 0.89 (0.80, 0.95) | 0.66 (NR)
TYM - Calculation | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <4 | 0.40 (NR) | 0.73 (NR) | 0.14 (NR) | 0.92 (NR) | 0.58 (0.47, 0.69)
TYM - Copying | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <1 | 0.05 (NR) | 0.99 (NR) | 0.85 (NR) | 0.95 (NR) | 0.52 (0.49, 0.67)
TYM - Fluency | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <4 | 0.73 (NR) | 0.66 (NR) | 0.19 (NR) | 0.96 (NR) | 0.72 (0.63, 0.82)
TYM - Free recall | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <3 | 0.50 (NR) | 0.93 (NR) | 0.44 (NR) | 0.94 (NR) | 0.72 (0.62, 0.82)
TYM - Help | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <4 | 0.13 (NR) | 0.93 (NR) | 0.17 (NR) | 0.91 (NR) | 0.53 (0.43, 0.64)
TYM - Naming | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <5 | 0.13 (NR) | 0.96 (NR) | 0.27 (NR) | 0.91 (NR) | 0.54 (0.43, 0.65)
TYM - Orientation | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <10 | 0.30 (NR) | 0.83 (NR) | 0.16 (NR) | 0.91 (NR) | 0.57 (0.46, 0.67)
TYM - Semantic | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <2 | 0.40 (NR) | 0.91 (NR) | 0.33 (NR) | 0.93 (NR) | 0.67 (0.56, 0.77)
TYM - Similarities | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <4 | 0.53 (NR) | 0.68 (NR) | 0.16 (NR) | 0.93 (NR) | 0.61 (0.51, 0.72)
TYM - Visuospatial 1 | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <1 | 0.13 (NR) | 0.94 (NR) | 0.19 (NR) | 0.91 (NR) | 0.50 (0.40, 0.61)
TYM - Visuospatial 2 | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <4 | 0.15 (NR) | 0.90 (NR) | 0.14 (NR) | 0.91 (NR) | 0.53 (0.42, 0.63)
VAT | Dementia | Fuchs, 2012^144^ | All | 5 (21/423) | 423 | 7/8 | 0.952 (0.861, 1.00) | 0.960 (0.941, 0.979) | 0.556 (0.393, 0.718) | 0.997 (0.992, 1.00) | 0.981 (0.963, 0.999)
VFT | Dementia | Del Ser, 2006^137^ | All | 12 (48/416) | 416 | NR | 0.979 (NR) | 0.839 (NR) | 0.443 (NR) | 0.996 (NR) | 0.975 (NR)
VFT | Dementia | Fuchs, 2012^144^ | All | 5 (21/423) | 423 | ≤12 | 0.895 (0.757, 1.00) | 0.883 (0.851, 0.914) | 0.266 (0.157, 0.374) | 0.994 (0.987, 1.00) | 0.918 (0.833, 1.002)
VFT | Dementia | Lipton, 2003^163^ | All-extrapolated | 9 (27/300) | 300 | 19 | 0.68 (NR) | 0.88 (NR) | 0.36 (NR) | NR (NR) | 0.89 (NR)
VFT | Cognitive Impairment | Vannier-Nitenberg, 2016^*^,^179^ | All | 31 (182/585) | 553 | NA | 0.247 (NR) | 0.885 (NR) | 0.506 (NR) | 0.712 (NR) | NR (NR)
VFT - animals | Dementia | Ranson, 2018^461^ | All | 35 (291/824) | 824 | ≤8 | 0.78 (0.73, 0.83) | 0.90 (0.87, 0.92) | 0.55 (0.48, 0.61) | 0.96 (0.95, 0.91) | 0.92 (NR)
VFT - animals and names | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤30 | 0.84 (NR) | 0.81 (NR) | NR | NR | 0.902 (0.806, 0.998)
VFT - animals category | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤14 | 0.81 (NR) | 0.83 (NR) | NR (NR) | NR (NR) | 0.886 (0.828, 0.942)
VFT - repeated animal names | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤1 | 0.31 (NR) | 0.76 (NR) | NR | NR | 0.533 (0.423, 0.643)
VFT - repeated first names | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤1 | 0.32 (NR) | 0.70 (NR) | NR | NR | 0.512 (0.402, 0.622)

* New study

Abbreviations: 3-Word = 3-Word Memory Test; AD8 = 8-item informant interview; ADL = activities of daily living; AUC = area under the curve; CDT = Clock Drawing Test; CERAD = Consortium to Establish a Registry for Alzheimer’s Disease; CI = confidence interval; CoDEx = Cognitive Disorders Examination test; FAQ = Functional Activities Questionnaire; GPCOG = General Practitioner Assessment of Cognition; HVLT = Hopkins Verbal Learning Test; IADL = instrumental activities of daily living; KQ = key question; M@T = Memory Alteration Test; MCI = mild cognitive impairment; MCI = mild cognitive impairment; MF-2 = 2-item functional memory screen; MIS/MIS-T = Memory Impairment Screen/Memory Impairment Screen by Telephone; MSQ/SPMSQ = Mental Health Status Questionnaire/Short Portable Mental Status Questionnaire; N = number of participants; NA = not applicable; NPV = negative predictive value; NR = not reported; OMC = Orientation Memory Concentration; PPV = positive predictive value; SD = standard deviation; STMS = Short Test of Mental Status; TMT = Trail Making Test; TYM = Test Your Memory; Sens = sensitivity; Spec = specificity; VAT = Visual Association Test; VFT = Verbal Fluency Test

Table 5 Test Performance of Brief Screening Instruments, by Instrument and Target Condition (KQ 2)

Test name | Target condition | Author, year | Screened Group | Percent (n/n) with condition | Total n | Cutoff | Sens (95% CI) | Spec (95% CI) | PPV (95% CI) | NPV (95% CI) | AUC (95% CI)
7MS | Dementia | Del Ser, 2006^137^ | All | 12 (48/416) | 416 | NR | 1.00 (NR) | 0.951 (NR) | 0.786 (NR) | 1.00 (NR) | 0.996 (NR)
7MS | Dementia | Solomon, 2000^174^ | All | 10 (13/137) | 137 | ≥0.7 | NR | NR | NR | NR | NR
AMT | Dementia | Brodaty, 2002^129^ | All | 29 (82/283) | 269 | ≤7 | 0.42 (NR) | 0.93 (NR) | 0.71 (NR) | 0.80 (NR) | 0.78 (0.71, 0.84)
AMT | Dementia | Hooijer, 1992^150^ | All | 3.6 (13/358) | 358 | ≤7 | 0.923 (NR) | 0.954 (NR) | 0.429 (NR) | NR | NR
AMT | Dementia | Rait, 2000^170^ | All | 6 (6/96) | 96 | ≤7 | 1.0 (0.54, 1.0) | 0.83 (0.76, 0.91) | NR | NR | NR
AMT | Dementia | Rait, 2000^169^ | Gujarati | 11 (13/120) | 62 | ≤5 | 1.0 (0.16, 1.0) | 0.95 (0.858, 0.99) | NR | NR | NR
AMT | Dementia | Rait, 2000^169^ | Pakistani | NR | 39 | ≤6 | 1.0 (0.664, 1.0) | 0.867 (0.684, 0.956) | NR | NR | NR
FCR | Dementia | Del Ser, 2006^137^ | All | 12 (48/416) | 416 | NR | 1.00 (NR) | 0.872 (NR) | 0.505 (NR) | 1.00 (NR) | 0.994 (NR)
FOME-abbreviated | Cognitive Impairment | Rideaux, 2012^172^ | Black | 57 (401/701) | 87 | ≤21 | 0.65 (0.55, 0.75) | 0.74 (0.64, 0.83) | 0.76 (0.67, 0.85) | 0.62 (0.52, 0.72) | NR
FOME-abbreviated | Cognitive Impairment | Rideaux, 2012^172^ | Latino | 57 (401/701) | 55 | ≤24 | 0.93 (NR) | 0.57 (NR) | NR | NR | NR
FOME-abbreviated | Cognitive Impairment | Rideaux, 2012^172^ | White | 57 (401/701) | 380 | ≤20 | 0.55 (0.50, 0.60) | 0.93 (0.91, 0.96) | 0.83 (0.80, 0.87) | 0.80 (0.75, 0.84) | NR
Immediate Recall | Dementia | Fuchs, 2012^144^ | All | 5 (21/423) | 423 | ≤14 | 1.00 (1.00, 1.00) | 0.828 (0.790, 0.865) | 0.207 (0.122, 0.292) | 1.00 (1.00, 1.00) | 0.957 (0.927, 0.987)
Kendrick Cognitive Tests | Dementia | Fillenbaum, 1990 | All | 16 (26/159) | 159 | NA | NR | NR | NR | NR | NR
Labyrinth Test - mistakes | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤3 | 0.88 (NR) | 0.60 (NR) | NR | NR | 0.802 (0.716, 0.888)
Labyrinth Test - seconds | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤80 | 0.56 (NR) | 0.84 (NR) | NR | NR | 0.725 (0.592, 0.858)
M@T | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <40 | 0.85 (NR) | 0.84 (NR) | 0.37 (NR) | 0.98 (NR) | 0.91 (0.85, 0.96)
MMblind | Dementia | Resichies, 1997^171^ | 70–84 years | 20 (100/491) | 248 | 18/19 | 0.812 (NR) | 0.894 (NR) | NR | NR | NR
MMblind | Dementia | Resichies, 1997^171^ | 85–95+ years | 20 (100/491) | 243 | 16/17 | 0.734 (NR) | 0.781 (NR) | NR | NR | NR
MMblind | Dementia | Resichies, 1997^171^ | All | 20 (100/491) | 491 | 17/18 | 0.849 (NR) | 0.821 (NR) | NR | NR | NR
MMSE | Dementia | Brodaty, 2002^129^ | All | 29 (82/283) | 283 | ≤24 | 0.81 (NR) | 0.76 (NR) | 0.57 (NR) | 0.90 (NR) | 0.85 (0.80, 0.90)
MMSE | Dementia | Callahan, 2002^131^ | All | 4 (15/344) | 344 | ≤24 | 0.984 (NR) | 0.836 (NR) | 0.248 (NR) | 0.994 (NR) | 0.96 (NR)
MMSE | Dementia | Callahan, 2002^131^ | All | 4 (15/344) | 344 | ≤23 | 0.952 (NR) | 0.867 (NR) | 0.242 (NR) | 0.998 (NR) | 0.96 (NR)
MMSE | Dementia | Chan, 2016^*^,^132^ | 60 years or older | 24 (113/478) | 309 | ≤20 | 0.75 (NR) | 0.94 (NR) | 0.66 (NR) | 0.96 (NR) | 0.92 (0.88, 0.97)
MMSE | Dementia | Chan, 2016^*^,^132^ | 75 years or older | 24 (113/478) | 110 | ≤17 | 0.71 (NR) | 0.92 (NR) | 0.82 (NR) | 0.86 (NR) | 0.87 (0.79, 0.94)
MMSE | Dementia | Chan, 2016^*^,^132^ | 79 years or older | 24 (113/478) | 59 | ≤19 | 0.81 (NR) | 0.86 (NR) | 0.86 (NR) | 0.80 (NR) | 0.84 (0.74, 0.95)
MMSE | Dementia | Cruz-Orduna, 2011^134^ | All | 9 (15/160) | 160 | ≤18 | 0.8000 (NR) | 0.8621 (NR) | 0.5750 (NR) | 0.9766 (NR) | 0.89 (0.82, 0.95)
MMSE | Dementia | Cullen, 2005^135^ | All | 4 (44/1115) | 1115 | ≤23 | 0.909 (NR) | 0.871 (NR) | NR | NR | NR
MMSE | Dementia | Fillenbaum, 1990^142^ | All | 16 (26/159) | 159 | ≤23 | NR | NR | NR | NR | NR
MMSE | Dementia | Fong, 2011^143^ | All | 1 (86/709) | 709 | ≤23 | 0.87 (0.78, 0.95) | 0.89 (0.86, 0.92) | 0.52 (0.44, 0.60) | 0.98 (0.99, 0.99) | 0.95 (NR)
MMSE | Dementia | Gagnon, 1990^145^ | All | 4 (10/2730) | 2730 | 24 | 1.00 (NR) | 0.78 (NR) | 0.15 (NR) | NR | NR
MMSE | Dementia | Grut, 1993^147^ | All | 14 (255/810) | 1810 | ≤23 | 0.87 (NR) | 0.92 (NR) | 0.68 (NR) | NR | NR
MMSE | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤23 | 0.84 (NR) | 0.99 (NR) | NR | NR | 0.988 (0.880, 1.0)
MMSE | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤24 | 0.92 (NR) | 0.96 (NR) | NR | NR | 0.988 (0.880, 1.0)
MMSE | Dementia | Hooijer, 1992^150^ | All | 3.6 (13/358) | 358 | ≤23 | 0.769 (NR) | 0.965 (NR) | 0.455 (NR) | NR | NR
MMSE | Dementia | Chan, 2016^*^,^132^ | 13 years edu or more | 6 (16/276) | 97 | 27.5 | 0.63 (NR) | 1.00 (NR) | NR | NR | NR
MMSE | Dementia | Chan, 2016^*^,^132^ | 6 years edu or less | 6 (16/276) | 61 | 24.5 | 0.79 (NR) | 0.75 (NR) | NR | NR | 0.7965 (0.60, 0.99)
MMSE | Dementia | Chan, 2016^*^,^132^ | 60–69 years | 6 (16/276) | 171 | 25.5 | 0.85 (NR) | 1.00 (NR) | NR | NR | 0.8925 (0.83, 0.96)
MMSE | Dementia | Chan, 2016^*^,^132^ | 70–79 years | 6 (16/276) | 91 | 24.5 | 0.87 (NR) | 0.38 (NR) | NR | NR | 0.6456 (0.44, 0.85)
MMSE | Dementia | Chan, 2016^*^,^132^ | 7–12 years edu | 6 (16/276) | 118 | 28.5 | 0.41 (NR) | 0.88 (NR) | NR | NR | 0.6290 (0.45, 0.81)
MMSE | Dementia | Chan, 2016^*^,^132^ | 80 years or more | 6 (16/276) | 14 | 28.5 | 0.27 (NR) | 1.00 (NR) | NR | NR | 0.5758 (0.19, 0.96)
MMSE | Dementia | Chan, 2016^*^,^132^ | All | 6 (16/276) | 276 | 28.5 | 0.38 (NR) | 0.92 (NR) | NR | NR | 0.6976 (0.56, 0.83)
MMSE | Dementia | Chan, 2016^*^,^132^ | Men | 6 (16/276) | 136 | 28.5 | 0.35 (NR) | 1.00 (NR) | NR | NR | 0.6717 (0.51, 0.84)
MMSE | Dementia | Chan, 2016^*^,^132^ | Women | 6 (16/276) | 140 | 25.5 | 0.77 (NR) | 0.67 (NR) | NR | NR | 0.7317 (0.50, 0.96)
MMSE | Dementia | Jeong, 2004^152^ | All | 20 (46/235) | 235 | ≤18 | 0.91 (0.79, 0.98) | 0.76 (0.69, 0.82) | NR | NR | 0.89 (NR)
MMSE | Dementia | Jorm, 1996^153^ | All | NR | NR | ≤26 | 0.67 (NR) | 0.85 (NR) | NR | NR | 0.81 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 90 to 93 college grad | 36 (155/435) | 63 | 25 | 0.82 (NR) | 0.80 (NR) | NR | NR | 0.90 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 90 to 93 some college | 36 (155/435) | 57 | 22 | 0.92 (NR) | 0.96 (NR) | NR | NR | 0.98 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 90–93 HS edu or less | 36 (155/435) | 49 | 23 | 0.87 (NR) | 0.94 (NR) | NR | NR | 0.92 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 94 to 96 college grad | 36 (155/435) | 74 | 24 | 0.85 (NR) | 0.80 (NR) | NR | NR | 0.92 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 94 to 96 some college | 36 (155/435) | 43 | 25 | 0.88 (NR) | 0.85 (NR) | NR | NR | 0.94 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 94–96 HS edu or less | 36 (155/435) | 35 | 23 | 0.90 (NR) | 0.93 (NR) | NR | NR | 0.94 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 97 or over college grad | 36 (155/435) | 49 | 23 | 0.89 (NR) | 0.90 (NR) | NR | NR | 0.95 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 97 or over HS edu or less | 36 (155/435) | 32 | 22 | 0.80 (NR) | 0.76 (NR) | NR | NR | 0.93 (NR)
MMSE | Dementia | Kahle-Wrobleski, 2007^155^ | Age 97 or over some college | 36 (155/435) | 33 | 24 | 0.94 (NR) | 0.88 (NR) | NR | NR | 0.93 (NR)
MMSE | Dementia | Kaufer, 2008^156^ | All | 38 (55/146) | 146 | ≤26 | 0.82 (0.69, 0.91) | 0.67 (0.56, 0.77) | 0.60 (NR) | 0.86 (NR) | 0.854 (NR)
MMSE | Dementia | Kay, 1985^157^ | All | 14 (39/274) | 274 | ≤24 | 0.846 (NR) | 0.808 (NR) | NR | NR | NR
MMSE | Dementia | Kirby, 2001^158^ | All | 6 (41/648) | 648 | ≤23 | NR | NR | NR | NR | NR
MMSE | Dementia | Lam, 2008^160^ | All | 10 (44/459) | 459 | NR | NR | NR | NR | NR | 0.811 (NR)
MMSE | Dementia | McDowell, 1997^166^ | All | 23 (368/1600) | 1600 | 24 | 0.63 (NR) | 0.89 (NR) | NR | NR | 0.89 (NR)
MMSE | Dementia | Mao, 2018^460^ | All | 9 (917/10340) | 8805 | 20.5 | 0.89 (, ) | 0.82 (, ) | (, ) | (, ) | 0.93 (0.92, 0.94)
MMSE | Dementia | Mao, 2018^460^ | Edu Elem School | NR | NR | 21.5 | 0.89 (, ) | 0.85 (, ) | (, ) | (, ) | 0.94 (0.92, 0.95)
MMSE | Dementia | Mao, 2018^460^ | Edu illiterate | NR | NR | 15.5 | 0.89 (, ) | 0.91 (, ) | (, ) | (, ) | 0.95 (0.94, 0.96)
MMSE | Dementia | Mao, 2018^460^ | Edu Jr HS or higher | NR | NR | 24.5 | 0.90 (, ) | 0.80 (, ) | (, ) | (, ) | 0.94 (0.92, 0.97)
MMSE | Dementia | Mao, 2018^460^ | Men | NR | NR | 21.5 | 0.87 (, ) | 0.85 (, ) | (, ) | (, ) | 0.93 (0.92, 0.94)
MMSE | Dementia | Mao, 2018^460^ | Women | NR | NR | 17.5 | 0.84 (, ) | 0.90 (, ) | (, ) | (, ) | 0.94 (0.25, 0.95)
MMSE | Dementia | Morales, 1997^167^ | Rural | 13 (34/257) | 160 | 20 | 0.83 (NR) | 0.74 (NR) | 0.34 (NR) | 0.95 (NR) | NR
MMSE | Dementia | Rait, 2000^170^ | All | 6 (6/96) | 96 | ≤25 | 0.83 (0.76, 0.91) | 0.78 (0.69, 0.86) | NR | NR | NR
MMSE | Dementia | Rait, 2000^169^ | Gujarati | 11 (13/120) | 62 | ≤23 | 1.0 (0.16, 1.0) | 0.95 (0.858, 0.99) | NR | NR | NR
MMSE | Dementia | Rait, 2000^169^ | Pakistani | NR | 39 | ≤26 | 1.0 (0.664, 1.0) | 0.767 (0.573, 0.894) | NR | NR | NR
MMSE | Dementia | Ranson, 2018^461^ | All | 35 (291/824 | 824 | ≤23 | 0.931 (0.896, 0.958) | 0.713 (0.672, 0.751) | 0.344 (0.313, 0.375) | 0.985 (0.977, 0.990) | 0.94 (NR)
MMSE | Dementia | Resichies, 1997^171^ | 70–84 years | 20 (100/491) | 236 | ≤26 | 0.80 (NR) | 0.824 (NR) | NR | NR | NR
MMSE | Dementia | Resichies, 1997^171^ | 85–95+ years | 20 (100/491) | 213 | ≤23 | 0.851 (NR) | 0.753 (NR) | NR | NR | NR
MMSE | Dementia | Resichies, 1997^171^ | All | 20 (100/491) | 449 | ≤24 | 0.841 (NR) | 0.831 (NR) | NR | NR | NR
MMSE | Dementia | Resichies, 1997^171^ | All | 20 (100/491) | 449 | ≤23 | 0.78 (NR) | 0.876 (NR) | NR | NR | NR
MMSE | Dementia | Stein, 2015^*^,^175^ | All | 3 (86/2657) | 2657 | ≤24 | 0.930 (NR) | 0.959 (NR) | 0.432 (NR) | 0.997 (NR) | 0.979 (0.965, 0.993)
MMSE | Dementia | Tariq, 2006^177^ | HS edu or more | 12 (82/702) | 488 | ≤28.5 | NR | NR | NR | NR | NR
MMSE | Dementia | Tariq, 2006^177^ | Less than HS edu | 12 (82/702) | 214 | ≤27.5 | NR | NR | NR | NR | NR
MMSE | Dementia | Waite, 1998^181^ | All | 28 (99/360) | 360 | ≤23 | 0.84 (NR) | 0.88 (NR) | NR | NR | 0.93 (NR)
MMSE | MCI | Donnelly, 2008^138^ | All | 20 (20/100) | 100 | 1 SD | 0.20 (0.06, 0.44) | 0.93 (0.84, 0.97) | 0.40 (0.12, 0.74) | 0.82 (0.73, 0.89) | 0.72 (NR)
MMSE | MCI | Kaufer, 2008^156^ | All | 52 (76/146) | 91 | ≤27 | 0.47 (0.36, 0.59) | 0.73 (0.45, 0.92) | 0.90 (NR) | 0.22 (NR) | 0.666 (NR)
MMSE | MCI | Saxton, 2009^173^ | All | 44 (228/524) | 524 | 28 | 0.45 (NR) | 0.80 (NR) | NR | NR | NR
MMSE | MCI | Tariq, 2006^177^ | HS edu or more | 26 (180/702) | 433 | ≤29.5 | 0.75 (NR) | 0.48 (NR) | 0.38 (NR) | 0.82 (NR) | 0.643 (NR)
MMSE | MCI | Tariq, 2006^177^ | Less than HS edu | 26 (180/702) | 187 | ≤28.5 | 0.60 (NR) | 0.65 (NR) | 0.38 (NR) | 0.82 (NR) | 0.671 (NR)
MMSE | Cognitive Impairment | Callahan, 2002^131^ | All | 26 (91/344) | 344 | ≤25 | 0.715 (NR) | 0.873 (NR) | 0.669 (NR) | 0.895 (NR) | 0.84 (NR)
MMSE | Cognitive Impairment | Cruz-Orduna, 2011^134^ | All | 56 (90/160) | 160 | ≤23 | 0.7667 (NR) | 0.7000 (NR) | 0.7667 (NR) | 0.7000 (NR) | 0.82 (0.76, 0.88)
MMSE | Cognitive Impairment | Cullen, 2005^135^ | All | 9 (97/1115) | 1115 | ≤23 | 0.722 (NR) | 0.894 (NR) | NR | NR | NR
MMSE | Cognitive Impairment | Jeong, 2004^152^ | All | 42 (100/235) | 235 | ≤20 | 0.82 (0.73, 0.89) | 0.79 (0.71, 0.86) | NR | NR | 0.89 (NR)
MMSE | Cognitive Impairment | Jorm, 1996^153^ | All | NR | NR | NR | NR | NR | NR | NR | 0.70 (NR)
MMSE | Cognitive Impairment | Kaufer, 2008^156^ | All | 90 (131/146) | 146 | ≤26 | NR | NR | NR | NR | NR
MMSE | Cognitive Impairment | Lam, 2008^160^ | All | 45 (206/459) | 459 | NR | NR | NR | NR | NR | 0.961 (NR)
MMSE | Cognitive Impairment | McDowell, 1997^166^ | All | 53 (848/1600) | 1600 | NR | NR | NR | NR | NR | 0.77 (NR)
MMSE | Cognitive Impairment | Rideaux, 2012^172^ | Black | 57 (401/701) | 87 | ≤22 | 0.67 (NR) | 0.71 (NR) | NR | NR | NR
MMSE | Cognitive Impairment | Rideaux, 2012^172^ | Latino | 57 (401/701) | 55 | ≤24 | 0.93 (0.86, 1.0) | 0.71 (0.60, 0.83) | 0.93 (0.64, 0.87) | 0.71 (0.83, 0.99) | NR
MMSE | Cognitive Impairment | Rideaux, 2012^172^ | White | 57 (401/701) | 380 | ≤25 | 0.58 (NR) | 0.86 (NR) | NR | NR | NR
MMSE | Cognitive Impairment | Tariq, 2006^177^ | HS edu or more | 37 (262/702) | 488 | ≤28.5 | NR | NR | NR | NR | NR
MMSE | Cognitive Impairment | Tariq, 2006^177^ | Less than HS edu | 37 (262/702) | 214 | ≤27.5 | NR | NR | NR | NR | NR
MMSE | Cognitive Impairment | Vercambre, 2010^180^ | All | 23 (28/120) | 120 | NR | NR | NR | NR | NR | 0.72 (NR)
MoCA | Dementia | Chan, 2016^*^,^132^ | 60 years or older | 24 (113/478) | 309 | ≤16 | 0.84 (NR) | 0.89 (NR) | 0.56 (NR) | 0.97 (NR) | 0.94 (0.92, 0.97)
MoCA | Dementia | Chan, 2016^*^,^132^ | 75 years or older | 24 (113/478) | 110 | ≤12 | 0.76 (NR) | 0.88 (NR) | 0.76 (NR) | 0.88 (NR) | 0.88 (0.82, 0.95)
MoCA | Dementia | Chan, 2016^*^,^132^ | 79 years or older | 24 (113/478) | 59 | ≤12 | 0.81 (NR) | 0.86 (NR) | 0.86 (NR) | 0.80 (NR) | 0.87 (0.78, 0.96)
MoCA | Dementia | Hsu, 2015^*^,^151^ | 13 years edu or more | 6 (16/276) | 97 | 22.5 | 0.92 (NR) | 1.00 (NR) | NR | NR | NR
MoCA | Dementia | Hsu, 2015^*^,^151^ | 6 years edu or less | 6 (16/276) | 61 | 20.5 | 0.89 (NR) | 1.00 (NR) | NR | NR | 0.9709 (0.91, 1.00)
MoCA | Dementia | Hsu, 2015^*^,^151^ | 60–69 years | 6 (16/276) | 171 | 23.5 | 0.84 (NR) | 1.00 (NR) | NR | NR | 0.9625 (0.90, 1.00)
MoCA | Dementia | Hsu, 2015^*^,^151^ | 70–79 years | 6 (16/276) | 91 | 23.5 | 0.67 (NR) | 0.88 (NR) | NR | NR | 0.8244 (0.71, 0.94)
MoCA | Dementia | Hsu, 2015^*^,^151^ | 7–12 years edu | 6 (16/276) | 118 | 23.5 | 0.80 (NR) | 0.90 (NR) | NR | NR | 0.8465 (0.75, 0.94)
MoCA | Dementia | Hsu, 2015^*^,^151^ | 80 years or more | 6 (16/276) | 14 | 22.0 | 0.73 (NR) | 1.00 (NR) | NR | NR | 0.8788 (0.69, 1.00)
MoCA | Dementia | Hsu, 2015^*^,^151^ | All | 6 (16/276) | 276 | 23.5 | 0.78 (NR) | 0.94 (NR) | NR | NR | 0.8913 (0.83, 0.96)
MoCA | Dementia | Hsu, 2015^*^,^151^ | Men | 6 (16/276) | 136 | 22.5 | 0.84 (NR) | 0.88 (NR) | NR | NR | 0.8882 (0.79, 0.98)
MoCA | Dementia | Hsu, 2015^*^,^151^ | Women | 6 (16/276) | 140 | 23.5 | 0.76 (NR) | 1.00 (NR) | NR | NR | 0.8984 (0.81, 0.99)
MoCA | Dementia | Lee, 2008^161^ | All | 22 (44/196) | 196 | ≤22 | NR | NR | NR | NR | NR
MoCA | Dementia | Markwick, 2012^165^ | All | 8 (8/107) | 107 | <26 | NR | NR | NR | NR | NR
MoCA | MCI | Cummings-Vaughn, 2014^*^,^136^ | All | 42 (57/136) | 108 | ≤24 | 0.72 (NR) | 0.75 (NR) | 0.76 (NR) | 0.70 (NR) | 0.77 (0.68, 0.86)
MoCA | MCI | Cummings-Vaughn, 2014^*^,^136^ | All | 42 (57/136) | 108 | ≤25 | 0.81 (NR) | 0.55 (NR) | 0.67 (NR) | 0.72 (NR) | 0.77 (0.68, 0.86)
MoCA | MCI | Lee, 2008^161^ | All | 19 (37/196) | 152 | ≤22 | 0.89 (NR) | 0.84 (NR) | 0.65 (NR) | 0.96 (NR) | 0.94 (0.90, 0.98)
MoCA | MCI | Markwick, 2012^165^ | All | 19 (20/107) | 99 | <26 | NR | NR | NR | NR | NR
MoCA | Cognitive Impairment | Cummings-Vaughn, 2014^*^,^136^ | All | 62 (85/136) | 136 | ≤24 | 0.80 (NR) | 0.75 (NR) | 0.84 (NR) | 0.69 (NR) | 0.83 (0.77, 0.90)
MoCA | Cognitive Impairment | Cummings-Vaughn, 2014^*^,^136^ | All | 62 (85/136) | 136 | ≤25 | 0.86 (NR) | 0.55 (NR) | 0.76 (NR) | 0.70 (NR) | 0.83 (0.77, 0.90)
MoCA | Cognitive Impairment | Lee, 2008^161^ | All | 41 (81/196) | 196 | ≤22 | NR | NR | NR | NR | NR
MoCA | Cognitive Impairment | Markwick, 2012^165^ | All | 26 (28/107) | 107 | <26 | NR | NR | NR | NR | NR
OT | Dementia | Del Ser, 2006^137^ | All | 12 (48/416) | 416 | NR | 0.958 (NR) | 0.855 (NR) | 0.464 (NR) | 0.993 (NR) | 0.970 (NR)
SBT | Dementia | Ball, 2001^127^ | All | 9 (10/170) (estimated) | 53 | >8 | 0.40 (NR) | 0.89 (NR) | 0.67 (NR) | 0.87 (NR) | NR
SLUMS | Dementia | Tariq, 2006^177^ | HS edu or more | 12 (82/702) | 488 | ≤24.5 | NR | NR | NR | NR | NR
SLUMS | Dementia | Tariq, 2006^177^ | Less than HS edu | 12 (82/702) | 214 | ≤22.5 | NR | NR | NR | NR | NR
SLUMS | MCI | Cummings-Vaughn, 2014^*^,^136^ | All | 42 (57/136) | 108 | ≤26 | 0.74 (NR) | 0.65 (NR) | 0.70 (NR) | 0.69 (NR) | 0.74 (065, 0.84)
SLUMS | MCI | Tariq, 2006^177^ | HS edu or more | 26 (180/702) | 433 | ≤25.5 | 0.95 (NR) | 0.76 (NR) | 0.74 (NR) | 0.93 (NR) | 0.643 (NR)
SLUMS | MCI | Tariq, 2006^177^ | Less than HS edu | 26 (180/702) | 187 | ≤23.5 | 0.92 (NR) | 0.81 (NR) | 0.64 (NR) | 0.97 (NR) | 0.927 (NR)
SLUMS | Cognitive Impairment | Cummings-Vaughn, 2014^*^,^136^ | All | 62 (85/136) | 136 | ≤25 | 0.72 (NR) | 0.75 (NR) | 0.82 (NR) | 0.61 (NR) | 0.82 (0.75, 0.89)
SLUMS | Cognitive Impairment | Tariq, 2006^177^ | HS edu or more | 37 (262/702) | 488 | ≤24.5 | NR | NR | NR | NR | NR
SLUMS | Cognitive Impairment | Tariq, 2006^177^ | Less than HS edu | 37 (262/702) | 214 | ≤22.5 | NR | NR | NR | NR | NR
SMMSE | Dementia | Stein, 2015^*^,^175^ | All | 3 (86/2657) | 2657 | ≤4 | 0.976 (NR) | 0.711 (NR) | 0.101 (NR) | 0.998 (NR) | 0.909 (0.884, 0.935)
Storandt Battery | Dementia | Fillenbaum, 1990^142^ | All | 16 (26/159) | 159 | ≥0 | NR | NR | NR | NR | NR
TICS | Dementia | Lipton, 2003^163^ | All | 9 (27/300) | 300 | 28 | 0.74 (NR) | 0.93 (NR) | 0.34 (NR) | NR | 0.86 (NR)
TICS | Dementia | Manly, 2011^164^ | All | 14 (53/377) | 377 | ≤22 | 0.88 (NR) | 0.87 (NR) | 0.51 (NR) | 0.98 (NR) | 0.94 (NR)
TICS | Cognitive Impairment | Manly, 2011^164^ | All | 32 (121/377) | 377 | ≤26 | 0.73 (NR) | 0.77 (NR) | 0.59 (NR) | 0.86 (NR) | 0.81 (NR)
TICS | Cognitive Impairment | Vercambre, 2010^180^ | All | 23 (28/120) | 120 | NR | NR | NR | NR | NR | 0.78 (NR)
TICS-M | MCI | Cook, 2009^133^ | All | 24 (17/71) | 71 | 34 | 0.824 (NR) | 0.870 (NR) | 0.667 (NR) | 0.940 (NR) | 0.933 (NR)
TICS-M | Cognitive Impairment | Vercambre, 2010^180^ | All | 23 (28/120) | 120 | 31 | 0.71 (NR) | 0.83 (NR) | 0.56 (NR) | 0.90 (NR) | 0.83 (NR)
TYM | MCI | Ozer, 2016^*^,^168^ | All | 26 (40/152) | 152 | <43 | 0.63 (NR) | 0.87 (NR) | 0.35 (NR) | 0.95 (NR) | 0.80 (0.72, 0.88)
Word List Learning - immediate recall | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤3 | 0.82 (NR) | 0.77 (NR) | NR | NR | 0.871 (0.814, 0.928)
Word List Learning - immediate recognition false alarms | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤1 | 0.23 (NR) | 0.77 (NR) | NR | NR | 0.515 (0.401, 0.629)
Word List Learning - immediate recognition hit | Dementia | Heun, 1998^148^ | All | 13 (37/287) | 287 | ≤6 | 0.57 (NR) | 0.71 (NR) | NR | NR | 0.670 (0.562, 0.778)
Word List Recognition | Dementia | Fuchs, 2012^144^ | All | 5 (21/423) | 423 | ≤16 | 0.706 (0.489, 0.922) | 0.933 (0.908, 0.957) | 0.308 (0.163, 0.453) | 0.987 (0.975, 0.998) | 0.881 (0.784, 0.978)

Abbreviations: 7MS = 7 Minute Screen; AMT = Abbreviated Mental Test; AUC = area under the curve; CI = confidence interval; edu = education; FCR = Free and Cued Recall; FOME-abbreviated = Fuld Object Memory Evaluation – abbreviated version; M@T = Memory Alteration Test; MMblind = MMSE version for persons with visual impairment; MMSE = Mini-Mental State Examination; MoCA = Montreal Cognitive Assessment; n = number of participants analyzed; NPV = negative predictive value; NR = not reported; OT = Benton’s Orientation Test; PPV = positive predictive value; SBT = Short Blessed Test; Sens = sensitivity; SLUMS = Veterans Affairs Saint Louis University Mental Status; Spec = specificity; TICS = Telephone Instrument for Cognitive Status; TICS-M = Telephone Interview for Cognitive Status modified; TYM = Test Your Memory

* New study

Table 6 Test Performance of Longer, Self-Administered Screening Instruments, by Instrument and Target Condition (KQ 2)

Test name | Target condition | Author, year | Screened Group | Percent (n/n) with condition | Total n | Cutoff | Sens (95% CI) | Spec (95% CI) | PPV (95% CI) | NPV (95% CI) | AUC (95% CI)
CAMCI | MCI | Saxton, 2009^173^ | All | 44 (228/524) | 524 | NA | 0.86 (NR) | 0.94 (NR) | NR | NR | NR
CAST | Dementia | Swearer, 2002^176^ | All | 17 (8/46) | 46 | ≤33 | 0.88 (NR) | 0.95 (NR) | NR | NR | NR
CIDS | Dementia | Waite, 1998^181^ | All | 28 (99/360) | 360 | 6/7 | 0.89 (NR) | 0.89 (NR) | NR | NR | 0.91 (NR)
IQCODE | Dementia | Cruz-Orduna, 2011^134^ | All | 9 (15/160) | 160 | 95/96 | 0.8000 (NR) | 0.7671 (NR) | 0.2609 (NR) | 0.9739 (NR) | 0.85 (0.76, 0.94)
IQCODE | Dementia | Jorm, 1996^153^ | All | NR | NR | 3.27/3.30 | 0.79 (NR) | 0.65 (NR) | NR | NR | 0.77 (NR)
IQCODE | Dementia | Morales, 1997^167^ | Rural | 13 (34/257) | 160 | 86 | 0.83 (NR) | 0.83 (NR) | 0.45 (NR) | 0.97 (NR) | NR
IQCODE | Dementia | Tokuhara, 2006^178^ | All | 7 (16/230) | 230 | 3.5 | 0.875 (NR) | 0.911 (NR) | 0.424 (NR) | 0.99 (NR) | NR
IQCODE | Cognitive Impairment | Cruz-Orduna, 2011^134^ | All | 56 (90/160) | 160 | 87/88 | 0.7111 (NR) | 0.7429 (NR) | 0.7805 (NR) | 0.6667 (NR) | 0.75 (0.67, 0.82)
IQCODE | Cognitive Impairment | Jorm, 1996^153^ | All | NR | NR | NR | NR | NR | NR | NR | 0.75 (NR)
IQCODE | Cognitive Impairment | Tokuhara, 2006^178^ | All | 17 (39/230) | 230 | 3.5 | 0.739 (NR) | 0.922 (NR) | 0.515 (NR) | 0.969 (NR) | 0.87 (NR)
IQCODE-Short | Dementia | Ayalon, 2011^126^ | All | 32 (206/647) | 647 | >3 | NR | NR | NR | NR | NR
IQCODE-Short | Dementia | Jorm, 1996^153^ | All | NR | NR | 3.31/3.38 | 0.75 (NR) | 0.68 (NR) | NR | NR | 0.77 (NR)
IQCODE-Short | MCI | Ayalon, 2011^126^ | All | 29 (185/647) | 441 | >3 | 0.748 (NR) | 0.690 (NR) | 0.309 (NR) | 0.251 (NR) | 0.77 (NR)
IQCODE-Short | Cognitive Impairment | Ayalon, 2011^126^ | All | 60 (391/647) | 647 | >3 | NR | NR | NR | NR | NR
IQCODE-Short | Cognitive Impairment | Jorm, 1996^153^ | All | NR | NR | NR | NR | NR | NR | NR | 0.74 (NR)
SCIDS | Dementia | Waite, 1998^181^ | All | 28 (99/360) | 360 | 3/4 | 0.83 (NR) | 0.87 (NR) | NR | NR | 0.89 (NR)

Abbreviations: AUC = area under the curve; CAMCI = Computer Assessment of Mild Cognitive Impairment; CAST = Cognitive Assessment Screening Test; CI = confidence interval; CIDS = Concord Informant Dementia Scale; IQCODE = Informant Questionnaire on Cognitive Decline in the Elderly; IQCODE-Short = Informant Questionnaire on Cognitive Decline in the Elderly - short version; MCI = mild cognitive impairment; n = number of participants analyzed; NPV = negative predictive value; NR = not reported; PPV = Positive predictive value; SCIDS = Short Concord Informant Dementia Scale

##### Very Brief Instruments (5 Minutes or Less)

The accuracy of 25 very brief screening tests to identify dementia or cognitive impairment was evaluated in 31 studies (n=22,359) (Table 4). Only eight very brief tests were reported in more than one study (Figure 2). Very brief tests evaluated in only one study are shown in Figure 3; these tests had wide variation in sensitivity and specificity and are not discussed in detail. The eight tests evaluated in at least two studies included six tests administered to patients: the CDT (k=9), MIS/MIS-T (k=5), MSQ/SPMSQ (k=4), Mini-Cog (k=4), verbal fluency (k=6), Lawton IADL (k=2), and two that were informant-based, the AD8 (k=3) and FAQ (k=2). Among all very brief screening tests, sensitivity was generally higher in the detection of dementia compared with the detection of cognitive impairment (inclusive of MCI alone or MCI and dementia diagnoses), although the confidence intervals often overlapped, and the cutoffs were not always adjusted to identify a lower level of impairment. Sensitivity and specificity to detect dementia were above 0.75 (range, 0.43 to 1.0) and 0.80 (range, 0.54 to 1.0) (respectively) for most studies, while sensitivity and specificity to detect cognitive impairment (MCI alone or MCI and dementia diagnoses) were less consistent.

Figure 2 Test Accuracy of Very Brief Screening Tests Reported in More Than One Study (KQ 2)

Abbreviations: AD8 = 8-item informant interview; CDT = Clock Drawing Test; CI = confidence interval; FAQ = Functional Activities Questionnaire; KQ = key question; MCI = mild cognitive impairment; MIS/MIS-T = Memory Impairment Screen/Memory Impairment Screen by Telephone; MSQ/SPMSQ = Mental Health Status Questionnaire/Short Portable Mental Status Questionnaire; NR = not reported.

* MIS-T.

† MSQ.

‡ Informant target.

This figure is a forest plot that shows the test accuracy of very brief screening tests to detect mild cognitive impairment, dementia, or general cognitive impairment. This figure represents evidence for very brief screening tests that were reported in two or more studies.

Figure 3 Test Accuracy of Very Brief Screening Tests Reported in One Study (KQ 2)

Abbreviations: 3-Word = 3-Word Memory Test; ADL = activities of daily living; CI = confidence interval; HVLT = Hopkins Verbal Learning Test; IADL = instrumental activities of daily living; KQ = key question; M@T = Memory Alteration Test; MCI = mild cognitive impairment; MCI = mild cognitive impairment; MF-2 = 2-item functional memory screen; NA = not applicable; OMC = Orientation Memory Concentration; SD = standard deviation; STMS = Short Test of Mental Status; TMT = Trail Making Test; TYM = Test Your Memory; VAT = Visual Association Test

This figure is a forest plot that shows the test accuracy of very brief screening tests to detect mild cognitive impairment, dementia, or general cognitive impairment. This figure represents evidence for very brief screening tests that were reported in only one study.

For the CDT, the sensitivity to detect dementia ranged from 0.75 to 0.98 (95% CI range, 0.61 to 1.0) and specificity ranged from 0.81 to 0.94 (95% CI range, 0.76 to 0.97) (k=4). To detect cognitive impairment, sensitivity ranged from 0.41 to 0.85 (95% CI range, 0.34 to 0.97) and the specificity ranged from 0.44 to 0.83 (95% CI range, 0.33 to 0.87) (k=4). For the Mini-Cog (the CDT plus 3-item word recall), sensitivity ranged from 0.76 to 1.0 (95% CI range, 0.54 to 1.0) to detect dementia (k=4) and from 0.39 to 0.84 (95% CI range, 0.34 to 0.88) to detect cognitive impairment (k=3). Specificity ranged from 0.54 to 0.85 (95% CI range, 0.43 to 0.88) to detect dementia (k=4) and from 0.73 to 0.88 (95% CI range, 0.45 to 0.92) to detect cognitive impairment (k=3). Two studies evaluated the Lawton IADL at various cutoffs (≤4 and 6.5); sensitivity ranged from 0.89 to 0.91 (95% CI range, 0.81 to 0.96) and specificity ranged from 0.81 to 0.86 (95% CI range, 0.80 to 0.89). For the MIS/MIS-T at a cutoff of ≤4, sensitivity to detect dementia ranged from 0.43 to 0.86 (95% CI range, 0.24 to 0.94) and specificity ranged from 0.85 to 0.97 (95% CI range, 0.82 to 0.99) (k=5). Test accuracy did not differ by version (MIS vs. MIS-T), but the study with the lowest prevalence of dementia had the poorest performance. Only one study evaluated the MIS (4-item free and cued recall) to detect cognitive impairment, with sensitivity of 0.17 (95% CI, 0.13 to 0.22) and specificity of 0.98 (95% CI, 0.96 to 0.99) using the same cutoff of ≤4. The MSQ and the SPMSQ (a shorter version derived from the MSQ) were only evaluated to detect dementia with a range in sensitivity of 0.92 to 1.0 (95% CI range, 0.44 to 1.0) and range in specificity of 0.83 to 1.0 (95% CI range, 0.76 to 1.0) (k=4). Test performance did not differ by the version (MSQ vs. SPMSQ). For verbal fluency tests (category or names), sensitivity to detect dementia ranged from 0.68 to 0.98 (95% CI range, 0.48 to 1.0) and specificity ranged from 0.81 to 0.89 (95% CI range, 0.76 to 0.92) (k=5). These studies did not examine the test accuracy to detect cognitive impairment using verbal fluency tests.

Two very brief instruments queried the informant—the AD8 and the FAQ. The AD8 was evaluated in three studies and the FAQ in two. The sensitivity of the AD8 to detect dementia ranged from 0.88 to 0.91 (95% CI range, 0.79 to 0.96) and the specificity ranged from 0.84 to 0.91 (95% CI range, 0.83 to 0.94) (k=2). To detect cognitive impairment, the sensitivity ranged from 0.74 to 0.85 (95% CI range, 0.62 to 0.90)—the lower value corresponding to the assessment of MCI without dementia and the upper value corresponding to cognitive impairment inclusive of MCI and dementia—and the specificity was the same for both at 0.86 (95% CI, 0.78 to 0.91). The sensitivity of the FAQ to detect dementia ranged from 0.87 to 0.94 (95% CI range, 0.62 to 0.98) and the specificity ranged from 0.82 to 0.84 (95% CI, 0.75 to 0.88). To detect cognitive impairment, the sensitivity was 0.73 (95% CI, 0.63 to 0.81) and the specificity was 0.73 (95% CI, 0.61 to 0.82).

##### Brief Instruments (6–10 Minutes)

The accuracy of 20 brief screening tests to identify dementia or cognitive impairment was evaluated in 48 studies (n=29,950) (Table 5). Only six brief tests were evaluated in two or more studies (Figure 4). The other 14 brief tests evaluated in only one study are shown in Figure 5. All six tests that were evaluated in at least two studies were administered to patients and include the MMSE (k=32), 7MS (k=2), AMT (k=5), MoCA (k=5), SLUMS (k=2), and TICS/TICS-M (k=4).

Figure 4 Test Accuracy of Brief Screening Tests Reported in More Than One Study (KQ 2)

Abbreviations: 7MS = 7-Minute Screen; AMT = Abbreviated Mental Test; CI = confidence interval; HS edu = high school education; KQ = key question; MCI = mild cognitive impairment; NR = not reported; SLUMS = Saint Louis University Mental Status Examination; TICS/TICS-M = Telephone Instrument for Cognitive Status/Telephone Interview for Cognitive Status modifie

This figure is a forest plot that shows the test accuracy of brief screening tests to detect mild cognitive impairment, dementia, or general cognitive impairment. This figure represents evidence for brief screening tests that were reported in two or more studies.

Figure 5 Test Accuracy of Brief Screening Tests Reported in One Study (KQ 2)

Abbreviations: CI = confidence interval; FCR = Free and Cued Recall; FOME = Fuld Object Memory Evaluation; MMblind = MMSE version for persons with visual impairment; KQ = key question; MCI = mild cognitive impairment; NR = not reported; SLUMS = Saint Louis University Mental Status Examination; TICS/TICS-M = Telephone Instrument for Cognitive Status/Telephone Interview for Cognitive Status modified

This figure is a forest plot that shows the test accuracy of brief screening tests to detect mild cognitive impairment, dementia, or general cognitive impairment. This figure represents evidence for brief screening tests that were reported in only one study.

The instrument most widely evaluated in the included studies was the MMSE (k=32; n=25,209). The bivariate pooled analysis for the MMSE at a cutoff of 23 or less or 24 or less to identify dementia (≤23 is the recommended cutoff) resulted in a sensitivity of 0.89 (95% CI, 0.85 to 0.92; I^2^=73.8%) and a specificity of 0.89 (95% CI, 0.85 to 0.93; I^2^=97.7%) (k=15, n=12,796) (Figure 6). At cutoffs that were not pooled (≤18 to ≤29.5), the sensitivity of the MMSE to detect dementia ranged from 0.38 to 1.0 (95% CI range, 0.18 to 0.99) and the specificity ranged from 0.67 to 0.96 (95% CI range, 0.53 to 0.99) (Figure 7). To detect cognitive impairment, and at a variety of cutoffs (≤20 to ≤29.5), the sensitivity ranged from 0.20 to 0.93 (95% CI range, 0.06 to 1.0) and specificity ranged from 0.48 to 0.93 (95% CI range, 0.42 to 0.97). Use of a higher cutoff (i.e., higher than the recommended ≤23) does not appear to increase the ability to detect cognitive impairment. The study with the poorest test performance (sensitivity of 0.48 and specificity of 0.48) used a very high cutoff (≤29.5 out of a score of 30).

Figure 6 Bivariate Pooled Analysis of Test Accuracy of the MMSE to Detect Dementia at a Cut-Off of ≥23 or ≥24 (KQ)

Abbreviations: CI = confidence interval; HS edu = high school education; KQ = key question; MMSE = Mini-Mental State Examination

This figure is a forest plot that shows the bivariate pooled test accuracy of the Mini-Mental State Examination to detect dementia at cut-off scores of 23 and 24.

Figure 7 Test Accuracy of the MMSE at Other Cut-Offs (KQ 2)

Abbreviations: CI = confidence interval; HS edu = high school education; KQ = key question; MCI = mild cognitive impairment; MMSE = Mini-Mental State Examination

This figure is a forest plot that shows the test accuracy of the Mini-Mental State Examination to detect dementia at various cut-off scores.

Five additional brief tests were evaluated in more than one study (Figure 4). The sensitivity of the 7MS (n=553) to detect dementia was 1.0 in two studies (95% CI range, 0.77 to 1.0) and specificity ranged from 0.95 to 0.96 (95% CI range, 0.91 to 0.98). For the AMT, sensitivity to detect dementia ranged from 0.92 to 1.0 (95% CI range, 0.16 to 1.0) and the specificity ranged from 0.83 to 0.95 (95% CI range, 0.68 to 0.99) (k=2). For the MoCA, sensitivity to detect dementia ranged from 0.78 to 1.0 (95% CI range, 0.51 to 1.0) and specificity ranged from 0.65 to 0.94 (95% CI range, 0.55 to 0.96) (k=4). To detect cognitive impairment, sensitivity ranged from 0.72 to 0.94 (95% CI range, 0.58 to 0.97) and specificity ranged from 0.75 to 0.84 (95% CI range, 0.61 to 0.90) (k=3). For the SLUMS, to detect dementia, sensitivity for two education subgroups (with different cutoffs selected for each group) ranged from 0.98 to 1.0 (95% CI range, 0.88 to 1.0) and specificity ranged from 0.65 to 0.69 (95% CI range, 0.61 to 0.75). To detect cognitive impairment, sensitivity ranged from 0.74 to 0.95 (95% CI range, 0.61 to 0.98) and specificity ranged from 0.65 to 0.87 (95% CI range, 0.51 to 0.91) (k=2). For the TICS/TICS-M, sensitivity to detect dementia ranged from 0.74 to 0.88 (95% CI range, 0.55 to 0.95) and specificity ranged from 0.87 to 0.93 (95% CI range, 0.83 to 0.95) (k=2). To detect cognitive impairment, sensitivity ranged from 0.71 to 0.82 (95% CI range, 0.53 to 0.94) and specificity ranged from 0.77 to 0.87 (95% CI range, 0.71 to 0.94) (k=3).

##### Longer, Self-Administered Instruments (>10 minutes)

The test accuracy of four longer, self-administered tests was reported in eight studies (n=2,271) (Table 6; Figure 8). The tests were the CAMCI (k=1), CAST (k=1), CIDS/SCIDS (k=1), and IQCODE/IQCODE-Short (k=5).

Figure 8 Test Accuracy of Longer, Self-Administered Tests (KQ 2)

Abbreviations: CAMCI = Computer Assessment of Mild Cognitive Impairment; CAST = Cognitive Assessment Screening Test; CI = confidence interval; CIDS = Concord Informant Dementia Scale; IQCODE = Informant Questionnaire on Cognitive Decline in the Elderly; IQCODE-Short = Informant Questionnaire on Cognitive Decline in the Elderly - short version; MCI = mild cognitive impairment; NA = not applicable; SCIDS = Short Concord Informant Dementia Scale

* Short IQCODE

This figure is a forest plot that shows the test accuracy of longer, self-administered tests to detect MCI, dementia, or general cognitive impairment.

The most common instruments evaluated were the full 26-item IQCODE and the 12-item IQCODE-Short. To screen for dementia, sensitivity ranged from 0.80 to 0.83 (95% CI range, 0.55 to 0.97) and specificity ranged from 0.51 to 0.91 (95% CI range, 0.46 to 0.94) (k=4). For detection of cognitive impairment, sensitivity ranged from 0.71 to 0.82 (95% CI range, 0.54 to 0.87) and specificity ranged from 0.69 to 0.92 (95% CI range, 0.63 to 0.95) (k=3). The other three tests were reported in only one study each and reported sensitivity of 0.83 or higher and specificity of 0.87 or higher to detect dementia or cognitive impairment.

### KQ 3 What Are the Harms of Screening for Cognitive Impairment in Community-Dwelling Older Adults?

The IU CHOICE trial compared symptoms of depression and anxiety among those randomized to screening for dementia vs. those randomized to no screening.^124,^ ^125^ At 1-month postscreening, depressive symptoms (as measured by the PHQ-9) and anxiety symptoms (as measured by the GAD-7) were equivalent between groups after adjusting for baseline values. A similar pattern was evident at 6 and 12 months as well, suggesting no differences in feelings of depression or anxiety following screening for dementia. No data were provided, however, on the proportion of those with screen-detected dementia (7.7%) whom went on for further diagnostic assessment were diagnosed and referred for treatment, a sequalae of events that could presumably influence participants’ moods. Furthermore, within the screening arm, among those who screened positive on either the MIS or the Mini-Cog, 66 percent refused a followup diagnostic assessment.

We found no additional studies that directly addressed potential adverse psychological effects from screening, adverse effects from unnecessary diagnostic testing (workup for false-positives), adverse effects from labeling or treating someone with dementia without diagnostic testing (false-positives without appropriate followup), or adverse effects from missed or delayed diagnosis (false-negatives). Based on the test accuracy studies included for KQ 2, where most very brief tests had a sensitivity of 75 percent or higher and a specificity of 80 percent or higher, very brief tests could result in up to 20 percent false-positives and 25 percent false-negatives among older adults screened for dementia. The brief tests performed somewhat better and would likely yield fewer false-positives and false-negatives; for example, the pooled MMSE resulted in 89 percent sensitivity and 90 percent specificity, which yields approximately 10 percent for both false-positives and false-negatives.

## KQs 4 and 5: Overall Summary of Results for Treatment and Management of Cognitive Impairment

We identified 224 trials representing more than 50,000 patients and/or caregivers and three cohort studies with more than 190,000 patients that addressed the treatment or management of MCI or mild to moderate dementia (Table 7; Appendix C). Forty-eight trials plus three observational studies addressed the benefits and harms of AChEIs and memantine, 29 trials addressed other medications and supplements, 61 trials addressed nonpharmacologic patient-level interventions, and 88 trials addressed caregiver and caregiver-patient dyad interventions (Table 8). Just more than one-third of this evidence (82/224 studies) was newly identified, with most new evidence related to nonpharmacologic patient-level interventions and caregiver interventions. We discuss the benefits and harms of each type of intervention separately due to the broad range of interventions we examined.

Table 7 Trial and Population Characteristics: Summary Across All Intervention Types (KQs 4 and 5)

Intervention Type | No. trials^*^ | No. new studies (%) | No. randomized | No. studies (%) good quality | No. studies (%) conducted in U.S.^‡^ | Median study duration, months (range) | Mean age, years^†^ | No. studies (%) with condition | Mean baseline MMSE | % Female^†^
FDA-approved medication | 48 | 6 (12) | 22,431 | 4 (8)^§^ | 24 (50) | 6 (3–48) | 74 | MCI: 4 (8); Dem: 44 (92) | 19.5 | 55
Donepezil | 18 | 1 (6) | 6,209 | 0 (0) | 11 (61) | 6 (3–36) | 73 | MCI:3 (17); Dem: 15 (83) | 22.0 | 52
Galantamine | 10 | 1 (10) | 7,464 | 0 (0) | 5 (50) | 6 (3–12) | 74 | Dem: 10 (100) | 19.1 | 59
Rivastigmine | 8 | 0 (0) | 4,569 | 0 (0) | 4 (50) | 6 (3–6) | 73 | Dem: 8 (100) | 18.4 | 57
Memantine | 12 | 4 (33) | 4,189 | 4 (33) | 4 (33) | 6 (3–48) | 76 | MCI: 1 (8); Dem: 11 (92) | 17.8 | 49
Other medication or supplement | 29 | 5 (17) | 6,489 | 6 (21) | 16 (55) | 12 (3–48) | 75 | MCI: 5 (17); Dem: 23 (79); MCI/Dem: 1 (3) | 22.3 | 52
Antihypertensives | 1 | 1 (100) | 385 | 0 (0) | 0 (0) | 4 (NA) | 81 | MCI: 1 (100) | 26.0 | 59
HMG-CoA Reductase Inhibitors | 4 | 0 (0) | 1,153 | 0 (0) | 3 (75) | 12 (6–18) | 74 | Dem: 4 (100) | 21.2 | 54
Dietary Supplements | 14 | 3 (21) | 3,777 | 4 (29) | 7 (50) | 12 (4–48) | 75 | MCI: 4 (29); Dem: 9 (64); MCI/Dem: 1 (7) | 23.0 | 46
Gonadal Steroids | 6 | 1 (17) | 337 | 1 (17) | 4 (67) | 6 (3–12) | 76 | Dem: 6 (100) | 20.1 | 95
NSAIDs | 4 | 0 (0) | 837 | 1 (25) | 2 (50) | 12 (12–12) | 74 | Dem: 4 (100) | 20.1 | 56
Patient | 61 | 39 (64) | 7,847 | 13 (21) | 13 (21) | 6 (3–26) | 76 | MCI: 25 (41); Dem: 28 (46); MCI/Dem: 8 (13) | 23.1 | 59
Cognitive Training, Stimulation, or Rehabilitation | 28 | 17 (61) | 3,212 | 5 (18) | 6 (21) | 6 (3–26) | 76 | MCI: 12 (43); Dem: 14 (50); MCI/Dem: 2 (7) | 23.3 | 57
Exercise Interventions | 21 | 14 (67) | 2,831 | 6 (29) | 4 (19) | 6 (3–18) | 75 | MCI: 9 (43); Dem: 9 (43); MCI/Dem: 3 (14) | 23.4 | 62
Multicomponent and Other Interventions | 16 | 12 (75) | 2,302 | 2 (12) | 4 (25) | 6 (3–24) | 76 | MCI: 7 (44); Dem: 6 (38); MCI/Dem: 3 (19) | 22.8 | 59
Caregiver | 88 | 33 (38) | 14,880 | 13 (15) | 40 (45) | 9 (3–144) | 78 | MCI: 0; Dem: 84 (95); MCI/Dem: 4 (5) | 17.6 | 56
Psychoeducation Interventions | 58 | 24 (41) | 9,139 | 6 (10) | 28 (48) | 6 (3–144) | 78 | Dem: 56 (97); MCI/Dem: 2 (3) | 16.2 | 54
Care/Case Management | 17 | 6 (35) | 3,039 | 4 (24) | 6 (35) | 12 (6–24) | 79 | Dem: 15 (88); MCI/Dem: 2 (12) | 19.8 | 58
Other Interventions | 13 | 3 (23) | 2,702 | 3 (23) | 6 (46) | 12 (3–24) | 79 | Dem: 13 (100) | 19.1 | 57
Total | 224 | 82 (37) | 50,265 | 35 (16) | 91 (41) | 6 (3–144) | 76 | MCI: 33 (15); Dem: 178 (79); MCI/Dem: 13 (6) | 19.9 | 56

* Studies can be counted in more than one intervention type.

† Values reported for patients (not caregivers)

‡ Including studies that were conducted in multiple countries, of which the US was one country.

§ 27 of these studies originated from a systematic review that was included in the previous review and were not quality rated again. For this table, they were all counted as “fair.”

Abbreviations: Dem = dementia; FDA = US Food and Drug Administration; HMG-CoA = β-Hydroxy β-methylglutaryl-CoA; MCI = mild cognitive impairment; MMSE = Mini-Mental State Examination; No. = number; NSAIDs = nonsteroidal anti-inflammatory drugs

Table 8 Intervention Characteristics: Summary Across All Intervention Types (KQs 4 and 5)

Intervention Category | Intervention Type | No. Trials^*^ | Summary of Intervention Characteristics | Median (Range) of Intervention Duration, Months | Summary of Control Group Characteristics
AChEIs and Memantine (k=48) | Donepezil | 18 | Daily dosage ranged from 1 to 10 mg, with most trials using 5 to 10 mg per day. | 6 (3–12) | Placebo controlled.
AChEIs and Memantine (k=48) | Galantamine | 10 | Daily dosage ranged from 8 to 36 mg, with most trials used 16 to 24 mg per day. | 6 (4–24) | Placebo controlled.
AChEIs and Memantine (k=48) | Rivastigmine | 8 | Daily dosage of oral rivastigmine ranged from 1 to 12 mg, with considerable variability in daily dosage. Three trials examined the rivastigmine patch, with daily dosages of 9.5 mg, 12 mg and 17.4 mg. | 6 (3–6) | Placebo controlled.
AChEIs and Memantine (k=48) | Memantine | 12 | Daily dosage of 20 mg. In two trials, both intervention and control participants were also given galantamine (24 mg) or rivastigmine (9.5 mg). | 6 (3–48) | Placebo controlled, except for one open-label study. Two studies gave all participants an additional AChEI.
Other Medications and Supplements (k=29) | Antihypertensive | 1 | Discontinuation of antihypertensive medication. | 4 (NA) | Usual care consisting of continuation of antihypertensive treatment.
Other Medications and Supplements (k=29) | HMG-CoA Reductase Inhibitors | 4 | Two studies of Atorvastatin (80 mg daily dosage), and two studies of Simvastatin (daily dosages ranged from 40–80 mg). | 14 (6–18) | Placebo controlled, except for one study of Atorvastatin in which participants received 10 mg of Donepezil along with a placebo.
Other Medications and Supplements (k=29) | NSAIDs | 4 | Four studies of different NSAIDs: One study of Celecoxib (400 mg daily dosage), one study of Ibuprofen (800 mg daily dosage), one study of Indomethacin (100 mg daily dosage) and omeprazole (20 mg daily dosage), and one study of Naproxen (440 mg daily dosage). | 12 (12–12) | Placebo controlled, except for one study of Indomethacin that provided control participants with omeprazole (20 mg) along with a placebo, and another study of Ibuprofen that provided control participants with esomeprazole (20 mg).
Other Medications and Supplements (k=29) | Gonadal Steroids | 6 | Four studies of estrogen (daily dosage ranging from 0.625–120 mg). One study of estrogen and progestin (1.5 mg daily dosage) and one study of testosterone (75 mg daily dosage). | 9 (3–12) | Placebo controlled.
Other Medications and Supplements (k=29) | Dietary Supplements | 14 | Four studies of B vitamins (variable combinations and daily dosages of B vitamins and folic acid).; Three studies of vitamin E with daily dosages ranging from 1,000 to 2,000 IU.; Six studies of omega-3 fatty acids (variable combinations and doses of DHA, EPA, and LA).; One study of multivitamins (daily dosage: mecobalamin [0.5 mg] + multivitamin supplement that contained folic acid, pyridoxine HCl, ferrous [60 mg], nicotinamide [10 mg], calcium carbonate [250 mg], riboflavin [2 mg], thiamine mononitrate [3 mg], calcium pantothenate [1 mg], ascorbic acid [100 mg]). | 10 (4–48) | Placebo controlled, except for four studies: One study of b vitamins provided participants with an AChEI along with a placebo. Two studies of omega-3 fatty acids provided participants with dietary supplements along with or included in the placebo; one placebo containing safflower oil (containing 2.2 g linoleic acid) and the other containing isocaloric oil (1 g corn oil, 0.6 g linoleic acid). One study of vitamin E provided participants with a multivitamin containing 15 IU vitamin E along with a placebo.
Nonpharmacologic Patient-Level Interventions (k=61) | Cognitive Training, Cognitive Stimulation, or Cognitive Rehabilitation | 28 | Interventions that directly or indirectly targeted cognitive functioning through cognitive stimulation (engaging the person with CI in a range of activities and discussions aimed at general enhancement of cognitive and social functioning), cognitive training (guided practice on a set of standardized tasks designed to reflect particular cognitive functions such as memory, attention, or problem-solving), and/or cognitive rehabilitation (setting personally relevant goals related to performance in everyday life with patient and family and devising strategies to address these). Most cognitive-focused activities were group-based interventions, but the intensity of activities varied considerably from 1 day a week for 6 weeks to 5 days a week for up to two years with most sessions ranging from 45 to 90 minutes per session. Most common interventionists were trained psychologists or neuropsychologists. Four studies tested computer-based cognitive training programs. | 3 (1–24) | Highly variable ranging from no intervention or waitlist (11 trials), usual care not including cognitive-focused activities (7 trials), brief interventions including psychoeducation and social support (3 trials), and “sham” cognitive-focused activities (7 trials).
Nonpharmacologic Patient-Level Interventions (k=61) | Exercise Interventions | 21 | Most exercise interventions included supervised group-based exercise sessions focused on aerobic activities, strength and resistance training, and/or balance training that took place in a community setting and were led by an exercise specialist. Four trials included individualized, supervised exercise sessions in the home or community setting whereas three trials encouraged self- or caregiver-guided exercises at home. Two trials evaluated the effectiveness of a group-based ballroom dancing intervention and one trial evaluated the impact of Tai Chi. Most interventions took place for 2–3 days per week for 30 minutes to 2 hours per session. | 6 (3–12) | Over half of the trials provided attention control groups including general health education relevant for older adults or brief interventions including supervised “sham” exercise sessions focused on stretching or toning (k=12). In the remaining trials, control groups received usual care with or without being offered the intervention at the end of the trial (k=9).
Nonpharmacologic Patient-Level Interventions (k=61) | Multicomponent and Other Interventions | 16 | Interventions in this group were all unique. Two trials included multicomponent interventions consisting of combined exercise with cognitive training or cognitive behavioral therapy and support groups. Three trials targeted patient well-being through diagnostic support and in-home counseling, group-based psychoeducation, and a self-management program and the remaining trial focused on vascular care through pharmacological and nonpharmacological interventions. | 6 (2–24) | Highly variable, ranging from usual care provided by general practitioners (k=4); minimal or sham interventions (k=5); attention-control interventions (k=2); waitlist (k=4); or no intervention (k=1).
Caregiver and Caregiver-Patient Dyad Interventions (k=88) | Psychoeducation Interventions | 58 | Wide range of approaches with the most common format consisting of interventionists meeting individually with caregivers, dyads, or families, most commonly in participants’ homes; however, a substantial number of interventions took place in group settings or were provided remotely through telephone counseling, computer-based programs or applications, videos, or a combination of these methods. Most interventions provided information about dementia and community resources and also included training in problem solving, communication techniques, and stress management. A variety of additional components were used, including peer or social support, supportive counseling, home safety assessments or information, occupational therapy, and environmental modifications. The interventionists were highly variable, including general educators or counselors, psychologists, nurses, occupational therapists, social workers, and hired and trained research staff. Most interventions involved multiple modes of delivery and included 10–15 sessions, with each session ranging from 30- to 120-minutes. | 4 (1–24) | Highly variable, ranging from no intervention or waitlist (k=19); attention-control interventions (k=3); brief interventions (k=12) primarily consisting of basic educational materials about dementia caregiving (k=8), information on local resources (k=2), and some providing additional brief (10–15-min) telephone support calls with research staff or a social worker (k=3); minimal interventions (k=15) that were similar to the brief interventions, but had more intensive (20–60 min) telephone calls offering social support and tips for behavior management; and usual care interventions (k=39) consisting of standard care provided to dementia caregivers, which varied largely by country.
Caregiver and Caregiver-Patient Dyad Interventions (k=88) | Care/Case Management | 17 | Interventions included professional assistance to help arrange, implement, or facilitate services to meet a patient’s and family’s needs and generally all provided assessment, advice and information, individualized treatment planning, caregiver psychoeducation and skills training, ongoing monitoring, and either referral or care coordination with outside social and health care services (such as occupational and physical therapy, respite care, personal care assistance, social, and social work). Interventionists varied, but most often included a nurse or other health provider serving as a “case manager” or “care coordinator.” | 12 (3–24) | Minimal interventions (k=5) involving enhanced usual care (k=3) and in-home visits by occupational therapists and primary care staff (k=2). The remaining control groups received usual care (k=12) consisting of standard care provided to dementia caregivers, which varied largely by country.
Caregiver and Caregiver-Patient Dyad Interventions (k=88) | Other Interventions | 13 | Interventions in this group were all unique. Interventions included:; Physical activity counseling for the caregiver (k=3) provided in-person and remotely by educators/counselors or was entirely self-administered. Multicomponent dyadic intervention (k=2) delivered at home by psychologists or home health specialists.; Social support only (k=3) delivered at home or community settings by peers and trained research staff.; Assessment and treatment planning or multidisciplinary assessment only (k=3) delivered in medical settings by primary care staff.; Provider training (k=1) delivered at home by nurses or psychologists.; Transcendental meditation (k=1) delivered in community settings by a educators/counselors. | 6 (2–24) | Variable, included attention-control (k=1) or no intervention (k=4); usual care (k=5) of standard care provided to dementia caregivers, which varied largely by country; a brief intervention (k=1) monthly mailings of general information and three brief emotional support telephone calls and minimal interventions (k=2), which varied by intervention type (exercise – pedometer provided; multidisciplinary assessment – biweekly telephone contact).

* Studies can be counted in more than one intervention type.

Abbreviations: AChEI = acetylcholinesterase inhibitor; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; HMG-CoA = β-Hydroxy β-methylglutaryl-CoA; IU = International Unit; k = number of trials analyzed; LA = linoleic acid; mg = milligrams; No. = number; NSAIDs = nonsteroidal anti-inflammatory drugs

Overall, based on 48 trials (n=22,431) that evaluated AChEIs (i.e., donepezil [k=18; n=6,209], galantamine [k=10; n=7,464], rivastigmine [k=8; n=4,569]), and memantine (k=12; n=4,189), these medications may improve measures of global cognitive function in the short term, but the magnitude of change is small. In meta-analyses, the differences in changes between those on AChEIs or memantine compared with those on placebo ranged from approximately 1 to 2.5 points on the ADAS-Cog-11 (scale range, 0 to 70) and 0.5 to 1 points on the MMSE (scale range, 0 to 30) over 3 months to 3 years of followup (Table 9). There was no clear pattern of effects across outcomes that suggested greater benefit of one medication over another. AChEIs and memantine appeared to increase the likelihood of improving or maintaining patients’ global function by 15 percent (for memantine) to 50 percent (for rivastigmine) in the short term (pooled 95% CI range, 0.49 to 2.69); change at longer followup was not reported. Outcome measures of physical function were only reported in about half the trials and showed mixed results. Other important measures such as neuropsychiatric symptoms and rates of institutionalization were rarely reported; no medication trials included measures of QOL. Only eight trials of medications examined outcomes beyond 6 months, and generally found persistent effects that were consistent with outcomes from shorter timeframes.

Table 9 Meta-Analyses Results: Summary Across All Intervention Types (KQs 4 and 5)

Main intervention category | Intervention type | Outcome | Pooled mean difference in change^*^ | 95% CI^†^ | k | N | I ^2^ | Tau
FDA Medications | Donepezil | GCF – ADAS-Cog | −2.13 | −3.32 to −0.94 | 6 | 1,981 | 64.4 | 0.90
FDA Medications | Donepezil | GCF – MMSE | 1.24 | 0.81 to 1.67 | 12 | 3,192 | 65.3 | 0.57
FDA Medications | Donepezil | GF (cont) | −0.24 | −0.39 to −0.09 | 8 | 3,302 | 70.7 | 0.15
FDA Medications | Donepezil | GF (dichot) | 1.33 | 1.07 to 1.66 | 9 | 2,440 | 77.4 | 0.23
FDA Medications | Donepezil | SAEs | 1.18 | 0.99 to 1.40 | 12 | 4,045 | 0.0 | 0
FDA Medications | Donepezil | Withdrawals | 1.88 | 1.54 to 2.29 | 13 | 4,124 | 8.8 | 0
FDA Medications | Galantamine | GCF – ADAS-Cog | −2.13 | −2.94 to −1.32 | 9 | 3,786 | 65.9 | 0.84
FDA Medications | Galantamine | GCF – MMSE | NA | NA | 1 | 1,765 | NA | NA
FDA Medications | Galantamine | GF (cont) | NA | NA | 1 | 126 | NA | NA
FDA Medications | Galantamine | GF (dichot) | 1.21 | 1.11 to 1.31 | 8 | 3,486 | 56.2 | 0.07
FDA Medications | Galantamine | SAEs | 1.06 | 0.88 to 1.29 | 7 | 4,987 | 0.0 | 0
FDA Medications | Galantamine | Withdrawals | 1.98 | 1.52 to 2.57 | 10 | 6,147 | 51.1 | 0.28
FDA Medications | Rivastigmine | GCF – ADAS-Cog | −2.43 | −4.10 to −0.75 | 5 | 2,618 | 81.9 | 1.21
FDA Medications | Rivastigmine | GCF – MMSE | 0.88 | 0.28 to 1.49 | 6 | 2,415 | 44.9 | 0.39
FDA Medications | Rivastigmine | GF (cont) | −0.14 | −0.43 to 0.15 | 6 | 2,535 | 85.7 | 0.25
FDA Medications | Rivastigmine | GF (dichot) | 1.49 | 1.13 to 1.98 | 5 | 1,934 | 61.4 | 0.16
FDA Medications | Rivastigmine | SAEs | 1.15 | 0.87 to 1.52 | 6 | 2,619 | 10.4 | 0
FDA Medications | Rivastigmine | Withdrawals | 2.21 | 1.43 to 3.42 | 8 | 3,131 | 57.0 | 0.38
FDA Medications | Memantine | GCF – ADAS-Cog | −0.88 | −1.65 to −0.11 | 8 | 2,609 | 78.1 | 0.69
FDA Medications | Memantine | GCF – MMSE | 0.36 | −0.31 to 1.04 | 5 | 1,217 | 33.2 | 0.27
FDA Medications | Memantine | GF (cont) | −0.14 | −0.33 to 0.05 | 5 | 1,396 | 32.9 | 0.09
FDA Medications | Memantine | GF (dichot) | 1.15 | 0.49 to 2.69 | 2 | 545 | 0.0 | 0
FDA Medications | Memantine | SAEs | 0.88 | 0.77 to 1.01 | 10 | 3,350 | 0.0 | 0
FDA Medications | Memantine | Withdrawals | 1.26 | 0.94 to 1.70 | 9 | 3,288 | 0.0 | 0
Nonpharm Patient Level | Cognitive Stimulation and Training | GCF – ADAS-Cog | −0.66 | −1.60 to 0.29 | 8 | 842 | 0 | 0
Nonpharm Patient Level | Cognitive Stimulation and Training | GCF – MMSE | 1.33 | 0.29 to 2.37 | 15 | 1,384 | 91.1 | 1.91
Nonpharm Patient Level | Exercise | GCF – ADAS-Cog | −1.05 | −3.49 to 1.10 | 6 | 1,071 | 77.4 | 1.62
Nonpharm Patient Level | Exercise | GCF – MMSE | 1.17 | 0.45 to 1.90 | 10 | 1,168 | 81.3 | 0.98
Nonpharm Patient Level | Multicomponent and Other Interventions | GCF – ADAS-Cog | −1.66 | −10.03 to 6.72 | 2 | 167 | 56.5 | 0.72
Nonpharm Patient Level | Multicomponent and Other Interventions | GCF – MMSE | 0.26 | −0.54 to 1.00 | 8 | 1,238 | 30.3 | 0.55
Caregiver | Psychoeducation Interventions | CGR burden | −0.24 | −0.36 to −0.13 | 27 | 2,776 | 50.2 | 0.20
Caregiver | Psychoeducation Interventions | CGR depression | −0.26 | −0.39 to −0.13 | 37 | 4,555 | 76.9 | 0.35
Caregiver | Care or Case Management | CGR burden | −0.54 | −0.96 to −0.12 | 8 | 1,215 | 82.9 | 0.45
Caregiver | Care or Case Management | CGR depression | −0.13 | −0.39 to 0.12 | 4 | 668 | 0.0 | 0
Caregiver | Other Caregiver or Caregiver-Patient Dyad Interventions | CGR burden | −0.30 | −2.26 to 1.36 | 5 | 459 | 89.6 | 1.36
Caregiver | Other Caregiver or Caregiver-Patient Dyad Interventions | CGR depression | −0.00 | −0.34 to 0.34 | 5 | 645 | 53.7 | 0.20

* For dichotomous outcomes, this represents a RR.

† For analyses with <10 studies, the REML method was used to calculate the CI.

Abbreviations: ADAS-Cog = Alzheimer’s Disease Assessment Scale-Cognitive Subscale; CGR = caregiver; CI = confidence interval; cont = continuous; dichot = dichotomous; FDA = US Food and Drug Administration; GCF = global cognitive function; GF = global function; k = number of trials analyzed; MMSE = Mini-Mental State Examination; n = number of participants analyzed; Nonpharm = nonpharmacological; SAEs = serious adverse events

Most of the available evidence on the effectiveness of FDA-approved medications came from trials involving persons with dementia, particularly among those with moderate vs. mild forms of dementia, mostly commonly AD. Four trials (n=1,919) tested these medications in persons with MCI; these trials, testing donepezil and memantine, showed no benefit on global cognitive function. The mean age of participants across medication trials was 74 years. Only one trial reported an outcome of progression of MCI to AD, finding no differences in the rate of conversion between those on donepezil vs. placebo at 3 years.

Overall, side effects from these medications were quite common. AEs were reported in all 48 trials (n=22,431) in addition to 3 large observational studies (n=190,076). Discontinuation was more common with AChEIs than placebo (13% withdrew for donepezil and rivastigmine, 14% for galantamine, and 8% for placebo) (Table 9). Total AEs were also statistically significantly higher for all three types of AChEIs vs. placebo. In trials that tested various doses of medications, there was some evidence of slightly higher total AEs and withdrawals among arms receiving the higher doses than among those with a lower dose (i.e., 10 mg vs. 5 mg donepezil, 32 mg vs. 24 mg galantamine, and 6–12 mg vs. 1–4 mg rivastigmine), although no formal tests of differences between these groups were reported. Memantine appeared to be better tolerated (8% withdrew), with no difference in discontinuation rates or total AEs compared with placebo. Overall, there did not appear to be a difference in total SAEs for these medications across trials with limited duration of followup. However, individual studies, including observational evidence, reported increased rates of bradycardia, and relatedly, of syncope, falls, and need for pacemaker placement among those exposed vs. unexposed to AChEIs.

Twenty-nine trials (n=6,489) evaluated other medications or supplements, including antihypertensives, HMG-CoA reductase inhibitors (atorvastatin and simvastatin), NSAIDs (ibuprofen, naproxen, indomethacin, and celecoxib), gonadal steroids (estrogen [plus or minus progesterone] and testosterone), and dietary supplements and vitamins (multivitamins, B vitamins, vitamin E, and omega-3 fatty acids). None of these had any benefit on global cognition or physical function in persons with mild to moderate dementia or MCI (mean age, 75 years). Twenty-one of the trials (n=5,688) reported on harms, with harms not clearly significantly increased in intervention groups compared with control groups.

We identified 61 trials (n=7,847) that evaluated nonpharmacologic patient-level interventions, including cognitive-focused, exercise, and multicomponent and other interventions. In general, these trials were quite small and of limited duration. The body of evidence represented both persons with dementia and those with MCI, with a mean age of 76 years across trials. Among all interventions, there was no clear benefit on global or domain-specific measures of cognitive function compared with control conditions at 3 months to 2 years followup among persons with MCI or dementia (Table 9). Effect estimates generally favored the intervention groups over control groups, but the magnitude of effect was inconsistent across trials and represented very wide confidence intervals (ranging from no effect to a large effect). While a pooled analysis of cognitive training, stimulation, and rehabilitation intervention trials found a small, statistically significant mean difference of 1.33 points on MMSE scores (95% CI, 0.29 to 2.37; k=15) favoring cognitive-focused interventions compared with control conditions at 3 to 12 months followup, there was substantial clinical and statistical heterogeneity given these inconsistencies. Furthermore, combining eight trials that reported change in ADAS-Cog scores found a slightly greater improvement of 0.66 points (scale range, 0 to 70, where higher scores indicate greater cognitive impairment) among intervention vs. control group participants, but this difference was not statistically significant (mean difference [MD], −0.66 [05% CI, −1.60 to 0.29]). There was no evidence that the effect of the interventions was modified based on study, population, or intervention characteristics and no evidence of longer-term effects (up to 2 years) on cognitive function. Physical function outcomes, including change in ADLs and IADLs, as well as QOL and mental and neuropsychiatric symptoms, were inconsistently reported. Cognitive training, stimulation, and rehabilitation interventions consistently resulted in very little change over time in both intervention and control groups or small and relatively equal decline in these measures from baseline to 3 months to 2 years, and few trials reported any statistically significant benefit. For trials of exercise interventions, pooled, conservative estimates of differences in measures of global cognitive function show no to small effects based on the MMSE (MD, 1.17 [95% CI, 0.45 to 1.90]; k=10; n=1,168) and ADAS-Cog (MD, −1.05 [95% CI, −1.60 to 0.29]; k=8; n=1,071) at 3 to 12 months followup. There was, however, a pattern of effect for exercise interventions, with small improvements seen in measures of physical function and symptoms for intervention groups, whereas control groups reported worsening function. The clinical meaningfulness of these differences, however, and the possibility of selective reporting limit this finding. There was no consistent benefit of multicomponent and other patient-level interventions across outcomes. Little harm was evident in the few (k=12; n=2,370) trials that reported harms.

Finally, we included 88 trials (n=14,880) that evaluated the effect of multiple types of caregiver or caregiver-patient dyad interventions. Most of the caregiver and caregiver-patient dyad trials randomized more than 100 participants or dyads, and almost half of the trials took place in the United States (40/88). These trials followed participants for slightly longer durations than the patient-focused intervention trials, with just about half of the trials following participants for 1 year or longer. More than half of the trials targeted caregivers only, while the remaining targeted both the patient and caregiver or the entire family. Almost all included evidence pertaining to patients (or their caregivers) with dementia; very few had evidence pertaining to patients with MCI. Also, most trials represented patients with moderate as opposed to mild dementia, with a mean age across trials of 78 years.

Overall, there was a consistent benefit of psychoeducation and care and case management interventions on caregiver burden and depression outcomes (Table 9). Effect sizes were mostly small, however, and were of unclear clinical significance. Psychoeducation interventions resulted in a small but statistically significant benefit on caregiver burden at 3 to 12 months (standardized mean difference [SMD], −0.24 [95% CI, −0.36 to −0.13]; k=27; n=2,776; I^2^=50.2%) and a medium effect on caregiver burden was seen for care and case management interventions (SMD, −0.54 [95% CI, −0.85 to −0.22]; k=8; n=1,215; I^2^=82.9%). The clinical importance of these changes in self-reported caregiver burden scores is unclear, however, with these standardized effects translating to a between-group difference of approximately 2 to 4 points on the Zarit-22 (scale range, 0 to 88), the equivalent of changing from being bothered “always” to “sometimes” or “almost never” on one or two of the 22 items. Similarly, small effect sizes were seen for caregiver depression outcomes. Across both outcomes and across trials, the 95% confidence intervals of the study-level between-group differences were often wide, suggesting a range in benefit (or lack thereof) across participants. There was no evidence in our meta-regressions that one type of intervention (psychoeducation vs. care or case management vs. other caregiver or caregiver-patient dyad interventions) was more effective than the others on measures of caregiver burden or caregiver depression. Likewise, there were no study, population, or intervention characteristics that consistently and robustly predicted larger effects on caregiver burden or depression outcomes.

Other outcomes such as caregiver or patient QOL, rates or time to institutionalization, patient mental health and neuropsychiatric symptoms, and patient functional ability were sparsely reported across the trials with no consistent evidence of a benefit. Decision making and preparation for meeting dementia-related needs were only reported by one trial each, with neither finding statistically significant benefit of the interventions vs. control conditions on overall scores for these measures. Only four trials (n=486) reported monitoring harms related to the intervention, and no harms were evident.

### KQ 4 Do Interventions for Mild to Moderate Dementia or MCI in Community-Dwelling Older Adults Improve Decision Making, Patient, Family/Caregiver, or Societal Outcomes?

### KQ 5 What Are the Harms of Interventions for Mild to Moderate Dementia or MCI in Community-Dwelling Older Adults?

#### Pharmacological Interventions

##### AChEIs and Memantine

In all, 48 fair- to good-quality RCTs (n=22,431) evaluated the effectiveness and harms of AChEIs or memantine for cognitive impairment. We identified 18 donepezil trials (n=6,209),^186–203^ 10 galantamine trials (n=7,464),^204–213^ eight rivastigmine trials (n=4,569),^214–221^ and 12 memantine trials (n=4,189).^222–233^ Six trials are new, including one on donepezil,^191^ one on galantamine,^207^ and four on memantine.^223,^ ^224,^ ^226,^ ^229^ Three additional, large observational studies (n=190,076), including one new study, evaluated harms related to AChEIs.^234–236^

The primary effectiveness outcomes for trials of pharmacologic interventions were measures of global cognitive function and global function (often referred to as overall dementia severity). The ADAS-Cog-11 and MMSE were the most commonly used instruments for assessing global cognitive function. The ADAS-Cog-11 consists of 11 parts, including a word recall task, naming objects and fingers, following commands, constructional praxis, ideational praxis, orientation, word recognition task, remembering test directions, spoken language, comprehension, and word-finding difficulty. The total score ranges from 0 to 70 and captures the errors for each task; the greater the cognitive impairment, the greater the score. The MMSE combines scores from the five cognitive domains of orientation (10 points), memory (3 points for registration and 3 points for recall), attention/calculation (5 points), language (8 points), and visuospatial abilities (1 point) for a total score ranging from 0 to 30, where lower scores indicate greater cognitive impairment. Global function was almost exclusively reported as a measure of the clinician’s impression of change, typically assessed with the CIBIC+. The CIBIC+ is a comprehensive global measure of detectable change in cognition, function, and behavior based on separate interviews with the patient and an informant. Clinicians assess any change in the patients’ condition from baseline with a score ranging from 1 to 7, where 1 is very much improved, 4 is no change, and 7 is very much worse. Other measures of global function such as the Global Deterioration Scale (a clinician’s rating based on cognitive change only) were less commonly used. Less than half of the trials of pharmacotherapy reported the effects of the medications on patients’ physical function and mental or neuropsychiatric symptoms and no studies reported the effects on QOL. Harms-related outcomes were reported by all the included trials.

Study, population, and intervention characteristics of all included studies are presented in Table 10 and Table 11. A summary of results is provided in Table 12 and detailed results for each outcome are provided in Appendix E.

Table 10 AChEIs and Memantine: Study Characteristics, by Medication Type (KQs 4 and 5)

Medication | Author, year (Study name) | Quality | Country | N randomized | Population | Baseline MMSE, mean | Age, mean | Female, %
Donepezil | Black, 2003^186^ (Donepezil 307 Vascular Dementia Study Group) | Fair-Good | US, GBR, AUS, CAN, DEU, IRL | 603 | Dem | 21.8^†^ | 74 | 45
Donepezil | Burns, 1999^187^ | Fair-Good | GBR, AUS, BEL, CAN, FRA, DEU, IRL, NZL, ZAF | 818 | Dem | 20 | 72 | 57
Donepezil | Doody, 2009^188^ | Fair | US | 821 | MCI | 27.5 | 70 | 46
Donepezil | Feldman, 2001^189^ | Fair-Good | AUS, CAN, FRA | 290 | Dem | 11.8^‡^ | 74 | 61
Donepezil | Holmes, 2004^190^ | Fair-Good | GBR | 96 | Dem | 21 | 79 | 62
Donepezil | Ikeda, 2015^*^,^191^ | Fair | JPN | 142 | Dem | 20.4 | 78 | 58
Donepezil | Krishnan, 2003^192^ | Fair-Good | US | 67 | Dem | 19.3 | 73 | 72
Donepezil | Mazza, 2006^193^ | Fair-Good | ITA | 51 | Dem | 18.7 | 68 | 54
Donepezil | Mohs, 2001^194^ | Fair | US | 431 | Dem | 17.1 | 75 | 63
Donepezil | Mori, 2012^195^ | Fair | JPN | 140 | Dem | 19.6 | 79 | 66
Donepezil | Petersen, 2005^196^ | Fair | US, CAN | 769 | MCI | 27.3 | 73 | 46
Donepezil | Rogers, 1996^198^ | Fair-Good | US | 161 | Dem | 18.8 | 72 | 60
Donepezil | Rogers, 1998^197^ (Donepezil Study Group) | Fair-Good | US | 468 | Dem | 19.5 | 74 | 64
Donepezil | Salloway, 2004^199^ (Donepezil 401 MCI Study) | Fair-Good | US | 269 | MCI | 27.4 | 72 | 42
Donepezil | Seltzer, 2004^200^ (Donepezil 402 Study) | Fair-Good | US | 153 | Dem | 24.2 | 74 | 54
Donepezil | Tune, 2003^201^ | Fair-Good | US | 28 | Dem | 21.1 | 73 | 75
Donepezil | Wilkinson, 2003^202^ (Donepezil 308 Study) | Fair-Good | US, GBR, AUS, CAN, DEU, IRL | 616 | Dem | 21.8 | 75 | 40
Donepezil | Winblad, 2001^213^ (Donepezil Nordic Study Group) | Fair-Good | DNK, FIN, NLD, NOR, SWE | 286 | Dem | 19.3 | 72 | 46
Galantamine | Auchus, 2007^204^ (GAL-INT-26) | Fair | US | 788 | Dem | 20.3 | 72 | 36
Galantamine | Brodaty, 2005^205^ (GAL-INT-10) | Fair-Good | US, AUS, CAN, NZL, ZAF | 971 | Dem | 18 | 76 | 64
Galantamine | Erkinjuntti, 2002^206^ (GAL-INT-6) | Fair-Good | GBR, CAN, DNK, FIN, FRA, DEU, IRL, ISR, NLD, POL | 592 | Dem | 20.5 | 75 | 47
Galantamine | Hager, 2014^*^,^207^ | Fair | CZE, FRA, DEU, GRC, ITA, LTU, RUS, SVK, EST, LVA, SVN, ROU, UKR | 2045 | Dem | 19 | 73 | 65
Galantamine | Raskind, 2000^208^ (Galantamine USA - Study Group (GAL-USA-1)) | Fair-Good | US | 636 | Dem | 19.3 | 75 | 62
Galantamine | Rockwood, 2001^210^ (GAL-INT-2) | Fair-Good | US, GBR, AUS, CAN, NZL, ZAF | 386 | Dem | 19.7 | 75 | 56
Galantamine | Rockwood, 2006^209^ (Video-Imaging Synthesis of Treated Alzheimer’s disease (VISTA)) | Fair | CAN | 130 | Dem | 20.3 | 78 | 63
Galantamine | Tariot, 2000^211^ (Galantamine USA - Study Group (GAL-USA-10)) | Fair-Good | US | 978 | Dem | 17.8 | 77 | 64
Galantamine | Wilcock, 2000^212^ (Galantamine International-1-Group Study (GAL-INT-1)) | Fair-Good | GBR, CAN, FIN, FRA, DEU, NLD, NOR, SWE | 653 | Dem | 19.3 | 72 | 63
Galantamine | Wilkinson, 2001^213^ | Fair-Good | GBR | 285 | Dem | 18.6 | 74 | 58
Rivastigmine | Agid, 1998^214^ | Fair-Good | GBR, AUT, BEL, CZE, DNK, FIN, FRA, DEU, IRL, NOR, SVK, SWE, CHE | 402 | Dem | NR | 69 | 56
Rivastigmine | Ballard, 2008^215^ (Vascular Dementia Trial studying Exelon (VantagE)) | Fair | US, GBR, AUT, CAN, FRA, DEU, ITA, KOR, RUS, ESP, TWN | 710 | Dem | 19.2 | 73 | 38
Rivastigmine | Corey-Bloom, 1998^216^ | Fair-Good | US | 699 | Dem | 19.7 | 74 | 61
Rivastigmine | Feldman, 2007^217^ (Study 304) | Fair | GBR, AUS, CAN, IRL, ITA, ZAF | 678 | Dem | 18.6 | 71 | 59
Rivastigmine | McKeith, 2000^218^ | Fair-Good | GBR, ITA, ESP | 120 | Dem | 17.8 | 74 | 43
Rivastigmine | Mok, 2007^219^ | Fair | HKG | 40 | Dem | 13.2 | 75 | 60
Rivastigmine | Rosler, 1999^220^ (B303 Exelon Study) | Fair-Good | US, AUT, CAN, FRA, DEU, CHE | 725 | Dem | 19.9 | 72 | 59
Rivastigmine | Winblad, 2007^221^ (Investigation of transDermal Exelon in ALzheimer’s disease (IDEAL)) | Fair | US, CHL, CZE, DNK, FIN, DEU, GTM, ISR, ITA, KOR, MEX, NOR, PER, POL, PRT, RUS, SVK, SWE, TWN, VEN | 1195 | Dem | 16.5 | 74 | 66
Memantine | Bakchine, 2008^222^ | Good | GBR, AUT, BEL, DNK, FIN, FRA, GRC, LTU, NLD, POL, ESP, SWE | 470 | Dem | 18.7 | 74 | 63
Memantine | Choi, 2011^*^,^223^ | Fair | KOR | 172 | Dem | 16.6 | 75 | 80
Memantine | Dysken, 2014^*^,^224^ (TEAM-AD VA) | Good | US | 613 | Dem | 21 | 79 | 3
Memantine | Ferris, 2007^225^ | Fair | US | 60 | MCI | 28.8 | 67 | 65
Memantine | Herrmann, 2013^*^,^226^ | Fair | CAN | 369 | Dem | 11.8 | 75 | 58
Memantine | Orgogozo, 2002^227^ (MMM 300) | Fair-Good | BEL, FRA, CHE | 321 | Dem | 16.9 | 76 | 47
Memantine | Peskind, 2006^228^ (MEM-MD-10) | Fair-Good | US | 403 | Dem | 17.3 | 78 | 59
Memantine | Peters, 2015^*^,^229^ | Fair | DEU | 226 | Dem | 22.2 | 72 | 64
Memantine | Porsteinsson, 2008^230^ (MEM-MD-12) | Good | US | 433 | Dem | 16.8 | 75 | 52
Memantine | Saxton, 2012^231^ (MEM-MD-71) | Good | AUS, NZL, ZAF | 265 | Dem | 15.8 | 75 | 58
Memantine | Wilcock, 2002^232^ (MMM500) | Fair-Good | GBR | 579 | Dem | 17.6 | 77 | 48
Memantine | Wilkinson, 2012^233^ | Fair | GBR, FRA, DEU, CHE | 278 | Dem | 16.9 | 74 | 57
Any AChEI | Gill, 2009^234^ | Good | CAN | 81,302 | Dem | NR | 80 | 61
Any AChEI | Hernandez, 2009^235^ | Good | US | 11,328 | Dem | NR | 74 | 4
Any AChEI | Thavorn, 2014^236^ | Fair | CAN | 97,446 | Dem | NR | 82 | 64

* New Study

† Least squares mean

‡ Standardized MMSE

Abbreviations: AUS = Australia; AUT = Austria; BEL = Belgium; CAN = Canada; CHE = Switzerland; CZE = Czech Republic; Dem = Dementia; DEU = Germany; DNK = Denmark; ESP = Spain; EST = Estonia; FIN = Finland; FRA = France; GBR = Great Britain/United Kingdom; GRC = Greece; GTM = Guatemala; HKG = Hong Kong; IRL = Ireland; ISR = Israel; ITA = Italy; JPN = Japan; KOR = Korea; LEADe = Lipitor’s Effect in Alzheimer’s; Dementia; LVA = Latvia; LTU = Lithuania; MCI = mild cognitive impairment; MEX = Mexico; MMSE = Mini-Mental State Examination; N = number of participants; NLD = Netherlands; NOR = Norway; NR = not reported; NZL = New Zealand; PER = Peru; POL = Poland; PRT = Portugal; ROU = Romania; RUS = Russia; SVK = Slovakia; SVN = Slovenia; SWE = Sweden; TWN = Taiwan; UKR = Ukraine; VEN = Venezuela; ZAF = South Africa

Table 11 AChEIs and Memantine: Interventions Characteristics, by Medication Type (KQs 4 and 5)

Author, year | Country | Pop cat | Medication (total daily dose) | Duration, weeks | Intervention details | CG description
Black, 2003^186^; Fair-Good | US, GBR, AUS, CAN, DEU, IRL | Dem | IG1: Donepezil (10 mg); IG2: Donepezil (5 mg) | 24 | IG1: Started at 5 mg qd and increased to 10 mg qd after 4 weeks; IG2: 5 mg qd | Placebo
Burns, 1999^187^; Fair-Good | GBR, AUS, BEL, CAN, FRA, DEU, IRL, NZL, ZAF | Dem | IG1: Donepezil (10 mg); IG2: Donepezil (5 mg) | 24 | IG1: Started with 5 mg qd and increased 10 mg qd after 7 days; IG2: 5 mg qd | Placebo
Doody, 2009^188^; Fair | US | MCI | Donepezil (5–10 mg) | 48 | 5 mg qd for 6 weeks followed by 10 mg qd for remainder of 28 weeks; allowed to reduce down to 5 mg qd if tolerability issues. | Placebo
Feldman, 2001^189^; Fair-Good | AUS, CAN, FRA | Dem | Donepezil (10 mg) | 24 | Started with 5 mg qd for first 28 days, then increased dose to 10 mg qd. Study medication could be reduced to 5 mg qd at any time during study to improve tolerability | Placebo
Holmes, 2004^190^; Fair-Good | GBR | Dem | Donepezil (10 mg) | 24 | Run-in was open label phase with 5 mg qd, for 6 weeks, then 10 mg qd for further 6 weeks, then patients randomized to placebo or 10 mg qd for further 12 weeks. | Placebo
Ikeda, 2015^*^,^191^; Fair | JPN | Dem | IG1: Donepezil (10 mg); IG2: Donepezil (5 mg) | 12 | IG1: Treatment began with 3 mg qd for 2 weeks then dose increased to 5 mg qd, then to 10 mg qd at week 6.; IG2: Started at 3 mg qd for 2 weeks, then dose increased to 5 mg qd. | Placebo
Krishnan, 2003^192^; Fair-Good | US | Dem | Donepezil (10 mg) | 24 | Started at 5 mg qd for first 28 days, then 10 mg qd thereafter | Placebo
Mazza, 2006^193^; Fair-Good | ITA | Dem | Donepezil (5 mg) | 24 | 5 mg qd | Placebo
Mohs, 2001^194^; Fair | US | Dem | Donepezil (10 mg) | 54 | Started at 5 mg qd for first 28 days and 10 mg qd thereafter | Placebo
Mori, 2012^195^; Fair | JPN | Dem | IG1: Donepezil (10 mg); IG2: Donepezil (5 mg); IG3: Donepezil (3 mg) | 12 | IG1: Titrated from 3 mg qd for 2 weeks, 5 mg qd for 4 weeks and then 10 mg qd for 6 weeks.; IG2: Titrated from 3 mg qd for 2 weeks up to 5 mg qd.; IG3: 3 mg qd | Placebo
Petersen, 2005^196^; Fair | US, CAN | MCI | Donepezil (10 mg) | 156 | Started at 5 mg qd, then increased to 10mg qd after 6 weeks | Placebo + multivitamin containing 15 IU Vitamin E
Rogers, 1996^198^; Fair-Good | US | Dem | IG1: Donepezil (5 mg); IG2: Donepezil (3 mg); IG3: Donepezil (1 mg) | 12 | IG1: 5 mg qd for 12 weeks followed by 2 week placebo washout period; IG2: 3 mg qd for 12 weeks followed by 2 week placebo washout period; IG3: 1 mg qd for 12 weeks followed by 2 week placebo washout period | Placebo
Rogers, 1998^197^; Fair-Good | US | Dem | IG1: Donepezil (10 mg); IG2: Donepezil (5 mg) | 15 | IG1: Started at 5 mg qd during week 1 and increased to 10 mg qd weeks 2–12, followed by placebo washout weeks 13–15; IG2: 5 mg qd for 12 weeks followed by placebo washout weeks 13–15 | Placebo
Salloway, 2004^199^; Fair-Good | US | MCI | Donepezil (10 mg) | 24 | Started at 5 mg qd and increased to 10 mg qd after 42 days | Placebo
Seltzer, 2004^200^; Fair-Good | US | Dem | Donepezil (10 mg) | 24 | Started at 5 mg and increased to 10 mg qd after 6 weeks | Placebo
Tune, 2003^201^; Fair-Good | US | Dem | Donepezil (10 mg) | 24 | Started at 5 mg qd for first 28 days and then increased to 10 mg qd after 28 days | Placebo
Wilkinson, 2003^202^; Fair-Good | US, GBR, AUS, CAN, DEU, IRL | Dem | IG1: Donepezil (10 mg); IG2: Donepezil (5 mg) | 24 | IG1: Started at 5 mg qd and increased to 10 mg qd after 28 days; IG2: 5 mg qd | Placebo
Winblad, 2001^203^; Fair-Good | DNK, FIN, NLD, NOR, SWE | Dem | Donepezil (10 mg) | 52 | Started on 5 mg qd for 28 days, and then 10 mg qd. If required, a dose reduction to 5 mg qd was permitted. | Placebo
Auchus, 2007^204^; Fair | US | Dem | Galantamine (16–24 mg) | 26 | 4 mg bid for 4 weeks followed by 8 mg bid for 4 weeks; dosage could be maintained or increased to 12 mg bid (after additional 4 weeks, maintained or reduced to 8 mg bid for tolerability). Mean (SD) dose over entire treatment, 16.4 (3.98) mg qd | Placebo
Brodaty, 2005^205^; Fair-Good | US, AUS, CAN, NZL, ZAF | Dem | IG1: Galantamine (16–24 mg); IG2: Galantamine (16–24 mg) | 26 | IG1: Run-in period: placebo for 4 weeks; Titrated from initial dosage of 4 mg bid for weeks 1 through 4; weeks 5 through 8 titrated to 8 mg bid; after 8 weeks, 8- or 12-mg bid; IG2: Run-in period: placebo for 4 weeks; Titrated from initial dosage of 8 mg qd in morning with placebo in the evening for weeks 1 through 4; weeks 5 through 8 titrated to 16 mg qd in morning with placebo in evening; after 8 weeks, 16- or 24-mg qd in morning | Placebo
Erkinjuntti, 2002^206^; Fair-Good | GBR, CAN, DNK, FIN, FRA, DEU, IRL, ISR, NLD, POL | Dem | Galantamine (24 mg) | 26 | After 4 weeks placebo run-in period, started 4 mg qd in the first week, with weekly increments of 4 mg qd until reached 24 mg qd in week 6. | Placebo
Hager, 2014^*^,^207^; Fair | CZE, FRA, DEU, GRC, ITA, LTU, RUS, SVK, EST, LVA, SVN, ROU, UKR | Dem | Galantamine (24 mg) | 104 | 12 week titration period started at 8 mg qd, then increased to 16 mg qd, and up to 24 mg qd. Galantamine maintained at stable dose of at least 16 mg qd for next 21 months. | Placebo
Raskind, 2000^208^; Fair-Good | US | Dem | IG1: Galantamine (24 mg); IG2: Galantamine (32 mg) | 26 | IG1: Following a 4-week run-in period, started at 8 mg qd for the first week, followed by 16 mg qd in the second and 24 mg qd in the third week. In the fourth week, continued to receive the 24 mg qd dose for an additional 5 months.; IG2: Following a 4-week run-in period, started at 8 mg qd for the first week, followed by 16 mg qd in the second and 24 mg qd in the third week. In the fourth week, dose was increased to 32 mg qd dose for an additional 5 months. | Placebo
Rockwood, 2001^210^; Fair-Good | US, GBR, AUS, CAN, NZL, ZAF | Dem | Galantamine (24–32 mg) | 12 | Started at 4 mg bid for 1 week, increased to 8 mg bid for the 2nd week and 12 mg bid for the 3rd week; during week 4 increased to 16 mg bid at the discretion of the investigator based on tolerance and by the end of the 4th week, the investigator could red | Placebo
Rockwood, 2006^209^; Fair | CAN | Dem | Galantamine (16–24 mg) | 16 | 16 to 24 mg qd; 1 tablet bid with food. Titrated from 8 mg qd (4 mg bid) for 4 weeks; 16 mg qd for another 4 weeks. At end of 8 weeks, dose could be increased to 24 mg qd depending on tolerability. At 12 weeks, dose could be reduced to 16 mg qd. | Placebo
Tariot, 2000^211^; Fair-Good | US | Dem | IG1: Galantamine (24 mg); IG2: Galantamine (16 mg); IG3: Galantamine (8 mg) | 21 | IG1: Started at 4 mg bid for 4 weeks, then 8 mg bid for 4 weeks, and then maintenance dose at 12 mg bid from weeks 9 to 21; IG2: Started at 4 mg bid for 4 weeks followed by 8 mg bid for 17 weeks; IG3: Started at 4 mg bid for 4 weeks followed by 8 mg bid for 17 weeks | Placebo
Wilcock, 2000^212^; Fair-Good | GBR, CAN, FIN, FRA, DEU, NLD, NOR, SWE | Dem | IG1: Galantamine (24 mg); IG2: Galantamine (32 mg) | 26 | IG1: Started at 4 mg bid for one week, increasing to 8 mg bid for second week, and in the third week increased to 12 mg bid which was continued for rest of the study (5 months).; IG2: Started at 4 mg bid for one week, increasing to 8 mg bid for second week, increasing to 12 mg bid for the third week, and in the fourth week increased to 16 mg bid which was continued rest of the study (5 months). | Placebo
Wilkinson, 2001^213^; Fair-Good | GBR | Dem | IG1: Galantamine (24 mg); IG2: Galantamine (36 mg); IG3: Galantamine (18 mg) | 12 | IG1: After a 2-week washout period, started at 4 mg bid; increased progressively at 2- to 3-day intervals until the target dosage level of 8 mg tid was achieved after 8 days - then followed by 10 weeks of continuous fixed medication.; IG2: After a 2-week washout period, started 4 mg bid; increased progressively at 2- to 3-day intervals until the target dosage level of 12 mg tid was achieved after 14 days - then followed by 10 weeks of continuous fixed medication.; IG3: After a 2-week washout period, started at 4 mg bid; increased progressively at 2- to 3-day intervals until the target dosage level of 6 mg tid was achieved after 5 days - then followed by 10 weeks of continuous fixed medication. | Placebo
Agid, 1998^214^; Fair-Good | GBR, AUT, BEL, CZE, DNK, FIN, FRA, DEU, IRL, NOR, SVK, SWE, CHE | Dem | IG1: Rivastigmine (6 mg); IG2: Rivastigmine (4 mg) | 13 | IG1: Started at 1 mg bid and titrated to 2.5 mg bid for 3 weeks, then maintained 3 mg bid for 10 weeks.; IG2: Started at 1 mg bid and titrated to 1.5 mg bid for 1 week, then maintained 2 mg bid for 12 weeks. | Placebo
Ballard, 2008^215^; Fair | US, GBR, AUT, CAN, FRA, DEU, ITA, KOR, RUS, ESP, TWN | Dem | Rivastigmine (3–12 mg) | 24 | Treatment began with 1.5 mg bid and doses were increased by 1.5 mg bid at every 4 week interval over 16 weeks. The highest well-tolerated dose was maintained for the duration of the study. Mean dose by the end of the study was 9.6 mg qd. | Placebo
Corey-Bloom, 1998^216^; Fair-Good | US | Dem | IG1: Rivastigmine (6–12 mg); IG2: Rivastigmine (1–4 mg) | 26 | IG1: Started at 3 mg bid and dose was titrated weekly to 6 mg bid during weeks 1–7; and during flexible dose maintenance phase weeks 8–26, doses increased within the assigned range (6–12 mg qd) until maximum dose or maximum tolerated dose was achieved.; IG2: Started at 0.5 mg bid and dose was titrated weekly to 2 mg bid during weeks 1–7; and during flexible dose maintenance phase weeks 8–26, doses increased within the assigned range (1–4 mg qd) until maximum dose or maximum tolerated dose was achieved. | Placebo
Feldman, 2007^217^; Fair | GBR, AUS, CAN, IRL, ITA, ZAF | Dem | IG1: Rivastigmine (9.6 mg); IG2: Rivastigmine (8.9 mg) | 26 | IG1: 2–12 mg qd given tid, mean 9.6 mg qd; IG2: 2–12 mg qd given bid, mean 8.9 mg qd | Placebo
McKeith, 2000^218^; Fair-Good | GBR, ITA, ESP | Dem | Rivastigmine (12 mg) | 20 | Started with 1.5 mg bid rivastigmine or placebo; doses escalated by 1.5 mg bid for a max of 2 weeks at each dose until 6 mg bid or maximum well tolerated maintenance dose reached. Titration lasted up to 8 weeks. | Placebo
Mok, 2007^219^; Fair | HKG | Dem | Rivastigmine (6 mg) | 26 | Started at 1.5 mg bid and increased to 3 mg bid after 4 weeks | Placebo
Rosler, 1999^220^; Fair-Good | US, AUT, CAN, FRA, DEU, CHE | Dem | IG1: Rivastigmine (6–12 mg); IG2: Rivastigmine (1–4 mg) | 26 | IG1: Dosages increased weekly in steps of up to 1.5 mg qd during weeks 1–12; must be within target range by week 7. Decreases were not permitted during the first 12 weeks. Mean dose 10.4 mg qd by the end of the study.; IG2: Dosages increased weekly in steps of up to 1.5 mg qd during weeks 1–12; must be within target range by week 7. Decreases were not permitted during the first 12 weeks. Mean dose 3.7 mg qd by the end of the study. | Placebo
Winblad, 2007^221^; Fair | US, CHL, CZE, DNK, FIN, DEU, GTM, ISR, ITA, KOR, MEX, NOR, PER, POL, PRT, RUS, SVK, SWE, TWN, VEN | Dem | IG1: Rivastigmine (12 mg); IG2: Rivastigmine (17.4 mg); IG3: Rivastigmine (9.5 mg) | 24 | IG1: 12 mg qd capsule titrated from 3 mg qd to maximum 12 mg qd in 4-week steps over 16 weeks.; IG2: 20 square centimeter patch (17.4 milligrams/24 hours), titrated in 5 square cm patches to the target dose in 4-week steps over 16 weeks. Patients maintained at their highest tolerated dose.; IG3: 10 square centimeter patch (9.5 milligrams/24 hours), titrated in 5 square cm patches to the target dose in 4-week steps over 16 weeks. Patients maintained at their highest tolerated dose. | Placebo
Bakchine, 2008^222^; Good | GBR, AUT, BEL, DNK, FIN, FRA, GRC, LTU, NLD, POL, ESP, SWE | Dem | Memantine (20 mg) | 24 | Three week up titration then 21 weeks of 20 mg qd (10 mg bid) | Placebo
Choi, 2011^*^,^223^; Fair | KOR | Dem | Memantine (20 mg) + Rivastigmine (9.5 mg) | 16 | Starting at baseline (end of run-in period for rivastigmine, considered as week 0, titrated in 5 mg weekly increments from a starting dose of 5 mg qd to 20 mg qd at week 4. Memantine use concurrent with 10 cm^2^ (9.5 mg qd) Rivastigmine patch. | Rivastigmine (9.5 mg)
Dysken, 2014^*^,^224^; Good | US | Dem | Memantine (20 mg) | 208 | Titrated over 4 weeks to maintenance dosage of 10 mg bid. | Placebo
Ferris, 2007^225^; Fair | US | MCI | Memantine (20 mg) | 12 | Titrated from 10 mg (5 mg bid) to 20 mg (10 mg bid) daily over a 1 month period. | Placebo
Herrmann, 2013^*^,^226^; Fair | CAN | Dem | Memantine (20 mg) | 24 | Titrated in 5 mg weekly increments from starting dose of 5 mg qd to 20 mg qd beginning at Week 4 | Placebo
Orgogozo, 2002^227^; Fair-Good | BEL, FRA, CHE | Dem | Memantine (20 mg) | 28 | 2-week placebo run-in period. Started at 5 mg qd at week 1, 10 mg qd at week 2, and 15 mg qd at week 3; patients received 20mg qd of memantine for remainder of followup | Placebo
Peskind, 2006^228^; Fair-Good | US | Dem | Memantine (20 mg) | 24 | After 7–14 day single-blind placebo lead-in, started at 5 mg qd and titrated in 5-mg weekly increments to final dose of 20 mg qd (administered as two 5-mg tablets bid) on day 22 | Placebo
Peters, 2015^*^,^229^; Fair | DEU | Dem | Memantine (20 mg) | 52 | Memantine titrated over 4 weeks in steps of 5 mg qd up to 20 mg qd. | Placebo + Galantamine (24 mg qd)
Porsteinsson, 2008^230^; Good | US | Dem | Memantine (20 mg) | 24 | 20 mg qd (four 5 mg tablets qd at bedtime); initial dose of 5 mg qd titrated in 5 mg weekly increments until reached final dose on day 22. Transient-dose adjustments permitted during weeks 3–8 for subjects with tolerability issues | Placebo
Saxton, 2012^231^; Good | AUS, NZL, ZAF | Dem | Memantine (20 mg) | 12 | Titrated in weekly increments of 5 mg reaching maximum target dose of 10 mg bid by week 4. | Placebo
Wilcock, 2002^232^; Fair-Good | GBR | Dem | Memantine (20 mg) | 28 | Single blind run-in using placebo only for 2 weeks and double-blind treatment phase after randomization (28 weeks). Patients titrated up to daily dose of 20 mg starting at 5 mg daily with weekly increments of 5 mg, | Placebo
Wilkinson, 2012; Fair^233^ | GBR, FRA, DEU, CHE | Dem | Memantine (20 mg) | 52 | 20 mg qd. Titrated up from 5 mg qd to target dose of 20 mg qd (increased 5 mg qd once a week during a 4 week dose escalation period); mean memantine dose ranging from 8.7–21.6 | Placebo

* New Study

Abbreviations: AUS = Australia; AUT = Austria; BEL = Belgium; bid = twice a day; CAN = Canada; CG = control group; CHE = Switzerland; cm^2^ = square centimeter; CZE = Czech Republic; Dem = Dementia; DEU = Germany; DNK = Denmark; ESP = Spain; EST = Estonia; FIN = Finland; FRA = France; GBR = Great Britain/United Kingdom; GRC = Greece; GTM = Guatemala; HKG = Hong Kong; IG = intervention group; IRL = Ireland; ISR = Israel; ITA = Italy; IU = International Unit; JPN = Japan; KOR = Korea; LVA = Latvia; LTU = Lithuania; MCI = mild cognitive impairment; MEX = Mexico; mg = milligram; MMSE = Mini-Mental State Examination; N = number of participants; NLD = Netherlands; NOR = Norway; NZL = New Zealand; PER = Peru; POL = Poland; PRT = Portugal; Pop cat = population category; qd = once a day; ROU = Romania; RUS = Russia; SVK = Slovakia; SVN = Slovenia; SWE = Sweden; tid = three times a day; TWN = Taiwan; UKR = Ukraine; VEN = Venezuela; ZAF = South Africa

Table 12 AChEIs and Memantine: Summary of Results, by Medication Type (KQs 4 and 5)

Medication | Author, year Quality | Pop cat | N rand | Age, mean | FU (mo.) | Global Function | Global Cognitive Function | Domain-specific Cognitive Function | Physical Function | Neuro Symptoms | Other
Donepezil | Black, 2003^186^; Fair-Good | Dem | 603 | 74 | 6 | IG1: ↔ (CIBIC+[D]), ↑ (CDR-SB); IG2: ↔ (CIBIC+[D]), ↔ (CDR-SB) | IG1: ↑ (ADAS-Cog), ↑ (MMSE); IG2: ↑ (ADAS-Cog), ↑ (MMSE) | NR | IG1: ↔ (ADL/IADL), ↔ IADL; IG2: ↔ (ADL/IADL), ↑ IADL | NR | NR
Donepezil | Burns, 1999^187^; Fair-Good | Dem | 818 | 72 | 6 | IG1: ↑ (CIBIC+), ↑ (CDR-SB); IG2: ↑ (CIBIC+), ↑ (CDR-SB) | IG1: ↑ (ADAS-Cog); IG2: ↑ (ADAS-Cog) | NR | IG1: ↑ (ADL/IADL); IG2: ↑ (ADL/IADL) | NR | NR
Donepezil | Doody, 2009^188^; Fair | MCI | 821 | 70 | 11 | ↔ (CIBIC+), ↔ (CDR-SB) | ↑ (ADAS-Cog), ↔ (MMSE) | ↔ (Attention) | NR | ↔ | NR
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | 291 | 74 | 6 | ↑ (CIBIC+[D]) | ↑ (MMSE) | NR | ↑ (ADL/IADL), ↑ (ADL), ↑ (IADL) | ↑ | NR
Donepezil | Holmes, 2004^190^; Fair-Good | Dem | 96 | 79 | 3 | NR | ↑ (MMSE) | NR | NR | ↑ | ↑ (CGR Burden)
Donepezil | Ikeda, 2015^*^,^191^; Fair | Dem | 142 | 78 | 3 | NR | IG1: ↑ (MMSE); IG2: ↔ (MMSE) | NR | NR | IG1: ↔; IG2: ↔ | IG1: ↔ (CGR Burden); IG2: ↔ (CGR Burden)
Donepezil | Krishnan, 2003^192^; Fair-Good | Dem | 67 | 73 | 6 | NR | ↑ (ADAS-Cog) | NR | NR | NR | NR
Donepezil | Mazza, 2006^193^; Fair-Good | Dem | 76 | 68 | 6 | ↑ (CGI Item 2) | ↔ (MMSE) | ↑ (Attention) | NR | NR | NR
Donepezil | Mohs, 2001^194^; Fair | Dem | 431 | 75 | 12 | ↑ (CDR/ADL/IADL[D]) | NR | NR | NR | NR | NR
Donepezil | Mori, 2012^195^; Fair | Dem | 140 | 79 | 3 | IG1: ↑ (CIBIC+[D]); IG2: ↔ (CIBIC+[D]); IG3: ↔ (CIBIC+[D]) | IG1: ↑ (MMSE); IG2: ↑ (MMSE); IG3: ↑ (MMSE) | IG1: ↔ (Attention), ↑ (EF), ↔ (Language); IG2: ↑ (Attention), ↑ (EF), ↔^‡^ (Language); IG3: ↑ (Attention), ↔ (EF), ↔ (Language) | NR | IG1: ↑; IG2: ↑; IG3: ↔ | IG1: ↑ (CGR Burden); IG2: ↔ (CGR Burden); IG3: ↔ (CGR Burden)
Donepezil | Petersen, 2005^196^; Fair | MCI | 769 | 73 | 36 | ↔ (CDR-SB), ↔^†^ (GDS) | ↔ (ADAS-Cog), ↔ (MMSE) | ↔ (EF), ↔^‡^ (Language), ↔^‡^ (Memory) | ↔ (IADL) | NR | ↑ (Dementia Incidence)
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | 161 | 72 | 3 | IG1: ↔ (CDR-SB); IG2: ↔ (CDR-SB); IG3: ↔ (CDR-SB) | IG1: ↑ (ADAS-Cog), ↔ (MMSE); IG2: ↑ (ADAS-Cog), ↔ (MMSE); IG3: ↔ (ADAS-Cog), ↔ (MMSE) | NR | IG1: ↔ (ADL); IG2: ↔ (ADL); IG3: ↔ (ADL) | NR | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Dem | 468 | 74 | 4 | IG1: ↑ (CIBIC+[D]), ↔ (CDR-SB); IG2: ↑ (CIBIC+[D]), ↔ (CDR-SB) | IG1: ↑ (ADAS-Cog), ↑ (MMSE); IG2: ↑ (ADAS-Cog), ↑ (MMSE) | NR | NR | NR | NR
Donepezil | Salloway, 2004^199^; Fair-Good | MCI | 270 | 72 | 6 | ↔ (CGIC-MCI [D]) | ↑ (ADAS-Cog), ↔ (ADAS-Cog [D]) | ↔ (Attention), ↔ (Memory) | NR | NR | NR
Donepezil | Seltzer, 2004^200^; Fair-Good | Dem | 153 | 74 | 6 | NR | ↑ (ADAS-Cog), ↑ (ADAS-Cog [D]), ↑ (MMSE) | ↔ (Memory) | NR | NR | NR
Donepezil | Tune, 2003^201^; Fair-Good | Dem | 28 | 73 | 6 | NR | ↔ (ADAS-Cog) | NR | NR | ↔ | NR
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | 616 | 75 | 6 | IG1: ↑ (CIBIC+[D]), ↑ (CDR-SB); IG2: ↑ (CIBIC+[D]), ↑ (CDR-SB) | IG1: ↑ (ADAS-Cog), ↑ (MMSE); IG2: ↑ (ADAS-Cog), ↑ (MMSE) | NR | IG1: ↔ (ADL/IADL); IG2: ↔ (ADL/IADL) | NR | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | 286 | 72 | 12 | ↔ (GBS), ↑ (GDS[D]) | ↑ (MMSE) | NR | ↑ (ADL/IADL) | NR | NR
Galantamine | Auchus, 2007^204^; Fair | Dem | 788 | 72 | 6 | ↔ (CIBIC+[D]) | ↑ (ADAS-Cog) | NR | ↔ (ADL/IADL) | NR | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | 971 | 76 | 6 | IG1: ↑ (CIBIC+[D]); IG2: ↔ (CIBIC+[D]) | IG1: ↑ (ADAS-Cog); IG2: ↑ (ADAS-Cog) | NR | IG1: ↑ (ADL/IADL); IG2: ↑ (ADL/IADL) | IG1: ↔; IG2: ↔ | NR
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | 592 | 75 | 6 | ↑ (CIBIC+[D]) | ↑ (ADAS-Cog), ↑ (ADAS-Cog [D]) | NR | ↑ (ADL/IADL) | ↑ | NR
Galantamine | Hager, 2014^*^,^208^; Fair | Dem | 2051 | 73 | 12 | NR | ↑ (MMSE) | NR | ↑ (ADL/IADL) | NR | NR
Galantamine | Raskind, 2000^208^; Fair-Good | Dem | 636 | 75 | 6 | IG1: ↑ (CIBIC+[D]); IG2: ↔ (CIBIC+[D]) | IG1: ↑ (ADAS-Cog); IG2: ↑ (ADAS-Cog) | NR | NR | NR | NR
Galantamine | Rockwood, 2001^210^; Fair-Good | Dem | 386 | 75 | 3 | ↑ (CIBIC+[D]) | ↑ (ADAS-Cog), ↔ (ADAS-Cog [D]) | NR | ↑ (ADL/IADL) | ↔ | NR
Galantamine | Rockwood, 2006^209^; Fair | Dem | 130 | 78 | 4 | ↔ (CIBIC+) | ↑ (ADAS-Cog) | NR | ↔ (ADL/IADL) | NR | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | 978 | 77 | 5 | ↑ (CIBIC+[D]) | IG1: ↑ (ADAS-Cog), ↑ (ADAS-Cog [D]); IG2: ↑ (ADAS-Cog), ↑ (ADAS-Cog [D]); IG3: ↔ (ADAS-Cog), ↔ (ADAS-Cog [D]) | NR | IG1: ↑ (ADL/IADL); IG2: ↑ (ADL/IADL); IG3: ↔ (ADL/IADL) | IG1: ↑; IG2: ↑; IG3: ↔ | IG1: ↔ (CGR Burden); IG2: ↔ (CGR Burden); IG3: ↔ (CGR Burden)
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | 653 | 72 | 6 | IG1: ↑ (CIBIC+[D]); IG2: ↑ (CIBIC+[D]) | IG1: ↑ (ADAS-Cog), ↑ (ADAS-Cog [D]); IG2: ↑ (ADAS-Cog), ↑ (ADAS-Cog [D]) | NR | IG1: ↔ (ADL/IADL); IG2: ↑ (ADL/IADL) | NR | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | 285 | 74 | 3 | ↔ (CIBIC+) | IG1: ↑ (ADAS-Cog); IG2: ↔ (ADAS-Cog); IG3: ↔ (ADAS-Cog) | NR | IG1: ↔ (ADL/IADL [D]); IG2: ↔ (ADL/IADL [D]); IG3: ↔ (ADL/IADL [D]) | NR | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | 402 | 69 | 3 | NR | IG1: ↑ (MMSE); IG2: ↑ (MMSE) | IG1: ↔^‡^ (Attention), ↔^‡^ (Memory); IG2: ↔ (Attention), ↔^‡^ (Memory) | IG1: ↔ (ADL), ↔ (IADL); IG2: ↔ (ADL), ↔ (IADL) | NR | NR
Rivastigmine | Ballard, 2008^215^; Fair | Dem | 710 | 73 | 6 | ↔ (CIBIC+), ↔ (GDS) | ↑ (ADAS-Cog), ↑ (MMSE) | NR | ↔ (ADL/IADL) | ↔ | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | 699 | 74 | 6 | IG1: ↔ (CIBIC+[D]), ↑ (GDS); IG2: ↔ (CIBIC+[D]), ↔ (GDS) | IG1: ↑ (ADAS-Cog), ↔ (ADAS-Cog [D]), ↑ (MMSE); IG2: ↔ (ADAS-Cog), ↔ (MMSE) | NR | | NR | NR
Rivastigmine | Feldman, 2007^217^; Fair | Dem | 678 | 71 | 6 | IG1: ↑ (CIBIC+[D]), ↔ (GDS); IG2: ↔ (CIBIC+[D]), ↔ (GDS) | IG1: ↑ (ADAS-Cog), ↑ (ADAS-Cog [D]), ↔ (MMSE); IG2: ↑ (ADAS-Cog), ↔ (ADAS-Cog [D]), ↔ (MMSE) | NR | IG1: ↔ (ADL/IADL); IG2: ↔ (ADL/IADL) | NR | NR
Rivastigmine | McKeith, 2000^218^; Fair-Good | Dem | 120 | 74 | 5 | NR | ↔ (MMSE) | NR | NR | ↑ | NR
Rivastigmine | Mok, 2007^219^; Fair | Dem | 40 | 75 | 6 | ↔ (CDR-SB) | ↔ (MMSE) | ↔ (EF) | ↔ (IADL) | ↔ | ↔ (Anxiety)
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | 725 | 72 | 6 | IG1: ↑ (CIBIC+[D]), ↑ (GDS); IG2: ↔ (CIBIC+[D]), ↔ (GDS) | IG1: ↑ (ADAS-Cog), ↑ (ADAS-Cog [D]), ↑ (MMSE); IG2: ↔ (ADAS-Cog), ↔ (ADAS-Cog [D]), ↔ (MMSE) | NR | | NR | NR
Rivastigmine | Winblad, 2007^221^; Fair | Dem | 1195 | 74 | 6 | IG1: ↑ (CIBIC+[D]); IG2: ↔ (CIBIC+[D]); IG3: ↑ (CIBIC+[D]) | IG1: ↑ (ADAS-Cog), ↑ (MMSE); IG2: ↑ (ADAS-Cog), ↑ (MMSE); IG3: ↑ (ADAS-Cog), ↑ (MMSE) | IG1: ↑ (Attention), ↔ (EF); IG2: ↑ (Attention), ↔ (EF); IG3: ↑ (Attention), ↔ (EF) | IG1: ↑ (ADL/IADL); IG2: ↑ (ADL/IADL); IG3: ↑ (ADL/IADL) | IG1: ↔; IG2: ↔; IG3: ↔ | NR
Memantine | Bakchine, 2008^222^; Good | Dem | 470 | 74 | 6 | ↔ (CIBIC+) | ↔ (ADAS-Cog) | NR | ↔ (ADL/IADL) | ↔ | NR
Memantine | Choi, 2011^*^,^223^; Fair | Dem | 172 | 75 | 4 | ↔ (CDR-SB) | ↔ (ADAS-Cog), ↔ (MMSE) | ↔ (EF) | ↔ (ADL/IADL) | ↔ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | 613 | 79 | 48 | NR | ↔ (ADAS-Cog), ↔ (MMSE) | | ↔ (ADL/IADL) | ↔ | NR
Memantine | Ferris, 2007^225^; Fair | MCI | 60 | 67 | 3 | NR | NR | ↔ (Attention), ↔ (Memory) | NR | NR | NR
Memantine | Herrmann, 2013^*^,^226^; Fair | Dem | 369 | 75 | 6 | NR | ↔ (SIB) | NR | NR | ↔ | ↔ (Institutionalization)
Memantine | Orgogozo, 2002^227^; Fair-Good | Dem | 321 | 76 | 6 | ↔ (ADCS-CGIC), ↔ (CIBIC+[D]), ↔ (GBS) | ↑ (ADAS-Cog), ↑ (MMSE) | NR | ↔ (ADL), ↔ (IADL) | NR | NR
Memantine | Peskind, 2006^228^; Fair-Good | Dem | 403 | 78 | 6 | ↑ (CIBIC+) | ↑ (ADAS-Cog) | NR | ↔ (ADL/IADL) | ↑ | NR
Memantine | Peters, 2015^*^,^229^; Fair | Dem | 226 | 72 | 12 | ↔ (CDR-SB) | ↔ (ADAS-Cog) | NR | ↔ (ADL/IADL) | ↔ | NR
Memantine | Porsteinsson, 2008^230^; Good | Dem | 433 | 75 | 6 | ↔ (CIBIC+) | ↔ (ADAS-Cog), ↔ (MMSE) | NR | ↔ (ADL/IADL) | ↔ | NR
Memantine | Saxton, 2012^231^; Good | Dem | 265 | 75 | 3 | ↔ (ADCS-CGIC[D]) | NR | NR | NR | NR | NR
Memantine | Wilcock, 2002^232^; Fair-Good | Dem | 579 | 77 | 6 | NR | ↑ (ADAS-Cog) | NR | NR | NR | NR
Memantine | Wilkinson, 2012^233^; Fair | Dem | 278 | 74 | 12 | NR | ↑ (MMSE) | ↔^‡^ (EF), ↑ (Language) | NR | ↔ | NR

NOTE: Arrows represent study-reported results.

Symbol Legend:

↑ = Statistically significant between-group difference in favor of intervention group

↔ = No statistically significant difference between groups or no clear between-group difference (not reported).

* New study

† Results are statistically significant for at least one timepoint

‡ Mixed results from multiple tests assessing same cognitive domain

Abbreviations: ADL = Activities of Daily Living; ADAS-Cog = Alzheimer’s Disease Assessment Scale-cognitive subscale; ADCS-CGIC = Alzheimer’s Disease Cooperative Stud – Clinical Global Impression of Change scale; CIBIC+ = Clinician’s Interview-Based Impression of Change with caregiver’s input; CDR-SB = Clinical Dementia Rating Scale Sum of Boxes; CGI = Clinical Global Impression scale; CGR = caregiver; D = dichotomized; Dem = dementia; EF = executive functioning; FU = followup; GBS = Gottfries-Brane-Steen scale; GDS = Global Deterioration Scale; IADL = Instrumental Activities of Daily Living; MCI = mild cognitive impairment; MMSE = Mini-Mental State Examination; mo. = months; NR = not reported; Pop cat = population category

###### Donepezil

Study and population characteristics. Eighteen fair- to good-quality trials involving 6,209 participants evaluated the effectiveness of donepezil for cognitive impairment. Eleven studies (61%) recruited patients partially or fully from the United States. Studies lasted a median of 6 months, with a range of 3 to 36 months. Fifteen studies evaluated donepezil for dementia, while three evaluated donepezil for MCI. The mean baseline MMSE for participants was 22.0, and 52 percent of study participants were women. Most donepezil trials enrolled participants with AD (k=11; n=2,827), but two trials enrolled participants with VaD (n=1,219),^186,^ ^202^ two trials enrolled participants with LBD (n=282),^191,^ ^195^ and three trials enrolled participants with MCI (n=1,881).^188,^ ^196,^ ^199^ Only one donepezil study was published since the last review—a study of 142 participants with LBD.^191^ Only seven studies reported on race, and these described overwhelmingly white samples: 87 percent in one study and 92 to 100 percent in the others. Only two studies reported on education, with one study reporting a mean of 15 years of education for the sample,^199^ and the other study reporting that 53 percent of the sample had 8 to 15 years of education and 47 percent had more than 15 years of education.^188^

Intervention characteristics. The daily dosage of donepezil ranged from 1 to 10 mg, with all trials using 5 to 10 mg per day in at least one trial arm. Most studies started participants on doses of 5 mg per day, increasing to 10 mg per day after 2 to 6 weeks. All control participants were given placebo.

##### Results

Cognitive function. Differences in global cognitive function favoring donepezil were statistically significant but generally small and of unclear clinical significance. Fourteen of the 18 studies had sufficient data to meta-analyze cognitive function results using the ADAS-Cog or the MMSE. For ADAS-Cog scores, the pooled between-group mean difference in change was 2.13 points in favor of the intervention group (95% CI, −3.32 to −0.94; k=6; n=1,981; I^2^=64.4%) (Figure 9), usually from an improvement in the intervention group of 1 to 4 points and no change or a decline in the placebo group of up to 4 points. Most studies reported differences at 6 months. Only one study followed participants for more than 12 months;^196^ the difference in ADAS-Cog scores for the group treated with donepezil and the group on placebo gradually decreased in magnitude between 6 and 36 months, but the difference was not statistically significant at any time. Consistent with the findings from the meta-analysis, two studies reported a higher percentage of patients treated with donepezil compared to the placebo group improving by 4 points or more on the ADAS-Cog 13 (37% vs. 16% [p=0.02]^200^ and 50% vs. 32% [p-value not reported]^199^). For MMSE scores, the pooled between-group mean difference in change over 3 to 36 months was 1.24 points (95% CI, 0.81 to 1.67; k=12; n=3,192; I^2^=65.3%) (Figure 10), usually from no change or an improvement of up to 2 points in the donepezil group and no change or a decline of up to 3 points in the placebo group. In the one study that reported longer followup, the MMSE score of both the group treated with donepezil and the group on placebo declined over time, and the magnitude and direction of the difference between the two groups remained consistent and not statistically significant.^196^ The Egger’s test of bias was statistically significant (p=0.015) for results for the MMSE, indicating a small studies effect, which is a marker of potential publication bias. Due to this potential bias, the pooled estimate may overestimate the true effect.

Figure 9 Pooled Analysis of Change in Global Cognitive Function (Measured by ADAS-Cog-11) (KQ 4), AchEIs, and Memantine Compared With Placebo, by Medication Type

* For all analyses, we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available.

† Pooled mean difference, −2.13 (95% CI: −3.32 to −0.94); k=6; n=1981; I^2^=64.4%, based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, −2.13 (95% CI: −2.94 to −1.32); k=9; n=3786; I^2^=65.9%, based on restricted maximum likelihood method with Knapp-Hartung modification

§ Pooled mean difference, −2.43 (95% CI: −4.10 to −0.75); k=5; n=2618; I^2^=81.9%, based on restricted maximum likelihood method with Knapp-Hartung modification

ǁ Pooled mean difference, −0.88 (95% CI: −1.65 to −0.11); k=8; n=2609; I^2^=78.1%, based on restricted maximum likelihood method with Knapp-Hartung modification

¶ Both intervention and control groups received 5–10 mg/day rivastigmine plus memantine or placebo

# Both intervention and control groups received 24 mg/day galantamine plus memantine or placebo

Abbreviations: AChEIs = acetylcholinesterase inhibitors; ADAS-Cog-11 = Alzheimer’s disease assessment scale–cognitive subscale (11-items); BG = between-group; BL = baseline; CG = control group; Chg = change; CI = confidence interval; IG = intervention group; KQ = key question; MD = mean difference; mg = milligrams; n = sample size

This figure is a forest plot of the change in global cognitive function, as measured by the eleven-item version of the Alzheimer’s disease assessment scale–cognitive subscale, comparing intervention groups assigned to acetylcholinesterase inhibitors or memantine with control groups assigned to a placebo. The forest plot is organized by medication type.

Figure 10 Pooled Analysis of Change in Global Cognitive Function (Measured by MMSE) (KQ 4), AchEIs, and Memantine Compared With Placebo, by Medication Type

* For all analyses, we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available.

† Pooled mean difference, 0.88 (95% CI: 0.28 to 1.49); k=6; n=2415; I^2^=44.9%, based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, 0.36 (95% CI: −0.31 to 1.04); k=5; n=1217; I^2^=33.2%, based on restricted maximum likelihood method with Knapp-Hartung modification

§ Both intervention and control groups received 5–10 mg/day rivastigmine plus memantine or placebo

Abbreviations: AChEIs = acetylcholinesterase inhibitors; BG = between-group; BL = baseline; CG = control group; Chg = change; CI = confidence interval; Intv = Intervention; IG = intervention group; KQ = key question; MD = mean difference; mg = milligrams; MMSE = mini-mental state examination; n = sample size

This figure is a forest plot of the change in global cognitive function, as measured by the mini-mental state examination, comparing intervention groups assigned to acetylcholinesterase inhibitors or memantine with control groups assigned to a placebo. The forest plot is organized by medication type.

Findings were similar for all types of cognitive impairment, including AD, LBD, VaD, and MCI. Six donepezil studies reported outcomes on at least one specific cognitive domain. There was no evidence of significant differences in language or memory between participants exposed to donepezil and those exposed to placebo, while results were mixed regarding differences in attention or executive functioning between groups.

Global function. Thirteen of the 18 donepezil trials reported global function using measures such as the CIBIC+ or the Clinical Dementia Rating Scale Sum of Boxes. Most trials reported a benefit of donepezil compared with placebo. In a pooled analysis, participants taking donepezil had a 31 percent higher likelihood of improving or maintaining their global function at 3 to 12 months compared with those on placebo (relative risk [RR], 1.31 [95% CI, 1.12 to 1.53]; k=9; n=2,440; I^2^=77.4%) (Figure 11). Likewise, when looking at continuous measures of global function, there was a small, statistically significant association between donepezil and higher global function at 3 to 11 months (SMD, −0.24 [95% CI, −0.39 to −0.09]; k=8; n=3,302; I^2^=70.7%) (Figure 12).

Figure 11 Pooled Analysis of Risk of Improvement or Maintenance in Global Function (KQ 4), AChEIs and Memantine Compared With Placebo, by Medication Type

* For all analyses, we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available.

† Pooled mean difference, 1.33 (95% CI: 1.07 to 1.66); k=9; n=2440; I^2^=77.4%, based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, 1.21 (95% CI: 1.11 to 1.31); k=8; n=3486; I^2^=56.2%, based on restricted maximum likelihood method with Knapp-Hartung modification

§ Pooled mean difference, 1.49 (95% CI: 1.13 to 1.98); k=5; n=1934; I^2^=61.4%, based on restricted maximum likelihood method with Knapp-Hartung modification

ǁ Pooled mean difference, 1.15 (95% CI: 0.49 to 2.69); k=2; n=545; I^2^=0.0%, based on restricted maximum likelihood method with Knapp-Hartung modification

Abbreviations: AChEIs = acetylcholinesterase inhibitors; CG = control group; CI = confidence interval; IG = intervention group; KQ = key question; RR = risk ratio; mg = milligrams; N = sample size

This figure is a forest plot of the change in global function, as measured by the clinician’s interview-based impression of change with caregiver input, global deterioration scale, or clinical dementia rating scale sum of boxes, comparing intervention groups assigned to acetylcholinesterase inhibitors or memantine with control groups assigned to a placebo. The forest plot is organized by medication type.

Figure 12 Pooled Analysis of Change in Global Function (Standardized Mean Difference) (KQ 4), AChEIs and Memantine Compared With Placebo, by Medication Type

* For all analyses, we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available.

† Pooled mean difference, −0.24 (95% CI: −0.39 to −0.09); k=8; n=3302; I^2^=70.7%, based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, −0.14 (95% CI: −0.43 to 0.15); k=6; n=2535; I^2^=85.7%, based on restricted maximum likelihood method with Knapp-Hartung modification

§ Pooled mean difference, −0.14 (95% CI: −0.33 to 0.05); k=5; n=1396; I^2^=32.9%, based on restricted maximum likelihood method with Knapp-Hartung modification which resulted to no statistical significance

ǁ Both intervention and control groups received 5–10 mg/day rivastigmine plus memantine or placebo

¶ Both intervention and control groups received 24 mg/day galantamine plus memantine or placebo

Abbreviations: AChEIs = acetylcholinesterase inhibitors; BL = baseline; CG = control group; CDR-SB = Clinical Dementia Rating Scale Sum of Boxes; CI = confidence interval; CIBIC+ = Clinician’s Interview-Based Impression of Change with caregiver’s input; GDS = Global Deterioration Scale; IG = intervention group; KQ = key question; SMD = standardized mean difference; mg = milligrams; n = sample size

This figure is a forest plot of the risk of improvement or maintenance in global function, as measured by the clinician’s interview-based impression of change with caregiver input, comparing intervention groups assigned to acetylcholinesterase inhibitors or memantine with control groups assigned to a placebo. The forest plot is organized by medication type.

Physical function. Only 7 of 18 donepezil trials reported a measure of physical function. Studies used a wide variety of instruments to measure ADLs or IADLs or a combination of these; only two studies used the same instrument (ADFACS). Four of these trials reported a statistically significant difference in favor of those randomized to donepezil. While the remaining three trials did not report a statistically significant difference, their results favored the intervention in that they declined less than those on placebo or improved at followup. However, these changes were very small (e.g., an improvement of 1 to 2 points on a scale from 0 to 100).

Neuropsychiatric symptoms. Six donepezil studies evaluated behavioral and neuropsychiatric symptoms in their trials using the 10- or 12-item NPI, with mixed findings. Three studies found significant differences in behavioral and neuropsychiatric symptoms between donepezil and placebo groups at 3 to 6 months,^189,^ ^190,^ ^195^ whereas the other three studies did not find such differences over 3 to 11 months.^188,^ ^191,^ ^201^ Of note, in one study of 140 patients with LBD, differences in the NPI that favored the intervention were seen in those exposed to 5 and to 10 mg of donepezil per day but not those exposed to 3 mg per day.^195^

Other outcomes. A 3-year study of 769 persons with MCI that investigated both donepezil and vitamin E reported progression to AD.^196^ While donepezil was associated with a lower rate of progression from MCI to AD at the end of years 1 (hazard ratio [HR], 0.42 [95% CI, 0.24 to 0.76]) and 2 (HR, 0.64 [95% CI, 0.44 to 0.95]), the rate of progression from MCI to AD at 3 years was not different between donepezil and placebo groups (HR, 0.80 [95% CI, 0.57 to 1.13]). Three studies showed a decrease in caregiver burden (two as measured by the Zarit-22).^190,^ ^191,^ ^195^ This decrease, however, was not always statistically significant and often small (change from baseline ranging from an improvement of 5 points to a decline of 1 point for the caregivers in the group treated with donepezil and from no improvement to a decline of 4 points for caregivers in the control group). Other outcomes, including QOL and rates of institutionalization, were not reported in trials of donepezil. While many of these studies reported mortality as part of their patient tracking throughout the trial, these studies were not designed or powered to detect mortality differences between groups.

Harms. All 18 trials and one observational study reported potential harms of donepezil. Total AEs were statistically significantly higher in the group receiving donepezil (84%) vs. the control group (76%), with a pooled RR of 1.10 (95% CI, 1.06 to 1.13; k=12; n=3,212; I^2^=0%) (figure not shown). The most commonly reported adverse events with donepezil were diarrhea and nausea. SAEs were not statistically significantly different between intervention (12%) and control groups (10%) in our meta-analysis (RR, 1.18, [95% CI, 0.99 to 1.40]; k=12; n=4,045; I^2^=0%) (Figure 13), although results of individual trials were mixed, with some suggesting up to a 70 percent greater risk of SAEs in control participants and others reporting up to an 80 percent greater risk among those on donepezil. Furthermore, individual studies reported increased rates of bradycardia, and, relatedly, of syncope, falls, and need for pacemaker placement.^234,^ ^235^ Study withdrawals due to adverse events were statistically significantly higher in patients receiving donepezil (13%) than in patients receiving placebo (8%) (RR, 1.88 [95% CI, 1.54 to 2.29]; k=13; n=4,124; I^2^=8.8%) (Figure 14).

Figure 13 Pooled Analysis of Risk of Serious Adverse Events (KQ 5), AChEIs and Memantine Compared With Placebo, by Medication Type

* Followup was at the end of trial.

† Pooled mean difference, 1.06 (95% CI: 0.88 to 1.29); k=7; n=4987; I^2^=0.0%, based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, 1.15 (95% CI: 0.87 to 1.52); k=6; n=2619; I^2^=10.4%, based on restricted maximum likelihood method with Knapp-Hartung modification

§ Both intervention and control groups received 5–10 mg/day rivastigmine plus memantine or placebo

ǁ Both intervention and control groups received 24 mg/day galantamine plus memantine or placebo

Abbreviations: AChEIs = acetylcholinesterase inhibitors; CG = control group; CI = confidence interval; IG = intervention group; Intv = intervention; KQ = key question; RR = risk ratio; mg = milligrams; N = sample size

This figure is a forest plot of serious adverse events, comparing intervention groups assigned to acetylcholinesterase inhibitors or memantine with control groups assigned to a placebo. The forest plot is organized by medication type.

Figure 14 Pooled Analysis of Risk of Withdrawals Due to Adverse Events (KQ 5), AChEIs and Memantine Compared With Placebo, by Medication Type

* Followup was at the end of trial.

† Pooled mean difference, 2.21 (95% CI: 1.43 to 3.42); k=8; n=3131; I^2^=57.0% based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, 1.26 (95% CI: 0.94 to 1.70); k=9; n=3288; I^2^=0.0%, based on restricted maximum likelihood method with Knapp-Hartung modification

§ Both intervention and control groups received 5–10 mg/day rivastigmine plus memantine or placebo

Abbreviations: AChEIs = acetylcholinesterase inhibitors; CG = control group; CI = confidence interval; IG = intervention group; Intv = intervention; KQ = key question; RR = risk ratio; mg = milligrams; N = sample size

This figure is a forest plot of withdrawals due to adverse events, comparing intervention groups assigned to acetylcholinesterase inhibitors or memantine with control groups assigned to a placebo. The forest plot is organized by medication type.

###### Galantamine

Study and population characteristics. Ten fair- to good-quality trials enrolling 7,464 participants assessed the effectiveness of galantamine for cognitive impairment. Only one galantamine study—of 2,045 participants with AD—was published after the last review.^207^ Five studies (50%) recruited patients in part or fully from the United States. Trials were conducted for 3 to 12 months, with a median of 6 months. All galantamine studies recruited patients with dementia; most studies (k=8; n=6,084) enrolled patients with AD, while one study enrolled patients with VaD (n=788)^204^ and one study enrolled patients with AD (48%), VaD (43%), or other dementias (9%) (n=592).^206^ None of the trials of galantamine included patients with MCI. The mean baseline MMSE score was 19.1, and 59 percent of participants were women. Six studies reported race, with white participants accounting for 91 to 100 percent of the sample. Only one galantamine study characterized the education level of the sample; it reported a mean education of 11 years.^209^

Intervention characteristics. The daily dosage of galantamine ranged from 8 to 36 mg, with most trials giving 16 to 24 mg per day. Studies generally titrated doses weekly to monthly until the target dose was reached. All control participants were given placebo.

##### Results

Cognitive function. All 10 studies of galantamine reported the effect of the medication on global cognitive function, using the ADAS-Cog or the MMSE. The pooled between-group mean differences in change in the ADAS-Cog score was 2.13 points in favor of those randomized to receive galantamine (MD, −2.13 [95% CI, −2.94 to −1.32]; k=9; n=3,786; I^2^=65.9%) over 3 to 6 months (Figure 9). Four studies^206,^ ^210–212^ reported a higher percentage of patients treated with galantamine compared to the placebo group improving by 4 points or more on the ADAS-Cog 11 (difference in proportion improving between groups ranging from 12% to 17%, with three studies reporting statistically significant differences). Only one study of 1,765 patients with AD reported MMSE findings,^207^ with a mean between-group difference of 0.58 points (95% CI, 0.26 to 0.90) over 12 months (Figure 10). There was no apparent difference in the effectiveness of galantamine among those with AD vs. VaD.

Global function. Nine of the 10 galantamine studies reported a global function outcome. Eight of these reported global function outcomes using the CIBIC+ dichotomized according to the number of patients whose global function was maintained or improved vs. those whose global function declined over time. The relative risk indicated a 21 percent higher likelihood of improvement or maintenance in global functioning among those on galantamine vs. placebo at 3 to 6 months (RR, 1.21 [95% CI, 1.11 to 1.31]; k=8; n=3,486; I^2^=56.2%) (Figure 11). Five studies reported global function using the CIBIC+ on a continuous scale. In all studies, those on galantamine had higher global function scores (5.3) vs. those on placebo (5.1), and two of these trials found that difference to be statistically significantly different.^209,^ ^212^

Physical function. All but one trial of galantamine reported a measure of ADLs or IADLs. Six of the trials demonstrated a benefit in physical function for at least some subgroups taking galantamine at doses of 16 to 32 mg per day compared with those taking placebo. Various instruments and scales were used, so the magnitude of the differences is hard to compare. In most cases, the differences between groups were small, ranging from about 1 to 4 points.

Neuropsychiatric symptoms. Four trials of galantamine evaluated behavioral and neuropsychiatric symptoms using the 10- or 12-item NPI. Findings were mixed. Two studies reported significant differences favoring galantamine in behavioral and neuropsychiatric symptoms for those taking 14 to 24 mg of galantamine per day compared with those taking placebo at 5 or 6 months.^206,^ ^211^ In contrast, there were no such differences in two studies of 8 to 32 mg of galantamine per day at 3 to 6 months.^205,^ ^210^ Of note, one study of 978 patients with AD found differences in the NPI-10 at 5 months that favored galantamine at doses of 16 to 24 mg per day, but not at doses of 8 mg per day.^211^

Other outcomes. None of the trials of galantamine reported QOL measures or rates of institutionalization. One study examined caregiver burden using the NPI-10 and found no difference between groups. Only one trial carefully ascertained mortality and was intended to determine whether there was mortality benefit from galantamine treatment.^207^ This study reported an HR of 0.58 (95% CI, 0.37 to 0.89; p=0.011), indicating that patients treated with galantamine had a higher survival rate than those treated with placebo. The remaining studies reported mortality as part of their patient tracking and were not designed or powered to detect mortality differences between groups.

Harms. All 10 trials of galantamine reported harms. Total AEs were statistically significantly higher for those receiving galantamine treatment (73%) compared with the control group (63%) (RR, 1.14 [95% CI, 1.06 to 1.22]; k=9; n=6,004; I^2^=57.7%) (figure not shown). Eight of nine trials and one observational study reported SAEs with galantamine. Rates of SAEs were similar in those treated with galantamine (12%) vs. those taking placebo (11%) (RR, 1.06 [95% CI, 0.91 to 1.24]; k=7; n=4,987; I^2^=97.8%) (Figure 13). However, study withdrawals due to adverse events were statistically significantly higher in patients taking galantamine (14%) than in those taking placebo (7%) (RR, 1.98 [95% CI, 1.52 to 2.57]; k=10; n=6,147; I^2^=51.1%) (Figure 14).

###### Rivastigmine

Study and population characteristics. Eight fair- to good-quality trials involving 4,569 participants evaluated the effectiveness of rivastigmine for cognitive impairment, none published since the previous review. Four studies (50%) recruited patients partially or fully from the United States. Trials ran for a median of 6 months, with a range from 3 to 6 months. All studies evaluated rivastigmine for dementia, and none enrolled participants with MCI. Five studies enrolled participants with AD (n=3,699),^214,^ ^216,^ ^217,^ ^220,^ ^221^ two studies enrolled participants with VaD (n=750),^215,^ ^219^ and one study enrolled participants with LBD (n=120).^218^ Four studies reported on race; white participants ranged from 75 to 97 percent. Three studies reported mean years of education of 3.3, 9.3, and 9.9 years.^215,^ ^219,^ ^221^

Intervention characteristics. The daily dosage of rivastigmine ranged from 1 to 17 mg, with considerable variability in daily dosage. Timing of dose escalation also varied between studies, with dose changes usually occurring weekly or monthly. All eight trials delivered rivastigmine orally; one of these trials also included two groups randomized to a rivastigmine patch (9.5 mg or 17.4 mg per day).^221^ All control participants in all studies of rivastigmine were given placebo.

##### Results

Cognitive function. Differences in cognitive function favored rivastigmine over placebo at 3 to 6 months, although most differences were small. The pooled between-group mean difference in change in ADAS-Cog score favored rivastigmine by 2.43 points (MD, −2.43 [95% CI, −0.75 to −4.10]; k=5; n=2,618; I^2^=81.9%) over 3 to 6 months (Figure 9). Two studies^217,^ ^220^ reported a higher percentage of patients treated with rivastigmine compared to the placebo group improving by 4 points or more on the ADAS-Cog 11 (difference of 9% or 10% between groups, p<0.05 for both studies). The pooled between-group mean difference in change in MMSE score favoring rivastigmine was 0.88 points (95% CI, 0.28 to 1.49; k=6; n=2,415; I^2^=44.9%) (Figure 10). These findings held across dementia diagnoses, including AD and VaD.

Global function. Seven of eight rivastigmine studies reported global function and had sufficient data for a meta-analysis. In the five studies that presented dichotomous measures of global functioning (i.e., improved or maintained vs. declined), the relative risk indicated a 50 percent higher likelihood of improvement or maintenance in global functioning for those on rivastigmine compared with those on placebo at 3 to 6 months (RR, 1.50 [95% CI, 1.22 to 1.85]; k=5; n=1,934; I^2^=61.4%) (Figure 11). In the six studies that presented continuous measures of global function, meta-analysis of the SMD did not find an association between rivastigmine and global function at 6 months (SMD, −0.14 [95% CI, −0.36 to 0.08]; k=6; n=2,535; I^2^=85.7%) (Figure 12). All studies using the CIBIC+, however, demonstrated an improvement or less of a decline in global function (three out of four were statistically significantly different).

Physical function. Seven of eight rivastigmine trials reported physical function outcomes. Four trials found a benefit of rivastigmine at doses of 6 to 17.4 mg per day over 3 to 6 months, with between-group mean differences in change ranging from 1.80 to 3.40 points.^216,^ ^217,^ ^220,^ ^221^ Two studies also examined a dichotomous version of the Progressive Deterioration Scale and found a statistically significant difference in groups in favor of the group taking rivastigmine.^216,^ ^220^ Two studies found that doses of 1 to 4 mg per day of rivastigmine were not associated with differences in physical function outcomes, while doses of 6 to 12 mg per day were.^216,^ ^220^

Neuropsychiatric symptoms. Four of eight rivastigmine studies evaluated behavioral and neuropsychiatric symptoms in their trials using the 10- and 12-item versions of the NPI, with mixed results. One study found differences in behavioral and neuropsychiatric symptoms that favored rivastigmine at a dose of 12 mg per day compared with placebo at 5 months.^218^ However, the other three studies that reported such outcomes did not find differences between participants taking 3 to 17.4 mg of rivastigmine per day over 6 months compared with those taking placebo.^215,^ ^219,^ ^221^ One study examined the effect of rivastigmine on anxiety symptoms and found no statistically significant difference between the group taking rivastigmine and the group given placebo.^219^

Other outcomes. No rivastigmine studies reported on QOL measures or rates of institutionalization. While many of the studies reported mortality as part of their patient tracking throughout the trial, they were not designed or powered to detect mortality differences between groups.

Harms. All eight trials of rivastigmine plus one observational study reported AEs. Total AEs were statistically significantly higher among patients treated with rivastigmine (90%) vs. those on placebo (73%) (RR, 1.23 [95% CI, 1.12 to 1.35]; k=4; n=1,090; I^2^=0%) (figure not shown). While SAE rates were not significantly different between those receiving rivastigmine (14%) and those receiving placebo (12%) (RR, 1.15 [95% CI, 0.92 to 1.43]; k=6; n=2,619; I^2^=10.4%) (Figure 13), the results for individual studies were mixed, ranging from a 300 percent greater risk from rivastigmine to a 20 percent greater risk from placebo. Nevertheless, study withdrawals due to AEs were higher in those taking rivastigmine (13%) compared with those taking placebo (6%) (RR, 2.21 [95% CI, 1.54 to 3.17]; k=8; n=3,131; I^2^=57.0%) (Figure 14).

###### Memantine

Study and population characteristics. Twelve trials of fair- to good-quality, including four new trials, involving 4,189 participants examined memantine for cognitive impairment. Four studies (33%) recruited patients partially or fully from the United States. Trials were conducted for a median of 6 months and a range of 3 to 48 months. Eleven studies recruited persons with dementia, with nine studies recruiting persons with AD (n=3,229)^222–224,^ ^226,^ ^228–231,^ ^233^ and two studies recruiting persons with VaD (n=900).^227,^ ^232^ One study recruited persons with MCI (n=60).^225^ The mean baseline MMSE score was 17.8, a bit lower than in the trials of AChEIs, which is to be expected of a medication that has an FDA indication for moderate to severe AD. Women comprised 49 percent of memantine trial samples. Four studies were published after the last review, all of which recruited participants with AD (n=1,380).^223,^ ^224,^ ^226,^ ^229^ Seven studies reported race and one reported ethnicity data; white participants comprised 86 to 100 percent of samples, while Hispanic ethnicity comprised 11 percent of one sample. Two memantine trials reported education, with one study reporting that 78 percent of participants had at least a high school education^224^ and another reporting a mean education of 11.5 years for participants.^231^

Intervention characteristics. All trials of memantine used an oral daily dosage of 20 mg, most often achieved by titrating from a starting dose of 5 mg per day and increasing the dose weekly by 5 mg per day. Two studies required all participants (those in intervention and control groups) to be on the rivastigmine patch at 9.5 mg per day^223^ or galantamine at 24 mg per day.^229^ All trials were placebo-controlled, with the exception of one open-label study in which intervention participants received both memantine and rivastigmine and control participants received rivastigmine only (and no placebo).^223^

##### Results

Cognitive function. Differences in cognitive function with memantine were generally statistically significant for participants with cognitive impairment. Nine of 12 memantine trials had sufficient data to meta-analyze cognitive function results using the ADAS-Cog or the MMSE. The pooled between-group mean difference in change in ADAS-Cog score was small, but statistically significantly different (MD, −0.88 [95% CI, −0.11 to −1.65]; k=8; n=2,609; I^2^=78.1%) (Figure 9), whereas the pooled between-group mean difference in change in MMSE score was not (MD, 0.36 [95% CI, −0.31 to 1.04]; k=5; n=1,217; I^2^=33.2%) (Figure 10). One study had longer-term followup (4 years) and found no difference between the group given memantine and the group given placebo for cognitive function.^224^ Findings were clinically marginal regardless of type of cognitive impairment, including AD, VaD, and MCI.

Global function. A smaller proportion of memantine trials reported global function outcomes compared with trials of AChEIs. While the pooled analysis of five trials (n=1,396) reporting results for the CIBIC+ using the random-effects model resulted in a small association between memantine and global function favoring memantine (SMD in change, −0.14 [95% CI, −0.27 to −0.01]; k=5; n=1,396; I^2^=32.9%), this result was sensitive to the use of a REML model correcting for small samples, resulting in a more conservative and no longer statistically significant association (MD in change, −0.14 [95% CI, −0.33 to 0.05]; I^2^=32.9%) (Figure 12). Consistent with the continuous results, two studies reported a dichotomous measure of global function in favor of those on memantine, but this association was not statically significant after using the more conservative REML model (RR, 1.15 [95% CI, 0.49 to 2.69]; k=2; n=545) (Figure 11).

Physical function. Six of 12 memantine trials reported physical function outcomes. Only one study found statistically significant differences in physical function at 4 and 6 months (but not at 12 months) favoring memantine, but these differences were small in magnitude (between-group mean difference in change at 4 months, 0.48 [95% CI, 0.19 to 0.77] and at 6 months, 0.85 [95% CI, 0.51 to 1.19]).^229^ The other five trials found no differences in physical function in those exposed and unexposed to memantine. Additionally, only one study had longer-term followup (4 years) and found no difference between the group given memantine and the group given placebo for physical function.^224^

Neuropsychiatric outcomes. Eight memantine trials reported on behavioral and neuropsychiatric symptoms using the NPI-12. Findings were mixed, with some trials showing improved scores among those taking memantine and worse scores among those on placebo, whereas others reported the opposite (improvement among those on placebo, and not memantine), and only one trial reported a statistically significant benefit of memantine at 3 and 6 months.^228^ The one trial reporting longer-term outcomes found no difference at 4 years.^224^

Other outcomes. One study reported on institutionalization and found a lower rate of nursing home placement in those taking memantine (2/182) compared with those taking placebo (9/187) at 6 months.^226^ None of the trials reported measures of QOL. One study conducted a survival analysis and found no statistically significant difference in mortality between memantine and placebo groups over 4 years (HR, 1.06 [95% CI, 0.91 to 1.24]).^224^

Harms. All 12 trials of memantine reported on harms. Total AE rates were similar between those taking memantine (65%) and those taking placebo (62%) (RR, 1.04 [95% CI, 0.99 to 1.09]; k=11; n=3,414; I^2^=0%). Rates of SAEs for individual trials were mixed, with some suggesting as much as a 71 percent greater risk of SAEs in control participants and others reporting up to a 68 percent greater risk among those on memantine. Across studies, however, rates of SAEs were not different between intervention and control groups (RR, 0.88 [95% CI, 0.77 to 1.01]; k=10; n=3,350; I^2^=0%) (Figure 13). Likewise, and in contrast to the AChEIs, withdrawals due to AEs were not significantly different between patients receiving memantine (8%) and those receiving placebo (7%) (RR, 1.26 [95% CI, 0.98 to 1.62]; k=9; n=3,288; I^2^=0%) (Figure 14).

##### Other Medications and Supplements

We included 29 trials (n=6,489) that examined the benefits and/or harms of using other medications or supplements for cognitive impairment. Twenty-four of these studies were included in the previous review, while five were newly identified for this update. A variety of different medications and supplements were evaluated, including antihypertensives (k=1; n=385),^237^ HMG-CoA reductase inhibitors (also known as statins; k=4; n=1,153),^238–241^ NSAIDS (k=4; n=837),^242–245^ gonadal steroids (k=6; n=337),^246–251^ and dietary supplements such as vitamins or omega-3 fatty acids (k=14; n=3,777).^196,^ ^224,^ ^252–263^

In general, the primary effectiveness outcomes for these trials were measures of global cognitive function, most often the ADAS-Cog-11 or MMSE. In some trials, however, global cognitive function was a secondary outcome, whereas measures of physical function or domain-specific cognitive function, for example, were primary outcomes. Fewer than half of the studies reported a measure of global function. Of those that did, most (9 out of 12 studies) used the CIBIC+; the remaining studies used the CDR-SB and CDR alone or in addition to the CIBIC+. Patient mental and neuropsychiatric symptoms were measured in two-thirds of the trials, typically depression symptoms with a variety of instruments or composite neuropsychiatric symptoms with the NPI-12. A little more than half of the studies reported the effect of medications or supplements on physical function and few trials reported a measure of QOL. Harms-related outcomes were reported by 20 of the 29 the included trials.

Study, population, and intervention characteristics of all 29 trials are presented in Table 13 and Table 14. A summary of results for all included trials is provided in Table 15, while detailed results related to global function, global cognitive function, physical function, neuropsychiatric symptoms, and harms are presented in Appendix F.

Table 13 Other Medications and Supplements: Study Characteristics, by Agent (KQs 4 and 5)

Medication type | Medication | Author, year (Study name) | Quality | Country | N randomized | Population | Baseline MMSE, mean | Age, mean | Female, %
Antihypertensive | Discontinuation of antihypertensive | Moonen, 2015^*^,^237^; (DANTE) | Fair | NLD | 385 | MCI | 26^†^ | 81 | 59
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; (LEADe) | Fair | US | 640 | Dem | 22.0 | 74 | 52
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^ | Fair | US | 406 | Dem | 20.4 | 75 | 59
HMG-CoA reductase inhibitor | Simvastatin | Simons, 2002^240^ | Fair | DEU | 44 | Dem | 17.5 | 68 | 55
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; (Alzheimer’s Disease Cholesterol-Lowering Treatment (ADCLT) trial) | Fair | US | 63 | Dem | 20.8 | 78 | 36
NSAID | Naproxen | Aisen, 2003^242^ | Good | US | 229 | Dem | 20.9 | 74 | 53
NSAID | Indomethacin | de Jong, 2008^243^ | Fair | NLD | 51 | Dem | 19.6 | 72 | 65
NSAID | Ibuprofen | Pasqualetti, 2009^244^ | Fair | ITA | 132 | Dem | 20.0 | 74 | 63
NSAID | Celecoxib | Soininen, 2007^245^ | Fair | US, GBR, AUS, BEL, FIN, FRA, DEU, NLD | 425 | Dem | 19.7 | 74 | 55
Gonadal steroid | Estrogen | Henderson, 2000^247^ | Fair | US | 42 | Dem | 19.5 | 78 | 100
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^ | Good | US | 42 | Dem | 20.3 | 76 | 100
Gonadal steroid | Testosterone | Lu, 2006^248^ | Fair | US | 18 | Dem | 22.0 | 70 | 0
Gonadal steroid | Estrogen | Mulnard, 2000^249^ | Fair | US | 120 | Dem | 20.7 | 75 | 100
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^ | Fair | NOR | 65 | Dem | 21.9 | 81 | 100
Gonadal steroid | Estrogen | Wang, 2000^251^ | Fair | TWN | 50 | Dem | 16.2 | 72 | 100
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^ | Good | US | 409 | Dem | 21.0 | 76 | 56
Dietary supplement | B vitamins (including folic acid) | Connelly, 2008^253^ | Fair | GBR | 57 | Dem | 24.0 | 76 | 71
Dietary supplement | B vitamins (including folic acid) | de Jager, 2012^254^; (VITACOG) | Fair | GBR | 271 | MCI | NR | 77 | 64
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; (TEAM-AD VA) | Good | US | 613 | Dem | 21.0 | 79 | 3
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^ | Fair | SWE | 204 | Dem | 23.4 | 74 | 54
Dietary supplement | B vitamins (including folic acid) | Kwok, 2011^256^ | Fair | HKG | 140 | Dem | 16.6 | 78 | 64
Dietary supplement | Vitamin E | Petersen, 2005^196^ | Fair | US, CAN | 769 | MCI | 27.3 | 73 | 46
Dietary supplement | Omega-3 fatty acids | Phillips, 2015^*^,^257^ | Fair | GBR | 76 | MCI + Dem | NR | 71 | 55
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^ | Fair | US | 402 | Dem | 20.7 | 76 | 52
Dietary supplement | Vitamin E | Sano, 1997^259^ | Good | US | 169 | Dem | 12.3 | 73 | 66
Dietary supplement | Omega-3 and LA | Shinto, 2014^*^,^260^ | Fair | US | 39 | Dem | 21.8 | 76 | 44
Dietary supplement | Omega-3 fatty acids - DHA | Sinn, 2012^261^ | Fair | AUS | 54 | MCI | 27.2 | 74 | 32
Dietary supplement | Multivitamin | Sun, 2007^262^ | Fair | JPN | 89 | Dem | 18.7 | 75 | 49
Dietary supplement | Omega-3 fatty acids | Yurko-Mauro, 2010^263^ | Good | US | 485 | MCI | 28.2 | 70 | 58

* New Study

† Median

Abbreviations: AUS = Australia; AUT = Austria; BEL = Belgium; CAN = Canada; CHE = Switzerland; CZE = Czech Republic; Dem = Dementia; DEU = Germany; DNK = Denmark; ESP = Spain; EST = Estonia; FIN = Finland; FRA = France; GBR = Great Britain/United Kingdom; GRC = Greece; GTM = Guatemala; HKG = Hong Kong; IRL = Ireland; ISR = Israel; ITA = Italy; JPN = Japan; KOR = Korea; LEADe = Lipitor’s Effect in Alzheimer’s; Dementia; LVA = Latvia; LTU = Lithuania; MCI = mild cognitive impairment; MEX = Mexico; MMSE = Mini-Mental State Examination; N = number of participants; NLD = Netherlands; NOR = Norway; NR = not reported; NZL = New Zealand; PER = Peru; POL = Poland; PRT = Portugal; ROU = Romania; RUS = Russia; SVK = Slovakia; SVN = Slovenia; SWE = Sweden; TWN = Taiwan; UKR = Ukraine; VEN = Venezuela; ZAF = South Africa

Table 14 Other Medications and Supplements: Intervention Characteristics, by Agent (KQs 4 and 5)

Author, year Quality | Country | Pop cat | Medication (total daily dose) | Duration, weeks | Intervention details | CG description
Moonen, 2015^*^,^237^; Fair | NLD | MCI | Discontinuation of antihypertensive treatment | 16 | During a 6-week period after randomization, the discontinuation of antihypertensive treatment according to an algorithm composed by the investigators; and until a maximum increase of 20 mm Hg in SBP was reached. Treatment was restarted when DBP was 120 mm | Usual care (continuation of anti-hypertensive treatment)
Feldman, 2010^238^; Fair | US | Dem | Atorvastatin (80 mg) | 72 | 80 mg qd and donepezil 10 mg qd | Placebo + donepezil (10 mg qd)
Sano, 2011^239^; Fair | US | Dem | Simvastatin (40 mg) | 78 | Started at 20 mg qd of simvastatin for 6 weeks and increased to 40-mg qd for remainder of 18-month study. | Placebo
Simons, 2002^240^; Fair | DEU | Dem | Simvastatin (80 mg) | 26 | 40 mg qd for 4 weeks; 80 mg qd for rest of the study | Placebo
Sparks, 2005^241^; Fair | US | Dem | Atorvastatin (80 mg) | 52 | 80 mg qd (given two 40 mg tablets qd) | Placebo
Aisen, 2003^242^; Good | US | Dem | Naproxen (440 mg) | 52 | 220 mg bid | Placebo
de Jong, 2008^243^; Fair | NLD | Dem | Indomethacin (100 mg) | 52 | 50 mg bid and omeprazole 20 mg qd | Placebo bid + omeprazole (20 mg qd)
Pasqualetti, 2009^244^; Fair | ITA | Dem | Ibuprofen (800 mg) | 52 | 400 mg bid | Placebo + esomeprazole (20 mg) placebo
Soininen, 2007^245^; Fair | US, GBR, AUS, BEL, FIN, FRA, DEU, NLD | Dem | Celecoxib (400 mg) | 52 | 200 mg bid | Placebo
Henderson, 2000^247^; Fair | US | Dem | Estrogen (1.25 mg) | 16 | Given daily as a single oral tablet of 1.25 mg for 16 weeks. | Placebo
Henderson, 2015^*^,^246^; Good | US | Dem | Estrogen (120 mg) | 52 | Started at two 60-mg tablets qd and continued through the end of the study. | Placebo
Lu, 2006^248^; Fair | US | Dem | Testosterone (75 mg) | 24 | Applied three packets of 25 mg of T-gel on three different sites in the morning after showering or bathing for total dose of 75 mg. | Placebo
Mulnard, 2000^249^; Fair | US | Dem | IG1: Estrogen (0.625 mg); IG2: Estrogen (1.24 mg) | 52 | IG1: Given one 0.625 mg and one identical placebo tablet qd for 12 months followed by a 3 month single-blind placebo washout period; IG2: Given two 0.625 mg tablets qd for 12 months followed by a 3 month single-blind placebo washout period | Placebo
Valen-Sendstad, 2010^250^; Fair | NOR | Dem | Estrogen plus progestin (1.5 mg) | 52 | Given 1 tablet containing 1 mg of estradiol and 0.5 mg norethisterone qd | Placebo
Wang, 2000^251^; Fair | TWN | Dem | Estrogen (1.25 mg) | 12 | Given 1.25 mg of conjugated estrogen (Premarin); taken orally qd | Placebo
Aisen, 2008^252^; Good | US | Dem | B vitamins (including folic acid) (31 mg) | 78 | 31 mg qd for 78 weeks | Placebo
Connelly, 2008^253^; Fair | GBR | Dem | B vitamins (including folic acid) (1 mg) | 26 | 1 mg qd combined with AChEI of clinician’s choice | Placebo and AChEI of clinician’s choice
de Jager, 2012^254^; Fair | GBR | MCI | B vitamins (including folic acid) (0.8 mg folic acid, 0.5 mg cyanocobalamin and 20 mg pyridoxine HCl) | 104 | NR | Placebo
Dysken, 2014^*^,^224^; Good | US | Dem | Vitamin E (2000 IU) | 208 | Alpha tocopherol at 1000 IU bid. Memantine placebo was titrated over 4 weeks. | Placebo
Freund-Levi, 2006^255^; Fair | SWE | Dem | Omega-3 fatty acids (4 g) | 26 | Four 1g capsules qd | Isocaloric placebo oil (1 g corn oil, 0.6 g linoleic acid); vitamin E 4 mg added to each packet.
Kwok, 2011^256^; Fair | HKG | Dem | B vitamins (including folic acid) (6 mg) | 104 | | Placebo
Petersen, 2005^196^; Fair | US, CAN | MCI | Vitamin E (2000 IU) and multivitamin | 36 | Started at 1000 IU qd, then increased to 2000 IU (1000 IU bid) after 6 weeks | Placebo + multivitamin containing 15 IU vitamin E
Phillips, 2015^*^,^257^; Fair | GBR | MCI + Dem | Omega-3 fatty acids (625 mg DHA + 600 mg EPA) | 16 | Started at a total of 625 mg of DHA and 600 mg of EPA | Placebo
Quinn, 2010^258^; Fair | US | Dem | Omega-3 fatty acids (2 g) | 78 | 1 g bid | Placebo
Sano, 1997 Good | US | Dem | Vitamin E (1.818 g) | 104 | 0.909 g bid | Placebo
Shinto, 2014^*^,^260^; Fair | US | Dem | IG1: Omega-3 fatty acids (675 mg DHA + 975 mg EPA) | 52 | IG1: Fish oil concentrate containing a daily dose of 675 mg DHA + 975 mg EPA | Placebo
Sinn, 2012^261^; Fair | AUS | MCI | IG1: Omega-3 fatty acids – DHA (1.95 g); IG2: Omega-3 fatty acids – EPA (1.83 g) | 26 | IG1: 1.95 g qd; IG2: 1.83 g qd | Placebo (safflower oil containing 2.2 g linoleic acid qd)
Sun, 2007^262^; Fair | JPN | Dem | Multivitamin (Mecobalamin [0.5 mg] + multivitamin supplement that contained folic acid, pyridoxine HCl, ferrous [60 mg], nicotinamide [10 mg], calcium carbonate [250 mg], riboflavin [2 mg], thiamine mononitrate [3 mg], calcium pantothenate [1 mg], ascorbic acid [100 mcg], iodine [100 mcg], copper [150 mcg], vitamin B12 [3 mcg], vitamin A (4,000 IU) and vitamin D3 [400 IU]) | 26 | To be taken after breakfast. | Placebo
Yurko-Mauro, 2010^263^; Good | US | MCI | Omega-3 fatty acids (900 mg) | 24 | 900 mg qd | Placebo

* New Study

Abbreviations: AChEI = acetyl-cholinesterase-inhibitor; AUS = Australia; BEL = Belgium; bid = twice a day; CAN = Canada; CG = control group; cm^2^ = square centimeter; DBP = diastolic blood pressure; Dem = Dementia; DEU = Germany; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FIN = Finland; FRA = France; g = grams; GBR = Great Britain/United Kingdom; HKG = Hong Kong; IG = intervention group; ITA = Italy; IU = International Unit; JPN = Japan; KOR = Korea; LVA = Latvia; LTU = Lithuania; MCI = mild cognitive impairment; mcg = microgram; mg = milligram; MMSE = Mini-Mental State Examination; N = number of participants; NLD = Netherlands; NOR = Norway; Pop cat = population category; qd = once a day; SBP = systolic blood pressure; SWE = Sweden; tid = three times a day; TWN = Taiwan

Table 15 Other Medications and Supplements: Summary of Results, by Agent (KQs 4 and 5)

Medication type | Medication | Author, year Quality | Pop cat | N rand | Age, mean | FU (mo.) | Global Function | Global Cognitive Function | Domain-specific Cognitive Function | Physical Function | Neuro Symptoms | Other
Antihypertensive | Discontinuation of antihypertensive | Moonen, 2015*^237^; Fair | MCI | 385 | 81 | 4 | NR | ↔ (MMSE) | ↔ (EF, Memory) | ↔ (ADL/IADL) | ↔ (Dep) | ↔ (QOL)
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | 640 | 74 | 18 | ↔ (CIBIC+, CDR-SB) | ↔ (ADAS-Cog 11, MMSE) | NR | ↔ (ADL/IADL) | ↔ (NPS) | NR
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | 406 | 75 | 18 | NR | ↔ (ADAS-Cog 11, MMSE) | NR | ↔ (ADL/IADL) | ↔ (NPS) | NR
HMG-CoA reductase inhibitor | Simvastatin | Simons, 2002^240^; Fair | Dem | 44 | 68 | 6 | NR | ↔ (ADAS-Cog 11), ↑ (MMSE) | NR | NR | NR | NR
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | 63 | 78 | 12 | ↔ (CIBIC+) | ↔ (ADAS-Cog 11, MMSE) | NR | ↔ (ADL/IADL) | ↑ (Dep) | NR
NSAID | Naproxen | Aisen, 2003^242^; Good | Dem | 229 | 74 | 12 | ↔ (CDR-SB) | ↔ (ADAS-Cog 11) | NR | ↔ (ADL/IADL) | ↔ (NPS) | ↔ (QOL)
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | 51 | 72 | 12 | ↔ (CIBIC+) | ↔ (ADAS-Cog 11, MMSE) | NR | NR | ↔ (NPS) | ↔ (CGR Burden)
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | 132 | 74 | 12 | ↔ (CDR-SB, CIBIC+) | ↔ (ADAS-Cog 11, MMSE) | NR | ↔ (ADL, IADL) | ↔ (Dep, NPS) | ↔ (CGR Anxiety, Depression, Burden) ↔ (Institutionalization)
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | 425 | 74 | 6 | ↔ (CIBIC+) | ↔ (ADAS-Cog 11, ADAS-Cog 11 [D], MMSE) | NR | NR | ↔ (NPS) | ↔ (QOL)
Gonadal steroid | Estrogen | Henderson, 2000^247^; Fair | Dem | 42 | 78 | 4 | ↔ (CIBIC+, CIBIC+ [D]) | ↔ (ADAS-Cog 11, ADAS-Cog 11 [D]) | ↔ (Attention), ↑ (EF), ↔* (Memory) | ↔ (IADL) | ↔ (Dep) | NR
Gonadal steroid | Estrogen | Henderson, 2015*^246^; Good | Dem | 42 | 76 | 12 | ↔ (CDR, CDR-SB) | ↔ (ADAS-Cog 11, MMSE) | ↔ (Attention, EF, Language), ↔* (Memory) | ↔ (ADL/IADL) | ↔ (NPS) | ↔ (CGR Burden)
Gonadal steroid | Testosterone | Lu, 2006^248^; Fair | Dem | 18 | 70 | 6 | ↔ (CIBIC+) | ↔ (ADAS-Cog 11) | ↔ (EF, Memory) | NR | ↔ (Dep, NPS) | ↔ (QOL)
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | 120 | 75 | 12 | IG1: ↓ (CDR), ↔ (CIBIC+, CIBIC+ [D]); IG1: ↓ (CDR), ↔ (CIBIC+, CIBIC+ [D]) | IG1: ↔ (ADAS-Cog 11, MMSE); IG2: ↔ (ADAS-Cog 11, MMSE) | IG1: ↔ (Attention, Language, Memory); IG2: ↔ (Attention, Language, Memory) | ↔ (ADL) | ↔ (Dep) | NR
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^; Fair | Dem | 65 | 81 | 12 | IG1: ↔ (GDS) | ↔ (MMSE) | ↔ (Attention, Language, Memory) | ↔ (ADL) | ↔ (Dep) | NR
Gonadal steroid | Estrogen | Wang, 2000^251^; Fair | Dem | 50 | 72 | 3 | ↔ (CDR, CIBIC+) | ↔ (MMSE) | NR | NR | ↔ (Anx, Dep, NPS) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | 409 | 76 | 18 | ↔ (CDR-SB) | ↔ (ADAS-Cog 11, MMSE) | NR | ↔ (ADL/IADL) | ↔ (NPS) | ↔ (QOL)
Dietary supplement | B vitamins (including folic acid) | Connelly, 2008^253^; Fair | Dem | 57 | 76 | 6 | ↑ (Unspecified [D]) | ↔ (MMSE) | ↔ (Attention) | ↑ (IADL) | NR | NR
Dietary supplement | B vitamins (including folic acid) | de Jager, 2012^254^; Fair | MCI | 271 | 77 | 24 | NR | NR | ↑ (EF) ↔ (Language, Memory) | NR | ↔ (Dep) | NR
Dietary supplement | Vitamin E | Dysken, 2014*^224^; Good | Dem | 613 | 79 | 48 | NR | ↔ (ADAS-Cog 11, MMSE) | NR | ↑ (ADL/IADL) | ↔ (NPS) | NR
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^; Fair | Dem | 204 | 74 | 6 | ↔ (CDR, CDR-SB) | ↔ (ADAS-Cog 13, MMSE) | NR | ↔ (ADL/IADL) | ↔ (Dep, NPS) | NR
Dietary supplement | B vitamins (including folic acid) | Kwok, 2011^256^; Fair | Dem | 140 | 78 | 24 | NR | ↔ (MDRS, MMSE) | ↔ (Attention, EF, Memory) | NR | ↔ (Dep, NPS) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | 769 | 73 | 36 | ↔ (CDR-SB, ↔ GDS) | ↔ (ADAS-Cog 11, ADAS-Cog 13, MMSE) | ↔* (EF, Language) ↔ (Memory) | ↔ (IADL) | NR | ↔ (Dementia Incidence)
Dietary supplement | Omega-3 fatty acids | Phillips, 2015*^257^; Fair | MCI + Dem | 76 | 71 | 4 | NR | NR | ↔ (Attention, EF, Language, Memory) | ↔ (ADL/IADL) | ↔ (Dep) | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | 402 | 76 | 18 | ↔ (CDR-SB) | ↔ (ADAS-Cog 11, MMSE) | NR | ↔ (ADL/IADL) | ↔ (NPS) | NR
Dietary supplement | Vitamin E | Sano, 1997^259^; Good | Dem | 169 | 73 | 24 | ↔ (CDR [D]) | ↔ (ADAS-Cog 11, MMSE) | NR | ↑ (ADL [D]) | NR | ↔ (Institutionalization)
Dietary supplement | Omega-3 and LA | Shinto, 2014*^260^; Fair | Dem | 39 | 76 | 12 | NR | IG1: ↔ (ADAS-Cog 11), ↔ (MMSE); IG2: ↔ (ADAS-Cog 11), ↑ (MMSE) | NR | IG1: ↔ (ADL), ↑ (IADL); IG2: ↔ (ADL), ↑ (IADL) | NR | NR
Dietary supplement | Omega-3 fatty acids - DHA | Sinn, 2012^261^; Fair | MCI | 54 | 74 | 6 | NR | NR | IG1: ↔ (Attention, Language), ↔* (EF); IG2: ↔ (Attention, EF, Language) | NR | IG1: ↑ (Dep); IG2: ↑ (Dep) | ↔ (QOL)
Dietary supplement | Multivitamin | Sun, 2007^262^; Fair | Dem | 89 | 75 | 6 | NR | ↔ (ADAS-Cog 11, MMSE) | ↔* (Memory) | ↔ (ADL, IADL) | NR | NR
Dietary supplement | Omega-3 fatty acids | Yurko-Mauro, 2010^263^; Good | MCI | 485 | 70 | 6 | NR | ↔ (MMSE) | ↑ (EF), ↔* (Memory) | ↔ (ADL) | ↔ (Dep) | NR

NOTE: Arrows represent study-reported results.

Symbol Legend:

↑ = Statistically significant between-group difference in favor of intervention group

↔ = No statistically significant difference between groups or no clear between-group difference (not reported).

↓= Statistically significant between-group difference in favor of control group

Abbreviations: ADAS-Cog 11 = Alzheimer’s Disease Assessment Scale-cognitive subscale; 11-item; ADAS-Cog 13 = Alzheimer’s Disease Assessment Scale-cognitive subscale; 13-item; ADL = Activities of Daily Living; Anx = anxiety; CDR = Clinical Dementia Rating Scale; CDR-SB = Clinical Dementia Rating Scale Sum of Boxes; CIBIC+ = Clinician’s Interview-Based Impression of Change with caregiver’s input; D = dichotomized; Dem = dementia; Dep = depression; DHA = docosahexaenoic acid; EF = executive functioning; FU = followup; GDS = global deterioration scale; HMG-CoA = β-Hydroxy β-methylglutaryl-CoA; IADL = Instrumental Activities of Daily Living; IG = intervention group; LA = linoleic acid; MCI = mild cognitive impairment; MMSE = Mini-Mental State Examination; NPS = Composite neuropsychiatric symptoms; NR = not reported; N rand = number of participants randomized; NSAID = Nonsteroidal Anti-inflammatory Drug; Pop cat = population category; QOL = quality of life

###### Antihypertensives

We identified one new study on the effects of discontinuing antihypertensives among participants with cognitive impairment.^237^ For 385 participants with MCI who were randomized to discontinue or continue their antihypertensive medication, there were no differences between groups in global cognitive function, executive function, memory, physical function, depressive symptoms, or QOL at 4 months. Similarly, no differences in rates of SAEs, including death, hospitalizations, or vascular events, were seen between those continuing (7.0%) or discontinuing (6.5%) their antihypertensives (p-value not reported).

###### HMG-CoA Reductase Inhibitors

In the four studies (n=1,153) that examined the effects of statins (atorvastatin [k=2] and simvastin [k=2]) for patients with AD dementia, none found differences between intervention and control groups on reported outcomes of global function, global cognitive function, or physical function at 6 to 18 months.^238–241^ One trial (n=63) out of three examining neuropsychiatric symptoms found a difference in depression symptoms that favored the intervention of atorvastatin at 80 mg per day at 12 months,^241^ while the other two found no difference.^238,^ ^239^ None of these three studies found a difference in total neuropsychiatric symptom scores between intervention and control groups.

Two HMG-CoA studies reported harms, with no significant differences in total or serious AEs between the intervention and control groups. While neither study found a difference in mortality rates between groups, they were neither designed nor powered to detect a difference in mortality between the intervention and control.

###### NSAIDs

None of the four studies of NSAIDs (n=837) (celecoxib 40 mg, ibuprofen 800 mg, indomethacin 100 mg, or naproxen 220 mg daily) found differences between intervention and control groups on reported outcomes of global function, global cognitive function, physical function, neuropsychiatric symptoms, QOL, institutionalization, or caregiver burden at 6 to 12 months in participants with AD dementia.^243–245,^ ^252^

All four studies of NSAIDs reported on harms. One trial reporting total AEs found that 229/285 participants (80%) in the intervention and 105/140 participants (75%) in the control group experienced at least one AE, with “generally no significant differences in AEs between groups.”^245^ Two trials reported no statistically significant difference in SAEs; in one trial, 32/140 participants (23%) in the intervention and 73/285 participants (26%) in the control group experienced an SAE,^245^ whereas in the other smaller trial, 5/26 participants (19%) in the intervention group and 1/25 participants (4%) in the control group reported an SAE.^243^ None of the four trials reported a statistically significant difference in withdrawals due to AEs. These studies were not designed nor powered to detect a difference in mortality between groups.

###### Gonadal Steroids

Six studies (n=337), including one new trial, examined the effects of gonadal steroids on patients with dementia, including five studies of estrogen^246,^ ^247,^ ^249–251^ (one of which also used progestin^250^) and one study of testosterone.^248^ Daily doses of estrogen for women included 0.625 mg to 1.25 mg of estradiol or conjugated equine estrogens (Premarin) or 120 mg of raloxifene, while daily doses of progesterone for women were 0.5 mg daily; daily doses of transdermal or topical testosterone for men were 75 mg daily. No studies of gonadal steroids showed differences in reported outcomes that favored the intervention, including global function, global cognitive function, domain-specific cognitive function, physical function, neuropsychiatric symptoms, caregiver burden, or QOL. However, two studies of estrogen or estrogen plus progestin found differences in global function at 1 year that favored the control group.^249,^ ^250^

Only two of the six trials reported AEs, with both finding greater AEs among those on the study medication vs. placebo.^246,^ ^250^ One of the studies, however, found more SAEs reported in participants receiving placebo (3 events/32 participants [9.4%]) than in those receiving estrogen plus progestin (0 events/33 participants [0%]; p-value not reported).^250^ However, these studies were small and in some cases, events were rare. While four of the studies on gonadal steroids reported mortality,^246,^ ^249–251^ they were not powered nor designed to detect differences in mortality between groups.

###### Dietary Supplements

B vitamins. Four studies (n=877) evaluated the efficacy and safety of B vitamin supplementation in the treatment of dementia.^252–254,^ ^256^ Specific supplementation included folic acid,^253^ folic acid plus vitamins B_6_ and B_12,_^252,^ ^254^ and folic acid plus B_12._^256^ One trial^252^ required participants to have normal folic acid, B_12,_ and homocysteine levels to be eligible to participate. The other three trials did not restrict inclusion based on baseline homocysteine levels (although no participants were found to have deficiencies) and conducted subanalyses among those with high vs. low baseline levels. One 6-month study of 57 individuals with AD who were on AchEIs found that randomization to folic acid was associated with a difference in change from baseline in a combined measure of IADLs and social behavior favoring the intervention at 6 months.^253^ There were no differences in global cognitive function or attention between groups and no significant differences between those with high vs. normal baseline homocysteine levels. Another larger study of 271 participants with MCI found differences in executive functioning that favored those taking B vitamins compared with those on placebo at 24 months, but found no differences in language, memory, or depression.^254^ In subanalyses, there were differences in global cognition and memory favoring the intervention for patients with baseline homocysteine levels above the median. In the remaining two studies, there were no differences in global function, global cognitive function, domain-specific cognitive function, physical function, or neuropsychiatric symptoms for patients with dementia who were or were not exposed to B vitamins.^252,^ ^256^

In two of four studies reporting harms, there were no differences between intervention and control groups in total AEs and SAEs.^252,^ ^254^ One study reported mortality but was not designed or powered to detect a difference in mortality between groups.^252^

Vitamin E. Three trials, one of which we identified in this update, reported on the effects of vitamin E for cognitive impairment (n=1,551).^196,^ ^224,^ ^259^ One new parallel group RCT randomized 613 patients with dementia to memantine, vitamin E (alpha tocopherol), or combination memantine plus vitamin E, or placebo, and found differences in ADLs and IADLs that favored vitamin E at 48 months, but no differences in global cognitive functioning or neuropsychiatric symptoms.^224^ Two other vitamin E studies, one in patients with dementia and another in patients with MCI who were also on a multivitamin, did not find differences in reported outcomes of global function, global cognitive function, executive function, language, memory, physical function, neuropsychiatric symptoms, or rates of institutionalization between intervention and control groups at 24 to 36 months.^196,^ ^259^

The two vitamin E studies that reported AE rates found no differences between intervention and control groups.^196,^ ^224^ In the longer-term trial of memantine, vitamin E, and combination memantine and vitamin E vs. placebo, there were no differences in rates of SAEs comparing vitamin E alone vs. placebo, whereas those on memantine alone or combined memantine and vitamin E did experience greater frequencies of SAEs.^224^ This same study conducted a survival analysis and found no statistically significant difference in survival between vitamin E and placebo groups over 48 months (HR, 0.87 [95% CI, 0.67 to 1.13]).^224^ The remaining two studies were not designed or powered to find differences in mortality rates between intervention and control groups.

Omega-3 fatty acids. Six studies (n=1,260), including two new studies, reported on the effects of omega-3 fatty acids on cognition, finding mixed results.^255,^ ^257,^ ^258,^ ^260,^ ^261,^ ^263^ One study of 39 patients with dementia found that one formulation of omega-3 fatty acids (docosahexaenoic acid [DHA] 675 mg + eicosapentaenoic acid (EPA) 975 mg/day) was associated with better IADL scores compared with controls, while another formulation (DHA 675 mg + EPA 975 mg + linoleic acid 600 mg/day) was associated with both better IADL scores and better MMSE scores (but not ADAS-Cog scores) compared with controls.^260^ Another study of 54 people with MCI found differences in depression outcomes at 6 months that favored the intervention groups, which took one of two formulations of omega-3 fatty acids (DHA 1.95 g/day or EPA 1.83 g/day), but no differences in attention, language, or executive function.^261^ Another study of 485 persons with MCI randomized to omega-3 fatty acids (DHA 900 mg/day) found differences in executive function at 6 months that favored the intervention, but no differences in global cognitive function, physical function, neuropsychiatric symptoms, or caregiver burden.^263^ The remaining three studies of omega-3 fatty acids (involving DHA or DHA + EPA) did not demonstrate differences between exposed and unexposed patients with MCI or dementia in global function, global cognitive function, domain-specific cognitive function, physical function, or neuropsychiatric symptoms at 4 to 18 months.^255,^ ^257,^ ^258^

Three of the six omega-3 fatty acid studies reported harms, and none reported differences in rates of total or serious AEs. These studies were not designed or powered to detect differences in deaths between intervention and control groups.

Multivitamins. The lone study of multivitamins (n=89) did not find any effects on reported outcomes of global cognitive function, memory, or physical function in 89 participants with dementia at 6 months.^262^ There were no differences in rates of AEs or SAEs between groups; deaths were not reported.

#### Nonpharmacologic Interventions

##### Patient-Level Nonpharmacologic Interventions

We identified 61 trials (n=7,847) that evaluated nonpharmacologic interventions targeting the patient directly, rather than the caregiver or patient-caregiver dyad. These interventions included: 1) cognitive training, rehabilitation, and/or stimulation (31 arms in 28 trials; n=3,212);^264–291^ 2) exercise interventions (21 trials; n=2,831);^292–312^ and 3) multicomponent and “other” interventions (16 trials; n=2,302).^280,^ ^291,^ ^309,^ ^312–324^ Almost two-thirds of these studies (39 studies) are new to this update; 22 were carried forward from the previous review.

The primary outcome in most patient-level nonpharmacologic interventions was a measure of global- or domain-specific cognitive function. Measures of physical function (ADLs and IADLs) and mental and neuropsychiatric symptoms were reported in approximately half of the trials, with various instruments used. Isolated trials also reported outcome measures related to institutionalization, conversion from MCI to dementia, global function, QOL, or caregiver burden. These results are only mentioned briefly, however, due to the sparse nature of these outcomes and concern of selective reporting.

Given the heterogeneity in interventions, we present results stratified by type of intervention. Study, population, and intervention characteristics for all nonpharmacologic patient-level interventions are presented in Table 16 and Table 17. A summary of results for all included trials is provided in Table 18, while detailed results are presented in Appendix G.

Table 16 Patient-Level Nonpharmacologic Interventions: Study Characteristics, by Intervention (KQs 4 and 5)

Author, year (Study name) | Quality | Country | N rand | Population | Baseline MMSE, mean | Age, mean | Female, % | AChEI or memantine use, %
Cognitive Stimulation, Training, and Rehabilitation
Amieva, 2016^*^,^277^ (ETNA3) | Good | FRA | 481 | Dem | 21.5 | 79 | 58 | 88
Belleville, 2018^291^ (MEMO+) | Fair | CAN | 145 | MCI | NR | 72 | 55 | NR
Bergamaschi, 2013^*^,^282^ | Fair | ITA | 32 | Dem | 21.1 | 78 | NR | 100
Buschert, 2011^271^ | Fair | DEU | 39 | MCI + Dem | 26.4 | 73 | 51 | 41
Cahn-Weiner, 2003^269^ | Fair | US | 34 | Dem | 24.7 | 77 | 59 | 100
Cavallo, 2016^*^,^286^ | Good | ITA | 80 | Dem | 22.9 | 76 | 64 | 92
Chapman, 2004^268^ | Fair | US | 54 | Dem | 20.9 | 76 | 54 | NR
Cove, 2014^*^,^279^ | Fair | GBR | 68 | Dem | 22.6 | 77 | 47 | 57
Fiatarone Singh, 2014^*^,^280^ (SMART[a]) | Fair | AUS | 78 | MCI | 27.0 | 70 | 68 | NR
Greenaway, 2012^273^ | Fair | US | 40 | MCI | 26.8 | 72 | 61 | NR
Herrera, 2012^*^,^283^ | Fair | FRA | 22 | MCI | 27.3 | 77 | 50 | NR
Hyer, 2016^*^,^287^ | Fair | US | 77 | MCI | 26 | 75 | 53 | 0
Jelcic, 2012^*^,^284^ | Fair | ITA | 40 | Dem | 24.7 | 82 | 82 | 0
Jeong, 2016^*^,^276^ | Fair | KOR | 293 | MCI | 25.7 | 70 | 63 | 34
Kallio, 2018^290^ (FINCOG) | Fair | FIN | 147 | Dem | 20.5 | 83 | 72 | 83
Kinsella, 2009^266^ | Fair | AUS | 54 | MCI | 26.0 | 77 | 57 | NR
Kurz, 2012^274^ (CORDIAL) | Fair | DEU | 201 | Dem | 25.1 | 74 | 44 | NR
Nousia, 2018^288^ | Fair | GRC | 50 | Dem | NR | 76 | 72 | NR
Olazaran, 2004^267^ | Fair | ESP | 84 | MCI + Dem | NR | 74 | 60 | 100
Orrell, 2014^*^,^281^ | Good | GBR | 236 | Dem | 17.8 | 83 | 64 | 32
Orrell, 2017^*^,^275^ | Good | GBR | 356 | Dem | 21.2 | 78 | 46 | 76
Pantoni, 2017 (RehAtt)^289^ | Fair | ITA | 46 | MCI | 26.4 | 75 | 35 | 0
Quayhagen, 1995^272^ | Fair | US | 63 | Dem | NR | 74 | 35 | NR
Rapp, 2002^270^ | Fair | US | 19 | MCI | 27.6 | 74 | 58 | 0
Troyer, 2008^264^ | Fair | CAN | 54 | MCI | 27.9 | 75 | 54 | NR
Tsantali, 2017^*^,^285^ | Fair | GRC | 63 | Dem | 22.9 | 74 | NR | 100
Tsolaki, 2011^265^ | Fair | GRC | 196 | MCI | 27.9 | 68 | 72 | 0
Vidovich, 2015^*^,^278^ (PACE) | Good | AUS | 160 | MCI | NR | 75 | 54 | NR
Exercise Interventions
Baker, 2010^298^ | Fair | US | 33 | MCI | 27.4 | 70 | 52 | NR
Blumenthal, 2018^309^ (ENLIGHTEN) | Fair | US | 160 | MCI | NR | 65 | 66 | NR
Dawson, 2016^*^,^307^ | Fair | US | 26 | Dem | 20.8 | 74 | 56 | NR
Doi, 2017^*^,^306^ | Good | JPN | 134 | MCI | 25.9 | 76 | 48 | 0
Ho, 2018^310^ | Fair | HKG | 204 | MCI + Dem | NR | 79 | 82 | NR
Hoffmann, 2016^*^,^304^ (ADEX) | Good | DNK | 200 | Dem | 23.9 | 70 | 56 | 96
Holthoff, 2015^*^,^305^ | Fair | DEU | 30 | Dem | 22.0 | 72 | 50 | 100
Hong, 2017^*^,^302^ | Fair | KOR | 25 | MCI | NR | 77 | 64 | NR
Karssemeijer, 2019^312^ | Fair | NLD | 115 | Dem | 22.4 | 80 | 46 | 21
Lam, 2011^295^ | Fair | HKG | 389 | MCI | 24.5 | 78 | 76 | NR
Lamb, 2018^308^ (DAPA) | Good | GBR | 494 | Dem | 21.9 | 77 | 61 | 55
Lautenschlager, 2008^294^ (FAB) | Good | AUS | 170 | MCI | NR | 68 | 51 | NR
Lazarou, 2017^*^,^301^ | Fair | GRC | 154 | MCI | 27.2 | 67 | 78 | NR
Liu-Ambrose, 2016^*^,^293^ (PROMOTE) | Fair | CAN | 70 | Dem | 26.4 | 74 | 51 | NR
Morris, 2017^*^,^303^ (ADEPT) | Good | US | 76 | MCI + Dem | 25.4 | 73 | 51 | NR
Pitkälä, 2013^*^,^292^ (FINALEX) | Good | FIN | 210 | Dem | 18.0 | 78 | 39 | 96
Schwenk, 2010^296^ | Fair | DEU | 61 | Dem | 21.4 | 82 | 64 | NR
Siu, 2018^311^ | Fair | HKG | 160 | MCI | 25.0 | NR | 74 | 0
Suzuki, 2012^299^ | Fair | JPN | 50 | MCI | 26.7 | 76 | 46 | NR
Venturelli, 2010^297^ | Fair | ITA | 30 | MCI + Dem | NR | 84 | NR | NR
Vreugdenhil, 2012^300^ | Fair | AUS | 40 | Dem | 22.0 | 74 | 60 | 63
Multicomponent and Other Interventions
Bae, 2019^322^ | Fair | JPN | 83 | MCI | 26.9 | 76 | 48 | NR
Bellantonio, 2008^313^ | Fair | US | 100 | Dem | 14.8 | 82 | 63 | NR
Belleville, 2018^291^ (MEMO+) | Fair | CAN | 145 | MCI | NR | 72 | 55 | NR
Blumenthal, 2018^309^ (ENLIGHTEN) | Fair | US | 160 | MCI | NR | 65 | 66 | NR
Burgener, 2008^314^ | Fair | US | 43 | Dem | 24.0 | 77 | 46 | NR
Jha, 2013^*^,^318^ | Fair | GBR | 48 | MCI + Dem | 22.0 | 79 | 67 | NR
Karssemeijer, 2019^312^ | Fair | NLD | 115 | Dem | 22.4 | 80 | 46 | 21
Marshall, 2015^*^,^317^ (Living Well with Dementia) | Fair | GBR | 58 | Dem | 23.0 | 76 | 57 | 81
Quinn, 2016^*^,^316^ (SMART[b]) | Good | GBR | 24 | Dem | 23.6 | 76 | 25 | NR
Richard, 2009^319^ | Fair | NLD | 123 | Dem | 22.3 | 76 | 57 | 32
Rovner, 2018^320^ | Good | US | 221 | MCI | 25.7 | 76 | 79 | 0
Shimada, 2017^323^ | Fair | JPN | 308 | MCI | 26.7 | 72 | 50 | 0
Straubmeier, 2017^324^ (DeTMAKS) | Fair | DEU | 453 | MCI + Dem | 19.6 | 81 | 61 | 28
Train the Brain Consortium, 2017^321^ (TTB) | Fair | ITA | 113 | MCI | 25.6 | 74 | 49 | NR
Wolfs, 2008^315^ | Fair | NLD | 230 | MCI + Dem | 20.0 | 78 | 64 | 14

* New study

Abbreviations: AChEI = acetyl-cholinesterase-inhibitor; ADEPT = Alzheimer’s Disease Exercise Program Trial; ADEX = Preserving Cognition, Quality of Life, Physical Health and Functional Ability in Alzheimer’s Disease: The Effect of Physical Exercise; AUS = Australia; CORDIAL= Cognitive Rehabilitation and Cognitive-behavioral Treatment for Early Dementia in Alzheimer Disease; DAPA = Dementia and Physical Activity; DeTMAKS = Dementia Day Care Motor, Activities of daily living, Cognitive, Social; DEU = Germany; ENLIGHTEN = Exercise and NutritionaL Interventions for coGnitive and Cardiovascular HealTh Enhancement; ESP = Spain; FAB = Fitness for the Aging Brain; FIN = Finland; FINALEX = Finnish Alzheimer Disease Exercise Trial; FINCOG = Finnish Cognitive Training Trial; MEMO = Methode d’Entrainement pour Memoire Optimale; MMSE = Mini-Mental State Examination; FRA = France; GBR = Great Britain/United Kingdom; GRC = Greece; HKG = Hong Kong; ITA = Italy; JPN = Japan; KOR = Korea; MCI = mild cognitive impairment; N = number of participants; NLD = Netherlands; NR = not reported; PACE = Promoting Healthy Ageing with Cognitive Exercise; PROMOTE = Promotion of the Mind Through Exercise; RehAtt = Rehabilitation of Attention; SMART(a) = Study of Mental and Resistance Training; SMART(b) = Self-management group intervention for people with early-stage dementia; TTB = Train the Brain

Table 17 Patient-Level Nonpharmacologic Interventions: Intervention Characteristics, by Intervention (KQs 4 and 5)

Author, year Quality | Country | Pop cat | Intervention type | Brief intervention group description | Duration, months | Brief control group description
Cognitive Stimulation, Training, and Rehabilitation
Amieva, 2016^*^,^277^; Good | FRA | Dem | IG1: Cognitive training; IG2: Cognitive rehabilitation | IG1: Group-based cognitive training for 1 d/wk, 90 min/d for first 3 months followed by maintenance sessions once every 6 months for the next 21 months plus separate caregiver support group sessions.; IG2: Individualized cognitive rehabilitation for 1 d/wk, 90 min/d over the first 3 months followed by maintenance sessions once every 6 months for the next 21 months plus ongoing caregiver support through telephone calls. | 24 | UC: Patients received usual care while caregivers were offered the same support group sessions as cognitive training intervention arm.
Belleville, 2018^291^; Fair | CAN | MCI | IG1: Cognitive training; IG2: Other | IG1: Group-based cognitive training for 1 d/wk, 120 min/d for 2 months followed by one intensive booster session delivered three months later.; IG2: Group-based cognitive behavioral therapy for 1 d/wk, 120 min/d for 2 months followed by one intensive booster session delivered three months later. | 2.2 | WL: Offered cognitive training intervention after study ended.
Bergamaschi, 2013^*^,^282^; Fair | ITA | Dem | Cognitive training | Group-based cognitive training over 5 one-month cycles over 1 year. Each cycle was 5 d/wk (20 sessions total) for 90 min/d. | 12 | Sham: Group-based cognitive activities during multiple, daily sessions (total # of sessions NR).
Buschert, 2011^271^; Fair | DEU | MCI + Dem | Cognitive stimulation and training | Group-based cognitive stimulation therapy and cognitive training over 20 sessions for 90 min/d over 6 months; stimulation and training activities were conducted and tailored separately for MCI and AD patients. | 6 | Sham: Paper-pencil cognitive exercises for self-study plus 6 monthly group-based sessions to review self-study exercises.
Cahn-Weiner, 2003^269^; Fair | US | Dem | Cognitive training | Group-based cognitive training focused specifically on memory training for 1 d/wk over 6 weeks. | 2 | BI: Group-based general education and support regarding aging and dementia 1 d/wk for 6 weeks.
Cavallo, 2016^*^,^286^; Good | ITA | Dem | Cognitive training | Computerized, individual-based cognitive training ("Brainer1") with neuropsychologist for 3 d/wk, 30 min/d over 3 months. | 3 | Sham: Computerized cognitive training sessions following same schedule as intervention (3 d/wk, 30 min/d) with neuropsychologist, but with general Internet browsing, reading, and games and no structured cognitive training.
Chapman, 2004^268^; Fair | US | Dem | Cognitive stimulation | Group-based cognitive stimulation therapy for 1 d/wk, 90 min/d over 2 months. | 2 | WL: Caregivers encouraged to attend education classes that were also offered to intervention group and offered stimulation program at end of study.
Cove, 2014^*^,^279^; Fair | GBR | Dem | IG1: Cognitive stimulation; IG2: Cognitive stimulation | IG1: Group-based cognitive stimulation therapy for 1 d/wk, 45 min/d over 3 months plus caregiver training on cognitive stimulation during two 60–180 min group sessions.; IG2: Group-based cognitive stimulation therapy for 1 d/wk, 45 min/d over 3 months. | 3 | WL: Offered intervention after completion of study.
Greenaway, 2012^273^; Fair | US | MCI | Cognitive training | Dyad training on the use of a calendar and note-taking system ("Memory Support System") to teach adaptation to memory loss (versus memory improvement) during 12 sessions for 60 min/session over 1.5 months. | 1.5 | None: Given same calendar as intervention group and encouraged to use it on their own without further instruction.
Herrera, 2012^*^,^283^; Fair | FRA | MCI | Cognitive training | Computerized, individual-based cognitive training focused on memory and attention with neuropsychologist supervision for 2 d/wk, 60 min/d over 3 months. | 3 | Sham: Paper-pencil general cognitive activities following same schedule as intervention (2 d/wk, 60 min/d) with neuropsychologist
Hyer, 2016^*^,^287^; Fair | US | MCI | Cognitive training | Computerized, individual-based cognitive training ("Cogmed QM©") focused on working memory for 25 sessions, 40 min/session over 1–2 months. | 2 | Sham: Computerized cognitive training sessions following same schedule as intervention (25 sessions, 40 min/session) and same general activities as Cogmed but without adaptivity based on individual’s performance.
Jelcic, 2012^*^,^284^; Fair | ITA | Dem | Cognitive stimulation | Group-based cognitive stimulation therapy (Lexical-Semantic Stimulation) for 2 d/wk, 60 min/d over 3 months. | 3 | Sham: Group-based unstructured cognitive stimulation following same schedule as intervention (2 d/wk, 60 min/d) including creative work, reading plus discussion, and activities for improving verbal skills.
Jeong, 2016^*^,^276^; Fair | KOR | MCI | IG1: Cognitive training; IG2: Cognitive training | IG1: Group-based cognitive training for 2 d/wk, 90 min/d over 3 months.; IG2: Home-based cognitive training using print-based materials for 5 d/wk for 3 months with visits to the clinic every week in the 1st month and every other week in the 2nd and 3rd months to check and discuss homework materials. | 3 | WL: Offered cognitive training after study ended.
Kallio, 2018^290^; Fair | FIN | Dem | Cognitive training | Group-based cognitive training focused to stimulate sub-skills of executive function for 2 d/wk, 45 min/d for 12 weeks. | 3 | UC: Usual care with routine treatment at a day care center twice a week for 6 hrs/d.
Kinsella, 2009^266^; Fair | AUS | MCI | Cognitive rehabilitation | Individualized cognitive rehabilitation focused on memory difficulties for 1 d/wk, 90 min/d over 5 weeks. | 1.25 | WL: Offered intervention after study ended.
Kurz, 2012^274^; Fair | DEU | Dem | Cognitive rehabilitation | Individualized cognitive rehabilitation 1 d/wk, 60 min/d over 3 months. | 3 | UC: Site-specific standard medical management including occupational therapy, physiotherapy, carer counseling, carer support groups, or medication alone.
Nousia, 2018^288^; Fair | GRC | Dem | Cognitive training | Individual cognitive training sessions for 2 d/wk, 60-min/d. | 3 | UC: Standard care.
Olazaran, 2004^267^; Fair | ESP | MCI + Dem | Cognitive stimulation | Group-based cognitive stimulation therapy 2 d/wk, 210 min/d over 1 year plus telephone help-line for caregivers. | 12 | MI: Psychosocial support (not described) plus telephone help-line for caregivers.
Orrell, 2014^*^,^281^; Good | GBR | Dem | Cognitive stimulation | Group-based maintenance cognitive stimulation therapy for 1 d/wk, 45 min/d for 6 months following a 7 week cognitive stimulation program. | 6 | UC: Site-specific usual care following a 7 week cognitive stimulation program.
Orrell, 2017^*^,^275^; Good | GBR | Dem | Cognitive stimulation | Home-based caregiver-led cognitive stimulation therapy for 3 d/wk, 30 min/d over 6 months. | 6 | UC: Site-specific usual care excluding cognitive stimulation, but including group-based activities such as gardening and support groups.
Pantoni, 2017^289^; Fair | ITA | MCI | Cognitive training | Individual cognitive training 1 d/wk, 120-min/d over 5 months. | 5 | UC: Instructed to continue usual activities and provided with standard care (medication and clinic consultations).
Quayhagen, 1995^272^; Fair | US | Dem | Cognitive stimulation | Home-based caregiver-led cognitive stimulation therapy for 1 d/wk, 60 min/d over 3 months. | 3 | WL: Offered training on cognitive stimulation after study ended.
Rapp, 2002^270^; Fair | US | MCI | Cognitive training | Group-based cognitive training focused on memory enhancement for 1 d/wk, 120 min/d over 6 weeks. | 1.5 | None: Given copies of intervention print materials after study ended.
Troyer, 2008^264^; Fair | CAN | MCI | Cognitive stimulation | Group-based cognitive stimulation therapy focused on memory enhancement for 10 sessions, 120 min/session over 6 months. | 6 | WL: Offered intervention after study ended.
Tsantali, 2017^*^,^285^; Fair | GRC | Dem | IG1: Cognitive training; IG2: Cognitive stimulation | IG1: Individual-based cognitive training focused on memory enhancement for 3 d/wk, 90 min/d for 4 months.; IG2: Individual-based non-specific cognitive stimulation activities for 3 d/wk, 90 min/d for 4 months. | 4 | WL: Offered intervention after study ended.
Tsolaki, 2011^265^; Fair | GRC | MCI | Cognitive stimulation and training | Group-based cognitive training, cognitive stimulation therapy, and cognitive-behavioral therapy for 3 d/wk, 90 min/d over 6 months. | 6 | WL: Offered intervention after study ended.
Vidovich, 2015^278^; Good | AUS | MCI | Cognitive rehabilitation, training, stimulation | Group-based cognitive training, stimulation, and rehabilitation for 2 d/wk, 90 min/d for 5 weeks. | 1 | MI: Group-based general education on healthy aging for 2 d/wk, 90 min/day over 5 weeks.
Exercise Interventions
Baker, 2010^298^; Fair | US | MCI | Exercise | Supervised individual-based aerobic exercise for 4 d/wk, 45–60 min/d over 6 months. | 6 | MI: Prescribed stretching and balance exercises.
Blumenthal, 2018^309^; Fair | US | MCI | IG1: Exercise and diet counseling; IG2: Exercise; IG3: Diet counseling | IG1: Supervised exercise for 3 d/wk, 45-min/d over three months; unsupervised home exercise sessions 3 d/wk, 45min/d over subsequent three months; and dietary counseling for 1 d/wk, 30-min/d for three months and 2 d/month, 30-min/d over subsequent three months; IG2: Supervised exercise for 3 d/wk, 45-min/d over three months; unsupervised home exercise sessions 3 d/wk, 45min/d over subsequent three months; IG3: Dietary counseling for 1 d/wk, 30-min/d for three months and 2 d/month, 30-min/d over subsequent three months. | 6 | AC: Instructed to maintain their normal activities, and educational calls on CVD health-related topics 1 d/wk, 30-min/d for three months and 2 d/month for subsequent three months.
Dawson, 2016^*^,^307^; Fair | US | Dem | Exercise | Supervised individual, home-based functional strength and balance exercises for 2 d/wk over 3 months. | 3 | WL: Maintain normal activities.
Doi, 2017^*^,^306^; Good | JPN | MCI | Exercise | Supervised group-based ballroom dancing for 1 d/wk, 60 min/d over 10 months. | 10 | AC: Three 90-min health education classes on general older adult health topics.
Ho, 2018^310^; Fair | HKG | MCI + Dem | Exercise | IG1: Dance-movement group-based intervention for 2 d/wk, 60-min/d over three months.; IG2: Supervised group-based exercise intervention for 2 d/wk, 60-min/d over three months. | IG1: 3; IG2: 12 | WL: Usual care plus wait list intervention.
Hoffmann, 2016^*^,^304^; Good | DNK | Dem | Exercise | Supervised group-based aerobic exercise for 3 d/wk, 60 min/d over 4 months. | 4 | UC: Treatment as usual with access to memory clinic staff as needed.
Holthoff, 2015^*^,^305^; Fair | DEU | Dem | Exercise | Self-guided individual, home-based lower body exercises on computer-controlled movement trainer for 3 d/wk, 30 min/d over 3 months. | 3 | BI: Monthly clinic visits and general advice on changing inactive habits and increasing physical activity.
Hong, 2017^*^,^302^; Fair | KOR | MCI | Exercise | Supervised group-based M42resistance exercises using elastic band for 2 d/wk, 60 min/d over 3 months. | 3 | None: Maintain normal activities.
Karssemeijer, 2019^312^; Fair | NLD | Dem | IG1: Multicomponent; IG2: Exercise | IG1: Supervised combined cognitive-aerobic exercise sessions for 3 d/wk, 30–50 min/d for 3 months.; IG2: Supervised aerobic exercise sessions for 3 d/wk, 30–50 min/d for 3 months. | 3 | Sham: Relaxation and stretching exercises for 3 d/week, 30-min/d over 3 months.
Lam, 2011^295^; Fair | HKG | MCI | Exercise | Supervised group-based and self-guided Tai Chi for minimum of 1 d/wk, 30 min/d over 2–3 months. | 3 | MI: Supervised stretching and toning exercises at same intensity as intervention group (1 d/wk for 30 min/day).
Lamb, 2018^308^; Good | GBR | Dem | Exercise | Dance-movement group-based intervention for 2 d/wk, 60-min/d over three months. | 12 | WL: Usual care plus wait list intervention.
Lautenschlager, 2008^294^; Good | AUS | MCI | Exercise | Self-guided individually-tailored aerobic exercise for 3 d/wk, 50 min/d (minimum of 150 min/wk) + workbook over 6 months. | 6 | AC: Educational material about general health topics, excluding physical activity.
Lazarou, 2017^*^,^301^; Fair | GRC | MCI | Exercise | Supervised group-based ballroom dancing for 2 d/wk, 60 min/d over 10 months. | 10 | None: Maintain normal activities.
Liu-Ambrose, 2016^*^,^293^; Fair | CAN | Dem | Exercise | Supervised group-based aerobic exercise for 3 d/wk, 60 min/d over 6 months. | 6 | UC: Usual care plus monthly educational materials about vascular cognitive impairment and healthy diet.
Morris, 2017^*^,^303^; Good | US | MCI + Dem | Exercise | Supervised individual-based aerobic exercise for 3–5 d/wk, 30–50 min/d (150 min/wk) over 6 months. | 6 | MI: Supervised non-aerobic exercises (core strengthening, resistance bands, modified tai chi, modified yoga) at same intensity as intervention group (3–5 d/wk for 30–50 min/d).
Pitkälä, 2013^*^,^292^; Good | FIN | Dem | IG1: Exercise; IG2: Exercise | IG1: Supervised group-based exercise focused on endurance, balance, strength training, and executive functioning for 2 d/wk, 60 min/d over 1 year.; IG2: Supervised home-based individually-tailored functional mobility exercises for 2 d/wk, 60 min/d over 1 year. | 12 | UC: Usual care plus general advice on nutrition and exercise.
Schwenk, 2010^296^; Fair | DEU | Dem | Exercise | Supervised group-based resistance-balance and functional-balance training, including specific dual-task training for concurrent motor or cognitive tasks for 2 d/wk, 120 min/d over 3 months. | 3 | MI: Supervised group-based motor placebo training including flexibility exercises, calisthenics, and ball games while seated for 2 d/wk, 60 min/d over 1 year.
Siu, 2018^311^; Fair | HKG | MCI | Exercise | Supervised group-based Tai Chi for 2 d/wk, 60-min/d over 4 months and telephone followup for emotional support and reinforcement of intervention. | 4 | UC: Usual care and advised to attend recreational activities provided by their elderly centers and to continue their daily activities.
Suzuki, 2012^299^; Fair | JPN | MCI | Exercise | Supervised group-based exercise including aerobic exercise, strength training, balance retraining, and dual-task training for 2 d/wk, 90 min/d over 1 year. | 12 | AC: Three general health education classes.
Venturelli, 2010^297^; Fair | ITA | MCI + Dem | Exercise | Supervised group-based resistance training for 3 d/wk, 45 min/d over 3 months plus usual physical therapy. | 3 | UC: Usual physical therapy including electrostimulation, massage, and passive leg movement on bed as well as bingo, music therapy, and patchwork.
Vreugdenhil, 2012^300^; Fair | AUS | Dem | Exercise | Self- and caregiver-guided home-based exercise including aerobic exercise, strength and balance training recommended to be performed daily over 4 months. | 4 | WL: Usual care plus wait list intervention.
Multicomponent and Other Interventions
Bae, 2019^322^; Fair | JPN | MCI | Multicomponent | Multicomponent group-based intervention with supervised exercise and cognitive and social activities 2d/wk, 90-min/d. | 6 | AC: Two 90-min health education classes about oral care and nutrition.
Bellantonio, 2008^313^; Fair | US | Dem | Multidisciplinary assessment | Four multidisciplinary assessments by geriatrician, physical therapist, dietitian, and medical social worker and associated care recommendations provided over 9 months to new dementia-specific assisted living patients. | 9 | UC: Medical evaluation by primary care physician within 7 days of admission.
Belleville, 2018^291^; Fair | CAN | MCI | IG1: Cognitive training; IG2: Other | IG1: Group-based cognitive training for 1 d/wk, 120 min/d for 2 months followed by one intensive booster session delivered three months later.; IG2: Group-based cognitive behavioral therapy for 1 d/wk, 120 min/d for 2 months followed by one intensive booster session delivered three months later. | 2.2 | WL: Offered cognitive training intervention after study ended.
Blumenthal, 2018^309^; Fair | US | MCI | IG1: Exercise and diet counseling; IG2: Exercise; IG3: Diet counseling | IG1: Supervised exercise for 3 d/wk, 45-min/d over three months; unsupervised home exercise sessions 3 d/wk, 45min/d over subsequent three months; and dietary counseling for 1 d/wk, 30-min/d for three months and 2 d/month, 30-min/d over subsequent three months; IG2: Supervised exercise for 3 d/wk, 45-min/d over three months; unsupervised home exercise sessions 3 d/wk, 45min/d over subsequent three months; IG3: Dietary counseling for 1 d/wk, 30-min/d for three months and 2 d/month, 30-min/d over subsequent three months. | 6 | AC: Instructed to maintain their normal activities, and educational calls on CVD health-related topics 1 d/wk, 30-min/d for three months and 2 d/month for subsequent three months.
Burgener, 2008^314^; Fair | US | Dem | Multicomponent | Multicomponent group-based intervention with exercise classes for 3 d/wk, 60 min/d and cognitive behavioral therapy and support groups 1 d/wk, 90 min/d over 5 months. | 5 | WL: Offered intervention after 5 months.
Fiatarone Singh, 2014^*^,^280^; Fair | AUS | MCI | IG1: Multicomponent; IG2: Cognitive training | IG1: Computerized, group-based cognitive training ("COGPACK") and group-based progressive resistance training for 2 d/wk, 100 min/d over 6 months.; IG2: Computerized, group-based cognitive training ("COGPACK") for 2 d/wk, 45 min/d over 6 months plus a 30 min of sham physical exercises of stretching and seated calisthenics during each session. | 6 | Sham: Sham cognitive training 2 d/wk, 30 min/d of watching videos and responding to questions regarding video content plus 30 min of sham physical exercises of stretching and seated calisthenics during each session.
Jha, 2013^*^,^318^; Fair | GBR | MCI + Dem | Other | Psychiatric assessment, counseling, and support for 1 d/month, 60 min/d over 6 months. | 6 | MI: General counseling to patient and caregiver (not focused on wellbeing or quality of life) for 1 d/month, 60 min/d over 6 months.
Karssemeijer, 2019^312^; Fair | NLD | Dem | IG1: Multicomponent; IG2: Exercise | IG1: Supervised combined cognitive-aerobic exercise sessions for 3 d/wk, 30–50 min/d for 3 months.; IG2: Supervised aerobic exercise sessions for 3 d/wk, 30–50 min/d for 3 months. | 3 | Sham: Relaxation and stretching exercises for 3 d/week, 30-min/d over 3 months.
Marshall, 2015^*^,^317^; Fair | GBR | Dem | Other | Group-based psychotherapy and psychoeducation for 1 d/wk, 75 min/day over 2.5 months. | 2.5 | WL: Offered intervention after study ended.
Quinn, 2016^*^,^316^; Good | GBR | Dem | Other | Group-based self-management program for 1 d/wk, 90 min/d over 2 months. | 2 | UC: Routine memory clinic services including psychiatry, psychology, occupational therapy, and social services.
Richard, 2009^319^; Fair | NLD | Dem | Other | Vascular care targeting hypercholesterolemia and hypertension including medications, exercise, diet and smoking cessation during outpatient visits every 3 months for 24 months. | 24 | UC: Physicians followed general guidelines for treatment for vascular risk factors in older adults.
Rovner, 2018^320^ | US | MCI | Other | Five in-home 60-min behavioral activation (goal-setting and action plans) intervention over 4 months and six in-home 60-min followup maintenance sessions over subsequent 20 months. | 4 | Sham: Five in-home 60-min general supportive therapy sessions over 4 months and six in-home 60-min followup maintenance sessions over subsequent 20 months.
Shimada, 2017^323^; Fair | JPN | MCI | Multicomponent | Group-based physical and cognitive exercises for 1 d/wk, 90 min/d over 9 months | 9 | MI: Three 90-minute health promotion classes and three booster calls over 9 months.
Straubmeier, 2017^324^; Fair | DEU | MCI + Dem | Multicomponent | Multicomponent group-based intervention with social, cognitive, and physical components for 5 d/wk, 120-min/d over 6 months. | 6 | WL: Offered intervention after 6 months.
Train the Brain Consortium, 2017^321^; Fair | ITA | MCI | Multicomponent | Multicomponent group-based intervention with twice daily 30-min/d cognitive training; music therapy 1 d/wk, 60-min/d; monthly 60-min movie and discussion sessions; and supervised exercise 3 d/wk, 60-min/d. | 7 | None: Maintain normal activities.
Wolfs, 2008^315^; Fair | NLD | MCI + Dem | Other | Multidisciplinary diagnostic assessment with results and recommended treatment and management plan sent to general practitioner ("Diagnostic Observation Center for Psychogeriatric Patients” [DOC-PG]). | NR | UC: Diagnosis by general practitioner or outside service.

* New study

Abbreviations: AC = attention control; AUS = Australia; BI = brief intervention; CG = control group; d = day; Dem = dementia; DEU = Germany; ESP = Spain; FIN = Finland; FRA = France; GBR = Great Britain/United Kingdom; GRC = Greece; HKG = Hong Kong; ITA = Italy; JPN = Japan; KOR = Korea; MCI = mild cognitive impairment; MI = minimal intervention; min = minutes; NLD = Netherlands; NR = not reported; Pop cat = population category; UC = usual care; wk = week; WL = waitlist

Table 18 Patient-Level Nonpharmacologic Interventions: Summary of Results, by Intervention (KQs 4 and 5)

Author, year Quality | Pop cat | N rand | Age, mean | FU (mo.) | Global Function | Global Cognitive Function | Domain-Specific Cognitive Function | Physical Function | Quality of Life | Mental Health and Behavioral Symptoms | Other
Cognitive Stimulation, Training, and Rehabilitation
Amieva, 2016^*^,^277^; Good | Dem | 481 | 79 | 24 | NR | IG1: ↔ (ADAS-Cog); IG2: ↔ (ADAS-Cog) | NR | IG1: ↔ (ADL/IADL); IG2: ↔ (ADL/IADL) | IG1: ↔; IG2: ↔ | IG1: ↔ (D, NPS); IG2: ↔ (D, NPS) | IG1: ↔ (CGR Burden, Institutionalization, Dementia Incidence); IG2: ↔ (CGR Burden, Institutionalization, Dementia Incidence)
Belleville, 2018^*^,^291^; Fair | MCI | 145 | 72 | 6 | NR | NR | ↔^†^ (Memory) | ↔ (ADL) | ↔ | ↔ (A, D) | NR
Bergamaschi, 2013^*^,^282^; Fair | Dem | 32 | 78 | 12 | NR | ↑ (MMSE) | ↑ (EF); ↔^†^ (Memory) | ↑ (ADL), ↔ (IADL) | NR | ↔ (D) | NR
Buschert, 2011^271^; Fair | MCI + Dem | 39 | 73 | 6 | NR | MCI: ↑ (ADAS-Cog), ↔ (MMSE); Dem: ↔ (ADAS-Cog), ↔ (MMSE) | ↔ (Attention); ↔ (EF); ↔ (Memory) | NR | MCI: ↔; Dem: ↔ | MCI: ↑ (D); Dem: ↔ (D) | NR
Cahn-Weiner, 2003^*^,^269^; Good | Dem | 34 | 77 | 3 | NR | NR | ↔ (Attention); ↔ (EF); ↔ (Language); ↔ (Memory) | ↔ (ADL/IADL) | NR | NR | NR
Cavallo, 2016^*^,^286^; Good | Dem | 80 | 76 | 6 | NR | ↔ (MMSE) | ↑ (Attention); ↔^†^ (EF); ↑ (Language); ↔^†^ (Memory) | NR | NR | ↔ (A, D) | NR
Chapman, 2004^268^; Fair | Dem | 54 | 76 | 12 | ↔ | ↔ (ADAS-Cog), ↔ (MMSE) | NR | ↔ (ADL/IADL) | ↔ | ↔ (NPS) | ↑ (CGR Burden)
Cove, 2014^*^,^279^; Fair | Dem | 72 | 77 | 3 | NR | IG1: ↔ (ADAS-Cog), ↔ (MMSE); IG2: ↔ (ADAS-Cog), ↔ (MMSE) | NR | NR | IG1: ↔; IG2: ↔ | NR | NR
Fiatarone Singh, 2014^280^; Fair | MCI | 100 | 70 | 18 | NR | IG2: ↔ (ADAS-Cog) | IG2: ↔ (EF), ↔ (Memory) | IG2: ↔ (IADL) | NR | NR | NR
Greenaway, 2012^*^,^273^; Fair | MCI | 40 | 72 | 6 | NR | ↔ (MMSE) | ↔ (Memory) | NR | ↔ | ↔ (D) | ↑ (CGR Burden, CGR MH [D]); ↔ (CGR QOL)
Herrera, 2012^283^; Fair | MCI | 22 | 77 | 6 | NR | NR | ↔^†^ (Attention); ↔^†^ (Memory) | NR | NR | NR | NR
Hyer, 2016^*^,^287^; Fair | MCI | 77 | 75 | 5 | NR | NR | ↔^†^ (EF); ↔ (Memory) | ↑ (IADL) | NR | NR | NR
Jelcic, 2012^*^,^284^; Fair | Dem | 40 | 82 | 3 | NR | ↑ (MMSE) | ↔^†^ (Attention); ↔ (EF); ↔^†^ (Language); ↔^†^ (Memory) | ↔ (IADL) | NR | NR | NR
Jeong, 2016^*^,^276^; Fair | MCI | 293 | 70 | 9 | IG1: ↔; IG2: ↑ | IG1: ↑ (ADAS-Cog), ↔ (MMSE); IG2: ↑ (ADAS-Cog), ↔ (MMSE) | IG1: ↔ (EF), ↔ (Memory); IG2: ↔ (EF), ↔ (Memory) | IG1: ↔ (IADL); IG2: ↔ (IADL) | IG1: ↔; IG2: ↑ | IG1: ↔ (D), ↑ (NPS); IG2: ↔ (D), ↔ (NPS) | NR
Kallio, 2018^*^,^290^; Fair | Dem | 147 | 83 | 9 | NR | ↔ (ADAS-Cog) | NR | NR | ↔ | NR | ↔ (Deaths, Institutionalization, Hospitalization)
Kinsella, 2009^266^; Fair | MCI | 54 | 77 | 4 | NR | NR | ↔ (Memory) | NR | NR | NR | NR
Kurz, 2012^274^; Fair | Dem | 201 | 74 | 9 | NR | ↔ (MMSE) | NR | ↔ (IADL) | ↔ | ↔ (D), ↔ (NPS) | ↔ (CGR Burden, CGR MH [D])
Nousia, 2018^*^,^288^; Fair | Dem | 50 | 76 | 3.5 | NR | NR | ↑ (Attention); ↑ (EF); ↑ (Language); ↔^†^ (Memory) | NR | NR | NR | NR
Olazaran, 2004^267^; Fair | MCI + Dem | 84 | 74 | 12 | NR | ↔ (ADAS-Cog), ↔ (MMSE) | NR | ↔ (IADL) | NR | ↑ (D) | NR
Orrell, 2014^*^,^281^; Good | Dem | 236 | 83 | 6 | NR | ↔ (ADAS-Cog), ↔ (MMSE) | NR | ↔ (ADL/IADL) | ↑ (Self-rated), ↔ (Proxy-rated) | ↔ (NPS) | ↔ (CGR QOL)
Orrell, 2017^*^,^275^; Good | Dem | 356 | 78 | 6 | NR | ↔ (ADAS-Cog), ↔ (MMSE) | NR | ↔ (ADL/IADL) | ↔ | ↔ (D), ↔ (NPS) | ↔ (CGR QOL, CGR MH, CGR Burden)
Pantoni, 2017^*^,^289^; Fair | MCI | 46 | 75 | 12 | NR | ↔ (MMSE) | ↔ (Attention); ↔ (EF); ↔^†^ (Memory) | ↔ (ADL), ↔ (IADL), ↔ (ADL/IADL) | ↔ | ↔ (D) | NR
Quayhagen, 1995^272^; Fair | Dem | 95 | 74 | 9 | NR | ↑ (MDRS) | NR | NR | NR | NR | NR
Rapp, 2002^270^; Fair | MCI | 19 | 74 | 6 | NR | NR | ↔^†^ (Memory) | NR | NR | NR | NR
Troyer, 2008^264^; Fair | MCI | 54 | 75 | 6 | NR | NR | ↔^†^ (Memory) | NR | NR | NR | NR
Tsantali, 2017^*^,^285^; Fair | Dem | 63 | 74 | 12 | NR | IG1: ↑ (MMSE); IG2: ↔ (MMSE) | IG1: ↑ (Language), ↑ (Memory); IG2: ↔ (Language), ↔^†^ (Memory) | NR | NR | NR | NR
Tsolaki, 2011^265^; Fair | MCI | 196 | 68 | 6 | NR | ↑ (MMSE) | NR | ↑ (ADL) | NR | NR | NR
Vidovich, 2015^*^,^278^; Good | MCI | 160 | 75 | 24 | NR | ↔ (CAMCOG-R) | ↔^†^ (Attention); ↔ (EF); ↔ (Memory) | NR | ↑ | ↔ (D) | ↔ (Dementia Incidence)
Exercise Interventions
Baker, 2010^298^; Fair | MCI | 33 | 70 | 6 | NR | NR | ↑ (Attention); ↑ (EF) | NR | NR | NR | NR
Blumenthal, 2019^*^,^309^; Fair | MCI | 160 | 65 | 6 | ↔ | NR | ↔ (EF); ↔ (Language); ↔ (Memory) | NR | NR | NR | ↔ (Dementia Incidence)
Dawson, 2016^*^,^307^; Fair | Dem | 26 | 74 | 3 | NR | NR | ↔ (EF) | ↔ (ADL/IADL) | NR | NR | ↔ (Institutionalization)
Doi, 2017^*^,^306^; Good | MCI | 201 | 76 | 9 | NR | ↑ (MMSE) | ↔ (Attention); ↔ (EF); ↔^†^ (Memory) | NR | NR | NR | ↔ (Dementia Incidence)
Ho, 2018^*^,^310^; Fair | MCI + Dem | 204 | 79 | 12 | NR | NR | IG1: ↔ (Attention); ↔ (EF); ↔ (Language); ↔ (Memory); IG2: ↔ (Attention); ↔ (EF); ↔ (Language); ↔ (Memory) | IG1: ↔ (IADL); IG2: ↔ (IADL) | NR | IG1: ↔ (D), ↔ (NPS); IG2; ↔ (D), ↔ (NPS) | NR
Hoffmann, 2016^*^,^304^; Good | Dem | 200 | 70 | 4 | NR | ↔ (MMSE) | ↔ (EF); ↔ (Language) | ↔ (ADL/IADL) | ↔ | ↔ (D); ↑ (NPS) | NR
Holthoff, 2015^*^,^305^; Fair | Dem | 30 | 72 | 6 | NR | ↔ (MMSE) | ↑ (EF) | ↑ (ADL) | NR | ↑ (NPS) | ↔ (CGR Burden, Institutionalization)
Hong, 2017^*^,^302^; Fair | MCI | 25 | 77 | 3 | NR | ↔ (MoCA) | ↔^†^ (Attention); ↔ (EF); ↔ (Memory) | NR | NR | NR | NR
Karssemeijer, 2019^*^,^312^; Fair | Dem | 115 | 80 | 6 | NR | NR | ↔ (EF); ↔ (Memory) | NR | NR | NR | ↔ (SAE)
Lam, 2011^295^; Fair | MCI | 389 | 78 | 5 | ↑ | ↔ (ADAS-Cog), ↔ (MMSE) | ↔^†^ (Attention); ↔ (EF); ↔ (Language); ↔ (Memory) | NR | NR | ↔ (D), ↔ (NPS) | NR
Lamb, 2018^*^,^308^; Good | Dem | 494 | 77 | 12 | NR | ↑ (ADAS-Cog) | NR | ↔ (ADL/IADL) | ↔ (Self-rated), ↔ (Proxy-rated) | ↔ (NPS) | ↔ (CGR Burden, CGR QOL)
Lautenschlager, 2008^294^; Good | MCI | 170 | 68 | 17 | ↑ | ↑ (ADAS-Cog) | ↔ (Attention); ↔ (EF); ↔^†^ (Memory) | NR | ↔ | ↔ (D) | NR
Lazarou, 2017^*^,^301^; Fair | MCI | 154 | 67 | 10 | ↑ | ↑ (MMSE) | ↑ (Attention); ↔^†^ (EF); ↑ (Memory) | NR | NR | ↔ (NPS) | NR
Liu-Ambrose, 2016^*^,^293^; Fair | Dem | 70 | 74 | 12 | NR | ↔ (ADAS-Cog) | ↔ (EF) | ↔ (ADL/IADL) | NR | NR | NR
Morris, 2017^*^,^303^; Good | MCI + Dem | 76 | 73 | 6 | NR | NR | ↔ (EF); ↔ (Memory) | ↑ (ADL/IADL) | NR | ↔ (D) | NR
Pitkälä, 2013^*^,^292^; Good | Dem | 210 | 78 | 12 | NR | IG1: ↔ (MMSE); IG2: ↔ (MMSE) | IG1: ↔ (EF); IG2: ↔^†^ (EF) | IG1: ↔ (ADL/IADL); IG2: ↑ (ADL/IADL) | NR | IG1: ↔ (D), ↔ (NPS); IG2: ↔ (D), ↔ (NPS) | IG1: ↔ (Institutionalization); IG2: ↔ (Institutionalization)
Schwenk, 2010^296^; Fair | Dem | 61 | 82 | 3 | NR | NR | ↔ (EF) | NR | NR | NR | NR
Siu, 2018^*^,^311^; Fair | MCI | 160 | NR | 4 | NR | ↑ (MMSE) | NR | ↑ (IADL) | NR | NR | NR
Suzuki, 2012^299^; Fair | MCI | 50 | 76 | 6 | NR | ↔ (ADAS-Cog), ↑ (MMSE) | ↔^†^ (Memory) | NR | NR | NR | NR
Venturelli, 2010^297^; Fair | MCI + Dem | 30 | 84 | 3 | NR | ↑ (MMSE) | NR | ↑ (ADL) | NR | NR | NR
Vreugdenhil, 2012^300^; Fair | Dem | 40 | 74 | 4 | NR | ↑ (ADAS-Cog), ↑ (MMSE) | NR | ↑ (ADL/IADL) | NR | ↔ (D) | ↔ (CGR Burden)
Multicomponent and Other Interventions
Bae, 2019^*^,^322^; Fair | MCI | 83 | 76 | 6 | NR | ↔ (MMSE) | ↔ (Attention); ↔ (EF); ↔^†^ (Memory) | NR | NR | ↔ (D) | ↔ (AE, SAE)
Belleville, 2018^*^,^291^; Fair | MCI | 145 | 72 | 6 | NR | NR | ↔ (Memory) | ↔ (ADL) | ↔ | ↔ (A, D) | NR
Blumenthal, 2019^*^,^309^; Fair | MCI | 160 | 65 | 6 | IG1: ↔; IG3: ↔ | NR | IG1: ↑ (EF); ↔ (Language); ↔ (Memory); IG3: ↔ (EF); ↔ (Language); ↔ (Memory) | NR | NR | NR | IG1: ↔ (Dementia Incidence); IG3: ↔ (Dementia Incidence)
Bellantonio, 2008^313^; Fair | Dem | 100 | 82 | 9 | NR | NR | NR | NR | NR | NR | ↔ (Institutionalization)
Burgener, 2008^314^; Fair | Dem | 43 | 77 | 5 | NR | ↔ (MMSE) | NR | NR | NR | ↔ (D) | NR
Fiatarone Singh, 2014^280^; Fair | MCI | 100 | 70 | 18 | NR | IG1: ↔ (ADAS-Cog) | IG1: ↔ (EF), ↔ (Memory) | IG1: ↔ (IADL) | NR | NR | NR
Jha, 2013^*^,^318^; Fair | MCI + Dem | 48 | 79 | 6 | NR | ↔ (MMSE) | NR | NR | ↔ (EQ-5D), ↑ (WHO-5) | ↔ (D) | ↔ (CGR Burden)
Karssemeijer, 2019^*^,^312^; Fair | Dem | 115 | 80 | 6 | NR | NR | ↔ (EF); ↔ (Memory) | NR | NR | NR | ↔ (SAE)
Marshall, 2015^*^,^317^; Fair | Dem | 58 | 76 | 5 | NR | ↔ (MMSE) | NR | NR | ↔ | ↔ (D) | ↔ (CGR MH [Psych Health])
Quinn, 2016^*^,^316^; Good | Dem | 24 | 76 | 6 | NR | NR | NR | NR | ↔ | ↔ (A, D) | NR
Richard, 2009^319^; Fair | Dem | 123 | 76 | 24 | NR | ↔ (MMSE) | NR | ↔ (ADL/IADL) | NR | ↔ (NPS) | ↔ (Institutionalization)
Rovner, 2018^*^,^320^; Good | MCI | 221 | 76 | 24 | NR | ↔ (MMSE) | ↔ (Attention); ↑ (EF); ↔ (Language); ↔^†^ (Memory) | NR | NR | ↔ (D) | ↔ (Hospitalization, ER visits); ↔ (Dementia Incidence)
Shimada, 2018^*^,^323^; Fair | MCI | 308 | 72 | 9 | NR | ↑ (MMSE) | ↔^†^ (EF); ↔^†^ (Memory) | NR | NR | NR | ↔ (AE, Falls, Hospitalization)
Straubmeier, 2017^*^,^324^; Fair | MCI + Dem | 453 | 81 | 6 | NR | ↑ (MMSE) | NR | ↑ (ADL) | NR | ↔ (NPS) | ↔ (AE)
Train the Brain Consortium, 2017^*^,^321^; Fair | MCI | 113 | 74 | 7 | NR | ↑ (ADAS-Cog) | ↔ (Attention); ↔^†^ (EF); ↔ (Memory) | NR | NR | NR | ↔ (AE)
Wolfs, 2008^315^ | MCI + Dem | 230 | 78 | 12 | ↔ | ↔ (MMSE) | NR | ↔ (IADL) | ↔ | ↔ (D, NPS)

NOTE: Arrows represent study-reported results.

Symbol Legend:

↑ = Statistically significant between-group difference in favor of intervention group

↔ = No statistically significant difference between groups or no clear between-group difference (not reported).

* New study

† Mixed results from multiple tests assessing same cognitive domain

Abbreviations: A = Anxiety; ADAS-Cog = Alzheimer’s Disease Assessment Scale-cognitive subscale; ADL = Activities of Daily Living; AE = adverse events; D = Depression; Dem = Dementia; EF = executive functioning; FU (mo.) = followup (months); CGR = caregiver; IADL = Instrumental Activities of Daily Living; MCI = mild cognitive impairment; MH = mental health; MMSE = Mini-Mental State Examination; NPS = Composite neuropsychiatric symptoms; NR = not reported; N rand = number of participants randomized; Pop cat = population category; Psych = psychological; QOL = quality of life; SAE = serious adverse events

###### Cognitive Stimulation, Cognitive Training, and/or Cognitive Rehabilitation

Study and population characteristics. Twenty-eight trials (n=3,212) evaluated the effectiveness of cognitive training, stimulation, and/or rehabilitation on improving cognitive or physical function outcomes and mental and behavioral symptoms vs. no intervention or an attention control group. Seventeen of the 28 trials were newly identified as part of this update; 11 trials were included in the previous review. We rated only five of these trials as good quality and the remaining 22 as fair quality. In general, trials were relatively small (n<100), ranging from 19 to 481 patients randomized (median n randomized, 63). Most were of limited study duration (3 to 6 months followup); only nine trials had followup at 12 months or longer (maximum of 26 months).^267,^ ^268,^ ^276–278,^ ^280,^ ^282,^ ^285,^ ^289^

Eleven of the 28 trials targeted patients with MCI (mean baseline MMSE score ranged from 25.7 to 27.9), 14 targeted patients with dementia (MMSE range, 17.8 to 25.1), and the remaining two^267,^ ^271^ targeted patients with either MCI or dementia (MMSE of 26.4 in one study that reported). Among the trials of patients with dementia, all but two^279,^ ^290^ were exclusively among patients with probable AD. In the remaining trials, most (68% and 83%) had AD, about a tenth had VaD (13% and 7%, respectively), and the remaining diagnoses were PDD or of mixed or other etiology. Most trials recruited patients directly from memory or neurology clinics or some other outpatient clinic. Among the trials targeting patients with MCI, most recruited patients presenting with memory complaints who were free of psychiatric symptoms or disorders. In four of the 28 trials,^267,^ ^269,^ ^282,^ ^285^ participants were required to be on a stable dose (1 month to 2 years) of an AChEI to be enrolled in the trial, whereas five other trials^265,^ ^270,^ ^284,^ ^287,^ ^289^ specifically excluded patients who were taking an AChEI or memantine. In the remaining trials, the proportion of participants taking an AChEI at baseline ranged from 32 to 92 percent and was similar across intervention and control groups for each individual study. Across trials, the average age of patients ranged from 68 to 83 years (median, 76). These trials included an even distribution of both men and women and were conducted mostly in the United States (k=6) and western Europe (k=13). The race/ethnicity and educational level of participants were rarely reported.

Intervention characteristics. Thirty-one unique cognitive-focused interventions were tested in the 28 trials. We broadly defined these interventions as those that directly or indirectly targeted cognitive functioning as opposed to those that focused primarily on behavioral, emotional, or physical function.^325^ Most of the cognitive-focused interventions were cognitive stimulation interventions (defined as engaging the person with dementia in a range of general activities and discussions aimed at general enhancement of cognitive and social functioning^326^) or cognitive training activities (defined as a guided practice on a set of standardized tasks designed to reflect particular cognitive functions such as memory, attention, or problem-solving^325^). Four interventions^266,^ ^274,^ ^277,^ ^278^ included individualized cognitive rehabilitation in which personally relevant goals were identified and the interventionist worked with the person and his or her family to devise strategies to address these. In cognitive rehabilitation studies, the emphasis was on improving performance in everyday life rather than on cognitive tests.^325^

Most of the cognitive stimulation and training interventions were group-based interventions, but the intensity of activities varied considerably from 1 day a week for 6 weeks to 5 days a week for up to 2 years (median duration, 3 months). Most ranged from 45 to 90 minutes per session. Four interventions tested computer-based cognitive training programs consisting of 24 to 52 sessions total over 2 to 6 months;^280,^ ^283,^ ^286,^ ^287^ three of these four interventions were among patients with MCI. Three interventions were delivered in the home;^272,^ ^275,^ ^276^ in two of them caregivers were trained to lead cognitive stimulation or training activities. The few remaining interventions were individual-based, in-person cognitive stimulation, or training activities. Across all interventions, the most common interventionists were trained psychologists or neuropsychologists, but others included social workers, occupational and speech therapists, and trained research staff. Where reported, adherence to the interventions was relatively high (e.g., more than 70% of participants completing the full intervention; participants completing 80% of sessions on average).

The comparison groups were highly variable and included no intervention (11 trials with no intervention or waitlist controls), usual care which generally did not include cognitive training (7 trials), brief interventions focused on psychoeducation and support (3 trials), and “sham” cognitive-focused activities (7 trials). In the “sham” control groups, participants took part in nonspecific cognitive activities following the same schedule as the intervention group, such as reading the newspaper, completing puzzles, and browsing the Internet, with or without interaction with an interventionist or other participants.

##### Results

Cognitive function. Twenty of the 28 trials reported results for global cognitive function (e.g., ADAS-Cog, MMSE), with or without reporting domain-specific measures of cognitive function. The remaining eight trials^264,^ ^266,^ ^269,^ ^270,^ ^283,^ ^287,^ ^288,^ ^291^ only reported results for domain-specific measures of cognitive function such as memory, executive functioning, or attention. Overall, there appeared to be a very small to no benefit of cognitive training and stimulation activities on global cognitive function at 3 to 12 months (k=21; n=2,754). In 15 trials that reported effects of the intervention on MMSE scores, the pooled result indicated a statistically significant association between cognitive-focused interventions and improved global cognitive function compared with control groups at 3 to 12 months; however, the confidence interval was quite wide, ranging from a very small to small effect (MD, 1.33 [95% CI, 0.29 to 2.37]; k=15; n=1,341) at 3 to 12 months followup. Additionally, there was substantial statistical heterogeneity in the model (I^2^=91.1%), which likely reflects the lack of consistency in the magnitude of effects across studies (Figure 15). In general, across all trials, the control groups experienced worsening scores on the MMSE from baseline to up to 12 months followup ranging from 0.4 points (−0.4) to 3.6 (−3.6), whereas the effects in the intervention groups were more variable, ranging from a decline of 1.3 (−1.3) to an improvement of 3.8 points. Based on the Egger’s test and visual inspection of funnel plots, we found no evidence of small-study effects (an indicator of publication bias) for this outcome.

Figure 15 Pooled Analysis of Change in Global Cognitive Function (Measured by MMSE) (KQ4), Patient-Level Nonpharmalogic Interventions Compared With Controls, by Intervention Type

* For all analyses, we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available.

† Pooled mean difference, 0.26 (95% CI: −0.54 to 1.00); k=8; n=1238; I^2^=30.3%, based on restricted maximum likelihood method with Knapp-Hartung modification which resulted to no statistical significance

Abbreviations: AC = attention control; BI = brief intervention; BG = between-group; BL = baseline; CG = control group; Chg = change; CI = confidence interval; Dem = dementia; Intv = Intervention; IG = intervention group; KQ = key question; MCI = mild cognitive impairment; MD = mean difference; MI = minimal intervention; MMSE = mini-mental state examination; n = sample size; NR = not reported; Pop = population; UC = usual care; WL = waitlist

This figure is a forest plot of the change in global cognitive function, as measured by the mini-mental state examination, comparing patient-level nonpharmacologic interventions with controls. The forest plot is organized by intervention type.

Similarly, a meta-analysis of six trials reporting the differences in change in ADAS-Cog scores between those taking part in a cognitive-focused intervention vs. control conditions found a lack of an association with cognitive improvement at 3 to 12 months followup (MD, −0.66 [95% CI, −1.60 to 0.29]; k=8; n=842; I^2^=0%) (Figure 16). The absolute change from baseline in ADAS-Cog scores varied across studies from an improvement of 1.5 points to a drop of 4.9 points in the intervention groups and an improvement of 1.0 points to a decline of 5.6 in the control groups. Again, wide confidence intervals within and between studies reflect clinical uncertainty regarding the magnitude of the effects seen.

Figure 16 Pooled Analysis of Change in Global Cognitive Function (Measured by ADAS-Cog-11) (KQ 4), Patient-Level Nonpharmalogic Interventions Compared With Controls, by Intervention Type

* For all analyses, we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available.

†Pooled mean difference, −0.66 (95% CI: −1.60 to 0.29); k=8; n=842; I^2^=0.0%, based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, −1.05 (95% CI: −3.49 to 1.10); k=6; n=1071; I^2^=77.4%, based on restricted maximum likelihood method with Knapp-Hartung modification

§ Pooled mean difference, −1.66 (95% CI: −10.03 to 6.72); k=2; n=167; I^2^=56.5%, based on restricted maximum likelihood method with Knapp-Hartung modification

Abbreviations: AC = attention control; ADAS-Cog-11 = Alzheimer’s disease assessment scale–cognitive subscale (11-items); BI = brief intervention; BG = between-group; BL = baseline; CG = control group; Chg = change; CI = confidence interval; Dem = dementia; Intv = Intervention; IG = intervention group; KQ = key question; MCI = mild cognitive impairment; MD = mean difference; MI = minimal intervention; n = sample size; NR = not reported; Pop = population; UC = usual care; WL = waitlist

This figure is a forest plot of the change in global cognitive function, as measured by the eleven-item version of the Alzheimer’s disease assessment scale–cognitive subscale, comparing patient-level nonpharmacologic interventions with controls. The forest plot is organized by intervention type.

Four trials that reported a measure of global cognitive function were not included in either meta-analysis due to data reporting limitations^267,^ ^277^ or because they reported a measure other than the ADAS-Cog or MMSE.^272,^ ^278^ None of these trials reported a statistically significant effect of cognitive-focused interventions on global function at 3 to 24 months followup, but the direction of effects was consistent with the meta-analyzed trials. There was no evidence that the effect of the intervention was modified based on study quality (good-fair vs. fair), population (dementia vs. MCI), the duration of the intervention, whether the intervention included group sessions or not, or the control group (sham activities vs. other). In the few trials that reported longer-term effects (at greater than 12 months followup),^277,^ ^278,^ ^280^ consistent between-group effects were seen over time, with cognitive function declining in both intervention and control group participants.

Eight trials reported results related to measures of specific domains of cognitive function without reporting a measure of global cognitive function.^264,^ ^266,^ ^269,^ ^270,^ ^283,^ ^287,^ ^288,^ ^291^ In general, there was not a consistent benefit of cognitive-focused activities across measures of attention, executive function, language, and memory compared with control conditions. In some cases, mixed effects were found within trials, with some domain-specific measures showing beneficial effects and other measures of the same domain finding no effect. Even within trials that reported both global cognitive function and domain-specific measures, results were inconsistent.

Physical function. Fifteen of the 28 trials reported physical function outcomes (ADL and/or IADL outcomes), with only three finding small but statistically significant improvements in measures of ADLs or IADLs among persons with MCI or dementia at 5 to 12 months followup.^265,^ ^282,^ ^287^ The remaining trials showed very little change over time for both intervention and control participants or small and relatively equal decline in measures of physical function over time.

QOL. Only three of the 12 studies that reported QOL outcomes reported small but statistically significant differences between cognitive-focused interventions and controls.^276,^ ^278,^ ^281^ Only one of these studies also found significant benefit of cognitive training on global cognitive function; the other two trials found no other benefits of the interventions.

Neuropsychiatric symptoms. Changes in mental health and neuropsychiatric symptoms, including symptoms of depression and anxiety and behavioral problems, were reported by half of the studies (k=14). Again, there was no consistent pattern of effect across trials. Many showed relatively equal declines in self- or informant-based measures of depression or behavioral symptoms in both intervention and control group participants. Though the scales range considerably across these measures (e.g., 0–15 on the Geriatric Depression Scale, 0–38 for the CSDD; 0–144 for the NPI), most between-group differences did not exceed a 1-point difference in favor of either group.

Harms. One trial^280^ reported no harms of a cognitive training and sham physical exercises over the course of the 6-month intervention. No other trial reported on harms that occurred during the study.

###### Exercise Interventions

Study and population characteristics. We included 21 trials (n=2,831), six of them good quality, that studied the effectiveness of an exercise intervention to improve cognitive function, physical function, and/or neuropsychiatric and depressive symptoms among adults with MCI or dementia. Fourteen of the 21 trials were newly identified as part of this update. Similar to the evidence on cognitive-focused interventions, the number of included participants in the exercise trials was quite small (median n randomized, 95; range, 25 to 494) and the duration of the studies were short (14 of the 21 trials were 6 months or less in duration).

Just less than half of the studies targeted patients with MCI (mean MMSE score ranged from 24.5 to 27.4) and the other half targeted patients with dementia (mean MMSE score ranged from 18 to 26.4), one of which limited inclusion to patients with VaD.^293^ Three trials included patients with MCI or dementia, with one only enrolling older adults with serious mobility limitations.^297,^ ^303,^ ^310^ Few studies reported what proportion of included participants was currently taking a cognitive medication. The mean age of patients ranged from 67 to 84 years. Both men and women were included in all trials, with most reporting an equal distribution of men and women. One trial^292^ that had among the most intense exercise interventions (including strength and endurance activities) had a majority male sample (61%), whereas two trials^301,^ ^310^ of dancing interventions had a mostly female sample (78% and 82%). Only four of the 21 trials took place in the United States; the remaining 17 were in Europe (k=8), Asia (k=6), Australia (k=2), and Canada (k=1).

Intervention characteristics. The included exercise interventions were highly variable across the trials. Most involved supervised group-based exercise sessions focused on aerobic activities, strength and resistance training, and/or balance training that took place in a community setting and were led by an exercise specialist. Four trials included individualized, supervised exercise sessions in the home or community setting,^292,^ ^298,^ ^303,^ ^307^ whereas three trials encouraged self- or caregiver-guided exercises at home.^294,^ ^300,^ ^305^ Four trials evaluated the effectiveness of a group-based ballroom dancing intervention^301,^ ^306^ or dance-based intervention^308,^ ^310^ and two trials evaluated the impact of a tai chi program.^295,^ ^311^ Only a few studies mentioned specific cognitive training activities as part of the exercise intervention, including dual-task training (e.g., walking while counting backwards) and ballroom dance activities that involve physical, mental, creative, and social components. Interventions were relatively intense, with activities taking place 2 to 3 days per week for 30 minutes to 2 hours per session. Only six interventions, including the four dancing interventions, lasted more than 6 months.^292,^ ^299,^ ^301,^ ^306,^ ^308,^ ^310^

In about half of the trials the comparison group consisted of an attention control including general health education relevant for older adults or brief interventions that included supervised “sham” exercise sessions focused on stretching or toning (k=9). In the remaining studies, control participants continued to receive usual care from their medical or memory-specific health care provider or were offered the intervention at the end of the trial (i.e., waitlist control).

##### Results

Cognitive function. All 21 trials reported a measure of global cognitive function or domain-specific cognitive function. Of the 14 trials that reported a measure of global cognitive function, all but two trials^302,^ ^307^ had sufficient data to meta-analyze results related to differences in change in the ADAS-Cog and/or MMSE measures at 3 to 12 months followup. Overall, there was mixed evidence related to the association between exercise interventions and improvement in global cognitive function at 3 to 12 months followup among patients with MCI or dementia. Effect estimates generally favored intervention groups compared with control groups, but findings were inconsistent across trials with nine of the 14 individual trials (6 among patients with MCI^294,^ ^297,^ ^299,^ ^301,^ ^306,^ ^311^ and 3 among patients with dementia^300,^ ^304,^ ^308,^ ^321,^ ^323,^ ^324^) reporting a statistically significant benefit of the intervention compared with usual care or no intervention control groups on at least one measure of global cognitive function. The pooled analysis of 10 trials reporting results for the MMSE using resulted in small, statistically significant association (MD in change, 1.17 [95% CI, 0.45 to 1.90]; k=10; n=1,168; I^2^=81.3%%) (Figure 15). However, the average mean difference in change in ADAS-Cog-11 scores across six trials that were pooled using the REML model with the Knapp-Hartung correction for small samples indicated no association (MD, −1.05 [95% CI, −3.49 to 1.10]; k=6; n=1,071; I^2^=77.4%) (Figure 16). Results related to global cognitive function did not appear to differ according to different study (good vs. fair quality), population (MCI vs. dementia patients), intervention (duration of intervention, inclusion of any group sessions, specific type of exercise [e.g., aerobic activities, resistance training, ballroom dancing, tai chi), or control group (no intervention vs. brief or sham activities) characteristics.

Physical function. Change in physical function was variably measured across exercise trials including measures of impairment in ADLs (e.g., bathing, dressing, toileting, eating), with or without measures of impairment in IADLs (e.g., meal preparation, laundry, grocery shopping, travel, finances). Across eleven of the 21 trials measuring physical function, small improvements were seen in the exercise groups within most trials, whereas control groups reported worsening function over 3 to 12 months; five of the 11 trials reported these effects to be statistically significantly different between groups. A pattern was seen, though not definitive, where exercise interventions that included individually tailored instruction or self-guided instruction found effects on measures of ADLs or IADLs, whereas those that employed supervised, group-based exercise sessions found no effect. This difference was not statistically tested, however, given the few studies reporting these measures and could be due to other confounding factors.

QOL. Only three studies that evaluated an exercise intervention reported a measure of QOL. In all three studies, self-reported or proxy-reported measures of QOL were nearly identical between groups after the intervention and inconsistent patterns of effects across different measures of QOL.

Neuropsychiatric symptoms. Ten trials reported the effects on symptoms of depression or other behavioral and neuropsychiatric symptoms; again, there was a pattern of effect favoring the exercise groups compared with the control groups but differences between groups were small and of unclear clinical magnitude.

Harms. Eight of the 21 trials (n=1,425) reported on harms of an exercise intervention.^292,^ ^294,^ ^303,^ ^304,^ ^306–308,^ ^312^ The most commonly reported AE in the intervention groups was musculoskeletal problems, including delayed-onset muscle soreness, back pain, or specific joint pain. In terms of SAEs, in one trial^304^ one case of atrial fibrillation experienced during one of the exercise sessions was deemed to possibly be related to the exercise intervention. In another trial of aerobic exercise,^303^ one case of back pain related to spinal stenosis was judged to be exacerbated by exercise (either as part of the intervention or the battery of study measures that included a cardiorespiratory treadmill test). One other trial found eight AEs related to the intervention with four deemed as serious (one hospital admission for exercise-induced angina, two injurious falls, and one case of substantially worsening hip pain).^308^ Two trials^292,^ ^304^ reported no difference in the proportion of participants experiencing a fracture between intervention and control groups. Other AEs reported during or following the exercise interventions were deemed by study researchers to not be related to the intervention.

###### Multicomponent and Other Interventions

Study and population characteristics. Sixteen trials (n=2,302), 12 of which are new to this update, included a multicomponent patient-level intervention or an intervention that was fundamentally different from the cognitive-focused and exercise interventions and therefore are reported separately here (these latter interventions were categorized as “other”). Most were small trials (median n randomized, 115; range, 24 to 453) and 10 of the 16 studies took place for 6 months or less, whereas the other six trials ran for 7 to 24 months.

Intervention characteristics. Each of these 16 trials evaluated different interventions. We categorized seven interventions as a multicomponent intervention. In these interventions, the primary aim was to investigate whether these multicomponent interventions could slow the cognitive and functional decline of persons with cognitive impairment and they typically consisted of a combination of group-based cognitive training and exercise with or without other components such as social activities or psychotherapy/cognitive behavioral therapy. The remaining nine trials, all conducted among patients with early-stage dementia, tested other unique patient-centered interventions. Interventions included diagnosis support and in-home counseling focused on patient well-being,^318^ in-home counseling related to goal setting and action planning,^320^ group-based psychotherapy and psychoeducation^317^ or cognitive behavioral therapy,^291^ and a group-based self-management program.^316^ Two trials focused on a multidisciplinary assessment and treatment plan coordination;^313,^ ^315^ one was specifically for patients with moderate-to-severe dementia who had recently transferred to a dementia-specific residential care facility (mean MMSE, 14.8) One trial^319^ aimed to slow functional decline among patients with mild dementia (not VaD) through pharmacologic and nonpharmacological vascular care (using aspirin, vitamin B6, folate, statins, and, if indicated, therapies targeting blood pressure, glucose, smoking, and diet/activity). And, the last trial was a four-arm trial comparing the effects of exercise, dietary counseling, and exercise plus dietary counseling with an attention control focused on general cardiovascular health topics.^309^ Comparison groups of these latter nine trials included usual care provided by general practitioners^315,^ ^316,^ ^319^ or residential care staff,^313^ a minimal intervention consisting of weekly home visits not focused on well-being,^318,^ ^320^ an attention control focused on cardiovascular disease prevention,^309^ and a waitlist.^291,^ ^317^

##### Results

Cognitive function. There was no clear effect for maintaining or improving global cognitive function in intervention groups compared with control groups. Only three individual trials^321,^ ^323,^ ^324^ targeting mostly patients with MCI found statistically significantly different differences in global cognitive function at 6 to 9 months followup. The remaining trials showed generally null effects for both domain-specific and global measures of cognitive function, with effect sizes often favoring the control groups (many of which were quite intense in content and delivery). Pooling eight trials that included a multicomponent or “other” intervention that reported changes in MMSE score found an average mean difference between groups of 0.26 in favor of the intervention group, although the confidence interval reflected no difference between groups (95% CI, −0.54 to 1.00; k=8; n=1,238; I^2^=30.3%).

Physical function. Changes in physical function were reported in only five trials with only one—a multicomponent group-based intervention with social, cognitive, and physical components over 6 months—finding a statistically significant benefit of the intervention.^324^ The trial of multicomponent exercise and cognitive training,^280^ cognitive behavioral therapy,^291^ a multidisciplinary assessment and treatment plan,^315^ and the trial of comprehensive vascular care^319^ did not find that the interventions slowed the progression of decline in ADLs or IADLs at 3 to 24 months followup compared with sham activities or usual care.

QOL. The four trials focused on improving patients’ well-being and QOL^291,^ ^316–318^ showed no clear benefit of the interventions on measures of QOL in comparison with control groups; only one trial reported greater improvement in the WHO Wellbeing Index (WHO-5) in intervention vs. control participants at 6 months. But this same study found no difference in the EQ-5D measure of health-related QOL.^318^ Likewise, one trial testing the effect of a diagnostic assessment and comprehensive treatment plan found a small effect on caregiver-reported patient QOL at 6 months using the EQ-VAS, but not on other measures of QOL.^315^

Neuropsychiatric symptoms. There was no clear benefit of these multicomponent interventions or interventions aimed at well-being on any measure of symptoms of depression or anxiety or caregiver-ratings of neuropsychiatric symptoms.

Other outcomes. One study conducted a survival analysis of mortality and found a 63 percent lower risk of death in the multidisciplinary assessment intervention group compared with the usual care control group, although the difference was not statistically significant (95% CI, 0.22 to 1.15; p=0.08).^313^

Harms. Five trials^280,^ ^312,^ ^317,^ ^321,^ ^324^ found no differences in the rate of harms between conditions; the remaining 11 trials did not report on harms.

##### Caregiver and Caregiver-Patient Dyad Interventions

We included 88 trials (n=14,880) that targeted the caregiver or caregiver-patient dyad with the primary aim of improving caregiver outcomes. More than one-third (33/88) of these trials were identified as part of this update and the remaining two-thirds (55/88) were included in the previous review. Most of the trials (k=58; n=9,139) evaluated interventions with some type of psychoeducational component for caregivers.^327–383^ These interventions provided information about dementia and/or caregiving and sought to increase caregiver skills (specific caregiving skills or general skills, such as problem solving, and communication applied to caregiving). Seventeen trials (n=3,039) provided case or care management directed at caregiver-patient dyad, with or without psychoeducation for the caregiver.^384–400^ The remaining 13 caregiver-focused intervention trials (n=2,702) evaluated other interventions such as physical activity counseling, social support interventions, and multicomponent dyadic interventions.^401–413^

There was no one consistent outcome reported across caregiver or caregiver-patient dyad intervention trials. The most commonly reported outcomes of these interventions were self-reported caregiver depressive and other mental health symptoms (reported in 62 of 88 trials) and caregiver burden (reported in 52 of 88 trials). Both outcomes were reported using a variety of self-reported measures. The Center for Epidemiologic Studies Depression Scale (CES-D) was the most commonly used instrument to assess symptoms associated with depression. Response options range from 0 to 3 for each item and scores range from 0 to 60, with high scores indicating greater depressive symptoms. For caregiver burden, the most commonly used instrument was the 22-item Zarit Burden Instrument (Zarit-22). The Zarit-22 measures perceived social, physical, financial, and emotional burden of caregiving, as well as providing a total summary score with a range of 0 to 88, where higher scores indicate greater burden. Rates of institutionalization or time to nursing home placement was often a primary outcome of caregiver-patient dyad interventions but should be interpreted alongside the results of other important caregiver and patient outcomes. While delay of institutionalization may be one of the most clinically important outcomes to examine within this field, it is potentially inappropriate if it is accompanied by declines in well-being on the part of family caregivers. Other outcomes such as caregiver and patient QOL were inconsistently reported.

Study, population, and intervention characteristics for all caregiver interventions are presented in Table 19 and Table 20. Summary results are provided in Table 21 and detailed results are provided in Appendix H.

Table 19 Caregiver and Caregiver-Patient Dyad Interventions: Study Characteristics, by Intervention (KQs 4 and 5)

Author, year (study name) | Quality | Country | Audience | N rand | Caregiver age, mean | Caregiver type | Caregiver female, % | Patient BL MMSE, mean
Psychoeducation Interventions
Barnes, 2018^*^,^327^ | Fair | GBR | Caregiver | 55 | 67 | Spouse: 67; Child: 29; Other: 4 | 77 | 24
Belle, 2006^328^; (REACH II) | Fair | US | Caregiver | 642 | 61 | Spouse: 43; Child: 48; Other: 9 | 83 | 13.0
Berwig, 2017^*^,^329^; (GE-REACH) | Fair | DEU | Caregiver | 92 | 73 | Spouse: 89; Child: NR; Other: 11 | 66 | 12.4
Brennan, 1995^330^ | Fair | US | Caregiver | 102 | 60 | Spouse: 68; Child: 28; Other: NR | 67 | NR
Bruvik, 2013^*^,^331^ | Good | NOR | Caregiver + Patient | 230 | 64 | Spouse: 53; Child: 40; Other: 7 | 77 | 21.2
Burgio, 2003^332^; (REACH - Birmingham) | Fair | US | Caregiver | 140 | 63 | Spouse: 50; Child: NR; Other: 50 | 79 | 13.0
Chang, 1999^333^ | Fair | US | Caregiver | 87 | 66 | Spouse: 89; Child: NR; Other: NR | NR | NR
Chu, 2011^334^ | Fair | TWN | Caregiver | 85 | NR | Spouse: 32; Child: 64; Other: NR | 57 | NR
Coon, 2003^335^ | Fair | US | Caregiver | 169 | 64 | Spouse: 57; Child: 43; Other: NR | 100 | 14.2
Cristancho-Lacroix, 2015^*^,^336^ | Fair | FRA | Caregiver | 49 | 62 | Spouse: 37; Child: 59; Other: 4 | 65 | 18.7
De Rotrou, 2011^337^ | Fair | FRA | Caregiver | 157 | 65 | Spouse: 57; Child: 29; Other: NR | 68 | NR
Ducharme, 2011^338^ | Fair | CAN | Caregiver | 121 | 61 | Spouse: 34; Child: 52; Other: 14 | 79 | NR
Duggleby, 2018^*^,^339^; (MT4C) | Fair | CAN | Caregiver | 199 | 64 | Spouse: 49; Child: 46; Other: 5 | 81 | NR
Finkel, 2007^340^ | Fair | US | Caregiver | 46 | 65 | Spouse: 44; Child: 53; Other: NR | 68 | NR
Fung, 2002^*^,^341^ | Fair | HKG | Caregiver | 60 | NR | Spouse: 50; Child: 29; Other: 21 | 63 | NR
Gallagher-Thompson, 2003^342^; (REACH - Palo Alto) | Fair | US | Caregiver | 257 | 57 | Spouse: NR; Child: NR; Other: NR | 100 | 13.7
Gallagher-Thompson, 2008^343^ | Fair | US | Caregiver | 184 | 58 | Spouse: 38; Child: NR; Other: 62 | 100 | 14.1
Gallagher-Thompson, 2010^*^,^344^ | Good | US | Caregiver | 76 | 59 | Spouse: 13; Child: NR; Other: NR | 87 | NR
Garand, 2014^*^,^345^ | Fair | US | Caregiver | 73 | 65 | Spouse: 75; Child: NR; Other: NR | 78 | NR
Gaugler, 2013^*^,^346^; (NYUCI-AC) | Fair | US | Family | 107 | 50 | Spouse: 0; Child: 100; Other: 0 | 94 | NR
Gitlin, 2001^347^ | Fair | US | Caregiver | 202 | 60 | Spouse: 25; Child: NR; Other: 75 | 73 | NR
Gitlin, 2003^349^; (REACH - Philadelphia) | Fair | US | Caregiver | 255 | 61 | Spouse: 35; Child: NR; Other: NR | 74 | 12.2
Gitlin, 2008^348^ | Fair | US | Caregiver + Patient | 60 | 65 | Spouse: 62; Child: 38; Other: 0 | 88 | 11.6
Gitlin, 2010^350^; (ACT) | Fair | US | Caregiver | 272 | 66 | Spouse: 51; Child: NR; Other: NR | 82 | 13.0
Gitlin, 2010^462^; (COPE) | Fair | US | Caregiver + Patient | 237 | 62 | Spouse: 38; Child: NR; Other: 62 | 89 | 13.4
Graff, 2006^351^ | Fair | NLD | Caregiver + Patient | 135 | 64 | Spouse: 58; Child: 32; Other: 10 | 70 | 19.0
Hebert, 2003^352^ | Fair | CAN | Caregiver | 144 | 60 | Spouse: 61; Child: NR; Other: NR | 80 | NR
Hepburn, 2005^353^ | Fair | US | Caregiver | 215 | 66 | Spouse: 66; Child: NR; Other: NR | 76 | 17.7
Joling, 2012^354^ | Fair | NLD | Family | 192 | 70 | Spouse: 94; Child: NR; Other: NR | 70 | 12.6
Judge, 2013^*^,^355^; (ANSWERS) | Fair | US | Caregiver + Patient | 128 | 65 | Spouse: 60; Child: NR; Other: NR | 74 | 23.0
Koivisto, 2016^*^,^356^; (ALSOVA) | Fair | FIN | Caregiver + Patient | 236 | 66 | Spouse: 70; Child: 23; Other: 6 | 66 | 21.5
Kurz, 2010^357^; (AENEAS) | Fair | AUT, DEU, CHE | Caregiver | 292 | 62 | Spouse: 58; Child: 38; Other: NR | 69 | 13.9
Kwok, 2013^*^,^358^ | Fair | HKG | Caregiver | 42 | NR | Spouse: 10; Child: 87; Other: 3 | 71 | NR
Laakkonen, 2016^*^,^359^ | Fair | FIN | Caregiver + Patient | 136 | 75 | Spouse: 100; Child: 0; Other: 0 | 62 | 20.8
Livingston, 2013^*^,^360^; (START) | Good | GBR | Caregiver | 260 | 59 | Spouse: 42; Child: 44; Other: 15 | 68 | NR
Losada, 2010^361^ | Fair | ESP | Caregiver | 167 | 60 | Spouse: 35; Child: 59; Other: 6 | 83 | NR
Mariott, 2000^362^ | Fair | GBR | Caregiver | 28 | 64 | Spouse: 52; Child: 41; Other: 7 | 69 | 12.5
Martin-Carrasco, 2009^364^ | Fair | ESP | Caregiver | 115 | 58 | Spouse: 55; Child: 36; Other: 9 | 69 | 18.7
Martin-Carrasco, 2014^*^,^363^; (EDUCA-II) | Fair | ESP | Caregiver | 238 | 62 | Spouse: 49; Child: 45; Other: 6 | 77 | 12.9
Martin-Cook, 2005^365^ | Fair | US | Caregiver + Patient | 49 | NR | Spouse: 92; Child: 6; Other: 2 | 70 | 19.4
Martindale-Adams, 2013^*^,^366^; (CONNECT) | Fair | US | Caregiver | 154 | 66 | Spouse: 72; Child: 23; Other: 5 | 84 | 15.4
Mittelman, 2004^*^,^367^; (NYUCI) | Fair | US | Family | 406 | 71 | Spouse: 100; Child: 0; Other: 0 | 60 | NR
Nunez-Naveira, 2016^*^,^368^ | Fair | DNK, POL, ESP | Caregiver | 77 | NR | Spouse: NR; Child: NR; Other: NR | 64 | NR
Ostwald, 1999^369^ | Fair | US | Caregiver + Patient | 117 | 66 | Spouse: 66; Child: 28; Other: NR | 65 | NR
Roberts, 1999^370^ | Fair | CAN | Caregiver | 77 | 62 | Spouse: 52; Child: 45; Other: NR | 70 | NR
Schoenmakers, 2010^371^ | Fair | BEL | Caregiver | 62 | 63 | Spouse: 46; Child: 34; Other: 20 | 76 | NR
Steffen, 2016^*^,^373^ | Good | US | Caregiver | 74 | 60 | Spouse: 52; Child: 43; Other: 10 | 100 | NR
Spaulding-Wilson, 2018^*^,^372^ | Fair | US | Caregiver | 104 | 63 | Spouse: 45; Child: 52; Other: 3 | 73 | NR
Teri, 2005^374^ | Fair | US | Caregiver | 95 | 65 | Spouse: 55; Child: 31; Other: 14 | 70 | 13.6
Tremont, 2015^*^,^375^ | Fair | US | Caregiver | 250 | 63 | Spouse: 51; Child: 42; Other: 7 | 78 | NR
Ulstein, 2007^376^ | Fair | NOR | Caregiver | 180 | 65 | Spouse: 70; Child: 28; Other: NR | 64 | 20.8
Voigt-Radloff, 2011^377^ | Fair | DEU | Caregiver + Patient | 141 | 65 | Spouse: 56; Child: 37; Other: 6 | 71 | 20.4
Waldorff, 2012^378^; (DAISY) | Good | DNK | Caregiver + Patient | 330 | 66 | Spouse: 65; Child: 26; Other: 9 | 67 | 24.1
Wang, 2011^*^,^379^ | Fair | HKG | Caregiver + Patient | 80 | 41 | Spouse: 40; Child: 38; Other: 22 | 65 | 17.4
Williams, 2010^380^ | Fair | US | Caregiver | 116 | 60 | Spouse: 41; Child: 50; Other: 9 | 78 | NR
Wilz, 2016^*^,^381^ | Fair | DEU | Caregiver | 176 | 62 | Spouse: NR; Child: NR; Other: NR | 82 | NR
Wilz, 2018^*^,^382^; (Tele.TAnDem) | Good | DEU | Caregiver | 273 | 64 | Spouse: 60; Child: 38; Other: 2 | 81 | NR
Wright, 2001^383^ | Fair | US | Caregiver | 93 | 60 | Spouse: 45; Child: 38; Other: 17 | 76 | NR
Care/Case Management Interventions
Bass, 2003^384^ | Fair | US | Caregiver + Patient | 182 | NR | Spouse: NR; Child: NR; Other: NR | NR | NR
Callahan, 2006^385^ | Fair | US | Caregiver + Patient | 153 | 61 | Spouse: 44; Child: 36; Other: 20 | 89 | 18.0
Chien, 2008^*^,^387^ | Fair | HKG | Family | 88 | 44 | Spouse: 32; Child: 36; Other: 32 | 64 | 17.4
Chien, 2011^*^,^386^ | Good | HKG | Caregiver + Patient | 92 | 45 | Spouse: 27; Child: 39; Other: 34 | 66 | NR
Chu, 2000^388^ | Fair | CAN | Caregiver + Patient | 75 | NR | Spouse: NR; Child: NR; Other: NR | 73 | 22.8
Eloniemi-Sulkava, 2009^390^ | Good | FIN | Caregiver + Patient | 125 | 75 | Spouse: 100; Child: 0; Other: NR | 62 | 13.8
Eloniemi-Sulvaka, 2001^389^ | Fair | FIN | Caregiver + Patient | 100 | 64 | Spouse: 56; Child: 34; Other: 10 | 69 | 14.8
Fortinsky, 2009^391^ | Fair | US | Caregiver + Patient | 84 | 62 | Spouse: 45; Child: 46; Other: 9 | 69 | NR
Jansen, 2011^392^ | Fair | NLD | Caregiver + Patient | 99 | 63 | Spouse: 40; Child: 48; Other: 9 | 70 | 22.3
Lam, 2010^393^ | Fair | HKG | Caregiver + Patient | 102 | NR | Spouse: 29; Child: 60; Other: NR | 74 | 17.8
Mavandadi, 2017^*^ | Fair | US | Caregiver + Patient | 75 | 70 | Spouse: 83; Child: NR; Other: NR | 97 | NR
Meewsen, 2012^395^; (AD-Euro) | Good | NLD | Caregiver + Patient | 175 | 64 | Spouse: 54; Child: 41; Other: 5 | 70 | 22.7
Menn, 2012^396^ | Fair | DEU | Caregiver + Patient | 390 | 59 | Spouse: 32; Child: 59; Other: 9 | 73 | 18.7
Samus, 2014^*^,^397^; (MIND) | Fair | US | Caregiver + Patient | 303 | 67 | Spouse: 43; Child: 48; Other: 9 | 75 | 19.1
Thyrian, 2017^*^,^398^; (DelpHi) | Fair | DEU | Caregiver + Patient | 516 | NR | Spouse: NR; Child: NR; Other: NR | NR | 22.8
Vickrey, 2006^399^ | Good | US | Caregiver + Patient | 408 | 66 | Spouse: 55; Child: 39; Other: 6 | 69 | NR
Xiao, 2016^*^,^400^ | Fair | AUS | Caregiver | 72 | 56^†^ | Spouse: 26; Child: NR; Other: NR | 84 | NR
Other Interventions
Charlesworth, 2008^401^ | Fair | GBR | Caregiver | 236 | 68 | Spouse: 67; Child: NR; Other: NR | 64 | NR
Connell, 2009^402^ | Fair | US | Caregiver | 157 | 67 | Spouse: 100; Child: 0; Other: NR | 100 | NR
Gitlin, 2018^*^,^403^; (TAP-VA) | Fair | US | Caregiver + patient | 160 | 72 | Spouse: 87; Child: NR; Other: 13 | 98 | 16.6
Hirano, 2011^404^ | Fair | JPN | Caregiver | 36 | 74 | Spouse: NR; Child: NR; Other: NR | 68 | 18.3
King, 2002^405^ | Fair | US | Caregiver | 100 | 63 | Spouse: 53; Child: 47; Other: 0 | 100 | NR
Leach, 2015^*^,^406^; (TRANSCENDENT) | Good | AUS | Caregiver | 17 | 66 | Spouse: 65; Child: 35; Other: 5 | 88 | NR
LoGiudice, 1999^407^ | Fair | AUS | Caregiver + Patient | 50 | 61 | Spouse: 54; Child: 36; Other: 10 | 78 | 17.0
Nourhashemi, 2010^408^; (PLASA) | Fair | FRA | Caregiver + Patient | 1131 | NR | Spouse: NR; Child: NR; Other: NR | NR | 19.7
Pillemer, 2002^409^ | Fair | US | Caregiver | 147 | 58 | Spouse: 40; Child: 60; Other: 0 | 71 | NR
Prick, 2015^*^,^410^ | Fair | NLD | Caregiver + Patient | 111 | 72 | Spouse: 90; Child: NR; Other: 10 | 72 | 21.0
Spijker, 2011^411^ | Good | NLD | Caregiver | 301 | 59 | Spouse: 28; Child: 52; Other: 6 | 73 | NR
Teri, 2003^412^ | Good | US | Caregiver + Patient | 153 | NR | Spouse: NR; Child: NR; Other: NR | NR | 16.7
Winter, 2006^413^ | Fair | US | Caregiver | 103 | 67 | Spouse: 41; Child: NR; Other: NR | 100 | NR

* New study

† Median

Abbreviations: ACT = Advancing Caregiver Training; AENEAS = A European Network for the Evaluation of Alzheimer Support groups; ALSOVA = Alzheimer’s Disease Follow-up Study; ANSWERS = Acquiring New Skills While Enhancing Remaining Strengths; AUS = Australia; AUT = Austria; BL = baseline; BEL = Belgium; CAN = Canada; CHE = Chile; CONNECT = Telephone Support for Dementia Caregivers; COPE = Care of Persons with Dementia in their Environments; DAISY = Danish Alzheimer Intervention Study; DelpHi = Dementia: Life- and Person-Centered Help in Mecklenburg-Western Pomerania; DEU = Germany; DNK = Denmark; ESP = Spain; FIN = Finland; FRA = France; GBR = Great Britain/United Kingdom; GE-REACH = German Adaptation of Resources for Enhancing Alzheimer’s Caregiver Health; HKG = Hong Kong; JPN = Japan; MIND = Maximizing Independence at Home; MT4C = My Tools 4 Care; N rand = number of participants randomized; NLD = Netherlands; NOR = Norway; NR = not reported; NYUCI = New York University Caregiver Intervention; NYUCI-AC = New York University Caregiver Intervention-Adult Child; PLASA = Plan de Soin et d’Aide dans la maladie d’Alzheimer or “Specific Care and Assistance Plan for Alzheimer Disease"; POL = Poland; REACH = Resources for Enhancing Alzheimer’s Caregiver Health; START = STrAtegies for RelaTives; TAP-VA = Tailored-Activity Program-Veterans Affairs; Tele.TAnDem = Telephone-based CBT for Family Caregivers of People With Dementia; TRANSCENDENT = Transcendental Meditation for the improvement of health and wellbeing in community-dwelling dementia caregivers; TWN = Taiwan

Table 20 Caregiver and Caregiver-Patient Dyad Interventions: Intervention Characteristics, by Intervention (KQs 4 and 5)

Author, year Quality | Country | Intervention type | Audience | Brief intervention group description | Duration, months | Brief control group description
Psychoeducation Interventions
Barnes, 2018^*^,^327^; Fair | GBR | Individual psychoeducation | Caregiver | Individual home-based psychoeducation sessions for 3 d/2 months, 60-min/d | 2 | BI: One 60-min general support session to discuss any issues identified at the point of referral.
Belle, 2006^328^; Fair | US | Individual psychoeducation | Caregiver | Individual- and group-based psychoeducation and support through nine 90-min in-home sessions and three 30-min telephone sessions plus 5 structured telephone support group sessions over 6 months. | 6 | BI: Educational materials and two 15-min phone calls.
Berwig, 2017^*^,^329^; Fair | DEU | Individual psychoeducation | Caregiver | Individual psychoeducation, problem-solving, and social support through nine 90-min in-home sessions and three 30-min telephone sessions over 6 months. | 6 | UC: Care as usual corresponding with available services determined by German Care Insurance.
Brennan, 1995^330^; Fair | US | Telehealth psychoeducation | Caregiver | Computer-based psychoeducation program and moderated support ("ComputerLink") with access 24 h/d, 7 d/wk. over 1 year. | 12 | BI: In-person training on identifying local services and resources
Bruvik, 2013^*^,^331^; Good | NOR | Individual psychoeducation | Caregiver + Patient | Individual- and group-based psychoeducation and support through five 60-min individual counseling sessions, 2 half-day seminars, and six 2-hr group meetings over 12 months. | 12 | BI: Information on local services.
Burgio, 2003^332^; Fair | US | Individual psychoeducation | Caregiver | Individualized psychoeducation through one 3-hr group workshop, eleven 60-min in-home sessions, and five 15-min phone calls over 1 year. | 12 | BI: Minimal support control delivered through five 15-min telephone calls focused on empathetic and active listening and generic educational materials.
Chang, 1999^333^; Fair | US | Telehealth psychoeducation | Caregiver | Videos demonstrating assisted modeling behaviors specific to dressing and eating plus reinforcing telephone calls 1 d/wk over 12 weeks. | 3 | MI: Telephone calls on same schedule as intervention (1 d/wk over 12 weeks) to assess general well-being, but offered no specific strategies for dressing or eating.
Chu, 2011^334^; Fair | TWN | Group-based psychoeducation | Caregiver | Group-based psychoeducation and support through 12 weekly group sessions over 3 months. | 3 | UC: Standard care provided in Taiwan (not described).
Coon, 2003^335^; Fair | US | IG1: Group-based psychoeducation; IG2: Group-based psychoeducation | Caregiver | IG1: Group-based psychoeducation focused on anger management through 8 weekly 120-min sessions over 4 months.; IG2: Group-based psychoeducation focused on depression management through 8 weekly 120-min sessions over 4 months. | 4 | WL: Offered either anger management or depression management intervention after study ended.
Cristancho-Lacroix, 2015^*^,^336^; Fair | FRA | Telehealth psychoeducation | Caregiver | Computer-based psychoeducation program and support ("Diapason") with 12 sessions intended for 1 d/wk, 15–30 min/d for 3 months. | 3 | WL: Offered intervention after study ended.
De Rotrou, 2011^337^; Fair | FRA | Group-based psychoeducation | Caregiver | Group-based psychoeducation through 12 weekly 120-min sessions over 3 months. | 3 | WL: Offered intervention after study ended.
Duggleby, 2018^*^,^339^; Fair | CAN | Individual psychoeducation | Caregiver | Self-administered web-based psychoeducation for 3 months | 3 | WL: Participants received a copy of the publicly available Alzheimer’s Society’s “The Progression of Alzheimer’s Disease” booklet via email and were offered access to the intervention website after three months.
Ducharme, 2011^338^; Fair | CAN | Individual psychoeducation | Caregiver | Individual-based “Learning to Become a Family Caregiver” program consisting of psychoeducation sessions for 1 d/wk, 90 min/d over 7 weeks. | 2 | UC: Usual care provided by memory clinics including referrals to local services.
Finkel, 2007^340^; Fair | US | Telehealth psychoeducation | Caregiver | Computer- and telephone-based psychoeducation and moderated support ("Computer-Telephone Integration System") including 2 in-home sessions and 12 sessions conducted via computer/telephone over 6 months. | 6 | BI: Basic educational materials and 2 brief telephone check-in calls.
Fung, 2002^*^,^341^; Fair | HKG | Group-based psychoeducation | Caregiver | Group-based psychoeducation program through 12 weekly 60-min sessions over 3 months. | 3 | UC: Standard family services provided by dementia care center (Hong Kong) including culturally tailored medical assessment and treatment, advice and referrals to social welfare services, and monthly educational talks in dementia care and social and recreational activities
Gallagher-Thompson, 2003^342^; Fair | US | Group-based psychoeducation | Caregiver | Group-based “Coping with Caregiving” psychoeducation class through 10 weekly 120-min group sessions followed by 8 monthly 120-min booster sessions over 10 months. | 10 | MI: Written educational materials and brief, regularly scheduled empathetic telephone support calls.
Gallagher-Thompson, 2008^343^; Fair | US | Group-based psychoeducation | Caregiver | Group-based “Coping with Caregiving” psychoeducation class through 12 weekly 120-min classes over 4 months. | 4 | MI: Written educational materials and seven 15–30 min empathetic telephone support calls.
Gallagher-Thompson, 2010^*^,^344^; Good | US | Telehealth psychoeducation | Caregiver | Culturally-tailored psychoeducational/cognitive behavioral skill training program delivered via 150 min DVD with 3 telephone check-in calls. | 3 | AC: General 150-min DVD on dementia with 3 telephone check-in calls.
Garand, 2014^*^,^345^; Fair | US | Individual psychoeducation | Caregiver | Individual problem-solving therapy including 6 in-person sessions, 90 min/session over 3 months followed by 3 telephone contacts, 45 min/call over 1.5 months. | 4.5 | AC: In-person and telephone counseling focused on nutrition following same schedule as intervention (6 in-person sessions and 3 telephone contacts).
Gaugler, 2013^*^,^346^; Fair | US | Family-based psychoeducation | Family | "New York University Caregiver Intervention - adapted for adult child caregivers" consisting of 6 individual and family counseling sessions, support group participation, and ad hoc counseling in-person or via phone or e-mail over 4 months. | 4 | MI: Biannual project newsletter and quarterly check-in calls including ad hoc consultations as necessary.
Gitlin, 2001^347^; Fair | US | Individual psychoeducation | Caregiver | Individual in-person psychoeducation sessions and home environmental modifications during five 90-min biweekly home visits over 3 months. | 3 | UC: Usual care not described; given education materials and booklet describing home environmental safety tips after study was over.
Gitlin, 2003^349^; Fair | US | Individual psychoeducation | Caregiver | Individual-based “Environment Skill-Building Program” including psychoeducation, problem-solving training, and adaptive equipment provided through five 90-min home visits and one 30-min telephone call over 6 months followed by maintenance sessions over another 6 months. | 12 | UC: Usual care not described; given information on local resources.
Gitlin, 2008^348^; Fair | US | Individual psychoeducation | Caregiver + Patient | Individual-based “Tailored Activity Program” including customized activities to address neuropsychiatric and functional needs through six 90-min home visits and two 150-min telephone contacts over 4 months. | 4 | WL: Offered intervention after study ended.
Gitlin, 2010^462^; Fair | US | Individual psychoeducation | Caregiver + Patient | Individual-based intervention including assessments, caregiver education, and caregiver training for up to 10 occupational therapy home visits and 1 in-person and 1 telephone call with a nurse over 4 months. | 4 | MI: Up to 3 20-min telephone calls and mailed materials.
Gitlin, 2010^350^; Fair | US | Individual psychoeducation | Caregiver | Individual-based “Advancing Caregiver Training” consisting of activities to address patient-, caregiver-, and environmental-based needs through up to 9 occupational therapy visits, 1 in-home and 1 telephone nursing session, and 3 brief telephone contacts over 4 months. | 6 | None: Offered 2-hr in-home workshop involving education and tips for managing problem behaviors after study ended.
Graff, 2006^351^; Fair | NLD | Individual psychoeducation | Caregiver + Patient | In-home, individual-based occupational therapy during ten 60-min sessions over 5 weeks. | 1 | WL: Offered intervention after study ended.
Hebert, 2003^352^; Fair | CAN | Group-based psychoeducation | Caregiver | Group-based psychoeducation through 15 weekly 120-min sessions over 4 months. | 4 | UC: Referred to regular support group program offered by local Alzheimer’s Society (Canada) or health care organizations in their region.
Hepburn, 2005^353^; Fair | US | Group-based psychoeducation | Caregiver | "Partners in Caregiving" group-based psychoeducation program through 6 weekly 120-min sessions over 6 weeks. | 1.5 | WL: Offered intervention after study ended.
Joling, 2012^354^; Fair | NLD | Family-based psychoeducation | Family | Family- and individual-based counseling through 2 individual counseling session and 4 family counseling sessions over 1 year. | 12 | UC: Standard care provided by the Netherland’s community health services, which does not include support groups.
Judge, 2013^*^,^355^; Fair | US | Individual psychoeducation | Caregiver + Patient | Individual-based “ANSWERS” psychoeducation and cognitive rehabilitation program consisting of six 90-min individual sessions over 3 months. | 3 | BI: Standardized education resource packet and information on local resources.
Koivisto, 2016^*^,^356^; Fair | FIN | Group-based psychoeducation | Caregiver + Patient | Group-based psychoeducation and support through 4 group-based courses (for 16 days total) over 2 years. | 24 | UC: Basic counseling by a memory nurse at time of diagnosis and followed up with their normal healthcare system.
Kurz, 2010^357^; Fair | AUT, DEU, CHE | Group-based psychoeducation | Caregiver | Group-based psychoeducation through 7 bi-weekly 90-min sessions and 6 bi-monthly refresher sessions over 15 months. | 15 | UC: One standard individual counseling session.
Kwok, 2013^*^,^358^; Fair | HKG | Telehealth psychoeducation | Caregiver | Telephone-based psychoeducation and training for 1 d/wk, 30 min/d plus educational DVD over 12 weeks. | 3 | BI: Educational DVD about dementia caregiving.
Laakkonen, 2016^*^,^359^; Fair | FIN | Group-based psychoeducation | Caregiver + Patient | Group-based psychoeducation and support through 8 weekly 4-hr sessions over 8 weeks. | 2 | UC: Standard care provided by Finnish health and social service system.
Livingston, 2013^*^,^360^; Good | GBR | Individual psychoeducation | Caregiver | Individual-based “START” psychoeducation and support program consisting of eight 60-min in-home sessions over 2–3 months. | 2–3 | UC: Standard care for the family member with dementia including pharmacologic and nonpharmacologic treatment and caregiver support.
Losada, 2010^361^; Fair | ESP | Group-based psychoeducation | Caregiver | Group-based psychoeducation through 12 weekly 90–120-min sessions over 3 months. | 3 | UC: Standard care or assistance provided by social and health centers in Spain plus offered intervention after study ended.
Mariott, 2000^362^; Fair | GBR | Individual psychoeducation | Caregiver | Individual-based psychoeducation during 14 sessions every other week over 7 months. | 7 | None: No intervention.
Martin-Carrasco, 2009^364^; Fair | ESP | Individual psychoeducation | Caregiver | Individual-based “Psychoeducational Intervention Program” through eight 90-min sessions over 4 months. | 4 | UC: Standard care for caregivers including information on dementia and local resources and on-demand in-person and phone support.
Martin-Carrasco, 2014^*^,^363^; Fair | ESP | Group-based psychoeducation | Caregiver | Group-based “Psychoeducational Intervention Program” consisting of 7 sessions, 90–120-min each over 3 months.^†^ | 3 | UC: Standard care from day center or memory clinic including information for caregivers.
Martin-Cook, 2005^365^; Fair | US | Individual psychoeducation | Caregiver + Patient | Individual-based psychoeducation through 4 weekly sessions over 1 month. | 1 | WL: Given information on local resources and offered intervention after study ended.
Martindale-Adams, 2013^*^,^366^; Fair | US | Telehealth psychoeducation | Caregiver | Telephone-based, group psychoeducation and support through fourteen 60-min telephone group sessions plus workbook over 12 months. | 12 | BI: General print materials on dementia and safety and information on local resources; offered intervention workbook and one workshop after study ended.
Mittelman, 2004^*^,^367^; Fair | US | Family-based psychoeducation | Family | Family- and individual-based counseling through two 60–180-min individual counseling sessions and four 60–180-min family counseling sessions, weekly support groups, and ad hoc counseling as needed over 4 months. | ≥4 | UC: Standard services provided by the NYU Alzheimer’s Disease Center including information and advice on request plus access to same support groups and ad hoc counseling provided to intervention group.
Nunez-Naveira, 2016^*^,^368^; Fair | DNK, POL, ESP | Telehealth psychoeducation | Caregiver | App-based psychoeducation and support ("UnderstAID application") with 5 different learning modules, a calendar and note-taking section, a moderated social networking section, and options for receiving personalized feedback. | 3 | None: No intervention.
Ostwald, 1999^369^; Fair | US | Group-based psychoeducation | Caregiver + Patient | "Minnesota Family Workshop" group-based psychoeducation program through 7 weekly 120-min sessions over 7 weeks. | 3 | WL: Offered intervention after study ended.
Roberts, 1999^370^; Fair | CAN | Individual psychoeducation | Caregiver | Individual-based problem-solving training through up to 10 in-home or telephone sessions over 6 months. | 6 | UC: Access to community and respite services by other nurses and volunteer agencies.
Schoenmakers, 2010^371^; Fair | BEL | Individual psychoeducation | Caregiver | Individual-based support to support home care through 4 home visits and 12 telephone calls over 1 year and ad-hoc care counselor support. | 12 | UC: Access to usual care systems.
Spaulding-Wilson, 2018^*^,^372^; Fair | US | Group-based psychoeducation | Caregiver | Group-based psychoeducation delivered in a 2 day workshop. | 0.07 | WL: Offered intervention after study ended.
Steffen, 2016^*^,^373^; Good | US | Telehealth psychoeducation | Caregiver | Video- and telephone-based psychoeducation consisting of ten 30-min video segments, a workbook, and ten telephone calls over 14 weeks. | 3 | MI: Basic education and support via an Alzheimer’s Basic Care Guide and seven 20-min telephone calls every other week.
Teri, 2005^374^; Fair | US | Individual psychoeducation | Caregiver | Individual-based psychoeducation program “STAR-Caregivers” consisting of 8 weekly in-home treatment sessions followed by 4 monthly phone calls over 6 months. | 6 | UC: Standard medical care including nonspecific advice and support routinely provided by nurses and primary physicians or community support services with no specific behavior-management training.
Tremont, 2015^*^,^375^; Fair | US | Telehealth psychoeducation | Caregiver | Individual, telephone-based psychoeducation provided over sixteen 30–60 min calls over 6 months. | 6 | MI: Non-directive telephone support following same schedule as intervention (sixteen 30–60 min calls over 6 months).
Ulstein, 2007^376^; Fair | NOR | Group-based psychoeducation | Caregiver | Group-based psychoeducation consisting of one 3-hr educational program and six 2-hr group meetings over 4.5 months. | 4.5 | UC: Patients received standard memory clinic care and caregivers were offered to talk with an experienced nurse and offered advice and ad hoc counseling as needed.
Voigt-Radloff, 2011^377^; Fair | DEU | Individual psychoeducation | Caregiver + Patient | Individual-based psychoeducation and support through three home visits and two telephone calls over 1 year. | 1.25 | MI: Usual care and 60 min of community occupational therapy consultation.
Waldorff, 2012^378^; Good | DNK | Group-based psychoeducation | Caregiver + Patient | Individual- and group-based psychoeducation and support through up to 7 individual counseling sessions for both patient and caregiver, five 2-hr educational group courses, and up to 8 followup phone calls over 8–12 months. | 8–12 | BI: General information and guidance about dementia and information and referral to local resources at 6 and 12 months.
Wang, 2011^*^,^379^; Fair | HKG | Group-based psychoeducation | Caregiver + Patient | Group-based psychoeducation program “Family Mutual Support Programme in Dementia Care” through 8 bi-weekly 120-min sessions over 6 months. | 6 | UC: Standard family services provided by dementia care center (Hong Kong) including culturally tailored medical assessment and treatment, advice and referrals to social welfare services, and monthly educational talks in dementia care and social and recreational activities.
Williams, 2010^380^; Fair | US | Telehealth psychoeducation | Caregiver | Video- and telephone-based psychoeducation consisting of ten 7–10-min video segments, a workbook, and five telephone calls over 5 weeks. | 1.25 | WL: Offered intervention after study ended.
Wilz, 2016^*^,^381^; Fair | DEU | Telehealth psychoeducation | Caregiver | Telephone-based psychoeducation and training through seven 60-min sessions over 3 months; first session was in home and remaining six sessions were via telephone. | 3 | BI: Written educational material on dementia, dementia caregiving, and local resources.
Wilz, 2018^*^,^382^; Good | DEU | Telehealth psychoeducation | Caregiver | Telephone-based psychoeducation and training through 12 50-min sessions over 6 months. | 6 | UC: Written educational material about dementia and caregiving.
Wright, 2001^383^; Fair | US | Individual psychoeducation | Caregiver | Individual-based psychoeducation and support through three home visits and two telephone calls over 1 year. | 12 | None: No intervention.
Care/Case Management Interventions
Bass, 2003^384^; Fair | US | Care/Case Management + Psychoeducation | Caregiver + Patient | Partnership between local Alzheimer’s Association and managed care plan to provide care consultation and individualized treatment plans to families over 1 year through regular telephone calls (12 calls per year on average). | 12 | UC: Standard care provided by managed care and ability to contact Alzheimer’s Association on their own.
Callahan, 2006^385^; Fair | US | Care/Case Management + Psychoeducation | Caregiver + Patient | Care management for patients and caregivers including pharmacotherapy treatment and individualized caregiver psychoeducation and support through monthly in-person sessions and telephone-based support groups over 1 year. | 12 | MI: Augmented usual care including 40–90 min of counseling by geriatric nurse practitioner, written consultation note to PCP communicating results of diagnostic assessment, and materials describing local resources.
Chien, 2008^*^,^387^; Fair | HKG | Care/Case Management + Psychoeducation | Family | Care management for patients and caregivers including assessment, education, support, and referrals including twelve 2-hr group sessions and monthly home visits over 6 months. | 6 | MI: Routine care provided by Hong Kong Dementia Care Center including pharmacotherapy, social and recreational activities, and materials for caregivers plus 6 monthly psychoeducation group sessions for caregivers.
Chien, 2011^*^,^386^; Good | HKG | Care/Case Management + Psychoeducation | Caregiver + Patient | Dementia Family Care Programme including assessment, education, support, and referrals including ten 2-hr individual sessions. | 6 | MI: Routine care provided by Hong Kong Dementia Care Center including pharmacotherapy, social and recreational activities, and materials for caregivers plus 6 monthly psychoeducation group sessions for caregivers.
Chu, 2000^388^; Fair | CAN | Care/Case Management + Psychoeducation | Caregiver + Patient | Multicomponent “Early Home Care Program” including case management with education, referrals to community services, ongoing monitoring, supportive counseling, and skills training through monthly in-person or telephone contacts in addition to conventional home care (occupational and physical therapy, respite care, personal care assistance, social work, nursing) over 1.5 years. | 18 | UC: Conventional home care program provided by local Canadian Home Care Program, but not including case management.
Eloniemi-Sulkava, 2009^390^; Good | FIN | Care/Case Management + Psychoeducation | Caregiver + Patient | Multicomponent support with family care coordinator, geriatrician medical assessments and treatment, support groups, and individualized services through group sessions over 2 years. | 24 | UC: Standard services provided for geriatric patients in Finland community care by the municipal social and healthcare system or private sector.
Eloniemi-Sulvaka, 2001^389^; Fair | FIN | Care/Case Management + Psychoeducation | Caregiver + Patient | Comprehensive support provided by a “Dementia Family Care Coordinator” through counseling, in-home visits, annual courses, facilitating care plans, and arranging social and health care services over 2 years. | 24 | UC: Standard services provided for geriatric patients in Finland community care by the municipal social and healthcare system or private sector.
Fortinsky, 2009^391^; Fair | US | Care/Case Management + Psychoeducation | Caregiver + Patient | Partnership between local Alzheimer’s Association and primary care physicians to provide care consultation and individualized treatment plans to families through monthly contact over 1 year. | 12 | UC: Standard primary care plus package of educational materials.
Jansen, 2011^392^; Fair | NLD | Care/Case Management + Psychoeducation | Caregiver + Patient | Case management including assessment, advice and information, planning, coordinating, organizing collaboration, and monitoring of care provided through home visits and telephone calls over 1 year. | 12 | UC: Standard health care and welfare services in the Netherlands.
Lam, 2010^393^; Fair | HKG | Care/Case Management + Psychoeducation | Caregiver + Patient | Case management including assessment and advice, cognitive stimulation, coordination with geriatricians, and referrals to local social services provided through home visits and telephone calls over 4 months. | 4 | MI: One home visit focused on home safety, with no case management.
Mavandadi, 2017^*^,^394^; Fair | US | Care/Case Management + Psychoeducation | Caregiver + Patient | Care management including assessment and advice, education, support, and coordination through monthly telephone calls over 3 months. | 3 | UC: Standard care through VA and mailed general materials about VA and community resources for patients and caregivers.
Meewsen, 2012^395^; Good | NLD | Care/Case Management + Psychoeducation | Caregiver + Patient | Care coordination and post-diagnosis treatment provided by memory clinic. | 12 | UC: Usual care coordination and post-diagnosis treatment provided only by general practitioner.
Menn, 2012^396^; Fair | DEU | IG1: Care/Case Management + Psychoeducation; IG2: Care/Case Management + Psychoeducation | Caregiver + Patient | IG1: Training for primary care physicians on evidence-based treatment for dementia plus physician suggested that caregiver attend support groups and receive counseling for up to 2 years.; IG2: Training for primary care physicians on evidence-based treatment for dementia plus physician suggested that caregiver attend support groups and receive counseling for up to 1 year. | 24 | UC: General training course on dementia care for physicians and usual dementia medical treatment.
Samus, 2014^*^,^397^; Fair | US | Care/Case Management + Psychoeducation | Caregiver + Patient | Dementia Care Needs Assessment and care coordination including two home visits and monthly contact with families over 18 months. | 18 | MI: Received results of Dementia Care Needs Assessment, recommendations for each unmet need, and brief resource guide with local and national aging organizations.
Thyrian, 2017^*^,^398^; Fair | DEU | Care/Case Management + Psychoeducation | Caregiver + Patient | Care management and interdisciplinary collaboration including assessment and individualized treatment plans, medication management, and caregiver support including 6 home visits over 6 months and ongoing telephone support for remaining 6 months. | 12 | UC: Usual primary care provided to patients and caregivers in Germany (not described).
Vickrey, 2006^399^; Good | US | Care/Case Management + Psychoeducation | Caregiver + Patient | Care coordination for 18 months including communication within and between organizations, Internet-based care management, collaborative care planning with caregivers, caregiver self-management support, ongoing follow-up, and provider education. | 18 | UC: Usual care provided by primary care clinics.
Xiao, 2016^*^,^400^; Fair | AUS | Care/Case Management + Psychoeducation | Caregiver | Extending usual care coordination for patient to also support caregivers through quarterly home visits and monthly telephone calls over 1 year. | 12 | UC: Care coordination for patient provided as part of usual care in Australia and optional activities for caregivers including monthly support group meetings and information sessions.
Other Interventions
Charlesworth, 2008^401^; Fair | GBR | Social support | Caregiver | "Befriending" intervention matching trained volunteers with caregivers to provide emotional and informational support through weekly home visits over at least 6 months. | 6 | UC: Standard care provided by local health, social, or voluntary services.
Connell, 2009^402^; Fair | US | Physical activity counseling | Caregiver | "Health First" video- and telephone-based counseling to encourage physical activity provided through 14 telephone calls over 6 months. | 6 | None: No intervention.
Gitlin, 2018^*^,^403^; Fair | US | Multidisciplinary assessment | Caregiver + patient | Multidisciplinary assessment and tailored care plan involving 8 treatment sessions over 4 months. | 4 | MI: Biweekly telephone-based dementia education sessions (8 30-min contacts) over 4 months.
Hirano, 2011^404^; Fair | JPN | Physical activity counseling | Caregiver | One-time prescription to participate in moderate-intensity physical activity 3 times per week over the course of 3 months. | 3 | MI: Carried a pedometer that recorded daily steps and asked to record their daily progress of exercise amount in a journal.
King, 2002^405^; Fair | US | Physical activity counseling | Caregiver | Prescription to participate in moderate-intensity physical activity at least 4 d/wk, 30–40 min/d provided through weekly and then monthly telephone calls plus daily logs over 12 months. | 12 | AC: Nutrition education provided at same intensity as intervention (weekly and then monthly telephone calls) over 12 months.
Leach, 2015^*^,^406^; Good | AUS | Other | Caregiver | Transcendental Meditation® program delivered in-person through twelve 30–90 min sessions over 3 months. | 3 | None: Offered 4-week healthy lifestyle education program (4 weekly 90-min sessions) after study ended.
LoGiudice, 1999^407^; Fair | AUS | Assessment and Treatment Planning | Caregiver + Patient | Attended hospital memory clinic on 2 occasions for assessment and referral to appropriate services. | NR | UC: Patients received same medical and cognitive assessments and caregivers received same interview as intervention group and all questions were answered and referrals back to primary care physician were encouraged.
Nourhashemi, 2010^408^; Fair | FRA | Multidisciplinary assessment and treatment plan | Caregiver + Patient | Multidisciplinary assessment and tailored care plan once every 6 months over 24 months. | 24 | UC: Standard medical care provided at community health centers.
Pillemer, 2002^409^; Fair | US | Social support | Caregiver | "Peer Support Project" providing one-on-one peer support through up to 8 weekly 120-min visits over 2 months. | 2 | None: No intervention.
Prick, 2015^*^,^410^; Fair | NLD | Multicomponent dyadic | Caregiver + Patient | Multicomponent dyadic intervention including exercise training, psychoeducation, communication skills training and pleasant skills training through eight 1-hr in-home sessions over 3 months. | 3 | BI: Monthly mailings with general information and 3 monthly 10-min telephone calls to provide emotional support.
Spijker, 2011^411^; Good | NLD | Provider training | Caregiver | "Systematic Care Program for Dementia" consisting of training professionals in the assessment of and strategies for reducing caregiver burden including screening, psychosocial support, and care coordination with medical, home, and respite care. | 12 | UC: Standard care provided by the Netherland’s community mental health services (not described).
Teri, 2003^412^; Good | US | Multicomponent dyadic | Caregiver + Patient | Multicomponent dyadic intervention including an exercise intervention for patients and caregiver psychoeducation through twelve 60-min in-home visits over the first 3 months and three 60-min followup sessions over the next 3 months. | 6 | UC: Monthly mailings with general information and 3 monthly 10-min telephone calls to provide emotional support.
Winter, 2006^413^; Fair | US | Social support | Caregiver | Telephone-based group social support through 26 weekly telephone calls over 6 months. | 6 | None: No intervention.

* New study

† Based on “Coping with Caregiving” Intervention tested in Gallagher-Thompson, 2003 and Gallagher-Thompson, 2008

Abbreviations: AC = attention control; AUS = Australia; AUT = Austria; BI = brief intervention; BL = baseline; BEL = Belgium; CAN = Canada; CHE = Chile; DEU = Germany; d = day; DNK = Denmark; ESP = Spain; FIN = Finland; FRA = France; GBR = Great Britain/United Kingdom; HKG = Hong Kong; hr = hour; IG = intervention groups; JPN = Japan; MI = minimal intervention; min = minute; NLD = Netherlands; NOR = Norway; NR = not reported; NYU = New York University; POL = Poland; TWN = Taiwan; UC = usual care; wk = week; WL = waitlist

Table 21 Caregiver and Caregiver-Patient Dyad Interventions: Summary of Results, by Intervention (KQs 4 and 5)

Author, year Quality | Intervention Type | N rand | FU (mo.)^†^ | Caregiver Burden | Caregiver Mental Health Symptoms | Caregiver QOL | Patient Institutionalization | Patient Mental Health and Behavioral Symptoms | Other Patient Outcomes
Psychoeducation Interventions
Barnes, 2018^*^,^327^; Fair | Individual psychoeducation | 55 | 3 | NR | ↔ (A, D) | ↔ | NR | NR | NR
Belle, 2006^328^; Fair | Individual psychoeducation | 642 | 6 | NR | ↑ (D) | NR | ↔ | NR | NR
Berwig, 2017^*^,^329^; Fair | Individual psychoeducation | 92 | 9 | ↑ | ↔ (A, D) | ↔ | NR | ↑ (NPS) | NR
Brennan, 1995^330^; Fair | Telehealth psychoeducation | 102 | 12 | ↔ | ↔ (D) | NR | NR | NR | NR
Bruvik, 2013^*^,^331^; Good | Individual psychoeducation | 230 | 12 | NR | ↔ (D) | NR | NR | ↔ (D) | NR
Burgio, 2003^332^; Fair | Individual psychoeducation | 140 | 6 | Black: ↔; White: ↔ | Black: ↔ (A, D); White: ↔ (A, D) | NR | NR | Black: ↔ (NPS); White: ↔ (NPS) | NR
Chang, 1999^333^; Fair | Telehealth psychoeducation | 87 | 3 | NR | ↔ (A, D) | NR | NR | NR | ↔ (ADL)
Chu, 2011^334^; Fair | Group-based psychoeducation | 85 | 4 | ↔ | ↑ (D) | NR | NR | NR | NR
Coon, 2003^335^; Fair | Group-based psychoeducation | 169 | 6 | NR | IG1: ↔ (D); IG2: ↔ (D) | NR | NR | NR | NR
Cristancho-Lacroix, 2015^*^,^336^; Fair | Telehealth psychoeducation | 49 | 6 | ↔ | ↔ (D, PS) | NR | NR | ↔ (NPS) | NR
De Rotrou, 2011^337^; Fair | Group-based psychoeducation | 157 | 6 | ↔ | ↔ (D) | NR | NR | ↔ (NPS) | ↔ (GCF), ↔ (ADL/IADL)
Ducharme, 2011^338^; Fair | Individual psychoeducation | 121 | 8 | ↔ | NR | NR | NR | NR | NR
Duggleby, 2018^*^,^339^; Fair | Individual psychoeducation | 199 | 6 | NR | NR | ↔ | NR | NR | NR
Finkel, 2007^340^; Fair | Telehealth psychoeducation | 46 | 6 | ↔ | ↔ (D) | NR | NR | NR | NR
Fung, 2002^*^,^341^; Fair | Group-based psychoeducation | 60 | 4 | ↑ | NR | ↑ | ↔ | NR | NR
Gallagher-Thompson, 2003^342^; Fair | Group-based psychoeducation | 257 | 6 | Hisp: ↔; White: ↔ | Hisp: ↔ (D); White: ↔ (D) | NR | NR | NR | NR
Gallagher-Thompson, 2008^343^; Fair | Group-based psychoeducation | 184 | 6 | Hisp: ↔; White: ↔ | Hisp: ↔ (D, PS); White: ↔ (D, PS) | NR | NR | NR | NR
Gallagher-Thompson, 2010^*^,^344^; Good | Telehealth psychoeducation | 76 | 4 | ↑ | ↔ (D) | NR | NR | ↔ (NPS) | NR
Garand, 2014^*^,^345^; Fair | Individual psychoeducation | 73 | 12 | NR | MCI pt: ↑ (A, D); Dem pt: ↑ (A, D) | NR | NR | NR | NR
Gaugler, 2013^*^,^346^; Fair | Family-based psychoeducation | 107 | 18/36 | ↑ | ↑ (D) | ↔ | ↑ | ↔ (NPS) | NR
Gitlin, 2001^347^; Fair | Individual psychoeducation | 202 | 3 | ↔ | NR | NR | NR | ↔ (NPS) | ↔ (ADL, IADL)
Gitlin, 2003^349^; Fair | Individual psychoeducation | 255 | 6 | ↔ | ↔ (D) | NR | NR | ↔ (NPS) | ↔ (ADL, IADL)
Gitlin, 2008^348^; Fair | Individual psychoeducation | 60 | 4 | ↔ | ↔ (D) | NR | NR | ↔ (D, NPS) | ↔ (Pt QOL)
Gitlin, 2010^350^; Fair | Individual psychoeducation | 272 | 4 | NR | NR | NR | NR | NR | ↑ (ADL/IADL), ↔ (ADL), ↑ (IADL)
Gitlin, 2010^462^; Fair | Individual psychoeducation | 237 | 6 | ↑ | ↑ (D) | NR | NR | NR | NR
Graff, 2006^351^; Fair | Individual psychoeducation | 135 | 3 | NR | ↑ (D, PM) | ↑ | NR | ↑ (D) | ↑ (ADL/IADL)
Hebert, 2003^352^; Fair | Group-based psychoeducation | 144 | 4 | ↔ | ↔ (A) | NR | NR | ↔ (NPS) | NR
Hepburn, 2005^353^; Fair | Group-based psychoeducation | 215 | 12 | ↔ | NR | NR | NR | NR | NR
Joling, 2012^354^; Fair | Family-based psychoeducation | 192 | 17 | NR | ↔ (A, D) | NR | NR | NR | NR
Judge, 2013^*^,^355^; Fair | Individual psychoeducation | 128 | 3 | NR | ↑ (D) | ↔ | NR | NR | NR
Koivisto, 2016^*^,^356^; Fair | Group-based psychoeducation | 236 | 36 | NR | NR | NR | ↔ | NR | NR
Kurz, 2010^357^; Fair | Group-based psychoeducation | 292 | 15 | NR | ↔ (D) | ↔ | ↔ | NR | NR
Kwok, 2013^*^,^358^; Fair | Telehealth psychoeducation | 42 | 3 | ↑ | NR | NR | NR | NR | NR
Laakkonen, 2016^*^,^359^; Fair | Group-based psychoeducation | 136 | 9 | NR | NR | ↔ | NR | NR | NR
Livingston, 2013^*^,^360^; Good | Individual psychoeducation | 260 | 24 | NR | ↔ (A, D, PM) | NR | NR | NR | ↔ (Pt QOL)
Losada, 2010^361^; Fair | Group-based psychoeducation | 167 | 3 | NR | ↑ (D) | NR | NR | NR | NR
Mariott, 2000^362^; Fair | Individual psychoeducation | 28 | 12 | NR | ↑ (D, PM) | NR | NR | ↔ (D) | ↔ (GCF), ↑ (ADL/IADL)
Martin-Carrasco, 2009^364^; Fair | Individual psychoeducation | 115 | 10 | ↑ | ↑ (PM) | ↑^‡^ | NR | NR | NR
Martin-Carrasco, 2014^*^,^363^; Fair | Group-based psychoeducation | 238 | 4 | ↔ | ↔ (PM) | ↔ | NR | NR | NR
Martin-Cook, 2005^365^; Fair | Individual psychoeducation | 49 | 4 | ↔ | ↔ (D) | NR | NR | NR
Martindale-Adams, 2013^*^,^366^; Fair | Telehealth psychoeducation | 154 | 12 | ↔ | ↔ (D) | NR | NR | NR | NR
Mittelman, 2004^*^,^367^; Fair | Family-based psychoeducation | 406 | 48/60 | ↑ | ↑ (D) | NR | ↑ | ↔ (NPS) | NR
Nunez-Naveira, 2016^*^,^368^; Fair | Telehealth psychoeducation | 77 | 3 | NR | ↔ (D) | NR | NR | NR | NR
Ostwald, 1999^369^; Fair | Group-based psychoeducation | 117 | 5 | ↔ | ↑ (D) | NR | NR | ↔ (NPS) | ↔ (GCF)
Roberts, 1999^370^; Fair | Individual psychoeducation | 77 | 12 | ↔ | NR | NR | NR | NR | NR
Schoenmakers, 2010^371^; Fair | Individual psychoeducation | 62 | 12 | NR | ↑ (D) | NR | NR | NR | NR
Steffen, 2016^*^,^373^; Good | Telehealth psychoeducation | 74 | 9 | ↑ | ↑ (A, D) | NR | NR | NR | NR
Spaulding-Wilson, 2018^*^,^372^; Fair | Group-based psychoeducation | 104 | 6 | ↔ | ↑ (PS), ↔ (A, D) | NR | NR | NR | NR
Teri, 2005^374^; Fair | Individual psychoeducation | 95 | 6 | ↑ | ↑ (D) | NR | NR | ↔ (NPS) | ↔ (Pt QOL)
Tremont, 2015^*^,^375^; Fair | Telehealth psychoeducation | 250 | 6 | ↑ | ↑ (D) | ↔ | ↔ | NR | NR
Ulstein, 2007^376^; Fair | Group-based psychoeducation | 180 | 12 | NR | ↔ (PS) | NR | ↔ | ↔ (NPS) | NR
Voigt-Radloff, 2011^377^; Fair | Individual psychoeducation | 141 | 6, 12 | NR | ↔ (D) | ↔ | ↔ | ↔ (D) | ↔ (ADL/IADL), ↔ (Pt QOL)
Waldorff, 2012^378^; Good | Group-based psychoeducation | 330 | 36 | NR | ↔ (D) | ↔ | ↔ | ↔ (D, NPS) | ↔ (GCF), ↑ (ADL/IADL), ↔ (Pt QOL)
Wang, 2011^*^,^379^; Fair | Group-based psychoeducation | 80 | 6 | ↑ | NR | ↑ | NR | NR | ↔ (GCF)
Williams, 2010^380^; Fair | Telehealth psychoeducation | 116 | 6 | NR | ↔ (A, D, PS) | NR | NR | NR | NR
Wilz, 2016^*^,^381^; Fair | Telehealth psychoeducation | 176 | 6 | NR | ↔ (D) | NR | NR | NR | NR
Wilz, 2018^*^,^382^; Good | Telehealth psychoeducation | 273 | 12 | NR | ↔ (D) | ↔ | NR | NR | NR
Wright, 2001^383^; Fair | Individual psychoeducation | 93 | 12 | ↔ | ↔ (D) | NR | ↔ | NR | NR
Care/Case Management Interventions
Bass, 2003^384^; Fair | Care/Case Management | 182 | 12 | NR | ↑ (D) | NR | NR | NR | NR
Callahan, 2006^385^; Fair | Care/Case Management | 153 | 17 | ↔ | ↑ (D) | NR | ↔ | ↔ (D), ↑ (NPS) | ↔ (GCF), ↔ (ADL/IADL)
Chien, 2008^*^,^387^; Fair | Care/Case Management | 88 | 12 | ↑ | NR | ↑ | ↑ | ↑ (NPS) | ↔ (GCF)
Chien, 2011^*^,^386^; Good | Care/Case Management | 92 | 18 | ↑ | NR | ↑ | ↑ | ↑ (NPS) | ↔ (GCF)
Chu, 2000^388^; Fair | Care/Case Management | 75 | 17 | ↔ | NR | NR | ↔ | NR | NR
Eloniemi-Sulkava, 2009^390^; Good | Care/Case Management | 125 | 24 | NR | NR | NR | ↔^§^ | NR | NR
Eloniemi-Sulvaka, 2001^389^; Fair | Care/Case Management | 100 | 12 | NR | NR | NR | ↔ | NR | NR
Fortinsky, 2009^391^; Fair | Care/Case Management | 84 | 12 | ↔ | ↔ (D) | NR | ↔ | NR | NR
Jansen, 2011^392^; Fair | Care/Case Management | 99 | 12 | ↔ | ↔ (D) | ↔ | NR | NR | ↔ (Pt QOL)
Lam, 2010^393^; Fair | Care/Case Management | 102 | 12 | ↑ | ↔ (PM) | ↔ | NR | ↔ (D, NPS) | ↔ (GCF), ↔ (Pt QOL)
Mavandadi, 2017^*^,^394^; Fair | Care/Case Management | 75 | 6 | ↑ | NR | NR | NR | ↔ (NPS) | NR
Meewsen, 2012^395^; Good | Care/Case Management | 175 | 12 | NR | ↑ (A, D) | ↔ | NR | ↔ (D) | ↔ (GCF), ↔ (ADL/IADL)
Menn, 2012^396^; Fair | Care/Case Management | 390 | 24 | ↔ | NR | NR | IG1: ↔; IG2: ↔ | NR | IG1: ↔ (GCF), ↔ (ADL), ↔ (IADL), ↔ (Pt QOL); IG2: ↔ (GCF), ↔ (ADL), ↔ (IADL), ↔ (Pt QOL)
Samus, 2014^*^,^397^; Fair | Care/Case Management | 303 | 12, 18 | ↔ | ↔ (D) | ↔ | ↑ | ↔ (D, NPS) | ↑ (Pt QOL)
Thyrian, 2017^*^,^398^; Fair | Care/Case Management | 516 | 12 | ↑ | NR | NR | ↔ | ↑ (D) | ↔ (GCF), ↔ (ADL/IADL), ↔ (Pt QOL)
Vickrey, 2006^399^; Good | Care/Case Management | 408 | 17 | NR | NR | ↔ | NR | NR | ↑ (Pt QOL)
Xiao, 2016^*^,^400^; Fair | Care/Case Management | 72 | 12 | ↑ | NR | ↑ | NR | ↔ (NPS) | NR
Other Interventions
Charlesworth, 2008^401^; Fair | Social support | 236 | 22 | NR | ↔ (A, D) | ↔ | ↔ | NR | NR
Connell, 2009^402^; Fair | Physical activity counseling | 157 | 12 | ↔ | ↔ (D, PS) | NR | NR | NR | NR
Gitlin, 2018^*^,^403^; Fair | Multidisciplinary assessment | 160 | 8 | ↔ | ↔ (D) | NR | NR | ↔ (NPS) | ↔ (AE), ↔ (PF), ↔ (Pt QOL)
Hirano, 2011^404^; Fair | Physical activity counseling | 36 | 3 | ↑ | NR | NR | NR | ↔ (NPS) | NR
King, 2002^405^; Fair | Physical activity counseling | 100 | 12 | ↔ | ↔ (A, D, PS) | NR | NR | ↔ (NPS) | NR
Leach, 2015^*^,^406^; Good | Other | 17 | 6 | NR | NR | ↔ | NR | NR | NR
Logiudice, 1999^407^; Fair | Assessment and treatment planning | 50 | 12 | ↔ | ↔ (PM) | NR | ↔ | NR | NR
Nourhashemi, 2010^408^; Fair | Multidisciplinary assessment and treatment plan | 1131 | 22 | NR | NR | NR | ↔ | NR | ↔ (ADL/IADL)
Pillemer, 2002^409^; Fair | Social support | 147 | 6 | NR | NR | NR | NR | NR | NR
Prick, 2015^*^,^410^; Fair | Multicomponent dyadic | 111 | 6 | ↔ | ↔ (D) | NR | ↔ | ↔ (D), ↑ (NPS) | ↔ (Pt QOL)
Spijker, 2011^411^; Good | Provider training | 301 | 12 | NR | NR | NR | ↔ | NR | NR
Teri, 2003^412^; Good | Multicomponent dyadic | 153 | 6, 17, 24 | NR | ↔ (D) | NR | ↔ | ↔ (D) | ↑ (Pt QOL)
Winter, 2006^413^; Fair | Social support | 103 | 6 | ↔ | ↔ (D) | NR | NR | NR | NR

NOTE: Arrows represent study-reported results.

Symbol Legend:

↑ = Statistically significant between-group difference in favor of intervention group

↔ = No statistically significant difference between groups or no clear between-group difference (not reported).

↓= Statistically significant between-group difference in favor of control group

* New study

† Longest followup. Some studies have more than one FU listed because longest followup differed by outcome

‡ Statistically significantly favored IG on 7 of 8 subscales of the SF-36

§ Results statistically significant for at least one timepoint

Abbreviations: A = anxiety; ADL = Activities of Daily Living; D = depression; DEM = dementia; FU = followup; GCF = global cognitive function; Hisp = Hispanic; IADL = IADL = Instrumental Activities of Daily Living; IG = intervention group; MCI = mild cognitive impairment; mo. = months; NPS = Composite neuropsychiatric symptoms; NR = not reported; N rand = number of participants randomized; PM = psychological morbidity; PS = perceived stress; Pt = patient; QOL = quality of life;

###### Psychoeducation Caregiver Interventions

Study and population characteristics. We included 58 trials, representing more than 9,139 caregivers or caregiver-patient dyads, that evaluated a caregiver psychoeducational intervention. Twenty-four of these trials are new to this update. We rated most of the studies fair quality given unclear allocation procedures, few baseline imbalances, and relatively high attrition (20% to 40%). Study sample sizes ranged from 28 to 642 participants, with most studies randomizing more than 100 caregivers or caregiver-patient dyads. Most followed participants for at least 1 year, with three studies including longer-term followup at 3 or 4 years^346,^ ^356,^ ^378^ and one including followup at 12 years.^367^

Almost three-quarters (74% [43/58]) of the trials targeted the caregiver only, with the remaining targeting the caregiver-patient dyad (21% [12/58]) or entire family (5% [3/58]). Most trials required that caregivers provide support to the patient for at least 4 hours a day to be eligible for the study and many limited inclusion to caregivers reporting burden related to caregiving (e.g., Zarit burden score >22) or high psychological distress (e.g., >4 on General Health Questionnaire). Two trials prespecified inclusion to spousal caregivers,^359,^ ^367^ and one trial focused specifically on adult caregiving children of dementia patients.^346^ When reported, the remaining trials included various proportions of spousal, child, and other nonprofessional caregivers. Caregivers were mostly female in all trials (range of female caregivers, 57% to 100%). The mean age of caregivers ranged from 41 to 75 years. Socioeconomic indicators such as education, income, and employment status were reported inconsistently and variably measured. Among those that reported educational level of caregivers, in most studies more than half of caregivers had at least a high school education with mean years of education ranging from 11 to 16 years. Race/ethnicity of caregivers was sparsely reported. Among the few trials that did report the race of participants, most caregivers and patients were white except for three trials^341,^ ^344,^ ^379^ that were limited to Asian caregivers (2 trials in Hong Kong and 1 in the United States). Across all psychoeducation intervention trials, most took place in the United States (k=28) or Western Europe (k=22). Four trials took place in East Asia (Hong Kong or Taiwan) and four took place in Canada.

In all but three trials, caregivers cared for patients with dementia, mostly characterized as Alzheimer’s-type dementia. Two trials included caregivers of patients with either MCI or dementia,^345,^ ^355^ and one remaining trial^371^ targeted caregivers of “frail community-dwelling older adults characterized as cognitively impaired” with an MMSE less than 23. The average MMSE scores across trials was consistent with patients having moderate, as opposed to mild, dementia (average MMSE score was 16.2 across studies that reported it). The mean age of patients ranged from 68 to 83 years.

Intervention characteristics. The psychoeducation intervention trials encompassed a wide range of approaches. The most common format was for interventionists to meet individually with caregivers, dyads, or families, most commonly in participants’ homes (k=20). A number of the interventions, however, took place in group settings (k=18) or were provided remotely through telephone counseling, computer-based programs or applications, videos, or a combination of these methods (k=13). Across all psychoeducation interventions, in addition to providing information about dementia and community resources, most interventions also included training in problem solving, communication techniques, and stress management. A variety of additional components were used, including peer or social support (e.g., group support meetings or online forums to interact with peers, to express their concerns, discuss solutions to daily problems, and share their feelings and experiences), supportive counseling (counseling focused on the caregiver’s emotional or psychological issues), home safety assessments or information, occupational therapy, and environmental modifications. The interventionists were also highly variable, reflecting the specific components within each intervention and included general educators or counselors, psychologists, nurses, occupational therapists, social workers, and hired and trained research staff. Only two interventions included contact with a geriatrician.^337,^ ^376^ The majority of interventions were relatively short (median, 4 months) but ranged from 1 month to 2 years, and participants generally meet every 1 to 3 weeks over the course of the interventions.

Most trials included a usual care control group (k=22) or attention controls where caregivers received similar or slightly less contact with an interventionist who provided general dementia education with or without nondirective social support (k=21). The remaining trials included no intervention or waitlist control groups. Usual care was rarely fully described. When it was, most mentioned usual memory or primary care for patients with referrals to outside organization or community resources for caregiver support.

Results. Although there were substantial clinical differences among the interventions evaluated, overall there was a consistent finding of a benefit on caregiver burden and depression outcomes in persons caring for patients with mostly moderate dementia. Effect sizes were mostly small, however, and few of the individual trials reported statistically significant differences between groups.

Caregiver burden. The standardized pooled effect for trials reporting sufficient data to be included in the meta-analysis (k=27; n=2,776) showed a small but statistically significant effect (SMD, −0.24 [95% CI, −0.36 to −0.13]; I^2^=50.2%) (Figure 17). We could not include nine of the trials that reported burden in the meta-analysis because of missing data (e.g., variance) or reporting of an incompatible outcome.^330,^ ^334,^ ^340,^ ^346,^ ^365–367,^ ^372,^ ^383^ In these studies, the effect sizes were similarly small, with few finding statistically significant group differences.^346,^ ^367^

Figure 17 Pooled Analysis of Change in Caregiver Burden (Standardized Mean Difference) (KQ 4), Caregiver and Caregiver-Patient Dyad Interventions Compared With Controls, by Intervention Type

* For all analyses, we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available.

† Pooled mean difference, −0.54 (95% CI: −0.96 to −0.12); k=8; n=1215; I^2^=82.9%, based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, −0.45 (95% CI: −2.26 to 1.36); k=5; n=459; I^2^=89.6%, based on restricted maximum likelihood method with Knapp-Hartung modification

Abbreviations: AC = attention control; BI = brief intervention; BIZA-D = Berlin Inventory of Caregivers’ Burden with Dementia; BG = between-group; BL = baseline; CG = control group; CI = confidence interval; Dem = dementia; FCBI = Family Caregiving Burden Inventory; IG = intervention group; KQ = key question; MCI = mild cognitive impairment; MBPC = Memory and Behavior Checklist; Mgmt = management; MI = minimal intervention; MMSE = mini-mental state examination; n = sample size; NPI-10 = Neuropsychiatric Inventory-10 item; NPI-12 = Neuropsychiatric Inventory-12 item; NR = not reported; Psychosocial Adj Illness = Psychosocial Adjustment to Illness scale; RMBPC = Revised Memory and Behavior Checklist; SMD = standardized mean difference; UC = usual care; WL = waitlist; Zarit-10 = Zarit Burden Interview-10 item; Zarit-22 = Zarit Burden Interview-22 item

This figure is a forest plot of the change in caregiver burden, comparing caregiver and caregiver-patient dyad interventions with controls. The forest plot is organized by intervention type.

The clinical importance of these changes in self-reported caregiver burden scores is unclear. Most studies reported group differences between 0.5 and 5 points on a scale of 0 to 88 on the Zarit-22. Baseline Zarit-22 scores ranged widely across studies from an average of around 23 to 56 points, and only one study reported average changes of greater than 2.5 points over 6 months followup in the intervention group. To aid in interpretation, we pooled the nine trials that reported change in the Zarit-22 and found an average 2.5-point difference favoring the intervention group vs. control group (MD, −2.47 [95% CI, −3.91 to −1.03]; k=9; n=1,089; I^2^=0%) (forest plot not shown). This is equivalent to a change from being bothered “always” to “sometimes” or “almost never” on one of the 22 items. Across all measure of burden, the confidence intervals of the study-level between-group differences were frequently quite wide, suggesting the possibility that some caregivers showed substantial improvement or benefit in their perceived burden and others did not benefit. Unfortunately, we could not identify what subgroups of caregivers may have benefited based on study-level data.

Caregiver mental health. Forty-three of the 58 psychoeducation trials reported a measure of caregiver depressive symptoms, using a variety of self-report instruments. Like findings for caregiver burden, the effect sizes for depression outcomes across all trials were relatively small and imprecise. Our meta-analysis included the pooled effect for 37 comparisons (n=4,555) and found a small but statistically significant effect favoring the intervention on depression measures at 3 to 12 months followup (SMD, −0.26 [95% CI, −0.39 to −0.13]; I^2^=76.9%) (Figure 18). In most cases, caregivers in the intervention groups reported experiencing fewer depressive symptoms over time, whereas caregivers in the control groups reported slightly more symptoms or little change over time. The CES-D, a 20-item instrument (scale of 0–60, with lower scores equaling fewer depressive symptoms), was the most commonly used instrument. Pooling the 20 trials that reported CES-D-measured depressive symptoms resulted in a between-group mean difference of 2.67 points favoring the intervention group (MD, −2.67 [95% CI, −3.85 to −1.48]; k=20; n=2,603; I^2^=65.1%), with most trials reporting an approximate 1- to 5-point difference (forest plot not shown). Similar to changes in caregiver burden, the clinical importance of these small changes in depression scores is unclear. A 3-point difference could mean that a person moved from endorsing a single symptom 5 to 7 days to rarely or never in the previous week, or from 3 to 4 days to 1 to 2 days for three symptoms in the previous week.

Figure 18 Pooled Analysis of Change in Caregiver Depression (Standardized Mean Difference) (KQ 4), Caregiver and Caregiver-Patient Dyad Interventions Compared With Controls, by Intervention Type

* For all analyses, we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available.

† Pooled mean difference, −0.13 (95% CI: −0.39 to 0.12); k=4; n=668; I^2^=0.0%, based on restricted maximum likelihood method with Knapp-Hartung modification

‡ Pooled mean difference, −0.0 (95% CI: −0.34 to 0.34); k=5; n=645; I^2^=53.7%, based on restricted maximum likelihood method with Knapp-Hartung modification

Abbreviations: AC = attention control; AD = Alzheimer’s disease; BDI = Beck Depression Inventory; BDI-II = Beck Depression Inventory – Second Edition; BI = brief intervention; BG = between-group; BL = baseline; CES-D = Center for Epidemiologic Studies – Depression; CES-D-10 = 10-item Center for Epidemiologic Studies – Depression; CG = control group; CI = confidence interval; Dem = dementia; DS, BSI = Brief Symptom Inventory – Depression subscale; GDS = Geriatric Depression Scale; GDS-15 = Geriatric Depression Scale-15 item; HADS-D = Hospital Anxiety and Depression Scale; IG = intervention group; KQ = key question; MAACL = Multiple Affect Adjective Checklist; MADRS = Montgomery Asberg Depression Rating Scale; MCI = mild cognitive impairment; Mgmt = management; MCI = mild cognitive impairment; MI = minimal intervention; MMSE = mini-mental state examination; n = sample size; NR = not reported; PHQ-9 = Patient Health Questionnaire-9; SMD = standardized mean difference; UC = usual care; WL = waitlist

This figure is a forest plot of the change in caregiver depression, comparing caregiver and caregiver-patient dyad interventions with controls. The forest plot is organized by intervention type.

We could not include 12 trials that reported a measure of depressive symptoms in the meta-analysis due to missing data.^327,^ ^328,^ ^335,^ ^340,^ ^346,^ ^350,^ ^362,^ ^371,^ ^372,^ ^383,^ ^388,^ ^414^ In five of these trials, study authors reported statistically significant benefit of the interventions on depressive symptoms.^328,^ ^350,^ ^362,^ ^388,^ ^414^ Five trials did not report depressive symptoms but reported measures of other mental health symptoms such as anxiety, perceived stress, and psychological morbidity.^333,^ ^352,^ ^363,^ ^364,^ ^376^ These trials, as well as others that reported such measures, found similar patterns of effects with intervention participants reporting slight improvements in mental health symptoms while control group participants reported similar scores over time. Few trials, however, reported statistically significant differences between groups over time.

For both caregiver burden and caregiver depressive symptoms, we visually explored the summary tables and forest plots and ran exploratory meta-regressions to determine if any design, population, or intervention feature explained the variability in effect sizes. These variables included study quality (good vs. fair), new vs. previously included trials, U.S.- vs non-U.S.–based trials, mean baseline MMSE of patients being cared for, type of control group (minimal or brief intervention vs. usual care, waitlist, or no intervention), target audience (caregiver and patient or whole family vs. caregiver only), intervention duration, setting of intervention (home vs. not in home), primary intervention format (individual- vs. group- or family-based, or telehealth interventions), and key intervention strategies (training and support vs. training only). For caregiver depression, there was evidence of a difference in effect based on the type of control group. A statistically significant favorable effect was found when comparing psychoeducation interventions with no treatment or usual care control groups (SMD, −0.44 [95% CI, −0.65 to −0.24]; k=20; n=2,347; I^2^=81.3%), whereas no effect was found when comparing psychoeducation interventions vs. attention controls consisting of brief or minimal interventions (SMD, −0.09 [95% CI, −0.25 to 0.06); k=15; n=1,873; I^2^=60.6%) (p-value for difference=0.036). This same effect was not seen for the outcome of caregiver burden (p=0.815). None of the other variables robustly predicted larger effect sizes for measures of caregiver burden or caregiver depression.

Caregiver QOL. Only 16 of the 58 trials reported effects of the interventions on caregivers’ assessments of their QOL. Patterns of change over time were inconsistent between trials, with some trials showing improved mean scores in both intervention and control participants, some showing decreased scores in both groups, and some reporting improvement in intervention participants with declines in control group participants. Seven of the 16 trials reported some statistically significant differences in favor of the intervention groups, but almost all only reported this for one of many measures of QOL within the study or only at shorter vs. longer followup.^341,^ ^351,^ ^357,^ ^359,^ ^364,^ ^378,^ ^379^

Decision making. One fair-quality trial (n=111) reported the effects of a psychoeducational intervention on caregivers’ reports of planning or decision making related to caring for their relative with dementia.^338^ The aim of this study was to test the efficacy of the “Learning to Become a Family Caregiver” program intended for caregivers following the diagnostic disclosure of AD in a relative. The intervention, delivered through seven 90-minute individual sessions over 2 months, was designed to foster a successful transition to the caregiving role by acquiring certain skills to manage stress, plan, and care for a relative. Caregivers randomized to the control arm received usual care provided by local memory care clinics, which consisted of putting caregivers in contact with a range of local available services. The relatives with dementia did not take part in the intervention; patients in both groups continued to attend the memory clinics as needed. Three months following the intervention (5 months postbaseline assessment), caregivers in both groups reported statistically significantly better planning for the future care needs of the relative with no difference between groups. Using a six-item Likert-type scale with a range of 6 to 30, where higher scores equaled greater planning, scores among intervention participants increased from a mean of 15 (SD, 5.84) to 19.67 (SD, 5.78). whereas scores for control participants increased from a mean of 15.04 (SD, 6.90) to 18.36 (SD, 6.84) and no group-by-time effect was found.^338^

Patient institutionalization. In terms of patient outcomes, 10 of the 54 trials reported rates of institutionalization or time to nursing home placement as primary or secondary outcomes.^328,^ ^346,^ ^356,^ ^357,^ ^367,^ ^375–378,^ ^383^ Half of these trials took place in the United States, and most provided followup for 1 year or longer (including 4 trials with 3 or more years followup). Only two trials, both evaluating a version of the New York University Caregiver Intervention (NYUCI), reported statistically significantly favorable effects of the interventions on delaying patient institutionalization.^346,^ ^367^ In the first trial among spousal caregivers, after 9.5 years of followup, patients whose spouses received the intervention experienced a 28.3 percent reduction in the rate of nursing home placement vs. usual care controls (HR, 0.717 [95% CI, 0.537 to 0.958], p=0.0247).^342^ In the second trial, adapted for adult child caregivers in Minnesota (NYUCI-AC), after 2 years, two-thirds (66%) of adult child caregivers in the control condition admitted their parent to a residential care setting (assisted living, family care home, or nursing home) compared with 37 percent in the treatment condition. Logistic regression and Cox proportional hazards models found that NYUCI-AC participants were significantly less likely (p<0.05) to admit their parents to a residential care setting and delayed their parents’ time to admission significantly longer (228.36 days longer on average) than those in the control group.^346^ In both trials, favorable benefits were also seen for outcomes of caregiver stress, burden, depression, and QOL measures. Other trials reported data on numbers of participants being institutionalized when describing participant attrition; those data are not presented here.

Other patient outcomes. Additional patient outcomes were inconsistently reported across the trials and included changes in patients’ global and cognitive function, ADLs and IADLs, mental and behavioral health symptoms, and QOL. Few trials reported statistically significant favorable effects on such outcomes.

Harms. Only three trials (n=326) monitored adverse events during the trial period. Neither found any harms of the intervention.^351,^ ^359^

###### Care/Case Management

Study and population characteristics. We categorized 18 interventions in 17 trials as care or case management interventions (n=3,039). We broadly labeled these interventions as care or case management if the intervention included professional assistance to help arrange, implement, or facilitate services to meet a patient’s and family’s needs. In all cases, care management was intended for both the caregiver and the patient with dementia (or the patient’s entire family). One trial^400^ extended existing care coordination for patients by also providing care coordination support for caregivers through a personalized caregiver support plan. Six of these 17 trials were new to this update, two of which took place in the United States.^394,^ ^397^

Four were cluster RCTs, randomizing at the level of the primary care clinician^385,^ ^398^ or practice.^396,^ ^399^ Six trials took place in the United States, six in Europe (Finland, Germany, or Netherlands), one in Australia, three in Hong Kong, and one in Canada. Most recruited participants from primary care,^385,^ ^391,^ ^392,^ ^394,^ ^396,^ ^398,^ ^399^ with the remaining recruiting from memory clinics or other outpatient clinics,^388,^ ^393,^ ^395^ health plan membership,^384^ local Alzheimer’s organization,^386^ or other social services or self-referred methods.^387,^ ^389,^ ^390,^ ^397,^ ^400^ Sample sizes ranged from 72 to 516 caregiver-patient dyads. Collectively, trials within this category of intervention provided the longest followup, with all but one^394^ following participants for a year or longer. Eight of the 18 trials provided results at 1.5 or 2 years followup.

All care management interventions were intended for patients with dementia. Two trials also included a small proportion of participants with MCI,^395,^ ^397^ and one trial enrolled health plan members whose medical records indicated they had a dementia diagnosis or a symptom code indicating memory loss.^384^ Baseline mean MMSE scores of patients ranged from mild dementia (22.8) to moderate dementia (13.8). Few (7 trials) reported the proportion of patients being treated for dementia with medication; in those that did, 27 to 78 percent of patients were taking an AChEI. One trial required patients to be on a stable dose of an AChEI to be eligible for the study.^394^

Two trials included only or mainly spousal caregivers;^390,^ ^394^ the others included a fairly even distribution of spouse, child, and other relational caregivers. The mean age of caregivers ranged from 44 to 75 years while the mean age of patients ranged from 68 to 84 years. Most caregivers in each trial were female. The gender distribution of patients within trials was more evenly distributed and ranged from 38 to 68 percent female, where reported. Extremely limited data about the race/ethnicity, education, or other socioeconomic variables were provided for patients or caregivers.

Intervention characteristics. While each intervention was unique, the interventions we categorized as care or case management generally all provided assessment, advice and information, individualized treatment planning, caregiver psychoeducation and skills training, ongoing monitoring, and either referral or care coordination with outside social and health care services (such as occupational and physical therapy, respite care, personal care assistance, social, and social work). Two interventions in the United States were partnerships between an Alzheimer’s Association chapter and a managed care plan^384^ or primary care physicians^391^ to provide care consultation and individualized treatment plans to families. One trial in the Netherlands compared the effectiveness of care coordination and postdiagnosis treatment provided by a memory clinic with the same service provided only by a general practitioner.^395^ Finally, one trial in Germany provided training for primary care physicians on non-medication–based and medical treatment options for dementia and information and counseling for caregivers; in one intervention arm, the physician suggested that the caregiver attend support groups and receive counseling for up to 2 years, and in the other arm, the physician made the same suggestion but for up to 1 year.^396^ These interventions were longer than any other category of intervention in general, providing support and care management to caregivers and patients for a year or longer (range, 3 months to 2 years [median, 1 year]).

All but two interventions were primarily provided through individual in-person interaction with or without other delivery methods such as group sessions or support groups, telephone contact, or mailed print materials. In the remaining two interventions, information, counseling, and coordination were provided solely by telephone.^384,^ ^394^ The interventionists varied, but most often included a nurse or other health provider serving as a “case manager” or “care coordinator.” Other providers included primary care clinicians, geriatricians, occupational therapists, neurologists, psychiatrists, social workers, and other research staff. Many interventions took a team approach, with different providers providing different components of the intervention. Interaction mostly took place in participants’ homes but planning and counseling also took place in a medical setting (i.e., primary care clinic, dementia-specific clinic).

In all trials, the control group consisted of usual care provided by primary care or a memory-specific clinic or organization (k=12) or another minimal intervention (k=5). Usual care varied, based on the study’s setting, including country. In most cases, patients continued usual medical care with their primary provider and were given information on other local social and health services. The two trials that partnered with Alzheimer’s Association chapters acknowledged that the control group participants had access to their normal managed or primary care and were able to contact the association independently and use any of its services other than care consultation. The five trials that included minimal attention control groups provided enhanced support for caregivers (e.g., individual counseling sessions) in addition to usual care for patients.

Results. The primary outcome or outcomes of the 17 trials of care and case management interventions differed across trials and included time to institutionalization or nursing home admissions,^388–391,^ ^396,^ ^397^ caregiver outcomes such as burden, strain, caregiving competence, and QOL,^384,^ ^386–388,^ ^393–395,^ ^398–400^ mental and neuropsychiatric symptoms of the patient,^385,^ ^394,^ ^398^ and patient QOL.^395,^ ^399^

Patient institutionalization. Ten of the 17 trials reported rates of patient institutionalization or time to institutionalization. There was a pattern of benefit among patients in intervention vs. control groups, with fewer persons in the intervention groups placed in nursing homes than those in usual care or a delayed time to institutionalization among intervention vs. control participants. Those with dementia who were placed in nursing homes ranged from 5.5 to 32.1 percent among adults in the intervention groups and from 1.5 to 33 percent in the control groups at 1 to 2 years followup. Only three trials reported statistically significant differences related to institutionalization, but all three measures also included other health care utilization or survival measures such as death.^386,^ ^387,^ ^397^ In the two disease management trials in Hong Kong, both found significantly less frequent and shorter rates of placements and stays in residential homes or hospital units, including temporary hospitalizations, over the previous 6 months.^386,^ ^387^ In the 18-month MIND care coordination trial, intervention participants were less likely to permanently leave their home or die compared with controls (30.9% vs. 45.6%; p=0.012) and remained in their homes significantly longer (mean, 496 days vs. 445 days; p=0.02). The hazard of leaving the home was decreased by 37 percent after adjusting for whether the caregiver lived in the home (HR, 0.63 [95% CI, 0.42 to 0.94]; p=0.022).^397^

The MIND care coordination trial was the only trial to include a measure of unmet care needs related to dementia.^397^ Using the Johns Hopkins Dementia Care Needs Assessment, evaluators assessed 19 common care needs for participants (71 items) and caregivers (15 items) each as being “fully met” or “unmet.” A total percent of unmet needs was calculated ([# of unmet needs/# of needs assessed] *100) as well as the proportion of unmet items in six specific areas: evaluation and treatment of memory symptoms; neuropsychiatric symptom management; home and personal safety; general, specialist, and allied health care; daily and meaningful activities; and legal issues/advanced care planning. After 18 months, there was no statistically significant group difference in reduction of total percent of unmet needs; however, the intervention participants had a significantly greater reduction in the proportion of unmet needs in the two domains of safety and legal/advance care planning domains relative to control participants.^397^

Caregiver burden. A benefit of care and case management on caregiver burden relative to usual care or other minimal interventions was evident. The effects were relatively larger than those seen for other types of caregiver interventions. Of the 12 trials reporting a measure of caregiver burden, five found a statistically significant benefit of caregiver interventions after 6 to 18 months. The combined standardized effect was −0.54 (95% CI, −0.85 to −0.22; k=8; n=1,215; I^2^=82.9%) (Figure 17) among the eight trials that could be pooled, translating to a between-group difference of approximately 3.5 to 4 points on the Zarit-22. Statistical heterogeneity was substantial, consistent with the clinical heterogeneity among the trials and interventions themselves.

Caregiver mental health. Fewer trials (k=7) reported caregiver depression outcomes. While effects trended toward a benefit of care management interventions, the effects were small, and a meta-analysis of available data indicated no association (MD, −0.13 [95% CI, −0.29 to 0.02]; k=4; n=668; I^2^=0%) (Figure 18).

Caregiver QOL. Caregiver QOL was again variably measured, and while self-reported QOL tended to improve in intervention participants and decrease in control participants, few trials reported consistent favorable effects across measures or time.

Other patient outcomes. In terms of patient outcomes, there were mixed findings related to behavioral and neuropsychiatric symptoms, measures of depressive symptoms, and QOL, with some trials finding very small benefits of the intervention on such outcomes and others finding no effects. Besides the one trial that reported a measure of unmet care needs related to care coordination, no other trial reported on how care or case management interventions affected clinician, patient, or family decision making.

Harms. None of the trials of care or case management interventions reported on AEs related to the trial.

###### Other Caregiver and Caregiver-Patient Dyad Interventions

Study, population, and intervention characteristics. We included 13 additional trials (n=2,702) that evaluated a caregiver or caregiver-patient dyad intervention that were unique in their intervention and were categorized as “other” interventions. Only three of these trials were new to this update. Interventions were: physical activity counseling for the caregiver; a multicomponent dyadic intervention; social support only; assessment and treatment planning or multidisciplinary assessment only; or another intervention.

Three fair-quality trials (n=293) focused on increasing physical activity of caregivers with a primary aim of reducing caregiver burden and improving caregivers’ QOL.^402,^ ^404,^ ^405^ All recruited caregivers of persons with dementia. One trial in the United States limited inclusion to female caregivers^405^ and another, also in the United States, comprised only spousal caregivers (all of whom ended up being female).^402^ The remaining trial in Japan recruited caregivers living with the person with dementia.^404^ The majority of women in both U.S. trials were white (>85%); race/ethnicity of caregivers in the Japanese trial was not reported. All three interventions included very little in-person contact with caregivers; rather, counseling and physical activity prescriptions were provided entirely via video and telephone,^402^ telephone only,^405^ or a one-time prescription for caregivers to participate in moderate-intensity physical activity and pedometer and journal for recording activity.^404^ Two additional trials (1 good-quality trial and 1 new fair-quality trial) (n=264) evaluated multicomponent dyadic interventions that included exercise training, psychoeducation, and skills training to both patients and caregivers in their homes for 3 to 6 months.^410,^ ^412^ Each had slightly different aims. In the new trial in the Netherlands, both patients with mild dementia (MMSE, 21.0) and the caregivers with whom they lived simultaneously received exercise training, psychoeducation, communication skills training, and pleasant skills training in an attempt to improve patients’ mood, behavior, and physical function as well as caregivers’ mood and perceived burden.^410^ In the older, good-quality trial, patients with moderate dementia (MMSE, 16.7) received exercise training and their caregivers received psychoeducation with an aim of reducing functional dependence and delaying institutionalization of the patient with dementia.^412^

Three additional fair-quality trials (n=486) tested the effects of a caregiver social support intervention on caregivers’ QOL and well-being.^401,^ ^409,^ ^413^ Two trials took place in the United States, while the other took place in the United Kingdom. All caregivers were caring for persons with dementia, although the severity of dementia was not reported. Most caregivers were female in all three trials (range, 64% to100%). In two trials, peer volunteers were matched with caregivers and provided informational and emotional support through weekly home visits over the course of 2^409^ or 6 months.^401^ In the other, telephone-based support groups were offered to caregivers through 26 weekly calls over 6 months.^413^

Three fair-quality trials (n=1,341) focused on providing comprehensive medical and cognitive assessments, including an assessment of caregivers’ impressions and well-being, and providing a standardized treatment plan.^403,^ ^407,^ ^408^ One each took place in the United States, Australia, and France. In all cases, persons with moderate dementia (MMSE range, 16.6 to 19.7) and their caregivers took part in the intervention. The intensity of the interventions varied: in the U.S.-based trials, participants took part in eight sessions over 4 months, in the trial in Australia, patients and caregivers attended a hospital memory clinic on two occasions over the course of a year, whereas in the trial in France, dyads met with a multidisciplinary team twice a year for 2 years.

One additional good-quality trial in the Netherlands (n=301) tested the effects of a provider training program to train professionals in the assessment of and strategies for reducing caregiver burden.^411^ And, the final new, good-quality trial evaluated the effects of a Transcendental Meditation® program on the stress and QOL of 17 dementia caregivers in Australia.^406^

Results. None of these trials showed a consistent benefit on patient or caregiver outcomes compared with control conditions. The pooled effects of the few trials reporting caregiver burden (Figure 17) or caregiver depressive symptoms (Figure 18) found inconsistent and imprecise results. Only one trial (n=160) reported adverse events experienced by the caregivers, with none occurring in either group over the course of the 2-month intervention.^403^