# Chapter 2 Methods

## Review Scope

This review is an update of the 2013 review^105,^ ^106^ that supported the 2014 USPSTF recommendation. Our update includes studies published since the previous review and studies from the previous review that met updated inclusion criteria. We did not make any substantive changes to the scope of the review for this update other than to exclude the medication tacrine from the list of included interventions as it is no longer available in the United States.

## Analytic Framework and Key Questions

With input from the USPSTF, we developed an Analytic Framework (Figure 1) and five Key Questions (KQs) to guide the search and selection of studies, data abstraction, and data synthesis.

Figure 1 Analytic Framework

Abbreviation: MCI = mild cognitive impairment.

This figure is the analytic framework that depicts the five Key Questions to be addressed in the systematic review. The figure illustrates how screening for cognitive impairment in adults aged 65 years or older may result in improved intermediate outcomes (decision making) and health outcomes (patient, family/caregiver, and societal outcomes) (Key Question 1). There is also a question related to the accuracy of screening instruments used to detect cognitive impairment (Key Question 2) and potential harms of screening (Key Question 3). Additionally, the figure illustrates how pharmacologic and nonpharmacologic interventions for early dementia may have an impact on intermediate outcomes (decision making) and health outcomes (patient, family/caregiver, and societal outcomes) (Key Question 4) and whether these interventions result in any harms (Key Question 5).

### Screening KQs (KQs 1–3)

1 Does screening for cognitive impairment in community-dwelling older adults in primary care–relevant settings improve decision making, patient, family/caregiver, or societal outcomes?
2 What is the accuracy of screening instruments to detect cognitive impairment in community-dwelling older adults?
3 What are the harms of screening for cognitive impairment in community-dwelling older adults?

### Treatment/Management KQs (KQs 4, 5)

4 Do interventions for mild to moderate dementia or MCI in community-dwelling older adults improve decision making, patient, family/caregiver, or societal outcomes?
5 What are the harms of interventions for mild to moderate dementia or MCI in community-dwelling older adults?

## Data Sources and Searches

First, we reviewed all included studies in the previous review,^105,^ ^106^ including those that were part of a systematic review that was previously used in its entirety.^107^ Next, we searched the following databases to identify English-language literature published between January 2012 and January 2019: Ovid MEDLINE, PubMED (for publisher-supplied records only), PsycInfo, and the Cochrane Central Register of Controlled Trials. A research librarian developed and executed the search, which was peer reviewed by a second research librarian (Appendix A). We supplemented our searches by examining the reference lists of other previously published reviews, meta-analyses, and primary studies and from suggestions from experts. We also searched ClinicalTrials.gov for ongoing trials related to KQ 1 and have conducted ongoing surveillance for relevant literature for all bodies of evidence through September 21, 2019. We imported the literature from these sources directly into EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific criteria to guide our study selection (Appendix A Table 1).

### Population

For all KQs, we included studies that were relevant to community-dwelling, noninstitutionalized adults age 65 years and older being seen in primary care in the United States. For screening studies, we excluded studies conducted among patients in hospitals or nursing homes (i.e., skilled nursing facilities, rehabilitation facilities, and intermediate care facilities) or in which patients were selected from referred settings (e.g., memory, neurology, psychogeriatric, AD Research Centers). We included only treatment studies conducted among community-dwelling older adults with MCI or mild to moderate dementia. We excluded treatment studies that focused on patients with severe dementia, as most severe cases would likely be clinically identified rather than screen detected. We also excluded primary prevention trials in which treatment was aimed at preventing or delaying the onset of cognitive impairment in older adults without known cognitive impairment.

### Screening Instruments

For KQs addressing screening, we included studies that evaluated any brief screening instrument that could be delivered in primary care in 10 minutes or less by a clinician or self-administered in 20 minutes or less. Screening instruments could be administered to the patient or an informant (family member or caregiver), and take place in person, by telephone, or online. We excluded screening done by diagnostic imaging or biomarker testing.

### Interventions and Comparators

For KQs addressing the treatment of cognitive impairment, we focused on major pharmacologic and nonpharmacologic interventions intended for use during the early and mild stages of cognitive impairment and aimed at improving patient cognition, physical function, or QOL; to improve caregiver burden or well-being; or a combination of these. We excluded interventions with a primary aim of improving patient behavioral and psychological symptoms of dementia, improving physical performance, or reducing falls. A full list of included and excluded interventions is included in Appendix A Table 1.

Comparator interventions included no treatment or waitlist, placebo, usual care, or attention controls. Attention controls included minimal support and “sham” cognitive activities (e.g., working on puzzles, reading the newspaper) or exercise interventions (e.g., light stretching). Usual or standard treatment refers to what would normally be provided in the study setting to participants with dementia, and might include medication, clinic consultations, contact with a community mental health team, or support from voluntary organizations. We excluded studies comparing two active interventions with no true control group, as the focus of this review was not on the comparative effectiveness of various interventions.

### Outcomes

We included studies examining the benefits or harms of screening or treatment that reported outcomes on decision making for patients and families or clinicians (e.g., health care planning, including advance directives; screening and diagnostic decisions; safety planning; legal and financial planning); patient health outcomes (i.e., mortality, health care utilization, institutionalization, global function, cognitive function, physical function, QOL, and neuropsychiatric symptoms including depression and anxiety); caregiver outcomes (i.e., caregiving burden, symptoms of depression and anxiety, QOL); or societal outcomes (e.g., automobile accidents). We excluded studies if they included only patient satisfaction or cost outcomes. For harms, we included studies reporting total adverse events (AEs), withdrawals due to AEs, and serious adverse events (SAEs) that resulted in unexpected medical care, morbidity, or mortality.

### Study Design

For KQs 1 and 3, we included randomized and nonrandomized controlled trials that compared individuals who received screening with those who received no screening or usual care. For studies of test accuracy of screening tests (KQ 2), we included studies that reported the sensitivity and specificity (or data that would allow us to calculate the sensitivity and specificity) of a screening test compared with a diagnostic reference standard (i.e., clinical assessment or neuropsychological testing, with explicit diagnostic criteria with or without expert consensus/conference). Studies designed to develop a screening instrument (rather than validate a screening instrument) were excluded unless they had a separate study sample to validate the instrument. We excluded case-control studies and studies that selectively recruited patients with known or clinically suspected dementia or MCI (or cognitively normal controls) due to the high risk of bias in patient selection for these studies. We did, however, include studies among patients with subjective memory complaints (not clinically suspected) because subjective memory complaints are relatively common among older adults.^108^

Treatment effectiveness studies (KQ 4) were limited to randomized clinical trials (RCTs) or nonrandomized clinical trials. For harms (KQ 5), we included all trials that were included for the effectiveness question (KQ 4), and cohort or case-control studies with 1,000 or more persons. We excluded open-label extension data because there was not a comparison group.

Because of the large volume of search results, we used a single-screen process (i.e., one reviewer screened for exclusion) for records with terms clearly outside of the scope of the review in the title or abstract (e.g., “mice,” “HIV,” “brain injury”). Two independent reviewers then screened the titles and abstracts, using the inclusion and exclusion criteria as a guide, of all other records and those not flagged for exclusion during single screening. Subsequently, at least two reviewers assessed the full text of potentially relevant studies using a standard form that outlined the eligibility criteria. Disagreements were resolved through discussion and consensus. Title and abstract and full-text review were conducted in DistillerSR (Evidence Partners, Ottawa, Canada). We kept detailed records of all included and excluded studies (and the reason for their exclusion) during full-text review.

## Quality Assessment

At least two reviewers critically appraised all newly identified eligible studies in DistillerSR. We assigned each study a quality rating of “good,” “fair,” or “poor” according to the USPSTF’s study design–specific criteria.^109^ We supplemented these criteria with items from the Newcastle-Ottawa Scale for cohort studies^110^ and the Quality Assessment of Diagnostic Accuracy Studies I and II for studies of diagnostic accuracy^111,^ ^112^ (Appendix A Table 2). Disagreements were resolved by consensus and, if needed, consultation with a third independent reviewer. Because this review was an update of our own work, we did not repeat critical appraisal of the original studies through full dual-quality rating; rather, we confirmed the quality rating during data abstraction. Likewise, we did not systematically critically appraise all of the studies that were previously identified and included from a related systematic review.^107^ In that review, the methodological quality of the included studies was assessed using a modified Jadad scale and included only studies with a minimum score of 3. We critically appraised only studies that scored a 3 out of 5 on the Jadad scale to examine whether they were at high risk of bias.

Good-quality studies were those that met nearly all specified quality criteria. For studies of test accuracy, we assigned a good-quality rating if they recruited patients consecutively or randomly, administered the index test blinded to, or at least prior to, the reference standard, used a reference standard that could accurately classify the target condition, interpreted the reference standard independently from the screening test, and administered the screening test and reference standard on the same day to all participants. For treatment studies, we rated them as good quality if comparable groups were assembled initially and maintained throughout the study, reliable and valid measurement instruments were used and applied equally to the groups, procedures for maintaining fidelity to the intervention were in place, followup was adequate (i.e., ≥80% retention overall) and not differential between groups, data were complete, and there was no evidence of selective reporting. Fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study.

Studies rated as poor quality had several important limitations or one critical flaw and were excluded from this review. The most common potential risk of bias for diagnostic studies that warranted a poor-quality rating was application of the reference standard to only those patients who screened positive. In these kinds of cases, when missing data are not random, analysis will generate biased estimates of diagnostic accuracy,^113–116^ and verification of only screen-positive patients will generally lead to an overestimation of both sensitivity and specificity. Potential risk of bias for treatment trials resulting in poor-quality ratings included very high attrition (>40%) or differential attrition (>15% between groups), no information on the number of participants with complete data or reasons for missing data, and unclear randomization procedures coupled with imbalances in baseline characteristics between groups.

## Data Abstraction

For screening studies (KQ 2), we extracted details about each study’s screening instrument(s) (e.g., administration time, language, cut-point); recruitment and inclusion criteria; number of participants approached and analyzed; patient characteristics (i.e., age, sex, race/ethnicity, socioeconomic status [SES]); prevalence of dementia, MCI, or both; reference standard details; and diagnostic outcomes for given cut-points (i.e., contingency table, sensitivity, specificity, positive and negative predictive values, area under the curve). When more than one cutoff was reported for a screening instrument, only the optimal cutoff (as indicated by the author or as assessed by the reviewer as the best balance of sensitivity and specificity) was abstracted. For the MMSE, cutoffs of 23, 24, 23/24, or 24/25 were always abstracted.

For treatment trials (KQs 4, 5), we extracted details about each study’s design (e.g., recruitment and inclusion criteria, number of participants recruited and analyzed); patient characteristics (e.g., proportion with MCI or specific dementia syndromes, age, sex, race/ethnicity, SES); and intervention characteristics (e.g., intervention components, dose/intensity, frequency and duration, interventionists) and control groups. For all outcomes, if a study reported results at more than one followup time point, we abstracted data for all time points at 3 months’ followup or longer. Results related to the following outcomes were abstracted: any decision making outcome (on behalf of the clinician, caregiver, or patient); any societal outcome; patient mortality; institutionalization; health care utilization including hospitalizations and emergency department visits; global function (e.g., Clinical Dementia Rating [CDR], Clinician’s Interview-Based Impression of Change–Plus [CIBIC+]); global cognitive function and domain-specific cognitive function; physical function (i.e., ADLs and IADLs); patient and caregiver QOL, psychological morbidity, depressive symptoms, and anxiety symptoms; neuropsychiatric symptoms; measures of caregiver burden; and adverse events. A table of the most commonly reported instruments for each outcome, including a description, is provided in Appendix A Table 3. Given the already complex nature of this review, we did not abstract caregiver outcomes related to caregiving self-efficacy, caregiving competence or mastery, time spent caregiving, and other measures of perceived needs, mood, or satisfaction with caregiving.

For measures of global cognitive function, we abstracted the Alzheimer’s Disease Assessment Scale (ADAS-Cog) as the primary measure and used the MMSE when the ADAS-Cog was not available. In the rare instance in which neither of these two measures was used, we accepted other measures of global cognitive functioning (e.g., Mattis Dementia Rating Scale, Telephone Interview for Cognitive Status [TICS]). We abstracted results for domain-specific cognitive function measures (i.e., executive function, memory, attention, and language) qualitatively for each measure to compare these results to measures of global cognitive function. For QOL outcomes, we included measures of general QOL (e.g., Short-Form 12- and 36-Item Health Survey [SF-12 and SF-36], EuroQol 5-Dimensions [EQ-5D]) and dementia-related QOL (e.g., Dementia Quality of Life [DQOL], Dementia Quality of Life [DEMQOL], Quality of Life in Alzheimer’s Disease [QOL-AD]). We only abstracted results for neuropsychiatric symptoms for depression, anxiety, overall psychological morbidity, and composite behavioral and symptoms (e.g., total scores on the Neuropsychiatric Inventory [NPI], frequency scores on the Revised Memory and Behavior Problems Checklist [RMBPC]). Given the focus of the review and overall volume of results, we did not abstract results for other specific neuropsychiatric symptoms such as agitation, hallucinations, and insomnia.

We abstracted data from each included study into detailed abstraction forms using DistillerSR. One reviewer completed primary data abstraction, and a secondary reviewer checked all data for accuracy and completeness. We contacted authors when data reporting was incomplete or data points required clarification. In cases where data was only presented in graphical format, we used WebPlotDigitizer© Version 3.10 to extract data and provide estimates of the within-group means and variance at followup. Such data was not abstracted if only group means (and not measures of dispersion or between-group differences) were displayed.

## Data Synthesis and Analysis

For test accuracy studies (KQ 2), our primary outcomes of interest were sensitivity and specificity. We synthesized results in summary tables and figures organized by instrument type (according to length of administration) and separated by screening for dementia, MCI and dementia, or MCI only. We categorized these instruments as very brief (administered in ≤5 minutes), brief (administered in 6 to 10 minutes), or longer, self-administered instruments (>10 minutes). We relied on published administration times or administration times reported in the individual studies.

We reported the sensitivity and specificity for the most commonly accepted or reported cutoffs. While we also extracted positive and negative predictive values, we did not focus on these measures because the prevalence of cognitive impairment varied widely across studies. Test performance was either directly extracted from individual study results, calculated using study presented contingency tables, or calculated using the prevalence of cognitive impairment and the reported sensitivity and specificity. We summarized ranges of sensitivity and specificity for each instrument and used figures to visually display the data, as we were unable to quantitatively pool most data given the limited number of studies per instrument by condition, heterogeneity in population or diagnostic criteria, or lack of reporting about cutoffs (and scoring). We conducted quantitative synthesis for only one instrument—the MMSE at a cutoff of 23 or 24 to detect dementia. We ran a bivariate model, which modeled sensitivity and specificity simultaneously, thus accounting for the correlation between these variables.

For treatment trials, we grouped the interventions into four broad categories: 1) FDA-approved medications to treat AD (i.e., AChEIs and memantine); 2) other medications or dietary supplements (e.g., NSAIDs, gonadal steroids, and vitamins); 3) nonpharmacologic interventions aimed primarily at the patient, including: cognitive training, stimulation, and/or rehabilitation; exercise interventions; and multicomponent and other interventions; and 4) nonpharmacologic interventions aimed primarily at the caregiver or caregiver-patient dyad, including psychoeducation, care and case management, and other caregiver-focused interventions. Given that there is no agreed-upon classification system for grouping or describing nonpharmacologic interventions,^117^ we classified interventions based on the content of the intervention and intended audience, using available taxonomies and definitions where available. We categorized interventions based on how they were described in each study in relation to our working definitions rather than how they were named or classified in the study. We acknowledge that our categorization scheme represents broad definitions, that there may be some overlap between categories, and that our assignments may not be precise. Nonetheless, given the volume and heterogeneity of evidence, such categorization helped to adequately synthesize and interpret results.

For each body of literature, we conducted qualitative syntheses for each of the commonly reported outcomes, which varied by intervention type. While we also address less commonly reported outcomes, we primarily focus on the commonly reported outcomes due to the bias from selective reporting. We created summary tables to capture the key study characteristics and sources of clinical heterogeneity as well as intervention characteristics for each body of evidence. Additionally, we created tables for each body of evidence that display a summary of results for each primary outcome within that body of evidence. In these summary tables, we focus on the longest duration of followup for each trial.

We conducted meta-analyses on the most commonly reported outcomes for each body of evidence. As a result, pooled analyses were conducted for FDA-approved medications on global cognitive function outcomes, global function outcomes, and harms; for nonpharmacologic patient-level interventions for global cognitive function outcomes; and for caregiver and caregiver-patient dyad interventions for caregiver burden and caregiver depression measures. For consistency across the body of evidence, in quantitative analyses we focused on 6- to 12-month outcomes and included only shorter- or longer-term results when 6- or 12-month outcomes were not available. When more than one treatment group was included in a study, we selected the group that provided the treatment most like that described in other studies for the meta-analyses.

We ran random-effects models using the DerSimonian and Laird method.^118^ For analyses with fewer than 10 trials, we also ran a sensitivity analysis using a more conservative restricted maximum likelihood (REML) analysis with the Knapp-Hartung correction for small samples.^119^ Our summary table reflects the results of these more conservative analyses, including the standard deviation of the effect size, Tau. In cases where continuous outcomes were measured using a variety of different instruments with differing scales (e.g., caregiver burden), we analyzed a standardized effect size (Hedge’s g) based on the differences in change between groups from baseline to followup. A pooled risk ratio (for binary data) was used to analyze harms outcomes and improvement or maintenance in global function for AChEIs and memantine interventions. When trials only reported results separately for subgroups (e.g., patients with dementia and patients with MCI), we included entries for both subgroups in the meta-analysis.

We examined the association between key study characteristics and effect sizes when possible. This included study quality (i.e., good vs. fair), population characteristics (i.e., age, dementia vs. MCI, and baseline MMSE scores), setting (United States vs. other country), intervention characteristics (i.e., duration of intervention, group- vs. non-group–based cognitive-focused activities), and control conditions (no intervention or usual care vs. sham or minimal interventions). In quantitative analyses with at least 10 trials, we used meta-regressions to explore heterogeneity in effect sizes. For analyses with fewer trials or no quantitative analysis, we visually inspected the results for any patterns of effects. We assessed the presence of statistical heterogeneity among the studies using standard chi-square tests and estimated the magnitude of heterogeneity using the I^2^ statistic. Finally, for outcomes with 10 or more trials in the meta-analysis, we generated funnel plots and ran an Egger’s test to evaluate small study effects and potential publication bias.^120,^ ^121^

We used Stata version 15.1 (StataCorp LP, College Station, TX) for all analyses. All significance testing was two-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center (EPC) approach,^122^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation Working Group.^123^ Our method explicitly addresses four of the five EPC-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). The limitations in the body of evidence reflects potential reporting bias, study quality, and other important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. We developed our overall strength of evidence grade based on consensus discussion involving at least two reviewers.

## Expert Review and Public Comment

A draft Research Plan was posted on the USPSTF Web site for public comment from June 29 to July 26, 2017. In response to public comment, the USPSTF provided a definition for MCI, clarified the specific etiologies of dementia that would be included, and clarified that studies conducted exclusively among persons with potential reversible causes of dementia would be excluded. A final research plan was posted on the USPSTF Web site on October 19, 2017. We made no deviations from the final research plan in the conduct of this review.

A draft version of this report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. Additionally, a draft of the full report was posted on the USPSTF Web site from September 10 through October 7, 2019. A few comments were received during this public comment period. All comments were read and considered; minor editorial changes were made to the report based on these comments but no changes were made to the evidence or to our conclusions.

## USPSTF Involvement

We worked with four USPSTF members at key points throughout this review, particularly when determining the scope and methods and developing the Analytic Framework and KQs. The USPSTF members approved the final Analytic Framework, KQs, and inclusion and exclusion criteria after revisions reflecting the public comment period. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.