# Chapter 1 Introduction

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2014 recommendation on screening for cognitive impairment in older adults.^1^

## Condition Definition

Clinical definitions of cognitive disorders have evolved over time. In the Diagnostic and Statistical Manual of Mental Disorders (Fourth Edition) (DSM-IV), published in 1994, dementia is defined as a decline in two or more cognitive domains (memory, attention, language, or visuospatial or executive functioning) that affects social or occupational functioning.^2^ In the DSM-5, published in 2013, dementia is subsumed under the broader category of “major neurocognitive disorder” and is defined as a decline in one or more cognitive domains (learning and memory, language, executive function, complex attention, perceptual-motor [visuospatial], or social cognition) that interferes with independence in everyday activities.^3^ In the updated nomenclature, any domain could be impaired to meet the definition of dementia, whereas in DSM-IV, a decline in memory is required. Furthermore, in the DSM-5, a sixth cognitive domain, social cognition, was added. In both cases, these deficits do not occur exclusively during delirium, and are not better explained by another mental disorder, such as schizophrenia.

The dementia syndrome is further classified according to the symptoms and course of the impairment and the suspected underlying pathology. The major causes of dementia syndrome are: Alzheimer’s disease (AD), vascular dementia (VaD), frontotemporal dementia (FTD), Lewy body dementia (LBD), Parkinson’s disease with dementia (PDD), and dementia of mixed etiology (most commonly AD and VaD or mixed etiology with VaD).^4^ With AD, FTD, LBD, and PDD, abnormal protein deposits that accumulate in the brain are believed to contribute to deterioration of brain function and dementia (amyloid plaques, neurofibrillary tangles, Lewy bodies).^5^ Other neuropathological changes associated with dementia can include cortical atrophy, hemorrhage, small-vessel ischemic disease, and neuronal and white matter loss.^6^ The exact etiological mechanisms for many types of dementia (e.g., AD, FTD, LBD, and PDD), however, have not been clearly defined.^7^ For example, amyloid plaques found during brain autopsies are associated with AD and LBD, but these pathological findings are not always consistent with premorbid clinical diagnoses.^8^ Other established causes of dementia include depression, alcohol and other substance abuse, medications (e.g., antihistamines), metabolic disorders (e.g., thyroid disorders and diabetes), intracranial tumors, normal pressure hydrocephalus, subdural hematomas, infections (e.g., HIV, prion disease), traumatic brain or anoxic injury, and rare neurodegenerative disorders (e.g., Huntington’s disease, progressive supranuclear palsy).^9,^ ^10^

Mild cognitive impairment (MCI) is distinguished from dementia as cognitive impairment that is not severe enough to interfere with independence in daily functioning. The nomenclature for MCI is varied and includes cognitive impairment without functional impairment, cognitive impairment no dementia (CIND), mild neurocognitive disorder, and mild cognitive disorder, all of which have varied definitions and criteria.^11^ In the DSM-5, MCI is classified under the broad category of “mild neurocognitive disorder.” DSM-5 criteria for MCI include concerns of cognitive impairment by the patient, informant, or clinician; findings of modest cognitive deficits; and absence of interference with daily functioning (even though greater effort or compensatory strategies may be needed).^3^ This definition is consistent with that used by the International Working Group on Mild Cognitive Impairment.^12^ The DSM-5 definition contrasts somewhat with earlier working definitions of MCI, including one of the most commonly used definitions of MCI published by Petersen and colleagues in 1999. The Petersen definition focuses on amnestic MCI, defined as complaints of memory impairment corroborated by an informant, memory impairment on objective testing, normal performance in nonmemory cognitive domains, preserved activities of daily living (ADLs), and no dementia.^13,^ ^14^ Some research in MCI distinguishes between amnestic and non-amnestic MCI, and between single- or multidomain MCI.^15–17^ Regardless of the nomenclature, MCI is an intermediate but not necessarily transitional cognitive state between normal cognition and dementia.

## Prevalence and Burden

### Dementia

Dementia is a common condition, affecting an estimated 2.4 to 5.5 million Americans.^4,^ ^6,^ ^18^ The prevalence of dementia is likely underestimated given the challenges of diagnosis, particularly in primary care settings.^19,^ ^20^ By 2050, it is projected that AD will affect 13.8 million Americans, largely due to the increase in size of the elderly population.^21^ The estimated total health, long-term, and hospice care costs for dementia in the United States were $290 billion in 2019. Medicare and Medicaid pay approximately 70 percent of those costs. These cost estimates do not include the $34 billion in uncompensated care that informal caregivers are estimated to provide annually.^22^

The prevalence of dementia was estimated at 8.8 percent in 2012 among adults age 65 years and older in the United States, a significant decrease from the estimated prevalence of 11.6 percent in 2000.^23^ The proportion of dementia caused by different etiologies varies widely between studies because of differences in diagnostic criteria, study setting, and age of participants. A 2017 study that used administrative enrollment and claims data from Medicare beneficiaries age 68 years and older during the years 2011–2013 found that the most commonly defined dementia subtype was AD (accounting for 43.5% of dementia claims), followed by VaD (14.5%), LBD (5.4%), and FTD (1.0%).^24^ Similarly, one systematic review found that AD accounted for 56.3 percent of cases, followed by VaD (20.3%) and mixed etiologies (6.2%).^25^ Other causes, such as PDD and alcohol abuse, were much less common.^25^ Only 4 percent of dementia cases were due to potentially reversible causes, although only 0.6 percent of dementia cases actually reversed to normal cognition in studies that reported followup.^25^

The prevalence of dementia increases with age. In 2012, the estimated prevalence of dementia in the United States was 3.2 percent in adults ages 65 to 74 years, rising to 9.9 percent for those ages 75 to 84 years, and 29.3 percent for those age 85 years and older.^23^ Dementia incidence also increases exponentially with age between the ages of 65 and 90 years and doubles approximately every 5 years.^26,^ ^27^ One study among older adults age 90 years and older without dementia found the overall incidence rate was 18.2 percent per year, with rates increasing markedly with age from 12.7% per year in the 90- to 94-year-old age group, to 21.2% per year in the 95- to 99-year-old group, to 40.7% per year in the 100+-year-old group.^27^

Dementia prevalence varies by race and ethnicity. A population-based study found the prevalence of dementia in adults age 71 years and older was 21.3 percent for black adults compared with 11.2 percent for white adults.^28^ Another study found that the prevalence of AD in older black adults is roughly double (10.5% vs. 5.4%) the prevalence in non-Hispanic white adults,^29^ while several studies have found the prevalence of AD in Hispanics to be approximately 1.5 times that observed in the white population.^28,^ ^30,^ ^31^ Epidemiological data suggests that certain risk factors are more common in blacks and Hispanics than whites, such as hypertension, coronary artery disease, and stroke, which may account for some of the racial disparities observed in AD.^30^ There is little consensus, however, on the cause for observed disparities in prevalence.

Dementia prevalence also varies by gender, affecting more women than men. One study estimated that in adults age 71 years and older, approximately 16 percent of women had dementia compared with 11 percent of men.^32^ While previous research suggested that higher rates of dementia prevalence in women were related largely to women’s longer life expectancy,^32^ newer research suggests that differences in genetic factors^33^ and education^34^ levels may contribute to disparate prevalence rates by gender as well.

### MCI

The prevalence of MCI is even more difficult to ascertain than the prevalence of dementia because of even greater between-study differences in sampling, methods of clinical assessment, and the criteria used to define MCI.^29^ Estimates of MCI prevalence range widely, from 3 to 42 percent in adults age 65 years and older.^35,^ ^36^ One systematic review of 35 population-based studies found the median prevalence to be 4.9 percent (range, 0.5% to 31.9%) for amnestic MCI, 26.4 percent (range, 3% to 42%) for MCI, and 20.6 percent (range, 5.1% to 35.9%) for CIND across a broad age range of older adults.^36^ While the prevalence of MCI and CIND appeared to increase with age, these studies did not identify a consistent relationship with age across different definitions.^35,^ ^36^ Likewise, these studies found no consistent relationship between MCI and gender, race/ethnicity, or education.^35,^ ^36^

## Natural History

### Dementia

The most common types of dementia are irreversible and usually progressive, including AD, VaD, LBD, and FTD. Early stages of dementia generally affect instrumental activities of daily living (IADLs), such as money and medication management, shopping, or cooking, along with the ability to learn and retain new information. As the dementia progresses, patients become unable to carry out basic self-care ADLs, such as dressing, toileting, or grooming.^37,^ ^38^ The onset and progression of dementia are highly variable and depend in part on the etiology or type. The median survival time from diagnosis of dementia is estimated to range from 4.5 to 6.7 years, although this varies by how onset of disease is defined, age at diagnosis, degree of impairment, and the etiological type of dementia.^39,^ ^40^ For example, median survival time for AD is thought to be longer than for FTD, and some patients with AD can live as long as 20 years after diagnosis.^32,^ ^41–43^ The rate of progression of cognitive decline also varies with the type of dementia. Patients with AD, for example, can experience a decline of 2 points or less per year on the Mini Mental State Examination (MMSE), whereas the decline in those with other types of dementia can be more rapid.^44^ The rate of decline can also depend on the stage of disease, as patients may experience an accelerated rate of decline as their disease progresses.^45,^ ^46^ In addition to cognitive decline, neuropsychiatric symptoms such as depression, anxiety, apathy, agitation, aggression, personality changes, and psychosis (e.g., delusions, paranoia, hallucinations) can occur.^6^ Neuropsychiatric symptoms can occur with any type of dementia but tend to be more common with specific types. FTD, for example, is commonly associated with euphoria or disinhibition, whereas PDD and LBD are commonly associated with visual hallucinations. AD is associated with apathy, anxiety, and depression in early stages and agitation and delusions in later stages.^47–50^

### MCI

The rates of stability, progression, and regression of MCI vary markedly between studies. This variation likely reflects the complex underlying pathology as well as differences in diagnostic criteria, population settings, and participants. Variations in diagnostic criteria have implications for understanding the natural history of MCI. For example, the 1999 Petersen criteria defined MCI essentially as amnestic MCI, while broader criteria used by others include categories for amnestic and nonamnestic MCI, and for single-domain and multidomain MCI. Each category of MCI has different predicted rates of conversion from MCI to dementia. Amnestic MCI and multidomain MCI are more likely to progress to dementia than others.^51^ Additionally, single-domain MCI is often a precursor of multidomain MCI; therefore, single-domain impairment may be the earliest detectable stage of a progressive condition, but may also be more likely than other MCI subtypes to revert to normal cognition.^51–53^

Overall, there is strong evidence that persons with MCI have a much greater risk of progressing to dementia than persons with normal cognition. A 2013 systematic review found that an average of 32 percent of persons with MCI go on to develop dementia over 5 years.^54^ This is consistent with a 2009 meta-analysis that found that on average, 38 percent of persons with MCI went on to develop dementia when followed for at least 5 years.^15^ In a subset of five studies included in the 2009 meta-analysis, the annual conversion rate to dementia over a mean followup of 6.0 years was 3.6 percent for persons with MCI compared with 0.43 percent for healthy subjects (relative risk [RR], 13.8 [95% confidence interval (CI), 8.44 to 22.6]). Overall, the annual rate of progression from MCI to dementia (adjusted for sample size and dementia type) was 4.9 percent (95% CI, 1.6 to 9.9). The adjusted rate of progression from MCI to AD dementia was 6.8 percent (95% CI, 1.9 to 14.5) and 1.6 percent (95% CI, 0.3 to 9.4) from MCI to VaD.^15^ Other studies using different definitions of MCI found cumulative rates of progression to dementia of 22 to 40 percent over mean study times of 5 to 10 years. MCI may also regress to normal cognition over time in 10 to 40 percent of persons with MCI.^51,^ ^55,^ ^56^ Although several population-based studies have noted an increased risk of mortality in persons with MCI compared with those with normal cognition,^57–61^ other studies have found no associated increase in mortality.^62,^ ^63^

## Risk and Protective Factors

Increasing age is the strongest known risk factor for cognitive decline in general and for AD specifically.^18^ Other proposed risk factors for cognitive decline have varying levels of evidence to support an association. The ε4 allele of the lipoprotein E gene has good observational evidence in white and Asian adults as a risk factor for AD.^64^ Other risk factors with lower-quality observational evidence include family history, depression, physical frailty, and low social support.^64–68^

In contrast, more years of formal education have been associated with a reduced risk of dementia, likely through multiple causal pathways, including a direct effect on brain development and function and the association between higher levels of education and positive health behaviors and better access to health care.^4,^ ^23,^ ^69^ Likewise, better control of cardiovascular risk factors over the past decade has been associated with declining dementia risk.^23,^ ^70,^ ^71^ Obesity has also been found to be associated with a decreased risk of dementia with the hypothesis that while obesity in midlife may increase risk for later-life cognitive decline and dementia, obesity at older ages may be associated with cognitive and other health advantages.^72^ In addition, several dietary and lifestyle factors have been associated with a decreased risk of dementia, including adequate folic acid intake, low saturated fat and longer-chain omega-3 fatty acid intake, high fruit and vegetable intake, adherence to Mediterranean diet, moderate alcohol intake, cognitive engagement, social engagement, and higher physical activity level.^73–76^

## Prevention of Cognitive Impairment

There is a robust evidence base exploring the effectiveness of interventions targeting modifiable risk factors that are potentially associated with age-related cognitive decline. In 2017, a comprehensive systematic review was published by Kane and colleagues^77^ on the effectiveness and harms of pharmacological and nonpharmacological interventions to prevent age-related cognitive decline, MCI, and dementia. The review, which was also subsequently published in individual manuscripts,^78–80^ included 263 studies addressing 13 classes of interventions: cognitive training, physical activity, nutraceuticals, diet, multimodal interventions, hormone therapy, vitamins, antihypertensive treatment, lipid-lowering treatment, nonsteroidal anti-inflammatory drugs (NSAIDs), antidementia drugs, diabetes treatment, and “other interventions.”

Of the 13 classes of interventions examined, none of the interventions had high strength of evidence to suggest that they delayed or prevented age-related cognitive decline, MCI, or dementia. There were a few interventions types, however, that showed more potential than others in benefiting cognitive performance. For instance, the review found that some forms of cognitive training improved certain domain-specific measures of cognitive function that were targeted by the intervention (i.e., reasoning, executive function, attention, processing speed, and memory) for adults with normal cognition, but there was little evidence to support the transfer of benefits to other cognitive areas or to reduced dementia incidence. Additionally, the benefit for any form of cognitive training beyond 2 years was uncertain. Although the evidence was less compelling, physical activity and vitamin B12 plus folic acid also showed potential benefit on brief cognitive tests and memory. A few specific interventions reached moderate strength of evidence for no benefit in cognitive performance, including vitamin E in women, angiotensin-converting enzymes and thiazide, and angiotensin receptor blockers.^77^

The absence of strong and consistent evidence in support of preventive interventions to delay or reduce onset of MCI and dementia in older adults with normal cognition may largely result from limitations inherent in the included evidence. Most published trials were of limited duration and followup, ranging between 6 months and 4 years. Even at 4 years, this period is substantially shorter than the expected latency period to reach MCI and dementia, which is thought to initiate years before participants begin to experience any symptoms. Furthermore, most randomized trials were underpowered to detect changes in the incidence of MCI and dementia due to small sample sizes.^77^

## Rationale for Screening

It is estimated that 29 to 76 percent of patients with dementia or probable dementia are not diagnosed by primary care clinicians.^81–83^ That may be because primary care clinicians fail to recognize cognitive impairment during clinic checks that rely on routine history and physical examination.^84^ Moreover, the sensitivity of a clinician’s diagnosis appears to be strongly related to dementia severity, with few practitioners recognizing mild dementia.^85^ Early identification of cognitive impairment, through screening, would ideally allow patients and their families to receive care at an earlier stage in the disease process, potentially facilitating discussions regarding decision making (e.g., health care, financial, legal) while the patient still retains decision making capacity. Clinical experts and researchers have suggested that the health, psychological, and social benefits from early recognition of dementia include: early education of patients and caregivers on the disease process; early coaching of caregivers in how to manage the patient; advanced planning (e.g., establishing a will, health care proxy, power of attorney, and advance directives; timely discussion of care transitions and appropriate placement options); reduced patient and family anxiety and stress, as well as reduced caregiver burden, blame, and denial; patient safety (e.g., monitoring driving, medication compliance, cooking); and promotion of advocacy for research and treatment development.^86,^ ^87^

## Screening and Diagnostic Workup for Cognitive Impairment

Many different brief cognitive screening instruments are available to clinicians in primary care. These cognitive tests alone, however, are not diagnostic of dementia or MCI. A positive screening test triggers subsequent diagnostic testing that assesses the level and possible etiology of cognitive impairment. When dementia is suspected, the practitioner should complete a detailed and focused clinical history and physical examination. Family members or other persons close to the patient who could provide an accurate history should ideally be present or contacted. This diagnostic workup may also include more comprehensive cognitive and functional assessments (e.g., neuropsychological testing or clinical evaluation by a trained clinician).

A diagnosis of dementia requires that the patient has developed requisite cognitive deficits (impairments in learning and memory, language, executive function, complex attention, perceptual-motor, or social cognition), which can be established with specific tests and interpreted relative to appropriate norms. Practitioners also can order laboratory tests to rule out potentially reversible causes of dementia (e.g., hypothyroidism, vitamin B12 deficiency). Since depression is common and treatable and often presents as cognitive impairment, it is necessary to rule it out in patients with suspected dementia. The American Academy of Neurology currently recommends structural neuroimaging with noncontrast head computed tomography or magnetic resonance imaging in the initial evaluation of dementia patients,^88^ although the need for neuroimaging in routine cognitive workups is controversial and may be more useful for those with acute onset or rapid progression or among those with other symptoms.^89^ Genetic testing for the APOE-ε4 allele (which increases the risk of developing AD) is not currently recommended, nor is genetic testing for other potential causes of dementia (e.g., specific mutations) unless there is a specific characteristic family history obtained.^88,^ ^90^

## Interventions and Treatment for Cognitive Impairment

The goals of treatment for cognitive impairment are to maintain quality of life (QOL) and maximize functional performance by addressing cognitive, mood, and behavioral impairments, as well as to treat any modifiable or reversible causes of impairment. Treatment options for those with MCI and dementia are numerous and include both pharmacologic and nonpharmacologic interventions. Pharmacologic treatments approved by the U.S. Food and Drug Administration (FDA) include acetylcholinesterase inhibitors (AChEIs) (i.e., donepezil, galantamine, and rivastigmine), memantine, and combination donepezil and memantine (Namzaric®). Donepezil (Aricept®) is approved for the treatment of all stages of AD, whereas galantamine (Razadyne®) and rivastigmine (Exelon®) are indicated for the treatment of mild to moderate AD and mild to moderate dementia associated with PDD (rivastigmine only). Memantine (Namenda®), on the other hand, is indicated for the treatment of moderate to severe AD. None of these medications is specifically FDA-indicated or recommended for the treatment of MCI, although they are used off-label.^91^ Other medications, including antiplatelet medications, antihypertension medications, and 3-hydroxy-3-methylglutaryl-CoA (HMG-CoA) reductase inhibitors (statins), are often prescribed for cardiovascular risk reduction, primarily for the treatment of VaD or mixed dementias. Additional therapies have been tested or suggested for preventing or treating cognitive decline or the symptoms related to cognitive decline such as NSAIDS, gonadal steroids, antipsychotics, antidiabetes drugs, and dietary supplements. Experimental drug therapies include various immunotherapies targeting beta-amyloid (solanezumab), beta-secretase (verubecestat), and tau protein (AADvac1 vaccine); medications targeting inflammation in the brain (CSP-1103), intravenous immunoglobulin (IVIG), and growth hormone–releasing hormone (GHRH).^92^ None of these experimental drug therapies are currently FDA-approved for use in the general population; access to these agents is restricted to individuals taking part in a clinical trial. Nonpharmacologic interventions include those targeting the patient, caregiver, or patient-caregiver dyad, and comprise multidisciplinary or multicomponent approaches, cognitive training, cognitive rehabilitation, cognitive stimulation interventions, exercise, peer support, caregiver counseling and psychoeducation, and case management.

## Current Clinical Practice in the United States and Recommendations of Other Groups

Although no professional organizations explicitly recommend routine screening for dementia in asymptomatic adults (Table 1), many groups—including the USPSTF, Alzheimer’s Association, American Academy of Neurology, American Geriatrics Society, Gerontological Society of America, U.S. Department of Veterans Affairs, Canadian Task Force on Preventive Health Care, European Federation of Neurological Societies, Royal Australian College of Practitioners, and International Association of Gerontology and Geriatrics—advise that clinicians assess the cognitive abilities of older adults who present with cognitive or cognitive-related functional complaints.^1,^ ^88,^ ^93–99^ The Veteran’s Health Administration explicitly recommends against screening in asymptomatic adults, regardless of age, given the lack of evidence to support a benefit of identification of early cognitive impairment and adequate evidence of harms from drug therapy.^97^

Table 1 Recommendations From Other Organizations

Organization | Year | Recommendation Statement
U.S. Department of Veterans Affairs^97^ | 2016 | Recommends against routine screening for cognitive impairment in persons of any age. Veteran’s Health Administration clinicians should use dementia warning signs to prompt assessment of cognitive function. If warning signs are present, patients should be evaluated further.
Canadian Task Force on Preventive Health Care (CTFPHC)^94^ | 2016 | Recommends against screening asymptomatic older adults (age ≥65 years) for cognitive impairment (Strong recommendation, low-quality evidence)
Gerontological Society of America (GSA)^99^ | 2015 | Recommends that primary care providers routinely ask beneficiaries about any noticeable changes in memory or cognition that have occurred since previous office visits during the Medicare Annual Wellness Visit (AWV). Additionally, primary care providers should use their clinical judgment and observational skills to determine whether any changes in memory or cognition since previous encounters with beneficiaries are noticeable during the Medicare AWV.
International Association of Gerontology and Geriatrics (IAGG)^458^ | 2015 | Recommends screening to identify early cognitive impairment among individuals with known risk factors for dementia (e.g., subjective cognitive concerns or family history of dementia)
Alzheimer’s Association^98,^ ^103^ | 2013 | Recommends screening for cognitive impairment among:; - Individuals with memory concerns or other cognitive complaints. Non-memory triggers include personality change, depression, deterioration of chronic disease without explanation, and falls or balance issues; - Informant reports of cognitive impairment, with or without patient concurrence; - Medicare beneficiaries, as part of the Annual Wellness Visit
National Institute for Health Care and Excellence (NICE)^459^ | 2011 | Recommends against screening for dementia in general population.
Royal Australian College of General Practitioners (RACGP)^96^ | 2012 | Found no evidence of benefit from screening for dementia in adults over age 65 without symptoms. Symptoms and signs of dementia should be detected opportunistically and assessed using questions addressed to the person and/or their caregiver.
European Federation of Neurological Societies (EFNS)^95^ | 2010 | No recommendations for general, asymptomatic populations.

In 2011, Medicare began covering “detection of cognitive impairment” as part of the new Annual Wellness Visit (AWV) benefit, which is mandated by the Affordable Care Act.^100^ The AWV requires an assessment of the patient’s cognitive function by direct observation with consideration of information obtained via patient reports and concerns raised by informants.^100^ The cognitive assessment is intended to result in the development of a personalized prevention plan in which the provider offers feedback and educates the patient about risks, including risks for cognitive impairment, when indicated.^101^ The AWV is mandated by the Affordable Care Act; however, only 20 percent of the 35 million Medicare Part B enrollees had an AWV in 2016.^102^ In 2013, the Alzheimer’s Association published recommendations for operationalizing the detection of cognitive impairment during the AWV. It recommended the use of a brief structured assessment (i.e., the General Practitioner assessment of Cognition [GPCOG], Mini-Cog, Memory Impairment Screen [MIS], AD8, or short Informant Questionnaire on Cognitive Decline in the Elderly [IQCODE]) if a health risk assessment reveals signs or symptoms of cognitive impairment, through clinical observation, or via concerns raised by the patient or informant.^103^ Likewise, both the National Institute on Aging (NIA) (2014)^87^ and Gerontological Society of America (2016)^104^ developed reference guides for primary care providers that describe the benefits of early screening, when to screen, how providers and staff can find time for screening, and how to screen for cognitive impairment. The NIA guide emphasizes and provides access to instruments that require 10 minutes or less to administer, including the AD8, Mini-Cog, and IQCODE,^87^ whereas the Gerontological Society of America workgroup specifically endorses the Mini-Cog, GPCOG, and MIS.^104^

## Previous USPSTF Recommendation

In 2014, the USPSTF concluded that current evidence was insufficient to assess the balance of benefits and harms of screening for cognitive impairment (I statement).^1^ At that time, the USPSTF found adequate evidence that some screening tools had sufficiently high sensitivity and specificity to be clinically useful in identifying dementia, but there was inadequate direct evidence on the benefits of screening for cognitive impairment. Additionally, while the evidence showed that several drug therapies and nonpharmacologic therapies, including those targeting caregivers, had a small effect on cognitive function and caregiver burden measures in the short term, the magnitude of the clinically relevant benefits was uncertain.