# Appendix H Detailed Trial Results for Trials of Caregiver and Caregiver-Patient Dyad Interventions

Appendix H Table 1 Caregiver and Caregiver-Patient Dyad Interventions: Detailed Results for Caregiver Burden Outcomes, by Intervention Type

Author, year Quality | Audience | Instrument (range)^†^ | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Psychoeducation Interventions
Berwig, 2017^*^,^329^; Fair | Caregiver | RMBPC Disruptive behaviors (total burden) (0–96) | IG1 | 6 | 21.1 (9.1) | 41 | NR | −5.461 (7.257) | 16.6 (9.6) | 40 | NR | 2.342 (6.379) | ES=1.144, 0.000
Berwig, 2017^*^,^329^; Fair | Caregiver | RMBPC Disruptive behaviors (total burden) (0–96) | IG1 | 9 | 21.1 (9.1) | 31 | NR | −6.173 (7.865) | 16.6 (9.6) | 31 | NR | 3.243 (6.999) | ES=1.267, 0.000
Berwig, 2017^*^,^329^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 6 | 32.5 (12.8) | 41 | NR | −0.425 (8.409) | 28.16 (12.5) | 40 | NR | 7.047 (8.093) | ES=0.906, 0.000
Berwig, 2017^*^,^329^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 9 | 32.5 (12.8) | 31 | NR | 2.669 (8.858) | 28.16 (12.5) | 31 | NR | 8.102 (8.576) | ES=0.623, 0.017
Brennan, 1995^330^; Fair | Caregiver | Impact of Caregiving Scale (Emotional Impact) (NR) | IG1 | 12 | 11.4 (3.2) | 47 | 11.0 (3.4) | NR | 11.6 (2.0) | 49 | 10.9 (2.5) | NR | NR, 0.65
Brennan, 1995^330^; Fair | Caregiver | Impact of Caregiving Scale (Physical Impact) (NR) | IG1 | 12 | 10.8 (3.3) | 47 | 11.4 (4.0) | NR | 10.5 (3.5) | 49 | 11.6 (3.9) | NR | NR, 0.47
Brennan, 1995^330^; Fair | Caregiver | Impact of Caregiving Scale (Relational Impact) (NR) | IG1 | 12 | 12.2 (3.5) | 47 | 12.1 (3.9) | NR | 12.0 (3.4) | 49 | 11.5 (3.3) | NR | NR, 0.63
Brennan, 1995^330^; Fair | Caregiver | Impact of Caregiving Scale (Social Impact) (NR) | IG1 | 12 | 13.7 (2.1) | 47 | 12.8 (3.2) | NR | 14.0 (2.3) | 49 | 12.9 (2.7) | NR | NR, 0.56
Burgio, 2003^332^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 (Black) | 6 | 1.35 (1.10) | 20 | 0.91 (0.88) | NR | 1.73 (1.18) | 20 | 1.77 (1.14) | NR | NR
Burgio, 2003^332^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 (White) | 6 | 1.62 (1.06) | 27 | 1.54 (1.02) | NR | 1.50 (0.88) | 29 | 1.15 (0.83) | NR | NR
Burgio, 2003^332^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 6 | 19.0 (15.9) | 47 | 13.6 (1.7) | NR | 19.9 (15.9) | 52 | 15.0 (1.7) | NR | NR, 0.52
Chu, 2011^334^; Fair | Caregiver | CBI (0–96) | IG1 | 3 | 79.79 (NR) | 30 | 75.03 (NR) | NR | 76.01 (NR) | 30 | 75.00 (NR) | NR | NR, 0.16
Chu, 2011^334^; Fair | Caregiver | CBI (0–96) | IG1 | 4 | 79.79 (NR) | 30 | 77.29 (NR) | NR | 76.01 (NR) | 30 | 76.22 (NR) | NR | NR, 0.36
Cristancho-Lacroix, 2015^*^,^336^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 | 3 | 2.2 (0.4) | 25 | 2.2 (0.6) | 0.0 (0.4) | 2.2 (0.6) | 24 | 2.1 (0.6) | −0.1 (0.5) | NR, 0.66
Cristancho-Lacroix, 2015^*^,^336^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 | 6 | 2.2 (0.4) | 25 | 2.3 (0.5) | NR | 2.2 (0.6) | 24 | 2.1 (0.6) | NR | NS
Cristancho-Lacroix, 2015^*^,^336^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 3 | 38.0 (14.5) | 25 | 38.3 (14.9) | 0.3 (6.6) | 35.0 (15.0) | 24 | 33.5 (15.3) | −1.5 (6.1) | NR, 0.74
Cristancho-Lacroix, 2015^*^,^336^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 6 | 38.0 (14.5) | 25 | 39.6 (15.7) | NR | 35.0 (15.0) | 24 | 34.8 (15.9) | NR | NS
De Rotrou, 2011^337^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 3 | 23.0 (14.2) | 62 | 22.2 (12.5) | NR | 24.3 (16.9) | 64 | 23.6 (17.0) | NR | MD=0.55, NR
De Rotrou, 2011^337^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 6 | 23.0 (14.2) | 55 | 23.0 (14.6) | NR | 24.3 (16.9) | 56 | 26.5 (17.0) | NR | MD=0.25, NR
Finkel, 2007^340^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 6 | 15.7 (NR) | 13 | 10.4 (NR) | NR | 15.7 (NR) | 12 | 16.9 (NR) | NR | Cohen’s D: 0.77, 0.089
Fung, 2002^*^,^341^; Fair | Caregiver | NPI-12 (0–60) | IG1 | 4 | 47.20 (10.11) | 26 | 36.80 (9.38) | NR | 47.87 (12.68) | 26 | 42.49 (13.56) | NR | F statistic=5.099, 0.003
Gallagher-Thompson, 2003^342^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 (Hispanic) | 6 | 18.24 (14.39) | 32 | 13.69 (1.85) | NR | 16.02 (9.24) | 14 | 16.35 (2.81) | NR | NR
Gallagher-Thompson, 2003^342^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 (White) | 6 | 19.27 (10.68) | 41 | 14.69 (1.29) | NR | 19.22 (14.08) | 18 | 15.50 (1.94) | NR | NR
Gallagher-Thompson, 2008^343^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 (Hispanic) | 6 | 1.30 (1.05) | 47 | 1.24 (0.85) | NR | 1.22 (0.93) | 42 | 1.15 (0.84) | NR | NR
Gallagher-Thompson, 2008^343^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 (White) | 6 | 1.58 (0.95) | 50 | 1.24 (0.84) | NR | 1.61 (0.64) | 45 | 1.57 (0.65) | NR | NR
Gallagher-Thompson, 2010^*^,^344^; Good | Caregiver | RMBPC (average burden) (0–4) | IG1 | 4 | 1.60 (0.62) | 36 | 1.23 (0.41) | NR | 1.56 (0.65) | 34 | 1.54 (0.61) | NR | Beta=−0.286, 0.012
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC (total burden) (0–96) | IG1 | 8 | 27.25 (14.38) | 54 | NR | NR | 25.07 (14.00) | 53 | NR | NR | Beta (SE)=−3.26 (2.21), NS
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC (total burden) (0–96) | IG1 | 12 | 27.25 (14.38) | 54 | NR | NR | 25.07 (14.00) | 53 | NR | NR | Beta (SE)=−2.16 (0.67), <0.01
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC (total burden) (0–96) | IG1 | 18 | 27.25 (14.38) | 54 | NR | NR | 25.07 (14.00) | 53 | NR | NR | Beta (SE)=−1.82 (1.19), NS
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Depressive behaviors (total burden) (0–36) | IG1 | 8 | 11.68 (7.97) | 54 | NR | NR | 10.43 (8.31) | 53 | NR | NR | Beta (SE)=−0.62 (1.33), NS
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Depressive behaviors (total burden) (0–36) | IG1 | 12 | 11.68 (7.97) | 54 | NR | NR | 10.43 (8.31) | 53 | NR | NR | Beta (SE)=−1.58 (0.98), NS
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Depressive behaviors (total burden) (0–36) | IG1 | 18 | 11.68 (7.97) | 54 | NR | NR | 10.43 (8.31) | 53 | NR | NR | Beta (SE)=−0.44 (0.66), NS
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Disruptive behaviors (total burden) (0–32) | IG1 | 8 | 7.90 (6.07) | 54 | NR | NR | 6.08 (5.00) | 53 | NR | NR | Beta (SE)=−3.23 (1.00), <0.01
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Disruptive behaviors (total burden) (0–32) | IG1 | 12 | 7.90 (6.07) | 54 | NR | NR | 6.08 (5.00) | 53 | NR | NR | Beta (SE)=−2.27 (0.71), <0.01
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Disruptive behaviors (total burden) (0–32) | IG1 | 18 | 7.90 (6.07) | 54 | NR | NR | 6.08 (5.00) | 53 | NR | NR | Beta (SE)=−1.34 (0.43), <0.01
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Memory problems (total burden) (0–28) | IG1 | 8 | 8.04 (5.15) | 54 | NR | NR | 8.56 (5.43) | 53 | NR | NR | Beta (SE)=−0.48 (0.76), NS
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Memory problems (total burden) (0–28) | IG1 | 12 | 8.04 (5.15) | 54 | NR | NR | 8.56 (5.43) | 53 | NR | NR | Beta (SE)=−0.48 (0.56), NS
Gaugler, 2013^*^,^346^; Fair | Family | RMBPC Memory problems (total burden) (0–28) | IG1 | 18 | 8.04 (5.15) | 54 | NR | NR | 8.56 (5.43) | 53 | NR | NR | Beta (SE)=−0.20 (0.42), NS
Gitlin, 2001^347^; Fair | Caregiver | MBPC (average) (0–1) | IG1 | 3 | 0.48 (0.27) | 93 | 0.43 (0.31) | NR | 0.47 (0.30) | 78 | 0.45 (0.29) | NR | Adj MD (95% CI)=−0.02 (−0.09, 0.05), 0.50
Gitlin, 2003^349^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 6 | 15.76 (13.84) | 89 | 12.09 (1.00) | NR | 13.90 (13.87) | 102 | 14.16 (0.93) | NR | NR, 0.12
Gitlin, 2003^349^; Fair | Caregiver | RMBPC Disruptive behaviors (average burden) (0–4) | IG1 | 6 | 0.53 (0.53) | 89 | 0.43 (0.50) | NR | 0.56 (0.66) | 101 | 0.50 (0.67) | NR | Adj MD (95% CI)=−0.05 (−0.19, 0.09), 0.47
Gitlin, 2003^349^; Fair | Caregiver | RMBPC Memory problems (average burden) (0–4) | IG1 | 6 | 0.81 (0.86) | 89 | 0.65 (0.75) | NR | 0.72 (0.77) | 101 | 0.78 (0.85) | NR | Adj MD (95% CI)=−0.17 (−0.35, −0.02), 0.03
Gitlin, 2008^348^; Fair | Caregiver + patient | RMBPC (average burden) (1–8) | IG1 | 4 | 4.5 (1.9) | 27 | 4.5 (1.8) | NR | 4.6 (3.0) | 29 | 4.8 (2.5) | NR | Adj MD (95% CI)=−0.01 (−1.21, 1.18), 0.98
Gitlin, 2008^348^; Fair | Caregiver + patient | Zarit-10 (0–40) | IG1 | 4 | 21.0 (9.0) | 27 | 20.3 (8.8) | NR | 21.3 (9.2) | 29 | 20.6 (10.4) | NR | Adj MD (95% CI)=0.75 (−3.36, 4.85), 0.72
Gitlin, 2010^350^; Fair | Caregiver | Zarit-12 (0–48) | IG1 | 4 | 21.2 (9.5) | 117 | 19.0 (8.5) | NR | 22.0 (9.6) | 122 | 21.0 (9.3) | NR | MD (95% CI)=−1.37 (−2.75, −0.01), 0.05
Gitlin, 2010^350^; Fair | Caregiver | Zarit-12 (0–48) | IG1 | 6 | 21.2 (9.5) | 114 | 19.1 (9.0) | NR | 22.0 (9.6) | 106 | 21.3 (9.8) | NR | MD (95% CI)=−1.61 (−3.13, −0.09), 0.04
Hebert, 2003^352^; Fair | Caregiver | RMBPC (average burden) (0–4) | IG1 | 4 | 2.01 (0.75) | 60 | 1.77 (0.74) | −0.28 (0.55) | 2.18 (0.69) | 56 | 2.07 (0.72) | −0.10 (0.60) | NR, 0.04
Hebert, 2003^352^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 4 | 42.47 (14.63) | 60 | 40.07 (14.84) | −2.40 (14.96) | 41.44 (15.16) | 56 | 41.25 (16.55) | 0.09 (11.99) | NR, 0.39
Hepburn, 2005^353^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 6 | 34.8 (12.5) | 120 | 36.2 (12.2) | 1.2 (8.1) | 32.0 (13.7) | 46 | 34.9 (14.5) | 3.5 (7.9) | NR, 0.25
Hepburn, 2005^353^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 12 | 34.8 (12.5) | 91 | 37.0 (13.9) | 1.9 (10.8) | 32.0 (13.7) | 40 | 37.0 (12.7) | 5.0 (10.5) | NR, 0.21
Kwok, 2013^*^,^358^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 3 | 37.4 (8.66) | 18 | 35.6 (7.52) | −1.83 (5.26) | 34.1 (13.3) | 20 | 36.4 (11.4) | 2.25 (7.09) | NR, 0.002
Martin-Carrasco, 2009^364^; Fair | Caregiver | Zarit-22 (22–110) | IG1 | 4 | 62.0 (14.9) | 4 | 56.6 (16.4) | NR | 58.4 (15.9) | 38 | 58.3 (16.7) | NR | NR, 0.6
Martin-Carrasco, 2009^364^; Fair | Caregiver | Zarit-22 (22–110) | IG1 | 10 | 62.0 (14.9) | 44 | 54.0 (15.9) | −8.1 (17.3) | 58.4 (15.9) | 38 | 60.5 (16.6) | 2.1 (16.5) | NR, 0.08
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 4 | 33.9 (14.5) | 115 | NR | −1.17 (12.3) | 34.0 (14.4) | 123 | NR | −0.63 (12.0) | MDC (95% CI)=−0.55 (−3.64, 2.55), 0.73
Martin-Cook, 2005^365^; Fair | Caregiver + patient | NPI-10 (1–114) | IG1 | 4 | 13.29 (13.90) | 24 | 10.63 (2.53)^‡^ | NR | 12.48 (11.33) | 23 | 10.41 (2.64)^‡^ | NR | NS
Martindale-Adams, 2013^*^,^366^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 3 | 21.0 (13.7) | 77 | 17.7 (12.0) | NR | 26.4 (18.0) | 77 | 22.4 (16.2) | NR | NR
Martindale-Adams, 2013^*^,^366^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 6 | 21.0 (13.7) | 77 | 17.0 (12.4) | NR | 26.4 (18.0) | 77 | 22.6 (17.2) | NR | NR
Martindale-Adams, 2013^*^,^366^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 9 | 21.0 (13.7) | 77 | 15.1 (10.7) | NR | 26.4 (18.0) | 77 | 19.0 (13.3) | NR | NR
Martindale-Adams, 2013^*^,^366^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 12 | 21.0 (13.7) | 77 | 18.6 (14.1) | NR | 26.4 (18.0) | 77 | 21.7 (16.5) | NR | Cohen’s D: 0.07, 0.875
Martindale-Adams, 2013^*^,^366^; Fair | Caregiver | Zarit-12 (0–48) | IG1 | 6 | 16.4 (8.3) | 77 | 15.6 (7.9) | NR | 17.7 (9.1) | 77 | 15.6 (9.3) | NR | NR
Martindale-Adams, 2013^*^,^366^; Fair | Caregiver | Zarit-12 (0–48) | IG1 | 12 | 16.4 (8.3) | 77 | 14.5 (6.6) | NR | 17.7 (9.1) | 77 | 15.3 (9.1) | NR | Cohen’s D: 0.07, 0.708
Mittelman, 2004^*^,^367^; Fair | Family | MBPC (average) (NR) | IG1 | 48 | 22.3 (13.8) | 203 | NR | NR | 24.8 (17.0) | 203 | NR | NR | logBeta (SE)=−1.86 (0.89), 0.0368
Ostwald, 1999^369^; Fair | Caregiver + patient | RMBPC Disruptive behaviors (average burden) (0–32) | IG1 | 3 | 6.8 (6.3) | 53 | 5.0 (5.4) | NR | 5.2 (5.1) | 31 | 4.4 (4.2) | NR | NR
Ostwald, 1999^369^; Fair | Caregiver + patient | RMBPC Disruptive behaviors (average burden) (0–32) | IG1 | 5 | 6.8 (6.3) | 60 | 4.148 (4.358) | NR | 5.2 (5.1) | 34 | 5.790 (4.366) | NR | F statistic=5.734, 0.019
Ostwald, 1999^369^; Fair | Caregiver + patient | Zarit-22 (0–88) | IG1 | 3 | 56.2 (13.3) | 50 | 56.8 (11.8) | NR | 56.5 (15.9) | 30 | 55.4 (15.9) | NR | NR
Ostwald, 1999^369^; Fair | Caregiver + patient | Zarit-22 (0–88) | IG1 | 5 | 56.2 (13.3) | 60 | 53.9 (12.4) | NR | 56.5 (15.9) | 34 | 59.4 (5.6) | NR | NR, 0.05
Roberts, 1999^370^; Fair | Caregiver | PAIS (NR) | IG1 | 12 | 42.2 (16.5) | 29 | 42.9 (17.1) | NR | 47.5 (21.7) | 29 | 46.1 (23.5) | NR | NR, 0.55
Spaulding-Wilson, 2018^*^,^372^; Fair | Caregiver | CBI (0–96) | IG1 | 6 | 34.9 (15.3) | 54 | NR | NR | 34.3 (12.2) | 41 | NR | NR | Beta (SE)=−0.448 (0.53), 0.397
Steffen, 2016^*^,^373^; Good | Caregiver | RMBPC (total burden) (0–96) | IG1 | 3 | 19.3 (0) | 28 | 10.7 (1.4) | NR | 19.3 (0) | 38 | 14.5 (1.2) | NR | Cohen’s D: 0.05, ≤0.05
Steffen, 2016^*^,^373^; Good | Caregiver | RMBPC (total burden) (0–96) | IG1 | 9 | 19.3 (0) | 22 | 10.1 (1.8) | NR | 19.3 (0) | 30 | 13.3 (1.5) | NR | NR, 0.18
Teri, 2005^374^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 6 | 11.3 (3.9) | 32 | 9.2 (4.6) | NR | 10.5 (3.9) | 34 | 9.1 (5.2) | NR | Adj MD (95% CI)=−3.2 (−6.1, −0.2),
Tremont, 2015^*^,^375^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 6 | 22.98 (12.89) | 133 | 20.04 (13.68) | NR | 22.59 (13.94) | 117 | 22.00 (12.82) | NR | NR, 0.16
Tremont, 2015^*^,^375^; Fair | Caregiver | RMBPC Depressive behaviors (total burden) (0–36) | IG1 | 6 | 8.87 (7.06) | 133 | 6.53 (6.36) | NR | 7.96 (7.85) | 117 | 7.97 (6.74) | NR | NR, 0.009
Tremont, 2015^*^,^375^; Fair | Caregiver | RMBPC Disruptive behaviors (total burden) (0–32) | IG1 | 6 | 5.92 (5.44) | 133 | 5.81 (5.80) | NR | 5.91 (4.84) | 117 | 5.73 (5.20) | NR | NR, 0.909
Tremont, 2015^*^,^375^; Fair | Caregiver | RMBPC Memory problems (total burden) (0–28) | IG1 | 6 | 8.25 (5.24) | 133 | 7.72 (5.28) | NR | 8.90 (5.82) | 117 | 8.33 (5.50) | NR | NR, 0.955
Tremont, 2015^*^,^375^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 6 | 38.61 (13.98) | 133 | 35.95 (14.34) | NR | 38.82 (14.63) | 117 | 37.17 (13.93) | NR | NR, 0.485
Wang, 2011^*^,^379^; Fair | Caregiver + patient | FCBI (0–96) | IG1 | 6 | 68.2 (11.9) | 40 | 55.2 (15.0) | NR | 68.8 (16.7) | 40 | 65.0 (18.1) | NR | NR, <0.001
Wright, 2001^383^; Fair | Caregiver | Caregiving Hassle Scale (0–123) | IG1 | 3 | 27.5^§^ (NR) | 68 | 23.4^§^ (NR) | NR | 28.7^§^ (NR) | 25 | 24.3^§^ (NR) | NR | NS
Wright, 2001^383^; Fair | Caregiver | Caregiving Hassle Scale (0–123) | IG1 | 6 | 27.5^§^ (NR) | 68 | 24.0^§^ (NR) | NR | 28.7^§^ (NR) | 25 | 24.2^§^ (NR) | NR | NS
Wright, 2001^383^; Fair | Caregiver | Caregiving Hassle Scale (0–123) | IG1 | 12 | 27.5^§^ (NR) | 68 | 21.9^§^ (NR) | NR | 28.7^§^ (NR) | 25 | 21.6^§^ (NR) | NR | NR, 0.98
Care/Case Management Interventions
Callahan, 2006^385^; Fair | Caregiver + patient | NPI-12 (0–60) | IG1 | 6 | 4.2 (5.6) | 84 | 4.4 (6.4) | NR | 6.5 (10.4) | 69 | 5.7 (7.2) | NR | Adj MD (95% CI)=−0.1 (−2.0, 1.8), 0.92
Callahan, 2006^385^; Fair | Caregiver + patient | NPI-12 (0–60) | IG1 | 12 | 4.2 (5.6) | 84 | 3.5 (5.8) | NR | 6.5 (10.4) | 69 | 7.7 (8.7) | NR | Adj MD (95% CI)=−2.2 (−4.2, −0.2), 0.03
Callahan, 2006^385^; Fair | Caregiver + patient | NPI-12 (0–60) | IG1 | 17 | 4.2 (5.6) | 84 | 4.6 (6.3) | NR | 6.5 (10.4) | 69 | 7.4 (9.7) | NR | Adj MD (95% CI)=−1.0 (−3.0, 1.0), 0.33
Chien, 2008^*^,^387^; Fair | Family | FCBI (0–96) | IG1 | 6 | 68.1 (14.9) | 44 | 56.7 (15.7) | NR | 67.8 (15.7) | 44 | 63.0 (15.1) | NR | NR
Chien, 2008^*^,^387^; Fair | Family | FCBI (0–96) | IG1 | 12 | 68.1 (14.9) | 44 | 48.3 (13.9) | NR | 67.8 (15.7) | 44 | 65.9 (16.3) | NR | F statistic=7.1, <0.001
Chien, 2011^*^,^386^; Good | Caregiver + patient | FCBI (0–96) | IG1 | 12 | 68.0 (14.6) | 46 | 48.1 (13.0) | NR | 66.9 (13.7) | 46 | 65.3 (15.3) | NR | MD (SE)=−17.2 (0.8), 0.01
Chien, 2011^*^,^386^; Good | Caregiver + patient | FCBI (0–96) | IG1 | 18 | 68.0 (14.6) | 45 | 45.5 (10.0) | NR | 66.9 (13.7) | 45 | 64.1 (11.4) | NR | MD (SE)=−18.6 (1.0), 0.01
Chu, 2000^388^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 3 | 15.6 (NR) | 32 | 17.8 (NR) | NR | 14.9 (NR) | 31 | 18.8 (NR) | NR | NS
Chu, 2000^388^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 6 | 15.6 (NR) | 22 | 10.7 (NR) | NR | 14.9 (NR) | 26 | 21.1 (NR) | NR | NR, <0.05
Chu, 2000^388^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 10 | 15.6 (NR) | 22 | 15.7 (NR) | NR | 14.9 (NR) | 26 | 20.2 (NR) | NR | NS
Chu, 2000^388^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 13 | 15.6 (NR) | 18 | 23.9 (NR) | NR | 14.9 (NR) | 19 | 21.4 (NR) | NR | NS
Chu, 2000^388^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 17 | 15.6 (NR) | 27 | 18.6 (NR) | NR | 14.9 (NR) | 22 | 17.2 (NR) | NR | NS
Chu, 2000^388^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 3 | 26.2 (NR) | 32 | 26.0 (NR) | NR | 26.2 (NR) | 31 | 27.5 (NR) | NR | NS
Chu, 2000^388^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 6 | 26.2 (NR) | 22 | 22.3 (NR) | NR | 26.2 (NR) | 26 | 33.5 (NR) | NR | NR, <0.05
Chu, 2000^388^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 10 | 26.2 (NR) | 22 | 25.3 (NR) | NR | 26.2 (NR) | 20 | 30.0 (NR) | NR | NS
Chu, 2000^388^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 13 | 26.2 (NR) | 16 | 28.3 (NR) | NR | 26.2 (NR) | 19 | 33.9 (NR) | NR | NS
Chu, 2000^388^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 17 | 26.2 (NR) | 27 | 27.1 (NR) | NR | 26.2 (NR) | 21 | 29.5 (NR) | NR | NS
Fortinsky, 2009^391^; Fair | Caregiver + patient | Zarit-22 (0–88) | IG1 | 12 | 30.42 (NR) | 44 | 26.18 (NR) | NR | 36.02 (NR) | 25 | 30.57 (NR) | NR | MD=0.73, NR
Jansen, 2011^392^; Fair | Caregiver | SPPIC (0–9) | IG1 | 6 | 3.9 (NR) | 54 | 3.8 (NR) | NR | 3.3 (NR) | 45 | 2.7 (NR) | NR | NS
Jansen, 2011^392^; Fair | Caregiver | SPPIC (0–9) | IG1 | 12 | 3.9 (NR) | 54 | 4.2 (NR) | NR | 3.3 (NR) | 45 | 3.3 (NR) | NR | F statistic=0.72, 0.49
Lam, 2010^393^; Fair | Caregiver + patient | Zarit-22 (0–88) | IG1 | 4 | 33.2 (17.8) | 57 | NR | 2.0^ǁ^ (−7.0, 9.5) | 32.3 (15.8) | 42 | NR | 1.5^ǁ^ (−7.0, 9.3) | NS
Lam, 2010^393^; Fair | Caregiver + patient | Zarit-22 (0–88) | IG1 | 12 | 33.2 (17.8) | 53 | NR | 5.0^ǁ^ (−10.5, 12.0) | 32.3 (15.8) | 39 | NR | 3.5^ǁ^ (−9.3, 12.3) | NS
Mavandadi, 2017^*^,^394^; Fair | Caregiver + patient | NPI-10 (0–50) | IG1 | 6 | 10.04 (0.55)^‡^ | 25 | 6.74 (0.72)^‡^ | NR | 9.17 (0.58)^‡^ | 31 | 9.67 (0.69)^‡^ | NR | Beta (SE)=−0.68 (0.26), 0.01
Mavandadi, 2017^*^,^394^; Fair | Caregiver + patient | RMBPC (total burden) (0–96) | IG1 | 6 | 18.59 (0.83)^‡^ | 25 | 13.71 (1.07)^‡^ | NR | 18.21 (0.86)^‡^ | 31 | 18.03 (1.03)^‡^ | NR | Beta (SE)=−0.80 (0.41), 0.05
Mavandadi, 2017^*^,^394^; Fair | Caregiver + patient | Zarit-12 (0–48) | IG1 | 6 | 14.89 (10.04) | 25 | NR | NR | 14.30 (9.17) | 31 | NR | NR | Beta (SE)=−0.05 (0.22), 0.82
Menn, 2012^396^; Fair | Caregiver + patient | BSFC (0–72) | IG1 | 22 | 22.1 (NR) | 53 | 27.8 (NR) | NR | 23.6 (NR) | 83 | 29.0 (NR) | NR | NS
Menn, 2012^396^; Fair | Caregiver + patient | BSFC (0–72) | IG2 | 22 | 24.5 (NR) | 60 | 29.1 (NR) | NR | 23.6 (NR) | 83 | 29.0 (NR) | NR | NS
Samus, 2014^*^,^397^; Fair | Caregiver + patient | Zarit-12 (0–44) | IG1 | 18 | 14.18 (0.89)^‡^ | 106 | 13.90 (0.99)^‡^ | NR | 14.51 (0.67)^‡^ | 183 | 16.14 (0.79)^‡^ | NR | MDC (95% CI)=−1.91 (−3.9, 0.5), 0.29
Thyrian, 2017^*^,^398^; Fair | Caregiver + patient | BIZA-D (NR) | IG1 | 12 | −0.14 (2.62) | 291 | −0.13 (2.63) | NR | −0.07 (2.57) | 116 | 0.40 (2.62) | NR | Beta (95% CI)=−0.50 (−1.09, 0.08), 0.045
Xiao, 2016^*^,^400^; Fair | Caregiver | NPI-10 (0–50) | IG1 | 6 | 10.8 (9.4) | 31 | 6.5 (6.7) | NR | 11.2 (9.3) | 30 | 11.9 (11.7) | NR | NR
Xiao, 2016^*^,^400^; Fair | Caregiver | NPI-10 (0–50) | IG1 | 12 | 10.8 (9.4) | 31 | 6.3 (6.6) | NR | 11.2 (9.3) | 30 | 13.1 (11.9) | NR | F statistic=4.97, 0.01
Other Interventions
Connell, 2009^402^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 6 | 14.7 (11.5) | 74 | 12.9 (10.9) | NR | 14.4 (9.1) | 63 | 13.4 (10.0) | NR | NR, <0.05
Connell, 2009^402^; Fair | Caregiver | RMBPC (total burden) (0–96) | IG1 | 12 | 14.7 (11.5) | 69 | 13.2 (12.8) | NR | 14.4 (9.1) | 61 | 13.4 (11.9) | NR | NS
Hirano, 2011^404^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 3 | 32.9 (18.2) | 17 | NR | −5.2 (2.1) | 38.5 (19.7) | 14 | NR | 0.07 (0.5) | NR
King, 2002^405^; Fair | Caregiver | RMBPC (total burden) (0–77) | IG1 | 12 | 24.6 (15.4) | 45 | 23.6 (15.4) | NR | 25.5 (10.3) | 40 | 23.0 (12.1) | NR | NS
King, 2002^405^; Fair | Caregiver | SCB objective (0–25) | IG1 | 12 | 11.5 (3.7) | 45 | 10.8 (3.6) | NR | 12.6 (4.0) | 40 | 11.8 (4.8) | NR | NR
King, 2002^405^; Fair | Caregiver | SCB subjective (25–100) | IG1 | 12 | 39.6 (9.4) | 45 | 35.7 (7.5) | NR | 43.7 (9.8) | 40 | 40.9 (12.8) | NR | NR
Logiudice, 1999^407^; Fair | Caregiver + patient | RMBPC (total burden) (0–96) | IG1 | 6 | 56.3 (58.0) | 20 | NR | 2.52 (NR) | 67.8 (45.0) | 14 | NR | 6.82 (NR) | MDC=0.30, NR
Logiudice, 1999^407^; Fair | Caregiver + patient | RMBPC (total burden) (0–96) | IG1 | 12 | 56.3 (58.0) | 15 | NR | 2.1 (NR) | 67.8 (45.0) | 12 | NR | −6.29 (NR) | MDC=0.70, NR
Logiudice, 1999^407^; Fair | Caregiver + patient | Zarit-22 (0–88) | IG1 | 6 | 39.0 (8.7) | 23 | NR | 0.16 (NR) | 42.7 (10.3) | 16 | NR | 4.21 (NR) | NR, 0.02
Logiudice, 1999^407^; Fair | Caregiver + patient | Zarit-22 (0–88) | IG1 | 12 | 39.0 (8.7) | 16 | NR | 0.77 (NR) | 42.7 (10.3) | 14 | NR | 3.11 (NR) | NR, 0.4
Prick, 2015^*^,^410^; Fair | Caregiver + patient | RMBPC (total burden) (0–100) | IG1 | 3 | 13.48 (9.21) | 57 | 13.06 (10.38) | NR | 13.76 (8.40) | 54 | 12.13 (8.55) | NR | Beta (95% CI)=0.00 (−0.29, 0.30), 0.98
Prick, 2015^*^,^410^; Fair | Caregiver + patient | RMBPC (total burden) (0–100) | IG1 | 6 | 13.48 (9.21) | 57 | 15.98 (11.11) | NR | 13.76 (8.40) | 54 | 11.71 (9.25) | NR | Beta (95% CI)=0.08 (−0.22, −0.37), 0.61
Prick, 2015^*^,^410^; Fair | Caregiver + patient | SPPIC (0–9) | IG1 | 3 | 5.53 (2.39) | 57 | 5.67 (2.36) | NR | 5.52 (2.37) | 54 | 5.85 (2.13) | NR | Beta (95% CI)=−0.19 (−0.72, 0.34), 0.49
Prick, 2015^*^,^410^; Fair | Caregiver + patient | SPPIC (0–9) | IG1 | 6 | 5.53 (2.39) | 57 | 5.69 (2.38) | NR | 5.52 (2.37) | 54 | 5.60 (2.13) | NR | Beta (95% CI)=−0.21 (−0.73, 0.31), 0.43
Winter, 2006^413^; Fair | Caregiver | Zarit-22 (0–88) | IG1 | 6 | 33.7 (14.5) | 53 | 31.66 (15.16) | NR | 35.0 (15.1) | 49 | 31.74 (17.29) | NR | MD=0.490, NR

* New study

† Higher values indicate better outcomes for all instruments

‡ Standard error

§ Least squares mean

ǁ Median change (IQR)

Abbreviations: Adj MD = adjusted mean difference; BIZA-D = Berlin Inventory of Caregivers’ Burden with Dementia; BL = baseline; CBI = Caregiver Burden Inventory; CG = control group; CI = confidence interval; FCBI = Family Caregiving Burden Inventory; FU = followup; IG = intervention group; Int arm = intervention arm; IQR = interquartile range; MD = mean difference; MDC = mean difference in change; mo. = months; NPI-10 = Neuropsychiatric Inventory-10 item; NPI-12 = Neuropsychiatric Inventory-12 item; NR = not reported; NS = not statistically significant; PAIS = Psychosocial Adjustment to Illness scale; RMBPC = Revised Memory and Behavior Checklist; SD = standard deviation; SE = standard error; SPPIC = Self-Perceived Pressure by Informal Care; Zarit-10 = Zarit Burden Interview-10 item; Zarit-22 = Zarit Burden Interview-22 item

Appendix H Table 2 Caregiver and Caregiver-Patient Dyad Interventions: Detailed Results for Caregiver Mental Health Outcomes, by Intervention Type

Author, year Quality | Audience | Symptom (Instrument, range, direction) | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Psychoeducation Interventions
Barnes, 2018^*^,^327^; Fair | Caregiver | Anx (HADS-A, 0–21, ↓) | IG1 | 3 | 8.1 (NR) | 27 | 7.8 (NR) | −0.3 (NR) | 7.9 (NR) | 25 | 8.4 (NR) | 0.5 (NR) | NR, 0.100
Barnes, 2018^*^,^327^; Fair | Caregiver | Dep (HADS-D, 0–21, ↓) | IG1 | 3 | 5.8 (NR) | 27 | 5.9 (NR) | 0.1 (NR) | 5.4 (NR) | 25 | 6.2 (NR) | 0.8 (NR) | NR, 0.122
Barnes, 2018^*^,^327^; Fair | Caregiver | Psych Health (HADS-T, 0–42, ↓) | IG1 | 3 | 13.9 (NR) | 27 | 13.7 (NR) | −0.2 (NR) | 13.3 (NR) | 25 | 14.6 (NR) | 1.3 (NR) | NR, 0.133
Belle, 2006^328^; Fair | Caregiver | Dep (CES-D, D) | IG1 | 6 | NA | 293 | 37 (12.6) ^†^ | NR | NA | 286 | 65 (22.7)^†^ | NR | NR, 0.0014
Berwig, 2017^*^,^329^; Fair | Caregiver | Anx (PHQ-4-Anx subscale, 0.6, ↓) | IG1 | 6 | 2.2 (1.6) | 41 | NR | −0.342 (1.995) | 1.8 (1.9) | 40 | NR | −0.025 (1.981) | ES=0.159, 0.476
Berwig, 2017^*^,^329^; Fair | Caregiver | Anx (PHQ-4-Anx subscale, 0.6, ↓) | IG1 | 9 | 2.2 (1.6) | 31 | NR | −0.194 (1.815) | 1.8 (1.9) | 31 | NR | 0.548 (2.743) | ES=0.326, 0.239
Berwig, 2017^*^,^329^; Fair | Caregiver | Dep (PHQ-4-Dep subscale, 0.6, ↓) | IG1 | 6 | 2.0 (1.4) | 41 | NR | −0.317 (1.439) | 1.4 (1.5) | 40 | NR | 0.075 (1.403) | ES=0.276, 0.218
Berwig, 2017^*^,^329^; Fair | Caregiver | Dep (PHQ-4-Dep subscale, 0.6, ↓) | IG1 | 9 | 2.0 (1.4) | 31 | NR | −0.097 (1.446) | 1.4 (1.5) | 31 | NR | 0.129 (1.432) | ES=0.157, 0.214
Brennan, 1995^330^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 12 | 21.2 (8.1) | 47 | 18.9 (11.0) | NR | 15.6 (10.6) | 49 | 15.7 (10.5) | NR | NR, 0.61
Bruvik, 2013^*^,^331^; Good | Caregiver + patient | Dep (GDS, 0–30, ↓) | IG1 | 12 | 7.3 (6.5) | 93 | 7.3 (6.8) | NR | 5.6 (5.5) | 102 | 5.6 (6.0) | NR | NR, 0.8236
Burgio, 2003^332^; Fair | Caregiver | Anx (STPI-Anx subscale, 10–40, ↓) | IG1 (Black) | 6 | 21.68 (7.92) | 25 | 19.16 (8.01) | NR | 19.91 (7.17) | 23 | 19.04 (6.79) | NR | NR
Burgio, 2003^332^; Fair | Caregiver | Anx (STPI-Anx subscale, 10–40, ↓) | IG1 (White) | 6 | 22.17 (5.93) | 36 | 22.61 (7.64) | NR | 18.03 (6.24) | 34 | 18.12 (7.36) | NR | NR
Burgio, 2003^332^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 15.7 (9.4) | 60 | 11.4 (1.2) | NR | 11.4 (9.9) | 61 | 12.1 (9.9) | NR | NR, 0.35
Chang, 1999^333^; Fair | Caregiver | Anx (BSI-A, 0–24, ↓) | IG1 | 3 | 0.68 (0.55) | 31 | 0.57 (0.58) | NR | 0.91 (0.63) | 34 | 0.78 (0.74) | NR | NR
Chang, 1999^333^; Fair | Caregiver | Dep (BSI-D, 0–4, ↓) | IG1 | 3 | 0.73 (0.66) | 31 | 0.60 (0.71) | NR | 0.74 (0.74) | 34 | 0.95 (0.85) | NR | NR
Chu, 2011^334^; Fair | Caregiver | Dep (BDI-II, 0–63, ↓) | IG1 | 3 | 9.3 (NR) | 30 | 5.77 (NR) | NR | 11.36 (NR) | 30 | 10.53 (NR) | NR | NR, 0.05
Chu, 2011^334^; Fair | Caregiver | Dep (BDI-II, 0–63, ↓) | IG1 | 4 | 9.3 (NR) | 30 | 5.31 (NR) | NR | 11.36 (NR) | 30 | 10.96 (NR) | NR | NR, <0.01
Coon, 2003^335^; Fair | Caregiver | Dep (MAACL Dep subscale, NR, ↓) | IG1 | 6 | 17.8 (1.4) | 45 | 15.4 (1.3) | NR | 14.6 (1.3) | 44 | 16.5 (1.3) | NR | NR, NR
Coon, 2003^335^; Fair | Caregiver | Dep (MAACL Dep subscale, NR, ↓) | IG2 | 6 | 16.4 (1.3) | 41 | 15.0 (1.3) | NR | 14.6 (1.3) | 44 | 16.5 (1.3) | NR | NR, NR
Cristancho-Lacroix, 2015^*^,^336^; Fair | Caregiver | Dep (BDI-II, 0–63, ↓) | IG1 | 3 | 11.2 (10.1) | 25 | 11.5 (9.2) | 0.3 (4.6) | 9.0 (7.4) | 24 | 8.9 (6.5) | −0.1 (2.7) | MDC (95% CI)=NR (NR, NR), 0.56
Cristancho-Lacroix, 2015^*^,^336^; Fair | Caregiver | Dep (BDI-II, 0–63, ↓) | IG1 | 6 | 11.2 (10.1) | 25 | 12.4 (11.6) | NR | 9.0 (7.4) | 24 | 8.8 (7.2) | NR | NS
Cristancho-Lacroix, 2015^*^,^336^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–56, ↓) | IG1 | 3 | 24.2 (9.0) | 25 | 23.7 (9.2) | −0.5 (8.0) | 24.5 (6.7) | 24 | 23.8 (6.2) | −0.7 (4.5) | MDC (95% CI)=NR (NR, NR), 0.98
Cristancho-Lacroix, 2015^*^,^336^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–56, ↓) | IG1 | 6 | 24.2 (9.0) | 25 | 25.0 (9.9) | NR | 24.5 (6.7) | 24 | 23.8 (6.9) | NR | NS
De Rotrou, 2011^337^; Fair | Caregiver | Dep (MADRS, 0–60, ↓) | IG1 | 3 | 9.0 (7.5) | 63 | 8.2 (7.5) | NR | 10.2 (9.2) | 64 | 10.1 (9.9) | NR | NR, 0.21
De Rotrou, 2011^337^; Fair | Caregiver | Dep (MADRS, 0–60, ↓) | IG1 | 6 | 9.0 (7.5) | 56 | 8.9 (7.8) | NR | 10.2 (9.2) | 57 | 11.4 (10.3) | NR | NR, 0.14
Finkel, 2007^340^; Fair | Caregiver | Dep (CES-D-10, 0–30, ↓) | IG1 | 6 | 7.2 (NR) | 17 | 4.3 (NR) | NR | 7.2 (NR) | 19 | 6.0 (NR) | NR | Cohen’s d=0.42, 0.099
Gallagher-Thompson, 2003^342^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (Hispanic) | 6 | 16.74 (12.53) | 38 | 15.27 (1.66) | NR | 26.67 (14.75) | 17 | 17.10 (2.55) | NR | NR
Gallagher-Thompson, 2003^342^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (White) | 6 | 18.84 (11.48) | 53 | 13.50 (1.08) | NR | 17.13 (13.50) | 24 | 15.44 (1.60) | NR | NR
Gallagher-Thompson, 2008^343^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (Hispanic) | 6 | 14.83 (12.47) | 47 | 10.26 (9.98) | NR | 15.64 (13.60) | 42 | 12.83 (10.31) | NR | NR
Gallagher-Thompson, 2008^343^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (White) | 6 | 15.14 (10.46) | 50 | 11.86 (9.90) | NR | 13.39 (9.42) | 45 | 12.82 (9.59) | NR | NR
Gallagher-Thompson, 2008^343^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–40, ↓) | IG1 (Hispanic) | 6 | 18.02 (7.91) | 47 | 15.23 (7.24) | NR | 17.00 (7.79) | 42 | 16.14 (6.97) | NR | NR
Gallagher-Thompson, 2008^343^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–40, ↓) | IG1 (White) | 6 | 18.92 (6.98) | 50 | 15.97 (6.49) | NR | 18.16 (6.67) | 45 | 17.04 (6.17) | NR | NR
Gallagher-Thompson, 2010^*^,^344^; Good | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 4 | 13.03 (11.85) | 36 | 10.78 (8.41) | NR | 14.74 (12.51) | 34 | 13.94 (10.31) | NR | Beta=−0.118, 0.164
Garand, 2014^*^,^345^; Fair | Caregiver | Anx (STAI-State, 20–80, ↓) | IG1 (AD patient) | 3 | 31.3 (2.9)^‡^ | 13 | 27.1 (3.1)^‡^ | NR | 32.3 (2.7)^‡^ | 17 | 39.5 (2.6)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Anx (STAI-State, 20–80, ↓) | IG1 (AD patient) | 6 | 31.3 (2.9)^‡^ | 13 | 27.1 (2.3)^‡^ | NR | 32.3 (2.7)^‡^ | 17 | 43.3 (2.6)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Anx (STAI-State, 20–80, ↓) | IG1 (AD patient) | 12 | 31.3 (2.9)^‡^ | 13 | 32.5 (3.0)^‡^ | NR | 32.3 (2.7)^‡^ | 17 | 40.5 (2.8)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Anx (STAI-State, 20–80, ↓) | IG1 (MCI patient) | 3 | 26.3 (2.2)^‡^ | 23 | 27.3 (2.2)^‡^ | NR | 27.1 (2.7)^‡^ | 20 | 28.2 (2.1)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Anx (STAI-State, 20–80, ↓) | IG1 (MCI patient) | 6 | 26.3 (2.2)^‡^ | 23 | 26.0 (2.0)^‡^ | NR | 27.1 (2.7)^‡^ | 20 | 27.3 (2.4)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Anx (STAI-State, 20–80, ↓) | IG1 (MCI patient) | 12 | 26.3 (2.2)^‡^ | 23 | 28.5 (2.2)^‡^ | NR | 27.1 (2.7)^‡^ | 20 | 29.9 (2.3)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (AD patient) | 3 | 13.3 (1.5)^‡^ | 13 | 10.8 (0.7)^‡^ | NR | 16.4 (2.5)^‡^ | 17 | 18.1 (4.0)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (AD patient) | 6 | 13.3 (1.5)^‡^ | 13 | 7.4 (0.6)^‡^ | NR | 16.4 (2.5)^‡^ | 17 | 19.4 (3.9)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (AD patient) | 12 | 13.3 (1.5)^‡^ | 13 | 7.9 (1.7)^‡^ | NR | 16.4 (2.5)^‡^ | 17 | 16.6 (2.0)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (MCI patient) | 3 | 6.1 (0.4)^‡^ | 23 | 6.6 (0.4)^‡^ | NR | 7.1 (0.6)^‡^ | 20 | 8.0 (0.4)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (MCI patient) | 6 | 6.1 (0.4)^‡^ | 23 | 6.3 (0.5)^‡^ | NR | 7.1 (0.6)^‡^ | 20 | 8.1 (2.9)^‡^ | NR | NR
Garand, 2014^*^,^345^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 (MCI patient) | 12 | 6.1 (0.4)^‡^ | 23 | 4.9 (0.3)^‡^ | NR | 7.1 (0.6)^‡^ | 20 | 11.5 (1.8)^‡^ | NR | NR
Gaugler, 2013^*^,^346^; Fair | Whole family | Dep (GDS, 0–30, ↓) | IG1 | 36 | 6.11 (5.39) | 54 | NR | NR | 5.48 (4.59) | 53 | NR | NR | Beta (SE)= 0.07 (0.51), NS
Gitlin, 2003^349^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 15.25 (12.17) | 116 | 15.06 (0.66) | NR | 14.85 (10.73) | 117 | 15.05 (0.66) | NR | NR, 0.99
Gitlin, 2008^348^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 4 | 14.6 (11.0) | 27 | 13.1 (9.4) | NR | 13.2 (9.6) | 29 | 14.3 (10.2) | NR | Adj MD (95% CI)=−0.74 (−4.31, 2.82), 0.68
Gitlin, 2010^350^; Fair | Caregiver | Dep (CES-D, D) | IG1 | 4 | NA | 117 | 62 (53.0)^§^ | NR | NA | 122 | 83 (68.0)^§^ | NR | NR, 0.02
Graff, 2006^351^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 3 | 11.7 (8.3) | 67 | 5.4 (4.5) | NR | 11.4 (7.2) | 65 | 13.1 (9.1) | NR | Adj MD (95% CI)=−8.4 (−11.0, −5.8), <0.0001
Graff, 2006^351^; Fair | Caregiver + patient | Psych Health (GHQ-12, 0–36, ↓) | IG1 | 3 | 12.0 (4.9) | 67 | 7.1 (3.5) | NR | 11.3 (4.0) | 65 | 12.1 (5.0) | NR | Adj MD (95% CI)=−4.9 (−6.6, −3.3), <0.0001
Hebert, 2003^352^; Fair | Caregiver | Anx (STAI-State, 20–80, ↓) | IG1 | 4 | 41.01 (12.96) | 60 | 39.75 (13.24) | −1.27 (16.47) | 45.46 (14.82) | 56 | 43.17 (14.02) | −1.64 (14.49) | NR, 0.39
Hebert, 2003^352^; Fair | Caregiver | Psych Health (PSI, 14–56, ↓) | IG1 | 4 | 26.17 (6.94) | 60 | 25.01 (6.92) | −1.16 (7.98) | 26.45 (8.12) | 56 | 26.89 (8.16) | 0.65 (6.03) | NR, 0.13
Joling, 2012^354^; Fair | Whole family | Anx (HADS-A, 0–21, ↓) | IG1 | 6 | 5.6 (NR) | 96 | 5.6 (NR) | NR | 5.3 (NR) | 96 | 5.7 (NR) | NR | NR
Joling, 2012^354^; Fair | Whole family | Anx (HADS-A, 0–21, ↓) | IG1 | 12 | 5.6 (NR) | 96 | 5.5 (NR) | NR | 5.3 (NR) | 96 | 5.8 (NR) | NR | ES (95% CI)=−0.6 (−1.6, 0.5), 0.3
Joling, 2012^354^; Fair | Whole family | Anx (HADS-A, D) | IG1 | 12 | NA | 96 | 28 (29.2)^ǁ^ | NR | NA | 96 | 27 (28.1)^ǁ^ | NR | HR (95% CI)=0.89 (0.51, 1.56)
Joling, 2012^354^; Fair | Whole family | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 11.4 (NR) | 96 | 12.4 (NR) | NR | 11.9 (NR) | 96 | 13.0 (NR) | NR | NR
Joling, 2012^354^; Fair | Whole family | Dep (CES-D, 0–60, ↓) | IG1 | 12 | 11.4 (NR) | 96 | 12.9 (NR) | NR | 11.9 (NR) | 96 | 14.8 (NR) | NR | ES (95% CI)=−1.4 (−3.9, 1.1), 0.27
Joling, 2012^354^; Fair | Whole family | Dep (CES-D, D) | IG1 | 12 | NA | 96 | 28 (29.2)^¶^ | NR | NA | 96 | 19 (19.8)^¶^ | NR | IRR (95% CI)=1.21 (0.80, 1.84), NR
Judge, 2013^*^,^355^; Fair | Caregiver + patient | Dep (CES-D, 0–20, ↓) | IG1 | 3 | 4.47 (3.60) | 59 | 3.75 (3.09) | NR | 4.58 (3.63) | 59 | 4.64 (3.19) | NR | Beta=−0.17, 0.04
Kurz, 2010^357^; Fair | Caregiver | Dep (CES-D, D) | IG1 | 6 | NA | 55 | NR | NR | NA | 53 | NR | NR | OR (95% CI)=0.15 (0.04, 0.65), <0.013^#^
Livingston, 2013^*^,^360^; Good | Caregiver | Anx (HADS-A, 0–21, ↓) | IG1 | 4 | 8.1 (4.4) | 150 | 7.5 (4.2) | NR | 9.3 (4.3) | 75 | 8.6 (4.2) | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Anx (HADS-A, 0–21, ↓) | IG1 | 8 | 8.1 (4.4) | 133 | 7.6 (4.4) | NR | 9.3 (4.3) | 71 | 8.8 (4.4) | NR | Adj MD (95% CI)=−0.91 (−1.76, −0.07), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Anx (HADS-A, 0–21, ↓) | IG1 | 12 | 8.1 (4.4) | 138 | 7.5 (4.4) | NR | 9.3 (4.3) | 67 | 8.8 (5.1) | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Anx (HADS-A, 0–21, ↓) | IG1 | 24 | 8.1 (4.4) | 132 | 8.1 (4.9) | NR | 9.3 (4.3) | 64 | 9.2 (5.3) | NR | Adj MD (95% CI)=−1.16 (−2.15, −0.18), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Anx (HADS-A, D) | IG1 | 4 | 85 (49.4)^**^ | 150 | 54 (36.0)^**^ | NR | 48 (55.2)^**^ | 75 | 36 (48.0)^**^ | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Anx (HADS-A, D) | IG1 | 8 | 85 (49.4)^**^ | 133 | 53 (39.8)^**^ | NR | 48 (55.2)^**^ | 71 | 33 (46.5)^**^ | NR | OR (95% CI)=0.30 (0.08, 1.05), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Anx (HADS-A, D) | IG1 | 12 | 85 (49.4)^**^ | 138 | 54 (39.1)^**^ | NR | 48 (55.2)^**^ | 67 | 33 (49.3)^**^ | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Anx (HADS-A, D) | IG1 | 24 | 85 (49.4)^**^ | 132 | 57 (43.2)^**^ | NR | 48 (55.2)^**^ | 64 | 32 (50.0)^**^ | NR | OR (95% CI)=0.57 (0.26, 1.24), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Dep (HADS-D, 0–21, ↓) | IG1 | 4 | 5.4 (3.8) | 150 | 4.9 (3.9) | NR | 5.5 (3.9) | 75 | 5.7 (4.0) | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Dep (HADS-D, 0–21, ↓) | IG1 | 8 | 5.4 (3.8) | 133 | 5.2 (4.0) | NR | 5.5 (3.9) | 71 | 6.1 (4.2) | NR | Adj MD (95% CI)=−0.91 (−1.71, −0.10), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Dep (HADS-D, 0–21, ↓) | IG1 | 12 | 5.4 (3.8) | 138 | 5.0 (4.2) | NR | 5.5 (3.9) | 67 | 5.9 (4.3) | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Dep (HADS-D, 0–21, ↓) | IG1 | 24 | 5.4 (3.8) | 132 | 5.5 (4.2) | NR | 5.5 (3.9) | 64 | 6.3 (4.9) | NR | Adj MD (95% CI)=−1.45 (−2.32, −0.57), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Dep (HADS-D, D) | IG1 | 4 | 36 (20.9)^††^ | 150 | 25 (16.7)^††^ | NR | 17 (19.5)^††^ | 75 | 18 (24.0)^††^ | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Dep (HADS-D, D) | IG1 | 8 | 36 (20.9)^††^ | 133 | 28 (21.1)^††^ | NR | 17 (19.5)^††^ | 71 | 23 (32.4)^††^ | NR | OR (95% CI)=0.24 (0.07, 0.76), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Dep (HADS-D, D) | IG1 | 12 | 36 (20.9)^††^ | 138 | 24 (17.4)^††^ | NR | 17 (19.5)^††^ | 67 | 18 (26.9)^††^ | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Dep (HADS-D, D) | IG1 | 24 | 36 (20.9)^††^ | 132 | 30 (22.7)^††^ | NR | 17 (19.5)^††^ | 64 | 19 (29.7)^††^ | NR | OR (95% CI)=0.14 (0.04, 0.53), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Psych Health (HADS-T, 0–42, ↓) | IG1 | 4 | 13.5 (7.3) | 150 | 12.4 (7.4) | NR | 14.8 (7.4) | 75 | 14.3 (7.4) | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Psych Health (HADS-T, 0–42, ↓) | IG1 | 8 | 13.5 (7.3) | 133 | 12.9 (7.9) | NR | 14.8 (7.4) | 71 | 14.9 (8.0) | NR | Adj MD (95% CI)=−1.80 (−3.29, −0.31), 0.02
Livingston, 2013^*^,^360^; Good | Caregiver | Psych Health (HADS-T, 0–42, ↓) | IG1 | 12 | 13.5 (7.3) | 138 | 12.5 (7.9) | NR | 14.8 (7.4) | 64 | 14.6 (8.9) | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Psych Health (HADS-T, 0–42, ↓) | IG1 | 24 | 13.5 (7.3) | 132 | 13.6 (8.3) | NR | 14.8 (7.4) | 64 | 15.5 (9.5) | NR | Adj MD (95% CI)=−2.58 (−4.26, −0.90), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Psych Health (HSQ-12, 0–100, ↑) | IG1 | 4 | 58.3 (22.4) | 144 | 62.7 (20.8) | NR | 58.2 (21.7) | 72 | 58.4 (18.0) | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Psych Health (HSQ-12, 0–100, ↑) | IG1 | 8 | 58.3 (22.4) | 122 | 58.6 (22.0) | NR | 58.2 (21.7) | 66 | 58.2 (19.2) | NR | Adj MD (95% CI)=4.09 (0.34, 7.83), NR
Livingston, 2013^*^,^360^; Good | Caregiver | Psych Health (HSQ-12, 0–100, ↑) | IG1 | 12 | 58.3 (22.4) | 121 | 61.9 (20.6) | NR | 58.2 (21.7) | 61 | 56.2 (22.5) | NR | NR
Livingston, 2013^*^,^360^; Good | Caregiver | Psych Health (HSQ-12, 0–100, ↑) | IG1 | 24 | 58.3 (22.4) | 113 | 60.2 (19.8) | NR | 58.2 (21.7) | 55 | 55.0 (21.2) | NR | Adj MD (95% CI)=7.47 (2.87, 12.08),
Losada, 2010^361^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 3 | 19.5 (12.7) | 68 | 14.9 (9.7) | NR | 17.6 (12.7) | 50 | 17.0 (12.0) | NR | Adj MD (SD)=−3.2 (NR), 0.03
Mariott, 2000^362^; Fair | Caregiver | Dep (BDI, 0–63, ↓) | IG1 | 8 | 11.5 (9.5) | 13 | 7.2 (7.5) | NR | 9.9 (5.5) | 14 | 10.9 (5.6) | NR | NR, <0.01
Mariott, 2000^362^; Fair | Caregiver | Dep (BDI, 0–63, ↓) | IG1 | 12 | 11.5 (9.5) | 13 | 6.3 (5.7) | NR | 9.9 (5.5) | 14 | 11.1 (6.4) | NR | NR, 0.001
Mariott, 2000^362^; Fair | Caregiver | Psych Health (GHQ-28, 0–84, ↓) | IG1 | 8 | 9.5 (4.8) | 13 | 5.1 (5.5) | NR | 9.6 (3.8) | 14 | 12.4 (6.4) | NR | NR, <0.05
Mariott, 2000^362^; Fair | Caregiver | Psych Health (GHQ-28, 0–84, ↓) | IG1 | 12 | 9.5 (4.8) | 13 | 3.2 (4.2) | NR | 9.6 (3.8) | 14 | 10.7 (5.5) | NR | NR, <0.05
Martin-Carrasco, 2009^364^; Fair | Caregiver | Psych Health (GHQ-28, 0–84, ↓) | IG1 | 4 | 8.8 (7.5) | 44 | 4.7 (7.2) | NR | 6.8 (5.5) | 38 | 6.3 (6.6) | NR | NR, 0.03
Martin-Carrasco, 2009^364^; Fair | Caregiver | Psych Health (GHQ-28, 0–84, ↓) | IG1 | 10 | 8.8 (7.5) | 44 | 2.2 (4.0) | NR | 6.8 (5.5) | 38 | 7.8 (7.6) | NR | NR, 0.0004
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | Psych Health (GHQ-28, 0–84, ↓) | IG1 | 4 | 28.2 (12.5) | 115 | NR | −4.76 (12.6) | 27.7 (12.7) | 123 | NR | −2.42 (10.3) | MDC (95% CI)=−2.34 (−5.27, 0.59), NS
Martin-Cook, 2005^365^; Fair | Caregiver + patient | Dep (GDS-15, 0–15, ↓) | IG1 | 4 | 1.79 (1.56) | 23 | 1.58 (0.46) | NR | 3.00 (3.26) | 24 | 2.68 (0.48) | NR | NR
Martindale-Adams, 2013^*^,^366^; Fair | Caregiver | Dep (CES-D-10, 0–30, ↓) | IG1 | 6 | 10.8 (6.2) | 77 | 10.0 (6.5) | NR | 10.4 (6.8) | 77 | 10.2 (7.1) | NR | NR
Martindale-Adams, 2013^*^,^366^; Fair | Caregiver | Dep (CES-D-10, 0–30, ↓) | IG1 | 12 | 10.8 (6.2) | 77 | 9.4 (5.7) | NR | 10.4 (6.8) | 77 | 9.4 (6.6) | NR | Cohen’s d=0.04, 0.802
Mittelman, 2004^*^,^367^; Fair | Whole family | Dep (GDS, 0–30, ↓) | IG1 | 12 | 8.9 (5.7) | 203 | NR | −1.1 (5.0) | 10.6 (7.2) | 203 | NR | 0.3 (6.0) | logBeta (SE)= −1.41 (0.409), 0.006
Mittelman, 2004^*^,^367^; Fair | Whole family | Dep (GDS, 0–30, ↓) | IG1 | 60 | 8.9 (5.7) | 203 | NR | NR | 10.6 (7.2) | 203 | NR | NR | Beta (SE)= −1.047 (0.473), 0.03
Mittelman, 2004^*^,^367^; Fair | Whole family | Dep (GDS, D) | IG1 | 12 | 81 (39.9)^‡‡^ | 203 | 60 (29.6)^‡‡^ | NR | 93 (45.8)^‡‡^ | 203 | 92 (45.3)^‡‡^ | NR | NR
Mittelman, 2004^*^,^367^; Fair | Whole family | Dep (GDS, D) | IG1 | 36 | 81 (39.9) | 203 | 53 (26.1) | NR | 93 (45.8) | 203 | 65 (32.0) | NR | NR
Mittelman, 2004^*^,^367^; Fair | Whole family | Dep (GDS, D) | IG1 | 60 | 81 (39.9) | 203 | 55 (27.1) | NR | 93 (45.8) | 203 | 61 (30.0) | NR | NR
Nunez-Naveira, 2016^*^,^368^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 3 | 19.40 (9.03) | 30 | 17.03 (7.07) | NR | 21.42 (8.64) | 31 | 20.77 (9.02) | NR | NR
Ostwald, 1999^369^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 3 | 13.1 (8.2) | 51 | 17.2 (4.1) | NR | 14.7 (7.6) | 30 | 18.0 (4.8) | NR | NR, NR
Ostwald, 1999^369^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 5 | 13.1 (8.2) | 60 | 12.0 (7.7) | NR | 14.7 (7.6) | 34 | 16.1 (9.1) | NR | NR, 0.04
Spaulding-Wilson, 2018^*^,^372^; Fair | Caregiver | Anx (BAI, 0–63, ↓) | IG1 | 6 | 8.1 (8.0) | 54 | NR | NR | 7.7 (7.2) | 41 | NR | NR | Beta (SE)=−0.154 (0.39), 0.693
Spaulding-Wilson, 2018^*^,^372^; Fair | Caregiver | Dep (BDI-II, 0–63, ↓) | IG1 | 6 | 11.8 (7.7) | 54 | NR | NR | 11.7 (7.1) | 41 | NR | NR | Beta (SE)=−0.414 (0.37), 0.269
Spaulding-Wilson, 2018^*^,^372^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–48, ↓) | IG1 | 6 | 16.0 (6.5) | 54 | NR | NR | 16.3 (5.6) | 41 | NR | NR | Beta (SE)=−0.716 (0.28), 0.010
Schoenmakers, 2010^371^ | Caregiver | Dep (BDI, D) | IG1 | NR | NA | 23 | NR | NR | NR | 23 | NR | NR | OR (95% CI)=0.16 (0.03, 0.86), NR^§§^
Steffen, 2016^*^,^373^; Good | Caregiver | Anx (MAACL Anx, 0–21, ↓) | IG1 | 3 | 4.8 (2.3) | 28 | 3.5 (2.2) | NR | 4.6 (2.3) | 38 | 5.0 (2.7) | NR | Cohen’s d=0.63, ≤0.05
Steffen, 2016^*^,^373^; Good | Caregiver | Anx (MAACL Anx, 0–21, ↓) | IG1 | 9 | 4.8 (2.3) | 22 | 4.4 (2.6) | NR | 4.6 (2.3) | 30 | 4.2 (2.6) | NR | NR
Steffen, 2016^*^,^373^; Good | Caregiver | Dep (BDI-II, 0–63, ↓) | IG1 | 3 | 15.4 (0) | 28 | 9.8 (1.3) | NR | 15.4 (0) | 38 | 13.2 (1.1) | NR | Cohen’s d=0.50, ≤0.05
Steffen, 2016^*^,^373^; Good | Caregiver | Dep (BDI-II, D) | IG1 | 3 | NA | 28 | 20 (71.4)^ǁǁ^ | NR | NA | 38 | 16 (42.1)^ǁǁ^ | NR | NR, ≤0.05
Steffen, 2016^*^,^373^; Good | Caregiver | Dep (BDI-II, 0–63, ↓) | IG1 | 9 | 15.4 (0) | 22 | 10.3 (1.3) | NR | 15.4 (0) | 30 | 9.4 (1.1) | NR | NR, 0.61
Steffen, 2016^*^,^373^; Good | Caregiver | Psych Health (NAS, 10–50, ↓) | IG1 | 9 | 24.5 (6.9) | 22 | 20.1 (7.3) | NR | 24.1 (7.3) | 30 | 21.7 (7.6) | NR | NR, 0.89
Steffen, 2016^*^,^373^; Good | Caregiver | Psych Health (NAS, 10–50, ↓) | IG1 | 3 | 24.5 (6.9) | 28 | 17.6 (4.4) | NR | 24.1 (7.3) | 38 | 22.0 (7.0) | NR | Cohen’s d=0.66, ≤0.05
Teri, 2005^374^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 14.8 (9.1) | 32 | 12.5 (7.7) | NR | 13.2 (8.5) | 34 | 15.8 (10.5) | NR | Adj MD (95% CI)=−2.3 (−6.0, 0.0),
Teri, 2005^374^; Fair | Caregiver | Dep (HDRS, 0–52, ↓) | IG1 | 6 | 6.9 (4.1) | 32 | 6.7 (3.9) | NR | 7.6 (5.0) | 34 | 8.5 (5.7) | NR | Adj MD (95% CI)=−1.2 (−2.4, −0.0),
Tremont, 2015^*^,^375^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 17.04 (10.22) | 133 | 14.15 (10.00) | NR | 15.19 (9.98) | 117 | 15.62 (10.18) | NR | NR, 0.003
Ulstein, 2007^376^; Fair | Caregiver | Perc Stress (RSS, 0–60, ↓) | IG1 | 4 | 22.0 (10.3) | 87 | NR | −0.8 (−2.6, 1.0)^¶¶^ | 23.2 (10.8) | 84 | NR | −0.7 (−2.4, 0.9)^¶¶^ | MDC (95% CI)=−0.1 (−2.5, 2.3), 0.94
Ulstein, 2007^376^; Fair | Caregiver | Perc Stress (RSS, 0–60, ↓) | IG1 | 12 | 22.0 (10.3) | 87 | NR | −2.4 (−4.7, −0.19)^¶¶^ | 23.2 (10.8) | 84 | NR | −1.2 (−3.2, 0.8)^¶¶^ | MDC (95% CI)=−1.2 (−4.2, 1.8), 0.42
Voigt-Radloff, 2011^377^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 12.1 (7.7) | 52 | 10.0 (7.9) | NR | 11.3 (5.9) | 46 | 10.0 (6.9) | NR | MD (95% CI)=0.0 (−3.0, 3.0), NS
Voigt-Radloff, 2011^377^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 12 | 12.1 (7.7) | 52 | 14.3 (10.3) | NR | 11.3 (5.9) | 46 | 12.9 (7.7) | NR | MD (95% CI)=−1.4 (−5.1, 2.3), NS
Waldorff, 2012^378^; Good | Caregiver + patient | Dep (GDS, 0–30, ↓) | IG1 | 6 | 4.74 (5.16) | 141 | 4.97 (5.06) | 0.43 (3.51) | 4.71 (5.02) | 150 | 5.38 (5.77) | 0.81 (3.91) | MDC (95% CI)=−0.39 (−0.72, −0.07), 0.02
Waldorff, 2012^378^; Good | Caregiver + patient | Dep (GDS, 0–30, ↓) | IG1 | 12 | 4.74 (5.16) | 128 | 5.64 (5.45) | 1.16 (4.59) | 4.71 (5.02) | 143 | 4.82 (5.70) | 0.20 (4.27) | MDC (95% CI)=0.91 (−0.21, 2.03), 0.11
Waldorff, 2012^378^; Good | Caregiver + patient | Dep (GDS, 0–30, ↓) | IG1 | 36 | 4.74 (5.16) | 163 | 5.83 (NR) | 0.47 (−0.58, 1.52)^¶¶^ | 4.71 (5.02) | 167 | 4.98 (NR) | −0.33 (−1.39, 0.72)^¶¶^ | NR, 0.29
Williams, 2010^380^; Fair | Caregiver | Anx (STAI-Trait, 20–80, ↓) | IG1 | 3 | 41.6 (10.3) | 50 | 37.0 (NR) | NR | 38.4 (11.1) | 53 | 38.8 (NR) | NR | NS
Williams, 2010^380^; Fair | Caregiver | Anx (STAI-Trait, 20–80, ↓) | IG1 | 6 | 41.6 (10.3) | 48 | 35.1 (NR) | NR | 38.4 (11.1) | 51 | 38.7 (NR) | NR | NS
Williams, 2010^380^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 3 | 18.7 (10.6) | 50 | 12.9 (NR) | NR | 14.4 (9.6) | 53 | 14.5 (NR) | NR | NS
Williams, 2010^380^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 18.7 (10.6) | 48 | 11.8 (NR) | NR | 14.4 (9.6) | 51 | 15.4 (NR) | NR | NS
Williams, 2010^380^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–40, ↓) | IG1 | 3 | 21.5 (6.7) | 50 | 16.5 (NR) | NR | 19.1 (7.2) | 53 | 17.8 (NR) | NR | NS
Williams, 2010^380^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–40, ↓) | IG1 | 6 | 21.5 (6.7) | 48 | 15.4 (NR) | NR | 19.1 (7.2) | 51 | 18.1 (NR) | NR | NS
Wilz, 2016^*^,^381^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 3 | 16.89 (9.14) | 102 | 15.12 (10.08) | NR | 18.51 (8.79) | 44 | 17.52 (9.96) | NR | MD (95% CI)=−0.99 (−4.05, 2.05), 0.815
Wilz, 2016^*^,^381^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 16.89 (9.14) | 98 | 14.56 (9.61) | NR | 18.51 (8.79) | 39 | 17.33 (11.37) | NR | MD (95% CI)=0.06 (−5.09, 1.92), 0.624
Wilz, 2018^*^,^382^; Good | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 21.73 (9.66) | 139 | 18.94 (9.61) | NR | 23.27 (9.54) | 134 | 20.92 (9.16) | NR | MD=−0.228, 0.043
Wilz, 2018^*^,^382^; Good | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 12 | 21.73 (9.66) | 139 | 19.08 (10.12) | NR | 23.27 (9.54) | 134 | 20.10 (10.57) | NR | MD=−0.175, 0.180
Wright, 2001^383^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 3 | 13.1^##^ (NR) | 68 | 11.7^##^ (NR) | NR | 9.7^##^ (NR) | 25 | 7.6^##^ (NR) | NR | NS
Wright, 2001^383^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 13.1^##^ (NR) | 68 | 11.4^##^ (NR) | NR | 9.7^##^ (NR) | 25 | 6.7^##^ (NR) | NR | NS
Wright, 2001^383^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 12 | 13.1^##^ (NR) | 68 | 10.6^##^ (NR) | NR | 9.7^##^ (NR) | 25 | 8.3^##^ (NR) | NR | NR, 0.94
Care/Case Management Interventions
Bass, 2003^384^; Fair | Caregiver + patient | Dep (CES-D, 0–20, ↓) | IG1 | 12 | 0.57 (0.40) | 94 | 0.60 (0.39) | NR | 0.62 (0.45) | 63 | 0.76 (0.47) | NR | NR, ≤0.05
Callahan, 2006^385^; Fair | Caregiver + patient | Dep (PHQ-9, 0–27) | IG1 | 6 | 3.8 (5.1) | 84 | 3.6 (5.0) | NR | 4.4 (5.6) | 69 | 4.3 (5.1) | NR | Adj MD (95% CI)=−0.5 (−1.8, 0.9), 0.50
Callahan, 2006^385^; Fair | Caregiver + patient | Dep (PHQ-9, 0–27) | IG1 | 12 | 3.8 (5.1) | 84 | 3.1 (3.9) | NR | 4.4 (5.6) | 69 | 4.6 (5.6) | NR | Adj MD (95% CI)=−0.9 (−2.2, 0.5), 0.21
Callahan, 2006^385^; Fair | Caregiver + patient | Dep (PHQ-9, 0–27) | IG1 | 17 | 3.8 (5.1) | 84 | 3.1 (4.5) | NR | 4.4 (5.6) | 69 | 5.2 (5.3) | NR | Adj MD (95% CI)=−1.6 (−3.0, −0.2), 0.02
Fortinsky, 2009^391^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 12 | 12.1 (NR) | 44 | 9.8 (NR) | NR | 15.1 (NR) | 25 | 15.0 (NR) | NR | NR, 0.41
Jansen, 2011^392^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 10.6 (NR) | 54 | 11.9 (NR) | NR | 11.2 (NR) | 45 | 9.7 (NR) | NR | NS
Jansen, 2011^392^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 12 | 10.6 (NR) | 54 | 11.2 (NR) | NR | 11.2 (NR) | 45 | 11.2 (NR) | NR | F=1.80, 0.17
Lam, 2010^393^; Fair | Caregiver + patient | Psych Health (GHQ-28, 0–84, ↓) | IG1 | 4 | 13.1 (5.4) | 57 | NR | 0.0 (−2.5, 3.0)^***^ | 14.2 (6.6) | 42 | NR | 1.0 (−4.0, 4.0)^***^ | NS
Lam, 2010^393^; Fair | Caregiver + patient | Psych Health (GHQ-28, 0–84, ↓) | IG1 | 12 | 13.1 (5.4) | 53 | NR | 1.0 (−2.0, 5.5)^***^ | 14.2 (6.6) | 39 | NR | 0.0 (−2.0, 3.0)^***^ | NS
Meewsen, 2012^395^; Good | Caregiver + patient | Anx (STAI-State, 20–80, ↓) | IG1 | 6 | 34.9 (9.7) | 80 | NR | NR | 36.5 (9.3) | 78 | NR | NR | Adj MD (95% CI)=3.55 (1.29, 5.81), 0.002
Meewsen, 2012^395^; Good | Caregiver + patient | Anx (STAI-State, 20–80, ↓) | IG1 | 12 | 34.9 (9.7) | 78 | NR | NR | 36.5 (9.3) | 75 | NR | NR | Adj MD (95% CI)=2.35 (0.35, 4.36), 0.02
Meewsen, 2012^395^; Good | Caregiver + patient | Anx (STAI-Trait, 20–80, ↓) | IG1 | 12 | 34.0 (10.2) | 80 | NR | NR | 34.6 (9.1) | 78 | NR | NR | Adj MD (95% CI)=2.14 (0.24, 4.03), 0.03
Meewsen, 2012^395^; Good | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 9.3 (7.6) | 80 | NR | NR | 9.8 (7.6) | 78 | NR | NR | Adj MD (95% CI)=0.05 (−2.04, 2.13), 0.96
Meewsen, 2012^395^; Good | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 12 | 9.3 (7.6) | 78 | NR | NR | 9.8 (7.6) | 75 | NR | NR | Adj MD (95% CI)=2.09 (0.15, 4.02), 0.04
Samus, 2014^*^,^397^; Fair | Caregiver + patient | Dep (GDS-15, 0–15, ↓) | IG1 | 18 | 2.85 (3.1)^‡^ | 106 | 2.93 (0.34)^‡^ | NR | 2.54 (0.23)^‡^ | 183 | 3.01 (0.28)^‡^ | NR | MDC (95% CI)=−0.38 (−1.0, 0.25), 0.43
Other Interventions
Charlesworth, 2008^401^; Fair | Caregiver | Anx (HADS-A, 0–21, ↓) | IG1 | 6 | 7.55 (4.58) | 104 | 6.35 (4.46) | NR | 7.97 (4.68) | 113 | 6.96 (4.37) | NR | LSM change (95% CI)=0.22 (−0.43, 0.97),
Charlesworth, 2008^401^; Fair | Caregiver | Anx (HADS-A, 0–21, ↓) | IG1 | 15 | 7.55 (4.58) | 96 | 6.55 (4.54) | NR | 7.97 (4.68) | 106 | 7.55 (4.47) | NR | LSM change (95% CI)=0.61 (−0.33, 1.55),
Charlesworth, 2008^401^; Fair | Caregiver | Anx (HADS-A, 0–21, ↓) | IG1 | 22 | 7.55 (4.58) | 93 | 6.55 (4.49) | NR | 7.97 (4.68) | 97 | 6.97 (4.50) | NR | LSM change (95% CI)=−0.04 (−1.10, 1.03),
Charlesworth, 2008^401^; Fair | Caregiver | Dep (HADS-D, 0–21, ↓) | IG1 | 6 | 6.73 (3.63) | 104 | 6.03 (3.63) | NR | 6.96 (3.94) | 113 | 5.84 (3.96) | NR | LSM change (95% CI)=−0.48 (−1.23, 0.26), 0.20
Charlesworth, 2008^401^; Fair | Caregiver | Dep (HADS-D, 0–21, ↓) | IG1 | 15 | 6.73 (3.63) | 96 | 6.03 (4.00) | NR | 6.96 (3.94) | 106 | 6.71 (4.18) | NR | LSM change (95% CI)=0.47 (−0.50, 1.44), 0.34
Charlesworth, 2008^401^; Fair | Caregiver | Dep (HADS-D, 0–21, ↓) | IG1 | 22 | 6.73 (3.63) | 93 | 6.25 (4.12) | NR | 6.96 (3.94) | 97 | 6.35 (4.59) | NR | LSM change (95% CI)=−0.21 (−1.32, 0.90), 0.71
Connell, 2009^402^; Fair | Caregiver | Dep (CES-D, 0–20, ↓) | IG1 | 6 | 9.4 (2.9) | 74 | 8.1 (3.0) | NR | 7.9 (2.8) | 63 | 8.3 (2.9) | NR | NS
Connell, 2009^402^; Fair | Caregiver | Dep (CES-D, 0–20, ↓) | IG1 | 13 | 9.4 (2.9) | 69 | 8.5 (2.8) | NR | 7.9 (2.8) | 61 | 7.7 (2.7) | NR | NS
Connell, 2009^402^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–4, ↓) | IG1 | 6 | 1.9 (0.5) | 74 | 1.7 (0.6) | NR | 1.8 (0.5) | 63 | 1.8 (0.6) | NR | NR, <0.05
Connell, 2009^402^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–4, ↓) | IG1 | 12 | 1.9 (0.5) | 69 | 1.8 (0.6) | NR | 1.8 (0.5) | 61 | 1.7 (0.6) | NR | NS
King, 2002^405^; Fair | Caregiver | Anx (TMAS, 0–20, ↓) | IG1 | 12 | 6.4 (4.3) | 45 | 6.3 (4.3) | NR | 8.9 (4.5) | 40 | 7.2 (4.9) | NR | NS
King, 2002^405^; Fair | Caregiver | Dep (BDI, 0–63, ↓) | IG1 | 12 | 10.7 (6.5) | 45 | 7.4 (4.8) | NR | 13.7 (6.3) | 40 | 9.4 (7.2) | NR | NS
King, 2002^405^; Fair | Caregiver | Perc Stress (Cohen PSS, 0–56, ↓) | IG1 | 12 | 28.1 (8.3) | 45 | 24.8 (8.1) | NR | 29.3 (6.8) | 40 | 26.6 (8.5) | NR | NR
Logiudice, 1999^407^; Fair | Caregiver + patient | Psych Health (GHQ-30, 0–90, ↓) | IG1 | 6 | 6.8 (7.2) | 23 | NR | 0.79 (NR) | 8.3 (7.4) | 16 | NR | −0.14 (NR) | NR, 0.50
Logiudice, 1999^407^; Fair | Caregiver + patient | Psych Health (GHQ-30, 0–90, ↓) | IG1 | 12 | 6.8 (7.2) | 17 | NR | 2.50 (NR) | 8.3 (7.4) | 15 | NR | 2.23 (NR) | NR, 0.90
Prick, 2015^*^,^410^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 3 | 10.84 (6.85) | 57 | 13.71 (8.18) | NR | 11.02 (8.57) | 54 | 10.94 (8.42) | NR | logBeta (95% CI)=0.14 (−0.04, 0.33), 0.13
Prick, 2015^*^,^410^; Fair | Caregiver + patient | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 10.84 (6.85) | 57 | 13.62 (7.18) | NR | 11.02 (8.57) | 54 | 11.38 (8.56) | NR | logBeta (95% CI)=0.07 (−0.10, 0.25), 0.41
Winter, 2006^413^; Fair | Caregiver | Dep (CES-D, 0–60, ↓) | IG1 | 6 | 15.9 (11.1) | 53 | 18.7 (7.19) | NR | 14.1 (10.8) | 49 | 20.2 (7.20) | NR | NR, 0.121

* New study

† N (%) of participants scoring ≥15 on CES-D, indicating extremely high levels of depression symptoms

‡ Standard error

§ N (%) of participants scoring ≥8 on CES-D, indicating clinically significant depression symptoms

ǁ Number (%) of participants scoring ≥8 on HADS-A (clinically significant anxiety)

¶ N (%) of participants scoring ≥16 on CES-D, indicating clinically significant depression symptoms

# Odds of scoring ≥15 on CES-D, indicating extremely high levels of depression symptoms

** Number (%) of participants scoring ≥9 on HADS-A indicating clinically significant anxiety symptoms

†† N (%) of participants scoring ≥9 on HADS-D, indicating clinically significant depression symptoms

‡‡ N (%) of participants scoring ≥11 on GDS, indicating clinically significant depression symptoms

§§ Odds of scoring ≥10 on BDI, indicating clinically significant depression symptoms

ǁǁ N (%) of participants scoring <11.35 on BDI, indicating absence of clinically significant depression symptoms

¶¶ 95% CI

## Least squares mean

*** Median change (IQR)

Abbreviations: AD = Alzheimer’s Disease; Adj MD = adjusted mean difference; Anx = anxiety; BDI = Beck Depression Inventory; BDI-II = Beck Depression Inventory – Second Edition; BL = baseline; BSI-A = Brief Symptom Inventory, Anxiety subscale; BSI-D = Brief Symptom Inventory, depression subscale; CES-D = Center for Epidemiologic Studies – Depression; CES-D-10 = 10-item Center for Epidemiologic Studies – Depression; CG = control group; CI = confidence interval; Cohen PSS = Cohen Perceived Stress Scale; D = dichotomized; Dep = depression; ES = effect size; FU = followup; GDS = Geriatric Depression Scale; GDS-15 = Geriatric Depression Scale-15 item; GHQ-12 = General Health Questionnaire-12 item; GHQ-28 = General Health Questionnaire-28 item; GHQ-30 = General Health Questionnaire-30 item; HADS-A = Hospital Anxiety and Depression Scale, Anxiety subscale; HADS-D = Hospital Anxiety and Depression Scale, Depression subscale; HADS-T = Hospital Anxiety and Depression Scale, Total score; HDRS = Hamilton Depression Rating Scale; HR = hazard ratio; HSQ-12 = Health Status Questionnaire, mental health domain; IG = intervention group; Int arm = intervention arm; IRR = incident rate ratio; LSM = least squares mean; MAACL = Multiple Affect Adjective Checklist; MADRS = Montgomery Asberg Depression Rating Scale; MCI = mild cognitive impairment; MD = mean difference; mo. = months; NA = not applicable; NAS = Negative Affect Scale; NR = not reported; NS = not statistically significant; OR = odds ratio; Perc Stress = perceived stress; PHQ-4 = Patient Health Questionnaire-4 items; PHQ-9 = Patient Health Questionnaire-9 items; RSS = Relative Stress Scale; SD = standard deviation; SE = standard error; STAI = State-Trait Anxiety Inventory; STPI = State-Trait Personality Inventory; TMAS = Taylor Manifest Anxiety Scale-Short form

Appendix H Table 3 Caregiver and Caregiver-Patient Dyad Interventions: Detailed Results for Caregiver Quality of Life Outcomes, by Intervention Type

Author, year Quality | Audience | Instrument (range)^†^ | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Psychoeducation Interventions
Barnes, 2018^*^,^327^; Fair | Caregiver | ACQOL (0–120) | IG1 | 3 | 69.6 (NR) | 27 | 73.9 (NR) | 4.3 (NR) | 69.4 (NR) | 25 | 69.2 (NR) | −0.2 (NR) | NR, 0.138
Berwig, 2017^*^,^329^; Fair | Caregiver | SF-12 MCS (0–100) | IG1 | 6 | 43.7 (11.1) | 41 | NR | 2.398 (8.703) | 49.0 (10.6) | 40 | NR | −2.528 (8.556) | ES=0.571, 0.012
Berwig, 2017^*^,^329^; Fair | Caregiver | SF-12 MCS (0–100) | IG1 | 9 | 43.7 (11.1) | 31 | NR | 3.868 (10.662) | 49.0 (10.6) | 31 | NR | −4.618 (8.157) | ES=0.902, 0.001
Berwig, 2017^*^,^329^; Fair | Caregiver | SF-12 PCS (0–100) | IG1 | 6 | 43.6 (10.7) | 41 | NR | 2.600 (9.960) | 44.1 (10.7) | 40 | NR | −1.310 (7.711) | ES=0.443, 0.052
Berwig, 2017^*^,^329^; Fair | Caregiver | SF-12 PCS (0–100) | IG1 | 9 | 43.6 (10.7) | 31 | NR | −0.053 (9.591) | 44.1 (10.7) | 31 | NR | 0.191 (6.699) | ES=0.030, 0.908
Duggleby, 2018^*^,^339^; Fair | Caregiver | SF-12 MCS (0–100) | IG1 | 3 | NR | 101 | NR | NR | NR | 98 | NR | NR | LSM (95% CI)=−0.23 (−3.25, 2.80), 0.88
Duggleby, 2018^*^,^339^; Fair | Caregiver | SF-12 MCS (0–100) | IG1 | 6 | NR | 101 | NR | NR | NR | 98 | NR | NR | Beta (95% CI)=0.68 (−0.76, 2.12), 0.35
Duggleby, 2018^*^,^339^; Fair | Caregiver | SF-12 PCS (0–100) | IG1 | 3 | NR | 101 | NR | NR | NR | 98 | NR | NR | LSM (95% CI)=−0.02 (−2.07, 2.01), 0.98
Duggleby, 2018^*^,^339^; Fair | Caregiver | SF-12 PCS (0–100) | IG1 | 6 | NR | 101 | NR | NR | NR | 98 | NR | NR | NS
Fung, 2002^*^,^341^; Fair | Caregiver | WHOQoL-BREF (28–140) | IG1 | 4 | 96.90 (14.11) | 26 | 113.21 (9.98) | NR | 103.75 (0.68) | 26 | 88.19 (9.56) | NR | F statistic=23.145, 0.000
Gaugler, 2013^*^,^346^; Fair | Whole family | Cantril Ladder QoL (0–100) | IG1 | 4 | 74.63 (16.71) | 54 | 82.29 (NR) | NR | 76.77 (10.62) | 53 | 81.49 (NR) | NR | NR
Gaugler, 2013^*^,^346^; Fair | Whole family | Cantril Ladder QoL (0–100) | IG1 | 8 | 74.63 (16.71) | 54 | 80.56 (NR) | NR | 76.77 (10.62) | 53 | 81.12 (NR) | NR | NR
Gaugler, 2013^*^,^346^; Fair | Whole family | Cantril Ladder QoL (0–100) | IG1 | 12 | 74.63 (16.71) | 54 | 80.14 (NR) | NR | 76.77 (10.62) | 53 | 80.60 (NR) | NR | NR
Gaugler, 2013^*^,^346^; Fair | Whole family | Cantril Ladder QoL (0–100) | IG1 | 18 | 74.63 (16.71) | 54 | 81.07 (NR) | NR | 76.77 (10.62) | 53 | 79.62 (NR) | NR | NR
Gaugler, 2013^*^,^346^; Fair | Whole family | Cantril Ladder QoL (0–100) | IG1 | 24 | 74.63 (16.71) | 54 | 82.63 (NR) | NR | 76.77 (10.62) | 53 | 78.41 (NR) | NR | NR
Gaugler, 2013^*^,^346^; Fair | Whole family | Cantril Ladder QoL (0–100) | IG1 | 30 | 74.63 (16.71) | 54 | 83.46 (NR) | NR | 76.77 (10.62) | 53 | 77.01 (NR) | NR | NR
Gaugler, 2013^*^,^346^; Fair | Whole family | Cantril Ladder QoL (0–100) | IG1 | 36 | 74.63 (16.71) | 54 | 82.19 (NR) | NR | 76.77 (10.62) | 53 | 75.53 (NR) | NR | Beta (SE)=−0.21 (1.59), NS
Graff, 2006^351^; Fair | Caregiver + patient | DQOL single item (1–5) | IG1 | 3 | 3.3 (0.9) | 67 | 4.1 (0.6) | NR | 3.4 (0.8) | 65 | 3.4 (0.8) | NR | Adj MD (95% CI)=0.9 (0.6, 1.1), <0.0001
Judge, 2013^*^,^355^; Fair | Caregiver + patient | QOL-AD (0–18) | IG1 | 3 | 10.88 (2.73) | 59 | 10.92 (3.04) | NR | 10.92 (3.76) | 59 | 10.69 (3.40) | NR | Beta=0.04,>0.05
Kurz, 2010^357^; Fair | Caregiver | SF-36 emotional well-being (0–100) | IG1 | 15 | NR | 127 | NR | −5.3 (24.5) | NR | 113 | NR | −7.8 (25.9) | NR, 0.33
Kurz, 2010^357^; Fair | Caregiver | SF-36 role functioning, emotional (0–100) | IG1 | 15 | NR | 125 | NR | 5.3 (48.5) | NR | 115 | NR | −10.4 (51.2) | NR, 0.01
Kurz, 2010^357^; Fair | Caregiver | SF-36 social functioning (0–100) | IG1 | 15 | NR | 127 | NR | 2.3 (31.3) | NR | 115 | NR | 2.0 (33.5) | NR, 0.64
Laakkonen, 2016^*^,^359^; Fair | Caregiver + patient | SF-36 MCS (0–100) | IG1 | 3 | 51.0 (9.1) | 67 | NR | −0.22 (NR) | 47.6 (45.1) | 67 | NR | −0.25 (NR) | NR, 0.99
Laakkonen, 2016^*^,^359^; Fair | Caregiver + patient | SF-36 MCS (0–100) | IG1 | 9 | 51.0 (9.1) | 67 | NR | −1.21 (NR) | 47.6 (45.1) | 67 | NR | −0.42 (NR) | NR, 0.58
Laakkonen, 2016^*^,^359^; Fair | Caregiver + patient | SF-36 PCS (0–100) | IG1 | 3 | 44.0 (9.8) | 67 | NR | 1.0 (NR) | 43.8 (10.5) | 67 | NR | −2.0 (NR) | Cohen’s D=0.38,0.006
Laakkonen, 2016^*^,^359^; Fair | Caregiver + patient | SF-36 PCS (0–100) | IG1 | 9 | 44.0 (9.8) | 67 | NR | −0.0 (NR) | 43.8 (10.5) | 67 | NR | −1.7 (NR) | NR, 0.13
Martin-Carrasco, 2009^364^; Fair | Caregiver | SF-36 emotional well-being (0–100) | IG1 | 10 | 60.2 (9.5) | 44 | 63.0 (9.2) | NR | 60.8 (8.1) | 38 | 60.9 (8.3) | NR | NR, 0.3197
Martin-Carrasco, 2009^364^; Fair | Caregiver | SF-36 energy/vitality (0–100) | IG1 | 10 | 47.4 (21.6) | 44 | 53.8 (15.9) | NR | 42.8 (16.1) | 38 | 38.9 (17.9) | NR | NR, 0.0002
Martin-Carrasco, 2009^364^; Fair | Caregiver | SF-36 general health (0–100) | IG1 | 10 | 48.4 (18.5) | 44 | 53.4 (18.0) | NR | 44.6 (19.2) | 38 | 40.1 (15.7) | NR | NR, 0.0011
Martin-Carrasco, 2009^364^; Fair | Caregiver | SF-36 pain (0–100) | IG1 | 10 | 63.0 (25.9) | 44 | 74.0 (18.7) | NR | 61.4 (26.2) | 38 | 61.7 (26.9) | NR | NR, 0.0157
Martin-Carrasco, 2009^364^; Fair | Caregiver | SF-36 physical functioning (0–100) | IG1 | 10 | 74.3 (25.5) | 44 | 80.1 (20.7) | NR | 71.7 (21.4) | 55 | 68.8 (25.6) | NR | NR, 0.0310
Martin-Carrasco, 2009^364^; Fair | Caregiver | SF-36 role functioning, emotional (0–100) | IG1 | 10 | 57.6 (45.7) | 44 | 73.5 (41.0) | NR | 63.2 (39.4) | 38 | 47.4 (48.2) | NR | NR, 0.0160
Martin-Carrasco, 2009^364^; Fair | Caregiver | SF-36 role functioning, physical (0–100) | IG1 | 10 | 61.4 (44.6) | 44 | 84.7 (34.6) | NR | 53.9 (44.5) | 38 | 56.8 (47.0) | NR | NR, 0.0074
Martin-Carrasco, 2009^364^; Fair | Caregiver | SF-36 social functioning (0–100) | IG1 | 10 | 63.4 (28.5) | 44 | 71.0 (23.4) | NR | 70.8 (27.0) | 38 | 58.9 (27.7) | NR | NR, 0.0488
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | SF-12 emotional well-being (0–100) | IG1 | 4 | 60.5 (22.9) | 115 | NR | 1.53 (23.8) | 60.0 (23.9) | 123 | NR | 2.76 (19.2) | MDC (95% CI)=−1.23 (−7.22, 4.75), NS
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | SF-12 energy/vitality (0–100) | IG1 | 4 | 53.3 (28.6) | 115 | NR | 2.04 (28.6) | 59.5 (30.7) | 123 | NR | −1.67 (29.5) | MDC (95% CI)=3.71 (−4.34, 11.76), NS
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | SF-12 general health (0–100) | IG1 | 4 | 40.9 (21.5) | 115 | NR | −3.12 (19.3) | 41.0 (21.3) | 123 | NR | 1.89 (20.0) | MDC (95% CI)=−5.01 (−10.48, 0.45), NS
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | SF-12 pain (0–100) | IG1 | 4 | 68.4 (32.6) | 115 | NR | 6.38 (25.7) | 71.2 (32.0) | 123 | NR | −0.47 (34.3) | MDC (95% CI)=6.85 (−1.58, 15.28), NS
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | SF-12 physical functioning (0–100) | IG1 | 4 | 72.7 (33.3) | 115 | NR | −1.02 (30.0) | 66.7 (35.2) | 123 | NR | 0.0 (41.3) | MDC (95% CI)=−1.02 (−11.10, 9.06),
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | SF-12 role functioning, emotional (0–100) | IG1 | 4 | 77.3 (25.3) | 115 | NR | −3.06 (27.7) | 78.4 (24.6) | 123 | NR | 1.19 (24.5) | MDC (95% CI)=−4.25 (−11.48, 2.98), NS
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | SF-12 role functioning, physical (0–100) | IG1 | 4 | 66.9 (27.0) | 115 | NR | 3.09 (26.9) | 72.3 (27.2) | 123 | NR | 1.30 (26.7) | MDC (95% CI)=1.80 (−5.63, 9.22), NS
Martin-Carrasco, 2014^*^,^363^; Fair | Caregiver | SF-12 social functioning (0–100) | IG1 | 4 | 73.0 (28.2) | 115 | NR | −4.08 (31.6) | 74.1 (28.0) | 123 | NR | −3.30 (30.3) | MDC (95% CI)=−0.78 (−9.33, 7.77), NS
Tremont, 2015^*^,^375^; Fair | Caregiver | EQ-VAS (0–100) | IG1 | 6 | 80.08 (16.07) | 133 | 79.87 (15.00) | NR | 77.14 (17.61) | 117 | 77.59 (15.69) | NR | NR, 0.748
Voigt-Radloff, 2011^377^; Fair | Caregiver + patient | DQOL single item (1–5) | IG1 | 6 | 3.1 (0.8) | 51 | 3.0 (0.7) | NR | 3.1 (0.7) | 48 | 3.2 (0.8) | NR | MD (95% CI)=0.2 (−0.1, 0.5), NS
Voigt-Radloff, 2011^377^; Fair | Caregiver + patient | DQOL single item (1–5) | IG1 | 12 | 3.1 (0.8) | 51 | 2.8 (0.8) | NR | 3.1 (0.7) | 48 | 3.0 (0.8) | NR | MD (95% CI)=0.2 (−0.1, 0.5), NS
Voigt-Radloff, 2011^377^; Fair | Caregiver + patient | SF-12 MCS (0–100) | IG1 | 6 | 50.9 (9.1) | 40 | 50.2 (9.1) | NR | 49.8 (10.7) | 38 | 50.1 (10.7) | NR | MD (95% CI)=0.0 (−4.5, 4.4), NS
Voigt-Radloff, 2011^377^; Fair | Caregiver + patient | SF-12 MCS (0–100) | IG1 | 12 | 50.9 (9.1) | 40 | 49.5 (11.9) | NR | 49.8 (10.7) | 38 | 47.7 (10.7) | NR | MD (95% CI)=−1.7 (−6.7, 3.4), NS
Voigt-Radloff, 2011^377^; Fair | Caregiver + patient | SF-12 PCS (0–100) | IG1 | 6 | 42.4 (11.5) | 40 | 45.4 (10.7) | NR | 43.5 (11.3) | 38 | 45.0 (10.5) | NR | MD (95% CI)=−0.4 (−5.2, 4.4), NS
Voigt-Radloff, 2011^377^; Fair | Caregiver + patient | SF-12 PCS (0–100) | IG1 | 12 | 42.4 (11.5) | 40 | 42.7 (10.7) | NR | 43.5 (11.3) | 38 | 41.6 (11.7) | NR | MD (95% CI)=−1.0 (−6.1, 4.0), NS
Waldorff, 2012^378^; Good | Caregiver + patient | EQ-VAS (0–100) | IG1 | 6 | 79.3 (16.3) | 141 | 81.6 (16.4) | 2.07 (16.3) | 81.4 (16.3) | 150 | 80.3 (18.2) | −1.25 (14.3) | MDC (95% CI)=2.61 (0.76, 4.46), 0.006
Waldorff, 2012^378^; Good | Caregiver + patient | EQ-VAS (0–100) | IG1 | 12 | 79.3 (16.3) | 128 | 79.5 (16.0) | 0.02 (16.3) | 81.4 (16.3) | 144 | 81.8 (17.0) | −0.38 (14.5) | MDC (95% CI)=−0.65 (−1.70, 0.39), 0.22
Waldorff, 2012^378^; Good | Caregiver + patient | EQ-VAS (0–100) | IG1 | 36 | 79.3 (16.3) | 163 | 80.3 (NR) | 0.14 (NR) | 81.4 (16.3) | 167 | 79.5 (NR) | −2.71 (NR) | NR, 0.28
Wang, 2011^*^,^379^; Fair | Caregiver + patient | WHOQoL-BREF (28–144) | IG1 | 6 | 65.9 (13.0) | 40 | 78.8 (19.0) | NR | 67.0 (13.5) | 40 | 68.9 (15.7) | NR | NR, <0.001
Wilz, 2018^*^,^382^; Good | Caregiver | WHOQoL-BREF (0–100) | IG1 | 6 | 50.18 (17.99) | 139 | 55.58 (17.75) | NR | 47.48 (17.99) | 134 | 50.00 (18.37) | NR | MD=0.386, 0.006
Wilz, 2018^*^,^382^; Good | Caregiver | WHOQoL-BREF (0–100) | IG1 | 12 | 50.18 (17.99) | 139 | 54.20 (19.55) | NR | 47.48 (17.99) | 134 | 53.35 (18.91) | NR | MD=0.057, 0.714
Care/Case Management Interventions
Chien, 2011^*^,^386^; Good | Whole family | WHOQoL-BREF (28–144) | IG1 | 6 | 64.9 (15.0) | 44 | 75.1 (16.8) | NR | 67.1 (15.5) | 44 | 69.8 (16.7) | NR | NR
Chien, 2011^*^,^386^; Good | Whole family | WHOQoL-BREF (28–144) | IG1 | 12 | 64.9 (15.0) | 444 | 81.4 (16.0) | NR | 67.1 (15.5) | 44 | 65.2 (17.5) | NR | F statistic=6.7, <0.001
Chien, 2011^*^,^386^; Good | Caregiver + patient | WHOQoL-BREF (28–144) | IG1 | 12 | 64.8 (13.0) | 46 | 80.4 (15.0) | NR | 67.1 (15.5) | 46 | 65.2 (17.5) | NR | MD (SE)=15.2 (1.1), 0.01
Chien, 2011^*^,^386^; Good | Caregiver + patient | WHOQoL-BREF (28–144) | IG1 | 18 | 64.8 (13.0) | 45 | 82.7 (13.5) | NR | 67.1 (15.5) | 45 | 64.5 (13.1) | NR | MD (SE)=18.2 (1.2), 0.005
Jansen, 2011^392^; Fair | Caregiver | SF-36 MCS (0–100) | IG1 | 6 | 51.0 (NR) | 54 | 48.7 (NR) | NR | 48.0 (NR) | 45 | 49.1 (NR) | NR | NS
Jansen, 2011^392^; Fair | Caregiver | SF-36 MCS (0–100) | IG1 | 12 | 51.0 (NR) | 54 | 48.2 (NR) | NR | 48.0 (NR) | 45 | 47.7 (NR) | NR | F statistic=1.37, 0.26
Jansen, 2011^392^; Fair | Caregiver | SF-36 PCS (0–100) | IG1 | 6 | 44.5 (NR) | 54 | 45.5 (NR) | NR | 48.0 (NR) | 45 | 46.5 (NR) | NR | NS
Jansen, 2011^392^; Fair | Caregiver | SF-36 PCS (0–100) | IG1 | 12 | 44.5 (NR) | 54 | 46.0 (NR) | NR | 48.0 (NR) | 45 | 47.5 (NR) | NR | F statistic=1.06, 0.35
Lam, 2010^393^; Fair | Caregiver + patient | PWI-A (0–100) | IG1 | 4 | 63.6 (15.1) | 57 | NR | 1.4^‡^ (NR) | 61.2 (18.5) | 42 | NR | −4.3^‡^ (NR) | NS
Lam, 2010^393^; Fair | Caregiver + patient | PWI-A (0–100) | IG1 | 12 | 63.6 (15.1) | 53 | NR | 2.9^‡^ (NR) | 61.2 (18.5) | 39 | NR | 0.0^‡^ (NR) | NS
Meewsen, 2012^395^; Good | Caregiver + patient | QOL-AD (13–52) | IG1 | 6 | 37.6 (3.6) | 80 | NR | NR | 38.5 (4.7) | 78 | NR | NR | Adj MD (95% CI)=−0.20 (−1.07, 0.66), 0.64
Meewsen, 2012^395^; Good | Caregiver + patient | QOL-AD (13–52) | IG1 | 12 | 37.6 (3.6) | 78 | NR | NR | 38.5 (4.7) | 75 | NR | NR | Adj MD (95% CI)=0.17 (−0.70, 1.04), 0.70
Samus, 2014^*^,^397^; Fair | Caregiver + patient | SF-12 MCS (0–100) | IG1 | 18 | 48.89 (1.08)^§^ | 106 | 48.45 (1.22)^§^ | NR | 48.64 (0.82)^§^ | 183 | 47.54 (1.00)^§^ | NR | MDC (95% CI)=−0.66 (−1.9, 3.2), 0.69
Samus, 2014^*^,^397^; Fair | Caregiver + patient | SF-12 PCS (0–100) | IG1 | 18 | 48.88 (1.11)^§^ | 106 | 49.31 (1.25)^§^ | NR | 48.11 (0.84)^§^ | 183 | 47.00 (1.02)^§^ | NR | MDC (95% CI)=1.53 (−1.1, 4.2), 0.43
Vickrey, 2006^399^; Good | Caregiver | EQ-5D index value (assume 0–1) | IG1 | 12 | 0.83 (0.17) | 205 | 0.83 (0.18) | NR | 0.80 (0.22) | 156 | 0.79 (0.22) | NR | Adj MD (95% CI)=0.02 (−0.01, 0.06), 0.19
Vickrey, 2006^399^; Good | Caregiver | EQ-5D index value (assume 0–1) | IG1 | 17 | 0.83 (0.17) | 166 | 0.81 (0.16) | NR | 0.80 (0.22) | 124 | 0.77 (0.23) | NR | Adj MD (95% CI)=0.02 (−0.01, 0.06), 0.13
Xiao, 2016^*^,^400^; Fair | Caregiver | SF-36 MCS (0–100) | IG1 | 6 | 30.3 (5.3) | 31 | 37.1 (8.2) | NR | 27.3 (10.9) | 30 | 24.7 (10.1) | NR | NR
Xiao, 2016^*^,^400^; Fair | Caregiver | SF-36 MCS (0–100) | IG1 | 12 | 30.3 (5.3) | 31 | 38.7 (7.0) | NR | 27.3 (10.9) | 30 | 23.0 (8.6) | NR | F statistic=22.35, <0.001
Xiao, 2016^*^,^400^; Fair | Caregiver | SF-36 PCS (0–100) | IG1 | 6 | 42.2 (7.2) | 31 | 41.8 (7.6) | NR | 44.9 (8.5) | 30 | 41.8 (8.5) | NR | NR
Xiao, 2016^*^,^400^; Fair | Caregiver | SF-36 PCS (0–100) | IG1 | 12 | 42.2 (7.2) | 31 | 41.1 (7.7) | NR | 44.9 (8.5) | 30 | 41.6 (8.7) | NR | F statistic=2.68, 0.08
Other Interventions
Charlesworth, 2008^401^; Fair | Caregiver | EQ-VAS (0–100) | IG1 | 6 | 74.0 (16.8) | 104 | 75.7 (17.0) | NR | 73.1 (18.1) | 113 | 72.9 (17.7) | NR | LSM (95% CI)=−2.06 (−5.51, 1.38), NR
Charlesworth, 2008^401^; Fair | Caregiver | EQ-VAS (0–100) | IG1 | 15 | 74.0 (16.8) | 96 | 73.8 (18.3) | NR | 73.1 (18.1) | 106 | 69.9 (18.1) | NR | LSM (95% CI)=−2.33 (−6.88, 2.23), NR
Charlesworth, 2008^401^; Fair | Caregiver | EQ-VAS (0–100) | IG1 | 22 | 74.0 (16.8) | 93 | 72.5 (19.7) | NR | 73.1 (18.1) | 97 | 68.1 (18.2) | NR | LSM (95% CI)=−3.03 (−8.42, 2.35), NR
Leach, 2015^*^,^406^; Good | Caregiver | AQoL-8D Mental superdomain (0–1) | IG1 | 3 | 0.35 (0.21) | 8 | 0.42 (0.22) | NR | 0.30 (0.11) | 9 | 0.29 (0.07) | NR | Adj MD (SD)=0.09 (0.14), 0.024
Leach, 2015^*^,^406^; Good | Caregiver | AQoL-8D Mental superdomain (0–1) | IG1 | 6 | 0.35 (0.21) | 8 | 0.37 (0.22) | NR | 0.30 (0.11) | 9 | 0.33 (0.10) | NR | Adj MD (SD)=0.004 (0.14), 0.359
Leach, 2015^*^,^406^; Good | Caregiver | AQoL-8D Physical superdomain (0–1) | IG1 | 3 | 0.66 (0.24) | 8 | 0.77 (0.23) | NR | 0.73 (0.17) | 9 | 0.76 (0.14) | NR | Adj MD (SD)=0.05 (0.27), 0.043
Leach, 2015^*^,^406^; Good | Caregiver | AQoL-8D Physical superdomain (0–1) | IG1 | 6 | 0.66 (0.24) | 8 | 0.74 (0.21) | NR | 0.73 (0.17) | 9 | 0.79 (0.14) | NR | Adj MD (SD)=−0.006 (0.22), 0.669
Leach, 2015^*^,^406^; Good | Caregiver | AQoL-8D utility score (0–1) | IG1 | 3 | 0.65 (0.23) | 8 | 0.74 (0.21) | NR | 0.66 (0.14) | 9 | 0.67 (0.10) | NR | Adj MD (SD)=0.08 (0.19), 0.878
Leach, 2015^*^,^406^; Good | Caregiver | AQoL-8D utility score (0–1) | IG1 | 6 | 0.65 (0.23) | 8 | 0.70 (0.21) | NR | 0.66 (0.14) | 9 | 0.71 (0.12) | NR | Adj MD (SD)=−0.002 (0.17), 0.878

* New study

† Higher values indicate better outcomes for all instruments

‡ Median change

§ Standard error

Abbreviations: ACQOL = Adult Carers Quality of Life scale; Adj MD = adjusted mean difference; AQoL-8D = Assessment of Quality of Life 8-demension; BL = baseline; CG = control group; CI = confidence interval; DQOL = Dementia Quality of Life; EQ-5D = EuroQol 5-Dimensions; EQ-VAS = EuroQol Visual Analog Scale; FU = followup; IG = intervention group; Int arm = intervention arm; MD = mean difference; MDC = mean difference in change; mo. = months; NR = not reported; NS = not statistically significant; PWI-A = Personal Well-being Index-Adults; QOL = Quality of Life; QOL-AD = Quality of Life in Alzheimer’s Disease; SD = standard deviation; SE = standard error; SF-12 = Short Form 12-item SF-36 Short Form 36-item; SF-36 MCS = Short Form 36-item, Mental Component Summary; SF-36 PCS = Short Form 36-item, Physical Component Summary; WHOQoL-BREF = World Health Organization Quality of Life Measure-Brief Version