# Appendix G Detailed Trial Results for Trials of Patient-Level Nonpharmacologic Interventions

Appendix G Table 1 Patient-Level Nonpharmacologic Interventions: Detailed Results for Global Cognitive Function Outcomes, by Intervention Type

Author, year Quality | Pop cat | Instrument (range)^†^ | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Cognitive Stimulation, Training, and Rehabilitation
Amieva, 2016^*^,^277^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | NR | 151 | 21.26 (12.9) | NR | NR | 141 | 19.84 (11.5) | NR | NR, 0.5041
Amieva, 2016^*^,^277^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 24 | NR | 124 | 39.96 (24.8) | NR | NR | 109 | 38.25 (24.5) | NR | NR, 0.7060
Amieva, 2016^*^,^277^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | NR | 144 | 19.92 (12.0) | NR | NR | 141 | 19.84 (11.5) | NR | NR, 0.8876
Amieva, 2016^*^,^277^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 24 | NR | 121 | 34.57 (23.7) | NR | NR | 109 | 38.25 (24.5) | NR | NR, 0.1012
Bergamaschi, 2013^*^,^282^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 20.25 (2.95) | 16 | 23.0 (2.0) | NR | 21.94 (2.01) | 16 | 18.37 (2.96) | NR | NR, <0.001
Buschert, 2011^271^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 12.1 (5.3) | 8 | 11.4 (6.0) | NR | 16.4 (4.8) | 7 | 16.4 (4.9) | NR | NS
Buschert, 2011^271^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 6 | 8.7 (2.9) | 10 | 7.3 (3.1) | NR | 9.8 (4.3) | 12 | 11.7 (5.6) | NR | NR, 0.02
Buschert, 2011^271^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 24.5 (1.6) | 8 | 25.0 (2.7) | NR | 25.3 (1.5) | 7 | 24.4 (2.4) | NR | NS
Buschert, 2011^271^; Fair | MCI | MMSE (0–30) | IG1 | 6 | 28.1 (1.5) | 10 | 26.8 (1.5) | NR | 28.2 (1.2) | 12 | 26.0 (1.3) | NR | NR, 0.07
Cavallo, 2016^*^,^286^; Good | Dem | MMSE (0–30) | IG1 | 6 | 22.65 (1.74) | 38 | 22.32 (0.97) | NR | 23.05 (2.44) | 38 | 22.64 (0.96) | NR | NS
Chapman, 2004^268^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | NR | 26 | 21.5 (NR) | NR | NR | 28 | 20.2 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 7 | NR | 26 | 23.5 (NR) | NR | NR | 28 | 23.0 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | NR | 26 | 24.6 | 4.89 (2.67, 7.11) | | 28 | 26.5 | 5.62 (3.39, 7.85) | ES=0.00, NS
Chapman, 2004^268^; Fair | Dem | MMSE (0–30) | IG1 | 4 | NR | 26 | 21.0 (NR) | NR | NR | 28 | 21.9 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | MMSE (0–30) | IG1 | 7 | NR | 26 | 19.7 (NR) | NR | NR | 28 | 20.1 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | MMSE (0–30) | IG1 | 12 | NR | 26 | 19.4 (NR) | −1.25 (−2.78, 0.28) | NR | 28 | 19.0 (NR) | −2.14 (−4.18, −0.10) | ES=0.06, NS
Cove, 2014^*^,^279^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 18.35 (7.1) | 21 | 20.10 (7.6) | NR | 17.68 (6.51) | 23 | 20.09 (7.2) | NR | NS
Cove, 2014^*^,^279^; Fair | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | 18.13 (8.24) | 24 | 19.04 (8.13) | NR | 17.68 (6.51) | 23 | 20.09 (7.2) | NR | NS
Cove, 2014^*^,^279^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 22.33 (3.54) | 21 | 22.19 (4.48) | NR | 22.91 (3.01) | 23 | 22.13 (3.40) | NR | ES=0.003, 0.92
Cove, 2014^*^,^279^; Fair | Dem | MMSE (0–30) | IG2 | 3 | 22.71 (3.76) | 24 | 22.38 (4.75) | NR | 22.91 (3.01) | 23 | 22.13 (3.40) | NR | NS
Fiatarone Singh, 2014^*^,^280^; Fair | MCI | ADAS-Cog 11 (0–70) | IG2 | 6 | 8.79 (NR) | 24 | 7.31 (NR) | NR | 8.09 (NR) | 27 | 7.14 (NR) | NR | NR
Fiatarone Singh, 2014^*^,^280^; Fair | MCI | ADAS-Cog 11 (0–70) | IG2 | 18 | 8.79 (NR) | 24 | 6.49 (NR) | NR | 8.09 (NR) | 27 | 5.75 (NR) | NR | NR
Greenaway, 2012^273^; Fair | MCI | MMSE (0–30) | IG1 | 6 | 26.4 (2.2) | 18 | 26.1 (2.2) | −0.2 (1.4) | 27.2 (2.4) | 17 | 27.3 (1.8) | −0.4 (2.2) | Cohen’s d=0.1, NS
Jelcic, 2012^*^,^284^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 24.4 (2.8) | 20 | 26.4 (2.3) | NR | 25.0 (2.6) | 20 | 24.0 (3.3) | NR | NR, <0.001
Jeong, 2016^*^,^276^; Fair | MCI | ADAS-Cog 13 (0–89) | IG1 | 3 | 25.9 (6.6) | 71 | NR | −2.3 (4.6) | 26.5 (6.6) | 76 | NR | −0.8 (4.8) | NR, 0.01
Jeong, 2016^*^,^276^; Fair | MCI | ADAS-Cog 13 (0–89) | IG1 | 9 | 25.9 (6.6) | 67 | NR | −2.3 (5.2) | 26.5 (6.6) | 62 | NR | −0.5 (5.2) | NR, 0.03
Jeong, 2016^*^,^276^; Fair | MCI | ADAS-Cog 13 (0–89) | IG2 | 3 | 24.9 (6.8) | 71 | NR | −2.5 (4.5) | 26.5 (6.6) | 76 | NR | −0.8 (4.8) | NR, 0.02
Jeong, 2016^*^,^276^; Fair | MCI | ADAS-Cog 13 (0–89) | IG2 | 9 | 24.9 (6.8) | 68 | NR | −2.3 (6.1) | 26.5 (6.6) | 62 | NR | −0.5 (5.2) | NR, 0.047
Jeong, 2016^*^,^276^; Fair | MCI | MMSE (0–30) | IG1 | 3 | 25.9 (2.5) | 71 | NR | 0.3 (1.8) | 25.3 (2.5) | 76 | NR | 0.3 (1.8) | NR, 0.23
Jeong, 2016^*^,^276^; Fair | MCI | MMSE (0–30) | IG1 | 9 | 25.9 (2.5) | 67 | NR | −0.1 (2.3) | 25.3 (2.5) | 62 | NR | 0.3 (2.4) | NR, 0.39
Jeong, 2016^*^,^276^; Fair | MCI | MMSE (0–30) | IG2 | 3 | 25.9 (2.4) | 77 | NR | 0.7 (2.0) | 25.3 (2.5) | 76 | NR | 0.3 (1.8) | NR, 0.16
Jeong, 2016^*^,^276^; Fair | MCI | MMSE (0–30) | IG2 | 9 | 25.9 (2.4) | 68 | NR | 0.2 (2.3) | 25.3 (2.5) | 62 | NR | 0.3 (2.4) | NR, 0.6
Kallio, 2018^*^,^290^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 9 | 21.1 (8.1) | 76 | NR | 0.8 (−0.2, 1.8) | 21.8 (8.3) | 71 | NR | 1.7 (0.6, 2.7) | NR, 0.23
Kallio, 2018^*^,^290^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 9 | 21.1 (8.1) | 76 | NR | 2.0 (0.9, 3.1) | 21.8 (8.3) | 71 | NR | 2.3 (1.1, 3.5) | NR, 0.43
Kurz, 2012^274^; Fair | Dem | MMSE (0–30) | IG1 | 9 | 25.01 (2.16) | 83 | NR | −1.48 (3.77) | 25.11 (2.20) | 88 | NR | −2.22 (3.24) | NR, 0.175
Olazaran, 2004^267^; Fair | MCI + Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 24.7 (1.5)^‡^ | 40 | NR | 0 (NR) | 25.8 (1.6)^‡^ | 40 | NR | 0.5 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 24.7 (1.5)^‡^ | 40 | NR | 0 (NR) | 25.8 (1.6)^‡^ | 40 | NR | 2 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 24.7 (1.5)^‡^ | 40 | NR | 4 (NR) | 25.8 (1.6)^‡^ | 40 | NR | 6.5 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | MMSE (0–30) | IG1 | 3 | NR | 40 | NR | 0 (NR) | NR | 40 | NR | −0.51 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | MMSE (0–30) | IG1 | 6 | NR | 40 | NR | −0.5 (NR) | NR | 40 | NR | −1.5 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | MMSE (0–30) | IG1 | 12 | NR | 40 | NR | −1.5 (NR) | NR | 40 | NR | −2.1 (NR) | NS
Orrell, 2014^*^,^281^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 31.1 (14.6) | 123 | 35.32 (2.56)^‡^ | NR | 33.2 (13.0) | 113 | 34.47 (2.59)^‡^ | NR | Adj MD (95% CI)=−0.85 (−3.40, 1.70), 0.27
Orrell, 2014^*^,^281^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 31.1 (14.6) | 123 | 35.94 (2.79)^‡^ | NR | 33.2 (13.0) | 113 | 35.29 (2.85)^‡^ | NR | Adj MD (95% CI)=−0.65 (−3.71, 2.42), 0.67
Orrell, 2014^*^,^281^; Good | Dem | MMSE (0–30) | IG1 | 3 | 17.8 (5.6) | 123 | 16.09 (0.88)^‡^ | NR | 17.8 (5.4) | 113 | 15.79 (0.91)^‡^ | NR | Adj MD (95% CI)=−0.30 (−0.72, 1.31), 0.56
Orrell, 2014^*^,^281^; Good | Dem | MMSE (0–30) | IG1 | 6 | 17.8 (5.6) | 123 | 16.34 (1.21)^‡^ | NR | 17.8 (5.4) | 113 | 15.49 (1.25)^‡^ | NR | Adj MD (95% CI)=0.85 (−0.29, 1.99), 0.15
Orrell, 2017^*^,^275^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 21.47 (9.22) | 142 | 20.86 (9.73) | −0.29 (5.87) | 19.79 (8.03) | 146 | 19.50 (8.97) | 0.03 (6.16) | Adj MD (95% CI)=0.29 (−1.10, 1.68), 0.68
Orrell, 2017^*^,^275^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 21.47 (9.22) | 134 | 20.69 (9.39) | 0.33 (5.65) | 19.79 (8.03) | 139 | 20.39 (9.91) | 1.24 (5.94) | Adj MD (95% CI)=−0.55 (−2.00, 0.90), 0.45
Orrell, 2017^*^,^275^; Good | Dem | MMSE (0–30) | IG1 | 3 | 21.12 (4.48) | 142 | 20.59 (5.02) | −0.46 (3.18) | 21.33 (4.11) | 146 | 20.89 (4.83) | −0.87 (3.5) | Adj MD (95% CI)=0.16 (−0.60, 0.92), 0.69
Orrell, 2017^*^,^275^; Good | Dem | MMSE (0–30) | IG1 | 6 | 21.12 (4.48) | 134 | 20.68 (4.76) | −0.96 (2.99) | 21.33 (4.11) | 139 | 21.19 (5.21) | −0.67 (3.62) | Adj MD (95% CI)=−0.47 (−1.26, 0.30), 0.23
Pantoni, 2017^*^,^289^; Fair | MCI | MMSE (0–30) | IG1 | 6 | 27.1 (2.6) | 21 | NR | −0.3 (1.9) | 25.7 (3.2) | 22 | NR | −0.8 (1.9) | NR, 0.458
Pantoni, 2017^*^,^289^; Fair | MCI | MMSE (0–30) | IG1 | 12 | 27.1 (2.6) | 21 | NR | −0.7 (2.8) | 25.7 (3.2) | 22 | NR | −0.3 (1.8) | NR, 0.601
Pantoni, 2017^*^,^289^; Fair | MCI | MMSE (0–30)^ǁ^ | IG1 | 6 | NA | 21 | 20 (95.2)^§^ | NA | NA | 22 | 22 (100.0)^§^ | NA | NR, 0.300
Pantoni, 2017^*^,^289^; Fair | MCI | MMSE (0–30)^ǁ^ | IG1 | 12 | NA | 21 | 20 (95.2)^§^ | NA | NA | 22 | 21 (95.4)^§^ | NA | NR, 0.973
Quayhagen, 1995^272^; Fair | Dem | MDRS (0–144) | IG1 | 3 | 109.8 (12.0) | 25 | 113.1 (11.7) | NR | 109.2 (11.7) | 25 | 104.8 (13.9) | NR | NR
Quayhagen, 1995^272^; Fair | Dem | MDRS (0–144) | IG1 | 9 | 109.8 (12.0) | 25 | 107.6 (15.1) | NR | 109.2 (11.7) | 25 | 96.6 (20.2) | NR | NR
Tsantali, 2017^*^,^285^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 23.2 (1.6) | 17 | 27.0 (1.0) | NR | 23.1 (1.4) | 21 | 21.6 (1.6) | NR | NR, <0.05
Tsantali, 2017^*^,^285^; Fair | Dem | MMSE (0–30) | IG2 | 12 | 22.5 (0.9) | 17 | 20.9 (1.0) | NR | 23.1 (1.4) | 21 | 21.6 (1.6) | NR | NS
Tsolaki, 2011^265^; Fair | MCI | MMSE (0–30) | IG1 | 6 | 28.09 (1.59) | 104 | 29.00 (6.18) | NR | 27.59 (1.88) | 72 | 27.06 (2.34) | NR | NR, 0.000
Vidovich, 2015^*^,^278^; Good | MCI | CAMCOG-R (0–105) | IG1 | 12 | 89.5 (6.9) | 77 | NR | 1.0 (0.3, 1.8) | 90.6 (6.4) | 77 | NR | 1.1 (0.4, 1.9) | NR
Vidovich, 2015^*^,^278^; Good | MCI | CAMCOG-R (0–105) | IG1 | 24 | 89.5 (6.9) | 67 | NR | −0.6 (−2.3, 1.0) | 90.6 (6.4) | 60 | NR | 0.8 (−0.8, 2.5) | NR, 0.276
Vidovich, 2015^*^,^278^; Good | MCI | MMSE (0–30) | IG1 | 24 | NR | 67 | 9 (13.4)^§^ | NR | NR | 60 | 2 (3.3)^§^ | NR | OR (95% CI)=3.48 (0.92, 13.18), NS^¶^
Exercise Interventions
Doi, 2017^*^,^306^; Good | MCI | MMSE (0–30) | IG1 | 9 | 26.0 (2.6) | 55 | NR | 0.29 (2.6) | 25.8 (2.4) | 63 | NR | −0.36 (2.3) | NR, 0.026
Hoffmann, 2016^*^,^304^; Good | Dem | MMSE (0–30) | IG1 | 4 | 23.8 (3.4) | 102 | 23.9 (3.4) | NR | 24.1 (3.8) | 88 | 23.9 (3.9) | NR | MDC (95% CI)=0.5 (0.3, 1.2) 0.244
Holthoff, 2015^*^,^305^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 22.05 (0.54)^‡^ | 15 | 21.99 (0.54)^‡^ | NR | 21.95 (0.54)^‡^ | 15 | 21.28 (0.54)^‡^ | NR | Adj MD (95% CI)=0.70 (−0.83, 2.23) NR
Holthoff, 2015^*^,^305^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 22.05 (0.54)^‡^ | 13 | 22.11 (0.57)^‡^ | NR | 21.95 (0.54)^‡^ | 14 | 20.72 (0.55)^‡^ | NR | Adj MD (95% CI)=1.39 (−0.21, 2.98) NS
Hong, 2017^*^,^302^; Fair | MCI | MoCA (0–30) | IG1 | 3 | 20.70 (3.46) | 10 | 21.70 (3.05) | NR | 20.08 (4.44) | 12 | 20.50 (5.05) | NR | NR, p=0.506
Lamb, 2018^*^,^308^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 21.4 (9.6) | 298 | 22.9 (11.6) | NR | 21.8 (7.7) | 145 | 22.4 (9.4) | NR | Adj MD (95% CI)= −0.6 (−1.58, 0.39), 0.237
Lamb, 2018^*^,^308^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 21.4 (9.6) | 278 | 25.2 (12.3) | NR | 21.8 (7.7) | 137 | 23.8 (10.4) | NR | Adj MD (95% CI)= −1.4 (−2.6, −0.2), 0.03
Lam, 2011^295^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 5 | 12.6 (5.1) | 135 | 10.7 (5.5) | 2.0 (3.9) | 14.1 (5.7) | 194 | 12.8 (6.1) | 1.3 (3.8) | NR
Lam, 2011^295^; Fair | MCI | MMSE (0–30) | IG1 | 5 | 24.8 (3.1) | 135 | 25.8 (3.1) | 0.9 (2.3) | 24.2 (2.9) | 194 | 25.1 (3.6) | 0.8 (2.7) | NR
Lautenschlager, 2008^294^; Good | MCI | ADAS-Cog 11 (0–70) | IG1 | 6 | NR | 85 | NR | −0.26 (−0.89, 0.54) | NR | 85 | NR | 1.04 (0.32, 1.82) | NR
Lautenschlager, 2008^294^; Good | MCI | ADAS-Cog 11 (0–70) | IG1 | 12 | NR | 85 | NR | −0.55 (−1.15, 0.20) | NR | 85 | NR | 0.04 (−0.66, 0.64) | NR
Lautenschlager, 2008^294^; Good | MCI | ADAS-Cog 11 (0–70) | IG1 | 17 | NR | 85 | NR | −0.73 (−1.27, 0.03) | NR | 85 | NR | −0.04 (−0.46, 0.88) | NR, 0.04
Lazarou, 2017^*^,^301^; Fair | MCI | MMSE (0–30) | IG1 | 10 | 27.60 (2.19) | 66 | 28.00 (2.39) | NR | 26.88 (2.1) | 63 | 25.65 (3.27) | NR | NR, 0.000
Liu-Ambrose, 2016^*^,^293^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 11.7 (5.5) | 35 | NR | −1.61 (0.50)^‡^ | 10.2 (5.4) | 35 | NR | 0.10 (0.53)^‡^ | MDC (95% CI)=−1.71 (−3.15, −0.26), 0.02
Liu-Ambrose, 2016^*^,^293^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 11.7 (5.5) | 35 | NR | −1.14 (0.57)^‡^ | 10.2 (5.4) | 35 | NR | −0.51 (0.64)^‡^ | MDC (95% CI)=−0.63 (−2.34, 1.07), 0.46
Pitkälä, 2013^*^,^292^; Good | Dem | MMSE (0–30) | IG1 | 12 | 18.5 (6.3) | 51 | NR | −1.23 (−2.33, −0.14) | 17.7 (6.2) | 51 | NR | −1.08 (−2.17, 0.02) | NR, 0.74
Pitkälä, 2013^*^,^292^; Good | Dem | MMSE (0–30) | IG2 | 12 | 17.8 (6.6) | 68 | NR | −1.63 (−2.64, −0.61) | 17.7 (6.2) | 65 | NR | −1.08 (−2.17, 0.02) | NR, 0.74
Siu, 2018^*^,^311^; Fair | MCI | MMSE (0–30) | IG1 | 4 | 25.46 (1.89) | 80 | 26.74 (2.42) | 1.38 (2.22) | 24.61 (2.75) | 80 | 24.70 (2.90) | 0.11 (2.78) | Beta (95% CI)=1.33 (0.53, 2.13), 0.001
Suzuki, 2012^299^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 6 | 6.3 (2.2) | 24 | NR | −1.2 (−2.1, −0.3) | 6.8 (2.2) | 23 | NR | −0.1 (−1.0, 0.8) | NS
Suzuki, 2012^299^; Fair | MCI | MMSE (0–30) | IG1 | 6 | 26.8 (1.8) | 25 | NR | 0.32 (−0.96, 1.60) | 26.6 (1.6) | 25 | NR | −1.37 (−2.66, −0.07) | NR, <0.05
Suzuki, 2012^299^; Fair | MCI | MMSE (0–30) | IG1 | 12 | 26.8 (1.8) | 25 | NR | −0.47 (−1.75, 0.81) | 26.6 (1.6) | 25 | NR | −0.44 (−1.74, 0.86) | F statistic=3.4, 0.04
Venturelli, 2010^297^; Fair | MCI + Dem | MMSE (0–30) | IG1 | 3 | 22.3 (2.1) | 12 | 23.0 (1.4) | NR | 22.1 (1.7) | 11 | 17.5 (2.1) | NR | NR, <0.05
Vreugdenhil, 2012^300^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 22.7 (9.7) | 20 | 18.5 (9.8) | −4.9 (1.1)^‡^ | 26.6 (16.6) | 20 | 30.6 (17.9) | 2.1 (1.4)^‡^ | NR, 0.001
Vreugdenhil, 2012^300^; Fair | Dem | MMSE (0–30) | IG1 | 4 | 22.9 (5.0) | 20 | 23.9 (5.0) | 1.0 (1.4)^‡^ | 21.0 (6.3) | 20 | 19.0 (7.7) | −1.6 (0.5)^‡^ | NR, 0.001
Multicomponent and Other
Bae, 2019^*^,^322^; Fair | MCI | MMSE (0–30) | IG1 | 6 | 27.1 (2.1) | 41 | NR | 0.51 (−1.35, 0.34) | 26.7 (2.0) | 42 | NR | 0.35 (−0.44, 1.15) | NR, 0.143
Burgener, 2008^314^; Fair | Dem | MMSE (0–30) | IG1 | 5 | 24.8 (3.5) | 19 | 25.2 (3.1) | 0.4 (NR) | 22.9 (5.2) | 14 | 22.4 (7.6) | −0.5 (NR) | NR, 0.05
Fiatarone Singh, 2014^*^,^280^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 6 | 8.02 (NR) | 27 | 6.26 (NR) | NR | 8.09 (NR) | 27 | 7.14 (NR) | NR | NR
Fiatarone Singh, 2014^*^,^280^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 18 | 8.02 (NR) | 27 | 5.76 (NR) | NR | 8.09 (NR) | 27 | 5.75 (NR) | NR | NR
Jha, 2013^*^,^318^; Fair | MCI + Dem | MMSE (0–30) | IG1 | 6 | 21 (6) | 17 | 21 (6) | −0.06 (NR) | 23 (5) | 17 | 22 (6) | 0.7 (NR) | NR, 0.44
Marshall, 2015^*^,^317^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 23.6 (4.3) | 28 | 22.4 (4.0) | NR | 22.4 (3.7) | 27 | 22.9 (3.1) | NR | MDC (95% CI): −1.34 (−2.88, 0.20), NS
Marshall, 2015^*^,^317^; Fair | Dem | MMSE (0–30) | IG1 | 5 | 23.6 (4.3) | 28 | 22.5 (4.4) | NR | 22.4 (3.7) | 24 | 22.4 (2.9) | NR | MDC (95% CI): −0.45 (−2.07, 1.16), NS
Richard, 2009^319^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 22.3 (3.3) | 57 | 19.7 (5.1) | NR | 22.2 (3.6) | 48 | 19.5 (5.2) | NR | NS
Richard, 2009^319^; Fair | Dem | MMSE (0–30) | IG1 | 24 | 22.3 (3.3) | 50 | 16.8 (8.1) | −5.78 (6.4) | 22.2 (3.6) | 44 | 17.0 (6.4) | −5.23 (6.0) | MDC (95% CI): −0.55 (−3.12, 2.02), 0.65
Rovner, 2018^*^,^320^; Good | MCI | MMSE (0–30) | IG1 | 6 | 25.8 (2.3) | 111 | NR | 0.01 (−0.39, 0.41) | 25.6 (2.5) | 110 | NR | −0.22 (−0.59, 0.15) | ES (95% CI)=0.23 (−0.32, 0.77), 0.41
Shimada, 2017^*^,^323^; Fair | MCI | MMSE (0–30) | IG1 | 9 | 26.6 (1.8) | 154 | NR | 0.0 (−0.4, 0.4) | 26.8 (1.8) | 154 | NR | −0.8 (−1.2, −0.4) | MDC (95% CI)=0.8 (0.2, 1.4), 0.012
Straubmeier, 2017^*^,^324^; Fair | MCI + Dem | MMSE (0–30) | IG1 | 6 | 19.8 (4.8) | 255 | 19.9 (6.0) | NR | 19.3 (4.8) | 178 | 18.3 (6.2) | NR | ES=0.21, 0.033
Train the Brain Consortium, 2017^*^,^321^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 7 | NR | 55 | NR | −1.40 (0.32)^‡^ | NR | 58 | NR | 1.1526. (0.25)^‡^ | MDC (95% CI)=−2.17 (−2.99, −1.34), <0.0001
Train the Brain Consortium, 2017^*^,^321^; Fair | MCI | ADAS-Cog 11 (0–70)^#^ | IG1 | 7 | NA | 55 | 25 (45.4) | NA | NA | 58 | 7 (12.1) | NA | NR, <0.001
Wolfs, 2008^315^; Fair | MCI + Dem | MMSE (0–30) | IG1 | 6 | 20.5 (6.0) | 116 | 18.8 (7.8) | NR | 19.8 (6.6) | 83 | 19.2 (7.5) | NR | MDC (95% CI): −0.9 (−2.23, 0.34), NS
Wolfs, 2008^315^; Fair | MCI + Dem | MMSE (0–30) | IG1 | 12 | 20.5 (6.0) | 113 | 18.0 (7.7) | NR | 19.8 (6.6) | 77 | 17.4 (8.8) | NR | MDC (95% CI): 0.0 (−1.43, 1.48), NS

* New study

† Higher scores indicate better outcomes for all instruments except for ADAS-Cog 11 and ADAS-Cog 13 where lower scores indicate better outcomes

‡ Standard error

§ N (%)

ǁ Participants with stable/better MMSE scores at followup

¶ Odds of attaining a MMSE score <24

# Participants with decerase of 1.5 points on ADAS-Cog (improvement)

Abbreviations: ADAS-Cog 11 = Alzheimer’s Disease Assessment Scale-cognitive subscale; 11-item; ADAS-Cog 13 = Alzheimer’s Disease Assessment Scale-cognitive subscale; 13-item; Adj MD = adjusted mean difference; BL = baseline; CAMCOG-R = Cambridge Cognitive Examination Revised; CG = control group; CI = confidence interval; Dem = dementia; FU = followup; IG = intervention group; Int arm = intervention arm; MCI = mild cognitive impairment; MDC = mean difference in change; MDRS = Mattis Dementia Rating Scale; MMSE = Mini-Mental State Examination; mo. = months; MoCA = Montreal Cognitive Assessment Test; Pop cat = population category; NR = not reported; NS = Not statistically significant; SD = standard deviation

Appendix G Table 2 Patient-Level Nonpharmacologic Interventions: Detailed Results for Physical Function Outcomes, by Intervention Type

Author, year Quality | Pop cat | ADL or IADL (Instrument, range, direction) | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Cognitive Stimulation, Training, and Rehabilitation
Amieva, 2016^*^,^277^; Good | Dem | ADL/IADL (DAD, 0–40, ↑) | IG1 | 3 | 26.5 (8.1) | 151 | 27.54 (9.2) | NR | 26.6 (8.8) | 141 | 26.94 (9.6) | NR | NR, 0.6201
Amieva, 2016^*^,^277^; Good | Dem | ADL/IADL (DAD, 0–40, ↑) | IG1 | 24 | 26.5 (8.1) | 124 | 24.74 (13.4) | NR | 26.6 (8.8) | 109 | 25.38 (13.4) | NR | NR, 0.6695
Amieva, 2016^*^,^277^; Good | Dem | ADL/IADL (DAD, 0–40, ↑) | IG2 | 3 | 26.5 (8.1) | 144 | 28.19 (9.4) | NR | 26.6 (8.8) | 141 | 26.94 (9.6) | NR | NR,
Amieva, 2016^*^,^277^; Good | Dem | ADL/IADL (DAD, 0–40, ↑) | IG2 | 24 | 26.5 (8.1) | 121 | 27.04 (11.9) | NR | 26.6 (8.8) | 109 | 25.38 (13.4) | NR | NR, 0.3882
Belleville, 2018^*^,^291^; Fair | MCI | ADL (ADL-PI, 0–45, ↓) | IG1 | 3 | 38.66 (4.95) | 36 | 39.31 (4.39) | NR | 37.70 (5.11) | 38 | 38.24 (6.07) | NR | NS
Belleville, 2018^*^,^291^; Fair | MCI | ADL (ADL-PI, 0–45, ↓) | IG1 | 6 | 38.66 (4.95) | 31 | 39.28 (4.41) | NR | 37.70 (5.11) | 38 | 38.30 (5.67) | NR | NS
Bergamaschi, 2013^*^,^282^; Fair | Dem | ADL (Katz Index, 0–6, ↑) | IG1 | 12 | 5.06 (1.12) | 16 | 4.75 (1.34) | NR | 5.18 (1.18) | 16 | 3.75 (1.75) | NR | NR, <0.05
Bergamaschi, 2013^*^,^282^; Fair | Dem | IADL (Lawton and Brody IADL, 0–8, ↑) | IG1 | 12 | 3.94 (2.51) | 16 | 3.56 (2.34) | NR | 3.94 (2.41) | 16 | 2.62 (1.76) | NR | NS
Cahn-Weiner, 2003^269^; Fair | Dem | ADL/IADL (Lawton and Brody IADL + Physical Self Maintenance Scale, NR, ↑) | IG1 | 3 | 18.8 (5.0) | 15 | 19.4 (4.8) | NR | 20.7 (4.8) | 14 | 20.2 (5.7) | NR | NS
Chapman, 2004^268^; Fair | Dem | ADL/IADL (TFLS, 0–52, ↓) | IG1 | 4 | NR | 26 | 30.5 (NR) | NR | NR | 28 | 29.7 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | ADL/IADL (TFLS, 0–52, ↓) | IG1 | 7 | NR | 26 | 29.0 (NR) | NR | NR | 28 | 28.7 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | ADL/IADL (TFLS, 0–52, ↓) | IG1 | 12 | NR | 26 | 28.5 (NR) | −2.89 (−5.66, −0.12) | NR | 28 | 26.4 (NR) | −6.86 (NR) (−10.72, −3.00) | ES=0.12, NS
Fiatarone Singh, 2014^*^,^280^; Fair | MCI | IADL (B-ADL,1–10^†^, ↓) | IG2 | 6 | 0.3 (NR) | 24 | 0.1 (NR) | NR | 0.2 (NR) | 27 | 0.1 (NR) | NR | NS
Fiatarone Singh, 2014^*^,^280^; Fair | MCI | IADL (B-ADL,1–10^†^, ↓) | IG2 | 18 | 0.3 (NR) | 24 | 0.1 (NR) | NR | 0.2 (NR) | 27 | 0.1 (NR) | NR | NS
Hyer, 2016^*^,^287^; Fair | MCI | IADL (FAQ, 0–30, ↓) | IG1 | 5 | 1.72 (3.59) | 34 | 1.33 (3.18) | NR | 2.06 (2.49) | 34 | 3.12 (4.53) | NR | NR, 0.04
Jelcic, 2012^*^,^284^; Fair | Dem | IADL (Lawton and Brody IADL, 0–8, ↑) | IG1 | 3 | 7.3 (1.7) | 20 | 7.4 (1.6) | NR | 6.6 (2.1) | 20 | 6.6 (2.2) | NR | NS
Jeong, 2016^*^,^276^; Fair | MCI | IADL (B-ADL,1–10, ↓) | IG1 | 3 | 2.7 (1.3) | 71 | NR | −0.1 (1.2) | 2.7 (1.3) | 76 | NR | −0.1 (0.8) | NR, 0.81
Jeong, 2016^*^,^276^; Fair | MCI | IADL (B-ADL,1–10, ↓) | IG1 | 9 | 2.7 (1.3) | 67 | NR | 0.0 (1.1) | 2.7 (1.3) | 62 | NR | 0.2 (1.2) | NR, 0.22
Jeong, 2016^*^,^276^; Fair | MCI | IADL (B-ADL,1–10, ↓) | IG2 | 3 | 2.5 (1.3) | 77 | NR | 0.0 (1.0) | 2.7 (1.3) | 76 | NR | −0.1 (0.8) | NR, 0.93
Jeong, 2016^*^,^276^; Fair | MCI | IADL (B-ADL,1–10, ↓) | IG2 | 9 | 2.5 (1.3) | 68 | NR | 0.2 (1.3) | 2.7 (1.3) | 62 | NR | 0.2 (1.2) | NR, 0.71
Kurz, 2012^274^; Fair | Dem | IADL (B-ADL,1–10, ↓) | IG1 | 3 | 3.54 (1.88) | 92 | NR | 0.13 (1.25) | 3.67 (1.93) | 97 | NR | 0.28 (1.53) | NR, 0.44
Kurz, 2012^274^; Fair | Dem | IADL (B-ADL,1–10, ↓) | IG1 | 9 | 3.54 (1.88) | 83 | NR | 0.73 (1.82) | 3.67 (1.93) | 88 | NR | 0.86 (1.59) | NR, 0.64
Olazaran, 2004^267^; Fair | MCI + Dem | IADL (FAQ, 0–30, ↓) | IG1 | 3 | 15.3 (1.1)^‡^ | 40 | NR | 1.5 (NR) | 14.1 (1.1)^‡^ | 40 | NR | 2 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | IADL (FAQ, 0–30, ↓) | IG1 | 6 | 15.3 (1.1)^‡^ | 40 | NR | 2.1 (NR) | 14.1 (1.1)^‡^ | 40 | NR | 4.6 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | IADL (FAQ, 0–30, ↓) | IG1 | 12 | 15.3 (1.1)^‡^ | 40 | NR | 4.2 (NR) | 14.1 (1.1)^‡^ | 40 | NR | 6 (NR) | NS
Orrell, 2014^*^,^281^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 3 | 42.7 (17.2) | 123 | 43.58 (2.32)^‡^ | NR | 41.5 (18.1) | 113 | 40.94 (2.32)^‡^ | NR | Adj MD (95% CI)=2.64 (0.08, 5.20), 0.04
Orrell, 2014^*^,^281^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 42.7 (17.2) | 123 | 43.29 (2.88)^‡^ | NR | 41.5 (18.1) | 113 | 42.35 (2.87)^‡^ | NR | Adj MD (95% CI)=0.94 (−2.04, 3.92), 0.54
Orrell, 2017^*^,^275^; Good | Dem | ADL/IADL (Bristol ADL, 0–60, ↓) | IG1 | 3 | 5.16 (5.45) | 142 | 14.53 (10.34) | 9.51 (6.23) | 4.49 (4.09) | 146 | 13.55 (8.20) | 9.35 (5.91) | Adj MD (95% CI)=−0.20 (−1.44, 1.04), 0.75
Orrell, 2017^*^,^275^; Good | Dem | ADL/IADL (Bristol ADL, 0–60, ↓) | IG1 | 6 | 5.16 (5.45) | 134 | 15.39 (10.78) | 10.52 (6.97) | 4.49 (4.09) | 139 | 14.56 (8.86) | 10.55 (6.54) | Adj MD (95% CI)=−0.66 (−2.07, 0.75), 0.36
Pantoni, 2017^*^,^289^; Fair | MCI | ADL (Katz Index, 0–6, ↑) | IG1 | 6 | 5.9 (0.3) | 21 | NR | 0.1 (0.3) | 5.9 (0.4) | 22 | NR | 0 (0) | NR, 0.145
Pantoni, 2017^*^,^289^; Fair | MCI | ADL (Katz Index, 0–6, ↑) | IG1 | 12 | 5.9 (0.3) | 21 | NR | 0 (0.9) | 5.9 (0.4) | 22 | NR | −0.2 (0.7) | NR, 0.262
Pantoni, 2017^*^,^289^; Fair | MCI | ADL/IADL (DAD, 0–100, ↑) | IG1 | 6 | 91.9 (11.9) | 21 | NR | −2.2 (10.3) | 84.2 (17.8) | 22 | NR | −3.9 (11.3) | NR, 0.612
Pantoni, 2017^*^,^289^; Fair | MCI | ADL/IADL (DAD, 0–100, ↑) | IG1 | 12 | 91.9 (11.9) | 21 | NR | −8.4 (21.1) | 84.2 (17.8) | 22 | NR | −6.9 (17.2) | NR, 0.800
Pantoni, 2017^*^,^289^; Fair | MCI | IADL (Lawton and Brody IADL, 0–8, ↑) | IG1 | 6 | 1.9 (2.1) | 21 | NR | −0.4 (1.1) | 2.2 (2.4) | 22 | NR | 0 (0.9) | NR, 0.240
Pantoni, 2017^*^,^289^; Fair | MCI | IADL (Lawton and Brody IADL, 0–8, ↑) | IG1 | 12 | 1.9 (2.1) | 21 | NR | −0.7 (1.1) | 2.2 (2.4) | 22 | NR | −1 (1.7) | NR, 0.457
Tsolaki, 2011^265^; Fair | MCI | ADL (FRSSD, NR, ↓) | IG1 | 6 | 3.04 (1.61) | 104 | 2.67 (1.7) | NR | 3.11 (1.68) | 72 | 3.91 (2.49) | NR | NR, 0.001
Exercise Interventions
Dawson, 2016^*^,^307^; Fair | Dem | ADL/IADL (ADL/IADL [unspecified], 0–48, ↓) | IG1 | 3 | 7.25 (5.13) | 13 | 6.83 (5.13) | NR | 4.20 (3.85) | 10 | 5.40 (6.72) | NR | NR, 0.36
Ho, 2018^*^,^310^; Fair | MCI + Dem | IADL (Lawton and Brody IADL, 0–18, ↑) | IG1 | 3 | 12.8 (5.0) | 69 | 13.2 (4.9) | NR | 14.0 (4.9) | 68 | 12.6 (5.9) | NR | Beta (SE)=1.92 (0.58), <0.01
Ho, 2018^*^,^310^; Fair | MCI + Dem | IADL (Lawton and Brody IADL, 0–18, ↑) | IG1 | 6 | 12.8 (5.0) | 69 | 12.8 (5.0) | NR | 14.0 (4.9) | 68 | 11.7 (6.2) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | IADL (Lawton and Brody IADL, 0–18, ↑) | IG1 | 12 | 12.8 (5.0) | 69 | 11.8 (6.0) | NR | 14.0 (4.9) | 68 | 11.4 (6.2) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | IADL (Lawton and Brody IADL, 0–18, ↑) | IG2 | 3 | 12.8 (5.2) | 67 | 11.8 (5.4) | NR | 14.0 (4.9) | 68 | 12.6 (5.9) | NR | Beta (SE)=0.74 (0.59), 0.21
Ho, 2018^*^,^310^; Fair | MCI + Dem | IADL (Lawton and Brody IADL, 0–18, ↑) | IG2 | 6 | 12.8 (5.2) | 67 | 11.1 (6.1) | NR | 14.0 (4.9) | 68 | 11.7 (6.2) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | IADL (Lawton and Brody IADL, 0–18, ↑) | IG2 | 12 | 12.8 (5.2) | 67 | 10.4 (6.0) | NR | 14.0 (4.9) | 68 | 11.4 (6.2) | NR | NS
Hoffmann, 2016^*^,^304^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 4 | 64.8 (8.8) | 102 | 64.4 (9.4) | NR | 62.4 (10.8) | 88 | 62.7 (10.4) | NR | MDC (95% CI)=−0.1 (−1.8, 1.5), 0.868
Holthoff, 2015^*^,^305^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 3 | 60.55 (0.91)^‡^ | 15 | 62.35 (0.91)^‡^ | NR | 60.53 (0.91)^‡^ | 15 | 57.47 (0.91)^‡^ | NR | Adj MD (95% CI)=4.89 (2.30, 7.48), NR
Holthoff, 2015^*^,^305^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 60.55 (0.91)^‡^ | 13 | 61.26 (1.00)^‡^ | NR | 60.53 (0.91)^‡^ | 14 | 53.50 (0.94)^‡^ | NR | Adj MD (95% CI)=7.76 (5.01, 10.51), <0.05
Liu-Ambrose, 2016^*^,^293^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 46.1 (6.8)^‡^ | 35 | NR | 0.77 (0.65)^‡^ | 46.5 (5.1)^‡^ | 35 | NR | 0.49 (0.69)^‡^ | MDC (95% CI)=1.25 (−0.63, 3.13), 0.19
Liu-Ambrose, 2016^*^,^293^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 12 | 46.1 (6.8) | 35 | NR | 0.22 (0.70)^‡^ | 46.5 (5.1) | 35 | NR | −1.13 (0.73)^‡^ | MDC (95% CI)=1.34 (−0.68, 3.37), 0.19
Morris, 2017^*^,^303^; Good | MCI + Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 3 | 88.0 (12.3) | 36 | 89.8 (12.5) | NR | 91.2 (8.0) | 37 | 89.5 (12.8) | NR | NR,
Morris, 2017^*^,^303^; Good | MCI + Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 6 | 88.0 (12.3) | 34 | 89.5 (13.7) | NR | 91.2 (8.0) | 34 | 86.7 (13.3) | NR | ES (95% CI)=5.27 (1.7, 8.84), 0.02
Pitkälä, 2013^*^,^292^; Good | Dem | ADL/IADL (FIM, 18–126, ↑) | IG1 | 3 | 88.5 (19.0) | 61 | NR | −5.52 (−7.21, −3.73) | 86.8 (17.9) | 65 | NR | −6.17 (−7.93, −4.56) | NR
Pitkälä, 2013^*^,^292^; Good | Dem | ADL/IADL (FIM, 18–126, ↑) | IG1 | 6 | 88.5 (19.0) | 61 | NR | −8.9 (−11.2, −6.7) | 86.8 (17.9) | 65 | NR | −11.8 (−14.0, −9.7) | NR, 0.07
Pitkälä, 2013^*^,^292^; Good | Dem | ADL/IADL (FIM, 18–126, ↑) | IG1 | 12 | 88.5 (19.0) | 61 | NR | −10.3 (−13.9, −6.7) | 86.8 (17.9) | 65 | NR | −14.4 (−18.0, −10.9) | NR, 0.12
Pitkälä, 2013^*^,^292^; Good | Dem | ADL/IADL (FIM, 18–126, ↑) | IG2 | 3 | 87.3 (19.1) | 68 | NR | −5.0 (−6.77, −3.44) | 86.8 (17.9) | 65 | NR | −6.17 (−7.93, −4.56) | NR
Pitkälä, 2013^*^,^292^; Good | Dem | ADL/IADL (FIM, 18–126, ↑) | IG2 | 6 | 87.3 (19.1) | 68 | NR | −6.5 (−8.6, −4.4) | 86.8 (17.9) | 65 | NR | −11.8 (−14.0, −9.7) | NR, 0.001
Pitkälä, 2013^*^,^292^; Good | Dem | ADL/IADL (FIM, 18–126, ↑) | IG2 | 12 | 87.3 (19.1) | 68 | NR | −7.1 (−10.5, −3.7) | 86.8 (17.9) | 65 | NR | −14.4 (−18.0, −10.9) | NR, 0.004
Venturelli, 2010^297^; Fair | MCI + Dem | ADL (Barthel Index, 0–100, ↑) | IG1 | 3 | 19.6 (12.8) | 12 | 34.8 (14.9) | NR | 19.6 (11.3) | 11 | 19.3 (11.9) | NR | NR, <0.05
Vreugdenhil, 2012^300^; Fair | Dem | ADL (Barthel Index, 0–100, ↑) | IG1 | 4 | 10.6 (4.1) | 20 | 11.0 (4.1) | 0.5 (0.3)^‡^ | 8.6 (4.2) | 20 | 7.6 (4.5) | −1.1 (0.4)^‡^ | NR, 0.047
Vreugdenhil, 2012^300^; Fair | Dem | IADL (Lawton and Brody IADL, 0–14, ↑) | IG1 | 4 | 99.5 (1.5) | 20 | 99.6 (1.2) | −0.4 (0.8)^‡^ | 98.4 (5.4) | 20 | 94.2 (12.6) | −3.0 (0.9)^‡^ | NR, 0.007
Multicomponent and Other Interventions
Belleville, 2018^*^,^291^; Fair | MCI | ADL (ADL-PI, 0–45, ↓) | IG2 | 3 | 39.63 (5.53) | 40 | 40.24 (4.69) | NR | 37.70 (5.11) | 38 | 38.24 (6.07) | NR | NS
Belleville, 2018^*^,^291^; Fair | MCI | ADL (ADL-PI, 0–45, ↓) | IG2 | 6 | 39.63 (5.53) | 31 | 38.91 (6.66) | NR | 37.70 (5.11) | 38 | 38.30 (5.67) | NR | NS
Fiatarone Singh, 2014^*^,^280^; Fair | MCI | IADL (B-ADL,1–10^†^, ↓) | IG1 | 6 | 0.2 (NR) | 27 | 0.2 (NR) | NR | 0.2 (NR) | 27 | 0.1 (NR) | NR | NS
Fiatarone Singh, 2014^*^,^280^; Fair | MCI | IADL (B-ADL,1–10^†^, ↓) | IG1 | 18 | 0.2 (NR) | 27 | 0.2 (NR) | NR | 0.2 (NR) | 27 | 0.1 (NR) | NR | NS
Richard, 2009^319^; Fair | Dem | ADL/IADL (IDDD - performance scale, 0–44, ↓) | IG1 | 12 | 9.5 (9.4) | 57 | 10.9 (7.4) | NR | 10.7 (9.3) | 48 | 15.2 (10.9) | NR | NS
Richard, 2009^319^; Fair | Dem | ADL/IADL (IDDD - performance scale, 0–44, ↓) | IG1 | 24 | 9.5 (9.4) | 50 | 17.9 (13.5) | 13.75 (10.3) | 10.7 (9.3) | 44 | 22.8 (13.4) | 11.04 (13.1) | MDC (95% CI)=2.71 (−3.14, 8.56), 0.26
Straubmeier, 2017^*^,^324^; Fair | MCI + Dem | ADL (Erlangen Test of ADL, 0–30, ↑) | IG1 | 6 | 17.9 (6.9) | 255 | 18.2 (7.0) | NR | 17.1 (7.5) | 178 | 16.4 (8.4) | NR | ES=0.20, 0.019
Wolfs, 2008^315^; Fair | MCI + Dem | IADL (Lawton and Brody IADL, 0–14, ↑) | IG1 | 6 | 17.1 (5.7) | 116 | 18.7 (6.2) | NR | 16.5 (6.1) | 83 | 18.1 (6.3) | NR | MDC (95% CI) = −0.1 (−1.16, 1.06), NS
Wolfs, 2008^315^; Fair | MCI + Dem | IADL (Lawton and Brody IADL, 0–14, ↑) | IG1 | 12 | 17.1 (5.7) | 113 | 20.2 (6.1) | NR | 16.5 (6.1) | 77 | 20.4 (6.5) | NR | MDC (95% CI) = −0.7 (−1.85, 0.46), NS

* New study

† Scale was logged prior to analysis

‡ Standard error

Abbreviations: ADL = Activities of Daily Living; ADCS-ADL = Alzheimer’s Disease Cooperative Study Activities of Daily Living 23 items; Adj MD = adjusted mean difference; B-ADL = Bayer Activities of Daily Living; Barthel Index = Barthel Index Activities of Daily Living; BL = baseline; Bristol ADL = Bristol Activities of Daily Living Scale; CG = control group; CI = confidence interval; DAD = Disability Assessment for Dementia; Dem = dementia; FAQ = Functional Activities Questionnaire; FIM = Functional Independence Measure; FRSSD = Functional Rating Scale for the Symptoms of Dementia; FU = followup; IADL = Instrumental Activities of Daily Living; IDDD = Interview for Deterioration in Daily Living Activities in Dementia; IG = intervention group; Int arm = intervention arm; Katz Index = Katz Index of Independence in Activities of Daily Living; MCI = mild cognitive impairment; MDC = mean difference in change; mo. = months; Pop cat = population category; NR = not reported; NS = Not statistically significant; SD = standard deviation; TFLS = Texas Functional Living Scale

Appendix G Table 3 Patient-Level Nonpharmacologic Interventions: Detailed Results for Quality of Life Outcomes, by Intervention Type

Author, year Quality | Pop cat | Instrument (range)^†^ | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Cognitive Stimulation, Training, and Rehabilitation
Amieva, 2016^*^,^277^; Good | Dem | QOL-AD (13–52) | IG1 | 3 | NR | 151 | 31.99 (8.0) | NR | NR | 141 | 33.28 (7.7) | NR | NR, 0.2161
Amieva, 2016^*^,^277^; Good | Dem | QOL-AD (13–52) | IG1 | 24 | NR | 124 | 27.39 (9.2) | NR | NR | 109 | 28.83 (9.5) | NR | NR, 0.1304
Amieva, 2016^*^,^277^; Good | Dem | QOL-AD (13–52) | IG2 | 3 | NR | 144 | 32.97 (7.7) | NR | NR | 141 | 33.28 (7.7) | NR | NR, 0.7987
Amieva, 2016^*^,^277^; Good | Dem | QOL-AD (13–52) | IG2 | 24 | NR | 121 | 29.05 (9.2) | NR | NR | 109 | 28.83 (9.5) | NR | NR, 0.9413
Buschert, 2011^271^; Fair | Dem | QOL-AD (13–52) | IG1 | 6 | 39.1 (7.4) | 8 | 38.7 (7.6) | NR | 33.5 (4.0) | 7 | 32.6 (3.8) | NR | NS
Buschert, 2011^271^; Fair | MCI | QOL-AD (13–52) | IG1 | 6 | 35.3 (3.8) | 10 | 35.7 (5.1) | NR | 36.6 (5.0) | 12 | 34.7 (5.5) | NR | NS
Chapman, 2004^268^; Fair | Dem | QOL-AD (0–52)^‡^ | IG1 | 4 | NR | 26 | 35.2 (NR) | NR | NR | 28 | 36.2 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | QOL-AD (0–52)^‡^ | IG1 | 7 | NR | 26 | 36.0 (NR) | NR | NR | 28 | 35.0 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | QOL-AD (0–52)^‡^ | IG1 | 12 | NR | 26 | 35.8 (NR) | 1.05 (−1.32, 3.42) | NR | 28 | 36.0 (NR) | 1.33 (−0.51, 3.17) | ES=0.02, NS
Chapman, 2004^268^; Fair | Dem | QOL-AD (0–52)^§^ | IG1 | 4 | NR | 26 | 37.6 (NR) | NR | NR | 28 | 37.1 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | QOL-AD (0–52)^§^ | IG1 | 7 | NR | 26 | 38.4 (NR) | NR | NR | 28 | 36.9 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | QOL-AD (0–52)^§^ | IG1 | 12 | NR | 26 | 38.5 (NR) | 1.77 (−0.38, 3.92) | NR | 28 | 37.2 (NR) | 0.38 (−1.14, 1.90) | ES=0.26, NS
Chapman, 2004^268^; Fair | Dem | QOL-AD (13–52) | IG1 | 4 | NR | 26 | 38.7 (NR) | NR | NR | 28 | 37.6 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | QOL-AD (13–52) | IG1 | 7 | NR | 26 | 39.5 (NR) | NR | NR | 28 | 37.9 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | QOL-AD (13–52) | IG1 | 12 | NR | 26 | 39.9 (NR) | 2.05 (−0.25, 4.35) | NR | 28 | 37.9 (NR) | −0.10 (−2.43, 2.23) | ES=0.33 , NR, NS
Cove, 2014^*^,^279^; Fair | Dem | QOL-AD (13–52) | IG1 | 3 | 36.43 (6.06) | 21 | 36.45 (5.6) | NR | 34.78 (5.43) | 23 | 35.32 (5.51) | NR | NS
Cove, 2014^*^,^279^; Fair | Dem | QOL-AD (13–52) | IG2 | 3 | 36.42 (5.44) | 24 | 35.65 (5.83) | NR | 34.78 (5.43) | 23 | 35.32 (5.51) | NR | NS
Greenaway, 2012^273^; Fair | MCI | QOL-AD (13–52) | IG1 | 6 | 43.4 (6.0) | 18 | 43.8 (6.2) | 0.6 (2.4) | 43.0 (5.1) | 17 | 43.5 (4.0) | −0.6 (3.1) | Cohen’s d=0.41, NS
Jeong, 2016^*^,^276^; Fair | MCI | QOL-AD (0–52) | IG1 | 3 | NR | 71 | NR | 1.1 (4.2) | NR | 76 | NR | −0.3 (4.1) | NR, 0.05
Jeong, 2016^*^,^276^; Fair | MCI | QOL-AD (0–52) | IG1 | 9 | NR | 67 | NR | 0.7 (3.6) | NR | 62 | NR | −0.1 (4.7) | NR, 0.13
Jeong, 2016^*^,^276^; Fair | MCI | QOL-AD (13–52) | IG2 | 3 | NR | 77 | NR | 0.9 (2.9) | NR | 76 | NR | −0.3 (4.1) | NR, 0.01
Jeong, 2016^*^,^276^; Fair | MCI | QOL-AD (13–52) | IG2 | 9 | NR | 68 | NR | 0.7 (3.3) | NR | 62 | NR | −0.1 (4.7) | NR, 0.04
Kallio, 2018^*^,^290^; Fair | Dem | 15D Index value (0–1) | IG1 | 3 | 0.740 (0.086) | 76 | NR | −0.040 (−0.058, −0.021) | 0.741 (0.083) | 71 | NR | −0.037 (−0.056, −0.018) | NR, 0.82
Kallio, 2018^*^,^290^; Fair | Dem | 15D Index value (0–1) | IG1 | 9 | 0.740 (0.086) | 76 | NR | −0.048 (−0.065, −0.031) | 0.741 (0.083) | 71 | NR | −0.058 (−0.077, −0.038) | NR, 0.61
Kurz, 2012^274^; Fair | Dem | DEMQOL (28–112)^‡^ | IG1 | 3 | 94.3 (14.6) | 92 | NR | −1.10 (10.40) | 89.9 (15.4) | 97 | NR | −2.06 (13.08) | NR, 0.58
Kurz, 2012^274^; Fair | Dem | DEMQOL (28–112)^‡^ | IG1 | 9 | 94.3 (14.6) | 83 | NR | −2.75 (11.47) | 89.9 (15.4) | 88 | NR | −4.89 (13.65) | NR, 0.28
Kurz, 2012^274^; Fair | Dem | DEMQOL (28–112) | IG1 | 3 | 91.3 (12.4) | 92 | NR | 0.52 (9.79) | 87.5 (13.8) | 97 | NR | −0.03 (12.02) | NR, 0.73
Kurz, 2012^274^; Fair | Dem | DEMQOL (28–112) | IG1 | 9 | 91.3 (12.4) | 83 | NR | 0.67 (9.56) | 87.5 (13.8) | 88 | NR | −2.32 (13.05) | NR, 0.09
Orrell, 2014^*^,^281^; Good | Dem | DEMQOL (28–112)^‡^ | IG1 | 3 | 102.2 (13.5) | 123 | 101.36 (2.67)^ǁ^ | NR | 102.2 (11.2) | 113 | 98.12 (2.67)^ǁ^ | NR | Adj MD (95% CI)=3.24 (0.29, 6.19), 0.03
Orrell, 2014^*^,^281^; Good | Dem | DEMQOL (28–112)^‡^ | IG1 | 6 | 102.2 (13.5) | 123 | 97.75 (3.23)^ǁ^ | NR | 102.2 (11.2) | 113 | 96.61 (3.21)^ǁ^ | NR | Adj MD (95% CI)=1.13 (−2.24, 4.51), 0.50
Orrell, 2014^*^,^281^; Good | Dem | DEMQOL (28–112) | IG1 | 3 | 94.8 (10.9) | 123 | 89.85 (2.34)^ǁ^ | NR | 95.1 (11.7) | 113 | 90.71 (2.38)^ǁ^ | NR | Adj MD (95% CI)=−0.86 (−3.45, 1.73), 0.54
Orrell, 2014^*^,^281^; Good | Dem | DEMQOL (28–112) | IG1 | 6 | 94.8 (10.9) | 123 | 89.13 (3.55)^ǁ^ | NR | 95.1 (11.7) | 113 | 88.83 (3.56)^ǁ^ | NR | Adj MD (95% CI)=0.30 (−2.70, 3.31), 0.87
Orrell, 2014^*^,^281^; Good | Dem | QOL-AD (13–52)^‡^ | IG1 | 3 | 33.7 (5.9) | 123 | 33.93 (1.05)^ǁ^ | NR | 33.3 (4.9) | 113 | 32.40 (1.07)^ǁ^ | NR | Adj MD (95% CI)=1.53 (0.37, 2.69), 0.01
Orrell, 2014^*^,^281^; Good | Dem | QOL-AD (13–52)^‡^ | IG1 | 6 | 33.7 (5.9) | 123 | 34.12 (1.41)^ǁ^ | NR | 33.3 (4.9) | 113 | 34.05 (1.41)^ǁ^ | NR | Adj MD (95% CI)=0.07 (−1.39, 1.53), 0.95
Orrell, 2014^*^,^281^; Good | Dem | QOL-AD (13–52) | IG1 | 3 | 36.1 (4.8) | 123 | 34.29 (1.03)^ǁ^ | NR | 36.5 (5.7) | 113 | 33.97 (1.04)^ǁ^ | NR | Adj MD (95% CI)=0.32 (−0.88, 1.52), 0.54
Orrell, 2014^*^,^281^; Good | Dem | QOL-AD (13–52) | IG1 | 6 | 36.1 (4.8) | 123 | 35.62 (1.43)^ǁ^ | NR | 36.5 (5.7) | 113 | 33.84 (1.53)^ǁ^ | NR | Adj MD (95% CI)=1.78 (−0.01, 3.57), 0.03
Orrell, 2017^*^,^275^; Good | Dem | DEMQOL single item (1–4)^‡^ | IG1 | 3 | 93.85 (11.76) | 142 | 94.08 (10.92) | −0.47 (7.59) | 92.18 (13.55) | 146 | 94.05 (11.80) | 0.32 (10.85) | Adj MD (95% CI)=−0.33 (−2.31, 1.65), 0.74
Orrell, 2017^*^,^275^; Good | Dem | DEMQOL single item (1–4)^‡^ | IG1 | 6 | 93.85 (11.76) | 134 | 95.46 (11.17) | 1.09 (7.2) | 92.18 (13.55) | 139 | 95.12 (11.11) | 1.56 (10.39) | Adj MD (95% CI)=0.31 (−1.62, 2.22), 0.79
Orrell, 2017^*^,^275^; Good | Dem | QOL-AD (13–52)^‡^ | IG1 | 3 | 38.01 (5.44) | 142 | 37.90 (5.52) | −0.36 (5.01) | 37.96 (6.04) | 146 | 38.09 (5.63) | −0.13 (4.6) | Adj MD (95% CI)=−0.14 (−1.12, 0.84), 0.78
Orrell, 2017^*^,^275^; Good | Dem | QOL-AD (13–52)^‡^ | IG1 | 6 | 38.01 (5.44) | 134 | 37.86 (5.13) | −0.70 (4.07) | 37.96 (6.04) | 139 | 37.71 (5.91) | −0.43 (5.13) | Adj MD (95% CI)=−0.02 (−1.04, 1.00), 0.97
Pantoni, 2017^*^,^289^; Fair | MCI | EQ-5D index value (−1, 1) | IG1 | 6 | 0.7 (0.3) | 21 | NR | 0.1 (0.2) | 0.7 (0.3) | 22 | NR | 0.1 (0.2) | NR, 0.698
Pantoni, 2017^*^,^289^; Fair | MCI | EQ-5D index value (−1, 1) | IG1 | 12 | 0.7 (0.3) | 21 | NR | 0 (0.3) | 0.7 (0.3) | 22 | NR | 0.1 (0.3) | NR, 0.647
Pantoni, 2017^*^,^289^; Fair | MCI | EQ-VAS (0–100) | IG1 | 6 | 63.1 (18.3) | 21 | NR | 5.2 (15.3) | 67.3 (17.5) | 22 | NR | −2.3 (9.2) | NR, 0.057
Pantoni, 2017^*^,^289^; Fair | MCI | EQ-VAS (0–100) | IG1 | 12 | 63.1 (18.3) | 21 | NR | 5.0 (14.2) | 67.3 (17.5) | 22 | NR | −4.3 (16.6) | NR, 0.056
Pantoni, 2017^*^,^289^; Fair | MCI | SF-36 MCS (0–100) | IG1 | 6 | NR | 21 | NR | 1.4 (5.3) | NR | 22 | NR | 3.0 (11.4) | NR, 0.567
Pantoni, 2017^*^,^289^; Fair | MCI | SF-36 MCS (0–100) | IG1 | 12 | NR | 21 | NR | 1.3 (7.0) | NR | 22 | NR | 0.2 (9.6) | NR, 0.668
Pantoni, 2017^*^,^289^; Fair | MCI | SF-36 PCS (0–100) | IG1 | 6 | NR | 21 | NR | −1.1 (6.5) | NR | 22 | NR | −1.9 (8.2) | NR, 0.709
Pantoni, 2017^*^,^289^; Fair | MCI | SF-36 PCS (0–100) | IG1 | 12 | NR | 21 | NR | −2.0 (8.1) | NR | 22 | NR | −1.5 (10.2) | NR, 0.867
Vidovich, 2015^*^,^278^; Good | MCI | QOL-AD (13–52) | IG1 | 12 | NR | 77 | NR | 0.0 (−0.7, 0.8) | NR | 77 | NR | −0.9 (−1.6, −0.1) | NR
Vidovich, 2015^*^,^278^; Good | MCI | QOL-AD (13–52) | IG1 | 24 | NR | 67 | NR | −0.1 (−0.9, 0.7) | NR | 60 | NR | −1.0 (−1.8, −0.2) | NR, 0.018
Exercise Interventions
Hoffmann, 2016^*^,^304^; Good | Dem | EQ-5D index value (−0.624–1)^‡^ | IG1 | 4 | 0.88 (0.12) | 102 | 0.87 (0.12) | NR | 0.86 (0.11) | 88 | 0.85 (0.13) | NR | MDC (95% CI)=0.02 (−0.02, 0.06), 0.300
Hoffmann, 2016^*^,^304^; Good | Dem | EQ-5D index value (−0.624–1) | IG1 | 4 | 0.93 (0.10) | 102 | 0.92 (0.11) | NR | 0.93 (0.09) | 88 | 0.92 (0.09) | NR | MDC (95% CI)=0.01 (−0.02, 0.04), 0.402
Hoffmann, 2016^*^,^304^; Good | Dem | EQ-VAS (0–100)^‡^ | IG1 | 4 | 72.9 (18.0) | 102 | 71.1 (19.0) | NR | 73.8 (17.1) | 88 | 70.2 (17.2) | NR | MDC (95% CI)=2.0 (−2.7, 6.7), 0.406
Hoffmann, 2016^*^,^304^; Good | Dem | EQ-VAS (0–100) | IG1 | 4 | 83.2 (13.7) | 102 | 82.5 (15.5) | NR | 83.3 (15.5) | 88 | 80.7 (16.6) | NR | MDC (95% CI)=2.7 (−2.2, 7.7), 0.283
Lamb, 2018^*^,^308^; Good | Dem | EQ-5D-3L (0–1) | IG1 | 6 | 0.82 (0.20) | 292 | 0.80 (0.21) | NR | 0.85 (0.18) | 139 | 0.83 (0.21) | NR | Adj MD (95% CI)=0.02 (−0.01, 0.06), 0.240
Lamb, 2018^*^,^308^; Good | Dem | EQ-5D-3L (0–1) | IG1 | 12 | 0.82 (0.20) | 261 | 0.81 (0.22) | NR | 0.85 (0.18) | 131 | 0.82 (0.25) | NR | Adj MD (95% CI)=−0.002 (−0.04, 0.04), 0.928
Lamb, 2018^*^,^308^; Good | Dem | EQ-5D-3L (0–1)^‡^ | IG1 | 6 | 0.68 (0.24) | 277 | 0.64 (0.27) | NR | 0.70 (0.24) | 134 | 0.65 (0.29) | NR | Adj MD (95% CI)=−0.01 (−0.06, 0.03), 0.53
Lamb, 2018^*^,^308^; Good | Dem | EQ-5D-3L (0–1)^‡^ | IG1 | 12 | 0.68 (0.24) | 259 | 0.60 (0.28) | NR | 0.70 (0.24) | 128 | 0.60 (0.32) | NR | Adj MD (95% CI)=−0.02 (−0.07, 0.03), 0.43
Lamb, 2018^*^,^308^; Good | Dem | EQ-VAS (0–100) | IG1 | 6 | NR | 288 | 75.4 (20.6) | NR | NR | 138 | 78.7 (18.8) | NR | Adj MD (95% CI)=−0.1 (−3.62, 3.36), 0.942
Lamb, 2018^*^,^308^; Good | Dem | EQ-VAS (0–100) | IG1 | 12 | NR | 261 | 75.5 (19.3) | NR | NR | 124 | 78.3 (19.4) | NR | Adj MD (95% CI)=1.4 (−2.58, 5.23), 0.464
Lamb, 2018^*^,^308^; Good | Dem | EQ-VAS (0–100)^‡^ | IG1 | 6 | NR | 278 | 66.1 (20.1) | NR | NR | 135 | 65.4 (20.5) | NR | Adj MD (95% CI)=−0.6 (−4.3, 3.1), 0.74
Lamb, 2018^*^,^308^; Good | Dem | EQ-VAS (0–100)^‡^ | IG1 | 12 | NR | 260 | 65.0 (20.0) | NR | NR | 128 | 65.6 (19.9) | NR | Adj MD (95% CI)=1.2 (−2.4, 4.8), 0.52
Lamb, 2018^*^,^308^; Good | Dem | QOL-AD (13–52) | IG1 | 6 | 38.7 (5.6) | 263 | 38.9 (6.1) | NR | 39.3 (5.2) | 124 | 39.0 (5.9) | NR | Adj MD (95% CI)=−0.1 (−0.98, 0.84), 0.879
Lamb, 2018^*^,^308^; Good | Dem | QOL-AD (13–52) | IG1 | 12 | 38.7 (5.6) | 237 | 38.4 (5.8) | NR | 39.3 (5.2) | 119 | 39.1 (5.7) | NR | Adj MD (95% CI)=0.7 (−0.21, 1.65), 0.127
Lamb, 2018^*^,^308^; Good | Dem | QOL-AD (13–52)^‡^ | IG1 | 6 | NR | 239 | 31.6 (6.2) | NR | NR | 114 | 31.3 (6.2) | NR | Adj MD (95% CI)=0.1 (−0.9, 1.0), 0.89
Lamb, 2018^*^,^308^; Good | Dem | QOL-AD (13–52)^‡^ | IG1 | 12 | NR | 234 | 30.6 (6.1) | NR | NR | 118 | 30.6 (6.0) | NR | Adj MD (95% CI)=0.02 (−1.0, 1.0), 0.96
Lautenschlager, 2008^294^; Good | MCI | SF-36 MCS (0–100) | IG1 | 6 | NR | 85 | NR | 5.13 (3.40, 6.86) | NR | 85 | NR | 4.37 (2.73, 6.01) | NR
Lautenschlager, 2008^294^; Good | MCI | SF-36 MCS (0–100) | IG1 | 12 | NR | 85 | NR | 6.31 (4.80, 7.82) | NR | 85 | NR | 3.38 (1.63, 5.14) | NR
Lautenschlager, 2008^294^; Good | MCI | SF-36 MCS (0–100) | IG1 | 17 | NR | 85 | NR | 4.58 (2.38, 6.78) | NR | 85 | NR | 2.74 (0.77, 4.72) | NR, 0.67
Lautenschlager, 2008^294^; Good | MCI | SF-36 PCS (0–100) | IG1 | 6 | NR | 85 | NR | −4.04 (−5.71, −2.37) | NR | 85 | NR | −4.40 (−6.10, −2.70) | NR
Lautenschlager, 2008^294^; Good | MCI | SF-36 PCS (0–100) | IG1 | 12 | NR | 85 | NR | −4.49 (−6.03, −2.96) | NR | 85 | NR | −3.73 (−5.67, −1.79) | NR
Lautenschlager, 2008^294^; Good | MCI | SF-36 PCS (0–100) | IG1 | 17 | NR | 85 | NR | −4.85 (−6.78, −2.92) | NR | 85 | NR | −4.69 (−6.52, −2.87) | NR, 0.95
Multicomponent and Other Interventions
Jha, 2013^*^,^318^; Fair | MCI + Dem | EQ-5D (0–100) | IG1 | 6 | NR | 17 | 64 (12) | 3.82 (NR) | NR | 17 | 66 (10) | −2.1 (NR) | NR, 0.66
Jha, 2013^*^,^318^; Fair | MCI + Dem | WHO-5 (0–100) | IG1 | 6 | NR | 17 | 61 (10) | 18.3 (NR) | NR | 17 | 58 (13) | 9.46 (NR) | NR, 0.03
Marshall, 2015^*^,^317^; Fair | Dem | QOL-AD (13–52)^‡^ | IG1 | 3 | 31.5 (6.6) | 28 | 30.3 (7.0) | NR | 33.6 (5.7) | 27 | 32.5 (6.6) | NR | MDC (95% CI)=−0.50 (−2.90, 1.88), NS
Marshall, 2015^*^,^317^; Fair | Dem | QOL-AD (13–52)^‡^ | IG1 | 5 | 31.5 (6.6) | 28 | 30.8 (6.7) | NR | 33.6 (5.7) | 24 | 32.9 (5.2) | NR | MDC (95% CI)=−0.31 (−3.09, 2.47), NS
Marshall, 2015^*^,^317^; Fair | Dem | QOL-AD (13–52) | IG1 | 3 | 34.4 (5.8) | 28 | 35.4 (7.2) | NR | 37.5 (4.6) | 27 | 36.3 (6.5) | NR | MDC (95% CI)=2.12 (−0.17, 4.42), NS
Marshall, 2015^*^,^317^; Fair | Dem | QOL-AD (13–52) | IG1 | 5 | 34.4 (5.8) | 28 | 35.9 (6.3) | NR | 37.5 (4.6) | 24 | 38.7 (5.8) | NR | MDC (95% CI)=0.30 (−2.09, 2.69), NS
Quinn, 2016^*^,^316^; Good | Dem | EQ-5D-3L (0–1) | IG1 | 3 | NR | 13 | NR | NR | NR | 11 | NR | NR | Adj MD (95% CI)=0.05 (−0.05, 0.14), NS
Quinn, 2016^*^,^316^; Good | Dem | EQ-5D-3L (0–1) | IG1 | 6 | NR | 13 | NR | NR | NR | 11 | NR | NR | Adj MD (95% CI)=−0.04 (−0.15, 0.07), NS
Wolfs, 2008^315^; Fair | MCI + Dem | EQ-5D index value (0–1)^‡^ | IG1 | 6 | 0.54 (0.33) | 116 | 0.58 (0.33) | NR | 0.54 (0.30) | 83 | 0.53 (0.33) | NR | MDC (95% CI)=0.1 (−0.04, 0.12), NS
Wolfs, 2008^315^; Fair | MCI + Dem | EQ-5D index value (0–1)^‡^ | IG1 | 12 | 0.54 (0.33) | 113 | 0.49 (0.35) | NR | 0.54 (0.30) | 77 | 0.43 (0.34) | NR | MDC (95% CI)=0.1 (−0.04, 0.14), NS
Wolfs, 2008^315^; Fair | MCI + Dem | EQ-VAS (0–100)^‡^ | IG1 | 6 | 58.7 (20.7) | 116 | 60.2 (18.3) | NR | 60.0 (19.3) | 83 | 56.1 (18.8) | NR | MDC (95% CI)=5.4 (0.29, 10.45), 0.04
Wolfs, 2008^315^; Fair | MCI + Dem | EQ-VAS (0–100)^‡^ | IG1 | 12 | 58.7 (20.7) | 113 | 58.3 (20.5) | NR | 60.0 (19.3) | 77 | 54.4 (21.8) | NR | MDC (95% CI)=5.2 (−0.58, 10.94), NS

* New study

† Higher values indicate better outcomes for all instruments

‡ Caregiver-reported

§ Combined patient- and caregiver-reported

ǁ Standard error

Abbreviations: Adj MD = adjusted mean difference; BL = baseline; CG = control group; CI = confidence interval; Dem = dementia; DEMQOL = Dementia Quality of Life; EQ-5D-3L = EuroQol 5-Dimensions 3 Level; EQ-5D Index = EuroQol 5-Dimensions; EQ-VAS = EuroQol Visual Analog Scale; ES = effect size; FU = followup; IG = intervention group; Int arm = intervention arm; MCI = mild cognitive impairment; MDC = mean difference in change; mo. = months; Pop cat = population category; QOL-AD = Quality of Life in Alzheimer’s Disease; NR = not reported; NS = Not statistically significant; SD = standard deviation; SF-36 MCS = Short Form 36-item, Mental Component Summary; SF-36 PCS = Short Form 36-item, Physical Component Summary; WHO-5 = World Health Organization Well-Being Index

Appendix G Table 4 Patient-Level Nonpharmacologic Interventions: Detailed Results for Mental Health and Neuropsychiatric Symptom Outcomes, by Intervention Type

Author, year Quality | Pop cat | Symptom (Instrument, range^†^) | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Cognitive Stimulation, Training, and Rehabilitation
Amieva, 2016^*^,^277^; Good | Dem | Dep (MADRS, 0–60) | IG1 | 3 | NR | 151 | 10.65 (9.9) | NR | NR | 141 | 8.82 (9.1) | NR | NR, 0.0590
Amieva, 2016^*^,^277^; Good | Dem | Dep (MADRS, 0–60) | IG1 | 24 | NR | 124 | 20.21 (17.2) | NR | NR | 109 | 18.51 (17.1) | NR | NR, 0.3127
Amieva, 2016^*^,^277^; Good | Dem | Dep (MADRS, 0–60) | IG2 | 3 | NR | 144 | 10.00 (9.9) | NR | NR | 141 | 8.82 (9.1) | NR | NR, 0.3221
Amieva, 2016^*^,^277^; Good | Dem | Dep (MADRS, 0–60) | IG2 | 24 | NR | 121 | 16.82 (16.4) | NR | NR | 109 | 18.51 (17.1) | NR | NR, 0.4953
Amieva, 2016^*^,^277^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | NR | 151 | 25.34 (28.8) | NR | NR | 141 | 23.29 (28.4) | NR | NR, 0.2224
Amieva, 2016^*^,^277^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 24 | NR | 124 | 41.52 (32.1) | NR | NR | 109 | 39.31 (32.3) | NR | NR, 0.5313
Amieva, 2016^*^,^277^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 3 | NR | 144 | 24.64 (29.2) | NR | NR | 141 | 23.29 (28.4) | NR | NR, 0.6847
Amieva, 2016^*^,^277^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 24 | NR | 121 | 34.44 (32.8) | NR | NR | 109 | 39.31 (32.3) | NR | NR, 0.0808
Belleville, 2018^*^,^291^; Fair | MCI | Anx (GAI, 0–20) | IG1 | 3 | 4.92 (5.04) | 36 | 5.42 (5.06) | NR | 5.38 (5.06) | 38 | 4.32 (4.83) | NR | NS
Belleville, 2018^*^,^291^; Fair | MCI | Anx (GAI, 0–20) | IG1 | 6 | 4.92 (5.04) | 36 | 4.56 (5.14) | NR | 5.38 (5.06) | 38 | 4.73 (5.18) | NR | NS
Belleville, 2018^*^,^291^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 3 | 3.00 (3.11) | 36 | 3.39 (3.47) | NR | 3.23 (2.82) | 38 | 3.47 (2.45) | NR | NS
Belleville, 2018^*^,^291^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 6 | 3.00 (3.11) | 36 | 2.67 (3.29) | NR | 3.23 (2.82) | 38 | 3.27 (2.24) | NR | NS
Bergamaschi, 2013^*^,^282^; Fair | Dem | Dep (CSDD, 0–38) | IG1 | 12 | NR | 16 | 30.44 (4.87) | NR | NR | 16 | 26.75 (7.73) | NR | NS
Buschert, 2011^271^; Fair | MCI | Dep (MADRS, 0–60) | IG1 | 6 | 3.6 (2.6) | 10 | 0.7 (1.3) | NR | 3.7 (5.9) | 12 | 3.8 (6.1) | NR | NR, <0.01
Buschert, 2011^271^; Fair | Dem | Dep (MADRS, 0–60) | IG1 | 6 | 3.1 (4.1) | 8 | 1.6 (3.4) | NR | 4.3 (4.0) | 7 | 4.7 (4.0) | NR | NR, 0.09
Cavallo, 2016^*^,^286^; Good | Dem | Dep (HADS-D, 0–21) | IG1 | 3 | 6.87 (2.41) | 38 | 6.42 (2.21) | NR | 6.05 (2.31) | 38 | 6.35 (2.21) | NR | NS
Cavallo, 2016^*^,^286^; Good | Dem | Dep (HADS-D, 0–21) | IG1 | 6 | 6.87 (2.41) | 38 | NR | NR | 6.05 (2.31) | 38 | NR | NR | NS
Cavallo, 2016^*^,^286^; Good | Dem | Anx (HADS-A, 0–21) | IG1 | 3 | 8.60 (2.77) | 38 | 7.65 (2.41) | NR | 7.97 (1.29) | 38 | 7.57 (1.33) | NR | NS
Cavallo, 2016^*^,^286^; Good | Dem | Anx (HADS-A, 0–21) | IG1 | 6 | 8.60 (2.77) | 38 | NR | NR | 7.97 (1.29) | 38 | NR | NR | NS
Chapman, 2004^268^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 4 | NR | 26 | 11.4 (NR) | NR | NR | 28 | 12.4 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 7 | NR | 26 | 10.4 (NR) | NR | NR | 28 | 13.4 (NR) | NR | NR
Chapman, 2004^268^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | NR | 26 | 10.2 (NR) | −2.25 (−7.76, 3.26) | NR | 28 | 17.7 (NR) | 2.19 (−3.49, 7.87) | ES=0.36, NS
Greenaway, 2012^273^; Fair | MCI | Dep (CES-D, 0–60) | IG1 | 6 | NR | 18 | 8.7 (10.0) | −0.3 (5.8) | NR | 17 | 8.1 (6.1) | −0.5 (3.7) | Cohen’s d=0.03, NS
Jeong, 2016^*^,^276^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 3 | NR | 71 | NR | −0.4 (2.7) | NR | 76 | NR | −0.2 (2.9) | NR, 0.11
Jeong, 2016^*^,^276^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 9 | NR | 67 | NR | −0.1 (2.6) | NR | 62 | NR | −0.5 (3.3) | NR, 0.24
Jeong, 2016^*^,^276^; Fair | MCI | Dep (GDS-15, 0–15) | IG2 | 3 | NR | 77 | NR | −0.8 (2.5) | NR | 76 | NR | −0.2 (2.9) | NR, 0.20
Jeong, 2016^*^,^276^; Fair | MCI | Dep (GDS-15, 0–15) | IG2 | 9 | NR | 68 | NR | −0.7 (2.5) | NR | 62 | NR | −0.5 (3.3) | NR, 0.33
Jeong, 2016^*^,^276^; Fair | MCI | NPS (NPI-12, 0–144) | IG1 | 3 | 4.7 (8.4) | 71 | NR | −1.8 (7.1) | 4.1 (5.3) | 76 | NR | 1.3 (9.1) | NR, 0.07
Jeong, 2016^*^,^276^; Fair | MCI | NPS (NPI-12, 0–144) | IG1 | 9 | 4.7 (8.4) | 67 | NR | −1.6 (8.8) | 4.1 (5.3) | 62 | NR | 1.5 (8.9) | NR, 0.03
Jeong, 2016^*^,^276^; Fair | MCI | NPS (NPI-12, 0–144) | IG2 | 3 | 3.4 (4.9) | 77 | NR | 0.9 (5.6) | 4.1 (5.3) | 76 | NR | 1.3 (9.1) | NR, 0.45
Jeong, 2016^*^,^276^; Fair | MCI | NPS (NPI-12, 0–144) | IG2 | 9 | 3.4 (4.9) | 68 | NR | −0.6 (5.0) | 4.1 (5.3) | 62 | NR | 1.5 (8.9) | NR, 0.16
Kurz, 2012^274^; Fair | Dem | Dep (GDS-15, 0–15) | IG1 | 3 | 8.54 (4.83) | 92 | NR | −1.58 (3.83) | 9.25 (5.47) | 97 | NR | −0.75 (4.13) | NR, 0.16
Kurz, 2012^274^; Fair | Dem | Dep (GDS-15, 0–15) | IG1 | 9 | 8.54 (4.83) | 83 | NR | −1.23 (4.48) | 9.25 (5.47) | 88 | NR | −0.41 (3.86) | NR, 0.20
Kurz, 2012^274^; Fair | Dem | NPS (NPI-12, 0–12) | IG1 | 3 | 6.77 (6.798) | 92 | NR | 0.11 (6.429) | 7.94 (7.802) | 97 | NR | −1.38 (6.087) | NR, 0.103
Kurz, 2012^274^; Fair | Dem | NPS (NPI-12, 0–12) | IG1 | 9 | 6.77 (6.798) | 83 | NR | 1.16 (8.658) | 7.94 (7.802) | 88 | NR | 0.42 (6.874) | NR, 0.539
Olazaran, 2004^267^; Fair | MCI + Dem | Dep (GDS-15, 0–15) | IG1 | 3 | 3.0 (0.3)^‡^ | 40 | NR | 0 (NR) | 3.4 (0.4)^‡^ | 40 | NR | −0.5 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | Dep (GDS-15, 0–15) | IG1 | 6 | 3.0 (0.3)^‡^ | 40 | NR | 0 (NR) | 3.4 (0.4)^‡^ | 40 | NR | −0.5 (NR) | NS
Olazaran, 2004^267^; Fair | MCI + Dem | Dep (GDS-15, 0–15) | IG1 | 12 | 3.0 (0.3)^‡^ | 40 | NR | −0.5 (NR) | 3.4 (0.4)^‡^ | 40 | NR | 0.25 (NR) | NR, 0.05
Orrell, 2014^*^,^281^; Good | Dem | NPS (NPI-10, 0–120) | IG1 | 3 | NR | 123 | 14.71 (2.84)^‡^ | NR | NR | 113 | 16.18 (2.76)^‡^ | NR | Adj MD=1.47 (−1.59, 4.53), 0.34
Orrell, 2014^*^,^281^; Good | Dem | NPS (NPI-10, 0–120) | IG1 | 6 | NR | 123 | 18.76 (3.78)^‡^ | NR | NR | 113 | 20.35 (3.94)^‡^ | NR | Adj MD=1.58 (−2.67, 5.84), 0.53
Orrell, 2017^*^,^275^; Good | Dem | Dep (GDS-15, 0–15) | IG1 | 3 | NR | 142 | 2.98 (2.56) | −0.14 (1.98) | NR | 146 | 3.03 (2.86) | 0.11 (2.24) | Adj MD=−0.09 (−0.56, 0.38), 0.71
Orrell, 2017^*^,^275^; Good | Dem | Dep (GDS-15, 0–15) | IG1 | 6 | NR | 134 | 2.90 (2.55) | −0.11 (1.94) | NR | 139 | 2.85 (2.67) | −0.09 (2.7) | Adj MD=−0.02(−0.51, 0.47), 0.94
Orrell, 2017^*^,^275^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | 11.21 (13.96) | 142 | 10.67 (13.30) | 0.21 (11.05) | 10.99 (11.98) | 146 | 12.07 (12.61) | 1.96 (10.08) | Adj MD=−1.45 (−3.68, 0.76), 0.20
Orrell, 2017^*^,^275^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 11.21 (13.96) | 134 | 11.57 (13.72) | 1.14 (11.72) | 10.99 (11.98) | 139 | 11.59 (12.80) | 1.40 (10.1) | Adj MD=−0.32 (−2.78, 2.12), 0.79
Pantoni, 2017^*^,^289^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 6 | 4.6 (4.0) | 21 | NR | −0.1 (2.1) | 4.9 (3.8) | 22 | NR | −0.8 (2.9) | NR, 0.393
Pantoni, 2017^*^,^289^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 12 | 4.6 (4.0) | 21 | NR | −0.1 (2.9) | 4.9 (3.8) | 22 | NR | −0.7 (2.5) | NR, 0.448
Vidovich, 2015^*^,^278^; Good | MCI | Dep (PHQ-9, 0–27) | IG1 | 12 | NR | 77 | NR | 0.1 (−0.9, 1.1) | NR | 77 | NR | −0.4 (−1.3, 0.4) | NR
Vidovich, 2015^*^,^278^; Good | MCI | Dep (PHQ-9, 0–27) | IG1 | 24 | NR | 67 | NR | −0.4 (−1.2, 0.5) | NR | 60 | NR | −0.2 (−1.0, 0.6) | NR, 0.953
Exercise Interventions
Ho, 2018^*^,^310^; Fair | MCI + Dem | Dep (GDS-4, 0–4) | IG1 | 3 | 0.8 (1.1) | 69 | 0.6 (0.9) | NR | 0.9 (1.1) | 68 | 1.2 (1.2) | NR | Beta (SE)=−0.51 (0.19), <0.01
Ho, 2018^*^,^310^; Fair | MCI + Dem | Dep (GDS-4, 0–4) | IG1 | 6 | 0.8 (1.1) | 69 | 0.7 (1.0) | NR | 0.9 (1.1) | 68 | 1.1 (1.1) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | Dep (GDS-4, 0–4) | IG1 | 12 | 0.8 (1.1) | 69 | 0.7 (1.0) | NR | 0.9 (1.1) | 68 | 1.0 (1.0) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | Dep (GDS-4, 0–4) | IG2 | 3 | 1.1 (1.2) | 67 | 1.0 (1.2) | NR | 0.9 (1.1) | 68 | 1.2 (1.2) | NR | Beta (SE)=−0.30 (0.20), 0.13
Ho, 2018^*^,^310^; Fair | MCI + Dem | Dep (GDS-4, 0–4) | IG2 | 6 | 1.1 (1.2) | 67 | 1.3 (1.3) | NR | 0.9 (1.1) | 68 | 1.1 (1.1) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | Dep (GDS-4, 0–4) | IG2 | 12 | 1.1 (1.2) | 67 | 1.2 (1.4) | NR | 0.9 (1.1) | 68 | 1.0 (1.0) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | NPS (NPI-Q-12, 0–36) | IG1 | 3 | 3.1 (3.7) | 69 | 2.5 (4.4) | NR | 2.8 (4.6) | 68 | 2.2 (3.0) | NR | Beta (SE)=0.01 (0.65), 0.98
Ho, 2018^*^,^310^; Fair | MCI + Dem | NPS (NPI-Q-12, 0–36) | IG1 | 6 | 3.1 (3.7) | 69 | 2.7 (3.9) | NR | 2.8 (4.6) | 68 | 1.5 (2.5) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | NPS (NPI-Q-12, 0–36) | IG1 | 12 | 3.1 (3.7) | 69 | 2.8 (4.5) | NR | 2.8 (4.6) | 68 | 1.7 (2.7) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | NPS (NPI-Q-12, 0–36) | IG2 | 3 | 2.6 (4.1) | 67 | 2.8 (4.7) | NR | 2.8 (4.6) | 68 | 2.2 (3.0) | NR | Beta (SE)=1.04 (0.63), 0.10
Ho, 2018^*^,^310^; Fair | MCI + Dem | NPS (NPI-Q-12, 0–36) | IG2 | 6 | 2.6 (4.1) | 67 | 2.8 (3.7) | NR | 2.8 (4.6) | 68 | 1.5 (2.5) | NR | NS
Ho, 2018^*^,^310^; Fair | MCI + Dem | NPS (NPI-Q-12, 0–36) | IG2 | 12 | 2.6 (4.1) | 67 | 2.5 (4.5) | NR | 2.8 (4.6) | 68 | 1.7 (2.7) | NR | NS
Hoffmann, 2016^*^,^304^; Good | Dem | Dep (HDRS, 0–52) | IG1 | 4 | 1.9 (2.6) | 102 | 1.7 (2.5) | NR | 2.0 (2.5) | 88 | 1.8 (2.3) | NR | MDC=−0.1 (−0.7, 0.5), 0.791
Hoffmann, 2016^*^,^304^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 4 | 10.0 (10.8) | 102 | 8.8 (8.5) | NR | 9.4 (9.7) | 88 | 11.4 (11.0) | NR | MDC=−3.5 (−5.8, −1.3), 0.002
Holthoff, 2015^*^,^305^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | NR | 15 | 10.05 (1.26)^‡^ | NR | NR | 15 | 15.71 (1.26)^‡^ | NR | Adj MD (95% CI)=5.66 (−9.28, −2.03), NR
Holthoff, 2015^*^,^305^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | NR | 13 | 10.40 (1.38)^‡^ | NR | NR | 14 | 16.09 (1.29)^‡^ | NR | Adj MD (95% CI)=5.69 (−9.55, −1.83), <0.05
Lam, 2011^295^; Fair | MCI | Dep (CSDD, 0–38) | IG1 | 5 | 0.9 (1.8) | 135 | 0.7 (0.9) | NR | 0.8 (1.8) | 194 | 0.6 (0.9) | NR | NS
Lam, 2011^295^; Fair | MCI | NPS (NPI-12, 0–12) | IG1 | 5 | 0.6 (0.9) | 135 | 0.5 (0.9) | NR | 0.6 (0.9) | 194 | 0.7 (1.0) | NR | NS
Lamb, 2018^*^,^308^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 12.8 (15.0) | 234 | 15.2 (16.1) | NR | 13.3 (13.2) | 110 | 14.8 (15.6) | NR | Adj MD (95% CI)=−0.5 (−3.08, 2.05), 0.695
Lamb, 2018^*^,^308^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | 12.8 (15.0) | 215 | 16.2 (15.9) | NR | 13.3 (13.2) | 105 | 13.5 (13.1) | NR | Adj MD (95% CI)=−2.1 (−4.83, 0.65), 0.135
Lautenschlager, 2008^294^; Good | MCI | Dep (BDI, 0–63) | IG1 | 6 | NR | 85 | NR | −0.94 (−1.77, −0.12) | NR | 85 | NR | −0.75 (−1.62, 0.13) | NR
Lautenschlager, 2008^294^; Good | MCI | Dep (BDI, 0–63) | IG1 | 12 | NR | 85 | NR | −0.75 (−1.62, 0.12) | NR | 85 | NR | −0.44 (−1.29, 0.40) | NR
Lautenschlager, 2008^294^; Good | MCI | Dep (BDI, 0–63) | IG1 | 17 | NR | 85 | NR | −0.46 (−1.47, 0.55) | NR | 85 | NR | −0.51 (−1.44, 0.42) | NR, 0.44
Lazarou, 2017^*^,^301^; Fair | MCI | NPS (NPI-12, 0–144) | IG1 | 10 | 3.18 (4.91) | 66 | 1.78 (2.28) | NR | 2.97 (4.04) | 63 | 3.76 (4.84) | NR | NR, 0.02
Marshall, 2015^*^,^317^; Fair | Dem | Dep (CSDD, 0–38) | IG1 | 3 | 11 (39.3)^§^ | 28 | 12 (42.8)^§^ | NR | 7 (25.9)^§^ | 27 | 6 (22.2)^§^ | NR | NR
Marshall, 2015^*^,^317^; Fair | Dem | Dep (CSDD, 0–38) | IG1 | 5 | 11 (39.3)^§^ | 28 | 7 (25.0)^§^ | NR | 7 (25.9)^§^ | 24 | 6 (25.0 )^§^ | NR | NR
Morris, 2017^*^,^303^; Good | MCI + Dem | Dep (CSDD, 0–38) | IG1 | 3 | 8.6 (5.1) | 36 | 8.4 (4.6) | NR | 7.4 (3.8) | 37 | 8.1 (4.4) | NR | NR
Morris, 2017^*^,^303^; Good | MCI + Dem | Dep (CSDD, 0–38) | IG1 | 6 | 8.6 (5.1) | 34 | 7.8 (5.2) | NR | 7.4 (3.8) | 34 | 7.8 (4.4) | NR | ES=0.98 (−2.65, 0.69), 0.51
Pitkälä, 2013^*^,^292^; Good | Dem | Dep (CSDD, 0–38) | IG1 | 12 | NR | 57 | NR | 1.35 (0.14, 2.66) | NR | 59 | NR | 0.04 (−1.56, 1.40) | NR, 0.81
Pitkälä, 2013^*^,^292^; Good | Dem | Dep (CSDD, 0–38) | IG2 | 12 | NR | 63 | NR | 0.5 (−0.67, 1.54) | NR | 59 | NR | 0.04 (−1.56, 1.40) | NR, 0.81
Pitkälä, 2013^*^,^292^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 6 | NR | 63 | NR | 2.73 (1.08, 5.05) | NR | 59 | NR | 0.64 (−2.23, 3.46) | NR, 0.41
Pitkälä, 2013^*^,^292^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | NR | 61 | NR | 0.88 (−1.30, 2.84) | NR | 65 | NR | 0.64 (−2.23, 3.46) | NR, 0.41
Vreugdenhil, 2012^300^; Fair | Dem | Dep (GDS-15, 0–15) | IG1 | 4 | 2.6 (1.7) | 20 | 2.0 (1.5) | −0.5 (0.2)^‡^ | 2.3 (1.4) | 20 | 2.3 (1.4) | 0.2 (0.3)^‡^ | NR, 0.071
Multicomponent and Other Interventions
Bae, 2019^*^,^322^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 6 | 2.9 (2.2) | 41 | NR | −0.11 (−0.84, 0.61) | 2.9 (2.7) | 42 | NR | 0.36 (−0.32, 1.04) | NR, 0.35
Belleville, 2018^*^,^291^; Fair | MCI | Anx (GAI, 0–20) | IG1 | 3 | 5.42 (4.75) | 40 | 5.75 (4.74) | NR | 5.38 (5.06) | 38 | 4.32 (4.83) | NR | NS
Belleville, 2018^*^,^291^; Fair | MCI | Anx (GAI, 0–20) | IG1 | 6 | 5.42 (4.75) | 31 | 5.52 (5.55) | NR | 5.38 (5.06) | 38 | 4.73 (5.18) | NR | NS
Belleville, 2018^*^,^291^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 3 | 3.56 (3.17) | 40 | 3.38 (3.19) | NR | 3.23 (2.82) | 38 | 3.47 (2.45) | NR | NS
Belleville, 2018^*^,^291^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 6 | 3.56 (3.17) | 31 | 3.36 (2.92) | NR | 3.23 (2.82) | 38 | 3.27 (2.24) | NR | NS
Burgener, 2008^314^; Fair | Dem | Dep (GDS-15, 0–15) | IG1 | 5 | NR | 19 | 3.3 (2.9) | 0.4 (NR) | NR | 14 | 4.3 (3.4) | 0.9 (NR) | NR, 0.37
Jha, 2013^*^,^318^; Fair | MCI + Dem | Dep (CSDD, 0–38) | IG1 | 6 | NR | 16 | 4.0 (1.7) | −2.56 (NR) | NR | 17 | 4.5 (1.8) | −2.53 (NR) | NR, 0.38
Marshall, 2015^*^,^317^; Fair | Dem | Dep (CSDD, 0–38) | IG1 | 3 | NR | 28 | 6.7 (4.2) | NR | NR | 27 | 5.0 (4.5) | NR | MDC=0.11 (−2.02, 2.25),
Marshall, 2015^*^,^317^; Fair | Dem | Dep (CSDD, 0–38) | IG1 | 5 | NR | 28 | 7.0 (4.6) | NR | NR | 24 | 5.4 (4.0) | NR | MDC=0.29 (−2.08, 2.67),
Quinn, 2016^*^,^316^; Good | Dem | Dep (HDRS, 0–21) | IG1 | 6 | NR | 13 | NR | NR | NR | 11 | NR | NR | Adj MD:0.96 (−1.58, 3.49), NS
Quinn, 2016^*^,^316^; Good | Dem | Anx (HADS-A, 0–21) | IG1 | 3 | NR | 13 | NR | NR | NR | 11 | NR | NR | Adj MD (95% CI)=0.8 (−3.07, 1.47), NS
Quinn, 2016^*^,^316^; Good | Dem | Anx (HADS-A, 0–21) | IG1 | 6 | NR | 13 | NR | NR | NR | 11 | NR | NR | Adj MD (95% CI)=1.14 (−3.41, 1.13), NS
Richard, 2009^319^; Fair | Dem | NPS (RMBPC, Total freq, 0–100) | IG1 | 12 | 25.5 (10.3) | 57 | 30.3 (13.6) | NR | 26.1 (9.9) | 48 | 31.9 (12.5) | NR | NS
Richard, 2009^319^; Fair | Dem | NPS (RMBPC, Total freq, 0–100) | IG1 | 24 | 25.5 (10.3) | 50 | 31.1 (14.7) | 11.17 (13.1) | 26.1 (9.9) | 44 | 37.3 (15.4) | 6.63 (12.8) | MDC=4.54 (−1.39, 10.49), 0.35
Rovner, 2018^*^,^320^; Good | MCI | Dep (GDS-15, 0–15) | IG1 | 24 | 3.7 (3.1) | 111 | NR | −0.07 (−0.33, 0.18) | 3.2 (3.0) | 110 | NR | −0.14 (−0.38, 0.10) | Beta (95% CI)=0.07 (−0.28, 0.41), 0.709
Straubmeier, 2017^*^,^324^; Fair | MCI + Dem | NPS (NPI-Q-12, 0–36) | IG1 | 6 | 5.2 (2.7) | 208 | NR | 0.16 (1.8) | 5.3 (2.7) | 154 | NR | −0.27 (1.9) | ES=0.23, 0.055
Wolfs, 2008^315^; Fair | MCI + Dem | Dep (CSDD, 0–38) | IG1 | 6 | 7.9 (4.3) | 116 | 7.2 (4.7) | NR | 7.4 (3.8) | 83 | 7.9 (5.0) | NR | MDC=−1.3 (−2.62, 0.07), NS
Wolfs, 2008^315^; Fair | MCI + Dem | Dep (CSDD, 0–38) | IG1 | 12 | 7.9 (4.3) | 113 | 7.5 (5.0) | NR | 7.4 (3.8) | 77 | 7.8 (4.9) | NR | MDC=−0.8 (−2.24, 0.69), NS
Wolfs, 2008^315^; Fair | MCI + Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 23.4 (15.6) | 116 | 24.3 (18.5) | NR | 22.6 (16.5) | 83 | 27.3 (20.8) | NR | MDC=−4.0 (−8.46, 0.54), NS
Wolfs, 2008^315^; Fair | MCI + Dem | NPS (NPI-12, 0–144) | IG1 | 12 | 23.4 (15.6) | 113 | 28.4 (20.8) | NR | 22.6 (16.5) | 77 | 29.0 (21.0) | NR | MDC=−1.2 (−6.06, 3.63), NS

* New study

† Lower values indicate better outcomes for all instruments

‡ Standard error

§ N (%) participants with CSDD score ≥7 (indicator for clinically significant levels of depression)

Abbreviations: Anx = Anxiety; BDI = Beck Dep Inventory; BL = baseline; CG = control group; CI = confidence interval; CSDD = Cornell Scale for Depression in Dementia; Dem = dementia; freq. = frequency; Dep = depression; FU = followup; GDS-15 = Geriatric Depression Scale-15 item; HADS-A = Hospital Anxiety and Depression Scale – Anxiety subscale; HADS-A = Hospital Anxiety and Depression Scale – Depression subscale; HDRS = Hamilton Depression Rating Scale; IG = intervention group; Int arm = intervention arm; MADRS = Montgomery-Åsberg Depression Rating Scale; MCI = mild cognitive impairment; MDC = mean difference in change; mo. = months; NPI-10 = Neuropsychiatric Inventory-10 item; NPI-12 = Neuropsychiatric Inventory-12 item; NPS = Composite neuropsychiatric symptoms; NR = not reported; PHQ-9 = Patient Health Quesionnaire-9 item; Pop cat = population category; RMBPC = Revised Memory and Behavior Problems Checklist; SD = standard deviation