# Appendix F Detailed Trial Results for Trials of Other Medications and Supplements

Appendix F Table 1 Other Medications and Supplements: Detailed Results for Global Cognitive Function Outcomes, by Agent

Medication type | Intervention | Author, year Quality | Pop cat | Instrument (range)^†^ | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Antihypertensive | Discontinuation of antihypertensive | Moonen, 2015^*^,^237^; Fair | MCI | MMSE (0–30) | IG1 | 4 | 26^‡^ (NR) | 180 | NR | 1.15 (0.85, 1.45)^§^ | 26^‡^ (NR) | 176 | NR | 0.81 (0.51, 1.12)^§^ | NR, 0.12
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 22.3 (9.1) | 296 | NR | 0.17^ǁ^ (0.27)^¶^ | 22.5 (9.9) | 316 | NR | 0.35^ǁ^ (0.26)^¶^ | LSM change (SE)=−0.18 (0.38), 0.63
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 22.3 (9.1) | 263 | NR | 0.36^ǁ^ (0.34)^¶^ | 22.5 (9.9) | 308 | NR | 0.79^ǁ^ (0.32)^¶^ | LSM change (SE)=−0.42 (0.47), 0.36
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 11 | 22.3 (9.1) | 236 | NR | 3.61^ǁ^ (0.45)^¶^ | 22.5 (9.9) | 278 | NR | 4.12^ǁ^ (0.42)^¶^ | LSM change (SE)=−0.51 (0.61), 0.41
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 18 | 22.3 (9.1) | 202 | NR | 5.98^ǁ^ (0.56)^¶^ | 22.5 (9.9) | 235 | NR | 6.82^ǁ^ (0.52)^¶^ | LSM change (SE)=−0.84 (0.76), 0.27
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 21.8 (3.2) | 295 | NR | 0.11^ǁ^ (0.16)^¶^ | 21.9 (3.2) | 316 | NR | −0.07^ǁ^ (0.15)^¶^ | LSM change (SE)=0.17 (0.22), 0.42
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 21.8 (3.2) | 263 | NR | −0.28^ǁ^ (0.17)^¶^ | 21.9 (3.2) | 308 | NR | −0.45^ǁ^ (0.16)^¶^ | LSM change (SE)=0.16 (0.24), 0.49
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | MMSE (0–30) | IG1 | 11 | 21.8 (3.2) | 236 | NR | −0.96^ǁ^ (0.22)^¶^ | 21.9 (3.2) | 278 | NR | −1.35^ǁ^ (0.21)^¶^ | LSM change (SE)=0.39 (0.31), 0.20
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | MMSE (0–30) | IG1 | 18 | 21.8 (3.2) | 205 | NR | −1.66^ǁ^ (0.26)^¶^ | 21.9 (3.2) | 234 | NR | −2.18^ǁ^ (0.24)^¶^ | LSM change (SE)=0.52 (0.35), 0.14
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 24.5 (9.7) | 204 | NR | 1.89 (5.35) | 23.9 (10.5) | 202 | NR | 1.11 (5.32) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 24.5 (9.7) | 204 | NR | 2.51 (5.61) | 23.9 (10.5) | 202 | NR | 2.32 (5.9) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 24.5 (9.7) | 204 | NR | 5.79 (7.76) | 23.9 (10.5) | 202 | NR | 5.36 (6.95) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 18 | 24.5 (9.7) | 204 | NR | 9.51 (9.48) | 23.9 (10.5) | 202 | NR | 8.18 (8.7) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 20.0 (4.5) | 204 | NR | −0.52 (2.74) | 20.7 (4.9) | 202 | NR | −0.1 (3.1) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 20.0 (4.5) | 204 | NR | −0.72 (3.26) | 20.7 (4.9) | 202 | NR | −0.89 (3.23) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 20.0 (4.5) | 204 | NR | −2.47 (3.8) | 20.7 (4.9) | 202 | NR | −2.28 (4.08) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | MMSE (0–30) | IG1 | 18 | 20.0 (4.5) | 204 | NR | −4.23 (4.77) | 20.7 (4.9) | 202 | NR | −3.75 (4.38) | NS
HMG-CoA reductase inhibitor | Simvastatin | Simons, 2002^240^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 29.4 (10.4) | 20 | NR | 4.1 (6.5) | 33.2 (11.3) | 17 | NR | 3.4 (7.0) | NS
HMG-CoA reductase inhibitor | Simvastatin | Simons, 2002^240^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 17.8 (5.0) | 20 | 17.2 (4.8) | NR | 17.1 (4.9) | 17 | 14.4 (5.6) | NR | NR, <0.02
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 20.6 (1.73)^¶^ | 32 | 20.5 (NR) | NR | 19.9 (1.73)^¶^ | 31 | 20.7 (NR) | NR | NS
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 20.6 (1.73)^¶^ | 32 | 18.8 (1.4)^¶^ | NR | 19.9 (1.73)^¶^ | 31 | 22.1 (1.9) | NR | NR, 0.003
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 8 | 20.6 (1.73)^¶^ | 32 | 20.8 (1.5)^¶^ | NR | 19.9 (1.73)^¶^ | 31 | 22.8 (1.5)^¶^ | NR | NR, 0.18
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 20.6 (1.73)^¶^ | 32 | 20.3 (1.7)^¶^ | NR | 19.9 (1.73)^¶^ | 31 | 23.6 (2.0)^¶^ | NR | NR, 0.055
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 21.09 (0.61)^¶^ | 32 | 20.2 (NR) | NR | 20.52 (0.76)^¶^ | 31 | 20.5 (NR) | NR | NS
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 21.09 (0.61)^¶^ | 32 | 21.2 (0.8)^¶^ | NR | 20.52 (0.76)^¶^ | 31 | 19.4 (1.0)^¶^ | NR | NR, 0.46
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | MMSE (0–30) | IG1 | 8 | 21.09 (0.61)^¶^ | 32 | 20.7 (0.7)^¶^ | NR | 20.52 (0.76)^¶^ | 31 | 18.1 (1.1)^¶^ | NR | NR, 0.41
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 21.09 (0.61)^¶^ | 32 | 20.3 (0.9)^¶^ | NR | 20.52 (0.76)^¶^ | 31 | 18.1 (1.1)^¶^ | NR | NR, 0.25
NSAID | Naproxen | Aisen, 2003^242^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 24.4 (10.2) | 118 | 30.2 (13.9) | 5.8 (8.0) | 24.2 (9.6) | 111 | 29.9 (13.7) | 5.7 (8.2) | MDC (SE) (95% CI)=−0.1 (1.07) (−2.24, 2.04), 0.96
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 20.2 (8.3) | 20 | NR | 4.8 (5.8) | 19.7 (8.8) | 23 | NR | 3.9 (4.5) | MDC (95% CI)=0.9 (−2.2, 4.1), NR
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 20.2 (8.3) | 19 | NR | 7.8 (7.6) | 19.7 (8.8) | 19 | NR | 9.3 (10.0) | MDC (95% CI)=−1.5 (−7.5, 4.5), NR
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 19.1 (4.1) | 20 | NR | −2.3 (3.2) | 20.2 (3.9) | 23 | NR | −2.4 (3.6) | MDC (95% CI)=−0.1 (−2.1, 1.9), NR
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 19.1 (4.1) | 19 | NR | −3.4 (4.3) | 20.2 (3.9) | 19 | NR | −5.4 (5.5) | MDC (95% CI)=−1.6 (−4.8, 1.6), NR
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 26.8 (10.6) | 66 | NR | −3.0 (1.3)^¶^ | 25.6 (10.7) | 66 | NR | −3.1 (1.3)^¶^ | MDC (95% CI)=0.1 (−2.7, 2.9), 0.951
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 19.7 (3.0) | 66 | NR | 2.1 (0.5)^¶^ | 20.3 (3.8) | 66 | NR | 2.7 (0.5)^¶^ | MDC (95% CI)=−0.6 (−1.8, 0.5), 0.288
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 24.8 (10.7) | 263 | NR | 0.77^ǁ^ (NR) | 24.6 (10.1) | 124 | NR | 0.69^ǁ^ (NR) | NR, 0.897
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 24.8 (10.7) | 274 | NR | 1.64^ǁ^ (NR) | 24.6 (10.1) | 135 | NR | 2.15^ǁ^ (NR) | NR, 0.461
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 24.8 (10.7) | 278 | NR | 4.39^ǁ^ (NR) | 24.6 (10.1) | 135 | NR | 5.00^ǁ^ (NR) | NR, 0.541
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | ADAS-Cog 11 (D) | IG1 | 12 | NA | 278 | 158 (56.8)^#^ | NR | NA | 135 | 85 (63.0)^#^ | NR | NS
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 19.8 (4.2) | 255 | NR | −2.3 (NR) | 19.4 (3.9) | 128 | NR | −2.0 (NR) | NR, 0.244
Gonadal steroid | Estrogen | Henderson, 2000^247^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 25.1 (2.2)^¶^ | 17 | 26.9 (2.6)^¶^ | 1.8 (1.2)^¶^ | 26.8 (2.8)^¶^ | 17 | 27.3 (2.5)^¶^ | 0.5 (1.7)^¶^ | MDC =1.3, >0.1
Gonadal steroid | Estrogen | Henderson, 2000^247^; Fair | Dem | ADAS-Cog 11 (D) | IG1 | 4 | NA | 17 | 2 (11.8)^**^ | NR | NA | 17 | 5 (29.4)^**^ | NR | NR
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 24.3 (11.0) | 21 | NR | −1.5 (NR) | 25.8 (12.0) | 21 | NR | 2.3 (NR) | ES (95% CI)=−0.33 (−0.66, 0.003), 0.048
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 24.3 (11.0) | 21 | NR | −0.7 (NR) | 25.8 (12.0) | 21 | NR | 1.8 (NR) | ES (95% CI)=−0.22 (−0.54, 0.10), 0.18
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 9 | 24.3 (11.0) | 21 | NR | −1.1 (NR) | 25.8 (12.0) | 21 | NR | 1.3 (NR) | ES (95% CI)=−0.21 (−0.52, 1.10), 0.17
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 24.3 (11.0) | 21 | NR | 3.2 (NR) | 25.8 (12.0) | 21 | NR | 3.5 (NR) | ES (95% CI)=−0.03 (−0.44, 0.39), 0.89
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | MMSE (0–30) | IG1 | 6 | 21.2 (4.9) | 21 | NR | −0.8 (NR) | 19.4 (6.2) | 21 | NR | −0.6 (NR) | ES (95% CI)=−0.05 (−0.44, 0.35), NR
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | MMSE (0–30) | IG1 | 12 | 21.2 (4.9) | 21 | NR | −2.5 (NR) | 19.4 (6.2) | 21 | NR | −1.6 (NR) | ES (95% CI)=−0.17 (−0.65, 0.31), NR
Gonadal steroid | Testosterone | Lu, 2006^248^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 25.0 (13.2) | 5 | 27.4 (8.4) | 2.4 (5.0) | 25.2 (8.9) | 6 | 28.3 (10.3) | 3.2 (7.3) | NR, 0.82
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | NR | 42 | NR | 6.3 (8.7) | NR | 39 | NR | 3.6 (4.7) | NR, 0.09
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | ADAS-Cog 11 (0–70) | IG2 | 12 | NR | 39 | NR | 4.8 (5.4) | NR | 39 | NR | 3.6 (4.7) | NR, 0.32
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 20.2 (4.7) | 42 | NR | −2.7 (3.5) | 21.1 (3.3) | 39 | NR | −3.1 (4.1) | NR, 0.48
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | MMSE (0–30) | IG2 | 12 | 20.8 (4.2) | 39 | NR | −2.7 (3.9) | 21.1 (3.3) | 39 | NR | −3.1 (4.1) | NR, 0.64
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 22.0 (4.3) | 29 | 19.9 (4.7) | NR | 21.8 (3.9) | 26 | 19.8 (4.9) | NR | MDC (SD)=−0.1 (3.1), 0.90
Gonadal steroid | Estrogen | Wang, 2000^251^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 16.1 (4.3) | 25 | NR | 0.2 (3.3) | 16.2 (4.2) | 25 | NR | 0.2 (2.5) | NR, 0.975
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 22.43 (9.0) | 234 | NR | 1.58 (5.61) | 22.63 (8.6) | 161 | NR | 1.51 (4.68) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 22.43 (9.0) | 232 | NR | 2.44 (6.04) | 22.63 (8.6) | 156 | NR | 1.72 (4.74) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 22.43 (9.0) | 216 | NR | 4.42 (6.61) | 22.63 (8.6) | 143 | NR | 4.46 (6.32) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 18 | 22.43 (9.0) | 197 | NR | 7.38 (9.72) | 22.63 (8.6) | 136 | NR | 6.54 (8.17) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | MMSE (0–30) | IG1 | 3 | 20.98 (3.4) | 235 | NR | −0.17 (3.02) | 20.91 (3.7) | 164 | NR | −0.67 (2.89) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | MMSE (0–30) | IG1 | 6 | 20.98 (3.4) | 231 | NR | −0.44 (3.19) | 20.91 (3.7) | 160 | NR | −1.13 (3.13) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | MMSE (0–30) | IG1 | 12 | 20.98 (3.4) | 215 | NR | −1.64 (3.84) | 20.91 (3.7) | 147 | NR | −1.8 (3.56) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | MMSE (0–30) | IG1 | 18 | 20.98 (3.4) | 206 | NR | −2.65 (4.56) | 20.91 (3.7) | 140 | NR | −3.08 (4.46) | NR
Dietary supplement | B vitamins (including folic acid) | Connelly, 2008^253^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 23.48 (4.1) | 23 | NR | 0.09 (3.3) | 23.5 (2.75) | 18 | NR | 0.22 (2.67) | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 18.5 (8.8) | 126 | NR | 1.37^ǁ^ (0.13, 2.63)^§^ | 19.1 (8.4) | 128 | NR | 3.04^ǁ^ (1.81, 4.28)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 12 | 18.5 (8.8) | 114 | NR | 2.38^ǁ^ (0.98, 3.82)^§^ | 19.1 (8.4) | 106 | NR | 4.24^ǁ^ (2.81, 5.70)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 18 | 18.5 (8.8) | 89 | NR | 4.33^ǁ^ (2.57, 6.12)^§^ | 19.1 (8.4) | 88 | NR | 6.04^ǁ^ (4.25, 7.86)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 24 | 18.5 (8.8) | 82 | NR | 4.32^ǁ^ (2.16, 6.47)^§^ | 19.1 (8.4) | 69 | NR | 6.70^ǁ^ (4.43, 8.97)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 30 | 18.5 (8.8) | 56 | NR | 7.86^ǁ^ (5.30, 10.42)^§^ | 19.1 (8.4) | 48 | NR | 8.9^ǁ^ (6.20, 11.62)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 36 | 18.5 (8.8) | 42 | NR | 8.99^ǁ^ (6.02, 12.00)^§^ | 19.1 (8.4) | 35 | NR | 10.76^ǁ^ (7.58, 13.96)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 42 | 18.5 (8.8) | 27 | NR | 10.34^ǁ^ (7.22, 13.49)^§^ | 19.1 (8.4) | 25 | NR | 10.60^ǁ^ (7.30, 13.92)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 48 | 18.5 (8.8) | 135 | NR | 5.97^ǁ^ (0.70)^¶^ | 19.1 (8.4) | 137 | NR | 7.78^ǁ^ (0.70)^¶^ | MDC (95% CI)=−1.80 (−3.28, −0.33), 0.10
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG2 | 6 | 21.3 (3.3) | 126 | NR | −0.34^ǁ^ (−0.90, 0.22)^§^ | 20.8 (3.8) | 128 | NR | −0.34^ǁ^ (−0.91, 0.23)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG2 | 12 | 21.3 (3.3) | 115 | NR | −0.96^ǁ^ (−1.62, −0.27)^§^ | 20.8 (3.8) | 106 | NR | −1.39^ǁ^ (−2.08, −0.69)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG2 | 18 | 21.3 (3.3) | 89 | NR | −2.00^ǁ^ (−2.86, −1.12)^§^ | 20.8 (3.8) | 88 | NR | −2.21^ǁ^ (−3.09, −1.31)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG2 | 24 | 21.3 (3.3) | 83 | NR | −2.63^ǁ^ (−3.65, −1.58)^§^ | 20.8 (3.8) | 70 | NR | −2.90^ǁ^ (−3.99, −1.80)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG2 | 30 | 21.3 (3.3) | 56 | NR | −3.67^ǁ^ (−4.86, −2.47)^§^ | 20.8 (3.8) | 47 | NR | −3.27^ǁ^ (−4.53, −2.01)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG2 | 36 | 21.3 (3.3) | 43 | NR | −4.98^ǁ^ (−6.44, −3.51)^§^ | 20.8 (3.8) | 36 | NR | −3.88^ǁ^ (−5.43, −2.31)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG2 | 42 | 21.3 (3.3) | 27 | NR | −4.85^ǁ^ (−6.41, −3.28)^§^ | 20.8 (3.8) | 26 | NR | −4.68^ǁ^ (−6.29, −3.05)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG2 | 48 | 21.3 (3.3) | 136 | NR | −2.97^ǁ^ (0.33)^¶^ | 20.8 (3.8) | 137 | NR | −3.16^ǁ^ (0.33)^¶^ | MDC (95% CI)=0.19 (−0.54, 0.92), 0.84
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^; Fair | Dem | ADAS-Cog 13 (0–85) | IG1 | 6 | 25.7 (NR) | 91 | 27.7 (NR) | NR | 27.2 (NR) | 87 | 28.3 (NR) | NR | NR
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 23.6 | 91 | 22.8 | NR | 23.2 | 87 | 22.4 | NR | NR
Dietary supplement | B vitamins (including folic acid) | Kwok, 2011^256^; Fair | Dem | MDRS (0–144) | IG1 | 24 | 104.2 (13.0) | 59 | NR | −6^††^ (−14, −2) | 103.7 (10.6) | 53 | NR | −6^††^ (−15, 0) | NR, 0.841
Dietary supplement | B vitamins (including folic acid) | Kwok, 2011^256^; Fair | Dem | MMSE (0–30) | IG1 | 24 | 16.5 (4.9) | 59 | NR | −2^††^ (−5, 0) | 16.6 (4.6) | 53 | NR | −2^††^ (−5, 0) | NR, 0.998
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG2 | 6 | 11.48 (4.4) | NR | NR | −0.16 (4.19) | 11.03 (4.2) | NR | NR | −0.13 (3.34) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG2 | 12 | 11.48 (4.4) | NR | NR | 0.91 (4.21) | 11.03 (4.2) | NR | NR | 0.61 (4.10) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG2 | 18 | 11.48 (4.4) | NR | NR | 1.19 (4.32) | 11.03 (4.2) | NR | NR | 1.29 (4.71) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG2 | 24 | 11.48 (4.4) | NR | NR | 1.93 (5.13) | 11.03 (4.2) | NR | NR | 1.49 (5.07) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG2 | 30 | 11.48 (4.4) | NR | NR | 3.01 (5.57) | 11.03 (4.2) | NR | NR | 2.98 (5.62) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG2 | 36 | 11.48 (4.4) | 185 | NR | 4.59 (6.54) | 11.03 (4.2) | 193 | NR | 3.74 (6.97) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG2 | 6 | 18.04 (6.0) | NR | NR | −0.47 (5.06) | 17.40 (6.0) | NR | NR | −0.09 (4.38) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG2 | 12 | 18.04 (6.0) | NR | NR | 0.27 (5.20) | 17.40 (6.0) | NR | NR | 0.60 (4.96) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG2 | 18 | 18.04 (6.0) | NR | NR | 0.49 (5.42) | 17.40 (6.0) | NR | NR | 0.99 (6.07) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG2 | 24 | 18.04 (6.0) | NR | NR | 1.15 (6.37) | 17.40 (6.0) | NR | NR | 1.02 (6.27) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG2 | 30 | 18.04 (6.0) | NR | NR | 2.48 (6.68) | 17.40 (6.0) | NR | NR | 2.65 (7.02) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG2 | 36 | 18.04 (6.0) | 185 | NR | 3.98 (7.56) | 17.40 (6.0) | 193 | NR | 3.72 (8.54) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG2 | 6 | 27.20 (1.9) | NR | NR | −0.53 (2.28) | 27.35 (1.8) | NR | NR | −0.36 (2.02) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG2 | 12 | 27.20 (1.9) | NR | NR | −0.54 (2.28) | 27.35 (1.8) | NR | NR | −0.80 (2.34) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG2 | 18 | 27.20 (1.9) | NR | NR | −0.96 (2.61) | 27.35 (1.8) | NR | NR | −1.02 (2.61) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG2 | 24 | 27.20 (1.9) | NR | NR | −1.21 (2.78) | 27.35 (1.8) | NR | NR | −1.49 (2.90) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG2 | 30 | 27.20 (1.9) | NR | NR | −1.75 (3.09) | 27.35 (1.8) | NR | NR | −1.77 (3.24) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG2 | 36 | 27.20 (1.9) | 185 | NR | −2.20 (3.64) | 27.35 (1.8) | 193 | NR | −2.75 (4.04) | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 23.77 (8.9) | 215 | NR | 2.7 (1.8, 3.3)^§^ | 23.96 (9.2) | 147 | NR | 3.1 (2.0, 3.9)^§^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 23.77 (8.9) | 190 | NR | 4.0 (3.0, 5.0)^§^ | 23.96 (9.2) | 139 | NR | 5.5 (4.4, 6.7)^§^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 18 | 23.77 (8.9) | 173 | NR | 7.98 (6.51, 9.45)^§^ | 23.96 (9.2) | 127 | NR | 8.27 (6.72, 9.82)^§^ | MDC (95% CI)=NR (NR, NR), 0.41
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | MMSE (0–30) | IG1 | 18 | 20.9 (3.6) | 173 | NR | −3.70 (−4.44, −2.96)^§^ | 20.3 (3.7) | 127 | NR | −4.04 (−4.85, −3.23)^§^ | MDC (95% CI)=NR (NR, NR), 0.88
Dietary supplement | Vitamin E | Sano, 1997^259^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 24 | NR | 85 | NR | 8.3 (NR) | NR | 84 | NR | 6.7 (NR) | NR
Dietary supplement | Vitamin E | Sano, 1997^259^; Good | Dem | MMSE (0–30) | IG1 | 24 | 11.3 (5.7) | 85 | NR | −4.6 (NR) | 13.3 (4.9) | 84 | NR | −4.6 (NR) | NR
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 31.8 (9.4)^¶^ | 11 | NR | 4.4 (2.2)^¶^ | 32.2 (9.5)^¶^ | 11 | NR | 3.2 (2.1)^¶^ | NR, 0.86
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | ADAS-Cog 11 (0–70) | IG2 | 12 | 29.0 (7.1)^¶^ | 12 | NR | 2.8 (2.0)^¶^ | 32.2 (9.5)^¶^ | 11 | NR | 3.2 (2.1)^¶^ | NR, 0.98
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 20.7 (2.7)^¶^ | 11 | NR | −1.63 (0.97)^¶^ | 22.2 (3.1)^¶^ | 11 | NR | −1.59 (1.09)^¶^ | NR, NR
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 20.7 (2.7)^¶^ | 11 | NR | −4.3 (1.3)^¶^ | 22.2 (3.1)^¶^ | 11 | NR | −4.6 (1.4)^¶^ | NR, 0.80
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | MMSE (0–30) | IG2 | 6 | 22.5 (3.0)^¶^ | 12 | NR | 0.83 (0.80)^¶^ | 22.2 (3.1)^¶^ | 11 | NR | −1.59 (1.09)^¶^ | NR
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | MMSE (0–30) | IG2 | 12 | 22.5 (3.0)^¶^ | 12 | NR | −1.0 (0.7)^¶^ | 22.2 (3.1)^¶^ | 11 | NR | −4.6 (1.4)^¶^ | NR, <0.01
Dietary supplement | Multivitamin | Sun, 2007^262^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 24.0 (12.3) | 45 | NR | 0.67 (−2.33, 3.69)^§^ | 21.2 (10.5) | 44 | NR | −0.9 (−2.77, 0.85)^§^ | NR, 0.34
Dietary supplement | Multivitamin | Sun, 2007^262^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 18.7 (4.6) | 45 | NR | 0.15 (−1.06, 1.35)^§^ | 18.6 (5.3) | 44 | NR | 0.41 (−1.12, 1.93)^§^ | NR, 0.79
Dietary supplement | Omega-3 fatty acids | Yurko-Mauro, 2010^263^; Good | MCI | MMSE (0–30) | IG1 | 6 | 28.3 (1.3) | 241 | 28.0 (1.9) | −0.4 (0.12)^¶^ | 28.2 (1.3) | 242 | 27.9 (1.9) | −0.3 (0.11)^¶^ | MDC (SE)=0 (0.15), 0.866

* New study

† Higher scores indicate better outcomes for all instruments except for ADAS-Cog 11 and ADAS-Cog 13 where lower scores indicate better outcomes

‡ Median

§ 95% CI

ǁ Least squares mean change

¶ Standard error

# Number (%) of participants who demonstrated deterioration (≥4 point increase) on ADAS-Cog 11

** Number (%) of participants who improved by ≥4 points (decreasing) on ADAS-Cog 11

†† Median change (IQR)

Abbreviations: ADAS-Cog 11 = Alzheimer’s Disease Assessment Scale-cognitive subscale; 11-item; ADAS-Cog 13 = Alzheimer’s Disease Assessment Scale-cognitive subscale; 13-item; BL = baseline; CG = control group; CI = confidence interval; D = results are dichotomized; Dem = dementia; ES = effect size; FU = followup; HMG-CoA = β-Hydroxy β-methylglutaryl-CoA; IG = intervention group; Int arm = intervention arm; LSM = least squares mean; MCI = mild cognitive impairment; MDC = mean difference in change; MMSE = Mini-Mental State Examination; mo. = months; Pop cat = population category; NR = not reported; NS = Not statistically significant; NSAID = Nonsteroidal Anti-inflammatory Drug; SD = standard deviation; SE = standard error

Appendix F Table 2 Other Medications and Supplements: Detailed Results for Global Function Outcomes, by Agent

Medication type | Medication | Author, year Quality | Pop cat | Instrument (range)^*^ | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | CDR-SB (0–18) | IG1 | 11 | 5.7 (2.4) | 272 | NR | 1.34^§^ (0.14)^‡^ | 5.9 (2.5) | 296 | NR | 1.35^§^ (0.13)^‡^ | LSM change (SE)=−0.01 (0.19), 0.96
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | CDR-SB (0–18) | IG1 | 18 | 5.7 (2.4) | 208 | NR | 1.98^§^ (0.18)^‡^ | 5.9 (2.5) | 238 | NR | 2.11^§^ (0.17)^‡^ | LSM change (SE)=−0.12 (0.25), 0.63
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | CIBIC+ (1–7) | IG1 | 3 | NR | 293 | 4.2^†^ (0.04)^‡^ | NR | NR | 310 | 4.2^†^ (0.04)^‡^ | NR | MD (SE)=0.010 (0.058), 0.8654
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | CIBIC+ (1–7) | IG1 | 6 | NR | 258 | 4.3^†^ (0.06)^‡^ | NR | NR | 306 | 4.4^†^ (0.03)^‡^ | NR | MD (SE)=0.032 (0.073), 0.6578
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | CIBIC+ (1–7) | IG1 | 9 | NR | 244 | 4.6^†^ (0.07)^‡^ | NR | NR | 283 | 4.6^†^ (0.06)^‡^ | NR | MD (SE)=−0.021 (0.081), 0.7937
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | CIBIC+ (1–7) | IG1 | 12 | NR | 233 | 4.8^†^ (0.07)^‡^ | NR | NR | 272 | 4.8^†^ (0.07)^‡^ | NR | MD (SE)=−0.034 (0.083), 0.6817
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | CIBIC+ (1–7) | IG1 | 15 | NR | 222 | 4.9^†^ (0.06)^‡^ | NR | NR | 264 | 5.0^†^ (0.07)^‡^ | NR | MD (SE)=0.019 (0.090), 0.8363
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | CIBIC+ (1–7) | IG1 | 18 | NR | 297 | 4.9^†^ (0.06)^‡^ | NR | NR | 317 | 5.1^†^ (0.07)^‡^ | NR | MD (SE)=0.160 (0.086), 0.628
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | CIBIC+ (1–7) | IG1 | 3 | NR | 32 | NR | −0.36 (NR) | NR | 31 | NR | −0.40 (NR) | NS
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | CIBIC+ (1–7) | IG1 | 6 | NR | 29 | NR | −0.53 (NR) | NR | 27 | NR | −0.68 (NR) | NR, 0.62
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | CIBIC+ (1–7) | IG1 | 8 | NR | 26 | NR | −0.57 (0.16)^‡^ | NR | 22 | NR | −0.90 (0.14)^‡^ | NR, 0.058
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | CIBIC+ (1–7) | IG1 | 12 | NR | 25 | NR | −0.73 (0.20)^‡^ | NR | 21 | NR | −1.04 (0.15)^‡^ | NR, 0.07
NSAID | Naproxen | Aisen, 2003^242^; Good | Dem | CDR-SB (0–18) | IG1 | 12 | 6.0 (2.9) | 118 | 8.3 (4.0) | 2.3 (2.3) | 5.5 (2.5) | 111 | 7.7 (3.9) | 2.2 (2.3) | NR, 0.89
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | CIBIC+ (1–7) | IG1 | 6 | NR | 20 | 5.1 (0.8) | NR | NR | 23 | 5.3 (0.7) | NR | MD (95% CI)=−0.2 (−0.6, 0.2), NS
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | CIBIC+ (1–7) | IG1 | 12 | NR | 19 | 5.6 (0.8) | NR | NR | 19 | 5.7 (0.7) | NR | MD (95% CI)=−0.1 (−0.5, 0.3), NS
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | CDR-SB (0–18) | IG1 | 12 | 4.5 (2.0) | 66 | NR | −1.7 (0.3)^‡^ | 4.4 (2.1) | 66 | NR | −1.3 (0.4)^‡^ | MDC (95% CI)=−0.4 (−1.2, 0.4), 0.324
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | CIBIC+ (1–7) | IG1 | 12 | NR | 66 | 4.0 (0.2)^‡^ | NR | NR | 66 | 3.9 (0.2)^‡^ | NR | MD (95% CI)=0.1 (−0.4, 0.5), 0.741
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | CIBIC+ (1–7) | IG1 | 3 | NR | 261 | 4.25^†^ (NR) | NR | NR | 122 | 4.30^†^ (NR) | NR | NR, 0.571
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | CIBIC+ (1–7) | IG1 | 6 | NR | 276 | 4.51^†^ (NR) | NR | NR | 135 | 4.40^†^ (NR) | NR | NR, 0.277
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | CIBIC+ (1–7) | IG1 | 12 | NR | 279 | 4.92^†^ (NR) | NR | NR | 135 | 4.83^†^ (NR) | NR | NR, 0.446
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | CIBIC+ (D) | IG1 | 12 | NA | 278 | 201 (72.0)^ǁ^ | NR | NA | 135 | 99 (73.3)^ǁ^ | NR | NS
Gonadal steroid | Estrogen | Henderson, 2000^247^; Fair | Dem | CIBIC+ (1–7) | IG1 | 4 | NR | 18 | 4.2 (0.2)^‡^ | NR | NR | 18 | 4.2 (0.1)^‡^ | NR | MD=−0.1, >0.1
Gonadal steroid | Estrogen | Henderson, 2000^247^; Fair | Dem | CIBIC+ (D) | IG1 | 4 | NA | 18 | 13 (72.2)^¶^ | NR | NA | 18 | 14 (77.8)^¶^ | NR | NR
Gonadal steroid | Estrogen | Henderson, 2015^246^,^#^; Good | Dem | CDR (0–3) | IG1 | 6 | 1.0 (0.5) | 21 | NR | 0.2 (NR) | 1.2 (0.6) | 21 | NR | 0.2 (NR) | ES (95% CI)=0.08 (−0.57, 0.74), NS
Gonadal steroid | Estrogen | Henderson, 2015^246^,^#^; Good | Dem | CDR (0–3) | IG1 | 12 | 1.0 (0.5) | 21 | NR | 0.5 (NR) | 1.2 (0.6) | 21 | NR | 0.3 (NR) | ES (95% CI)=0.30 (−0.56, 1.16), NS
Gonadal steroid | Estrogen | Henderson, 2015^246^,^#^; Good | Dem | CDR-SB (0–18) | IG1 | 6 | 5.5 (3.0) | 21 | NR | 0.8 (NR) | 6.8 (3.1) | 21 | NR | 1.0 (NR) | ES (95% CI)=−0.07 (−0.58, 0.44), NS
Gonadal steroid | Estrogen | Henderson, 2015^246^,^#^; Good | Dem | CDR-SB (0–18) | IG1 | 12 | 5.5 (3.0) | 21 | NR | 2.6 (NR) | 6.8 (3.1) | 21 | NR | 2.0 (NR) | ES (95% CI)=0.18 (−0.39, 0.75), NS
Gonadal steroid | Testosterone | Lu, 2006^248^; Fair | Dem | CIBIC+ (1–7) | IG1 | 6 | NR | 6 | 4.7 (0.49) | NR | NR | 9 | 5.0 (0.49) | NR | NR, 0.30
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | CDR (0–5) | IG1 | 12 | 1.2 (0.5) | 42 | NR | 0.4 (0.7) | 1.0 (0.5) | 39 | NR | 0.2 (0.4) | NR, 0.03
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | CDR (0–5) | IG2 | 12 | 1.1 (0.5) | 39 | NR | 0.5 (0.6) | 1.0 (0.5) | 39 | NR | 0.2 (0.4) | NR, 0.01
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | CIBIC+ (1–5) | IG2 | 12 | NR | 39 | 5.2 (0.9) | NR | NR | 39 | 5.0 (1.1) | NR | NR, 0.36
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | CIBIC+ (1–7) | IG1 | 12 | NR | 42 | 5.1 (0.9) | NR | NR | 39 | 5.0 (1.1) | NR | NR, 0.66
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | CIBIC+ (D) | IG1 | 12 | NA | 42 | 33 (78.6)^ǁ^ | NR | NA | 39 | 28 (72.0)^ǁ^ | NR | NR, 0.73
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | CIBIC+ (D) | IG2 | 12 | NA | 39 | 31 (79.5)^ǁ^ | NR | NA | 39 | 28 (72.0)^ǁ^ | NR | NR, 0.73
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^; Fair | Dem | GDS (1–7) | IG1 | 12 | 4.2 (0.6) | 29 | 5.1 (0.7) | NR | 4.4 (0.6) | 26 | 5.0 (0.7) | NR | MDC (SD)=0.1 (0.6), 0.43
Gonadal steroid | Estrogen | Wang, 2000^251^; Fair | Dem | CDR (0–3) | IG1 | 3 | 1.3 (0.5) | 25 | NR | 0.0 (0.4) | 1.2 (0.4) | 25 | NR | 0.1 (0.4) | NR, 0.366
Gonadal steroid | Estrogen | Wang, 2000^251^; Fair | Dem | CIBIC+ (1–7) | IG1 | 3 | NR | 25 | NR | −0.2 (1.0) | NR | 25 | NR | −0.2 (0.8) | NR, 0.944
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | CDR-SB (0–18) | IG1 | 6 | 5.61 (2.7) | 231 | 0.69 (1.67) | NR | 5.85 (2.9) | 159 | 0.79 (2.9) | NR | NR, 0.57
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | CDR-SB (0–18) | IG1 | 12 | 5.61 (2.7) | 214 | 1.5 (1.92) | NR | 5.85 (2.9) | 144 | 1.6 (2.12) | NR | NR, 0.57
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | CDR-SB (0–18) | IG1 | 18 | 5.61 (2.7) | 200 | 2.58 (2.45) | NR | 5.85 (2.9) | 139 | 2.51 (2.57) | NR | NR, 0.57
Dietary Supplement | B vitamins (including folic acid) | Connelly, 2008^253^; Fair | Dem | NR | IG1 | 6 | NA | 28 | 20 (71.4)^**^ | NR | NA | 21 | 8 (38.1)^**^ | NR | NR, 0.02
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^; Fair | Dem | CDR (0–3) | IG1 | 6 | 1.0 (NR) | 91 | 1.1 (NR) | NR | 1.1 (NR) | 87 | 1.1 (NR) | NR | NR
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^; Fair | Dem | CDR-SB (0–18) | IG1 | 6 | 5.8 (NR) | 91 | 6.2 (NR) | NR | 6.0 (NR) | 87 | 6.5 (NR) | NR | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | CDR-SB (0–18) | IG2 | 6 | 1.78 (0.8) | NR | NR | 0.17 (0.70) | 1.87 (0.8) | NR | NR | 0.14 (0.86) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | CDR-SB (0–18) | IG2 | 12 | 1.78 (0.8) | NR | NR | 0.51 (1.21) | 1.87 (0.8) | NR | NR | 0.40 (1.28) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | CDR-SB (0–18) | IG2 | 18 | 1.78 (0.8) | NR | NR | 0.75 (1.44) | 1.87 (0.8) | NR | NR | 0.72 (1.55) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | CDR-SB (0–18) | IG2 | 24 | 1.78 (0.8) | NR | NR | 1.02 (1.76) | 1.87 (0.8) | NR | NR | 0.97 (1.76) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | CDR-SB (0–18) | IG2 | 30 | 1.78 (0.8) | NR | NR | 1.26 (1.89) | 1.87 (0.8) | NR | NR | 1.26 (2.15) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | CDR-SB (0–18) | IG2 | 36 | 1.78 (0.8) | 185 | NR | 1.67 (2.18) | 1.87 (0.8) | 193 | NR | 1.64 (2.55) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | GDS (1–7) | IG2 | 6 | 2.64 (0.6) | NR | NR | 0.11 (0.49) | 2.72 (0.6) | NR | NR | 0.07 (0.53) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | GDS (1–7) | IG2 | 12 | 2.64 (0.6) | NR | NR | 0.21 (0.61) | 2.72 (0.6) | NR | NR | 0.15 (0.65) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | GDS (1–7) | IG2 | 18 | 2.64 (0.6) | NR | NR | 0.27 (0.73) | 2.72 (0.6) | NR | NR | 0.27 (0.73) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | GDS (1–7) | IG2 | 24 | 2.64 (0.6) | NR | NR | 0.42 (0.80) | 2.72 (0.6) | NR | NR | 0.38 (0.81) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | GDS (1–7) | IG2 | 30 | 2.64 (0.6) | NR | NR | 0.51 (0.85) | 2.72 (0.6) | NR | NR | 0.48 (0.87) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | GDS (1–7) | IG2 | 36 | 2.64 (0.6) | 185 | NR | 0.64 (0.96) | 2.72 (0.6) | 193 | NR | 0.56 (0.99) | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | CDR-SB (0–18) | IG1 | 6 | 5.61 (2.62) | 216 | NR | 1.2 (0.9, 1.5)^††^ | 5.77 (2.61) | 148 | NR | 1.1 (0.8, 1.4)^††^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | CDR-SB (0–18) | IG1 | 12 | 5.61 (2.62) | 191 | NR | 1.8 (1.5, 2.1)^††^ | 5.77 (2.61) | 137 | NR | 2.0 (1.6, 2.4)^††^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | CDR-SB (0–18) | IG1 | 18 | 5.61 (2.62) | 177 | NR | 2.87 (2.44, 3.30)^††^ | 5.77 (2.61) | 127 | NR | 2.93 (2.44, 3.42)^††^ | NR, 0.68
Dietary supplement | Vitamin E | Sano, 1997^259^; Good | Dem | CDR (D) | IG1 | 24 | NA | 85 | 41 (48.2)^‡‡^ | NR | NA | 84 | 43 (51.2)^‡‡^ | NR | NS

* Lower scores indicate better outcomes for all instruments

† Least squares mean

‡ Standard error

§ Least squares mean change

ǁ Number (%) of participants demonstrating functional deterioration (CIBIC + score 5–7)

¶ Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3)

# New study

** Number (%) of participants who improved or had no deterioration in MMSE score, as well as evidence of global function improvement on the basis of behavioral and/or functional assessment

†† 95% CI

‡‡ Number (%) of participants receiving a score of 3 on the CDR

Abbreviations: BL = baseline; CDR = Clinical Dementia Rating Scale; CDR-SB = Clinical Dementia Rating Scale Sum of Boxes; CG = control group; CI = confidence interval; CIBIC+ = Clinician’s Interview-Based Impression of Change with caregiver’s input; D = dichotomized; Dem = dementia; ES = effect size; FU = followup; GDS = Global Deterioration Scale; HMG-CoA = β-Hydroxy β-methylglutaryl-CoA; IG = intervention group; Int arm = intervention arm; LSM = least squares mean; MCI = mild cognitive impairment; MD = mean difference; MDC = mean difference in change; mo. = months; Pop cat = population category; NA = not applicable; NR = not reported; NS = not statistically significant; NSAID = Nonsteroidal Anti-inflammatory Drug; SD = standard deviation; SE = standard error

Appendix F Table 3 Other Medications and Supplements: Detailed Results for Physical Function Outcomes, by Agent

Medication type | Medication | Author, year Quality | Pop cat | ADL or ADL, (Instrument, range, direction) | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Antihypertensive | Discontinuation of antihypertensive | Moonen, 2015^*^,^237^; Fair | MCI | ADL/IADL (GARS, 18–72, ↓) | IG1 | 4 | 23^†^ (NR) | 180 | NR | −0.77 (−1.33, −0.20)^‡^ | 22^†^ (NR) | 176 | NR | −0.05 (−0.62, 0.52)^‡^ | NR, 0.08
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | ADL/IADL (ADFACS, 0–54, ↓) | IG1 | 6 | 13.2 (8.9) | 285 | NR | 2.51^§^ (0.30)^ǁ^ | 13.1 (8.5) | 311 | NR | 2.06^§^ (0.29)^ǁ^ | LSM change (SE)=0.45 (0.41), 0.27
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | ADL/IADL (ADFACS, 0–54, ↓) | IG1 | 11 | 13.2 (8.9) | 233 | NR | 4.95^§^ (0.43)^ǁ^ | 13.1 (8.5) | 279 | NR | 4.55^§^ (0.40)^ǁ^ | LSM change (SE)=0.40 (0.58), 0.49
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | ADL/IADL (ADFACS, 0–54, ↓) | IG1 | 18 | 13.2 (8.9) | 214 | NR | 7.36^§^ (0.54)^ǁ^ | 13.1 (8.5) | 256 | NR | 6.91^§^ (0.50)^ǁ^ | LSM change (SE)=0.45 (0.74), 0.54
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADL (ADCS-ADL, 0–27, ↓) | IG1 | 3 | 67.2 (10.0) | 204 | NR | −1.54 (7.44) | 68.6 (10.4) | 202 | NR | −1.2 (6.09) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADL (ADCS-ADL, 0–27, ↓) | IG1 | 6 | 67.2 (10.0) | 204 | NR | −3.66 (8.18) | 68.6 (10.4) | 202 | NR | −3.95 (8.42) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADL (ADCS-ADL, 0–27, ↓) | IG1 | 12 | 67.2 (10.0) | 204 | NR | −7.45 (10.18) | 68.6 (10.4) | 202 | NR | −6.21 (10.94) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADL (Dependency Scale, 0–5, ↓) | IG1 | 3 | 5.2 (2.3) | 204 | NR | −0.04 (0.85) | 4.9 (2.3) | 202 | NR | −0.15 (0.87) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADL (Dependency Scale, 0–5, ↓) | IG1 | 6 | 5.2 (2.3) | 204 | NR | −0.1 (1.04) | 4.9 (2.3) | 202 | NR | −0.21 (0.83) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADL (Dependency Scale, 0–5, ↓) | IG1 | 12 | 5.2 (2.3) | 204 | NR | −0.26 (1.02) | 4.9 (2.3) | 202 | NR | −0.36 (0.96) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADL (Dependency Scale, 0–5, ↓) | IG1 | 18 | 5.2 (2.3) | 204 | NR | −0.48 (1.09) | 4.9 (2.3) | 202 | NR | −0.53 (1.1) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 18 | 67.2 (10.0) | 204 | NR | −10.47 (13.37) | 68.6 (10.4) | 202 | NR | −9.62 (13.86) | NS
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 38.8 (1.93)^ǁ^ | NR | 37.2 (2.10)^ǁ^ | NR | 41.2 (1.85)^ǁ^ | NR | 33.6 (2.35)^ǁ^ | NR | NR, 0.263
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 12 | 38.8 (1.93)^ǁ^ | NR | 31.2 (2.25)^ǁ^ | NR | 41.2 (1.85)^ǁ^ | NR | 27.6 (2.33)^ǁ^ | NR | NR, 0.226
NSAID | Naproxen | Aisen, 2003^242^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 12 | 60.0 (13.1) | 118 | 51.3 (16.3) | −8.7 (10.5) | 62.8 (11.4) | 111 | 51.3 (16.3) | −11.5 (11.2) | NR, 0.14
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | ADL (Katz Index, 0–6, ↑) | IG1 | 12 | NR | 66 | NR | −0.5 (0.2)^ǁ^ | NR | 66 | NR | −0.4 (0.2)^ǁ^ | MDC (95% CI)=−0.1 (−0.6, 0.4), 0.756
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | IADL (Lawton and Brody IADL, 0–8, ↑) | IG1 | 12 | NR | 66 | NR | −0.5 (0.2)^ǁ^ | NR | 66 | NR | −0.7 (0.2)^ǁ^ | MDC (95% CI)=0.2 (−0.3, 0.6), 0.483
Gonadal steroid | Estrogen | Henderson, 2000^247^; Fair | Dem | IADL (Lawton and Brody IADL, 0–54, ↑) | IG1 | 4 | 14.7 (2.0)^ǁ^ | 18 | 17.6 (2.6)^ǁ^ | 2.9 (1.1)^ǁ^ | 13.2 (2.0)^ǁ^ | 18 | 16.1 (2.3)^ǁ^ | 2.9 (1.5)^ǁ^ | MDC=0.0, >0.1
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 63.5 (12.4) | 21 | NR | −6.9 (NR) | 58.3 (14.8) | 21 | NR | −0.3 (NR) | ES (95% CI)=−0.48 (−0.82, −0.15), 0.006
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 12 | 63.5 (12.4) | 21 | NR | −9.1 (NR) | 58.3 (14.8) | 21 | NR | −4.5 (NR) | ES (95% CI)=−0.34 (−0.84, 0.18), NR
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | ADL (Dependency Scale, 0–5, ↓) | IG1 | 12 | NR | 42 | NR | 0.4 (0.8) | NR | 39 | NR | 0.4 (1.1) | NR, 0.59
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | ADL (Dependency Scale, 0–5, ↓) | IG2 | 12 | NR | 39 | NR | 0.5 (1.0) | NR | 39 | NR | 0.4 (1.1) | NR, 0.21
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^; Fair | Dem | ADL (Barthel Index, 0–20, ↑) | IG1 | 12 | 19.4 (1.2) | 29 | 18.5 (3.1) | NR | 19.2 (1.2) | 26 | 19.1 (1.3) | NR | MDC (SD)=−0.5 (1.8), 0.36
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 61.31 (11.6) | 231 | NR | −3.28 (7.99) | 59.66 (12.9) | 160 | NR | −2.86 (7.8) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 12 | 61.31 (11.6) | 220 | NR | −7.38 (9.97) | 59.66 (12.9) | 147 | NR | −7.82 (10.0) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 18 | 61.31 (11.6) | 206 | NR | −10.96 (12.36) | 59.66 (12.9) | 140 | NR | −10.0 (11.09) | NR
Dietary supplement | B vitamins (including folic acid) | Connelly, 2008^253^; Fair | Dem | IADL (NOSGER IADL subscale, 5–25, ↓) | IG1 | 6 | 18.7 (4.61) | 23 | NR | 0.61 (3.6) | 18.22 (4.28) | 18 | NR | −2.06 (4.17) | NR, 0.03
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78) | IG2 | 6 | 56.6 (14.9) | 134 | NR | −1.73^§^ (−3.61, 0.15)^‡^ | 56.8 (13.7) | 135 | NR | −4.54^§^ (−6.42, −2.68)^‡^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78) | IG2 | 12 | 56.6 (14.9) | 122 | NR | −4.30^§^ (−6.69, −1.94)^‡^ | 56.8 (13.7) | 112 | NR | −8.14^§^ (−10.5, −5.73)^‡^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 18 | 56.6 (14.9) | 103 | NR | −8.03^§^ (−10.7, −5.25)^‡^ | 56.8 (13.7) | 96 | NR | −10.2^§^ (−13.0, −7.40)^‡^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 24 | 56.6 (14.9) | 88 | NR | −11.9^§^ (−15.2, −8.64)^‡^ | 56.8 (13.7) | 77 | NR | −16.2^§^ (−19.6, −12.8)^‡^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 30 | 56.6 (14.9) | 66 | NR | −15.9^§^ (−19.7, −12.0)^‡^ | 56.8 (13.7) | 54 | NR | −19.7^§^ (−23.7, −15.6)^‡^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 36 | 56.6 (14.9) | 51 | NR | −19.7^§^ (−24.3, −15.1)^‡^ | 56.8 (13.7) | 41 | NR | −24.8^§^ (−29.7, −19.9)^‡^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 42 | 56.6 (14.9) | 39 | NR | −25.2^§^ (−30.3, −20.3)^‡^ | 56.8 (13.7) | 33 | NR | −28.1^§^ (−33.5, −22.7)^‡^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 48 | 56.6 (14.9) | 140 | NR | −13.81^§^ (1.11)^ǁ^ | 56.8 (13.7) | 140 | NR | −16.96^§^ (1.11)^ǁ^ | MDC (95% CI)=3.15 (0.92, 5.39), 0.03
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^; Fair | Dem | ADL/IADL (DAD, 0–46, ↑) | IG1 | 6 | 33.5 (NR) | 89 | 31.8 (NR) | NR | 33.1 (NR) | 85 | 30.5 (NR) | NR | NR, 0.34
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG2 | 6 | 45.82 (4.6) | NR | NR | −0.34 (4.29) | 45.87 (5.2) | NR | NR | −1.06 (4.54) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG2 | 12 | 45.82 (4.6) | NR | NR | −1.08 (4.90) | 45.87 (5.2) | NR | NR | −1.44 (5.00) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG2 | 18 | 45.82 (4.6) | NR | NR | −2.13 (5.76) | 45.87 (5.2) | NR | NR | −2.34 (6.02) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG2 | 24 | 45.82 (4.6) | NR | NR | −2.84 (6.16) | 45.87 (5.2) | NR | NR | −3.43 (6.73) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG2 | 30 | 45.82 (4.6) | NR | NR | −4.16 (7.46) | 45.87 (5.2) | NR | NR | −5.00 (8.05) | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG2 | 36 | 45.82 (4.6) | 185 | NR | −5.63 (8.75) | 45.87 (5.2) | 193 | NR | −6.39 (8.99) | NR
Dietary supplement | Omega-3 fatty acids | Phillips, 2015^*^,^257^; Fair | MCI + Dem | ADL/IADL (Bristol ADL, 0–60, ↓) | IG1 | 4 | 2.62 (5.28) | 37 | 3.35 (7.10) | NR | 4.72 (7.34) | 39 | 5.38 (8.07) | NR | NR, 0.595
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | ADL (ADCS-ADL, 0–27, ↓) | IG1 | 6 | NR | 219 | NR | −4.5 (−5.8, −3.4)^‡^ | NR | 147 | NR | −3.2 (−4.6, −2.0)^‡^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | ADL (ADCS-ADL, 0–27, ↓) | IG1 | 12 | NR | 192 | NR | −6.4 (−8.0, −5.2)^‡^ | NR | 141 | NR | −6.7 (−8.3, −5.1)^‡^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | ADL (ADCS-ADL, 0–27, ↓) | IG1 | 18 | NR | 178 | NR | −11.51 (−13.45, −9.57)^‡^ | NR | 130 | NR | −10.43 (−12.45, −8.41)^‡^ | NR, 0.38
Dietary supplement | Vitamin E | Sano, 1997^259^; Good | Dem | ADL (Dependency Scale, D) | IG1 | 24 | NA | 85 | 65 (76.5)^¶^ | NR | NA | 84 | 72 (85.7)^¶^ | NR | NR, 0.039
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | ADL (ADCS-ADL, 0–27, ↓) | IG1 | 12 | 2.2 (0.3)^ǁ^ | 11 | NR | 2.5 (1.0)^ǁ^ | 3.3 (1.0)^ǁ^ | 11 | NR | 2.9 (0.7)^ǁ^ | NR, 0.82
Dietary supplement | Omega-3 and LA | Shinto, 2014^*^,^260^; Fair | Dem | ADL (ADCS-ADL, 0–27, ↓) | IG2 | 12 | 1.5 (0.6)^ǁ^ | 12 | NR | 1.3 (0.8)^ǁ^ | 3.3 (1.0)^ǁ^ | 11 | NR | 2.9 (0.7)^ǁ^ | NR, 0.15
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | IADL (ADCS-ADL, 0–14, ↓) | IG1 | 6 | 10.8 (1.1)^ǁ^ | 11 | NR | 1.29 (0.75)^ǁ^ | 10.0 (1.8)^ǁ^ | 11 | NR | 1.53 (0.75)^ǁ^ | NR
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Dem | IADL (ADCS-ADL, 0–14, ↓) | IG1 | 12 | 10.8 (1.1)^ǁ^ | 12 | NR | 0.7 (1.0)^ǁ^ | 10.0 (1.8)^ǁ^ | 11 | NR | 4.2 (0.9)^ǁ^ | NR, <0.01
Dietary supplement | Omega-3 and LA | Shinto, 2014^*^,^260^; Fair | Dem | IADL (ADCS-ADL, 0–14, ↓) | IG2 | 6 | 6.8 (1.9)^ǁ^ | 12 | NR | 1.51 (0.6)^ǁ^ | 10.0 (1.8)^ǁ^ | 11 | NR | 1.53 (0.6)^ǁ^ | NR, NR
Dietary supplement | Omega-3 and LA | Shinto, 2014^*^,^260^; Fair | Dem | IADL (ADCS-ADL, 0–14, ↓) | IG2 | 12 | 6.8 (1.9)^ǁ^ | 12 | NR | 0.9 (1.1)^ǁ^ | 10.0 (1.8)^ǁ^ | 11 | NR | 4.2 (1.1)^ǁ^ | NR, 0.01
Dietary supplement | Multivitamin | Sun, 2007^262^; Fair | Dem | ADL (Barthel Index, 0–6, ↑) | IG1 | 24 | NR | 45 | NR | −0.33 (−1.03, 0.36)^‡^ | NR | 44 | NR | −0.19 (−0.57, 0.20)^‡^ | NR, 0.70
Dietary supplement | Multivitamin | Sun, 2007^262^; Fair | Dem | IADL (Lawton and Brody IADL, 0–8, ↑) | IG1 | 6 | NR | 45 | NR | 0.04 (−1.01, 1.08)^‡^ | NR | 44 | NR | 0.04 (−0.41, 0.33)^‡^ | NR, 0.89
Dietary supplement | Omega-3 fatty acids | Yurko-Mauro, 2010^263^; Good | MCI | ADL (ADCS-ADL, 0–27, ↓) | IG1 | 6 | NR | 241 | NR | −2.0 (0.3)^ǁ^ | NR | 242 | NR | −1.7 (0.3) | NR, <0.59

* New study

† Median

‡ 95% CI

§ Least squares mean change

ǁ Standard error

¶ Number (%) of patients receiving a higher score on Dependence Scale at followup

Abbreviations: ADL = Activities of Daily Living; ADCS-ADL = Alzheimer’s Disease Cooperative Study Activities of Daily Living 23 items; ADFACS = Alzheimer’s Disease Functional Assessment and Change Scale; BL = baseline; CG = control group; CI = confidence interval; D = dichotomized; DAD = Disability Assessment for Dementia; Dem = dementia; ES = effect size; FU = followup; GARS = Groningen Activity Restriction Scale; HMG-CoA = β-Hydroxy β-methylglutaryl-CoA; IADL = Instrumental Activities of Daily Living; IG = intervention group; Int arm = intervention arm; Katz Index = Katz Index of Independence in Activities of Daily Living; LSM = least squares mean; MCI = mild cognitive impairment; MDC = mean difference in change; mo. = months; n = number of participants analyzed; NOSGER = Nurses’ Observation Scale for Geriatric Patients scale; NA = not applicable; NR = not reported; NS = Not statistically significant; NSAID = Nonsteroidal Anti-inflammatory Drug; Pop cat = population category; SD = standard deviation; SE = standard error

Appendix F Table 4 Other Medications and Supplements: Detailed Results for Mental Health and Neuropsychiatric Symptom Outcomes, by Agent

Medication type | Medication | Author, year Quality | Pop cat | Symptom (Instrument, range^†^) | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Antihypertensive | Discontinuation of antihypertensive | Moonen, 2015^*^,^237^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 4 | 1^‡^ (NR) | 180 | NR | −0.05 (−0.29, 0.19)^§^ | 1^‡^ (NR) | 176 | NR | −0.19 (−0.43, 0.05)^§^ | NR, 0.41
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 9.7 (11.5) | 285 | NR | 1.01^ǁ^ (0.52)^¶^ | 9.6 (10.3) | 309 | NR | 0.42^ǁ^ (0.50)^¶^ | LSM change (SE)=0.59 (0.72), 0.41
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 11 | 9.7 (11.5) | 231 | NR | 1.03 (0.66)^¶^ | 9.6 (10.3) | 277 | NR | 1.89 (0.61)^¶^ | LSM change (SE)=−0.86 (0.90), 0.34
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 18 | 9.7 (11.5) | 215 | NR | 2.15^ǁ^ (0.88)^¶^ | 9.6 (10.3) | 255 | NR | 3.25^ǁ^ (0.81)^¶^ | LSM change (SE)=−1.1 (1.20), 0.36
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^259^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | 9.2 (10.5) | 204 | NR | −0.64 (8.61) | 7.8 (8.3) | 202 | NR | 0.21 (8.02) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^259^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 9.2 (10.5) | 204 | NR | −0.09 (9.61) | 7.8 (8.3) | 202 | NR | 1.26 (9.16) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^259^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | 9.2 (10.5) | 204 | NR | 1.95 (10.64) | 7.8 (8.3) | 202 | NR | 3.60 (10.38) | NS
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^259^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 18 | 9.2 (10.5) | 204 | NR | 3.21 (12.71) | 7.8 (8.3) | 202 | NR | 3.78 (10.73) | NS
HMG-CoA reductase inhibitor | Atorvastatin | Sparks, 2005^241^; Fair | Dem | Dep (GDS-15, 0–15) | IG1 | 12 | 5.25 (0.69)^¶^ | 25 | 3.75 (1.91)^¶^ | NR | 6.61 (0.88)^¶^ | 21 | 8.16 (1.76)^¶^ | NR | NR, 0.04
NSAID | Naproxen | Aisen, 2003^242^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | 9.4 (9.6) | 118 | 13.1 (14.4) | 3.7 (12.5) | 8.7 (10.6) | 111 | 12.2 (12.8) | 3.4 (11.9) | NR, 0.76
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | NPS (NPI-10, 0–120) | IG1 | 6 | 11.2 (12.0) | 20 | NR | 1.7 (14.0) | 7.1 (6.7) | 23 | NR | −0.3 (4.9) | MDC (95% CI)=3.6 (−2.9, 10.1), NR
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Dem | NPS (NPI-10, 0–120) | IG1 | 12 | 11.2 (12.0) | 19 | NR | 3.2 (18.1) | 7.1 (6.7) | 19 | NR | 9.4 (14.0) | MDC (95% CI)=−4.6 (−15.8, 6.6), NR
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | Dep (GDS, 0–30) | IG1 | 12 | NR | 66 | NR | 0.2 (0.5)^¶^ | NR | 66 | NR | −0.1 (0.5)^¶^ | MDC (95% CI)=0.4 (−0.8, 1.5), 0.545
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | NR | 66 | NR | −2.2 (2.0)^¶^ | NR | 66 | NR | −1.3 (2.2)^¶^ | MDC (95% CI)=−0.9 (−5.3, 3.4), 0.669
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | NPS (BEHAVE-AD1, 0–75) | IG1 | 3 | 4.6 (4.8) | 266 | NR | 0.25^ǁ^ (NR) | 5.0 (5.5) | 124 | NR | 0.30 (NR) | NR, 0.897
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | NPS (BEHAVE-AD1, 0–75) | IG1 | 6 | 4.6 (4.8) | 275 | NR | 1.01^ǁ^ (NR) | 5.0 (5.5) | 135 | NR | 0.28^ǁ^ (NR) | NR, 0.122
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Dem | NPS (BEHAVE-AD1, 0–75) | IG1 | 12 | 4.6 (4.8) | 276 | NR | 1.46^ǁ^ (NR) | 5.0 (5.5) | 135 | NR | 1.18^ǁ^ (NR) | NR, 0.655
Gonadal steroid | Estrogen | Henderson, 2000^247^; Fair | Dem | Dep (MADRS, 0–60) | IG1 | 4 | 9.7 (2.0)^¶^ | 18 | 9.8 (1.8)^¶^ | 0.2 (1.6)^¶^ | 10.9 (2.1)^¶^ | 18 | 12.0 (2.1)^¶^ | 1.1 (1.4)^¶^ | MDC=−0.9, >0.1
Gonadal steroid | Estrogen | Henderson, 2000^247^; Fair | Dem | Dep (GDS, 0–30) | IG1 | 4 | 17.8 (1.4)^¶^ | 18 | 16.4 (1.9)^¶^ | −1.4 (1.4)^¶^ | 16.5 (1.8)^¶^ | 18 | 15.8 (1.9)^¶^ | −0.7 (1.2)^¶^ | MDC=−0.7, >0.1
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | NPS (NPI-10, 0–120) | IG1 | 6 | 5.2 (6.6) | 21 | NR | 0.7 (NR) | 5.8 (7.8) | 21 | NR | 3.1 (NR) | ES (95% CI): −0.35 (−1.04, 0.35), NR
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Dem | NPS (NPI-10, 0–120) | IG1 | 12 | 5.2 (6.6) | 21 | NR | 2.3 (NR) | 5.8 (7.8) | 21 | NR | 2.5 (NR) | ES (95% CI): −0.02 (−0.70, 0.65), NR
Gonadal steroid | Testosterone | Lu, 2006^248^; Fair | Dem | Dep (BDI, 0–63) | IG1 | 6 | 6.8 (4.3) | 4 | 6.5 (2.5) | −0.3 (3.6) | 8.6 (4.9) | 7 | 9.1 (3.8) | 0.6 (6.0) | NR, 0.32
Gonadal steroid | Testosterone | Lu, 2006^248^; Fair | Dem | NPS (NPI-10, 0–120) | IG1 | 6 | 4.2 (3.5) | 5 | 5.4 (7.6) | 1.2 (5.4) | 7.8 (7.3) | 8 | 11.1 (17.1) | 3.4 (16.4) | NR, 0.74
Gonadal steroid | Testosterone | Lu, 2006^248^; Fair | Dem | NPS (NPI-10, D) | IG1 | 6 | NA | 9 | 4 (44.4)^#^ | NR | NA | 9 | 7 (77.8)^#^ | NR | NR, >0.16
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | Dep (HDRS, 0–52) | IG1 | 12 | 3.4 (4.0) | 42 | NR | 0.5 (3.7) | 3.8 (4.0) | 39 | NR | 0.03 (3.9) | NR, 0.69
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Dem | Dep (HDRS, 0–52) | IG2 | 12 | 3.2 (3.0) | 39 | NR | −0.1 (4.3) | 3.8 (4.0) | 39 | NR | 0.03 (3.9) | NR, 0.69
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^; Fair | Dem | Dep (CERAD Depression, 0–9) | IG1 | 12 | 1.1 (1.3) | 29 | 1.2 (1.8) | NR | 1.6 (1.6) | 26 | 1.2 (1.3) | NR | MDC (SD)=−0.6 (1.3), 0.13
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^; Fair | Dem | Dep (CERAD Depression, 0–9)^**^ | IG1 | 12 | 2.3 (2.0) | 29 | 2.4 (1.9) | NR | 3.0 (2.2) | 26 | 3.2 (1.7) | NR | MDC (SD)=−0.4 (2.8), 0.62
Gonadal steroid | Estrogen | Wang, 2000^251^; Fair | Dem | Anx (HARS, 0–56) | IG1 | 3 | 6.4 (4.7) | 25 | NR | −0.8 (4.7) | 7.2 (4.3) | 25 | NR | 0.4 (2.6) | NR, 0.277
Gonadal steroid | Estrogen | Wang, 2000^251^; Fair | Dem | Dep (HDRS, 0–52) | IG1 | 3 | 7.1 (4.5) | 25 | NR | −1.2 (5.8) | 7.5 (4.9) | 25 | NR | 0.4 (4.8) | NR, 0.335
Gonadal steroid | Estrogen | Wang, 2000^251^; Fair | Dem | NPS (BEHAVE-AD1, 0–75) | IG1 | 3 | 4.9 (5.7) | 25 | NR | −0.4 (3.8) | 4.7 (5.5) | 25 | NR | −0.8 (5.0) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | 6.0^‡^ (NR) | 234 | NR | 0.71 (6.31) | 5.0^‡^ (NR) | 164 | NR | 0.64 (4.83) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 6.0^‡^ (NR) | 231 | NR | 0.97 (10.82) | 5.0^‡^ (NR) | 159 | NR | 1.03 (8.82) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | 6.0^‡^ (NR) | 215 | NR | 1.03 (10.53) | 5.0^‡^ (NR) | 145 | NR | 1.19 (9.31) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 18 | 6.0^‡^ (NR) | 198 | NR | 3.31 (12.84) | 5.0^‡^ (NR) | 136 | NR | 2.2 (11.12) | NR
Dietary supplement | B vitamins (including folic acid) | de Jager, 2012^254^; Fair | MCI | Dep (GDS, 0–30) | IG1 | 24 | NR | 133 | NR | −0.073 (3.4) | NR | 133 | NR | 0.018 (3.6) | NS
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 6 | 7.5^‡^ (NR) | 133 | NR | −1.24^ǁ^ (−3.35, 0.87)^§^ | 8.0^‡^ (NR) | 135 | NR | 0.47^ǁ^ (−1.62, 2.57)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 12 | 7.5^‡^ (NR) | 122 | NR | −1.04^ǁ^ (−3.40, 1.34)^§^ | 8.0^‡^ (NR) | 112 | NR | 1.08^ǁ^ (−1.36, 3.53)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 18 | 7.5^‡^ (NR) | 103 | NR | 0.93^ǁ^ (−1.81, 3.68)^§^ | 8.0^‡^ (NR) | 96 | NR | 4.05^ǁ^ (1.26, 6.87)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 24 | 7.5^‡^ (NR) | 87 | NR | 2.16^ǁ^ (−1.25, 5.58)^§^ | 8.0^‡^ (NR) | 75 | NR | 3.59^ǁ^ (0.004, 7.19)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 30 | 7.5^‡^ (NR) | 64 | NR | 3.20^ǁ^ (−0.13, 6.55)^§^ | 8.0^‡^ (NR) | 55 | NR | 1.68^ǁ^ (−1.88, 5.21)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 36 | 7.5^‡^ (NR) | 51 | NR | 2.14^ǁ^ (−1.73, 6.01)^§^ | 8.0^‡^ (NR) | 41 | NR | 0.60^ǁ^ (−3.63, 4.83)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 42 | 7.5^‡^ (NR) | 39 | NR | 0.82^ǁ^ (−4.35, 6.01)^§^ | 8.0^‡^ (NR) | 33 | NR | 3.63^ǁ^ (−2.01, −9.31)^§^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG2 | 48 | 7.5^‡^ (NR) | 140 | NR | 0.79^ǁ^ (1.00)^¶^ | 8.0^‡^ (NR) | 140 | NR | 2.26^ǁ^ (1.01)^¶^ | MDC (95% CI)=−1.46 (−3.55, 0.63), 0.94
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^; Fair | Dem | Dep (MADRS, 0–30) | IG1 | 6 | 1.8 (NR) | 89 | 1.5 (NR) | NR | 1.9 (NR) | 85 | 1.6 (NR) | NR | NR, 0.49
Dietary supplement | Omega-3 fatty acids | Freund-Levi, 2006^255^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 15.6 (NR) | 89 | 16.6 (NR) | NR | 14.9 (NR) | 85 | 16.0 (NR) | NR | NR, 0.45
Dietary supplement | B vitamins (including folic acid) | Kwok, 2011^256^; Fair | Dem | Dep (CSDD, 0–38) | IG1 | 24 | 1.9 (2.5) | 59 | NR | 0^††^ (−2, 0) | 1.8 (2.5) | 53 | NR | 0^††^ (−2, 1) | NR, 0.436
Dietary supplement | B vitamins (including folic acid) | Kwok, 2011^256^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 24 | 7.7 (11.4) | 59 | NR | 0^††^ (−3, 7) | 9.0 (11.0) | 53 | NR | 0^††^ (−2.5, 7) | NR, 0.606
Dietary supplement | Omega-3 fatty acids | Phillips, 2015^*^,^257^; Fair | MCI + Dem | Dep (BASDEC, 0–21) | IG1 | 4 | 2.7 (2.4) | 37 | 2.3 (2.9) | NR | 2.3 (2.0) | 39 | 2.1 (2.5) | NR | NR, 0.548
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | NR | 219 | NR | 1.8 (0.4, 3.3)^§^ | NR | 146 | NR | 1.0 (−0.8, 2.6)^§^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | NR | 192 | NR | 0.7 (−0.9, 2.1)^§^ | NR | 141 | NR | 2.7 (0.8, 4.9)^§^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 18 | NR | 176 | NR | 2.93 (0.92, 4.94)^§^ | NR | 129 | NR | 5.09 (2.49, 7.69)^§^ | MDC (95% CI)=NR (NR, NR), 0.11
Dietary supplement | Omega-3 fatty acids - DHA | Sinn, 2012^261^; Fair | MCI | Dep (GDS-15, 0–15) | IG1 | 6 | 3.19 (3.17) | 18 | −0.68 (0.30) | NR | 3.15 (2.08) | 14 | 0.69 (0.61) | NR | ES (SE) (95% CI): −1.40 (0.53)(−2.47, −0.32), 0.01
Dietary supplement | Omega-3 fatty acids - EPA | Sinn, 2012^261^; Fair | MCI | Dep (GDS-15, 0–15) | IG2 | 6 | 4.40 (2.92) | 17 | −0.52 (0.30) | NR | 3.15 (2.08) | 14 | 0.69 (0.61) | NR | ES (SE) (95% CI): −1.23 (0.56)(−2.37, −0.09), 0.04
Dietary supplement | Omega-3 fatty acids | Yurko-Mauro, 2010^263^; Good | MCI | Dep (GDS, 0–30) | IG1 | 6 | 1.3 (1.2) | 241 | 1.4 (1.6) | 0.1 (0.10)^¶^ | 1.3 (1.3) | 242 | 1.3 (1.5) | 0.0 (0.08)^¶^ | MDC (SE)=0.1 (0.12), 0.230

* New study

† Lower scores indicate better outcomes for all instruments

‡ Median

§ 95% CI

ǁ Least squares mean change

¶ Standard error

# Number (%) of participants displaying at least 1 neuropsychiatric symptom of mild severity based on NPI

** Caregiver-reported

†† Median change (IQR)

Abbreviations: Anx = anxiety; BASDEC = Brief Assessment Schedule Depression Cards; BDI = Beck Depression Inventory; BEHAVE-AD1 = Behavioral Pathology in Alzheimer’s Disease – Part 1; BL = baseline; CERAD = Consortium to Establish a Registry for Alzheimer’s Disease; CG = control group; CI = confidence interval; CSDD = Cornell Scale for Depression in Dementia; Dem = dementia; Dep = depression; ES = effect size; FU = followup; GDS = Geriatric Depression Scale; GDS-15 = Geriatric Depression Scale-15 Item; HARS = Hamilton Anxiety Rating Scale; HDRS = Hamilton Depression Rating Scale; HMG-CoA = β-Hydroxy β-methylglutaryl-CoA; IG = intervention group; Int arm = intervention arm; LSM = least squares mean; MADRS = Montgomery-Åsberg Depression Rating Scale; MCI = mild cognitive impairment; MDC = mean difference in change; mo. = months; NPI-10 = Neuropsychiatric Inventory-10 item; NPI-12 = Neuropsychiatric Inventory-12 item; NPS = Composite neuropsychiatric symptoms; NR = not reported; NS = not statistically significant; NSAID = Nonsteroidal Anti-inflammatory Drug; Pop cat = population category; SD = standard deviation; SE = standard error

Appendix F Table 5 Other Medications and Supplements: Detailed Results for Harms, by Medication Type

Medication type | Intervention | Author, year Quality | Outcome | Int arm | Time, mo. | IG n at FU | IG FU N (%) with event | CG n at FU | CG FU N (%) with event | Between group difference, p-value
Antihypertensive | Discontinuation of antihypertensive | Moonen, 2015^*^,^237^; Fair | Serious adverse events | IG1 | 4 | 199 | 13^†^ | 186 | 13^†^ | NR
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Adverse events | IG1 | 18 | 314 | 272 (86.6) | 325 | 277 (85.2) | NR
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Serious adverse events | IG1 | 18 | 314 | 50 (15.9) | 325 | 51 (15.7) | NR
HMG-CoA reductase inhibitor | Atorvastatin | Feldman, 2010^238^; Fair | Withdrawals due to adverse events | IG1 | 18 | 314 | 56 (17.8) | 325 | 31 (9.5) | NR
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Adverse events | IG1 | 18 | 204 | 189 (92.6) | 202 | 181 (89.6) | NR, 0.91
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Serious adverse events | IG1 | 18 | 204 | 56 (27.5) | 202 | 54 (26.7) | NR, 0.91
HMG-CoA reductase inhibitor | Simvastatin | Sano, 2011^239^; Fair | Withdrawals due to adverse events | IG1 | 18 | 204 | 13 (6.4) | 202 | 16 (7.9) | NR
HMG-CoA reductase inhibitor | Simvastatin | Simons, 2002^240^; Fair | Withdrawals due to adverse events | IG1 | 6 | 24 | 2 (8.3) | 20 | 0 (0.0) | NR
NSAID | Naproxen | Aisen, 2003^242^; Good | Withdrawals due to adverse events | IG1 | 12 | 118 | 10 (8.5) | 111 | 11 (9.9) | NR
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Serious adverse events | IG1 | 12 | 26 | 5 (19.2) | 25 | 1 (4.0) | NR
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Withdrawals due to adverse events | IG1 | 6 | 26 | 5 (19.2) | 25 | 0 (0.0) | NR
NSAID | Indomethacin | de Jong, 2008^243^; Fair | Withdrawals due to adverse events | IG1 | 12 | 20 | 1 (5.0) | 23 | 0 (0.0) | NR
NSAID | Ibuprofen | Pasqualetti, 2009^244^; Fair | Withdrawals due to adverse events | IG1 | 12 | 66 | 7 (10.6) | 66 | 10 (15.2) | NR
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Adverse events | IG1 | 12 | 285 | 229 (80.4) | 140 | 105 (75.0) | NR
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Serious adverse events | IG1 | 12 | 285 | 73 (25.6) | 140 | 32 (22.9) | NR
NSAID | Celecoxib | Soininen, 2007^245^; Fair | Withdrawals due to adverse events | IG1 | 12 | 285 | 34 (11.9) | 140 | 15 (10.7) | NR
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Adverse events | IG1 | 12 | 21 | 54^†^ | 21 | 44^†^ | NR
Gonadal steroid | Estrogen | Henderson, 2015^*^,^246^; Good | Serious adverse events | IG1 | 12 | 21 | 2 (9.5) | 21 | 1 (4.8) | NR
Gonadal steroid | Testosterone | Lu, 2006^248^; Fair | Withdrawals due to adverse events | IG1 | 6 | 9 | 2 (22.2) | 9 | 0 (0.0) | NR
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Withdrawals due to adverse events | IG1 | 12 | 42 | 7 (16.7) | 39 | 2 (5.1) | NR
Gonadal steroid | Estrogen | Mulnard, 2000^249^; Fair | Withdrawals due to adverse events | IG2 | 12 | 39 | 4 (10.3) | 39 | 2 (5.1) | NR
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^; Fair | Adverse events | IG1 | 12 | 33 | 25 (75.8) | 32 | 18 (56.3) | NR
Gonadal steroid | Estrogen plus progestin | Valen-Sendstad, 2010^250^; Fair | Serious adverse events | IG1 | 12 | 33 | 0 (0) | 32 | 3 (9.4) | NR
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Adverse events | IG1 | 18 | 240 | 224 (93.3) | 169 | 161 (95.3) | NR, 0.52
Dietary supplement | B vitamins (including folic acid) | Aisen, 2008^252^; Good | Serious adverse events | IG1 | 18 | 240 | 123 (51.3) | 169 | 95 (56.2) | NR, 0.37
Dietary supplement | B vitamins (including folic acid) | de Jager, 2012^254^; Fair | Adverse events | IG1 | 24 | 133 | 242^†^ | 133 | 271^†^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Adverse events | IG2 | 48 | 152 | 198^†^ | 152 | 202^†^ | NR
Dietary supplement | Vitamin E | Dysken, 2014^*^,^224^; Good | Serious adverse events | IG2 | 48 | 152 | 180^†^ | 152 | 170^†^ | NR
Dietary supplement | Vitamin E | Petersen, 2005^196^; Fair | Adverse events | IG2 | 36 | 257 | 82^†^ | 259 | 64^†^ | NR
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Adverse events | IG1 | 18 | 238 | 214^†^ | 164 | 144^†^ | NR, 0.52
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Serious adverse events | IG1 | 18 | 238 | 76^†^ | 164 | 50^†^ | NR, 0.83
Dietary supplement | Omega-3 fatty acids | Quinn, 2010^258^; Fair | Withdrawals due to adverse events | IG1 | 18 | 238 | 14 (5.9) | 164 | 10 (6.1) | NR
Dietary supplement | Omega-3 fatty acids | Shinto, 2014^*^,^260^; Fair | Adverse events | IG1 | 12 | 13 | 4^†^ | 13 | 7^†^ | NR
Dietary supplement | Omega-3 and LA | Shinto, 2014^*^,^260^; Fair | Adverse events | IG2 | 12 | 13 | 7^†^ | 13 | 7^†^ | NR
Dietary supplement | Omega-3 fatty acids - DHA | Sinn, 2012^261^; Fair | Withdrawals due to adverse events | IG1 | 6 | 18 | 1 (5.6) | 15 | 0 (0.0) | NR
Dietary supplement | Omega-3 fatty acids - EPA | Sinn, 2012^261^; Fair | Withdrawals due to adverse events | IG2 | 6 | 17 | 0 (0.0) | 15 | 0 (0.0) | NR
Dietary supplement | Multivitamin | Sun, 2007^262^; Fair | Adverse events | IG1 | 6 | 45 | 21 (46.7) | 44 | 14 (31.8) | NR
Dietary supplement | Multivitamin | Sun, 2007^262^; Fair | Serious adverse events | IG1 | 6 | 45 | 2 (4.4) | 44 | 1 (2.3) | NR
Dietary supplement | Multivitamin | Sun, 2007^262^; Fair | Withdrawals due to adverse events | IG1 | 6 | 45 | 5 (11.1) | 44 | 4 (9.1) | NR
Dietary supplement | Omega-3 fatty acids | Yurko-Mauro, 2010^263^; Good | Adverse events | IG1 | 6 | 242 | 109^†^ | 243 | 109^†^ | NR
Dietary supplement | Omega-3 fatty acids | Yurko-Mauro, 2010^263^; Good | Serious adverse events | IG1 | 6 | 242 | 7 (2.9) | 243 | 7 (2.9) | NR
Dietary supplement | Omega-3 fatty acids | Yurko-Mauro, 2010^263^; Good | Withdrawals due to adverse events | IG1 | 6 | 242 | 8 (3.3) | 243 | 6 (2.5) | NR

* New study

† Number of events reported

Abbreviations: CG = control group; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FU = followup; HMG-CoA = β-Hydroxy β-methylglutaryl-CoA; IG = intervention group; Int arm = intervention arm; LA = linoleic acid; mo. = months; n (%) = number (percentage) of participants reporting events; NR = not reported; NSAID = Nonsteroidal Anti-inflammatory Drug