# Appendix E Detailed Trial Results for Trials of AChEIs and Memantine

Appendix E Table 1 AChEIs and Memantine: Detailed Results for Global Cognitive Function Outcomes, by Medication Type

Medication | Author, year Quality | Pop cat | Instrument (range)^†^ | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Donepezil | Black, 2003^186^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 20.9^‡^ (0.7)^§^ | 186 | NR | −1.52^ǁ^ (0.40)^§^ | 20.1^‡^ (0.7)^§^ | 188 | NR | 0.72^ǁ^ (0.40)^§^ | NR, <0.001
Donepezil | Black, 2003^186^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 21.2^‡^ (0.8)^§^ | 185 | NR | −0.96^ǁ^ (0.39)^§^ | 20.1^‡^ (0.7)^§^ | 188 | NR | 0.72^ǁ^ (0.40)^§^ | NR, <0.01
Donepezil | Black, 2003^186^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | 21.8^‡^ (0.3)^§^ | 195 | NR | 1.49^ǁ^ (0.20)^§^ | 21.7^‡^ (0.3)^§^ | 194 | NR | 0.39^ǁ^ (0.23)^§^ | NR, <0.001
Donepezil | Black, 2003^186^; Fair-Good | Dem | MMSE (0–30) | IG2 | 6 | 21.9^‡^ (0.3)^§^ | 196 | NR | 1.04^ǁ^ (0.21)^§^ | 21.7^‡^ (0.3)^§^ | 194 | NR | 0.39^ǁ^ (0.23)^§^ | NR, <0.05
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | NR | 202 | NR | −1.90^ǁ^ (0.31)^§^ | NR | 219 | NR | 0.37^ǁ^ (0.30)^§^ | NR, <0.0001
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | NR | 202 | NR | −1.70^ǁ^ (0.37)^§^ | NR | 219 | NR | 1.31^ǁ^ (0.38)^§^ | NR, <0.0001
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | NR | 273 | NR | −1.27^ǁ^ (0.35)^§^ | NR | 274 | NR | 1.66^ǁ^ (0.36)^§^ | LSM Change=−2.9, <0.0001
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | NR | 211 | NR | −1.54^ǁ^ (0.29)^§^ | NR | 219 | NR | 0.37^ǁ^ (0.30)^§^ | NR, <0.0001
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 4 | NR | 211 | NR | −0.58^ǁ^ (0.35)^§^ | NR | 219 | NR | 1.31^ǁ^ (0.38)^§^ | NR, 0.0002
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | NR | 271 | NR | 0.18^ǁ^ (0.35)^§^ | NR | 274 | NR | 1.66^ǁ^ (0.36)^§^ | LSM Change=−1.5, 0.0021
Donepezil | Doody, 2009^188^; Fair | MCI | ADAS-Cog 13 (0–89) | IG1 | 11 | 18.3 (6.6) | 379 | NR | −1.0 (0.4)^§^ | 18.2 (7.0) | 378 | NR | −0.13 (0.4)^§^ | MDC (SE)=−0.9 (0.37), 0.01
Donepezil | Doody, 2009^188^; Fair | MCI | MMSE (0–30) | IG1 | 11 | 27.5 (1.9) | 379 | NR | 0.1 (0.1)^§^ | 27.4 (1.9) | 378 | NR | 0.0 (0.2)^§^ | NS
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | MMSE (0–30) | IG1 | 3 | 11.72 (0.35)^§^ | 127 | NR | 1.79^ǁ^ (0.35)^§^ | 11.97 (0.34)^§^ | 132 | NR | 0.23^ǁ^ (0.34)^§^ | NR, 0.0004
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | 11.72 (0.35)^§^ | 131 | NR | 1.34^ǁ^ (0.34)^§^ | 11.97 (0.34)^§^ | 139 | NR | −0.42^ǁ^ (0.34)^§^ | MDC=1.79, <0.0001
Donepezil | Holmes, 2004^190^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | 21.1 (0.9)^§^ | 41 | NR | −0.1 (0.6)^§^ | 20.8 (0.6)^§^ | 55 | NR | 1.8 (0.5)^§^ | NR, 0.02
Donepezil | Ikeda, 2015^*^,^191^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 20.3 (4.8) | 49 | NR | 2.2 (0.4)^§^ | 20.3 (4.2) | 44 | NR | 0.6 (0.5)^§^ | MDC (95% CI)=1.6 (0.3, 2.8), 0.016
Donepezil | Ikeda, 2015^*^,^191^; Fair | Dem | MMSE (0–30) | IG2 | 3 | 20.6 (4.1) | 43 | NR | 1.4 (0.5)^§^ | 20.3 (4.2) | 44 | NR | 0.6 (0.5)^§^ | MDC (95% CI)=0.8 (−0.5, 2.1), 0.232
Donepezil | Krishnan, 2003^192^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 26.51 (12.13) | 31 | NR | −2.06^ǁ^ (NR) | 26.44 (12.29) | 30 | NR | 1.22^ǁ^ (NR) | NR, <0.007
Donepezil | Krishnan, 2003^192^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 26.51 (12.13) | 30 | NR | −1.72^ǁ^ (NR) | 26.44 (12.29) | 29 | NR | 1.60^ǁ^ (NR) | NR, <0.04
Donepezil | Krishnan, 2003^192^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 26.51 (12.13) | 34 | NR | 0.01^ǁ^ (NR) | 26.44 (12.29) | 32 | NR | 3.2^ǁ^ (NR) | NR, <0.04
Donepezil | Mazza, 2006^193^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | 18.55 (3.47) | 25 | NR | 1.2 (−3.6, 1.2)^¶^ | 18.80 (3.63) | 26 | NR | −0.25 (−2.17, 2.67)^¶^ | MDC (95% CI)=1.2 (−1.2, 3.6), 0.06
Donepezil | Mori, 2012^195^; Fair | Dem | MMSE (0–30) | IG1 | 3 | 19.8 (4.4) | 36 | NR | 2.0 (3.3) | 18.3 (4.7) | 31 | NR | −0.4 (2.7) | MDC (95% CI)=2.4 (0.9, 3.9), <0.001
Donepezil | Mori, 2012^195^; Fair | Dem | MMSE (0–30) | IG2 | 3 | 19.8 (4.4) | 32 | NR | 3.4 (3.2) | 18.3 (4.7) | 31 | NR | −0.4 (2.7) | MDC (95% CI)=3.8 (2.3, 5.3), <0.001
Donepezil | Mori, 2012^195^; Fair | Dem | MMSE (0–30) | IG3 | 3 | 20.4 (4.1) | 35 | NR | 1.6 (3.8) | 18.3 (4.7) | 31 | NR | −0.4 (2.7) | MDC (95% CI)=2.0 (0.4, 3.7), 0.013
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 6 | 11.28 (4.5) | NR | NR | −0.61 (3.79) | 11.03 (4.2) | NR | NR | −0.13 (3.34) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 12 | 11.28 (4.5) | NR | NR | 0.17 (3.73) | 11.03 (4.2) | NR | NR | 0.61 (4.10) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 18 | 11.28 (4.5) | NR | NR | 1.08 (4.37) | 11.03 (4.2) | NR | NR | 1.29 (4.71) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 24 | 11.28 (4.5) | NR | NR | 1.22 (4.79) | 11.03 (4.2) | NR | NR | 1.49 (5.07) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 30 | 11.28 (4.5) | NR | NR | 2.71 (5.21) | 11.03 (4.2) | NR | NR | 2.98 (5.62) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 11 (0–70) | IG1 | 36 | 11.28 (4.5) | 161 | NR | 3.68 (5.95) | 11.03 (4.2) | 193 | NR | 3.74 (6.97) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG1 | 6 | 17.72 (6.2) | NR | NR | −1.23 (4.74) | 17.40 (6.0) | NR | NR | −0.09 (4.38) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG1 | 12 | 17.72 (6.2) | NR | NR | −0.55 (5.20) | 17.40 (6.0) | NR | NR | 0.60 (4.96) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG1 | 18 | 17.72 (6.2) | NR | NR | 0.03 (5.64) | 17.40 (6.0) | NR | NR | 0.99 (6.07) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG1 | 24 | 17.72 (6.2) | NR | NR | 0.35 (6.23) | 17.40 (6.0) | NR | NR | 1.02 (6.27) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG1 | 30 | 17.72 (6.2) | NR | NR | 2.05 (6.74) | 17.40 (6.0) | NR | NR | 2.65 (7.02) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | ADAS-Cog 13 (0–85) | IG1 | 36 | 17.72 (6.2) | 161 | NR | 3.12 (7.39) | 17.40 (6.0) | 193 | NR | 3.72 (8.54) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG1 | 6 | 27.25 (1.8) | NR | NR | 0.06 (2.03) | 27.35 (1.8) | NR | NR | −0.36 (2.02) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG1 | 12 | 27.25 (1.8) | NR | NR | −0.31 (2.25) | 27.35 (1.8) | NR | NR | −0.80 (2.34) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG1 | 18 | 27.25 (1.8) | NR | NR | −0.52 (2.46) | 27.35 (1.8) | NR | NR | −1.02 (2.61) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG1 | 24 | 27.25 (1.8) | NR | NR | −0.98 (2.54) | 27.35 (1.8) | NR | NR | −1.49 (2.90) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG1 | 30 | 27.25 (1.8) | NR | NR | −1.47 (3.04) | 27.35 (1.8) | NR | NR | −1.77 (3.24) | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | MMSE (0–30) | IG1 | 36 | 27.25 (1.8) | 161 | NR | −2.31 (3.72) | 27.35 (1.8) | 193 | NR | −2.75 (4.04) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 29.1 (NR) | 38 | NR | −2.5 (−8.0, 7.0)^#^ | 27.2 (NR) | 40 | NR | 0.7 (−7.0, 14.5)^#^ | NR, <0.01
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | 29.2 (NR) | 40 | NR | −1.4 (−12.0, 11.0)^#^ | 27.2 (NR) | 40 | NR | 0.7 (−7.0, 14.5)^#^ | NR, <0.05
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG3 | 3 | 26.6 (NR) | 41 | NR | −0.9 (−11.3, 12.0)^#^ | 27.2 (NR) | 40 | NR | 0.7 (−7.0, 14.5)^#^ | NS
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | MMSE (0–30) | IG1 | 3 | 18.0 (NR) | 38 | NR | 2.0 (−1.0, 7.0)^#^ | 18.2 (NR) | 40 | NR | 1.2 (−6.0, 8.0)^#^ | NS
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | MMSE (0–30) | IG2 | 3 | 18.6 (NR) | 40 | NR | 0.9 (−7.0, 5.0)^#^ | 18.2 (NR) | 40 | NR | 1.2 (−6.0, 8.0)^#^ | NS
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | MMSE (0–30) | IG3 | 3 | 19.6 (NR) | 41 | NR | 0.6 (−4.0, 7.0)^#^ | 18.2 (NR) | 40 | NR | 1.2 (−6.0, 8.0)^#^ | NS
Donepezil | Rogers, 1998^197^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 26.4 (0.89)^§^ | 155 | NR | −2.7^ǁ^ (0.43)^§^ | 25.3 (0.87)^§^ | 150 | NR | 0.4^ǁ^ (0.43)^§^ | MDC (95% CI)=−3.1 (−4.22, −1.92), <0.001
Donepezil | Rogers, 1998^197^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | 26.4 (0.92)^§^ | 156 | NR | −2.1^ǁ^ (0.43)^§^ | 25.3 (0.87)^§^ | 150 | NR | 0.4^ǁ^ (0.43)^§^ | MDC (95% CI)=−2.5 (−3.59, −1.29), <0.001
Donepezil | Rogers, 1998^197^; Fair-Good | Dem | MMSE (0–30) | IG1 | 3 | 19.35 (0.40)^§^ | 156 | NR | 1.3^ǁ^ (0.24)^§^ | 19.80 (0.35)^§^ | 150 | NR | 0.04^ǁ^ (0.25)^§^ | MDC (95% CI)=1.3 (0.65, 1.97), <0.001
Donepezil | Rogers, 1998^197^; Fair-Good | Dem | MMSE (0–30) | IG2 | 3 | 19.39 (0.39)^§^ | 156 | NR | 1.0^ǁ^ (0.25)^§^ | 19.80 (0.35)^§^ | 150 | NR | 0.04^ǁ^ (0.25)^§^ | MDC (95% CI)=1.0 (0.33, 1.65), <0.004
Donepezil | Salloway, 2004^199^; Fair-Good | MCI | ADAS-Cog 13 (0–85) | IG1 | 6 | 20.0 (6.2) | 130 | NR | −3.1 (0.5)^§^ | 19.5 (6.9) | 132 | NR | −1.2 (0.5)^§^ | NR, 0.006
Donepezil | Salloway, 2004^199^; Fair-Good | MCI | ADAS-Cog 13 (D) | IG1 | 6 | NA | 130 | 105 (80.8)^**^ | NR | NA | 132 | 86 (65.2)^**^ | NR | NR
Donepezil | Salloway, 2004^199^; Fair-Good | MCI | ADAS-Cog 13 (D) | IG1 | 6 | NA | 130 | 65 (50.0)^††^ | NR | NA | 132 | 42 (31.8)^††^ | NR | NR
Donepezil | Salloway, 2004^199^; Fair-Good | MCI | ADAS-Cog 13 (D) | IG1 | 6 | NA | 130 | 29 (22.3)^‡‡^ | NR | NA | 132 | 16 (12.1)^‡‡^ | NR | NR
Donepezil | Seltzer, 2004^200^; Fair-Good | Dem | ADAS-Cog 13 (0–85) | IG1 | 3 | 21.0 (7.9) | 79 | NR | −1.52 (0.63)^§^ | 21.3 (6.8) | 51 | NR | 0.39 (0.68)^§^ | NR, 0.03
Donepezil | Seltzer, 2004^200^; Fair-Good | Dem | ADAS-Cog 13 (0–85) | IG1 | 4 | 21.0 (7.9) | 70 | NR | −1.32 (0.68)^§^ | 21.3 (6.8) | 49 | NR | 0.29 (0.65)^§^ | NR, NR
Donepezil | Seltzer, 2004^200^; Fair-Good | Dem | ADAS-Cog 13 (0–85) | IG1 | 6 | 21.0 (7.9) | 91 | NR | −1.64 (0.50)^§^ | 21.3 (6.8) | 55 | NR | 0.59 (0.64)^§^ | MDC=−2.3, 0.001
Donepezil | Seltzer, 2004^200^; Fair-Good | Dem | ADAS-Cog 13 (D) | IG1 | 6 | NA | 67 | 25 (37.3)^††^ | NR | NA | 45 | 7 (15.6)^††^ | NR | NR, 0.02
Donepezil | Seltzer, 2004^200^; Fair-Good | Dem | MMSE (0–30) | IG1 | 3 | 24.1 (1.7) | 79 | NR | 1.60 (0.37)^§^ | 24.3 (1.3) | 51 | NR | 0.39 (0.38)^§^ | NR, 0.04
Donepezil | Seltzer, 2004^200^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | 24.1 (1.7) | 91 | NR | 1.34 (0.36)^§^ | 24.3 (1.3) | 55 | NR | 0.09 (0.42)^§^ | MDC=1.8, 0.002
Donepezil | Tune, 2003^201^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 21.86 (6.59) | 14 | NR | −3.98^ǁ^ (3.46) | 21.81 (10.00) | 13 | NR | −2.95^ǁ^ (3.40) | MDC (95% CI)=NR, (−3.75, 1.69), 0.459
Donepezil | Tune, 2003^201^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 21.86 (6.59) | 14 | NR | −3.65^ǁ^ (5.03) | 21.81 (10.00) | 13 | NR | −1.56^ǁ^ (2.07) | MDC (95% CI)=NR, (−5.18, 1.00), 0.186
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 20.6^‡^ (0.7)^§^ | 172 | NR | −2.97^ǁ^ (0.41)^§^ | 18.8^‡^ (0.7)^§^ | 167 | NR | −0.91^ǁ^ (0.38)^§^ | NR, <0.001
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 20.6^‡^ (0.7)^§^ | 163 | NR | −2.62^ǁ^ (0.48)^§^ | 18.8^‡^ (0.7)^§^ | 160 | NR | −0.16^ǁ^ (0.44)^§^ | NR, <0.001
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 20.6^‡^ (0.7)^§^ | 194 | NR | −2.19^ǁ^ (0.44)^§^ | 18.8^‡^ (0.7)^§^ | 180 | NR | −0.10^ǁ^ (0.39)^§^ | NR, <0.001
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | 20.8^‡^ (0.7)^§^ | 183 | NR | −2.62^ǁ^ (0.35)^§^ | 18.8^‡^ (0.7)^§^ | 167 | NR | −0.91^ǁ^ (0.36)^§^ | NR, <0.001
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 4 | 20.8^‡^ (0.7)^§^ | 173 | NR | −2.18^ǁ^ (0.35)^§^ | 18.8^‡^ (0.7)^§^ | 160 | NR | −0.16^ǁ^ (0.38)^§^ | NR, <0.001
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 20.8^‡^ (0.7)^§^ | 199 | NR | −1.75^ǁ^ (0.33)^§^ | 18.8^‡^ (0.7)^§^ | 180 | NR | −0.10^ǁ^ (0.39)^§^ | NR, <0.01
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | MMSE (0–30) | IG1 | 3 | 21.5^‡^ (0.3)^§^ | 179 | NR | 1.66^ǁ^ (0.17)^§^ | 22.2^‡^ (0.3)^§^ | 174 | NR | 0.29^ǁ^ (0.24)^§^ | NR, <0.001
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | MMSE (0–30) | IG1 | 4 | 21.5^‡^ (0.3)^§^ | 169 | NR | 1.47^ǁ^ (0.23)^§^ | 22.2^‡^ (0.3)^§^ | 166 | NR | 0.62^ǁ^ (0.23)^§^ | NR, <0.05
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | 21.5^‡^ (0.3)^§^ | 203 | NR | 1.38^ǁ^ (0.23)^§^ | 22.2^‡^ (0.3)^§^ | 188 | NR | 0.23^ǁ^ (0.24)^§^ | NR, <0.001
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | MMSE (0–30) | IG2 | 3 | 21.8^‡^ (0.3)^§^ | 185 | NR | 1.39^ǁ^ (0.23)^§^ | 22.2^‡^ (0.3)^§^ | 174 | NR | 0.29^ǁ^ (0.22)^§^ | NR, <0.001
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | MMSE (0–30) | IG2 | 4 | 21.8^‡^ (0.3)^§^ | 175 | NR | 1.57^ǁ^ (0.21)^§^ | 22.2^‡^ (0.3)^§^ | 166 | NR | 0.62^ǁ^ (0.23)^§^ | NR, <0.01
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | MMSE (0–30) | IG2 | 6 | 21.8^‡^ (0.3)^§^ | 202 | NR | 1.38^ǁ^ (0.22)^§^ | 22.2^‡^ (0.3)^§^ | 188 | NR | 0.23^ǁ^ (0.24)^§^ | NR, <0.001
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | MMSE (0–30) | IG1 | 3 | 19.37 (4.37) | 127 | NR | 0.69^ǁ^ (0.27)^§^ | 12.26 (4.54) | 128 | NR | −0.12^ǁ^ (0.29)^§^ | NR, 0.053
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | 19.37 (4.37) | 121 | NR | 0.43^ǁ^ (0.34)^§^ | 12.26 (4.54) | 120 | NR | −1.05^ǁ^ (0.30)^§^ | NR, <0.001
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | MMSE (0–30) | IG1 | 8 | 19.37 (4.37) | 104 | NR | 0.02^ǁ^ (0.40)^§^ | 12.26 (4.54) | 105 | NR | −1.12^ǁ^ (0.39)^§^ | NR, 0.019
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | MMSE (0–30) | IG1 | 12 | 19.37 (4.37) | 135 | NR | −0.49^ǁ^ (0.34)^§^ | 12.26 (4.54) | 137 | NR | −2.19^ǁ^ (0.25)^§^ | NR, <0.001
Galantamine | Auchus, 2007^204^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 22.9 (9.5) | 388 | NR | −1.7 (6.0) | 22.5 (9.5) | 379 | NR | −0.3 (6.4) | NR, 0.001
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 27.3 (0.55)^§^ | 296 | NR | −2.5 (0.30)^§^ | 26.1 (0.54)^§^ | 296 | NR | 0.2 (0.31)^§^ | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 27.3 (0.55)^§^ | 296 | NR | −1.6 (0.36)^§^ | 26.1 (0.54)^§^ | 296 | NR | 1.2 (0.33)^§^ | MDC (95% CI)= NR, (−3.70, −1.86), <0.01
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | 26.3 (0.54)^§^ | 290 | NR | −2.0 (0.31)^§^ | 26.1 (0.54)^§^ | 296 | NR | 0.2 (0.31)^§^ | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 26.3 (0.54)^§^ | 291 | NR | −1.3 (0.31)^§^ | 26.1 (0.54)^§^ | 296 | NR | 1.2 (0.33)^§^ | MDC (95% CI)= NR, (−3.34, −1.49), <0.001
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 22.3 (8.8) | 290 | NR | −1.7 (0.4)^§^ | 24.1 (9.9) | 162 | NR | 1.0 (0.5)^§^ | MDC=−2.7, <0.0001
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 (AD) | 6 | NR | 152 | NR | −1.0 (0.46)^§^ | NR | 87 | NR | 1.8 (0.60)^§^ | MDC (95% CI)=−2.7 (−4.16, −1.17), 0.0005
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 (VaD ) | 6 | NR | 121 | NR | −2.4 (0.59)^§^ | NR | 67 | NR | −0.4 (0.78)^§^ | MDC (95% CI)=−1.9 (−3.88, 0.08), 0.06
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG1 | 6 | NA | 290 | 102 (35.2)^††^ | NR | NA | 162 | 36 (22.2)^††^ | NR | NR, 0.005
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | ADAS-Cog 13 (0–85) | IG1 | 6 | NR | 290 | NR | −2.4 (0.4)^§^ | NR | 162 | NR | 0.9 (0.6)^§^ | MDC=−3.2, <0.0001
Galantamine | Hager, 2014^*^,^208^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 19.0 (4.12) | 873 | NR | 0.15 (2.73) | 19.0 (4.04) | 888 | NR | −0.28 (2.94) | NR, <0.001
Galantamine | Hager, 2014^*^,^208^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 19.0 (4.12) | 874 | NR | −0.51 (0.11)^§^ | 19.0 (4.04) | 891 | NR | −1.09 (0.12)^§^ | NR, <0.05
Galantamine | Hager, 2014^*^,^208^; Fair | Dem | MMSE (0–30) | IG1 | 18 | 19.0 (4.12) | 874 | NR | −1.07 (0.13)^§^ | 19.0 (4.04) | 891 | NR | −1.74 (0.13)^§^ | NR, <0.05
Galantamine | Hager, 2014^*^,^208^; Fair | Dem | MMSE (0–30) | IG1 | 24 | 19.0 (4.12) | 874 | NR | −1.41 (0.12)^§^ | 19.0 (4.04) | 891 | NR | −2.14 (0.13)^§^ | NR, <0.001
Galantamine | Raskind, 2000^208^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 24.8 (0.7)^§^ | 202 | NR | 1.9 (0.36)^§^ | 25.7 (0.8)^§^ | 207 | NR | 2.0 (0.45)^§^ | NR, <0.001
Galantamine | Raskind, 2000^208^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 25.8 (0.8)^§^ | 197 | NR | −1.4 (0.44)^§^ | 25.7 (0.8)^§^ | 207 | NR | 2.0 (0.45)^§^ | NR, <0.001
Galantamine | Rockwood, 2001^210^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 25.6 (0.65)^§^ | 239 | NR | −1.1 (0.33)^§^ | 24.7 (0.85)^§^ | 120 | NR | 0.6 (0.45)^§^ | NR, <0.01
Galantamine | Rockwood, 2001^210^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | NA | 239 | 72 (30.1) | NR | NA | 120 | 27 (22.5) | NR | NS
Galantamine | Rockwood, 2006^209^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 24.2 (6.4) | 62 | NR | −1.64 (−2.94, −0.27)^¶^ | 27.9 (8.4) | 65 | NR | 0.29 (−1.02, 1.65)^¶^ | NR, 0.04
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 5 | 29.0 (0.7)^§^ | 253 | NR | −1.4 (0.39)^§^ | 29.4 (0.6)^§^ | 255 | NR | 1.7 (0.39)^§^ | NR, <0.001
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG1 | 5 | NA | 211 | 78 (37.0)^††^ | NR | NA | 225 | 44 (19.6)^††^ | NR | NR, <0.001
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG1 | 5 | NA | 211 | 56 (26.5)^‡‡^ | NR | NA | 225 | 19 (8.4)^‡‡^ | NR | NR, <0.01
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 5 | 29.4 (0.7)^§^ | 253 | NR | −1.4 (0.35)^§^ | 29.4 (0.6)^§^ | 255 | NR | 1.7 (0.39)^§^ | NR, <0.001
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG2 | 5 | NA | 253 | 40 (15.8)^††^ | NR | NA | 255 | 19 (7.4)^††^ | NR | NR, <0.01
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG2 | 5 | NA | 208 | 74 (35.6)^‡‡^ | NR | NA | 225 | 44 (19.6)^‡‡^ | NR | NR, <0.001
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG3 | 5 | 27.8 (0.9)^§^ | 126 | NR | 0.4 (0.52)^§^ | 29.4 (0.6)^§^ | 255 | NR | 1.7 (0.39)^§^ | NS
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 25.4 (9.4) | 220 | NR | −0.5 (0.38)^§^ | 24.7 (9.3) | 215 | NR | 2.4 (0.41)^§^ | MDC (95% CI)=−2.9 (−4.1, −1.6), <0.001
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG1 | 6 | NA | 220 | 138 (62.7)^**^ | NR | NA | 215 | 88 (40.9)^**^ | NR | PD (95% CI)=21.5 (12.0, 31.0), <0.001
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG1 | 6 | NA | 220 | 64 (29.1)^††^ | NR | NA | 215 | 32 (14.9)^††^ | NR | PD (95% CI)=14.0 (6.0, 22.0), <0.001
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 26.2 (10.4) | 217 | NR | −0.8 (0.43)^§^ | 24.7 (9.3) | 215 | NR | 2.4 (0.41)^§^ | MDC (95% CI)=−3.1 (−4.4, −1.9), <0.001
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG2 | 6 | NA | 217 | 130 (59.9)^**^ | NR | NA | 215 | 88 (40.9)^**^ | NR | PD (95% CI)=19.5 (10.0, 29.0), <0.001
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG2 | 6 | NA | 217 | 70 (32.2)^††^ | NR | NA | 215 | 32 (14.9)^††^ | NR | PD (95% CI)=17.0 (9.0, 25.0), <0.001
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 26.7 (1.1)^§^ | 55 | NR | −1.4 (0.9)^§^ | 26.9 (1.0)^§^ | 82 | NR | 1.6 (0.7)^§^ | MDC=NR, <0.01
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | 25.7 (1.1)^§^ | 51 | NR | −0.7 (0.7)^§^ | 26.9 (1.0)^§^ | 82 | NR | 1.6 (0.7)^§^ | MDC=NR, 0.08
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG3 | 3 | 26.0 (0.9)^§^ | 81 | NR | −0.1 (0.7)^§^ | 26.9 (1.0)^§^ | 82 | NR | 1.6 (0.7)^§^ | MDC=NR, NS
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | MMSE (0–30) | IG1 | 3 | NR | 103 | NR | 0.3 (3.1) | NR | 117 | NR | −0.0 (2.6) | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | MMSE (0–30) | IG2 | 3 | NR | 111 | NR | 0.0 (3.3) | NR | 117 | NR | −0.0 (2.6) | NR
Rivastigmine | Ballard, 2008^215^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 23.0 (9.9) | 360 | NR | −0.7 (0.38)^§^ | 23.7 (9.8) | 338 | NR | 0.4 (0.38)^§^ | MDC=−1.0, 0.029
Rivastigmine | Ballard, 2008^215^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 19.2 (4.1) | 360 | NR | 0.4 (0.38)^§^ | 19.2 (3.9) | 338 | NR | −0.2 (0.18)^§^ | MDC=0.6, 0.007
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 22.3 (NR) | 169 | NR | −1.0 (NR) | 21.7 (NR) | 216 | NR | 2.3 (NR) | NR, <0.001
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 22.3 (NR) | 157 | NR | −0.6 (NR) | 21.7 (NR) | 201 | NR | 3.5 (NR) | NR, <0.001
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 22.3 (NR) | 231 | NR | −0.31 (−1.08, 0.49)^¶^ | 21.7 (NR) | 234 | NR | 4.09 (3.32, 4.86)^¶^ | MDC=−4.40, <0.001
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG1 | 6 | NA | 145 | 81 (55.9)^**^ | NR | NA | 192 | 52 (27.1)^**^ | NR | NS
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | 22.4 (NR) | 223 | NR | 1.4 (NR) | 21.7 (NR) | 216 | NR | 2.3 (NR) | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 4 | 22.4 (NR) | 208 | NR | 1.8 (NR) | 21.7 (NR) | 201 | NR | 3.5 (NR) | NR, <0.05
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 22.4 (NR) | 233 | NR | 2.36 (1.59, 3.13)^¶^ | 21.7 (NR) | 234 | NR | 4.09 (3.32, 4.86)^¶^ | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | 19.62 (NR) | 145 | NR | 0.30 (NR) | 20.00 (NR) | 192 | NR | −0.79 (NR) | NR, <0.05
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | MMSE (0–30) | IG2 | 6 | 19.5 (NR) | 194 | NR | −0.34 (NR) | 20.0 (NR) | 192 | NR | −0.79 (NR) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 28.1 (12.5) | 227 | NR | −0.2 (7.3) | 28.5 (12.3) | 220 | NR | 2.8 (7.2) | MDC=−2.9, <0.001
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADAS-Cog 11 (D) | IG1 | 3 | NA | 227 | 68 (30.0)^††^ | NR | NA | 220 | 36 (16.4)^††^ | NR | NR, ≤0.001
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADAS-Cog 11 (D) | IG1 | 4 | NA | 227 | 75 (33.0)^††^ | NR | NA | 220 | 28 (12.7)^††^ | NR | NR, ≤0.001
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADAS-Cog 11 (D) | IG1 | 6 | NA | 227 | 52 (22.9)^††^ | NR | NA | 220 | 28 (12.7)^††^ | NR | NR, <0.05
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 27.7 (12.3) | 228 | NR | 1.2 (7.2) | 28.5 (12.3) | 220 | NR | 2.8 (7.2) | MDC=−1.6, 0.019
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADAS-Cog 11 (D) | IG2 | 3 | NA | 228 | 53 (23.2)^††^ | NR | NA | 220 | 36 (16.4)^††^ | NR | NR, <0.05
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADAS-Cog 11 (D) | IG2 | 4 | NA | 228 | 57 (25.0)^††^ | NR | NA | 220 | 28 (12.7)^††^ | NR | NR, ≤0.001
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADAS-Cog 11 (D) | IG2 | 6 | NA | 228 | 41 (18.0)^††^ | NR | NA | 220 | 28 (12.7)^††^ | NR | NS
Rivastigmine | Feldman, 2007^217^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 18.1 (4.7) | 277 | NR | 0.3 (3.6) | 18.6 (4.7) | 220 | NR | −1.4 (3.6) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Dem | MMSE (0–30) | IG2 | 6 | 18.8 (4.7) | 228 | NR | −0.6 (3.6) | 18.6 (4.7) | 220 | NR | −1.4 (3.6) | NR
Rivastigmine | McKeith, 2000^218^; Fair-Good | Dem | MMSE (0–30) | IG1 | 5 | 17.9 (4.7) | 41 | NR | 1.5 (NR) | 17.8 (4.4) | 51 | NR | −0.1 (NR) | NR, 0.072
Rivastigmine | Mok, 2007^219^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 13.0 (4.2) | 20 | 13.6 (5.8) | NR | 13.6 (6.0) | 19 | 13.5 (6.8) | NR | NR, 0.563
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | NR | 191 | NR | −1.85 (NR) | NR | 226 | NR | −0.08 (NR) | NR, <0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | NR | 179 | NR | −0.90 (NR) | NR | 218 | NR | 1.21 (NR) | NR, <0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | NR | 199 | NR | −0.83 (−1.79, 0.19)^¶^ | NR | 225 | NR | 1.45 (0.47, 2.33)^¶^ | NR, <0.001
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG1 | 6 | NA | 199 | 53 (26.6)^††^ | NR | NA | 225 | 40 (17.8)^††^ | NR | NR, <0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 3 | NR | 226 | NR | 0.13 (NR) | NR | 226 | NR | −0.08 (NR) | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 4 | NR | 219 | NR | 0.60 (NR) | NR | 218 | NR | 1.21 (NR) | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | NR | 226 | NR | 1.24 (0.37, 2.23)^¶^ | NR | 225 | NR | 1.45 (0.47, 2.33)^¶^ | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADAS-Cog 11 (D) | IG2 | 6 | NA | 226 | 36 (15.9)^††^ | NR | NA | 225 | 40 (17.8)^††^ | NR | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | NR | 199 | NR | 0.34 (−0.25, 0.85) | NR | 225 | NR | −0.54 (−0.99, −0.01)^¶^ | NR, <0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | MMSE (0–30) | IG2 | 6 | NR | 225 | NR | −0.60 (−1.08, −0.12)^¶^ | NR | 223 | NR | −0.54 (−0.99, −0.01)^¶^ | NR, NR
Rivastigmine | Winblad, 2007^221^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 27.9 (9.4) | 253 | NR | −0.6 (6.2) | 28.6 (9.9) | 281 | NR | 1.0 (6.8) | NR, 0.003
Rivastigmine | Winblad, 2007^221^; Fair | Dem | ADAS-Cog 11 (0–70) | IG2 | 6 | 27.4 (9.7) | 262 | NR | −1.6 (6.5) | 28.6 (9.9) | 281 | NR | 1.0 (6.8) | NR, <0.001
Rivastigmine | Winblad, 2007^221^; Fair | Dem | ADAS-Cog 11 (0–70) | IG3 | 6 | 27.0 (10.3) | 248 | NR | −0.6 (6.4) | 28.6 (9.9) | 281 | NR | 1.0 (6.8) | NR, 0.005
Rivastigmine | Winblad, 2007^221^; Fair | Dem | MMSE (0–30) | IG1 | 6 | 16.4 (3.0) | 256 | NR | 0.8 (3.2) | 16.4 (3.0) | 281 | NR | 0.0 (3.5) | NR, 0.002
Rivastigmine | Winblad, 2007^221^; Fair | Dem | MMSE (0–30) | IG2 | 6 | 16.6 (2.9) | 262 | NR | 0.9 (3.4) | 16.4 (3.0) | 281 | NR | 0.0 (3.5) | NR, <0.001
Rivastigmine | Winblad, 2007^221^; Fair | Dem | MMSE (0–30) | IG3 | 6 | 16.7 (3.0) | 250 | NR | 1.1 (3.3) | 16.4 (3.0) | 281 | NR | 0.0 (3.5) | NR, 0.002
Memantine | Bakchine, 2008^222^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 25.9 (10.4) | 268 | NR | −2.46 (NR) | 24.9 (9.7) | 135 | NR | −0.70 (NR) | MDC (95% CI)=−1.76 (−2.69, −0.83), 0.000
Memantine | Bakchine, 2008^222^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 25.9 (10.4) | 266 | NR | −2.26 (NR) | 24.9 (9.7) | 135 | NR | −0.98 (NR) | MDC (95% CI)=−1.29 (−2.33, −0.25), 0.016
Memantine | Bakchine, 2008^222^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 25.9 (10.4) | 268 | NR | −1.93 (NR) | 24.9 (9.7) | 135 | NR | −1.08 (NR) | MDC (95% CI)=−0.85 (−2.02, 0.32), 0.156
Memantine | Choi, 2011^*^,^223^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 29.1 (8.6) | 84 | NR | −0.7 (6.6) | 27.7 (9.8) | 74 | NR | −0.04 (7.1) | NR, 0.83
Memantine | Choi, 2011^*^,^223^; Fair | Dem | MMSE (0–30) | IG1 | 4 | 16.9 (4.3) | 84 | NR | −0.3 (2.9) | 16.7 (4.7) | 74 | NR | 0.1 (2.8) | NR, 0.49
Memantine | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 19.5 (7.9) | 131 | NR | 1.06^ǁ^ (−0.10, 2.32)^¶^ | 19.1 (8.1) | 128 | NR | 3.04^ǁ^ (1.81, 4.28)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 19.5 (7.9) | 116 | NR | 3.27^ǁ^ (1.91, 4.72)^¶^ | 19.1 (8.1) | 106 | NR | 4.24^ǁ^ (2.81, 5.70)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 18 | 19.5 (7.9) | 84 | NR | 5.63^ǁ^ (3.90, 7.48)^¶^ | 19.1 (8.1) | 88 | NR | 6.04^ǁ^ (4.25, 7.86)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 24 | 19.5 (7.9) | 76 | NR | 6.69^ǁ^ (4.53, 8.91)^¶^ | 19.1 (8.1) | 69 | NR | 6.70^ǁ^ (4.43, 8.97)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 30 | 19.5 (7.9) | 51 | NR | 7.61^ǁ^ (5.00, 10.28)^¶^ | 19.1 (8.1) | 48 | NR | 8.91^ǁ^ (6.20, 11.62)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 36 | 19.5 (7.9) | 36 | NR | 8.29^ǁ^ (5.20, 11.45)^¶^ | 19.1 (8.1) | 35 | NR | 10.76^ǁ^ (7.58, 13.96)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 42 | 19.5 (7.9) | 27 | NR | 8.21^ǁ^ (5.02, 11.46)^¶^ | 19.1 (8.1) | 25 | NR | 10.60^ǁ^ (7.30, 13.92)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 48 | 19.5 (7.9) | 142 | NR | 6.38^ǁ^ (0.70)^§^ | 19.1 (8.1) | 140 | NR | 7.78^ǁ^ (0.70)^§^ | MDC (95% CI)=−1.39 (−2.85, 0.07), 0.25
Memantine | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG1 | 6 | 20.8 (3.8) | 131 | NR | −0.25^ǁ^ (−0.79, 0.31)^¶^ | 20.8 (3.8) | 128 | NR | −0.33^ǁ^ (−0.90, 0.22)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG1 | 12 | 20.8 (3.8) | 115 | NR | −1.10^ǁ^ (−1.76, −0.42)^¶^ | 20.8 (3.8) | 106 | NR | −1.39^ǁ^ (−2.08, −0.69)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG1 | 18 | 20.8 (3.8) | 85 | NR | −2.64^ǁ^ (−3.50, −1.73)^¶^ | 20.8 (3.8) | 88 | NR | −2.21^ǁ^ (−3.09, −1.31)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG1 | 24 | 20.8 (3.8) | 75 | NR | −3.46^ǁ^ (−4.50, −2.38)^¶^ | 20.8 (3.8) | 70 | NR | −2.90^ǁ^ (−3.99, −1.80)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG1 | 30 | 20.8 (3.8) | 52 | NR | −3.80^ǁ^ (−5.01, −2.56)^¶^ | 20.8 (3.8) | 47 | NR | −3.27^ǁ^ (−4.53, −2.00)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG1 | 36 | 20.8 (3.8) | 36 | NR | −4.27^ǁ^ (−5.79, −2.72)^¶^ | 20.8 (3.8) | 36 | NR | −3.88^ǁ^ (−5.42, −2.31)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG1 | 42 | 20.8 (3.8) | 27 | NR | −4.62^ǁ^ (−6.17, −3.01)^¶^ | 20.8 (3.8) | 26 | NR | −4.68^ǁ^ (−6.29, −3.05)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | MMSE (0–30) | IG1 | 48 | 20.8 (3.8) | 140 | NR | −3.05^ǁ^ (0.33)^§^ | 20.8 (3.8) | 137 | NR | −3.16^ǁ^ (0.33)^§^ | MDC (95% CI)=0.12 (−0.61, 0.84), 0.84
Memantine | Herrmann, 2013^*^,^226^; Fair | Dem | SIB (0–133) | IG1 | 6 | 82.25 (1.16)^§^ | 159 | NR | −2.34 (0.76)^§^ | 81.98 (1.00)^§^ | 165 | NR | −1.86 (0.75)^§^ | MDC (95% CI)=−0.48 (−2.30, 1.34), 0.60
Memantine | Orgogozo, 2002^227^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 20.6 (9.55) | 147 | NR | 0.48 (0.49) | 21.5 (8.71) | 141 | NR | −0.34 (0.30) | NR
Memantine | Orgogozo, 2002^227^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 20.6 (9.55) | 147 | NR | −0.4 (NR) | 21.5 (8.71) | 141 | NR | 1.6 (NR) | MDC (95% CI)=−2.0 (−3.60, −0.49), 0.0016
Memantine | Orgogozo, 2002^227^; Fair-Good | Dem | MMSE (0–30) | IG1 | 6 | NR | 105 | NR | 1.75 (3.38) | NR | 108 | NR | 0.52 (4.07) | NR, 0.0121
Memantine | Peskind, 2006^228^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 3 | 27.2 (11.01) | 177 | NR | −1.20^ǁ^ (0.48)^§^ | 27.3 (9.74) | 177 | NR | −0.10^ǁ^ (0.48)^§^ | NR, <0.05
Memantine | Peskind, 2006^228^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 27.2 (11.01) | 163 | NR | −1.10^ǁ^ (0.56)^§^ | 27.3 (9.74) | 172 | NR | 0.40^ǁ^ (0.56)^§^ | NR, <0.05
Memantine | Peskind, 2006^228^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 27.2 (11.01) | 196 | NR | −0.93^ǁ^ (5.46) | 27.3 (9.74) | 198 | NR | 0.44^ǁ^ (5.49) | LSM Change (95% CI)=−1.37 (−2.3, −0.48), 0.003
Memantine | Peters, 2015^*^,^229^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 4 | 20.2 (7.0)^§^ | 91 | NR | −1.12 (0.57) | 18.9 (6.6)^§^ | 93 | NR | −0.29 (0.57) | NS
Memantine | Peters, 2015^*^,^229^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 20.2 (7.0)^§^ | 90 | NR | −0.29 (0.72) | 18.9 (6.6)^§^ | 85 | NR | 0.11 (0.71) | NS
Memantine | Peters, 2015^*^,^229^; Fair | Dem | ADAS-Cog 11 (0–70) | IG1 | 12 | 20.2 (7.0)^§^ | 94 | NR | 2.00 (0.86) | 18.9 (6.6)^§^ | 96 | NR | 1.74 (0.85) | NR, 0.831
Memantine | Porsteinsson, 2008^230^; Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | 27.9 (10.98) | 214 | 28.5 (12.83) | NR | 26.8 (9.88) | 213 | 28.0 (11.94) | NR | MDC (95% CI)=−0.7 (−1.8, 0.1), 0.184
Memantine | Porsteinsson, 2008^230^; Good | Dem | MMSE (0–30) | IG1 | 6 | 16.7 (3.68) | 210 | 16.5 (5.38) | NR | 17.0 (3.63) | 198 | 16.4 (5.08) | NR | MDC (95% CI)=0.5 (−0.1, 1.1), 0.123
Memantine | Wilcock, 2002^232^; Fair-Good | Dem | ADAS-Cog 11 (0–70) | IG1 | 6 | NR | 266 | NR | −0.53 (7.02) | NR | 261 | NR | −2.28 (7.77) | MDC (95% CI)=−1.75 (−3.023, −0.49), 0.0005
Memantine | Wilkinson, 2012^233^; Fair | Dem | MMSE (0–30) | IG1 | 12 | 16.7 (2.4) | 103 | NR | −0.43 (0.49)^§^ | 17.1 (2.4) | 114 | NR | −0.74 (0.48)^§^ | MDC (SE) : 0.24 (0.46), NS

* New study

† Higher scores indicate better outcomes for all instruments except for ADAS-Cog 11 and ADAS-Cog 13 where lower scores indicate better outcomes

‡ Least squares mean

§ Standard error

ǁ Least squares mean change

¶ 95% confidence interval

# Range

** N (%) of participants improving by ≥0 points

†† N (%) of participants improving by ≥4 points

‡‡ N (%) of participants improving by ≥7 points

Abbreviations: AD = Alzheimer’s disease; ADAS-Cog 11 = Alzheimer’s Disease Assessment Scale-cognitive subscale; 11-item; ADAS-Cog 13 = Alzheimer’s Disease Assessment Scale-cognitive subscale; 13-item; Adj MD = adjusted mean difference; BL = baseline; CG = control group; CI = confidence interval; D = results are dichotomized; Dem = dementia; FU = followup; IG = intervention group; Int arm = intervention arm; LSM = least squares mean; MCI = mild cognitive impairment; MDC = mean difference in change; MDRS = Mattis Dementia Rating Scale; MMSE = Mini-Mental State Examination; mo. = months; PD = proportion difference; Pop cat = population category; NR = not reported; NS = Not statistically significant; SD = standard deviation; VaD = vascular dementia

Appendix E Table 2 AChEIs and Memantine: Detailed Results for Global Function Dichotomous Outcomes, by Medication Type

Medication | Author, year Quality | Pop cat | Outcome | Instrument^*^ | Int arm | Time, mo. | IG n at FU | IG FU n (%) | CG n at FU | CG FU n (%) | Between group difference, p-value
Donepezil | Black, 2003^186^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 195 | 140 (71.8) | 194 | 134 (69.1) | NR
Donepezil | Black, 2003^186^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 6 | 196 | 152 (77.6) | 194 | 134 (69.1) | NR
Donepezil | Burns, 1999^187^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 273 | 172 (63.0) | 274 | 134 (48.9) | NR
Donepezil | Burns, 1999^187^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 6 | 211 | 154 (73.0) | 274 | 134 (48.9) | NR
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 140 | 88 (62.8) | 146 | 61 (41.8) | NR, <0.0001
Donepezil | Mohs, 2001^194^; Fair | Dem | Number (%) of participants without clinically evident functional decline (CDR/ADL/IADL) | CDR/ADL/IADL (0–365) | IG1 | 12 | 207 | 123 (59.4) | 208 | 92 (44.2) | NR
Donepezil | Mori, 2012^195^; Fair | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 3 | 28 | 27 (96.4) | 30 | 15 (50.0) | NR
Donepezil | Mori, 2012^195^; Fair | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 3 | 31 | 26 (83.9) | 30 | 15 (50.0) | NR
Donepezil | Mori, 2012^195^; Fair | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG3 | 3 | 32 | 30 (93.8) | 30 | 15 (50.0) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 3 | 38 | 34 (89.5) | 40 | 32 (80.0) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 3 | 40 | 33 (82.5) | 40 | 32 (80.0) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG3 | 3 | 41 | 34 (82.9) | 40 | 32 (80.0) | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG1 | 3 | 152 | 58 (38.2) | 150 | 27 (18.0) | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG2 | 3 | 153 | 49 (32.0) | 150 | 27 (18.0) | NR
Donepezil | Salloway, 2004^199^; Fair-Good | MCI | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CGIC-MCI (1–7) | IG1 | 6 | 89 | 75 (84.3) | 110 | 93 (84.5) | NS
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG1 | 6 | 202 | 65 (32.2) | 188 | 47 (25.0) | NR, 0.047
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG2 | 6 | 202 | 79 (39.1) | 188 | 47 (25.0) | NR, 0.004
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | Number (%) of participants improved from baseline (GBS) | GBS (0–162) | IG1 | 3 | 129 | 52 (40.3) | 129 | 40 (31.0) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | Number (%) of participants improved from baseline (GBS) | GBS (0–162) | IG1 | 6 | 122 | 47 (38.5) | 121 | 39 (32.2) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | Number (%) of participants improved from baseline (GBS) | GBS (0–162) | IG1 | 12 | 93 | 29 (31.2) | 97 | 21 (21.6) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | Number (%) of participants improved from baseline (GDS) | GDS (1–7) | IG1 | 3 | 128 | 13 (10.2) | 130 | 8 (6.2) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | Number (%) of participants improved from baseline (GDS) | GDS (1–7) | IG1 | 6 | 122 | 14 (11.5) | 121 | 8 (6.6) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | Number (%) of participants improved from baseline (GDS) | GDS (1–7) | IG1 | 8 | 105 | 15 (14.3) | 105 | 7 (6.7) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | Number (%) of participants improved from baseline (GDS) | GDS (1–7) | IG1 | 12 | 93 | 13 (14.0) | 98 | 5 (5.1) | NR, 0.047
Galantamine | Auchus, 2007^204^; Fair | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 363 | 274 (75.5) | 371 | 273 (73.6) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 240 | 191 (79.6) | 259 | 173 (66.8) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 6 | 246 | 180 (73.2) | 259 | 173 (66.8) | NR
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 288 | 213 (74.0) | 161 | 95 (59.0) | PD=0.15, 0.001
Galantamine | Raskind, 2000^208^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 186 | 136 (73.1) | 196 | 111 (56.6) | NR
Galantamine | Raskind, 2000^208^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 6 | 171 | 118 (69.0) | 196 | 111 (56.6) | NR
Galantamine | Rockwood, 2001^210^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 3 | 240 | 194 (80.8) | 123 | 77 (62.6) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 5 | 253 | 162 (64.0) | 261 | 128 (49.0) | NR, <0.001
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 5 | 256 | 169 (66.0) | 261 | 128 (49.0) | NR, <0.001
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG3 | 5 | 128 | 68 (53.1) | 261 | 128 (49.0) | NR
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 206 | 127 (61.7) | 203 | 101 (49.8) | NR, <0.05
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 6 | 198 | 130 (65.7) | 203 | 101 (49.8) | NR, <0.001
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–5) | IG1 | 3 | 53 | 44 (83.0) | 83 | 57 (68.7) | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–5) | IG2 | 3 | 47 | 41 (87.2) | 83 | 57 (68.7) | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–5) | IG3 | 3 | 79 | 67 (84.8) | 83 | 57 (68.7) | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | Number (%) of participants demonstrating moderate or marked improvement (CIBIC+ score ≤2) | CIBIC+ (1–7) | IG1 | 3 | 103 | 44 (42.7) | 117 | 35 (29.9) | NR, 0.05
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | Number (%) of participants demonstrating moderate or marked improvement (CIBIC+ score ≤2) | CIBIC+ (1–7) | IG2 | 3 | 111 | 35 (31.5) | 117 | 35 (29.9) | NS
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 145 | 35 (24.1) | 192 | 31 (16.1) | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 6 | 194 | 49 (25.3) | 192 | 31 (16.1) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG1 | 3 | 220 | 66 (30.0) | 213 | 34 (16.0) | NR, 0.001
Rivastigmine | Feldman, 2007^217^; Fair | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG1 | 4 | 220 | 67 (30.5) | 213 | 40 (18.8) | NR, 0.001
Rivastigmine | Feldman, 2007^217^; Fair | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG1 | 6 | 220 | 67 (30.5) | 213 | 40 (18.8) | NR, <0.05
Rivastigmine | Feldman, 2007^217^; Fair | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG2 | 3 | 215 | 62 (28.8) | 213 | 34 (16.0) | NR, <0.05
Rivastigmine | Feldman, 2007^217^; Fair | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG2 | 4 | 215 | 47 (21.9) | 213 | 40 (18.8) | NS
Rivastigmine | Feldman, 2007^217^; Fair | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG2 | 6 | 215 | 49 (22.8) | 213 | 40 (18.8) | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG1 | 6 | 193 | 78 (40.4) | 220 | 44 (20.0) | NR, <0.001
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | Number (%) of participants demonstrating minimal, moderate, or marked improvement (CIBIC+ score ≤3) | CIBIC+ (1–7) | IG2 | 6 | 224 | 71 (31.7) | 220 | 44 (20.0) | NR, <0.01
Rivastigmine | Winblad, 2007^221^; Fair | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 253 | 188 (74.3) | 278 | 169 (60.8) | NR
Rivastigmine | Winblad, 2007^221^; Fair | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG2 | 6 | 260 | 179 (68.8) | 278 | 169 (60.8) | NR
Rivastigmine | Winblad, 2007^221^; Fair | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG3 | 6 | 248 | 182 (73.4) | 278 | 169 (60.8) | NR
Memantine | Orgogozo, 2002^227^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CGIC (1–7) | IG1 | 6 | 93 | 74 (79.6) | 94 | 66 (70.2) | NR, 0.227
Memantine | Orgogozo, 2002^227^; Fair-Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 6 | 147 | 88 (59.9) | 141 | 74 (52.5) | NR
Memantine | Saxton, 2012^231^; Good | Dem | Number (%) of participants demonstrating no change or marked improvement (CIBIC+ score ≤4) | CIBIC+ (1–7) | IG1 | 3 | 133 | 97 (72.9) | 124 | 78 (62.9) | NR

* Lower scores indicate better outcomes for all instruments

Abbreviations: CDR-SB = Clinical Dementia Rating Scale Sum of Boxes; CG = control group; CGI = Clinical Global Impression scale; CIBIC+ = Clinician’s Interview-Based Impression of Change with caregiver’s input; Dem = dementia; FU = followup; GBS = Gottfries-Brane-Steen scale; GDS = Global Deterioration Scale; IG = intervention group; Int arm = intervention arm; MCI = mild cognitive impairment; mo. = months; PD = proportion difference; Pop cat = population category; n = number of participants analyzed; NR = not reported

Appendix E Table 3 AChEIs and Memantine: Detailed Results for Global Function Continuous Outcomes, by Medication Type

Medication | Author, year Quality | Instrument (range)^*^ | Pop cat | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Donepezil | Black, 2003^186^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 195 | 3.9 (NR) | NR | NA | 194 | 4.0 (NR) | NR | NR
Donepezil | Black, 2003^186^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 196 | 3.8 (NR) | NR | NA | 194 | 4.0 (NR) | NR | NR
Donepezil | Black, 2003^186^; Fair-Good | CDR-SB (0–18) | Dem | IG1 | 6 | 6.1^†^ (0.2)^‡^ | 195 | NR | −0.25^§^ (0.11)^‡^ | 6.1^†^ (0.2)^‡^ | 194 | NR | 0.11^§^ (0.12) | NR, <0.05
Donepezil | Black, 2003^186^; Fair-Good | CDR-SB (0–18) | Dem | IG2 | 6 | 6.4^†^ (0.2)^‡^ | 196 | NR | −0.01^§^ (0.12)^‡^ | 6.1^†^ (0.2) | 194 | NR | 0.11^§^ (0.12)^‡^ | NS
Donepezil | Burns, 1999^187^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 3 | NA | 202 | 3.90 (0.06)^‡^ | NR | NA | 219 | 4.23 (0.06)^‡^ | NR | NR, 0.0001
Donepezil | Burns, 1999^187^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 4 | NA | 202 | 4.00 (0.07)^‡^ | NR | NA | 219 | 4.45 (0.07)^‡^ | NR | NR, <0.0001
Donepezil | Burns, 1999^187^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 273 | 4.12 (0.07)^‡^ | NR | NA | 274 | 4.51 (0.06)^‡^ | NR | NR, 0.0002
Donepezil | Burns, 1999^187^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 3 | NA | 211 | 4.02 (0.07)^‡^ | NR | NA | 219 | 4.23 (0.06)^‡^ | NR | NR, 0.0010
Donepezil | Burns, 1999^187^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 4 | NA | 211 | 4.08 (0.06)^‡^ | NR | NA | 219 | 4.45 (0.07)^‡^ | NR | NR, 0.0326
Donepezil | Burns, 1999^187^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 271 | 4.22 (0.08)^‡^ | NR | NA | 274 | 4.51 (0.06)^‡^ | NR | NR, 0.0072
Donepezil | Burns, 1999^187^; Fair-Good | CDR-SB (0–18) | Dem | IG1 | 3 | NR | 202 | NR | −0.18^§^ (0.08)^‡^ | NR | 219 | NR | 0.15^§^ (0.08)^‡^ | NR, 0.0014
Donepezil | Burns, 1999^187^; Fair-Good | CDR-SB (0–18) | Dem | IG1 | 4 | NR | 202 | NR | −0.17^§^ (0.11)^‡^ | NR | 219 | NR | 0.33^§^ (0.11)^‡^ | NR, 0.0006
Donepezil | Burns, 1999^187^; Fair-Good | CDR-SB (0–18) | Dem | IG1 | 6 | NR | 273 | NR | −0.06^§^ (0.10)^‡^ | NR | 274 | NR | 0.36^§^ (0.10)^‡^ | −0.4, 0.0033
Donepezil | Burns, 1999^187^; Fair-Good | CDR-SB (0–18) | Dem | IG2 | 3 | NR | 211 | NR | −0.17^§^ (0.08)^‡^ | NR | 219 | NR | 0.15^§^ (0.08)^‡^ | NR, 0.0021
Donepezil | Burns, 1999^187^; Fair-Good | CDR-SB (0–18) | Dem | IG2 | 4 | NR | 211 | NR | −0.02^§^ (0.10)^‡^ | NR | 219 | NR | 0.32^§^ (0.11)^‡^ | NR, 0.0154
Donepezil | Burns, 1999^187^; Fair-Good | CDR-SB (0–18) | Dem | IG2 | 6 | NR | 271 | NR | 0.06^§^ (0.10)^‡^ | NR | 274 | NR | 0.36^§^ (0.10)^‡^ | 0.3, 0.0344
Donepezil | Doody, 2009^188^; Fair | CIBIC+ (1–7) | MCI | IG1 | 11 | NA | 379 | 3.9 (0.1)^‡^ | NR | NA | 378 | 3.9 (0.1)^‡^ | NR | NS
Donepezil | Doody, 2009^188^; Fair | CDR-SB (0–18) | MCI | IG1 | 11 | 1.5 (0.9) | 379 | NR | 0.0 (0.1)^‡^ | 1.5 (0.9) | 378 | NR | 0.1 (0.1) | NS
Donepezil | Feldman, 2001^189^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 3 | NA | 127 | 3.58^†^ (0.08)^‡^ | NR | NA | 132 | 4.06^†^ (0.08)^‡^ | NR | NR, <0.0001
Donepezil | Feldman, 2001^189^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 4 | NA | 122 | 3.72^†^ (0.09)^‡^ | NR | NA | 126 | 4.26^†^ (0.10)^‡^ | NR | NR, <0.0001
Donepezil | Feldman, 2001^189^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 140 | 4.04^†^ (0.09)^‡^ | NR | NA | 146 | 4.57^†^ (0.09)^‡^ | NR | MD=−0.54, <0.0001
Donepezil | Mazza, 2006^193^; Fair-Good | CGI Item 2 (1–7) | Dem | IG1 | 6 | 4.5 (0.76) | 25 | NR | −0.9 (−1.2, −0.5)^ǁ^ | 5.05 (0.99) | 26 | NR | 0.15 (−0.02, 0.3)^ǁ^ | MDC (95 CI)%=−1.6 (−2.2, −0.9), <0.001
Donepezil | Mohs, 2001^194^; Fair | CDR/ADL/IADL (0–365) | Dem | IG1 | 12 | NR | 207 | 357^¶^ (NR) | NR | NR | 208 | 208^¶^ (NR) | NR | NR
Donepezil | Mori, 2012^195^; Fair | CIBIC+ (1–7) | Dem | IG1 | 3 | NA | 28 | 3.1 (NR) | NR | NA | 30 | 4.3 (NR) | NR | NR
Donepezil | Mori, 2012^195^; Fair | CIBIC+ (1–7) | Dem | IG2 | 3 | NA | 31 | 3.0 (NR) | NR | NA | 30 | 4.3 (NR) | NR | NR
Donepezil | Mori, 2012^195^; Fair | CIBIC+ (1–7) | Dem | IG3 | 3 | NA | 32 | 3.2 (NR) | NR | NA | 30 | 4.3 (NR) | NR | NR
Donepezil | Petersen, 2005^196^; Fair | CDR-SB (0–18) | MCI | IG1 | 12 | 1.80 (0.8) | NR | NR | 0.25 (0.92) | 1.87 (0.8) | NR | NR | 0.40 (1.28) | NR
Donepezil | Petersen, 2005^196^; Fair | CDR-SB (0–18) | MCI | IG1 | 18 | 1.80 (0.8) | NR | NR | 0.51 (1.18) | 1.87 (0.8) | NR | NR | 0.72 (1.55) | NR
Donepezil | Petersen, 2005^196^; Fair | CDR-SB (0–18) | MCI | IG1 | 24 | 1.80 (0.8) | NR | NR | 0.87 (1.55) | 1.87 (0.8) | NR | NR | 0.97 (1.76) | NR
Donepezil | Petersen, 2005^196^; Fair | CDR-SB (0–18) | MCI | IG1 | 30 | 1.80 (0.8) | NR | NR | 1.19 (1.69) | 1.87 (0.8) | NR | NR | 1.26 (2.15) | NR
Donepezil | Petersen, 2005^196^; Fair | CDR-SB (0–18) | MCI | IG1 | 36 | 1.80 (0.8) | 161 | NR | 1.60 (2.09) | 1.87 (0.8) | 193 | NR | 1.64 (2.55) | NR
Donepezil | Petersen, 2005^196^; Fair | CDR-SB (0–18) | MCI | IG1 | 6 | 1.80 (0.8) | NR | NR | 0.05 (0.66) | 1.87 (0.8) | NR | NR | 0.14 (0.86) | NR
Donepezil | Petersen, 2005^196^; Fair | GDS (1–7) | MCI | IG1 | 12 | 2.66 (0.6) | NR | NR | 0.11 (0.57) | 2.72 (0.6) | NR | NR | 0.15 (0.65) | NR
Donepezil | Petersen, 2005^196^; Fair | GDS (1–7) | MCI | IG1 | 18 | 2.66 (0.6) | NR | NR | 0.19 (0.66) | 2.72 (0.6) | NR | NR | 0.27 (0.73) | NR, <0.05
Donepezil | Petersen, 2005^196^; Fair | GDS (1–7) | MCI | IG1 | 24 | 2.66 (0.6) | NR | NR | 0.32 (0.73) | 2.72 (0.6) | NR | NR | 0.38 (0.81) | NR
Donepezil | Petersen, 2005^196^; Fair | GDS (1–7) | MCI | IG1 | 30 | 2.66 (0.6) | NR | NR | 0.45 (0.78) | 2.72 (0.6) | NR | NR | 0.48 (0.87) | NR
Donepezil | Petersen, 2005^196^; Fair | GDS (1–7) | MCI | IG1 | 36 | 2.66 (0.6) | 161 | NR | 0.59 (0.89) | 2.72 (0.6) | 193 | NR | 0.56 (0.99) | NR
Donepezil | Petersen, 2005^196^; Fair | GDS (1–7) | MCI | IG1 | 6 | 2.66 (0.6) | NR | NR | −0.01 (0.52) | 2.72 (0.6) | NR | NR | 0.07 (0.53) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | CDR-SB (0–18) | Dem | IG1 | 3 | 7.3 (NR) | 38 | NR | 0.11 (−2.0, 3.0)^#^ | 6.7 (NR) | 40 | NR | 0.10 (−2.0, 3.0)^#^ | NS
Donepezil | Rogers, 1996^198^; Fair-Good | CDR-SB (0–18) | Dem | IG2 | 3 | 6.9 (NR) | 40 | NR | 0.23 (−3.0, 6.0)^#^ | 6.7 (NR) | 40 | NR | 0.10 (−2.0, 3.0)^#^ | NS
Donepezil | Rogers, 1996^198^; Fair-Good | CDR-SB (0–18) | Dem | IG3 | 3 | 6.6 (NR) | 41 | NR | 0.18 (−2.0, 5.0)^#^ | 6.7 (NR) | 40 | NR | 0.10 (−2.0, 3.0)^#^ | NS
Donepezil | Rogers, 1998^197^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 3 | NA | 152 | Mean (SE): 3.8 (0.08)^‡^ | NR | NA | 150 | Mean (SE): 4.2 (0.07) | NR | MD (95% CI)=−0.4 (−0.55, −0.13), 0.008
Donepezil | Rogers, 1998^197^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 3 | NA | 153 | 3.9 (0.08)^‡^ | NR | NA | 150 | 4.2 (0.07)^‡^ | NR | MD (95% CI)=−0.3 (−0.50, −0.08), 0.003
Donepezil | Rogers, 1998^197^; Fair-Good | CDR-SB (0–18) | Dem | IG1 | 3 | 7.18 (0.20)^‡^ | 154 | NR | −0.31^§^ (0.11)^‡^ | 6.81 (0.18)^‡^ | 150 | NR | −0.14^§^ (0.11)^‡^ | MDC (95% CI)=NR (−0.46, 0.12), NS
Donepezil | Rogers, 1998^197^; Fair-Good | CDR-SB (0–18) | Dem | IG2 | 3 | 6.85 (0.18)^‡^ | 156 | NR | −0.10^§^ (0.11)^‡^ | 6.81 (0.18)^‡^ | 150 | NR | 0.14^§^ (0.11)^‡^ | MDC (95% CI)=NR (−0.25, 0.33), 0.32
Donepezil | Wilkinson, 2003^202^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 202 | 3.9 (NR) | NR | NA | 188 | 4.1 (NR) | NR | NR, 0.047
Donepezil | Wilkinson, 2003^202^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 202 | 3.7 (NR) | NR | NA | 188 | 4.1 (NR) | NR | NR, 0.004
Donepezil | Wilkinson, 2003^202^; Fair-Good | CDR-SB (0–18) | Dem | IG1 | 6 | 6.1 (0.2)^‡^ | 203 | NR | −0.21^§^ (0.12)^‡^ | 5.6 (0.2)^‡^ | 188 | NR | 0.16^§^ (0.13)^‡^ | NR, 0.03
Donepezil | Wilkinson, 2003^202^; Fair-Good | CDR-SB (0–18) | Dem | IG2 | 6 | 6.0^†^ (0.2)^‡^ | 202 | NR | −0.15^§^ (0.12)^‡^ | 5.6^†^ (0.2) | 188 | NR | 0.16^§^ (0.13)^‡^ | NR, 0.07
Donepezil | Winblad, 2001^203^; Fair-Good | GBS (0–162) | Dem | IG1 | 12 | 29.51 (17.33) | 138 | NR | 8.05^§^ (1.53)^‡^ | 29.77 (17.84) | 144 | NR | 11.47^§^ (1.48)^‡^ | NR, 0.054
Donepezil | Winblad, 2001^203^; Fair-Good | GBS (0–162) | Dem | IG1 | 3 | 29.51 (17.33) | 129 | NR | 1.56^§^ (1.35)^‡^ | 29.77 (17.84) | 129 | NR | 2.78^§^ (1.03)^‡^ | NS
Donepezil | Winblad, 2001^203^; Fair-Good | GBS (0–162) | Dem | IG1 | 6 | 29.51 (17.33) | 122 | NR | 1.78^§^ (1.30)^‡^ | 29.77 (17.84) | 121 | NR | 4.93^§^ (1.38)^‡^ | NR, 0.046
Donepezil | Winblad, 2001^203^; Fair-Good | GBS (0–162) | Dem | IG1 | 8 | 29.51 (17.33) | 105 | NR | 3.87^§^ (1.86)^‡^ (2.01, 5.43)^ǁ^ | 29.77 (17.84) | 105 | NR | 9.14^§^ (1.88)^‡^ (7.26, 10.99)^ǁ^ | NR, 0.012
Donepezil | Winblad, 2001^203^; Fair-Good | GDS (1–7) | Dem | IG1 | 12 | 4.15 (0.83) | 136 | NR | 0.25^§^ (0.07)^‡^ | 4.16 (0.90) | 140 | NR | 0.44^§^ (0.06)^‡^ | NR, 0.014
Donepezil | Winblad, 2001^203^; Fair-Good | GDS (1–7) | Dem | IG1 | 3 | 4.15 (0.83) | 128 | NR | −0.33 (NR) | 4.16 (0.90) | 130 | NR | −0.30 (NR) | NR, 0.26
Donepezil | Winblad, 2001^203^; Fair-Good | GDS (1–7) | Dem | IG1 | 6 | 4.15 (0.83) | 122 | NR | 0.01^§^ (0.07)^‡^ | 4.16 (0.90) | 121 | NR | 0.17^§^ (0.17)^‡^ | NR, 0.004
Donepezil | Winblad, 2001^203^; Fair-Good | GDS (1–7) | Dem | IG1 | 8 | 4.15 (0.83) | 105 | NR | 0.09^§^ (0.07)^‡^ | 4.16 (0.90) | 105 | NR | 0.37^§^ (0.08)^‡^ | NR, 0.011
Galantamine | Brodaty, 2005^205^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 240 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 246 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | NR
Galantamine | Raskind, 2000^208^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 186 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | NR
Galantamine | Raskind, 2000^208^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 171 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | NR
Galantamine | Rockwood, 2001^208^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 3 | NA | 240 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | NR
Galantamine | Rockwood, 2006^209^; Fair | CIBIC+ (1–7) | Dem | IG1 | 4 | NA | 61 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | 0.03
Galantamine | Wilcock, 2000^212^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 206 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | NR, <0.05
Galantamine | Wilcock, 2000^212^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 198 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | NR, <0.001
Rivastigmine | Ballard, 2008^215^; Fair | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 329 | 4.0 (1.31) | NR | NA | 320 | 4.1 (1.27) | NR | MD=0.1, NS
Rivastigmine | Ballard, 2008^215^; Fair | GDS (1–7) | Dem | IG1 | 6 | 4.0 (0.8) | 365 | NR | −0.1 (0.85) | 4.0 (0.8) | 345 | NR | 0.0 (0.69) | MDC=0.1, NS
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | GDS (1–7) | Dem | IG1 | 6 | 4.0 (NR) | 231 | NR | −0.13 (−0.22, −0.04)^ǁ^ | 3.9 (NR) | 234 | NR | −0.32 (−0.41, −0.23)^ǁ^ | MDC (95% CI): 0.19 (0.06, 0.32), <0.030
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | GDS (1–7) | Dem | IG2 | 6 | 4.0 (NR) | 233 | NR | −0.16 (−0.25, −0.07)^ǁ^ | 3.9 (NR) | 234 | NR | −0.32 (−0.41, −0.23)^ǁ^ | NR
Rivastigmine | Feldman, 2007^217^; Fair | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 222 | 3.9 (1.3) | NR | NR | 216 | 4.5 (1.3) | NR | Cohen’s d=0.46, NR
Rivastigmine | Feldman, 2007^217^; Fair | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 222 | 4.1 (1.3) | NR | NR | 216 | 4.5 (1.3) | NR | Cohen’s d=0.31,
Rivastigmine | Feldman, 2007^217^; Fair | GDS (1–7) | Dem | IG1 | 6 | 4.1 (0.9) | 227 | NR | 0.0 (0.7) | 4.1 (0.9) | 222 | NR | −0.3 (0.7) | NR
Rivastigmine | Feldman, 2007^217^; Fair | GDS (1–7) | Dem | IG2 | 6 | 4.0 (0.9) | 227 | NR | −0.2 (0.7) | 4.1 (0.9) | 222 | NR | −0.3 (0.7) | NR
Rivastigmine | Mok, 2007^219^; Fair | CDR-SB (0–18) | Dem | IG1 | 6 | 8.7 (5.1) | 20 | 9.4 (5.5) | NR | 9.1 (4.6) | 19 | 9.5 (5.4) | NR | NR, 0.787
Rivastigmine | Rosler, 1999^220^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 3 | NA | 191 | 3.88 (NR) | NR | NA | 226 | 3.96 (NR) | NR | NR, <0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 4 | NA | 179 | 3.85 (NR) | NR | NA | 218 | 4.09 (NR) | NR | NR, <0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 193 | 3.88 (NR) | NR | NA | 220 | 4.32 (NR) | NR | NR, <0.001
Rivastigmine | Rosler, 1999^220^; Fair-Good | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 224 | 4.17 (NR) | NR | NA | 220 | 4.32 (NR) | NR | NR, >0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | GDS (1–7) | Dem | IG1 | 6 | NR | 198 | NR | −0.03 (−0.13, 0.13)^ǁ^ | NR | 223 | NR | −0.24 (−0.31, −0.09)^ǁ^ | NR, <0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | GDS (1–7) | Dem | IG2 | 6 | NR | 225 | NR | −0.20 (−0.31, −0.09)^ǁ^ | NR | 223 | NR | −0.24 (−0.31, −0.09)^ǁ^ | NR
Rivastigmine | Winblad, 2007^221^; Fair | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 253 | 3.9 (1.3) | NR | NA | 278 | 4.2 (1.3) | NR | NR, 0.009
Rivastigmine | Winblad, 2007^221^; Fair | CIBIC+ (1–7) | Dem | IG2 | 6 | NA | 260 | 4.0 (1.3) | NR | NA | 278 | 4.2 (1.3) | NR | NR, 0.054
Rivastigmine | Winblad, 2007^221^; Fair | CIBIC+ (1–7) | Dem | IG3 | 6 | NA | 248 | 3.9 (1.2) | NR | NA | 278 | 4.2 (1.3) | NR | NR, 0.01
Memantine | Bakchine, 2008^222^; Good | CIBIC+ (1–7) | Dem | IG1 | 3 | NA | 267 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | MD (95% CI)=−0.21 (−0.40, −0.02), 0.033
Memantine | Bakchine, 2008^222^; Good | CIBIC+ (1–7) | Dem | IG1 | 4 | NA | 268 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | MD (95% CI)=−0.28 (−0.49, −0.06), 0.012
Memantine | Bakchine, 2008^222^; Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 268 | 5.3 (NR) | NR | NA | 259 | 5.1 (NR) | NR | MD (95% CI)=−0.07 (−0.30, 0.15), 0.523
Memantine | Choi, 2011^**^,^223^; Fair | CDR-SB (0–18) | Dem | IG1 | 4 | 5.92 (3.08) | 84 | NR | 0.45 (1.72) | 5.84 (3.51) | 74 | NR | 0.34 (1.55) | NR, 0.71
Memantine | Orgogozo, 2002^227^; Fair-Good | CGIC (1–7) | Dem | IG1 | 6 | NA | 116 | 3.58 (1.09) | NR | NA | 117 | 3.85 (1.19) | NR | NR, 0.0938
Memantine | Orgogozo, 2002^227^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 114 | 3.82 (1.39) | NR | NA | 114 | 4.11 (1.48) | NR | NR, 0.284
Memantine | Orgogozo, 2002^227^; Fair-Good | GBS (0–162) | Dem | IG1 | 6 | NR | 114 | NR | −0.36 (15.38) | NA | 118 | NR | 3.38 (16.34) | NR, 0.1194
Memantine | Peskind, 2006^228^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 3 | NA | 178 | 3.99 (0.80) | NR | NA | 179 | 4.18 (0.85) | NR | NR, 0.02
Memantine | Peskind, 2006^228^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 4 | NA | 167 | 4.17 (0.88) | NR | NA | 172 | 4.43 (0.90) | NR | NR, 0.03
Memantine | Peskind, 2006^228^; Fair-Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 195 | 4.20 (0.96) | NR | NA | 198 | 4.52 (1.06) | NR | NR, 0.004
Memantine | Peters, 2015^**^,^229^; Fair | CDR-SB (0–18) | Dem | IG1 | 12 | 5.0 (1.5)^‡^ | 94 | NR | 1.14 (0.25) | 4.8 (1.4)^‡^ | 96 | NR | 1.17 (0.25) | NR, 0.921
Memantine | Peters, 2015^**^,^229^; Fair | CDR-SB (0–18) | Dem | IG1 | 4 | 5.0 (1.5)^‡^ | 94 | NR | 0.092 (0.17) | 4.8 (1.4)^‡^ | 94 | NR | 0.44 (0.26) | NS
Memantine | Peters, 2015^**^,^229^; Fair | CDR-SB (0–18) | Dem | IG1 | 6 | 5.0 (1.5)^‡^ | 87 | NR | 0.32 (0.15) | 4.8 (1.4)^‡^ | 90 | NR | 0.22 (0.14) | NS
Memantine | Peters, 2015^**^,^229^; Fair | CDR-SB (0–18) | Dem | IG1 | 9 | 5.0 (1.5)^‡^ | 86 | NR | 0.40 (0.20) | 4.8 (1.4)^‡^ | 91 | NR | 0.51 (0.19) | NS
Memantine | Porsteinsson, 2008^230^; Good | CIBIC+ (1–7) | Dem | IG1 | 6 | NA | 214 | 4.38 (1.00) | NR | NA | 213 | 4.42 (0.96) | NR | MD (95% CI)=0.0 (−0.2, 0.2), 0.843

* Lower scores indicate better outcomes for all instruments

† Least squares mean

‡ Standard error

§ Least squares mean change

ǁ 95% confidence interval

¶ Median

# Range

** New study

Abbreviations: BL = baseline; CDR-SB = Clinical Dementia Rating Scale Sum of Boxes; CG = control group; CGI = Clinical Global Impression scale; CI = confidence interval; CIBIC+ = Clinician’s Interview-Based Impression of Change with caregiver’s input; Dem = dementia; FU = followup; GBS = Gottfries-Brane-Steen scale; GDS = Global Deterioration Scale; IG = intervention group; Int arm = intervention arm; MCI = mild cognitive impairment; MDC = mean difference in change; mo. = months; Pop cat = population category; NR = not reported; NS = not statistically significant; SD = standard deviation

Appendix E Table 4 AChEIs and Memantine: Detailed Results for Physical Function Outcomes, by Medication Type

Medication | Author, year Quality | Pop cat | ADL or ADL, (Instrument, range, direction) | Int arm | Time, mo. | IG BL mean (SE) | IG n at FU | IG FU mean (SE) | IG mean change (SE or 95% CI) from BL | CG BL mean (SE) | CG n at FU | CG FU mean (SE) | CG mean change (SE or 95% CI) from BL | Between group difference, p-value
Donepezil | Black, 2003^186^; Fair-Good | Dem | ADL/IADL (ADFACS, 0–54, ↓) | IG1 | 6 | 15.3^*^ (0.7) | 180 | NR | 0.53^†^ (0.38) | 15.9^*^ (0.7) | 189 | NR | 1.44^†^ (0.42) | NR
Donepezil | Black, 2003^186^; Fair-Good | Dem | ADL/IADL (ADFACS, 0–54, ↓) | IG2 | 6 | 17.3^*^ (0.8) | 181 | NR | 0.64^†^ (0.36) | 15.9^*^ (0.7) | 180 | NR | 1.44^†^ (0.42) | NR
Donepezil | Black, 2003^186^; Fair-Good | Dem | IADL (ADFACS-IADL, 0–30, ↓) | IG1 | 6 | NR | 189 | NR | 0.13^†^ (0.27) | NR | 180 | NR | 0.87^†^ (0.32) | NR
Donepezil | Black, 2003^186^; Fair-Good | Dem | IADL (ADFACS-IADL, 0–30, ↓) | IG2 | 6 | NR | 181 | NR | −0.02^†^ (0.25) | NR | 180 | NR | 0.87^†^ (0.87) | NR, <0.05
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADL/IADL (IDDD - performance scale, 33–231, ↓) | IG1 | 3 | 69.85 (1.71) | 202 | 67.94 (0.40) | NR | 69.84 (1.68) | 219 | 69.75 (0.74) | NR | NR, 0.0085
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADL/IADL (IDDD - performance scale, 33–231, ↓) | IG1 | 4 | 69.85 (1.71) | 202 | 68.66 (0.40) | NR | 69.84 (1.68) | 219 | 70.93 (0.48) | NR | NR, 0.0033
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADL/IADL (IDDD - performance scale, 33–231, ↓) | IG1 | 6 | 69.85 (1.71) | 273 | 69.30 (0.46) | NR | 69.84 (1.68) | 274 | 71.45 (1.94) | NR | NR, 0.0072
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADL/IADL (IDDD - performance scale, 33–231, ↓) | IG2 | 3 | 67.78 (1.61) | 211 | 68.94 (0.36) | NR | 69.84 (1.68) | 219 | 69.75 (0.74) | NR | NR
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADL/IADL (IDDD - performance scale, 33–231, ↓) | IG2 | 4 | 67.78 (1.61) | 211 | 69.46 (0.40) | NR | 69.84 (1.68) | 219 | 70.93 (0.48) | NR | NR
Donepezil | Burns, 1999^187^; Fair-Good | Dem | ADL/IADL (IDDD - performance scale, 33–231, ↓) | IG2 | 6 | 67.78 (1.61) | 271 | 70.36 (0.45) | NR | 69.84 (1.68) | 274 | 71.45 (1.94) | NR | NR, 0.0072
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 3 | 52.11 (2.07) | 127 | NR | 1.51^†^ (1.28) | 54.07 (2.00) | 132 | NR | −3.16^†^ (1.22) | NR, 0.0037
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 6 | 52.11 (2.07) | 134 | NR | −0.74^†^ (1.31) | 54.07 (2.00) | 140 | NR | −8.98^†^ (1.40) | MDC=8.23, <0.0001
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | IADL (Lawton and Brody IADL, NR, ↑) | IG1 | 6 | 64.34 (2.06) | 144 | NR | NR | 63.88 (1.97) | 146 | NR | NR | MDC=6.83, <0.0001
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | ADL (PSMS, NR, ↑) | IG1 | 6 | 7.90 (0.43) | 144 | NR | NR | 7.63 (0.41) | 146 | NR | NR | MDC=1.32, 0.0015
Donepezil | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG1 | 12 | 46.49 (4.3)^‡^ | NR | NR | −1.41 (4.48)^‡^ | 45.87 (5.2)^‡^ | NR | NR | −1.44 (5.00)^‡^ | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG1 | 18 | 46.49 (4.3)^‡^ | NR | NR | 1.78 (5.02)^‡^ | 45.87 (5.2)^‡^ | NR | NR | −2.34 (6.02)^‡^ | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG1 | 24 | 46.49 (4.3)^‡^ | NR | NR | −3.09 (6.24)^‡^ | 45.87 (5.2)^‡^ | NR | NR | −3.43 (6.73)^‡^ | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG1 | 30 | 46.49 (4.3)^‡^ | NR | −4.44 (7.39)^‡^ | NR | 45.87 (5.2)^‡^ | NR | −5.00 (8.05)^‡^ | NR | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG1 | 36 | 46.49 (4.3)^‡^ | 161 | NR | −6.26 (8.67)^‡^ | 45.87 (5.2)^‡^ | 193 | NR | −6.39 (8.99)^‡^ | NR
Donepezil | Petersen, 2005^196^; Fair | MCI | IADL (ADCS-MCI-ADL, 0–53, ↑) | IG1 | 6 | 46.49 (4.3)^‡^ | NR | NR | −0.21 (3.43)^‡^ | 45.87 (5.2)^‡^ | NR | NR | −1.06 (4.54)^‡^ | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | ADL/IADL (Unified ADL, NR, ↓) | IG1 | 3 | 105.5 (NR) | 38 | NR | −3.1 (−36, 15)^§^ | 92.4 (NR) | 40 | NR | 1.5 (−38, 57)^§^ | NR, NS
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | ADL/IADL (Unified ADL, NR, ↓) | IG2 | 3 | 98.8 (NR) | 40 | NR | 0.6 (−21, 30)^§^ | 92.4 (NR) | 40 | NR | 1.5 (−38, 57)^§^ | NR, NS
Donepezil | Rogers, 1996^198^; Fair-Good | Dem | ADL/IADL (Unified ADL, NR, ↓) | IG3 | 3 | 94.7 (NR) | 41 | NR | 4.0 (−25, 97)^§^ | 92.4 (NR) | 40 | NR | 1.5 (−38, 57)^§^ | NR, NS
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | ADL/IADL (ADFACS, 0–54, ↓) | IG1 | 6 | 16.1^*^ (0.7) | 203 | NR | −0.23^†^ (0.40) | 15.1^*^ (0.7) | 188 | NR | 0.76^†^ (0.39) | NS
Donepezil | Wilkinson, 2003^202^; Fair-Good | Dem | ADL/IADL (ADFACS, 0–54, ↓) | IG2 | 6 | 15.7^*^ (0.7) | 202 | NR | 0.11^†^ (0.45) | 15.1^*^ (0.7) | 188 | NR | 0.76^†^ (0.39) | NS
Donepezil | Winblad, 2001^203^; Fair-Good | Dem | ADL/IADL (ADFACS, 0–54, ↓) | IG1 | 12 | 52.77 (20.58)^‡^ | 93 | NR | −11.19^†^ (NR) | 52.93 (20.45)^‡^ | 97 | NR | −15.25^†^ (NR) | NR, <0.05
Galantamine | Auchus, 2007^204^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 48.3 (17.2)^‡^ | 388 | NR | 0.8 (9.78) | 45.9 (16.8)^‡^ | 379 | NR | 0.2 (9.12) | NR, 0.789
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 3 | 52.0 (0.90) | 279 | NR | 1.1 (0.47) | 54.5 (0.87) | 281 | NR | −0.3 (0.46) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 52.0 (0.90) | 242 | NR | −1.0 (0.05) | 54.5 (0.87) | 258 | NR | −2.7 (0.56) | NR (95% CI)=(0.22, 3.04), 0.018
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 3 | 53.5 (0.88) | 276 | NR | 0.4 (0.48) | 54.5 (0.87) | 281 | NR | −0.3 (0.46) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 6 | 53.5 (0.88) | 245 | NR | 0.0 (0.48) | 54.5 (0.87) | 258 | NR | −2.7 (0.56) | NR (95% CI)=(1.09, 3.91), <0.001
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 6 | NR | 288 | NR | 0.2 (0.9) | NR | 161 | NR | −4.4 (1.3) | MDC=4.6, 0.0017
Galantamine | Hager, 2014^ǁ208^; Fair | Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 12 | 61.8 (21.61)^‡^ | 811 | NR | −4.55 (14.68)^‡^ | 60.9 (21.09)^‡^ | 822 | NR | −6.50 (16.17)^‡^ | NR, 0.009
Galantamine | Hager, 2014^ǁ208^; Fair | Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 24 | 61.8 (21.61)^‡^ | 810 | NR | −8.16 (17.25)^‡^ | 60.9 (21.09)^‡^ | 822 | NR | −10.81 (18.27)^‡^ | NR, 0.002
Galantamine | Rockwood, 2001^210^; Fair-Good | Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 3 | 73.0 (1.91) | 241 | NR | −0.4 (0.76) | 69.1 (1.42) | 123 | NR | −5.2 (1.18) | NR, <0.001
Galantamine | Rockwood, 2006^209^; Fair | Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 4 | 76.4 (19.7)^‡^ | NR | NR | NR | 70.6 (21.4)^‡^ | NR | NR | NR | ES=0.28, 0.13
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 5 | 51.9 (1.0) | 253 | NR | −1.5 (0.6) | 52.3 (0.9) | 262 | NR | −3.8 (0.6) | NR, <0.01
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 5 | 51.6 (0.9) | 255 | NR | −0.7 (0.5) | 52.3 (0.9) | 262 | NR | −3.8 (0.6) | NR, <0.001
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG3 | 5 | 54.2 (1.2) | 129 | NR | −3.2 (0.8) | 52.3 (0.9) | 262 | NR | −3.8 (0.6) | NR
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | ADL/IADL (DAD, 0–100, ↑) | IG1 | 6 | 69.9 (21.4)^‡^ | 212 | NR | −3.2 (1.02) | 66.6 (22.5)^‡^ | 210 | NR | −6.0 (1.08) | MDC (95% CI)=2.8 (−0.6, 6.1), 0.1
Galantamine | Wilcock, 2000^212^; Fair-Good | Dem | ADL/IADL (DAD, 0–100, ↑) | IG2 | 6 | 69.6 (20.6)^‡^ | 214 | NR | −2.5 (1.07) | 66.6 (22.5)^‡^ | 210 | NR | −6.0 (1.08) | MDC (95% CI)=3.4 (0.1, 6.7), <0.05
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | ADL/IADL (PDS, D) | IG1 | 3 | NA | 56 | 50 (89.3)^¶^ | NR | NA | 87 | 65 (74.7)^¶^ | NR | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | ADL/IADL (PDS, D) | IG2 | 3 | NA | 54 | 42 (77.8)^¶^ | NR | NA | 87 | 65 (74.7)^¶^ | NR | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Dem | ADL/IADL (PDS, D) | IG3 | 3 | NA | 88 | 72 (81.8)^¶^ | NR | NA | 87 | 65 (74.7)^¶^ | NR | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | ADL (NOSGER ADL subscale, 1–5, ↓) | IG1 | 3 | NR | 103 | NR | −0.1 (2.1)^‡^ | NR | 117 | NR | 0.1 (2.7)^‡^ | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | ADL (NOSGER ADL subscale, 1–5, ↓) | IG2 | 3 | NR | 111 | NR | 0.2 (2.8)^‡^ | NR | 117 | NR | 0.1 (2.7)^‡^ | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | ADL (NOSGER ADL subscale, 1–5, ↓) | IG1 | 3 | NR | 103 | NR | −0.7 (3.5)^‡^ | NR | 117 | NR | −0.2 (3.3)^‡^ | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Dem | ADL (NOSGER ADL subscale, 1–5, ↓) | IG2 | 3 | NR | 111 | NR | 0.0 (3.3)^‡^ | NR | 117 | NR | −0.2 (3.3)^‡^ | NR
Rivastigmine | Ballard, 2008^215^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 46.7 (17.7)^‡^ | 365 | NR | −0.1 (0.59) | 46.4 (17.2)^‡^ | 345 | NR | −0.7 (0.60) | MDC (95% CI)=0.6, NS
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG1 | 3 | NR | 169 | NR | −0.7 (NR) | NR | 216 | NR | −1.9 (NR) | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG1 | 4 | NR | 157 | NR | −0.6 (NR) | NR | 201 | NR | −4.0 (NR) | NR, <0.05
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG1 | 6 | NR | 231 | NR | −1.52 (−2.85, −0.19) | NR | 234 | NR | −4.90 (−6.22, −3.58) | MDC (95% CI)=3.38 (1.51, 5.25), <0.001
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG2 | 3 | NR | 223 | NR | −3.6 (NR) | NR | 216 | NR | −1.9 (NR) | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG2 | 4 | NR | 208 | NR | −3.4 (NR) | NR | 201 | NR | −4.0 (NR) | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG2 | 6 | NR | 233 | NR | −5.19 (−6.52, −3.86) | NR | 234 | NR | −4.90 (−6.22, −3.58) | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADL/IADL (PDS, D) | IG1 | 6 | NA | 145 | 36 (24.8)^#^ | NR | NA | 192 | 29 (15.1)^#^ | NR | NR, 0.006
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Dem | ADL/IADL (PDS, D) | IG1 | 6 | NA | 194 | NR^#^ | NR | NA | 192 | 29 (15.1)^#^ | NR | NS
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADL/IADL (PDS, 0–100, ↑) | IG1 | 6 | 49.2 (19.8)^‡^ | 225 | NR | −1.5 (11.3)^‡^ | 49.0 (19.6)^‡^ | 221 | NR | −4.9 (11.2)^‡^ | NR
Rivastigmine | Feldman, 2007^217^; Fair | Dem | ADL/IADL (PDS, 0–100, ↑) | IG2 | 6 | 48.7 (19.5)^‡^ | 227 | NR | −2.6 (11.1)^‡^ | 49.0 (19.6)^‡^ | 221 | NR | −4.9 (11.2)^‡^ | NR
Rivastigmine | Mok, 2007^219^; Fair | Dem | IADL (Lawton and Brody IADL, 0–8, ↑) | IG1 | 6 | 2.3 (0.7)^‡^ | 20 | 2.3 (0.5)^‡^ | NR | 2.3 (0.6)^‡^ | 19 | 2.2 (0.8)^‡^ | NR | NR, 0.299
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG1 | 3 | NR | 191 | NR | 0.48 (NR) | NR | 226 | NR | 0.12 (NR) | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG1 | 4 | NR | 179 | NR | 0.08 (NR) | NR | 218 | NR | −0.99 (NR) | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG1 | 6 | NR | 198 | NR | 0.5 (−1.32, 2.52) | NR | 223 | NR | −2.23 (−4.02, −0.38) | NR, <0.05
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG2 | 3 | NR | 226 | NR | −0.90 (NR) | NR | 226 | NR | 0.12 (NR) | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG2 | 4 | NR | 219 | NR | −1.78 (NR) | NR | 218 | NR | −0.99 (NR) | NS
Rivastigmine | Rosler, 1999^220^; Fair-Good | Dem | ADL/IADL (PDS, 0–100, ↑) | IG2 | 6 | NR | 225 | NR | −3.31 (−5.10, −1.50) | NR | 223 | NR | −2.23 (−4.02, −0.38) | NR, >0.05
Rivastigmine | Winblad, 2007^221^; Fair | Dem | ADL/IADL (PDS, D) | IG1 | 6 | NA | 198 | 66 (33.3)^#^ | NR | NA | 223 | 45 (20.2)^#^ | NR | NR, <0.01
Rivastigmine | Winblad, 2007^221^; Fair | Dem | ADL/IADL (PDS, D) | IG2 | 6 | NA | 225 | 45 (20.0)^#^ | NR | NA | 223 | 45 (20.0)^#^ | NR | NR, >0.05
Rivastigmine | Winblad, 2007^221^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 49.3 (15.8)^‡^ | 254 | NR | −0.5 (9.5) | 49.2 (16.0)^‡^ | 281 | NR | −2.3 (9.4)^‡^ | NR, 0.04
Rivastigmine | Winblad, 2007^221^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG2 | 6 | 47.6 (15.7)^‡^ | 263 | NR | 0.0 (11.6) | 49.2 (16.0)^‡^ | 281 | NR | −2.3 (9.4)^‡^ | NR, 0.02
Rivastigmine | Winblad, 2007^221^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG3 | 6 | 50.1 (16.3)^‡^ | 247 | NR | −0.1 (9.1) | 49.2 (16.0)^‡^ | 281 | NR | −2.3 (9.4)^‡^ | NR, 0.01
Memantine | Bakchine, 2008^222^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 3 | NR | 268 | NR | −0.67 (NR) | NR | 135 | NR | −0.19 (NR) | MDC (95% CI)=−0.48 (−1.8, 0.85), 0.480
Memantine | Bakchine, 2008^222^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | NR | 267 | NR | −1.99 (NR) | NR | 134 | NR | −2.08 (NR) | MDC (95% CI)=0.09 (−1.52, 1.70), 0.912
Memantine | Choi, 2011^ǁ223^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 4 | 51.0 (13.8)^‡^ | 84 | NR | −1.4 (7.9) | 52.4 (15.9)^‡^ | 74 | NR | −2.4 (8.5)^‡^ | NR, 0.50
Memantine | Dysken, 2014^ǁ224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 12 | 57.3 (14.2)^‡^ | 119 | NR | −7.08^†^ (−9.39, −4.64) | 56.8 (13.7)^‡^ | 112 | NR | −8.14^†^ (−10.5, −5.73) | NR
Memantine | Dysken, 2014^ǁ224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 18 | 57.3 (14.2)^‡^ | 95 | NR | −9.39^†^ (−12.1, −6.55) | 56.8 (13.7)^‡^ | 96 | NR | −10.2^†^ (−13.0, −7.40) | NR
Memantine | Dysken, 2014^ǁ224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 24 | 57.3 (14.2)^‡^ | 80 | NR | −14.0^†^ (−17.4, −10.7) | 56.8 (13.7)^‡^ | 77 | NR | −16.2^†^ (−19.6, −12.8) | NR
Memantine | Dysken, 2014^ǁ224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 30 | 57.3 (14.2)^‡^ | 64 | NR | −18.4^†^ (−22.1, −14.4) | 56.8 (13.7)^‡^ | 54 | NR | −19.7^†^ (−23.7, −15.6) | NR
Memantine | Dysken, 2014^ǁ224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 36 | 57.3 (14.2)^‡^ | 38 | NR | −18.9^†^ (−23.5, −14.0) | 56.8 (13.7)^‡^ | 33 | NR | −24.8^†^ (−29.7, −19.9) | NR
Memantine | Dysken, 2014^ǁ224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 42 | 57.3 (14.2)^‡^ | 38 | NR | −23.6^†^ (−28.7, −18.3) | 56.8 (13.7)^‡^ | 33 | NR | −28.1^†^ (−33.5, −22.7) | NR
Memantine | Dysken, 2014^ǁ224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 48 | 57.3 (14.2)^‡^ | 142 | NR | −14.98^†^ (1.10) | 56.8 (13.7)^‡^ | 140 | NR | −16.96^†^ (1.11) | MDC (95% CI)=1.98 (−0.24, 4.20), 0.40
Memantine | Dysken, 2014^ǁ224^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 57.3 (14.2)^‡^ | 139 | NR | −2.47^†^ (−4.30, −0.59) | 56.8 (13.7)^‡^ | 135 | NR | −4.54^†^ (−6.42, −2.68) | NR
Memantine | Orgogozo, 2002^227^; Fair-Good | Dem | ADL (NOSGER ADL subscale, 1–5, ↓) | IG1 | 6 | NR | 93 | NR | 0.40 (NR) | NR | 95 | NR | 0.19 (NR) | NR, 0.931
Memantine | Orgogozo, 2002^227^; Fair-Good | Dem | ADL (NOSGER ADL subscale, 1–5, ↓) | IG1 | 6 | NR | 116 | NR | 1.05 (NR) | NR | 118 | NR | 0.34 (NR) | NR, 0.321
Memantine | Peskind, 2006^228^; Fair-Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 57.2 (14.77)^‡^ | 196 | NR | −2.07^†^ (7.14)^‡^ | 56.2 (13.11)^‡^ | 197 | NR | −1.77^†^ (7.18)^‡^ | NR, 0.63
Memantine | Peters, 2015^ǁ229^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 12 | 62.1 (10.5)^‡^ | 94 | NR | −6.83 (1.33)^‡^ | 62.1 (12.9)^‡^ | 96 | NR | −6.16 (1.34)^‡^ | NR, 0.719
Memantine | Peters, 2015^ǁ229^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 4 | 62.1 (10.5)^‡^ | 77 | NR | −0.92 (0.90)^‡^ | 62.1 (12.9)^‡^ | 74 | NR | −1.40 (0.92)^‡^ | NS
Memantine | Peters, 2015^ǁ229^; Fair | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 62.1 (10.5)^‡^ | 72 | NR | −2.53 (1.09)^‡^ | 62.1 (12.9)^‡^ | 77 | NR | −3.38 (1.05)^‡^ | NS
Memantine | Porsteinsson, 2008^230^; Good | Dem | ADL/IADL (ADCS-ADL, 0–78, ↑) | IG1 | 6 | 54.7 (14.44)^‡^ | 214 | 51.8 (15.89)^‡^ | NR | 54.8 (13.08)^‡^ | 213 | 52.0 (15.70)^‡^ | NR | MDC (95% CI)=−0.2 (−1.6, 1.3), 0.816

* Least squares mean

† Least squares mean change

‡ Standard deviation

§ Range

ǁ New study

¶ Number (%) of participants demonstrating no change, improvement, or much improvement on PDS

# Number (%) of participants demonstrating clinically meaningful improvement (≥10% improvement in PDS total score)

Abbreviations: ADL = Activities of Daily Living; ADCS-ADL = Alzheimer’s Disease Cooperative Study Activities of Daily Living 23 items; ADFACS = Alzheimer’s Disease Functional Assessment and Change Scale; BL = baseline; CG = control group; CI = confidence interval; D = dichotomized; DAD = Disability Assessment for Dementia scale; Dem = dementia; ES = effect size; FU = followup; IADL = Instrumental Activities of Daily Living; IDDD = Interview for Deterioration in Daily Living Activities in Dementia; IG = intervention group; Int arm = intervention arm; MCI = mild cognitive impairment; MDC = mean difference in change; mo. = months; PDS = Progressive Deterioration Scale; Pop cat = population category; NA = not applicable; NOSGER = Nurses’ Observation Scale for Geriatric Patients scale; NR = not reported; NS = not statistically significant; PSMS = Physical Self-Maintenance Scale; SE = standard error

Appendix E Table 5 AChEIs and Memantine: Detailed Results for Mental Health and Neuropsychiatric Symptom Outcomes, by Medication Type

Medication | Author, year Quality | Pop cat | Symptom (Instrument, range^†^) | Int arm | Time, mo. | IG BL mean (SD) | IG n at FU | IG FU mean (SD) | IG mean change (SD) from BL | CG BL mean (SD) | CG n at FU | CG FU mean (SD) | CG mean change (SD) from BL | Between group difference, p-value
Donepezil | Doody, 2009^188^; Fair | MCI | NPS (NPI-12, 0–144) | IG1 | 11 | 4.0 (7.3) | 379 | NR | 1.8 (0.5)^‡^ | 3.4 (5.8) | 378 | NR | 3.4 (5.8)^‡^ | NS
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | 19.55 (1.48)^‡^ | 127 | NR | −4.69^§^ (1.22)^‡^ | 19.30 (1.45) | 132 | NR | −3.06^§^ (1.14)^‡^ | NR
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG1 | 4 | 19.55 (1.48)^‡^ | 122 | NR | −3.86^§^ (1.39)^‡^ | 19.30 (1.45) | 126 | NR | −0.47^§^ (1.29)^‡^ | NR
Donepezil | Feldman, 2001^189^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 19.55 (1.48)^‡^ | 138 | NR | −4.6^§^ (1.24)^‡^ | 19.30 (1.45) | 144 | NR | 1.0^§^ (1.19)^‡^ | MDC=−5.64, 0.0005
Donepezil | Holmes, 2004^190^; Fair-Good | Dem | NPS (NPI-10, 0–120) | IG1 | 6 | 14.3 (1.4)^‡^ | 41 | NR | −2.9 (1.6)^‡^ | 15.1 (1.8)^‡^ | 55 | NR | 3.3 (2.1)^‡^ | NR, 0.02
Donepezil | Ikeda, 2015^*^,^191^; Fair | Dem | NPS (NPI-10, 0–120) | IG1 | 3 | 16.6 (11.7) | 49 | NR | −5.5 (1.4)^‡^ | 20.5 (15.0) | 44 | NR | −6.4 (1.5)^‡^ | MDC (95% CI)=0.9 (−3.1, 4.9), 0.660
Donepezil | Ikeda, 2015^*^,^191^; Fair | Dem | NPS (NPI-10, 0–120) | IG2 | 3 | 18.9 (15.3) | 45 | NR | −3.3 (1.4)^‡^ | 20.5 (15.0) | 44 | NR | −6.4 (1.5)^‡^ | MDC (95% CI)=3.0 (−1.0, 7.1), 0.143
Donepezil | Mori, 2012^195^; Fair | Dem | NPS (NPI-10, 0–120) | IG1 | 3 | 19.5 (12.8) | 35 | NR | −8.0 (12.8) | 18.3 (8.9) | 32 | NR | 0.3 (17.5) | MDC (95% CI)=−8.3 (−15.8, −0.9), 0.019
Donepezil | Mori, 2012^195^; Fair | Dem | NPS (NPI-10, 0–120) | IG2 | 3 | 14.0 (8.3) | 32 | NR | −5.5 (6.7) | 18.3 (8.9) | 32 | NR | 0.3 (17.5) | MDC (95% CI)=−5.8 (−12.4, 0.8), 0.047
Donepezil | Mori, 2012^195^; Fair | Dem | NPS (NPI-10, 0–120) | IG3 | 3 | 20.7 (12.8) | 35 | NR | −3.9 (22.0) | 18.3 (8.9) | 32 | NR | 0.3 (17.5) | MDC (95% CI)=−4.2 (−13.9, 5.6), 0.602
Donepezil | Tune, 2003^201^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | 18.36 (12.40) | 14 | NR | 0.91^§^ (14.50) | 8.79 (9.79) | 13 | NR | −1.52^§^ (13.30) | NR (95% CI)=NR (−7.50, 12.37), 0.652
Donepezil | Tune, 2003^201^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 18.36 (12.40) | 14 | NR | 5.40^§^ (17.80) | 8.79 (9.79) | 13 | NR | 2.65^§^ (14.00) | NR (95% CI)=NR (−9.87, 15.39), 0.688
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 12.6 (NR) | 242 | NR | −0.9 (0.73)^‡^ | 10.3 (NR) | 258 | NR | 0.6 (0.62)^‡^ | NR (95% CI)=NR (−3.42, 0.23), 0.102
Galantamine | Brodaty, 2005^205^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG2 | 6 | 11.2 (NR) | 245 | NR | −0.6 (0.66)^‡^ | 10.3 (NR) | 258 | NR | 0.6 (0.62)^‡^ | NR (95% CI)=NR (−1.85, 1.82), 0.941
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Dem | NPS (NPI-10, 0–120) | IG1 | 6 | 12.2 (12.98) | 279 | NR | −1.2 (0.6)^‡^ | 11.4 (11.27) | 154 | NR | 1.0 (0.9)^‡^ | MDC=−2.2, 0.0164
Galantamine | Rockwood, 2001^210^; Fair-Good | Dem | NPS (NPI-10, 0–120) | IG1 | 3 | 9.2 (0.66)^‡^ | 241 | NR | −0.3 (0.70)^‡^ | 9.4 (1.01)^‡^ | 123 | NR | 0.5 (0.65)^‡^ | NS
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | NPS (NPI-10, 0–120) | IG1 | 5 | 11.9 (0.8)^‡^ | 253 | NR | 0.0 (0.8)^‡^ | 11.0 (0.7)^‡^ | 262 | NR | 2.0 (0.7)^‡^ | NR, 0.03
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | NPS (NPI-10, 0–120) | IG2 | 5 | 12.4 (0.8)^‡^ | 255 | NR | −0.1 (0.7)^‡^ | 11.0 (0.7)^‡^ | 262 | NR | 2.0 (0.7)^‡^ | NR, 0.04
Galantamine | Tariot, 2000^211^; Fair-Good | Dem | NPS (NPI-10, 0–120) | IG3 | 5 | 12.9 (1.2)^‡^ | 129 | NR | 2.3 (1.0)^‡^ | 11.0 (0.7)^‡^ | 262 | NR | 2.0 (0.7)^‡^ | NR
Rivastigmine | Ballard, 2008^215^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 13.4 (12.5) | 364 | NR | −1.4 (0.63)^‡^ | 12.9 (11.5) | 342 | NR | −1.8 (0.64)^‡^ | MDC=0.4, NS
Rivastigmine | McKeith, 2000^218^; Fair-Good | Dem | NPS (NPI-10, 0–120) | IG1 | 5 | 23.2 (15.0) | 47 | NR | −5.0 (16.2) | 20.2 (14.2) | 53 | NR | −1.2 (10.7) | MDC (95% CI)=−3.8 (−1.6, 9.2), 0.048
Rivastigmine | Mok, 2007^219^; Fair | Dem | Anxiety (NPI, Anxiety subscale, 0–12) | IG1 | 6 | 0.8 (1.9) | 20 | 0.3 (0.7) | NR | 0.2 (0.5) | 19 | 0.2 (0.7) | NR | NR, 0.346
Rivastigmine | Mok, 2007^219^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 15.0 (14.6) | 20 | 11.4 (9.4) | NR | 9.5 (6.5) | 19 | 10.4 (11.3) | NR | NR, 0.282
Rivastigmine | Winblad, 2007^221^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 15.1 (14.1) | 253 | NR | −2.2 (11.9) | 14.9 (15.7) | 281 | NR | −1.7 (13.8) | NR, 0.51
Rivastigmine | Winblad, 2007^221^; Fair | Dem | NPS (NPI-12, 0–144) | IG2 | 6 | 15.1 (13.4) | 263 | NR | −2.3 (13.3) | 14.9 (15.7) | 281 | NR | −1.7 (13.8) | NR, 0.69
Rivastigmine | Winblad, 2007^221^; Fair | Dem | NPS (NPI-12, 0–144) | IG3 | 6 | 13.9 (14.1) | 248 | NR | −1.7 (11.5) | 14.9 (15.7) | 281 | NR | −1.7 (13.8) | NR, 0.74
Memantine | Bakchine, 2008^222^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | NR | 268 | NR | −1.37 (NR) | NR | 135 | NR | −1.02 (NR) | MDC (95% CI)=−0.35 (−1.96, 1.26), 0.671
Memantine | Bakchine, 2008^222^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | NR | 267 | NR | −1.45 (NR) | NR | 134 | NR | −2.73 (NR) | MDC (95% CI)=1.28 (−0.5, 3.05), 0.159
Memantine | Choi, 2011^*^,^223^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 4 | 14.7 (18.4) | 84 | NR | 1.2 (10.8) | 13.3 (18.7) | 74 | NR | 1.0 (15.8) | NR, 0.88
Memantine | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 8.0^ǁ^ (NR) | 139 | NR | −0.26^§^ (−2.26, 1.89)^¶^ | 8.0^ǁ^ (NR) | 135 | NR | 0.47^§^ (−1.62, 2.57)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | 8.0^ǁ^ (NR) | 119 | NR | 0.26^§^ (−2.07, 2.70)^¶^ | 8.0^ǁ^ (NR) | 112 | NR | 1.08^§^ (−1.36, 3.53)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 18 | 8.0^ǁ^ (NR) | 94 | NR | 1.14^§^ (−1.62, 4.00)^¶^ | 8.0^ǁ^ (NR) | 96 | NR | 4.05^§^ (1.26, 6.87)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 24 | 8.0^ǁ^ (NR) | 80 | NR | 4.24^§^ (0.78, 7.81)^¶^ | 8.0^ǁ^ (NR) | 75 | NR | 3.59^§^ (0.004, 7.19)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 30 | 8.0^ǁ^ (NR) | 64 | NR | 2.57^§^ (−0.73, 5.98)^¶^ | 8.0^ǁ^ (NR) | 55 | NR | 1.68^§^ (−1.88, 5.21)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 36 | 8.0^ǁ^ (NR) | 45 | NR | 3.17 (−0.83, 7.31)^¶^ | 8.0^ǁ^ (NR) | 41 | NR | 0.60^§^ (−3.63, 4.83)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 42 | 8.0^ǁ^ (NR) | 38 | NR | 3.58^§^ (−1.75, 9.01)^¶^ | 8.0^ǁ^ (NR) | 33 | NR | 3.63^§^ (−2.01, 9.31)^¶^ | NR
Memantine | Dysken, 2014^*^,^224^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 48 | 8.0^ǁ^ (NR) | 142 | NR | 1.87^§^ (1.00)^‡^ | 8.0^ǁ^ (NR) | 140 | NR | 2.26^§^ (1.01)^‡^ | MDC (95% CI)=−0.39 (−2.47, 1.70), 0.94
Memantine | Herrmann, 2013^*^,^226^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 30.94 (1.17)^‡^ | 159 | NR | −3.90 (1.24)^‡^ | 29.18 (1.03)^‡^ | 165 | NR | −5.13 (1.23)^‡^ | MDC (95% CI)=1.23 (−1.75, 4.21), 0.42
Memantine | Peskind, 2006^228^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG1 | 3 | 11.5 (13.20) | 183 | NR | −1.70^§^ (13.66) | 12.2 (13.00) | 179 | NR | 0.20^§^ (13.78) | LSM change (95% CI)=−2.4 (−4.7, −0.2), 0.035
Memantine | Peskind, 2006^228^; Fair-Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 11.5 (13.20) | 196 | NR | −1.37^§^ (13.30) | 12.2 (13.00) | 198 | NR | 0.97^§^ (13.50) | LSM change (95% CI)=−2.34 (−4.5, −0.18), 0.03
Memantine | Peters, 2015^*^,^229^; Fair | Dem | NPS (NPI-12, 8–96) | IG1 | 12 | NR | 94 | NR | NR | NR | 96 | NR | NR | NR, 0.106
Memantine | Porsteinsson, 2008^229^; Good | Dem | NPS (NPI-12, 0–144) | IG1 | 6 | 11.8 (13.11) | 212 | 12.9 (14.48) | NR | 12.3 (13.28) | 209 | 12.6 (14.56) | NR | MDC (95% CI)=0.3 (−1.7, 2.4), 0.743
Memantine | Wilkinson, 2012^233^; Fair | Dem | NPS (NPI-12, 0–144) | IG1 | 12 | 13.1 (12.8) | 103 | NR | NR | 12.8 (12.4) | 114 | NR | NR | MDC (SE)=0.56 (1.19), NS

* New study

† Lower scores indicate better outcomes for all instruments

‡ Standard error

§ Least squares mean change

ǁ Median

¶ 95% CI

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; Dem = dementia; FU = followup; IG = intervention group; Int arm = intervention arm; LSM = least squares mean; MCI = mild cognitive impairment; MDC = mean difference in change; mo. = months; NPI-10 = Neuropsychiatric Inventory-10 item; NPI-12 = Neuropsychiatric Inventory-12 item; NPS = Composite neuropsychiatric symptoms; NR = not reported; NS = not statistically significant; SD = standard deviation; SE = standard error

Appendix E Table 6 AChEIs and Memantine: Detailed Results for Harms, by Medication Type

Medication | Author, year Quality | Outcome | Int arm | Time, mo. | IG n at FU | IG FU N (%) with event | CG n at FU | CG FU N (%) with event | Between group difference, p-value
Donepezil | Black, 2003^186^; Fair-Good | Adverse events | IG1 | 6 | 206 | 195 (94.7) | 199 | 176 (88.4) | NR, 0.03
Donepezil | Black, 2003^186^; Fair-Good | Adverse events | IG2 | 6 | 198 | 176 (88.9) | 199 | 176 (88.4) | NR, 1.0
Donepezil | Black, 2003^186^; Fair-Good | Serious adverse events | IG1 | 6 | 206 | 45 (21.8) | 199 | 30 (15.1) | NR
Donepezil | Black, 2003^186^; Fair-Good | Serious adverse events | IG2 | 6 | 198 | 32 (16.2) | 199 | 30 (15.1) | NR
Donepezil | Black, 2003^186^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 206 | 45 (21.8) | 199 | 22 (11.1) | NR
Donepezil | Black, 2003^186^; Fair-Good | Withdrawals due to adverse events | IG2 | 6 | 198 | 22 (11.1) | 199 | 22 (11.1) | NR
Donepezil | Burns, 1999^187^; Fair-Good | Serious adverse events | IG1 | 6 | 273 | 24 (8.8) | 274 | 25 (9.1) | NR
Donepezil | Burns, 1999^187^; Fair-Good | Serious adverse events | IG2 | 6 | 271 | 24 (8.9) | 274 | 25 (9.1) | NR
Donepezil | Burns, 1999^187^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 273 | 50 (18.3) | 274 | 27 (9.9) | NR
Donepezil | Burns, 1999^187^; Fair-Good | Withdrawals due to adverse events | IG2 | 6 | 271 | 24 (8.9) | 274 | 27 (9.9) | NR
Donepezil | Doody, 2009^188^; Fair | Adverse events | IG1 | 11 | 391 | 318 (81.3) | 387 | 267 (69.0) | NR
Donepezil | Doody, 2009^188^; Fair | Serious adverse events | IG1 | 11 | 391 | 48 (12.3) | 387 | 41 (10.6) | NR
Donepezil | Doody, 2009^188^; Fair | Withdrawals due to adverse events | IG1 | 11 | 391 | 72 (18.4) | 387 | 32 (8.3) | NR
Donepezil | Feldman, 2001^189^; Fair-Good | Adverse events | IG1 | 6 | 144 | 120 (83.3) | 146 | 117 (80.1) | NR
Donepezil | Feldman, 2001^189^; Fair-Good | Serious adverse events | IG1 | 6 | 144 | 19 (13.2) | 146 | 18 (12.3) | NR
Donepezil | Feldman, 2001^189^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 144 | 12 (8.3) | 146 | 9 (6.2) | NR
Donepezil | Holmes, 2004^190^; Fair-Good | Adverse events | IG1 | 6 | 41 | 3 (7.3) | 55 | 0 (0.0) | NR
Donepezil | Ikeda, 2015^*^,^191^; Fair | Adverse events | IG1 | 3 | 49 | 34 (69.4) | 46 | 31 (67.4) | NR
Donepezil | Ikeda, 2015^*^,^191^; Fair | Adverse events | IG2 | 3 | 47 | 30 (63.8) | 46 | 31 (67.4) | NR
Donepezil | Ikeda, 2015^*^,^191^; Fair | Serious adverse events | IG1 | 3 | 49 | 1 (2.0) | 46 | 3 (6.5) | NR
Donepezil | Ikeda, 2015^*^,^191^; Fair | Serious adverse events | IG2 | 3 | 47 | 4 (8.5) | 46 | 3 (6.5) | NR
Donepezil | Ikeda, 2015^*^,^191^; Fair | Withdrawals due to adverse events | IG1 | 3 | 49 | 2 (4.1) | 46 | 5 (10.9) | NR
Donepezil | Ikeda, 2015^*^,^191^; Fair | Withdrawals due to adverse events | IG2 | 3 | 47 | 10 (21.3) | 46 | 5 (10.9) | NR
Donepezil | Krishnan, 2003^192^; Fair-Good | Adverse events | IG1 | 6 | 34 | 32 (94.1) | 33 | 28 (84.8) | NS
Donepezil | Krishnan, 2003^192^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 34 | 0 (0.0) | 33 | 1 (3.0) | NR
Donepezil | Mazza, 2006^193^; Fair-Good | Adverse events | IG1 | 6 | 25 | 4 (16.0) | 26 | 0 (0.0) | NR
Donepezil | Mohs, 2001^194^; Fair | Serious adverse events | IG1 | 12 | 214 | 26 (12.1) | 217 | 19 (8.8) | NR
Donepezil | Mohs, 2001^194^; Fair | Withdrawals due to adverse events | IG1 | 12 | 214 | 20 (9.3) | 217 | 12 (5.5) | NR
Donepezil | Mori, 2012^195^; Fair | Adverse events | IG1 | 3 | 37 | 32 (86.5) | 34 | 24 (70.6) | NR
Donepezil | Mori, 2012^195^; Fair | Adverse events | IG2 | 3 | 33 | 27 (81.8) | 34 | 24 (70.6) | NR
Donepezil | Mori, 2012^195^; Fair | Adverse events | IG3 | 3 | 35 | 24 (68.6) | 34 | 24 (70.6) | NR
Donepezil | Mori, 2012^195^; Fair | Serious adverse events | IG1 | 3 | 37 | 4 (10.8) | 34 | 2 (5.9) | NR
Donepezil | Mori, 2012^195^; Fair | Serious adverse events | IG2 | 3 | 33 | 2 (6.1) | 34 | 2 (5.9) | NR
Donepezil | Mori, 2012^195^; Fair | Serious adverse events | IG3 | 3 | 35 | 2 (5.7) | 34 | 2 (5.9) | NR
Donepezil | Mori, 2012^195^; Fair | Withdrawals due to adverse events | IG1 | 3 | 37 | 3 (8.1) | 34 | 4 (11.8) | NR
Donepezil | Mori, 2012^195^; Fair | Withdrawals due to adverse events | IG2 | 3 | 33 | 1 (3.0) | 34 | 4 (11.8) | NR
Donepezil | Mori, 2012^195^; Fair | Withdrawals due to adverse events | IG3 | 3 | 35 | 3 (8.6) | 34 | 4 (11.8) | NR
Donepezil | Petersen, 2005^196^; Fair | Adverse events | IG1 | 36 | 253 | 221^†^ | 259 | 64^†^ | NR, <0.01
Donepezil | Rogers, 1996^198^; Fair-Good | Adverse events | IG1 | 3 | 39 | 26 (66.7) | 40 | 26 (65.0) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Adverse events | IG2 | 3 | 40 | 27 (67.5) | 40 | 26 (65.0) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Adverse events | IG3 | 3 | 42 | 27 (64.3) | 40 | 26 (65.0) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Withdrawals due to adverse events | IG1 | 3 | 39 | 3 (7.7) | 40 | 2 (5.0) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Withdrawals due to adverse events | IG2 | 3 | 40 | 2 (5.0) | 40 | 2 (5.0) | NR
Donepezil | Rogers, 1996^198^; Fair-Good | Withdrawals due to adverse events | IG3 | 3 | 42 | 5 (11.9) | 40 | 2 (5.0) | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Adverse events | IG1 | 3 | 158 | 124 (78.5) | 153 | 106 (69.3) | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Adverse events | IG2 | 3 | 157 | 106 (67.5) | 153 | 106 (69.3) | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Serious adverse events | IG1 | 3 | 158 | 6 (3.8) | 153 | 7 (4.6) | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Serious adverse events | IG2 | 3 | 157 | 6 (3.8) | 153 | 7 (4.6) | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Withdrawals due to adverse events | IG1 | 3 | 158 | 16 (10.1) | 153 | 3 (2.0) | NR
Donepezil | Rogers, 1998^197^; Fair-Good | Withdrawals due to adverse events | IG2 | 3 | 157 | 7 (4.5) | 153 | 3 (2.0) | NR
Donepezil | Salloway, 2004^199^; Fair-Good | Adverse events | IG1 | 6 | 132 | 116 (87.9) | 137 | 100 (73.0) | NR, ≤0.03
Donepezil | Salloway, 2004^199^; Fair-Good | Serious adverse events | IG1 | 6 | 133 | 5 (3.8) | 137 | 6 (4.4) | NR
Donepezil | Salloway, 2004^199^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 133 | 29 (21.8) | 137 | 10 (7.3) | NR
Donepezil | Seltzer, 2004^200^; Fair-Good | Adverse events | IG1 | 6 | 96 | 67 (69.8) | 57 | 37 (64.9) | NR
Donepezil | Seltzer, 2004^200^; Fair-Good | Serious adverse events | IG1 | 6 | 96 | 5 (5.2) | 57 | 3 (5.3) | NR
Donepezil | Seltzer, 2004^200^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 96 | 15 (15.6) | 57 | 5 (8.8) | NR
Donepezil | Tune, 2003^201^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 14 | 0 (0.0) | 14 | 0 (0.0) | NR
Donepezil | Wilkinson, 2003^202^; Fair-Good | Adverse events | IG1 | 6 | 215 | 197 (91.6) | 193 | 167 (86.5) | NR
Donepezil | Wilkinson, 2003^202^; Fair-Good | Adverse events | IG2 | 6 | 208 | 188 (90.4) | 193 | 167 (86.5) | NR
Donepezil | Wilkinson, 2003^202^; Fair-Good | Serious adverse events | IG1 | 6 | 215 | 31 (14.4) | 193 | 32 (16.6) | NR
Donepezil | Wilkinson, 2003^202^; Fair-Good | Serious adverse events | IG2 | 6 | 208 | 28 (13.5) | 193 | 32 (16.6) | NR
Donepezil | Wilkinson, 2003^202^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 215 | 35 (16.3) | 193 | 17 (8.8) | NR
Donepezil | Wilkinson, 2003^202^; Fair-Good | Withdrawals due to adverse events | IG2 | 6 | 208 | 21 (10.1) | 193 | 17 (8.8) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Adverse events | IG1 | 12 | 142 | 116 (81.7) | 144 | 109 (75.7) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Serious adverse events | IG1 | 12 | 142 | 35 (24.6) | 144 | 20 (13.9) | NR
Donepezil | Winblad, 2001^203^; Fair-Good | Withdrawals due to adverse events | IG1 | 12 | 142 | 10 (7.0) | 144 | 9 (6.3) | NR
Galantamine | Auchus, 2007^204^; Fair | Adverse events | IG1 | 6 | 396 | 301 (76.0) | 390 | 278 (71.3) | NR
Galantamine | Auchus, 2007^204^; Fair | Serious adverse events | IG1 | 6 | 396 | 80 (20.2) | 390 | 72 (18.5) | NR
Galantamine | Auchus, 2007^204^; Fair | Withdrawals due to adverse events | IG1 | 6 | 396 | 54 (13.6) | 390 | 27 (6.9) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Adverse events | IG1 | 6 | 326 | 235 (72.1) | 320 | 224 (70.0) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Adverse events | IG2 | 6 | 319 | 253 (79.3) | 320 | 224 (70.0) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Serious adverse events | IG1 | 6 | 326 | 3 (0.9) | 320 | 3 (0.9) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Serious adverse events | IG2 | 6 | 319 | 3 (0.9) | 320 | 3 (0.9) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 326 | 24 (7.4) | 320 | 15 (4.7) | NR
Galantamine | Brodaty, 2005^205^; Fair-Good | Withdrawals due to adverse events | IG2 | 6 | 319 | 28 (8.8) | 320 | 15 (4.7) | NR
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Adverse events | IG1 | 6 | 396 | 330 (83.3) | 196 | 133 (67.9) | NR
Galantamine | Erkinjuntti, 2002^206^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 396 | 78 (19.7) | 196 | 16 (8.2) | NR
Galantamine | Hager, 2014^*^,^207^; Fair | Adverse events | IG1 | 24 | 1024 | 553 (54.0) | 1021 | 496 (48.6) | NR
Galantamine | Hager, 2014^*^,^207^; Fair | Serious adverse events | IG1 | 24 | 1024 | 129 (12.6) | 1021 | 123 (12.0) | NR
Galantamine | Hager, 2014^*^,^207^; Fair | Withdrawals due to adverse events | IG1 | 24 | 1024 | 87 (8.5) | 1021 | 66 (6.5) | NR
Galantamine | Raskind, 2000^208^; Fair-Good | Adverse events | IG1 | 6 | 212 | 195 (92.0) | 213 | 168 (78.9) | NR
Galantamine | Raskind, 2000^208^; Fair-Good | Adverse events | IG2 | 6 | 211 | 195 (92.4) | 213 | 168 (78.9) | NR
Galantamine | Raskind, 2000^208^; Fair-Good | Serious adverse events | IG1 | 6 | 212 | NR | 213 | NR | NS
Galantamine | Raskind, 2000^208^; Fair-Good | Serious adverse events | IG2 | 6 | 211 | NR | 213 | NR | NS
Galantamine | Raskind, 2000^208^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 212 | 49 (23.1) | 213 | 16 (7.5) | NR
Galantamine | Raskind, 2000^208^; Fair-Good | Withdrawals due to adverse events | IG2 | 6 | 211 | 67 (31.8) | 213 | 16 (7.5) | NR
Galantamine | Rockwood, 2001^210^; Fair-Good | Adverse events | IG1 | 3 | 261 | 225 (86.2) | 125 | 79 (63.2) | NR
Galantamine | Rockwood, 2001^210^; Fair-Good | Serious adverse events | IG1 | 3 | 261 | 21 (8.0) | 125 | 8 (6.4) | NR
Galantamine | Rockwood, 2001^210^; Fair-Good | Withdrawals due to adverse events | IG1 | 3 | 261 | 66 (25.3) | 125 | 5 (4.0) | NR
Galantamine | Rockwood, 2006^209^; Fair | Adverse events | IG1 | 4 | 64 | 54 (84.4) | 66 | 41 (62.1) | NR
Galantamine | Rockwood, 2006^209^; Fair | Serious adverse events | IG1 | 4 | 64 | 5 (7.8) | 66 | 10 (15.2) | NR
Galantamine | Rockwood, 2006^209^; Fair | Withdrawals due to adverse events | IG1 | 4 | 64 | 5 (7.8) | 66 | 2 (3.0) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Adverse events | IG1 | 5 | 273 | 219 (80.2) | 286 | 206 (72.0) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Adverse events | IG2 | 5 | 279 | 206 (73.8) | 286 | 206 (72.0) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Adverse events | IG3 | 5 | 140 | 106 (75.7) | 286 | 206 (72.0) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Serious adverse events | IG1 | 5 | 273 | 35 (12.8) | 286 | 31 (10.8) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Serious adverse events | IG2 | 5 | 279 | 28 (10.0) | 286 | 31 (10.8) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Serious adverse events | IG3 | 5 | 140 | 14 (10.0) | 286 | 31 (10.8) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Withdrawals due to adverse events | IG1 | 5 | 273 | 27 (9.9) | 286 | 20 (7.0) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Withdrawals due to adverse events | IG2 | 5 | 279 | 19 (6.8) | 286 | 20 (7.0) | NR
Galantamine | Tariot, 2000^211^; Fair-Good | Withdrawals due to adverse events | IG3 | 5 | 140 | 9 (6.4) | 286 | 20 (7.0) | NR
Galantamine | Wilcock, 2000^212^; Fair-Good | Adverse events | IG1 | 6 | 220 | 182 (82.7) | 215 | 165 (76.7) | NR
Galantamine | Wilcock, 2000^212^; Fair-Good | Adverse events | IG2 | 6 | 218 | 194 (89.0) | 215 | 165 (76.7) | NR
Galantamine | Wilcock, 2000^212^; Fair-Good | Serious adverse events | IG1 | 6 | 220 | 28 (12.7) | 215 | 26 (12.1) | NR
Galantamine | Wilcock, 2000^212^; Fair-Good | Serious adverse events | IG2 | 6 | 218 | 28 (12.8) | 215 | 26 (12.1) | NR
Galantamine | Wilcock, 2000^212^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 220 | 31 (14.1) | 215 | 19 (8.8) | NR
Galantamine | Wilcock, 2000^212^; Fair-Good | Withdrawals due to adverse events | IG2 | 6 | 218 | 48 (22.0) | 215 | 19 (8.8) | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Adverse events | IG1 | 3 | 56 | 33^†^ | 87 | 38^†^ | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Adverse events | IG2 | 3 | 54 | 38^†^ | 87 | 38^†^ | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Adverse events | IG3 | 3 | 88 | 49^†^ | 87 | 38^†^ | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Serious adverse events | IG1 | 3 | 56 | 0 (0.0) | 87 | 3 (3.4) | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Serious adverse events | IG2 | 3 | 54 | 5 (9.3) | 87 | 3 (3.4) | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Serious adverse events | IG3 | 3 | 88 | 6 (6.8) | 87 | 3 (3.4) | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Withdrawals due to adverse events | IG1 | 3 | 56 | 10 (17.9) | 87 | 8 (9.2) | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Withdrawals due to adverse events | IG2 | 3 | 54 | 24 (44.4) | 87 | 8 (9.2) | NR
Galantamine | Wilkinson, 2001^213^; Fair-Good | Withdrawals due to adverse events | IG3 | 3 | 88 | 19 (21.6) | 87 | 8 (9.2) | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Adverse events | IG1 | 3 | 133 | 133^†^ | 133 | 38^†^ | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Adverse events | IG2 | 3 | 136 | 67^†^ | 133 | 38^†^ | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Serious adverse events | IG1 | 3 | 133 | 8 (6.0) | 133 | 2 (1.5) | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Serious adverse events | IG2 | 3 | 136 | 7 (5.1) | 133 | 2 (1.5) | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Withdrawals due to adverse events | IG1 | 3 | 133 | 16 (12.0) | 133 | 5 (3.8) | NR
Rivastigmine | Agid, 1998^214^; Fair-Good | Withdrawals due to adverse events | IG2 | 3 | 136 | 14 (10.3) | 133 | 5 (3.8) | NR
Rivastigmine | Ballard, 2008^215^; Fair | Serious adverse events | IG1 | 6 | 363 | 55 (15.2) | 344 | 38 (11.0) | NR
Rivastigmine | Ballard, 2008^215^; Fair | Withdrawals due to adverse events | IG1 | 6 | 365 | 49 (13.4) | 345 | 19 (5.5) | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Adverse events | IG1 | 6 | 231 | NR | 235 | NR | NS
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Adverse events | IG2 | 6 | 233 | NR | 235 | NR | NS
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 231 | 66 (28.6) | 235 | 17 (7.2) | NR
Rivastigmine | Corey-Bloom, 1998^216^; Fair-Good | Withdrawals due to adverse events | IG2 | 6 | 233 | 19 (8.2) | 235 | 17 (7.2) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Adverse events | IG1 | 6 | 227 | 208 (91.6) | 222 | 169 (76.1) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Adverse events | IG2 | 6 | 228 | 208 (91.2) | 222 | 169 (76.1) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Serious adverse events | IG1 | 6 | 227 | 40 (17.6) | 222 | 33 (14.9) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Serious adverse events | IG2 | 6 | 228 | 40 (17.5) | 222 | 33 (14.9) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Withdrawals due to adverse events | IG1 | 6 | 227 | 24 (10.6) | 222 | 20 (9.0) | NR
Rivastigmine | Feldman, 2007^217^; Fair | Withdrawals due to adverse events | IG2 | 6 | 228 | 38 (16.7) | 222 | 20 (9.0) | NR
Rivastigmine | McKeith, 2000^218^; Fair-Good | Adverse events | IG1 | 5 | 59 | 54 (91.5) | 61 | 46 (75.4) | NR
Rivastigmine | McKeith, 2000^218^; Fair-Good | Serious adverse events | IG1 | 5 | 59 | 10 (16.9) | 61 | 8 (13.1) | NR
Rivastigmine | McKeith, 2000^218^; Fair-Good | Withdrawals due to adverse events | IG1 | 5 | 59 | 7 (11.9) | 61 | 7 (11.5) | NR
Rivastigmine | Mok, 2007^219^; Fair | Adverse events | IG1 | 6 | 20 | 12 (60.0) | 20 | 10 (50.0) | NR
Rivastigmine | Mok, 2007^219^; Fair | Withdrawals due to adverse events | IG1 | 6 | 20 | 6 (30.0) | 20 | 3 (15.0) | NR
Rivastigmine | Rosler, 1999^220^; Fair-Good | Adverse events | IG1 | 6 | 242 | 220 (90.9) | 239 | 172 (72.0) | NR
Rivastigmine | Rosler, 1999^220^; Fair-Good | Adverse events | IG2 | 6 | 242 | 172 (71.1) | 239 | 172 (72.0) | NR
Rivastigmine | Rosler, 1999^220^; Fair-Good | Serious adverse events | IG1 | 6 | 242 | 44 (18.2) | 239 | 43 (18.0) | NR
Rivastigmine | Rosler, 1999^220^; Fair-Good | Serious adverse events | IG2 | 6 | 242 | 44 (18.2) | 239 | 43 (18.0) | NR
Rivastigmine | Rosler, 1999^220^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 242 | 55 (22.7) | 239 | 16 (6.7) | NR
Rivastigmine | Rosler, 1999^220^; Fair-Good | Withdrawals due to adverse events | IG2 | 6 | 242 | 18 (7.4) | 239 | 16 (6.7) | NR
Rivastigmine | Winblad, 2007^221^; Fair | Serious adverse events | IG1 | 6 | 294 | 21 (7.1) | 302 | 27 (8.9) | NR
Rivastigmine | Winblad, 2007^221^; Fair | Serious adverse events | IG2 | 6 | 303 | 36 (11.9) | 302 | 27 (8.9) | NR
Rivastigmine | Winblad, 2007^221^; Fair | Serious adverse events | IG3 | 6 | 291 | 23 (7.9) | 302 | 27 (8.9) | NR
Rivastigmine | Winblad, 2007^221^; Fair | Withdrawals due to adverse events | IG1 | 6 | 297 | 24 (8.1) | 302 | 15 (5.0) | NR
Rivastigmine | Winblad, 2007^221^; Fair | Withdrawals due to adverse events | IG2 | 6 | 303 | 26 (8.6) | 302 | 15 (5.0) | NR
Rivastigmine | Winblad, 2007^221^; Fair | Withdrawals due to adverse events | IG3 | 6 | 293 | 28 (9.6) | 302 | 15 (5.0) | NR
Memantine | Bakchine, 2008^222^; Good | Adverse events | IG1 | 6 | 318 | 178 (56.0) | 152 | 80 (52.6) | NR
Memantine | Bakchine, 2008^222^; Good | Withdrawals due to adverse events | IG1 | 6 | 318 | 28 (8.8) | 152 | 6 (3.9) | NR
Memantine | Choi, 2011^*^,^223^; Fair | Adverse events | IG1 | 4 | 88 | 47 (53.4) | 83 | 42 (50.6) | NR, 0.71
Memantine | Choi, 2011^*^,^223^; Fair | Serious adverse events | IG1 | 4 | 88 | 4 (4.5) | 83 | 4 (4.8) | NR
Memantine | Choi, 2011^*^,^223^; Fair | Withdrawals due to adverse events | IG1 | 4 | 88 | 6 (6.8) | 83 | 4 (4.8) | NR, 0.82
Memantine | Dysken, 2014^*^,^224^; Good | Adverse events | IG1 | 48 | 155 | 97 (62.6) | 152 | 89 (58.6) | NR
Memantine | Dysken, 2014^*^,^224^; Good | Serious adverse events | IG1 | 48 | 155 | 84 (54.2) | 152 | 95 (62.5) | NR
Memantine | Ferris, 2007^225^; Fair | Adverse events | IG1 | 3 | 30 | 19 (63.3) | 30 | 20 (66.7) | NR
Memantine | Ferris, 2007^225^; Fair | Serious adverse events | IG1 | 3 | 30 | 0 (0.0) | 30 | 0 (0.0) | NR
Memantine | Herrmann, 2013^*^,^226^; Fair | Adverse events | IG1 | 6 | 182 | 138 (75.8) | 187 | 136 (72.7) | NR
Memantine | Herrmann, 2013^*^,^226^; Fair | Serious adverse events | IG1 | 6 | 182 | 18 (9.9) | 187 | 11 (5.9) | NR
Memantine | Herrmann, 2013^*^,^226^; Fair | Withdrawals due to adverse events | IG1 | 6 | 182 | 15 (8.2) | 187 | 9 (4.8) | NR
Memantine | Orgogozo, 2002^227^; Fair-Good | Adverse events | IG1 | 6 | 165 | 125 (75.8) | 156 | 115 (73.7) | NR
Memantine | Orgogozo, 2002^227^; Fair-Good | Serious adverse events | IG1 | 6 | 165 | 38 (23.0) | 156 | 40 (25.6) | NR
Memantine | Orgogozo, 2002^227^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 165 | 19 (11.5) | 156 | 20 (12.8) | NR
Memantine | Peskind, 2006^228^; Fair-Good | Adverse events | IG1 | 6 | 201 | 143 (71.1) | 202 | 149 (73.8) | NR
Memantine | Peskind, 2006^228^; Fair-Good | Serious adverse events | IG1 | 6 | 201 | 20 (10.0) | 202 | 20 (9.9) | NR
Memantine | Peskind, 2006^228^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 201 | 19 (9.5) | 202 | 10 (5.0) | NR, 0.09
Memantine | Peters, 2015^*^,^229^; Fair | Adverse events | IG1 | 12 | 112 | 89 (79.5) | 114 | 80 (70.2) | NR, 0.108
Memantine | Peters, 2015^*^,^229^; Fair | Serious adverse events | IG1 | 12 | 112 | 15 (13.4) | 114 | 15 (13.2) | NR
Memantine | Porsteinsson, 2008^230^; Good | Serious adverse events | IG1 | 6 | 217 | 27 (12.4) | 216 | 30 (13.9) | NR
Memantine | Porsteinsson, 2008^230^; Good | Withdrawals due to adverse events | IG1 | 6 | 217 | 13 (6.0) | 216 | 17 (7.9) | NR
Memantine | Saxton, 2012^231^; Good | Adverse events | IG1 | 3 | 135 | 66 (48.9) | 129 | 64 (49.6) | NR
Memantine | Saxton, 2012^231^; Good | Serious adverse events | IG1 | 3 | 135 | 4 (3.0) | 129 | 13 (10.1) | NR
Memantine | Saxton, 2012^231^; Good | Withdrawals due to adverse events | IG1 | 3 | 136 | 3 (2.2) | 129 | 4 (3.1) | NR
Memantine | Wilcock, 2002^232^; Fair-Good | Adverse events | IG1 | 6 | 295 | 226 (76.6) | 284 | 212 (74.6) | NR
Memantine | Wilcock, 2002^232^; Fair-Good | Serious adverse events | IG1 | 6 | 295 | 37 (12.5) | 284 | 47 (16.5) | NR
Memantine | Wilcock, 2002^232^; Fair-Good | Withdrawals due to adverse events | IG1 | 6 | 295 | 27 (9.2) | 284 | 20 (7.0) | NR
Memantine | Wilkinson, 2012^233^; Fair | Adverse events | IG1 | 12 | 133 | 32 (24.1) | 144 | 22 (15.3) | NR
Memantine | Wilkinson, 2012^233^; Fair | Serious adverse events | IG1 | 12 | 133 | 17 (12.8) | 144 | 20 (13.9) | NR
Memantine | Wilkinson, 2012^233^; Fair | Withdrawals due to adverse events | IG1 | 12 | 133 | 15 (11.3) | 144 | 12 (8.3) | NR

* New study

† Number of events reported

Abbreviations: CG = control group; FU = followup; IG = intervention group; Int arm = intervention arm; mo. = months; n (%) = number (percentage) of participants reporting events