# Appendix D List of Excluded Studies

Exclusion Code and Definition
E1 Study relevance; E1b Treatment trial with primary prevention; healthy population without dementia or MCI
E2 Study design; E2a Not an included study design (be more specific if E2b-E2e apply); E2b Comparative effectiveness; E2c Followup <3 months (does not apply for harms); E2d Case-control (for KQ2 only); E2e Cohort or case-control n<1000 (KQ5 only); E2f No comparator/unexposed group (specific to harms outcomes)
E3 Setting; E3a Not conducted in ‘very high’ HDI country; E3b Intermediate care facility (nursing home, rehabilitation facility, subacute care); E3c Other unrepresentative setting (hospital, emergency department; KQ2: memory, dementia clinics)
E4 Population; E4a Mean age <65 years; E4b Exclusively among those with depression or psychosis, alcohol use disorder, HIV/AIDS, Down syndrome, posttraumatic brain injury, metabolic disorders, Parkinson’s disease, Huntington’s disease, or stroke; E4c Severe dementia; E4d Professional caregiver; E4e Not representative of community-dwelling population (e.g., patients needed to have a sign of cognitive decline during the clinical investigation) (KQ2 only)
E5 Outcomes: No relevant outcomes
E6a Screener: Not a relevant screening instrument (e.g., time for test administration too long [>10 min clinician, >20 min self], assessment battery [vs. screening instrument]); E6b Intervention: Not one of the specified interventions/treatments; E6c Intervention aim: Focused on improving symptoms (mood, neuropsychiatric symptoms) or functional performance or reducing falls
E7b Does not use a reference standard; E7c Study quality (general)
E8 Ancillary study to excluded primary study

1 Abdel-Aziz, K, Larner, AJ. Six-item cognitive impairment test (6CIT): pragmatic diagnostic accuracy study for dementia and MCI. Int Psychogeriatr. 27(6): 991–7. 2015. PMID: 25630996. 10.1017/S1041610214002932 KQ2E3c25630996
2 Abdin, E, Vaingankar, JA, . Validation of the short version of the 10/66 dementia diagnosis in multiethnic Asian older adults in Singapore. BMC Geriatr. 17(1): 94. 2017. PMID: 28431511. 10.1186/s12877-017-0475-7 KQ2E128431511
3 Adachi, H, Shinagawa, S, . Comparison of the utility of everyday memory test and the Alzheimer’s Disease Assessment Scale-Cognitive part for evaluation of mild cognitive impairment and very mild Alzheimer’s disease. Psychiatry Clin Neurosci. 67(3): 148–53. 2013. PMID: 23581865. 10.1111/pcn.12034 KQ2E123581865
4 Adapt-Fs Research Group. Follow-up evaluation of cognitive function in the randomized Alzheimer’s Disease Anti-inflammatory Prevention Trial and its Follow-up Study. Alzheimer’s & Dementia. 11(2): 216–25.e1. 2015. PMID: 25022541. 10.1016/j.jalz.2014.03.009 KQ4E1b, KQ5E1b25022541
5 Aguiar, P, Monteiro, L, . Rivastigmine transdermal patch and physical exercises for Alzheimer’s disease: a randomized clinical trial. Curr Alzheimer Res. 11(6): 532–7. 2014. PMID: 24938502. KQ4E3a, KQ5E3a24938502
6 Alagiakrishnan, K, Zhao, N, . Montreal Cognitive Assessment is superior to Standardized Mini-Mental Status Exam in detecting mild cognitive impairment in the middle-aged and elderly patients with type 2 diabetes mellitus. [Erratum appears in Biomed Res Int. 2014;2014:648472]. Biomed Res Int. 2013(): 186106. 2013. PMID: 23936778. 10.1155/2013/186106 KQ2E4b23936778
7 Alva, G, Cummings, JL, . Skin reactions at the application site of rivastigmine patch (4.6 mg/24 h, 9.5 mg/24 h or 13.3 mg/24 h): a qualitative analysis of clinical studies in patients with Alzheimer’s disease. Int J Clin Pract. 69(5): 518–30. 2015. PMID: 25684069. 10.1111/ijcp.12621 KQ4E2a, KQ5E2a25684069
8 Andersen, F, Viitanen, M, . The effect of stimulation therapy and donepezil on cognitive function in Alzheimer’s disease. A community based RCT with a two-by-two factorial design. BMC Neurol. 12: 59. 2012. PMID: 22813231. 10.1186/1471-2377-12-59 KQ4E2a, KQ5E2a22813231
9 Andrieu, Sandrine, Guyonnet, Sophie, . Effect of long-term omega 3 polyunsaturated fatty acid supplementation with or without multidomain intervention on cognitive function in elderly adults with memory complaints (MAPT): A randomised, placebo-controlled trial. The Lancet Neurology. 16(5): 377–389. 2017. 10.1016/S1474-4422%2817%2930040-6 KQ4E1b, KQ5E1b28359749
10 Apostolo, JLA, Paiva, DDS, . Adaptation and validation into Portuguese language of the six-item cognitive impairment test (6CIT). Aging Ment Health. 1–6. 2017. PMID: 28741373. 10.1080/13607863.2017.1348473 KQ2E7b28741373
11 Arabi, Z, Aziz, NA, . Early Dementia Questionnaire (EDQ): a new screening instrument for early dementia in primary care practice. BMC Fam Pract. 14: 49. 2013. PMID: 23586732. 10.1186/1471-2296-14-49 KQ2E3a23586732
12 Arabi, Z, Syed Abdul Rahman, SA, . Reliability and construct validity of the Early Dementia Questionnaire (EDQ). BMC Geriatr. 16(1): 202. 2016. PMID: 27903242. 10.1186/s12877-016-0384-1 KQ2E3a27903242
13 Arai, H, Sumitomo, K, . Disease state changes and safety of long-term donepezil hydrochloride administration in patients with Alzheimer’s disease: interim results from the long-term, large-scale J-GOLD study in Japan. Psychogeriatrics:The Official Journal of the Japanese Psychogeriatric Society. 16(2): 107–15. 2016. PMID: 26114729. 10.1111/psyg.12130 KQ4E2a, KQ5E2a26114729
14 Araki, T, Wake, R, . The effects of combine treatment of memantine and donepezil on Alzheimer’s disease patients and its relationship with cerebral blood flow in the prefrontal area. Int J Geriatr Psychiatry. 29(9): 881–9. 2014. PMID: 24436135. 10.1002/gps.4074 KQ4E2b, KQ5E2b24436135
15 Arcoverde, C, Deslandes, A, . Treadmill training as an augmentation treatment for Alzheimer’s disease: a pilot randomized controlled study. Arq Neuropsiquiatr. 72(3): 190–6. 2014. PMID: 24676435. KQ4E6b24676435
16 Arlt, S, Muller-Thomsen, T, . Effect of one-year vitamin C- and E-supplementation on cerebrospinal fluid oxidation parameters and clinical course in Alzheimer’s disease. Neurochem Res. 37(12): 2706–14. 2012. PMID: 22878647. 10.1007/s11064-012-0860-8 KQ4E7c, KQ5E7c22878647
17 Atri, A, Hendrix, SB, . Cumulative, additive benefits of memantine-donepezil combination over component monotherapies in moderate to severe Alzheimer’s dementia: a pooled area under the curve analysis. Alzheimers Res Ther. 7(1): 28. 2015. PMID: 25991927. 10.1186/s13195-015-0109-2 KQ4E2a, KQ5E2a25991927
18 Awata, S, Sugiyama, M, . Development of the dementia assessment sheet for community-based integrated care system. Geriatr Gerontol Int. 16 Suppl 1: 123–31. 2016. PMID: 27018290. 10.1111/ggi.12727 KQ2E6a27018290
19 Babacan-Yildiz, G, Isik, AT, . COST: Cognitive State Test, a brief screening battery for Alzheimer disease in illiterate and literate patients. Int Psychogeriatr. 25(3): 403–12. 2013. PMID: 23137551. 10.1017/S1041610212001780 KQ2E3a23137551
20 Babai, S, Auriche, P, . Comparison of adverse drug reactions with donepezil versus memantine: analysis of the French Pharmacovigilance Database. Therapie. 65(3): 255–259. 2010. PMID: 20699079. KQ5E2f20699079
21 Bademli K, Lok N, Canbaz M, . Effects of Physical Activity Program on cognitive function and sleep quality in elderly with mild cognitive impairment: A randomized controlled trial. Perspect Psychiatr Care. 2018. PMID: 30430592. KQ4E3b, KQ5E3b30430592
22 Bahar-Fuchs, A, Webb, S, . Tailored and Adaptive Computerized Cognitive Training in Older Adults at Risk for Dementia: A Randomized Controlled Trial. J Alzheimers Dis. 60(3): 889–911. 2017. PMID: 28922158. 10.3233/JAD-170404 KQ4E2b, KQ5E2b28922158
23 Baleztena J, Ruiz-Canela M, Sayon-Orea C, . Association between cognitive function and supplementation with omega-3 PUFAs and other nutrients in 75 years old patients: a randomized multicenter study. Plos one. 2018. KQ4E1b, KQ5E1b
24 Ballard, C, Margallo-Lana, M, . Quetiapine and rivastigmine and cognitive decline in Alzheimer’s disease: randomised double blind placebo controlled trial. BMJ. 330(7496): 874. 2005. PMID: 15722369. 10.1136/bmj.38369.459988.8F KQ4E3b, KQ5E3b15722369
25 Ballard, C, Thomas, A, . A double-blind randomized placebo-controlled withdrawal trial comparing memantine and antipsychotics for the long-term treatment of function and neuropsychiatric symptoms in people with Alzheimer’s disease (MAIN-AD). J Am Med Dir Assoc. 16(4): 316–22. 2015. PMID: 25523285. 10.1016/j.jamda.2014.11.002 KQ4E2b, KQ5E2b25523285
26 Bamidis, Pd, Fissler, P, . Gains in cognition through combined cognitive and physical training: The role of training dosage and severity of neurocognitive disorder. Front Aging Neurosci. 7(Jul). 2015. 10.3389/fnagi.2015.00152 KQ4E1b, KQ5E1b
27 Barban, F, Annicchiarico, R, . Protecting cognition from aging and Alzheimer’s disease: a computerized cognitive training combined with reminiscence therapy. Int J Geriatr Psychiatry. 31(4): 340–8. 2016. PMID: 26205305. 10.1002/gps.4328 KQ4E7c, KQ5E7c26205305
28 Barekatain, M, Alavirad, M, . Cognitive rehabilitation in patients with nonamnestic mild cognitive impairment. Journal of research in medical sciences. 21(7). 2016. KQ4E3a, KQ5E3a
29 Barnes, DE, Beiser, AS, . Development and validation of a brief dementia screening indicator for primary care. Alzheimer’s & Dementia. 10(6): 656–665.e1. 2014. PMID: 24491321. 10.1016/j.jalz.2013.11.006 KQ2E124491321
30 Barnes, DE, Santos-Modesitt, W, . The Mental Activity and eXercise (MAX) trial: a randomized controlled trial to enhance cognitive function in older adults. JAMA Intern Med. 173(9): 797–804. 2013. PMID: 23545598. 10.1001/jamainternmed.2013.189 KQ4E1b, KQ5E1b23545598
31 Bartos A, Fayette D. Validation of the Czech Montreal Cognitive Assessment for Mild Cognitive Impairment due to Alzheimer Disease and Czech Norms in 1,552 Elderly Persons. Dement Geriatr Cogn Disord. 2018;46(5–6):335–45. PMID: 30513529. KQ2E2d30513529
32 Bass, DM, Judge, KS, . Caregiver outcomes of partners in dementia care: effect of a care coordination program for veterans with dementia and their family members and friends. J Am Geriatr Soc. 61(8): 1377–86. 2013. PMID: 23869899. 10.1111/jgs.12362 KQ2E7c23869899
33 Beer, C, Horner, B, . A cluster-randomised trial of staff education to improve the quality of life of people with dementia living in residential care: the DIRECT study. PLoS One. 6(11): e28155. 2011. PMID: 22140531. KQ4E3b, KQ5E3b22140531
34 Beer, CD, Horner, B, . Dementia in residential care: education intervention trial (DIRECT); protocol for a randomised controlled trial. Trials. 11: 63. 2010. PMID: 20500891. KQ4E8, KQ5E820500891
35 Ben-Sadoun, G, Sacco, G, . Physical and cognitive stimulation using an Exergame in subjects with normal aging, mild and moderate cognitive impairment. Journal of alzheimers disease. 53(4): 1299–1314. 2016. KQ4E2a, KQ5E2a
36 Bergh, S, Selbæk, G, . Discontinuation of antidepressants in people with dementia and neuropsychiatric symptoms (DESEP study): double blind, randomised, parallel group, placebo controlled trial. BMJ. 344: e1566. 2012. PMID: Pubmed 22408266. KQ4E3b, KQ5E3b22408266
37 Berman SE, Koscik RL, Clark LR, . Use of the Quick Dementia Rating System (QDRS) as an Initial Screening Measure in a Longitudinal Cohort at Risk for Alzheimer’s Disease. J Alzheimers Dis Rep. 2017;1(1):9–13. PMID: 28819654. KQ2E128819654
38 Bernier, PJ, Gourdeau, C, . Validation and diagnostic accuracy of predictive curves for age-associated longitudinal cognitive decline in older adults. CMAJ. 189(48): E1472–E1480. 2017. PMID: 29203616. 10.1503/cmaj.160792 KQ2E129203616
39 Blautzik, J, Keeser, D, . Functional connectivity increase in the default-mode network of patients with Alzheimer’s disease after long-term treatment with Galantamine. Eur Neuropsychopharmacol. 26(3): 602–13. 2016. PMID: 26796681. 10.1016/j.euroneuro.2015.12.006 KQ4E7c, KQ5E7c26796681
40 Blom, MM, Bosmans, JE, . Effectiveness and cost-effectiveness of an internet intervention for family caregivers of people with dementia: design of a randomized controlled trial. BMC Psychiatry. 13: 17. 2013. PMID: 23305463. 10.1186/1471-244X-13-17 KQ4E8, KQ5E823305463
41 Blom, MM, Zarit, SH, . Effectiveness of an Internet intervention for family caregivers of people with dementia: results of a randomized controlled trial. PLoS ONE [Electronic Resource]. 10(2): e0116622. 2015. PMID: 25679228. 10.1371/journal.pone.0116622 KQ4E7c, KQ5E7c25679228
42 Boada-Rovira, M, Brodaty, H, . Efficacy and safety of donepezil in patients with Alzheimer’s disease: results of a global, multinational, clinical experience study. Drugs Aging. 21(1): 43–53. 2004. PMID: 14715043. KQ5E2f14715043
43 Bostrom, G, Conradsson, M, . Effects of a high-intensity functional exercise program on depressive symptoms among people with dementia in residential care: a randomized controlled trial. Int J Geriatr Psychiatry. 31(8): 868–78. 2016. PMID: 26644304. 10.1002/gps.4401 KQ4E6c, KQ5E6c26644304
44 Bouman, Z, Hendriks, MP, . Clinical validation of the WMS-IV-NL brief cognitive status exam (BCSE) in older adults with MCI or dementia. Int Psychogeriatr. 1–9. 2014. PMID: 25079232. 10.1017/s1041610214001471 KQ2E2d25079232
45 Bourgeois, J, Laye, M, . Relearning of Activities of Daily Living: a Comparison of the Effectiveness of Three Learning Methods in Patients with Dementia of the Alzheimer Type. Journal of nutrition, health & aging. 20(1): 48–55. 2016. PMID: Pubmed 26728933. 10.1007/s12603-015-0597-6 KQ4E2b, KQ5E2b26728933
46 Boustani, M, Callahan, CM, . Implementing a screening and diagnosis program for dementia in primary care. J Gen Intern Med. 20(7): 572–577. 2005. PMID: 16050849. KQ1E5, KQ3E516050849
47 Boustani, M, Perkins, AJ, . Who refuses the diagnostic assessment for dementia in primary care?. Int J Geriatr Psychiatry. 21(6): 556–563. 2006. PMID: 16783796. KQ3E816783796
48 Bowen, RL, Perry, G, . A clinical study of lupron depot in the treatment of women with Alzheimer’s disease: preservation of cognitive function in patients taking an acetylcholinesterase inhibitor and treated with high dose lupron over 48 weeks. J Alzheimers Dis. 44(2): 549–60. 2015. PMID: 25310993. 10.3233/JAD-141626 KQ4E7c, KQ5E7c25310993
49 Brandt, J, Blehar, J, . Further validation of the Internet-based Dementia Risk Assessment. J Alzheimers Dis. 41(3): 937–45. 2014. PMID: 24705550. 10.3233/JAD-140297 KQ2E4e24705550
50 Brijoux T, Kricheldorff C, M HL, . Supporting Families Living With Dementia in Rural Areas. Dtsch. 2016;113(41):681–7. PMID: 27839534. KQ4E2b, KQ5E2b27839534
51 Brijoux, Thomas, Kricheldorff, Cornelia, . Supporting families living with dementia in rural areas: A randomized controlled trial of quality of life improvement using qualified volunteers. Dtsch Arztebl Int. 113(41): 681–689. 2016. KQ4E2b, KQ5E2b27839534
52 Brinkman, SD, Reese, RJ, . Validation of a self-administered computerized system to detect cognitive impairment in older adults. J Appl Gerontol. 33(8): 942–62. 2014. PMID: 25332303. 10.1177/0733464812455099 KQ2E2a25332303
53 Brodaty, H, Connors, MH, . Screening for Dementia in Primary Care: A Comparison of the GPCOG and the MMSE. Dement Geriatr Cogn Disord. 42(5–6): 323–330. 2016. PMID: 27811463. 10.1159/000450992 KQ2E7b27811463
54 Brodaty, H, Gresham, M, . The Prince Henry Hospital dementia caregivers’ training programme. Int J Geriatr Psychiatry. 12(2): 183–192. 1997. PMID: 9097211. KQ4E8, KQ5E89097211
55 Brodaty, H, Gresham, M. Effect of a training programme to reduce stress in carers of patients with dementia. BMJ. 299(6712): 1375–1379. 1989. PMID: 2513967. KQ4E3c, KQ5E3c2513967
56 Brodaty, H, Mittelman, M, . The effects of counseling spouse caregivers of people with Alzheimer disease taking donepezil and of country of residence on rates of admission to nursing homes and mortality. Am J Geriatr Psychiatry. 17(9): 734–743. 2009. PMID: 19705519. KQ4E8, KQ5E819705519
57 Brown, JM, Lansdall, CJ, . The Test Your Memory for Mild Cognitive Impairment (TYM-MCI). J Neurol Neurosurg Psychiatry. 2017. PMID: 28912299. 10.1136/jnnp-2016-315327 KQ2E3c28912299
58 Brown, KW, Coogle, CL, . A pilot randomized controlled trial of mindfulness-based stress reduction for caregivers of family members with dementia. Aging Ment Health. 20(11): 1157–1166. 2016. PMID: 26211415. 10.1080/13607863.2015.1065790 KQ4E2b, KQ5E2b26211415
59 Brunelle-Hamann, L, Thivierge, S, . Impact of a cognitive rehabilitation intervention on neuropsychiatric symptoms in mild to moderate Alzheimer’s disease. Neuropsychol Rehabil. 25(5): 677–707. 2015. PMID: 25312605. 10.1080/09602011.2014.964731 KQ4E8, KQ5E825312605
60 Bunt, S, O’Caoimh, R, . Validation of the Dutch version of the quick mild cognitive impairment screen (Qmci-D). BMC Geriatr. 15: 115. 2015. PMID: 26431959. 10.1186/s12877-015-0113-1 KQ2E2d26431959
61 Burns, A, Gauthier, S, . Efficacy and safety of donepezil over 3 years: an open-label, multicentre study in patients with Alzheimer’s disease. Int J Geriatr Psychiatry. 22(8): 806–812. 2007. PMID: 17199235. KQ4E2f, KQ5E2f17199235
62 Buschert, VC, Giegling, I, . Long-term observation of a multicomponent cognitive intervention in mild cognitive impairment. J Clin Psychiatry. 73(12): e1492–8. 2012. PMID: 23290333. 10.4088/JCP.11m07270 KQ4E2f, KQ5E2f23290333
63 Cabrera, AG, Pena, MC, . Early detection of cognitive disorders: Follow-up study. Can J Neurosci Nurs. 37(2): 42–6. 2015. PMID: 26647494. KQ2E7b26647494
64 Cagnin, A, Cester, A, . Effectiveness of switching to the rivastigmine transdermal patch from oral cholinesterase inhibitors: a naturalistic prospective study in Alzheimer’s disease. Neurological Sciences. 36(3): 457–63. 2015. PMID: 25394739. 10.1007/s10072-014-2002-3 KQ4E2b, KQ5E2b25394739
65 Callahan, CM, Boustani, MA, . Alzheimer’s disease multiple intervention trial (ADMIT): study protocol for a randomized controlled clinical trial. Trials [Electronic Resource]. 13: 92. 2012. PMID: 22737979. 10.1186/1745-6215-13-92 KQ4E2b, KQ5E2b22737979
66 Callahan, CM, Boustani, MA, . Targeting Functional Decline in Alzheimer Disease: A Randomized Trial. Ann Intern Med. 166(3): 164–171. 2017. PMID: 27893087. 10.7326/M16-0830 KQ4E2b, KQ5E2b27893087
67 Campbell, NL, Perkins, AJ, . Adherence and Tolerability of Alzheimer’s Disease Medications: A Pragmatic Randomized Trial. J Am Geriatr Soc. 65(7): 1497–1504. 2017. PMID: 28295141. 10.1111/jgs.14827 KQ4E2b, KQ5E2b28295141
68 Campo, Nd, Cesari, M, . Refining Mild-to-Moderate Alzheimer Disease Screening: a Tool for Clinicians. J Am Med Dir Assoc. 17(10): 913–920. 2016. 10.1016/j.jamda.2016.06.005 KQ2E127670604
69 Caramelli, P, Laks, J, . Effects of galantamine and galantamine combined with nimodipine on cognitive speed and quality of life in mixed dementia: a 24-week, randomized, placebo-controlled exploratory trial (the REMIX study). Arq Neuropsiquiatr. 72(6): 411–7. 2014. PMID: 24964105. KQ4E3a, KQ5E3a24964105
70 Carnero-Pardo, C, Cruz-Orduna, I, . Utility of the mini-cog for detection of cognitive impairment in primary care: Data from two spanish studies. Int J Alzheimers Dis. 2013. 10.1155/2013/285462 KQ2E4e
71 Carretti, B, Borella, E, . Benefits of training working memory in amnestic mild cognitive impairment: specific and transfer effects. Int Psychogeriatr. 25(4): 617–26. 2013. PMID: 23253363. 10.1017/S1041610212002177 KQ4E2b, KQ5E2b23253363
72 Cassidy-Eagle E, Siebern A, Unti L, . Neuropsychological Functioning in Older Adults with Mild Cognitive Impairment and Insomnia Randomized to CBT-I or Control Group. Clinical Gerontologist. 2018;41(2):136–44. PMID: 29220627. KQ4E1, KQ5E129220627
73 Castanho, TC, Portugal-Nunes, C, . Applicability of the Telephone Interview for Cognitive Status (Modified) in a community sample with low education level: association with an extensive neuropsychological battery. Int J Geriatr Psychiatry. 31(2): 128–36. 2016. PMID: 25963399. 10.1002/gps.4301 KQ2E7c25963399
74 Chaaya, M, Phung, TK, . Validation of the Arabic Rowland Universal Dementia Assessment Scale (A-RUDAS) in elderly with mild and moderate dementia. Aging Ment Health. 20(8): 880–7. 2016. PMID: 25984584. 10.1080/13607863.2015.1043620 KQ2E3a25984584
75 Chan, AW, Yu, DS, . Tai chi qigong as a means to improve night-time sleep quality among older adults with cognitive impairment: a pilot randomized controlled trial. Clin Interv Aging. 11(): 1277–1286. 2016. PMID: 27698557. 10.2147/CIA.S111927 KQ4E6c, KQ5E6c27698557
76 Chan, J, Churcher Clarke, A, . A Mindfulness Program Manual for People With Dementia. Behav Modif. 41(6): 764–787. 2017. PMID: 28689469. 10.1177/0145445517715872 KQ4E2a, KQ5E2a28689469
77 Chang W, Teng J. Combined application of tenuigenin and beta-asarone improved the efficacy of memantine in treating moderate-to-severe Alzheimer’s disease. Drug Des Devel Ther. 2018;12:455–62. PMID: 29551889. KQ4E3a, KQ5E3a29551889
78 Charernboon, T. Diagnostic Accuracy of the Overlapping Infinity Loops, Wire Cube, and Clock Drawing Tests for Cognitive Impairment in Mild Cognitive Impairment and Dementia. Int J Alzheimers Dis. 2017(): 5289239. 2017. PMID: 28255496. 10.1155/2017/5289239 KQ2E3a28255496
79 Charlesworth, G, Burnell, K, . Peer support and reminiscence therapy for people with dementia and their family carers: a factorial pragmatic randomised trial. J Neurol Neurosurg Psychiatry. 87(11): 1218–1228. 2016. PMID: 27521377. 10.1136/jnnp-2016-313736 KQ4E2b, KQ5E2b27521377
80 Chase, Tn, Farlow, Mr, . Donepezil Plus Solifenacin (CPC-201) Treatment for Alzheimer’s Disease. Neurotherapeutics. 1–12. 2017. 10.1007/s13311-016-0511-x KQ4E2a, KQ5E2a27933486
81 Chen SF, Liu MH, Chen NC, . Educational effects on ascertain dementia 8-item informant questionnaire to detect dementia in the Taiwanese population. International Psychogeriatrics. 2018;30(8):1189–97. PMID: 29223190. KQ2E2a29223190
82 Chen, CH, Wang, LC, . A walk-in screening of dementia in the general population in Taiwan. ScientificWorldJournal. 2014(): 243738. 2014. PMID: 24883363. 10.1155/2014/243738 KQ2E124883363
83 Chen, H, Liu, S, . Folic Acid Supplementation Mitigates Alzheimer’s Disease by Reducing Inflammation: A Randomized Controlled Trial. Mediators Inflamm. 2016(): 5912146. 2016. PMID: 27340344. 10.1155/2016/5912146 KQ4E3a, KQ5E3a27340344
84 Chen, HM, Huang, MF, . Effectiveness of coping strategies intervention on caregiver burden among caregivers of elderly patients with dementia. Psychogeriatrics:The Official Journal of the Japanese Psychogeriatric Society. 15(1): 20–5. 2015. PMID: 25515800. 10.1111/psyg.12071 KQ4E7c, KQ5E7c25515800
85 Cheng, ST, Fung, HH, . Short-Term Effects of a Gain-Focused Reappraisal Intervention for Dementia Caregivers: A Double-Blind Cluster-Randomized Controlled Trial. American Journal of Geriatric Psychiatry. 24(9): 740–50. 2016. PMID: 27401052. 10.1016/j.jagp.2016.04.012 KQ4E2b, KQ5E2b27401052
86 Chenoweth, L, Jeon, YH, . PerCEN trial participant perspectives on the implementation and outcomes of person-centered dementia care and environments. Int Psychogeriatr. 27(12): 2045–57. 2015. PMID: 26307245. 10.1017/S1041610215001350 KQ4E3b, KQ5E3b26307245
87 Chenoweth L, Stein-Parbury J, White D, . Coaching in self-efficacy improves care responses, health and well-being in dementia carers: a pre/post-test/follow-up study. BMC health services research. 2016;16(pp 166). PMID: 27146060. KQ4E2a, KQ5E2a27146060
88 Cherrier, MM, Anderson, K, . Testosterone treatment of men with mild cognitive impairment and low testosterone levels. Am J Alzheimers Dis Other Demen. 30(4): 421–30. 2015. PMID: 25392187. 10.1177/1533317514556874 KQ4E4b, KQ5E4b25392187
89 Cheung, G, Clugston, A, . Performance of three cognitive screening tools in a sample of older New Zealanders. Int Psychogeriatr. 27(6): 981–9. 2015. PMID: 25603424. 10.1017/S1041610214002889 KQ2E2d25603424
90 Cheung, Karen Siu-Lan, Lau, Bobo Hi-Po, . Multicomponent intervention on enhancing dementia caregiver well-being and reducing behavioral problems among Hong Kong Chinese: A translational study based on REACH II. Int J Geriatr Psychiatry. 30(5): 460–469. 2015. 10.1002/gps.4160 KQ4E2a, KQ5E2a25043378
91 Cheung DSK, Li B, Lai DWL, . Cognitive Stimulating Play Intervention for Dementia: A Feasibility Randomized Controlled Trial. American Journal of Alzheimer’s Disease & Other Dementias. 2018:10.1177/1533317518808036. PMID: 30370782. KQ4E2c, KQ5E2c30370782
92 Chew, J, Chong, M-S, . Outcomes of a multimodal cognitive and physical rehabilitation program for persons with mild dementia and their caregivers: A goal-oriented approach. Clin Interv Aging. 10(): 1687–94. 2015. 10.2147/CIA.S93914 KQ4E2a, KQ5E2a26543358
93 Chhetri JK, de Souto Barreto P, Cantet C, . Effects of a 3-year multi-domain intervention with or without omega-3 supplementation on cognitive functions in older subjects with increased CAIDE dementia scores. Journal of Alzheimer’s Disease. 2018;64(1):71–8. PMID: 29865075. KQ4E1b, KQ5E1b29865075
94 Choe, JY, Han, JW, . A new scoring method of the mini-mental status examination to screen for dementia. Dement Geriatr Cogn Disord. 37(5–6): 347–56. 2014. 10.1159/000357471 KQ2E2d24503547
95 Choi, SH, Park, MH. Three screening methods for cognitive dysfunction using the Mini-Mental State Examination and Korean Dementia Screening Questionnaire. Geriatr Gerontol Int. 16(2): 252–8. 2016. PMID: 25655174. 10.1111/ggi.12464 KQ2E2d25655174
96 Chopard, G, Puyraveau, M, . Spectrum Effect and Spectrum Bias in the Screening Test Performance for Amnestic Mild Cognitive Impairment: What are the Clinical Implications?. J Alzheimers Dis. 48(2): 385–93. 2015. PMID: 26402002. 10.3233/JAD-150195 KQ2E3c26402002
97 Christie J. Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) for the Early Diagnosis of Dementia Across a Variety of Healthcare Settings. Issues in Mental Health Nursing. 2018;39(5):445–6. PMID: 29775136. KQ2E2a29775136
98 Clare, L, Linden, DE, . Goal-oriented cognitive rehabilitation for people with early-stage Alzheimer disease: a single-blind randomized controlled trial of clinical efficacy. Am J Geriatr Psychiatry. 18(10): 928–939. 2010. PMID: 20808145. KQ4E6c, KQ5E6c20808145
99 Clarfield, AM, Dwolatzky, T. Exercise in Alzheimer disease: comment on “Effects of the Finnish Alzheimer disease exercise trial (FINALEX): a randomized controlled trial”. JAMA Intern Med. 173(10): 901–2. 2013. PMID: 23588877. 10.1001/jamainternmed.2013.1215 KQ4E5, KQ5E523588877
100 Clarke, R, Harrison, G, . Effect of vitamins and aspirin on markers of platelet activation, oxidative stress and homocysteine in people at high risk of dementia. J Intern Med. 254(1): 67–75. 2003. PMID: 12823643. KQ4E2b, KQ5E2b12823643
101 Clarnette, R, O’Caoimh, R, . Comparison of the Quick Mild Cognitive Impairment (Qmci) screen to the Montreal Cognitive Assessment (MoCA) in an Australian geriatrics clinic. Int J Geriatr Psychiatry. 32(6): 643–649. 2017. PMID: 27427212. 10.1002/gps.4505 KQ2E2d27427212
102 Coelho, FG, Andrade, LP, . Multimodal exercise intervention improves frontal cognitive functions and gait in Alzheimer’s disease: a controlled trial. Geriatr Gerontol Int. 13(1): 198–203. 2013. PMID: 22686565. 10.1111/j.1447-0594.2012.00887.x KQ4E3a, KQ5E3a22686565
103 Collaborative Group AD, Bentham, P, Gray, . Aspirin in Alzheimer’s disease (AD2000): a randomised open-label trial. Lancet Neurol. 7(1): 41–9. 2008. PMID: 18068522. 10.1016/S1474-4422(07)70293-4 KQ4E2a, KQ5E2a18068522
104 Coley N, Raman R, Donohue MC, . Defining the Optimal Target Population for Trials of Polyunsaturated Fatty Acid Supplementation Using the Erythrocyte Omega-3 Index: A Step Towards Personalized Prevention of Cognitive Decline? Journal of Nutrition, Health & Aging. 2018;22(8):982–98. PMID: 30272103. KQ4E1b, KQ5E1b30272103
105 Connon, P, Larner, AJ. Six-item Cognitive Impairment Test (6CIT): diagnostic test accuracy study in primary care referrals. Int J Geriatr Psychiatry. 32(5): 583–584. 2017. PMID: 28379632. 10.1002/gps.4692 KQ2E3c28379632
106 Cooper, C, Barber, J, . Effectiveness of START psychological intervention in reducing abuse by dementia family carers: randomized controlled trial. Int Psychogeriatr. 28(6): 881–7. 2016. PMID: 26652193. 10.1017/S1041610215002033 KQ4E5, KQ5E526652193
107 Cornelis, E, Gorus, E, . Early diagnosis of mild cognitive impairment and mild dementia through basic and instrumental activities of daily living: Development of a new evaluation tool. PLoS Medicine / Public Library of Science. 14(3): e1002250. 2017. PMID: 28291801. 10.1371/journal.pmed.1002250 KQ2E2d28291801
108 Cothran, FA, Paun, O, . Comparing the Effect of a Moderate Physical Activity Intervention on the Mental Health Outcomes of African American and Caucasian Dementia Family Caregivers: A Secondary Data Analysis. Issues Ment Health Nurs. 1–9. 2017. PMID: 28956706. 10.1080/01612840.2017.1364807 KQ4E2b, KQ5E2b27937078
109 Cotroneo, AM, Castagna, A, . Effectiveness and safety of citicoline in mild vascular cognitive impairment: the IDEALE study. Clin Interv Aging. 8(): 131–7. 2013. PMID: 23403474. 10.2147/CIA.S38420 KQ4E7c, KQ5E7c23403474
110 Courtney, C, Farrell, D, . Long-term donepezil treatment in 565 patients with Alzheimer’s disease (AD2000): randomised double-blind trial. Lancet. 363(9427): 2105–2115. 2004. PMID: 15220031. KQ4E2a, KQ5E2a15220031
111 Creavin, S, Fish, M, . Clinical history for diagnosis of dementia in men: Caerphilly Prospective Study. Br J Gen Pract. 65(637): e489–99. 2015. PMID: 26212844. 10.3399/bjgp15X686053 KQ2E126212844
112 Cuc, AV, Locke, DE, . A pilot randomized trial of two cognitive rehabilitation interventions for mild cognitive impairment: caregiver outcomes. Int J Geriatr Psychiatry. 2017. PMID: 28233343. 10.1002/gps.4689 KQ4E7c, KQ5E7c28233343
113 Cummings, JL, Farlow, MR, . Rivastigmine transdermal patch skin tolerability: results of a 1-year clinical trial in patients with mild-to-moderate Alzheimer’s disease. Clin Drug Invest. 30(1): 41–49. 2010. PMID: 19995097. KQ4E2f, KQ5E2f19995097
114 Curiel, RE, Crocco, E, . A Brief Computerized Paired Associate Test for the Detection of Mild Cognitive Impairment in Community-Dwelling Older Adults. J Alzheimers Dis. 54(2): 793–9. 2016. PMID: 27567839. 10.3233/JAD-160370 KQ2E3c27567839
115 Custodio, N, Lira, D, . The Memory Alteration Test Discriminates between Cognitively Healthy Status, Mild Cognitive Impairment and Alzheimer’s Disease. Dement Geriatr Cogn Dis Extra. 4(2): 314–21. 2014. PMID: 25298775. 10.1159/000365280 KQ2E2d25298775
116 Danthiir V, Hosking DE, Nettelbeck T, . An 18-mo randomized, double-blind, placebo-controlled trial of DHA-rich fish oil to prevent age-related cognitive decline in cognitively normal older adults. American Journal of Clinical Nutrition. 2018;107(5):754–62. PMID: 29722833. KQ4E1b, KQ5E1b29722833
117 Da Re, F, Rucci, F, . Retrospective study on agitation provoked by memantine in dementia. Journal of Neuropsychiatry & Clinical Neurosciences. 27(1): e10–3. 2015. PMID: 25254933. 10.1176/appi.neuropsych.13100226 KQ4E2e, KQ5E2e25254933
118 Damirchi, A, Hosseini, F, . Mental Training Enhances Cognitive Function and BDNF More Than Either Physical or Combined Training in Elderly Women With MCI: A Small-Scale Study. Am J Alzheimers Dis Other Demen. 1533317517727068. 2017. PMID: 28946752. 10.1177/1533317517727068 KQ4E3a, KQ5E3a28946752
119 Davis, JC, Bryan, S, . An economic evaluation of resistance training and aerobic training versus balance and toning exercises in older adults with mild cognitive impairment. PLoS ONE [Electronic Resource]. 8(5): e63031. 2013. PMID: 23690976. 10.1371/journal.pone.0063031 KQ4E5, KQ5E523690976
120 de Andrade, LP, Gobbi, LT, . Benefits of multimodal exercise intervention for postural control and frontal cognitive functions in individuals with Alzheimer’s disease: a controlled trial. J Am Geriatr Soc. 61(11): 1919–26. 2013. PMID: 24219193. 10.1111/jgs.12531 KQ4E3a, KQ5E3a24219193
121 de Gobbi Porto, FH, Spindola, L, . A score based on screening tests to differentiate mild cognitive impairment from subjective memory complaints. Neurol Int. 5(3): e16. 2013. PMID: 24147213. 10.4081/ni.2013.e16 KQ2E4e24147213
122 De la Torre, GG, Suarez-Llorens, A, . Norms and reliability for the Spanish version of the Repeatable Battery for the Assessment of Neuropsychological Status (RBANS) Form A. Journal of Clinical & Experimental Neuropsychology: Official Journal of the International Neuropsychological Society. 36(10): 1023–30. 2014. PMID: 25363544. 10.1080/13803395.2014.965664 KQ2E2d25363544
123 de Oliveira AM, Radanovic M, Homem de Mello PC, . An intervention to reduce neuropsychiatric symptoms and caregiver burden in dementia: Preliminary results from a randomized trial of the tailored activity program-outpatient version. Int J Geriatr Psychiatry. 2018. PMID: 30035341. KQ4E3a, KQ5E3a30035341
124 De Vriendt, P, Mets, T, . Discriminative power of the advanced activities of daily living (a-ADL) tool in the diagnosis of mild cognitive impairment in an older population. Int Psychogeriatr. 27(9): 1419–27. 2015. PMID: 25901578. 10.1017/S1041610215000563 KQ2E2d25901578
125 DeGregory, Cristy. The effects of multiple gratitude interventions among informal caregivers of persons with dementia and Alzheimer’s disease. 148 p. 2014. KQ4E2c, KQ5E2c
126 Del Brutto, OH, Wright, C. Animal naming in the Spanish version of the Montreal Cognitive Assessment in rural Latin American communities: a cautionary note. Geriatr Gerontol Int. 15(1): 126–7. 2015. PMID: 25583395. 10.1111/ggi.12223 KQ2E125583395
127 Delgado, C, Munoz-Neira, C, . Comparison of the Psychometric Properties of the “Word” and “Picture” Versions of the Free and Cued Selective Reminding Test in a Spanish-Speaking Cohort of Patients with Mild Alzheimer’s Disease and Cognitively Healthy Controls. Archives of Clinical Neuropsychology. 31(2): 165–75. 2016. PMID: 26758367. 10.1093/arclin/acv107 KQ2E2d26758367
128 Dimitriou TD, Verykouki E, Papatriantafyllou J, . Non-pharmacological interventions for agitation/aggressive behaviour in patients with dementia: a randomized controlled crossover trial. Functional Neurology. 2018;33(3):143–7. PMID: 30457967. KQ4E2c, KQ5E2c30457967
129 DiZazzo-Miller R, Winston K, Winkler SL, . Family Caregiver Training Program (FCTP): A randomized controlled trial. Am J Occup Ther. 2017;71(5):1–10. PMID: 28809654. KQ4E5, KQ5E528809654
130 Dong, Y, Pang, WS, . The informant AD8 is superior to participant AD8 in detecting cognitive impairment in a memory clinic setting. J Alzheimers Dis. 35(1): 159–68. 2013. PMID: 23380993. 10.3233/JAD-122026 KQ2E2d23380993
131 Doody, RS, Ferris, S, . Safety and tolerability of donepezil in mild cognitive impairment: open-label extension study. Am J Alzheimers Dis Other Demen. 25(2): 155–159. 2010. PMID: 19949165. KQ4E2f, KQ5E2f19949165
132 dos Santos Moraes, W, Poyares, DR, . The effect of donepezil on sleep and REM sleep EEG in patients with Alzheimer disease: a double-blind placebo-controlled study. Sleep. 29(2): 199–205. 2006. PMID: 16494088. KQ4E3a, KQ5E3a16494088
133 Doyon Dolinar, RM, Pleta, BA, . MoCA cutoff score in relation to the functional assessment of seniors living in a rural Canadian community. Canadian Journal of Rural Medicine. 21(4): 101–6. 2016. PMID: 27627210. KQ2E7b27627210
134 D’Souza, MF, Davagnino, J, . Preliminary Data from the Caring for Older Adults and Caregivers at Home (COACH) Program: A Care Coordination Program for Home-Based Dementia Care and Caregiver Support in a Veterans Affairs Medical Center. J Am Geriatr Soc. 63(6): 1203–8. 2015. PMID: 26032224. 10.1111/jgs.13448 KQ4E2a, KQ5E2a26032224
135 Dunn, NR, Pearce, GL, . Adverse effects associated with the use of donepezil in general practice in England. J Psychopharmacol. 14(4): 406–408. 2000. PMID: 11198060. KQ5E2f11198060
136 Eichler, T, Thyrian, JR, . Patient Variables Associated with the Assignment of a Formal Dementia Diagnosis to Positively Screened Primary Care Patients. Curr Alzheimer Res. 2017. PMID: 28891445. 10.2174/1567205014666170908095707 KQ1E2a, KQ3E2a28891445
137 Eichler, T, Thyrian, JR, . Rates of formal diagnosis of dementia in primary care: The effect of screening. Alzheimer’s & Dementia : Diagnosis, Assessment & Disease Monitoring. 1(1): 87–93. 2015. PMID: 27239495. 10.1016/j.dadm.2014.11.007 KQ1E2a, KQ3E2a27239495
138 Eichler, T, Thyrian, JR, . Subjective memory impairment: No suitable criteria for case-finding of dementia in primary care. Alzheimer’s & Dementia : Diagnosis, Assessment & Disease Monitoring. 1(2): 179–86. 2015. PMID: 27239503. 10.1016/j.dadm.2015.02.004 KQ2E7b27239503
139 Eichler, T, Thyrian, JR, . The benefits of implementing a computerized intervention-management-system (IMS) on delivering integrated dementia care in the primary care setting. Int Psychogeriatr. 26(8): 1377–85. 2014. PMID: 24811145. 10.1017/S1041610214000830 KQ4E5, KQ5E524811145
140 Eleni P, Fotini K, Christina A, . Use it more and keep it alive: a Longitudinal Randomized Controlled Trial in people with Mild Cognitive Impairment. Hellenic J Nucl Med. 2017;20:218–32. KQ4E7c, KQ5E7c
141 Emsaki G, NeshatDoost HT, Tavakoli M, . Memory specificity training can improve working and prospective memory in amnestic mild cognitive impairment. Dementia & neuropsychologia. 2017;11(3):255–61. PMID: 29213522. KQ4E3a, KQ5E3a29213522
142 Eriksdotter, M, Vedin, I, . Plasma Fatty Acid Profiles in Relation to Cognition and Gender in Alzheimer’s Disease Patients During Oral Omega-3 Fatty Acid Supplementation: The OmegAD Study. J Alzheimers Dis. 48(3): 805–12. 2015. PMID: 26402079. 10.3233/JAD-150102 KQ4E5, KQ5E526402079
143 Evans S, Evans S, Brooker D, . The impact of the implementation of the Dutch combined Meeting Centres Support Programme for family caregivers of people with dementia in Italy, Poland and UK. Aging Ment Health. 2018:1–11. PMID: 30520312. KQ4E2a, KQ5E2a30520312
144 Eyre, HA, Siddarth, P, . A randomized controlled trial of Kundalini yoga in mild cognitive impairment. Int Psychogeriatr. 29(4): 557–567. 2017. PMID: 28088925. 10.1017/S1041610216002155 KQ4E2b, KQ5E2b28088925
145 Eyre, HarrisA, Acevedo, Bianca, . Changes in neural connectivity and memory following a yoga intervention for older adults: A pilot study. J Alzheimers Dis. 52(2): 673–684. 2016. 10.3233/JAD-150653 KQ4E2b, KQ5E2b27060939
146 Farlow, MR, Alva, G, . A 25-week, open-label trial investigating rivastigmine transdermal patches with concomitant memantine in mild-to-moderate Alzheimer’s disease: a post hoc analysis. Curr Med Res Opin. 26(2): 263–9. 2010. PMID: 19929593. 10.1185/03007990903434914 KQ4E7c, KQ5E7c19929593
147 Farran CJ, Paun O, Cothran F, . Impact of an Individualized Physical Activity Intervention on Improving Mental Health Outcomes in Family Caregivers of Persons with Dementia: A Randomized Controlled Trial. AIMS med. 2016;3(1):15–31. PMID: 29147683. KQ4E2b, KQ5E2b29147683
148 Feng, H, Li, G, . Training Rehabilitation as an Effective Treatment for Patients with Vascular Cognitive Impairment with No Dementia. Rehabilitation Nursing Journal. 27(): 27. 2016. PMID: 27118716. 10.1002/rnj.271 KQ4E3a, KQ5E3a27118716
149 Ferreira, L, Tanaka, K, . Respiratory training as strategy to prevent cognitive decline in aging: a randomized controlled trial. Clin Interv Aging. 10(): 593–603. 2015. PMID: 25848235. 10.2147/CIA.S79560 KQ4E1b, KQ5E1b25848235
150 Ferris, S, Cummings, J, . Effects of donepezil 23 mg on Severe Impairment Battery domains in patients with moderate to severe Alzheimer’s disease: Evaluating the impact of baseline severity. Alzheimers Res Ther. 5(1). 2013. 10.1186/alzrt166 KQ4E2b, KQ5E2b
151 Fis, T, Thyrian, JR, . Medication management for people with dementia in primary care: description of implementation in the DelpHi study. BMC Geriatr. 13(): 121. 2013. PMID: 24225205. 10.1186/1471-2318-13-121 KQ4E5, KQ5E524225205
152 Fish, M, Bayer, AJ, . Prevalence and pattern of cognitive impairment in a community cohort of men in South Wales: methodology and findings from the Caerphilly Prospective Study. Neuroepidemiology. 30(1): 25–33. 2008. PMID: 18259098. 10.1159/000115439 KQ4E8, KQ5E818259098
153 Forette, F, Anand, R, . A phase II study in patients with Alzheimer’s disease to assess the preliminary efficacy and maximum tolerated dose of rivastigmine (Exelon). Eur J Neurol. 6(4): 423–9. 1999. PMID: 10362894. KQ4E7c, KQ5E7c10362894
154 Forstl, H, Stamouli, SS, . Memantine in everyday clinical practice: a comparison of studies in Germany and Greece. Dement Geriatr Cogn Disord. 32(4): 267–272. 2011. PMID: 22237255. KQ5E2f22237255
155 Fosbol, EL, Peterson, ED, . Comparative Cardiovascular Safety of Dementia Medications: A Cross-National Study. J Am Geriatr Soc. 2012. PMID: 23176182. KQ5E2f23176182
156 Freitas, S, Prieto, G, . Psychometric properties of the Montreal Cognitive Assessment (MoCA): an analysis using the Rasch model. Clinical Neuropsychologist. 28(1): 65–83. 2014. PMID: 24404822. 10.1080/13854046.2013.870231 KQ2E124404822
157 Froelich, L, Andreasen, N, . Long-term treatment of patients with Alzheimer’s disease in primary and secondary care: results from an international survey. Curr Med Res Opin. 25(12): 3059–3068. 2009. PMID: 19852697. KQ5E2f19852697
158 Fung AW, Lam LCW. Validation of a computerized Hong Kong - vigilance and memory test (HK-VMT) to detect early cognitive impairment in healthy older adults. Aging Ment Health. 2018:1–7. PMID: 30270640. KQ2E2d30270640
159 Gaitan, A, Garolera, M, . Efficacy of an adjunctive computer-based cognitive training program in amnestic mild cognitive impairment and Alzheimer’s disease: a single-blind, randomized clinical trial. Int J Geriatr Psychiatry. 28(1): 91–9. 2013. PMID: 22473855. 10.1002/gps.3794 KQ4E2b, KQ5E2b22473855
160 Galetta, KM, Chapman, KR, . Screening Utility of the King-Devick Test in Mild Cognitive Impairment and Alzheimer Disease Dementia. Alzheimer Dis Assoc Disord. 31(2): 152–158. 2017. PMID: 27299935. 10.1097/WAD.0000000000000157 KQ2E2d27299935
161 Gallagher-Thompson, D, Tzuang, M, . Effectiveness of a fotonovela for reducing depression and stress in Latino dementia family caregivers. Alzheimer Dis Assoc Disord. 29(2): 146–53. 2015. PMID: 25590939. 10.1097/WAD.0000000000000077 KQ4E7c, KQ5E7c25590939
162 Galvin, JE. IMPROVING THE CLINICAL DETECTION OF LEWY BODY DEMENTIA WITH THE LEWY BODY COMPOSITE RISK SCORE. Alzheimers Dement (Amst). 1(3): 316–324. 2015. PMID: 26405688. 10.1016/j.dadm.2015.05.004 KQ2E3c26405688
163 Garcia-Alberca, Jm. Cognitive-behavioral treatment for depressed patients with Alzheimer’s disease. An open trial. Arch Gerontol Geriatr. 71(): 1–8. 2017. 10.1016/j.archger.2017.02.008 KQ4E2a, KQ5E2a28237746
164 Garcia-Campuzano, Mari Tere, Virues-Ortega, Javier, . Effect of cognitive training targeting associative memory in the elderly: A small randomized trial and a longitudinal evaluation. J Am Geriatr Soc. 61(12): 2252–2254. 2013. 10.1111/jgs.12574 KQ4E1b, KQ5E1b24329837
165 Gareri, P, Castagna, A, . The Citicholinage Study: citicoline Plus Cholinesterase Inhibitors in Aged Patients Affected with Alzheimer’s Disease Study. J Alzheimers Dis. 56(2): 557–565. 2017. 10.3233/JAD-160808 KQ4E2a, KQ5E2a28035929
166 Gaugler, JE, Reese, M, . A Pilot Evaluation of Psychosocial Support for Family Caregivers of Relatives with Dementia in Long-Term Care: The Residential Care Transition Module. Res Gerontol Nurs. 8(4): 161–72. 2015. PMID: 25751083. 10.3928/19404921-20150304-01 KQ4E3b, KQ5E3b25751083
167 Gaugler, JE, Roth, DL, . Can counseling and support reduce burden and depressive symptoms in caregivers of people with Alzheimer’s disease during the transition to institutionalization? Results from the New York University caregiver intervention study. J Am Geriatr Soc. 56(3): 421–428. 2008. PMID: 18179495. KQ4E8, KQ5E818179495
168 Gauthier, S, Robillard, A, . Real-life effectiveness and tolerability of the rivastigmine transdermal patch in patients with mild-to-moderate Alzheimer’s disease: the EMBRACE study. Curr Med Res Opin. 29(8): 989–1000. 2013. PMID: 23647369. 10.1185/03007995.2013.802230 KQ4E2a, KQ5E2a23647369
169 Georgakis, MK, Papadopoulos, FC, . Validation of TICS for detection of dementia and mild cognitive impairment among individuals characterized by low levels of education or illiteracy: a population-based study in rural Greece. Clin Neuropsychol. 1–11. 2017. PMID: 28569607. 10.1080/13854046.2017.1334827 KQ2E7c28569607
170 Gerdner, LA, Buckwalter, KC, . Impact of a psychoeducational intervention on caregiver response to behavioral problems. Nurs Res. 51(6): 363–374. 2002. 10.1097/00006199-200211000-00004 KQ4E7c, KQ5E7c12464756
171 Gildengers, ArielG, Butters, MerylA, . Design and implementation of an intervention development study: Retaining Cognition while Avoiding Late-Life Depression (ReCALL). The American Journal of Geriatric Psychiatry. 24(6): 444–454. 2016. 10.1016/j.jagp.2015.10.010 KQ4E5, KQ5E527066730
172 Giovagnoli, A, Manfredi, V, . Cognitive training in Alzheimer’s disease: A controlled randomized study. Neurological Sciences. 38(8): 1485–1493. 2017. 10.1007/s10072-017-3003-9 KQ4E2b, KQ5E2b28577267
173 Giuli, C, Papa, R, . The Effects of Cognitive Training for Elderly: Results from My Mind Project. Rejuvenation Res. 19(6): 485–494. 2016. PMID: 26952713. 10.1089/rej.2015.1791 KQ4E2c, KQ5E2c26952713
174 Goldstein, FC, Ashley, AV, . Validity of the montreal cognitive assessment as a screen for mild cognitive impairment and dementia in African Americans. J Geriatr Psychiatry Neurol. 27(3): 199–203. 2014. PMID: 24614202. 10.1177/0891988714524630 KQ2E3c24614202
175 Gonyea, JG, Lopez, LM, . The Effectiveness of a Culturally Sensitive Cognitive Behavioral Group Intervention for Latino Alzheimer’s Caregivers. Gerontologist. 56(2): 292–302. 2016. PMID: 24855313. 10.1093/geront/gnu045 KQ4E2b, KQ5E2b24855313
176 Gonzalez, Ew, Polansky, M, . Enhancing resourcefulness to improve outcomes in family caregivers and persons with Alzheimer’s disease: A pilot randomized trial. Int J Alzheimers Dis. 2014. 10.1155/2014/323478 KQ4E7c, KQ5E7c
177 Gonzalez-Palau, F, Franco, M, . Clinical utility of the hopkins Verbal Test-Revised for detecting Alzheimer’s disease and mild cognitive impairment in Spanish population. Archives of Clinical Neuropsychology. 28(3): 245–53. 2013. PMID: 23384601. 10.1093/arclin/act004 KQ2E3c23384601
178 Gonzalez-Palau, Fatima, Franco, Manuel, . The effects of a computer-based cognitive and physical training program in a healthy and mildly cognitive impaired aging sample. Aging Ment Health. 18(7): 838–846. 2014. 10.1080/13607863.2014.899972 KQ4E2a, KQ5E2a24697325
179 Gooding, AL, Choi, J, . Comparing three methods of computerised cognitive training for older adults with subclinical cognitive decline. Neuropsychol Rehabil. 26(5–6): 810–21. 2016. PMID: 26674122. 10.1080/09602011.2015.1118389 KQ4E2b, KQ5E2b26674122
180 Goudsmit M, van Campen J, Schilt T, . One Size Does Not Fit All: Comparative Diagnostic Accuracy of the Rowland Universal Dementia Assessment Scale and the Mini Mental State Examination in a Memory Clinic Population with Very Low Education. Dement Geriatr Cogn Dis Extra. 2018;8(2):290–305. PMID: 30323830. KQ2E4e30323830
181 Grober, E, Ehrlich, AR, . Screening older Latinos for dementia in the primary care setting. Journal of the International Neuropsychological Society. 20(8): 848–55. 2014. PMID: 25120108. 10.1017/S1355617714000708 KQ2E825120108
182 Grober, E, Hall, C, . Free and cued selective reminding distinguishes Alzheimer’s disease from vascular dementia. J Am Geriatr Soc. 56(5): 944–6. 2008. PMID: 18454754. 10.1111/j.1532-5415.2008.01652.x KQ2E818454754
183 Grober, E, Hall, C, . Neuropsychological strategies for detecting early dementia. J Int Neuropsychol Soc. 14(1): 130–142. 2008. PMID: 18078539. KQ2E7c18078539
184 Grober, E, Mowrey, WB, . Two-stage screening for early dementia in primary care. Journal of Clinical & Experimental Neuropsychology: Official Journal of the International Neuropsychological Society. 38(9): 1038–49. 2016. PMID: 27270103. 10.1080/13803395.2016.1187117 KQ2E7c27270103
185 Grober, E, Ocepek-Welikson, K, . The Free and Cued Selective Reminding Test: Evidence of Psychometric Adequacy. Psychol Sci Q. 51(): 266–282. 2009. PMID: None. KQ2E8
186 Grober, E, Sanders, AE, . Free and cued selective reminding identifies very mild dementia in primary care. Alzheimer Dis Assoc Disord. 24(3): 284–290. 2010. 10.1097/WAD.0b013e3181cfc78b KQ2E820683186
187 Grober, E, Wakefield, D, . Identifying memory impairment and early dementia in primary care. Alzheimer’s & Dementia : Diagnosis, Assessment & Disease Monitoring. 6(): 188–195. 2017. PMID: 28289701. 10.1016/j.dadm.2017.01.006 KQ2E7c28289701
188 Grober, E. Screening for early dementia. Geriatr Aging. 11(7): 405–409. 2008. PMID: None. KQ2E2a
189 Gross, AL, Jones, RN, . Calibration and validation of an innovative approach for estimating general cognitive performance. Neuroepidemiology. 42(3): 144–53. 2014. PMID: 24481241. 10.1159/000357647 KQ2E6a24481241
190 Grossberg, G, Sadowsky, C, . Safety and tolerability of the rivastigmine patch: results of a 28-week open-label extension. Alzheimer Dis Assoc Disord. 23(2): 158–164. 2009. PMID: 19484917. KQ4E2f, KQ5E2f19484917
191 Grossberg, GT, Manes, F, . The safety, tolerability, and efficacy of once-daily memantine (28 mg): a multinational, randomized, double-blind, placebo-controlled trial in patients with moderate-to-severe Alzheimer’s disease taking cholinesterase inhibitors. CNS Drugs. 27(6): 469–78. 2013. PMID: 23733403. 10.1007/s40263-013-0077-7 KQ4E4c, KQ5E4c23733403
192 Habiger, Tf, Flo, E, . The Interactive Relationship between Pain, Psychosis, and Agitation in People with Dementia: results from a Cluster-Randomised Clinical Trial. Behav Neurol. 2016. 2016. 10.1155/2016/7036415 KQ4E6b, KQ5E6b
193 Hager, K, Baseman, As, . Effect of concomitant use of memantine on mortality and efficacy outcomes of galantamine-treated patients with Alzheimer’s disease: post-hoc analysis of a randomized placebo-controlled study. Alzheimers Res Ther. 8(1): 1–10. 2016. 10.1186/s13195-016-0214-x KQ4E2a, KQ5E2a26776763
194 Hagovska, M, Dzvonik, O, . Comparison of Two Cognitive Training Programs With Effects on Functional Activities and Quality of Life. Res Gerontol Nurs. 10(4): 172–180. 2017. 10.3928/19404921-20170524-01 KQ4E2b, KQ5E2b28556876
195 Hagovska, M, Olekszyova, Z. Relationships between balance control and cognitive functions, gait speed, and activities of daily living. Z Gerontol Geriatr. 49(5): 379–85. 2016. PMID: 26458911. 10.1007/s00391-015-0955-3 KQ4E2b, KQ5E2b26458911
196 Hagovska, M, Takac, P, . Effect of a combining cognitive and balanced training on the cognitive, postural and functional status of seniors with a mild cognitive deficit in a randomized, controlled trial. European journal of physical & rehabilitation medicine. 52(1): 101–9. 2016. PMID: 26325026. KQ4E2c, KQ5E2c26325026
197 Hagovska, Magdalena, Nagyova, Iveta. The transfer of skills from cognitive and physical training to activities of daily living: A randomised controlled study. Eur J Ageing. 14(2): 133–142. 2017. 10.1007/s10433-016-0395-y KQ4E2b, KQ5E2b28804398
198 Hajjar, I, Hart, M, . Effect of antihypertensive therapy on cognitive function in early executive cognitive impairment: a double-blind randomized clinical trial. Arch Intern Med. 172(5): 442–4. 2012. PMID: 22412114. 10.1001/archinternmed.2011.1391 KQ4E2b, KQ5E2b22412114
199 Hamrick, I, Hafiz, R, . Use of days of the week in a modified mini-mental state exam (M-MMSE) for detecting geriatric cognitive impairment. Journal of the American Board of Family Medicine: JABFM. 26(4): 429–35. 2013. PMID: 23833158. 10.3122/jabfm.2013.04.120300 KQ2E7b23833158
200 Han, HR, Park, SY, . Feasibility and validity of dementia assessment by trained community health workers based on Clinical Dementia Rating. J Am Geriatr Soc. 61(7): 1141–5. 2013. PMID: 23730928. 10.1111/jgs.12309 KQ2E123730928
201 Han, JW, Lee, H, . Multimodal Cognitive Enhancement Therapy for Patients with Mild Cognitive Impairment and Mild Dementia: A Multi- Center, Randomized, Controlled, Double-Blind, Crossover Trial. J Alzheimers Dis. 55(2): 787–796. 2017. PMID: 27802233. 10.3233/JAD-160619 KQ4E2c, KQ5E2c27802233
202 Han JW, Son KL, Byun HJ, . Efficacy of the Ubiquitous Spaced Retrieval-based Memory Advancement and Rehabilitation Training (USMART) program among patients with mild cognitive impairment: a randomized controlled crossover trial. Alzheimers Res Ther. 2017;9(1):39. PMID: 28587629. KQ4E2c, KQ5E2c28587629
203 Hanson, Lc, Zimmerman, S, . Effect of the Goals of Care Intervention for Advanced Dementia: a Randomized Clinical Trial. JAMA Intern Med. 177(1): 24–31. 2017. PMID: Pubmed 27893884. 10.1001/jamainternmed.2016.7031 KQ4E3b, KQ5E3b27893884
204 Harris, JonathanB, Johnson, C. The impact of physical versus social activity on the physical and cognitive functioning of seniors with dementia. Act Adapt Aging. 41(2): 161–174. 2017. 10.1080/01924788.2017.1306383 KQ4E3b, KQ5E3b
205 Hattink, B, Meiland, F, . Web-Based STAR E-Learning Course Increases Empathy and Understanding in Dementia Caregivers: Results from a Randomized Controlled Trial in the Netherlands and the United Kingdom. J Med Internet Res. 17(10): e241. 2015. PMID: 26519106. 10.2196/jmir.4025 KQ4E1, KQ5E126519106
206 Hebert, R, Leclerc, G, . Efficacy of a support group programme for care-givers of demented patients in the community: a randomized controlled trial. Arch Gerontol Geriatr. 18(1): 1–14. 1994. PMID: 15374309. KQ4E7c, KQ5E7c15374309
207 Helmes, E. Cognitive screening of older adults: the utility of pentagon drawing. Int Psychogeriatr. 25(3): 413–9. 2013. PMID: 23194975. 10.1017/S1041610212001998 KQ2E123194975
208 Hessler, J, Bronner, M, . Suitability of the 6CIT as a screening test for dementia in primary care patients. Aging Ment Health. 18(4): 515–20. 2014. PMID: 24256425. 10.1080/13607863.2013.856864 KQ2E7b24256425
209 Heymann P, Gienger R, Hett A, . Early detection of Alzheimer’s disease based on the patient’s creative drawing process: First results with a novel neuropsychological testing method. Journal of Alzheimer’s Disease. 2018;63(2):675–87. PMID: 29689720. KQ2E2d29689720
210 Hilsabeck, RC, Holdnack, JA, . The Brief Cognitive Status Examination (BCSE): Comparing Diagnostic Utility and Equating Scores to the Mini-Mental State Examination (MMSE). Archives of Clinical Neuropsychology. 30(5): 458–67. 2015. PMID: 26085478. 10.1093/arclin/acv037 KQ2E4e26085478
211 Hinchliffe, AC, Hyman, IL, . Behavioural complications of dementia-Can they be treated?. Int J Geriatr Psychiatry. 10(10): 839–847. 1995. PMID: None. KQ4E6c, KQ5E6c
212 Hsu, CL, Best, JR, . Aerobic exercise promotes executive functions and impacts functional neural activity among older adults with vascular cognitive impairment. Br J Sports Med. 2017. PMID: 28432077. 10.1136/bjsports-2016-096846 KQ4E5, KQ5E528432077
213 Huang, HL, Shyu, YI, . A pilot study on a home-based caregiver training program for improving caregiver self-efficacy and decreasing the behavioral problems of elders with dementia in Taiwan. Int J Geriatr Psychiatry. 18(4): 337–345. 2003. PMID: 12673611. KQ4E5, KQ5E512673611
214 Hwang, Ty, Ahn, Is, . Efficacy of galantamine on cognition in mild-to-moderate Alzheimer’s dementia after failure to respond to Donepezil. Psychiatry Investig. 13(3): 341–8. 2016. 10.4306/pi.2016.13.3.341 KQ4E2a, KQ5E2a
215 Ilhan Algin, D, Dagli Atalay, S, . Memantine improves semantic memory in patients with amnestic mild cognitive impairment: A single-photon emission computed tomography study. J Int Med Res. 300060517715166. 2017. PMID: 28661262. 10.1177/0300060517715166 KQ4E3a, KQ5E3a28661262
216 Iwamoto, T, Hanyu, H, . Newly developed comprehensive geriatric assessment initiative “Dr. SUPERMAN” as a convenient screening test. Geriatr Gerontol Int. 13(3): 811–2. 2013. PMID: 23819635. 10.1111/ggi.12038 KQ2E523819635
217 Jahn, DanielleR, Dressel, JeffreyA, . An item response theory analysis of the Executive Interview and development of the EXIT8: A Project FRONTIER Study. J Clin Exp Neuropsychol. 37(3): 229–242. 2015. 10.1080/13803395.2014.1002757 KQ2E4a25748691
218 Jedrziewski MK, Meekins D, Gorka SA, . Feasibility of a Randomized Controlled Trial to Test the Impact of African Dance on Cognitive Function and Risk of Dementia: the REACT! Study. Journal of Mental Health & Clinical Psychology. 2018;2(1):12–3. PMID: 30320308. KQ4E2a, KQ5E2a30320308
219 Jelcic, N, Agostini, M, . Feasibility and efficacy of cognitive telerehabilitation in early Alzheimer’s disease: a pilot study. Clin Interv Aging. 9(): 1605–11. 2014. PMID: 25284993. 10.2147/CIA.S68145 KQ4E7c, KQ5E7c25284993
220 Jhoo, JH, Chi, YK, . A normative study of the disability assessment for dementia in community-dwelling elderly koreans. Psychiatry Investig. 11(4): 446–53. 2014. PMID: 25395976. 10.4306/pi.2014.11.4.446 KQ2E6a25395976
221 Jia, Jianping, Wei, Cuibai, . Efficacy and safety of donepezil in Chinese patients with severe Alzheimer’s disease: A randomized controlled trial. J Alzheimers Dis. 56(4): 1495–1504. 2017. 10.3233/JAD-161117 KQ4E3a, KQ5E3a28157100
222 Jiang, B, Ding, C, . Intervention effect of folic acid and vitamin B12 on vascular cognitive impairment complicated with hyperhomocysteinemia. Journal of Medical Biochemistry. 33(2): 169–74. 2014. 10.2478/jomb-2013-0033 KQ4E3a, KQ5E3a
223 Johansson, MM, Kvitting, AS, . Clinical utility of cognistat in multiprofessional team evaluations of patients with cognitive impairment in Swedish primary care. International Journal of Family Medicine Print. 2014(): 649253. 2014. PMID: 24778877. 10.1155/2014/649253 KQ2E2d24778877
224 Jorgensen K, Johannsen P, Vogel A. A Danish adaptation of the Boston Naming Test: Preliminary norms for older adults and validity in mild Alzheimer’s disease. The Clinical Neuropsychologist. 2017;31(Suppl 1):72–87. PMID: 28854839. KQ2E2d28854839
225 Jorgensen, K, Kristensen, MK, . The six-item Clock Drawing Test - reliability and validity in mild Alzheimer’s disease. Aging Neuropsychology & Cognition. 22(3): 301–11. 2015. PMID: 24974730. 10.1080/13825585.2014.932325 KQ2E3c24974730
226 Jouk, A, Tuokko, H. A reduced scoring system for the Clock Drawing Test using a population-based sample. Int Psychogeriatr. 24(11): 1738–48. 2012. PMID: 22651993. 10.1017/S1041610212000804 KQ2E2d22651993
227 Juncos-Rabadan, O, Facal, D, . Does tip-of-the-tongue for proper names discriminate amnestic mild cognitive impairment?. Int Psychogeriatr. 25(4): 627–34. 2013. PMID: 23253431. 10.1017/S1041610212002207 KQ2E2d23253431
228 Kaiser, AK, Hitzl, W, . Three-question dementia screening. Development of the Salzburg Dementia Test Prediction (SDTP). Z Gerontol Geriatr. 47(7): 577–82. 2014. PMID: 24292515. 10.1007/s00391-013-0568-7 KQ2E4e24292515
229 Kan CN, Zhang L, Cheng CY, . The Informant AD8 Can Discriminate Patients with Dementia From Healthy Control Participants in an Asian Older Cohort. J Am Med Dir Assoc. 2019. PMID: 30661859. KQ2E4e30661859
230 Kajiyama, B, Thompson, LW, . Exploring the effectiveness of an internet-based program for reducing caregiver distress using the iCare Stress Management e-Training Program. [Erratum appears in Aging Ment Health. 2013;17(5):c1]. Aging Ment Health. 17(5): 544–54. 2013. PMID: 23461355. 10.1080/13607863.2013.775641 KQ4E7c, KQ5E7c23461355
231 Kamkhagi, D, Costa, Aco, . Benefits of psychodynamic group therapy on depression, burden and quality of life of family caregivers to Alzheimer’s disease patients. Revista de psiquiatria clinica. 42(6): 157–160. 2015. 10.1590/0101-60830000000067 KQ4E3a, KQ5E3a
232 Kandiah, N, Zhang, A, . Early detection of dementia in multilingual populations: Visual Cognitive Assessment Test (VCAT). J Neurol Neurosurg Psychiatry. 87(2): 156–60. 2016. PMID: 25691617. 10.1136/jnnp-2014-309647 KQ2E3c25691617
233 Kano, Osamu, Ito, Hirono, . Clinically meaningful treatment responses after switching to galantamine and with addition of memantine in patients with Alzheimer’s disease receiving donepezil. Neuropsychiatric Disease and Treatment Vol 9 2013, ArtID 259–265. 9. 2013. KQ4E2b, KQ5E2b
234 Karaman, Y, Erdogan, F, . A 12-month study of the efficacy of rivastigmine in patients with advanced moderate Alzheimer’s disease. Dement Geriatr Cogn Disord. 19(1): 51–6. 2005. PMID: 15383747. 10.1159/000080972 KQ4E3a, KQ5E3a15383747
235 Karantzoulis, S, Novitski, J, . The Repeatable Battery for the Assessment of Neuropsychological Status (RBANS): Utility in detection and characterization of mild cognitive impairment due to Alzheimer’s disease. Archives of Clinical Neuropsychology. 28(8): 837–44. 2013. PMID: 23867976. 10.1093/arclin/act057 KQ2E2d23867976
236 Kato S, Homma A, Sakuma T, . Detection of mild Alzheimer’s disease and mild cognitive impairment from elderly speech: Binary discrimination using logistic regression. Conf Proc IEEE Eng Med Biol Soc. 2015;2015:5569–72. PMID: 26737554. KQ2E2d26737554
237 Kaur A, Edland SD, Peavy GM. The MoCA-Memory Index Score: An Efficient Alternative to Paragraph Recall for the Detection of Amnestic Mild Cognitive Impairment. Alzheimer Disease & Associated Disorders. 2018;32(2):120–4. PMID: 29319601. KQ2E4e29319601
238 Kemp, PM, Holmes, C, . A randomised placebo controlled study to assess the effects of cholinergic treatment on muscarinic receptors in Alzheimer’s disease. J Neurol Neurosurg Psychiatry. 74(11): 1567–1570. 2003. PMID: 14617718. KQ4E5, KQ5E514617718
239 Kim, Hee-Jin, Yang, YoungSoon, . Effectiveness of a community-based multidomain cognitive intervention program in patients with Alzheimer’s disease. Geriatr Gerontol Int. 16(2): 191–199. 2016. 10.1111/ggi.12453 KQ4E6b, KQ5E6b25656505
240 Kim, JW, Lee, DY, . Improvement of dementia screening accuracy of mini-mental state examination by education-adjustment and supplementation of frontal assessment battery performance. J Korean Med Sci. 28(10): 1522–8. 2013. PMID: 24133360. 10.3346/jkms.2013.28.10.1522 KQ2E3c24133360
241 Kim, JW, Lee, DY, . Improvement of Screening Accuracy of Mini-Mental State Examination for Mild Cognitive Impairment and Non-Alzheimer’s Disease Dementia by Supplementation of Verbal Fluency Performance. Psychiatry Investig. 11(1): 44–51. 2014. PMID: 24605123. 10.4306/pi.2014.11.1.44 KQ2E3c24605123
242 Kim, M-J, Han, C-W, . Physical Exercise with Multicomponent Cognitive Intervention for Older Adults with Alzheimer’s Disease: a 6-Month Randomized Controlled Trial. Dement Geriatr Cogn Dis Extra. 6(2): 222–232. 2016. 10.1159/000446508 KQ4E3b, KQ5E3b27403134
243 Kiosses, DN, Ravdin, LD, . Problem Adaptation Therapy for Older Adults With Major Depression and Cognitive Impairment: A Randomized Clinical Trial. JAMA Psychiatry. 72(1): 22–30. 2015. PMID: 25372657. KQ4E4b, KQ5E4b25372657
244 Koekkoek, PS, Rutten, GE, . The “Test Your Memory” test performs better than the MMSE in a population without known cognitive dysfunction. J Neurol Sci. 328(1–2): 92–7. 2013. PMID: 23531478. 10.1016/j.jns.2013.02.028 KQ2E523531478
245 Kohanpour, M-A, Peeri, M, . The effects of aerobic exercise with lavender essence use on cognitive state and serum brain-derived neurotrophic factor levels in elderly with mild cognitive impairment. Journal of herbmed pharmacology. 6(2): 80–84. 2017. KQ4E3a, KQ5E3a
246 Kohanpour M-A, Peeri M, Azarbayjani M-A. The Effects of Glycyrrhiza glabra L. extract use with aerobic training on inflammatory factors and cognitive state in elderly with mild cognitive impairment. Journal of herbmed pharmacology. 2017;6(4):178–84. KQ4E3a, KQ5E3a
247 Kohler, L, Meinke-Franze, C, . Does an interdisciplinary network improve dementia care? Results from the IDemUck-study. Curr Alzheimer Res. 11(6): 538–48. 2014. PMID: 24938504. KQ4E7c, KQ5E7c24938504
248 Koontz, J, Baskys, A. Effects of galantamine on working memory and global functioning in patients with mild cognitive impairment: a double-blind placebo-controlled study. Am J Alzheimers Dis Other Demen. 20(5): 295–302. 2005. PMID: 16273995. KQ4E7c, KQ5E7c16273995
249 Kroger, E, Mouls, M, . Adverse Drug Reactions Reported With Cholinesterase Inhibitors: An Analysis of 16 Years of Individual Case Safety Reports From VigiBase. Annals of Pharmacotherapy. 49(11): 1197–206. 2015. PMID: 26324356. 10.1177/1060028015602274 KQ5E2a26324356
250 Kroger, E, Van Marum, R, . Treatment with rivastigmine or galantamine and risk of urinary incontinence: results from a Dutch database study. Pharmacoepidemiol Drug Saf. 24(3): 276–85. 2015. PMID: 25652526. 10.1002/pds.3741 KQ5E2a25652526
251 Kuo LM, Huang HL, Huang HL, . A home-based training program improves Taiwanese family caregivers’ quality of life and decreases their risk for depression: a randomized controlled trial. Int J Geriatr Psychiatry. 2013;28(5):504–13. PMID: 22778053. KQ4E4c, KQ5E4c22778053
252 Kuo, LM, Huang, HL, . Health-related quality of life and self-efficacy of managing behavior problems for family caregivers of vascular dementia and Alzheimer’s disease patients. Dement Geriatr Cogn Disord. 38(5–6): 310–20. 2014. PMID: 25011490. 10.1159/000360414 KQ4E5, KQ5E525011490
253 Kurz, A, Grimmer, T. Efficacy of memantine hydrochloride once-daily in Alzheimer’s disease. Expert Opin Pharmacother. 15(13): 1955–60. 2014. PMID: 25085661. 10.1517/14656566.2014.945907 KQ4E5, KQ5E525085661
254 Kuster, OC, Fissler, P, . Cognitive change is more positively associated with an active lifestyle than with training interventions in older adults at risk of dementia: a controlled interventional clinical trial. BMC Psychiatry. 16(1): 315. 2016. PMID: 27608620. 10.1186/s12888-016-1018-z KQ4E1b, KQ5E1b27608620
255 Kvitting, AS, Wimo, A, . A quick test of cognitive speed (AQT): usefulness in dementia evaluations in primary care. Scand J Prim Health Care. 31(1): 13–9. 2013. PMID: 23293859. 10.3109/02813432.2012.751699 KQ2E3c23293859
256 Kwok, T, Lam, L, . Case management to improve quality of life of older people with early dementia and to reduce caregiver burden. Hong Kong Medical Journal. 18 Suppl 6(): 4–6. 2012. PMID: 23249844. KQ4E7c, KQ5E7c23249844
257 Kwok, TC, Bai, X, . Effectiveness of cognitive training in Chinese older people with subjective cognitive complaints: a randomized placebo-controlled trial. Int J Geriatr Psychiatry. 28(2): 208–15. 2013. PMID: 22528470. 10.1002/gps.3812 KQ4E7c, KQ5E7c22528470
258 Lacey, L, Bobula, J, . Informal Care Time and Cost in a Large Clinical Trial Sample of Patients with Mild to Moderate Alzheimer’s Disease: determinants and Level of Change Observed. Neurology and therapy. 6(1): 11–23. 2017. 10.1007/s40120-016-0056-2 KQ4E5, KQ5E527878522
259 Laforce, R, Jr, Sellami, . Validation of the Depistage Cognitif de Quebec: A New Cognitive Screening Tool for Atypical Dementias. Arch Clin Neuropsychol. 1–9. 2017. PMID: 28541543. 10.1093/arclin/acx048 KQ2E128122764
260 Lai, EC, Wong, MB, . Risk of pneumonia in new users of cholinesterase inhibitors for dementia. J Am Geriatr Soc. 63(5): 869–76. 2015. PMID: 25912671. 10.1111/jgs.13380 KQ4E2a, KQ5E2a25912671
261 Lam, LC, Chan, WM, . Effectiveness of Tai Chi in maintenance of cognitive and functional abilities in mild cognitive impairment: a randomised controlled trial. Hong Kong Medical Journal. 20(3 Suppl 3): 20–3. 2014. PMID: 25001031. KQ4E7c, KQ5E7c25001031
262 LaMantia, MA, Alder, CA, . The Aging Brain Care Medical Home: Preliminary Data. J Am Geriatr Soc. 63(6): 1209–13. 2015. PMID: 26096394. 10.1111/jgs.13447 KQ4E2a, KQ5E2a26096394
263 Langoni CDS, Resende TL, Barcellos AB, . Effect of Exercise on Cognition, Conditioning, Muscle Endurance, and Balance in Older Adults With Mild Cognitive Impairment: A Randomized Controlled Trial. Journal of geriatric physical therapy (2001). 2018. PMID: 29738405. KQ4E3a, KQ5E3a29738405
264 Langoni CDS, Resende TL, Barcellos AB, . The effect of group exercises on balance, mobility, and depressive symptoms in older adults with mild cognitive impairment: a randomized controlled trial. Clin Rehabil. 2018:10.1177/0269215518815218. PMID: 30514115. KQ4E1, KQ5E130514115
265 Laporte, Uribe F, Graske, J, . Regional dementia care networks in Germany: changes in caregiver burden at one-year follow-up and associated factors. Int Psychogeriatr. 1–14. 2017. 10.1017/S1041610217000126 KQ4E2a, KQ5E2a
266 Larner, A. MACE versus MoCA: Equivalence or superiority? Pragmatic diagnostic test accuracy study. Int Psychogeriatr. 29(6): 931–937. 2017. 10.1017/S1041610216002210 KQ2E3c28264749
267 Larner, AJ. Does combining an informant questionnaire with patient performance scales improve diagnostic test accuracy for cognitive impairment?. Int J Geriatr Psychiatry. 32(4): 466–467. 2017. PMID: 28272789. 10.1002/gps.4647 KQ2E3c28272789
268 Larner, AJ. Hard-TYM: a pragmatic study. Int J Geriatr Psychiatry. 30(3): 330–1. 2015. PMID: 25631916. 10.1002/gps.4249 KQ2E3c25631916
269 Larner, AJ. Implications of changing the Six-item Cognitive Impairment Test cutoff. Int J Geriatr Psychiatry. 30(7): 778–9. 2015. PMID: 26058457. 10.1002/gps.4303 KQ2E3c26058457
270 Larner, AJ. Mini-Addenbrooke’s cognitive examination diagnostic accuracy for dementia: reproducibility study. Int J Geriatr Psychiatry. 30(10): 1103–4. 2015. PMID: 26376107. 10.1002/gps.4334 KQ2E3c26376107
271 Larner, AJ. Mini-Addenbrooke’s Cognitive Examination: a pragmatic diagnostic accuracy study. Int J Geriatr Psychiatry. 30(5): 547–8. 2015. PMID: 25855207. 10.1002/gps.4258 KQ2E3c25855207
272 Larner AJ. Mini-Mental State Examination: diagnostic test accuracy study in primary care referrals. Neurodegenerative Disease Management. 2018;8(5):301–5. PMID: 30223710. KQ2E4e30223710
273 Lavery, LL, Lu, SY, . Cognitive assessment of older primary care patients with and without memory complaints. J Gen Intern Med. 22(7): 949–954. 2007. PMID: 17453265. 10.1007/s11606-007-0198-0 KQ2E7c17453265
274 Lebedeva, E, Gallant, S, . Improving the Measurement of Cognitive Ability in Geriatric Patients. Dement Geriatr Cogn Disord. 40(3–4): 148–57. 2015. PMID: 26107499. 10.1159/000381536 KQ2E526107499
275 Lee TM, Chan FH, Chu LW, . Auditory-based cognitive training programme for attention and memory in older people at risk of progressive cognitive decline: a randomised controlled trial. Hong Kong Med. 2017;23 Suppl 2(3):12–5. PMID: 29938664. KQ4E1b, KQ5E1b29938664
276 Lee SJ, Han JH, Hwang JW, . Screening for Normal Cognition, Mild Cognitive Impairment, and Dementia with the Korean Dementia Screening Questionnaire. Psychiatry Investigation. 2018;15(4):384–9. PMID: 29475235. KQ2E2d29475235
277 Lee, GY, Yip, CC, . Evaluation of a computer-assisted errorless learning-based memory training program for patients with early Alzheimer’s disease in Hong Kong: a pilot study. Clin Interv Aging. 8(): 623–33. 2013. PMID: 23766638. 10.2147/CIA.S45726 KQ4E7c, KQ5E7c23766638
278 Lee, LK, Shahar, S, . Docosahexaenoic acid-concentrated fish oil supplementation in subjects with mild cognitive impairment (MCI): a 12-month randomised, double-blind, placebo-controlled trial. Psychopharmacology (Berl). 225(3): 605–12. 2013. PMID: 22932777. 10.1007/s00213-012-2848-0 KQ4E3a, KQ5E3a22932777
279 Lees, R, Selvarajah, J, . Test accuracy of cognitive screening tests for diagnosis of dementia and multidomain cognitive impairment in stroke. Stroke. 45(10): 3008–18. 2014. PMID: 25190446. 10.1161/STROKEAHA.114.005842 KQ2E2a25190446
280 Lemke NC, Werner C, Wiloth S, . Transferability and Sustainability of Motor-Cognitive Dual-Task Training in Patients with Dementia: A Randomized Controlled Trial. Gerontology. 2019;65(1):68–83. PMID: 30041173. KQ4E3b, KQ5E3b30041173
281 Li, F, Harmer, P, . Tai Ji Quan and global cognitive function in older adults with cognitive impairment: a pilot study. Arch Gerontol Geriatr. 58(3): 434–9. 2014. PMID: 24398166. 10.1016/j.archger.2013.12.003 KQ4E2a, KQ5E2a24398166
282 Li, M, Ng, TP, . Brief informant screening test for mild cognitive impairment and early Alzheimer’s disease. Dement Geriatr Cogn Disord. 21(5–6): 392–402. 2006. PMID: 16645272. 10.1159/000092808 KQ2E3c16645272
283 Li, R, Cooper, C, . Coping strategies as mediators of the effect of the START (strategies for RelaTives) intervention on psychological morbidity for family carers of people with dementia in a randomised controlled trial. J Affect Disord. 168(): 298–305. 2014. PMID: 25083601. 10.1016/j.jad.2014.07.008 KQ4E5, KQ5E525083601
284 Li, T, Yao, Y, . Cognitive training can reduce the rate of cognitive aging: a neuroimaging cohort study. BMC Geriatr. 16(): 12. 2016. PMID: 26762334. 10.1186/s12877-016-0194-5 KQ4E3a, KQ5E3a26762334
285 Li, X, Jia, S, . The Gesture Imitation in Alzheimer’s Disease Dementia and Amnestic Mild Cognitive Impairment. J Alzheimers Dis. 53(4): 1577–84. 2016. PMID: 27540963. 10.3233/JAD-160218 KQ2E3a27540963
286 Lin, HC, Yang, YP, . Distinctive effects between cognitive stimulation and reminiscence therapy on cognitive function and quality of life for different types of behavioural problems in dementia. Scand J Caring Sci. 2017. PMID: 28881430. 10.1111/scs.12484 KQ4E7c, KQ5E7c28881430
287 Liu, Xy, Li, L, . Cognitive training in older adults with mild cognitive impairment. Biomed Environ Sci. 29(5): 356–364. 2016. KQ4E3a, KQ5E3a27353710
288 Locke, DE, Greenaway, MC, . A patient-centered analysis of enrollment and retention in a randomized behavioral trial of two cognitive rehabilitation interventions for Mild Cognitive Impairment. J Prev Alzheimers Dis. 1(3): 143–150. 2014. PMID: 27398353. 10.14283/jpad.2014.27 KQ4E8, KQ5E827398353
289 Logsdon, RebeccaG, Pike, KennethC, . Memory care and wellness services: Efficacy of specialized dementia care in adult day services. Gerontologist. 56(2): 318–325. 2016. 10.1093/geront/gnu012 KQ4E7c, KQ5E7c24615230
290 Lok, N, Bademli, K. Pilot testing of the “First You Should Get Stronger” program among caregivers of older adults with dementia. Arch Gerontol Geriatr. 68(): 84–89. 2017. PMID: 27689315. 10.1016/j.archger.2016.09.006 KQ4E2c, KQ5E2c27689315
291 Lord, K, Livingston, G, . A feasibility randomised controlled trial of the DECIDE intervention: dementia carers making informed decisions. BJPsych Open. 3(1): 12–14. 2017. PMID: 28243460. 10.1192/bjpo.bp.116.003509 KQ4E2c, KQ5E2c28243460
292 Lorig, Kate, Thompson-Gallagher, Dolores, . Building better caregivers: A pilot online support workshop for family caregivers of cognitively impaired adults. J Appl Gerontol. 31(3): 423–437. 2012. 10.1177/0733464810389806 KQ4E2a, KQ5E2a
293 Losada, A, Marquez-Gonzalez, M, . Cognitive-behavioral therapy (CBT) versus acceptance and commitment therapy (ACT) for dementia family caregivers with significant depressive symptoms: Results of a randomized clinical trial. J Consult Clin Psychol. 83(4): 760–72. 2015. PMID: 26075381. 10.1037/ccp0000028 KQ4E7c, KQ5E7c26075381
294 Low, LF, Harrison, F, . Can mild cognitive impairment be accurately diagnosed in english speakers from linguistic minorities? Results from the Sydney Memory and Ageing study. American Journal of Geriatric Psychiatry. 20(10): 866–77. 2012. PMID: 22261551. 10.1097/JGP.0b013e31823e31e2 KQ2E122261551
295 Lowery, D, Cerga-Pashoja, A, . The effect of exercise on behavioural and psychological symptoms of dementia: the EVIDEM-E randomised controlled clinical trial. Int J Geriatr Psychiatry. 29(8): 819–27. 2014. PMID: 24338799. 10.1002/gps.4062 KQ4E6c, KQ5E6c24338799
296 Lu, J, Sun, M, . Effects of momentum-based dumbbell training on cognitive function in older adults with mild cognitive impairment: a pilot randomized controlled trial. Clin Interv Aging. 11(): 9–16. 2016. PMID: 26766905. 10.2147/CIA.S96042 KQ4E3a, KQ5E3a26766905
297 Lykens, K, Moayad, N, . Impact of a community based implementation of REACH II program for caregivers of Alzheimer’s patients. PLoS ONE [Electronic Resource]. 9(2): e89290. 2014. PMID: 24586664. 10.1371/journal.pone.0089290 KQ4E2a, KQ5E2a24586664
298 Ma F, Li Q, Zhou X, . Effects of folic acid supplementation on cognitive function and Abeta-related biomarkers in mild cognitive impairment: a randomized controlled trial. Eur J Nutr. 2017. PMID: 29255930. KQ4E3a, KQ5E3a29255930
299 MacDougall, ElizabethE, Mansbach, WilliamE, . The Brief Cognitive Assessment Tool (BCAT): Cross-validation in a community dwelling older adult sample. Int Psychogeriatr. 27(2): 243–250. 2015. 10.1017/S1041610214001458 KQ2E7b
300 MacNeil Vroomen, J, Bosmans, JE, . Community-dwelling patients with dementia and their informal caregivers with and without case management: 2-year outcomes of a pragmatic trial. J Am Med Dir Assoc. 16(9): 800.e1–8. 2015. PMID: 26170035. 10.1016/j.jamda.2015.06.011 KQ4E2a26170035
301 MacNeil Vroomen, J, Van Mierlo, LD, . Comparing Dutch case management care models for people with dementia and their caregivers: The design of the COMPAS study. BMC Health Serv Res. 12(): 132. 2012. PMID: 22640695. 10.1186/1472-6963-12-132 KQ4E8, KQ5E822640695
302 Mahoney, DF, Tarlow, BJ, . Effects of an automated telephone support system on caregiver burden and anxiety: findings from the REACH for TLC intervention study. Gerontologist. 43(4): 556–567. 2003. PMID: 12937334. KQ4E4c, KQ5E4c12937334
303 Maillet, D, Matharan, F, . TNI-93: A New Memory Test for Dementia Detection in Illiterate and Low-Educated Patients. Arch Clin Neuropsychol. 2016. PMID: 27590305. 10.1093/arclin/acw065 KQ2E7c27590305
304 Maki, Y, Yamaguchi, T, . Symptoms of Early Dementia-11 Questionnaire (SED-11Q): A Brief Informant-Operated Screening for Dementia. Dement Geriatr Cogn Dis Extra. 3(1): 131–42. 2013. PMID: 23687508. 10.1159/000350460 KQ2E2d23687508
305 Makizako, H, Doi, T, . Does a multicomponent exercise program improve dual-task performance in amnestic mild cognitive impairment? A randomized controlled trial. Aging-Clinical & Experimental Research. 24(6): 640–6. 2012. PMID: 23211228. 10.3275/8760 KQ4E5, KQ5E523211228
306 Mansbach, We, Mace, Ra, . The efficacy of a computer-assisted cognitive rehabilitation program for patients with mild cognitive deficits: a pilot study. Exp Aging Res. 43(1): 94–104. 2017. PMID: Pubmed 28067610. 10.1080/0361073X.2017.1258256 KQ4E2c, KQ5E2c28067610
307 Marcone, S, Gagnon, JF, . Clinical Utility of the Envelope Task in Mild Cognitive Impairment and Dementia. Can J Neurol Sci. 44(1): 9–16. 2017. PMID: 27665668. 10.1017/cjn.2016.298 KQ2E2d27665668
308 Martinelli JE, Cecato JF, Martinelli MO, . Performance of the Pentagon Drawing test for the screening of older adults with Alzheimer’s dementia. Dementia & neuropsychologia. 2018;12(1):54–60. PMID: 29682234. KQ2E3a29682234
309 Matias-Guiu, JA, Fernandez de Bobadilla, R, . Validation of the Spanish version of Addenbrooke’s Cognitive Examination III for diagnosing dementia. Neurologia. 30(9): 545–51. 2015. PMID: 25002342. 10.1016/j.nrl.2014.05.004 KQ2E6a25002342
310 Matias-Guiu, JA, Fernandez-Bobadilla, R. Validation of the Spanish-language version of Mini-Addenbrooke’s Cognitive Examination as a dementia screening tool. Neurologia. 31(9): 646–648. 2016. PMID: 25529174. 10.1016/j.nrl.2014.10.005 KQ2E3c25529174
311 Matsuzono, K, Sato, K, . Clinical benefits of rivastigmine in the real world dementia clinics of the Okayama Rivastigmine Study (ORS). J Alzheimers Dis. 48(3): 757–763. 2015. 10.3233/JAD-150518 KQ4E2a, KQ5E2a26402119
312 McCulloch, K, Collins, RL, . Validation and diagnostic utility of the dementia rating scale in a mixed dementia population. Alzheimer Dis Assoc Disord. 28(2): 168–74. 2014. PMID: 24231456. 10.1097/WAD.0000000000000014 KQ2E3c24231456
313 McCulloch, Katie. Validation and diagnostic utility of the Mini-Mental State Examination and Montreal Cognitive Assessment in screening for dementia within a mixed clinical sample. Dissertation Abstracts International: Section B: The Sciences and Engineering. 76(4-B(E)): No Pagination Specified. 2015. KQ2E3c
314 McCurry, SusanM, Logsdon, RebeccaG, . Adopting evidence-based caregiver training programs in the real world: Outcomes and lessons learned from the STAR-C Oregon Translation Study. J Appl Gerontol. 36(5): 519–536. 2017. 10.1177/0733464815581483 KQ4E2a, KQ5E2a25873454
315 McDougall GJ, McDonough IM, LaRocca M. Memory training for adults with probable mild cognitive impairment: a pilot study. Aging Ment Health. 2018:1–9. PMID: 30303394. KQ4E7c, KQ5E7c30303394
316 Meichsner F, Theurer C, Wilz G. Acceptance and treatment effects of an internet-delivered cognitive-behavioral intervention for family caregivers of people with dementia: A randomized-controlled trial. Journal of clinical psychology. 2018. PMID: 30597537. KQ4E4c, KQ5E4c30597537
317 Michalec, J, Bezdicek, O, . Standardization of the Czech version of the Tower of London test - Administration, scoring, validity. Ceska a Slovenska Neurologie a Neurochirurgie. 77(5): 596–601. 2014. 10.14735/amcsnn2014596 KQ2E4b
318 Michalowsky, Bernhard, Eichler, Tilly, . Healthcare resource utilization and cost in dementia: Are there differences between patients screened positive for dementia with and those without a formal diagnosis of dementia in primary care in Germany?. Int Psychogeriatr. 28(3): 359–369. 2016. 10.1017/S1041610215001453 KQ1E126446797
319 Mioshi, E, McKinnon, C, . Improving burden and coping skills in frontotemporal dementia caregivers: a pilot study. Alzheimer Dis Assoc Disord. 27(1): 84–6. 2013. PMID: 22354158. 10.1097/WAD.0b013e31824a7f5b KQ4E2a, KQ5E2a22354158
320 Miranda DDC, Brucki SMD, Yassuda MS. The Mini-Addenbrooke’s Cognitive Examination (M-ACE) as a brief cognitive screening instrument in Mild Cognitive Impairment and mild Alzheimer’s disease. Dementia & neuropsychologia. 2018;12(4):368–73. PMID: 30546846. KQ2E3a30546846
321 Mittelman, MS, Brodaty, H, . A three-country randomized controlled trial of a psychosocial intervention for caregivers combined with pharmacological treatment for patients with Alzheimer disease: effects on caregiver depression. Am J Geriatr Psychiatry. 16(11): 893–904. 2008. PMID: 18978250. KQ4E7c, KQ5E7c18978250
322 Molinuevo, Jl, Frolich, L, . Responder analysis of a randomized comparison of the 13.3 mg/24 h and 9.5 mg/24 h rivastigmine patch. Alzheimers Res Ther. 7(1). 2015. 10.1186/s13195-014-0088-8 KQ4E2b, KQ5E2b
323 Montero-Odasso M, Speechley M, Chertkow H, . Donepezil for gait and falls in mild cognitive impairment: a randomized controlled trial. Eur J Neurol. 2018. PMID: 30565793. KQ4E1, KQ5E130565793
324 Moore, RC, Chattillion, EA, . A randomized clinical trial of Behavioral Activation (BA) therapy for improving psychological and physical health in dementia caregivers: results of the Pleasant Events Program (PEP). Behav Res Ther. 51(10): 623–32. 2013. PMID: 23916631. 10.1016/j.brat.2013.07.005 KQ4E2b23916631
325 Moreno-Martinez, FJ, Ruiz, M, . Why Almost Always Animals? Ranking Fluency Tasks for the Detection of Dementia Based on Receiver Operating Characteristic (ROC) and Quality ROC Analyses. Dement Geriatr Cogn Disord. 43(1–2): 59–70. 2017. PMID: 28013307. 10.1159/000454916 KQ2E2d28013307
326 Mori, E, Ikeda, M, . Effects of Donepezil on Extrapyramidal Symptoms in Patients with Dementia with Lewy Bodies: A Secondary Pooled Analysis of Two Randomized-Controlled and Two Open-Label Long-Term Extension Studies. Dement Geriatr Cogn Disord. 40(3–4): 186–98. 2015. PMID: 26226884. 10.1159/000433524 KQ5E2a26226884
327 Moriyama, Y, Yoshino, A, . The Japanese version of the Rapid Dementia Screening Test is effective compared to the clock-drawing test for detecting patients with mild Alzheimer’s disease. Psychogeriatrics:The Official Journal of the Japanese Psychogeriatric Society. 16(4): 233–9. 2016. PMID: 26211455. 10.1111/psyg.12144 KQ2E2d26211455
328 Mormont, E, Jamart, J, . Symptoms of depression and anxiety after the disclosure of the diagnosis of Alzheimer disease. J Geriatr Psychiatry Neurol. 27(4): 231–6. 2014. PMID: 24759087. 10.1177/0891988714532021 KQ3E2a24759087
329 Moro, V, Condoleo, MT, . Cognitive stimulation in a-MCI: an experimental study. Am J Alzheimers Dis Other Demen. 27(2): 121–30. 2012. PMID: 22495340. 10.1177/1533317512441386 KQ4E2a, KQ5E2a22495340
330 Moro, V, Condoleo, Mt, . Cognitive stimulation of executive functions in mild cognitive impairment: Specific efficacy and impact in memory. Am J Alzheimers Dis Other Demen. 30(2): 153–64. 2015. 10.1177/1533317514539542 KQ4E2a, KQ5E2a24963080
331 Morris, RG, Woods, RT, . The use of a coping strategy focused support group for carers of dementia sufferers. Couns Psychol Q. 5(4): 337–348. 1992. https://dx.doi.org/None KQ4E7c, KQ5E7c
332 Mukadam N, Cooper C, Livingston G. The EAST-Dem study: a pilot cluster randomized controlled trial. International psychogeriatrics. 2018;30(5):769–73. PMID: 29108532. KQ4E5, KQ5E529108532
333 Myhre, J, Bjornstad, JT, . The coping experiences of spouses of persons with dementia. J Clin Nurs. 2017. PMID: 28833748. 10.1111/jocn.14047 KQ4E2a, KQ5E2a28833748
334 Nagamatsu, LindsayS, Handy, ToddC, . Resistance training promotes cognitive and functional brain plasticity in seniors with probable mild cognitive impairment. Arch Intern Med. 172(8): 666–668. 2012. PMID: 22529236. KQ4E1b, KQ5E1b22529236
335 Nagamatsu, LS, Chan, A, . Physical activity improves verbal and spatial memory in older adults with probable mild cognitive impairment: a 6-month randomized controlled trial. J Aging Res. 2013(): 861893. 2013. PMID: 23509628. 10.1155/2013/861893 KQ4E1b, KQ5E1b23509628
336 Naismith SL, Pye J, Terpening Z, . “Sleep Well, Think Well” Group Program for Mild Cognitive Impairment: A Randomized Controlled Pilot Study. Behavioral sleep medicine. 2018:1–12. PMID: 30247939. KQ4E1, KQ5E130247939
337 Nakamae, T, Yotsumoto, K, . Effects of productive activities with reminiscence in occupational therapy for people with dementia: A pilot randomized controlled study. Hong Kong Journal of Occupational Therapy. 24(1): 13–9. 2014. 10.1016/j.hkjot.2014.01.003 KQ4E6b, KQ5E6b
338 Nakamura, Y, Kitamura, S, . Efficacy and safety of memantine in patients with moderate-to-severe Alzheimer’s disease: results of a pooled analysis of two randomized, double-blind, placebo-controlled trials in Japan. Expert Opin Pharmacother. 15(7): 913–25. 2014. PMID: 24673497. 10.1517/14656566.2014.902446 KQ4E4c, KQ5E4c24673497
339 Nakamura, Y, Strohmaier, C, . A 24-Week, Randomized, Controlled Study to Evaluate the Tolerability, Safety and Efficacy of 2 Different Titration Schemes of the Rivastigmine Patch in Japanese Patients with Mild to Moderate Alzheimer’s Disease. Dement Geriatr Cogn Dis Extra. 5(3): 361–374. 2015. 10.1159/000439269 KQ4E2b, KQ5E2b26557135
340 Nakanishi, M, Endo, K, . Psychosocial behaviour management programme for home-dwelling people with dementia: A cluster-randomized controlled trial. Int J Geriatr Psychiatry. 2017. PMID: 28857263. 10.1002/gps.4784 KQ4E4d, KQ5E4d28857263
341 Ng, A, Chew, I, . Effectiveness of Montreal Cognitive Assessment for the diagnosis of mild cognitive impairment and mild Alzheimer’s disease in Singapore. Singapore Med J. 54(11): 616–9. 2013. PMID: 24276096. KQ2E2d24276096
342 Ng, TP, Feng, L, . Montreal Cognitive Assessment for screening mild cognitive impairment: variations in test performance and scores by education in Singapore. Dement Geriatr Cogn Disord. 39(3–4): 176–85. 2015. 10.1159/000368827 KQ2E2d25572449
343 Ngandu, T, Lehtisalo, J, . A 2 year multidomain intervention of diet, exercise, cognitive training, and vascular risk monitoring versus control to prevent cognitive decline in at-risk elderly people (FINGER): a randomised controlled trial. Lancet. 385(9984): 2255–63. 2015. PMID: 25771249. 10.1016/S0140-6736(15)60461-5 KQ4E1b, KQ5E1b25771249
344 Ni, J, Shi, J, . Screening mild cognitive impairment by delayed story recall and instrumental activities of daily living. Int J Geriatr Psychiatry. 30(8): 888–90. 2015. PMID: 26172064. 10.1002/gps.4317 KQ2E3c26172064
345 Nielsen, TR, Phung, TK, . Combining the Rowland Universal Dementia Assessment Scale and the Informant Questionnaire on Cognitive Decline in the Elderly to Improve Detection of Dementia in an Arabic-Speaking Population. Dement Geriatr Cogn Disord. 41(1–2): 46–54. 2016. PMID: 26613533. 10.1159/000441649 KQ2E3a26613533
346 Nielsen, TR, Vogel, A, . Cognitive testing in non-demented Turkish immigrants--comparison of the RUDAS and the MMSE. Scand J Psychol. 53(6): 455–60. 2012. PMID: 23170863. 10.1111/sjop.12018 KQ2E123170863
347 O’Caoimh, R, Gao, Y, . Comparing Approaches to Optimize Cut-off Scores for Short Cognitive Screening Instruments in Mild Cognitive Impairment and Dementia. J Alzheimers Dis. 57(1): 123–133. 2017. PMID: 28222528. 10.3233/JAD-161204 KQ2E3c28222528
348 O’Caoimh, R, Gao, Y, . Which part of the Quick mild cognitive impairment screen (Qmci) discriminates between normal cognition, mild cognitive impairment and dementia?. Age Ageing. 42(3): 324–30. 2013. PMID: 23612864. 10.1093/ageing/aft044 KQ2E3c23612864
349 O’Caoimh, Ronan, Gao, Yang, . Comparing approaches to optimize cut-off scores for short cognitive screening instruments in mild cognitive impairment and dementia. J Alzheimers Dis. 57(1): 123–133. 2017. 10.3233/JAD-161204 KQ2E3c28222528
350 Ohnishi, T, Sakiyama, Y, . The prediction of response to galantamine treatment in patients with mild to moderate Alzheimer’s disease. Curr Alzheimer Res. 11(2): 110–8. 2014. PMID: 24156269. KQ4E5, KQ5E524156269
351 Okamura H, Otani M, Shimoyama N, . Combined Exercise and Cognitive Training System for Dementia Patients: A Randomized Controlled Trial. Dement Geriatr Cogn Disord. 2018;45(5–6):318–25. PMID: 30036871. KQ4E2b, KQ5E2b30036871
352 Okereke, OI, Pantoja-Galicia, N, . The SIST-M: predictive validity of a brief structured clinical dementia rating interview. Alzheimer Dis Assoc Disord. 26(3): 225–31. 2012. PMID: 21986342. 10.1097/WAD.0b013e318231cd30 KQ2E121986342
353 Okuizumi K, Kamata T, Matsui D, . Memantine in Japanese patients with moderate to severe Alzheimer’s disease: meta-analysis of multiple-index responder analyses. Expert Opinion on Pharmacotherapy. 2018;19(5):425–30. PMID: 29448852. KQ4E2a, KQ5E2a29448852
354 Olchik, MR, Farina, J, . Memory training (MT) in mild cognitive impairment (MCI) generates change in cognitive performance. Arch Gerontol Geriatr. 56(3): 442–7. 2013. PMID: 23260332. 10.1016/j.archger.2012.11.007 KQ4E1b, KQ5E1b23260332
355 Onoda, K, Hamano, T, . Validation of a new mass screening tool for cognitive impairment: Cognitive Assessment for Dementia, iPad version. Clin Interv Aging. 8(): 353–60. 2013. PMID: 23569368. 10.2147/CIA.S42342 KQ2E2a23569368
356 Onoda, K, Yamaguchi, S. Revision of the Cognitive Assessment for Dementia, iPad version (CADi2). PLoS ONE [Electronic Resource]. 9(10): e109931. 2014. PMID: 25310860. 10.1371/journal.pone.0109931 KQ2E2d25310860
357 Otero, P, Smit, F, . Differential response to depression prevention among a sample of informal caregivers: Moderator analysis of longer-term follow-up trial data. Psychiatry Res. 230(2): 271–8. 2015. PMID: 26456895. 10.1016/j.psychres.2015.09.005 KQ4E8, KQ5E826456895
358 Otero, P, Smit, F, . Long-term efficacy of indicated prevention of depression in non-professional caregivers: randomized controlled trial. Psychol Med. 45(7): 1401–12. 2015. PMID: 25331992. 10.1017/S0033291714002505 KQ4E125331992
359 Ott, BR, Blake, LM, . Open label, multicenter, 28-week extension study of the safety and tolerability of memantine in patients with mild to moderate Alzheimer’s disease. J Neurol. 254(3): 351–358. 2007. PMID: 17345042. KQ4E2f, KQ5E2f17345042
360 Oulhaj, A, Jerneren, F, . Omega-3 Fatty Acid Status Enhances the Prevention of Cognitive Decline by B Vitamins in Mild Cognitive Impairment. J Alzheimers Dis. 50(2): 547–57. 2016. PMID: 26757190. 10.3233/JAD-150777 KQ4E526757190
361 Pa, J, Berry, AS, . Cholinergic enhancement of functional networks in older adults with mild cognitive impairment. Ann Neurol. 73(6): 762–73. 2013. PMID: 23447373. 10.1002/ana.23874 KQ4E5, KQ5E523447373
362 Pa, J, Goodson, W, . Effect of exercise and cognitive activity on self-reported sleep quality in community-dwelling older adults with cognitive complaints: a randomized controlled trial. J Am Geriatr Soc. 62(12): 2319–26. 2014. PMID: 25516028. 10.1111/jgs.13158 KQ4E1b, KQ5E1b25516028
363 Paajanen, T, Hanninen, T, . CERAD neuropsychological compound scores are accurate in detecting prodromal alzheimer’s disease: a prospective AddNeuroMed study. J Alzheimers Dis. 39(3): 679–90. 2014. PMID: 24246420. 10.3233/JAD-122110 KQ2E2d24246420
364 Padala, KalpanaP, Padala, PrasadR, . Home-based exercise program improves balance and fear of falling in community-dwelling older adults with mild Alzheimer’s disease: A pilot study. J Alzheimers Dis. 59(2): 565–574. 2017. 10.3233/JAD-170120 KQ4E6c, KQ5E6c28655135
365 Pariente, A, Sanctussy, DJ, . Factors associated with serious adverse reactions to cholinesterase inhibitors: a study of spontaneous reporting. CNS Drugs. 24(1): 55–63. 2010. PMID: 20030419. KQ5E2f20030419
366 Park JH, Jung M, Kim J, . Validity of a novel computerized screening test system for mild cognitive impairment. International Psychogeriatrics. 2018;30(10):1455–63. PMID: 29923471. KQ2E2d29923471
367 Park, KW, Kim, EJ, . Efficacy and tolerability of rivastigmine patch therapy in patients with mild-to-moderate Alzheimer’s dementia associated with minimal and moderate ischemic white matter hyperintensities: A multicenter prospective open-label clinical trial. PLoS ONE [Electronic Resource]. 12(8): e0182123. 2017. PMID: 28786987. 10.1371/journal.pone.0182123 KQ4E2a, KQ5E2a28786987
368 Park, MH. Informant questionnaire on cognitive decline in the elderly (IQCODE) for classifying cognitive dysfunction as cognitively normal, mild cognitive impairment, and dementia. Int Psychogeriatr. 29(9): 1461–1467. 2017. PMID: 28560943. 10.1017/S1041610217000965 KQ2E3c28560943
369 Park-Wyllie, LY, Mamdani, MM, . Cholinesterase inhibitors and hospitalization for bradycardia: a population-based study. PLoS Medicine / Public Library of Science. 6(9): e1000157. 2009. PMID: 19787032. KQ5E2e19787032
370 Passoni, S, Moroni, L, . Cognitive behavioral group intervention for Alzheimer caregivers. Alzheimer Dis Assoc Disord. 28(3): 275–82. 2014. PMID: 24614271. 10.1097/WAD.0000000000000033 KQ4E2a, KQ5E2a24614271
371 Patocskai, AT, Pakaski, M, . Is there any difference between the findings of Clock Drawing Tests if the clocks show different times?. J Alzheimers Dis. 39(4): 749–57. 2014. PMID: 24270210. 10.3233/JAD-131313 KQ2E3b24270210
372 Pedraza, O, Clark, JH, . Diagnostic validity of age and education corrections for the Mini-Mental State Examination in older African Americans. J Am Geriatr Soc. 60(2): 328–31. 2012. PMID: 22150301. 10.1111/j.1532-5415.2011.03766.x KQ2E4e22150301
373 Pelton, GH, Soleimani, L, . Olfactory Deficits Predict Cognitive Improvement on Donepezil in Patients With Depression and Cognitive Impairment: A Randomized Controlled Pilot Study. Alzheimer Dis Assoc Disord. 30(1): 67–9. 2016. PMID: 26398910. 10.1097/WAD.0000000000000107 KQ4E4b, KQ5E4b26398910
374 Peters, O, Lorenz, D, . A combination of galantamine and memantine modifies cognitive function in subjects with amnestic MCI. Journal of Nutrition, Health & Aging. 16(6): 544–8. 2012. PMID: 22659994. KQ4E7c, KQ5E7c22659994
375 Perttila NM, Ohman H, Strandberg TE, . Effect of Exercise on Drug-Related Falls Among Persons with Alzheimer’s Disease: A Secondary Analysis of the FINALEX Study. Drugs & Aging. 2018;35(11):1017–23. PMID: 30315403. KQ4E5, KQ5E530315403
376 Phua AKS, Hiu SKW, Goh WK, . Low Accuracy of Brief Cognitive Tests in Tracking Longitudinal Cognitive Decline in an Asian Elderly Cohort. Journal of Alzheimer’s Disease. 2018;62(1):409–16. PMID: 29439344. KQ2E2d29439344
377 Phung, TK, Chaaya, M, . Performance of the 16-Item Informant Questionnaire on Cognitive Decline for the Elderly (IQCODE) in an Arabic-Speaking Older Population. Dement Geriatr Cogn Disord. 40(5–6): 276–89. 2015. PMID: 26338716. 10.1159/000437092 KQ2E2d26338716
378 Pirrotta, Fabio, Timpano, Francesca, . Italian validation of Montreal Cognitive Assessment. European Journal of Psychological Assessment. 31(2): 131–137. 2015. 10.1027/1015-5759/a000217 KQ2E7b
379 Poptsi E, Lazarou I, Markou N, . A Comparative Single-Blind Randomized Controlled Trial With Language Training in People With Mild Cognitive Impairment. American Journal of Alzheimer’s Disease & Other Dementias. 2018:10.1177/1533317518813554. PMID: 30518237. KQ4E7c, KQ5E7c30518237
380 Possin KL, Moskowitz T, Erlhoff SJ, . The Brain Health Assessment for detecting and diagnosing neurocognitive disorders. J Am Geriatr Soc. 2018;66(1):150–6. KQ2E2d29355911
381 Potkin, SG, Anand, R, . Brain metabolic and clinical effects of rivastigmine in Alzheimer’s disease. Int J Neuropsychopharmacol. 4(3): 223–30. 2001. PMID: 11602028. 10.1017/S1461145701002528 KQ4E1, KQ5E111602028
382 Prieto, G, Contador, I, . The Mini-Mental-37 test for dementia screening in the Spanish population: an analysis using the Rasch Model. Clinical Neuropsychologist. 26(6): 1003–18. 2012. PMID: 22809084. 10.1080/13854046.2012.704945 KQ2E122809084
383 Puterman E, Weiss J, Lin J, . Aerobic exercise lengthens telomeres and reduces stress in family caregivers: a randomized controlled trial - Curt Richter Award Paper 2018. Psychoneuroendocrinology. 2018;(no pagination). KQ4E1, KQ5E1
384 Qi M, Zhu Y, Zhang L, . The effect of aerobic dance intervention on brain spontaneous activity in older adults with mild cognitive impairment: A resting-state functional MRI study. Experimental Ther. 2019;17(1):715–22. PMID: 30651855. KQ4E3a, KQ5E3a30651855
385 Quintana-Hernandez, DJ, Miro-Barrachina, MT, . Mindfulness in the Maintenance of Cognitive Capacities in Alzheimer’s Disease: A Randomized Clinical Trial. J Alzheimers Dis. 50(1): 217–32. 2016. PMID: 26639952. 10.3233/JAD-143009 KQ4E7c, KQ5E7c26639952
386 Radford, K, Mack, HA, . Comparison of Three Cognitive Screening Tools in Older Urban and Regional Aboriginal Australians. Dement Geriatr Cogn Disord. 40(1–2): 22–32. 2015. PMID: 25896073. 10.1159/000377673 KQ2E7c25896073
387 Radford, K, Mack, HA, . Prevalence of dementia in urban and regional Aboriginal Australians. Alzheimers Dement. 11(3): 271–9. 2015. PMID: 24985534. 10.1016/j.jalz.2014.03.007 KQ2E824985534
388 Rami, L, Mollica, MA, . The Subjective Cognitive Decline Questionnaire (SCD-Q): a validation study. J Alzheimers Dis. 41(2): 453–66. 2014. PMID: 24625794. 10.3233/JAD-132027 KQ2E2d24625794
389 Ramlall, S, Chipps, J, . The sensitivity and specificity of subjective memory complaints and the subjective memory rating scale, deterioration cognitive observee, mini-mental state examination, six-item screener and clock drawing test in dementia screening. Dement Geriatr Cogn Disord. 36(1–2): 119–35. 2013. PMID: 23860433. 10.1159/000350768 KQ2E3a23860433
390 Raschetti, R, Maggini, M, . A cohort study of effectiveness of acetylcholinesterase inhibitors in Alzheimer’s disease. Eur J Clin Pharmacol. 61(5–6): 361–368. 2005. PMID: 15912389. KQ5E2f15912389
391 Reckess, GZ, Brandt, J, . Screening by telephone in the Alzheimer’s disease anti-inflammatory prevention trial. J Alzheimers Dis. 36(3): 433–43. 2013. PMID: 23645097. 10.3233/JAD-130113 KQ2E7c23645097
392 Regan, B, Wells, Y, . MAXCOG-Maximizing Cognition: A Randomized Controlled Trial of the Efficacy of Goal-Oriented Cognitive Rehabilitation for People with Mild Cognitive Impairment and Early Alzheimer Disease. American Journal of Geriatric Psychiatry. 16(): 16. 2016. PMID: 28034509. 10.1016/j.jagp.2016.11.008 KQ4E7c, KQ5E7c28034509
393 Reiner, K, Eichler, T, . The Clock Drawing Test: A Reasonable Instrument to Assess Probable Dementia in Primary Care?. Curr Alzheimer Res. 2017. PMID: 28891446. 10.2174/1567205014666170908101822 KQ2E2d28891446
394 Reisberg, B, Doody, R, . Memantine in moderate-to-severe Alzheimer’s disease. N Engl J Med. 348(14): 1333–41. 2003. PMID: 12672860. 10.1056/NEJMoa013128 KQ4E4c, KQ5E4c12672860
395 Reisberg, Barry, Shao, Yongzhao, . Comprehensive, individualized, person-centered management of community-residing persons with moderate-to-severe Alzheimer disease: A randomized controlled trial. Dement Geriatr Cogn Disord. 43(1–2): 100–117. 2017. 10.1159/000455397 KQ4E4c, KQ5E4c28122366
396 Relkin, NR, Reichman, WE, . A large, community-based, open-label trial of donepezil in the treatment of Alzheimer’s disease. Dement Geriatr Cogn Disord. 16(1): 15–24. 2003. PMID: 12714795. KQ5E2f12714795
397 Remington, R, Bechtel, C, . A Phase II Randomized Clinical Trial of a Nutritional Formulation for Cognition and Mood in Alzheimer’s Disease. J Alzheimers Dis. 45(2): 395–405. 2015. PMID: 25589719. 10.3233/JAD-142499 KQ4E7c, KQ5E7c25589719
398 Requena, C, Lopez Ibor, MI, . Effects of cholinergic drugs and cognitive training on dementia. Dement Geriatr Cogn Disord. 18(1): 50–54. 2004. PMID: 15084794. KQ4E7c, KQ5E7c15084794
399 Requena, C, Maestu, F, . Effects of cholinergic drugs and cognitive training on dementia: 2-year follow-up. Dement Geriatr Cogn Disord. 22(4): 339–345. 2006. PMID: 16954689. KQ4E8, KQ5E816954689
400 Richarz, U, Gaudig, M, . Galantamine treatment in outpatients with mild Alzheimer’s disease. Acta Neurol Scand. 129(6): 382–92. 2014. PMID: 24461047. 10.1111/ane.12195 KQ5E2f24461047
401 Riepe, MW. High-dose cholinergic therapy with rivastigmine patch does not prolong QTc time in patients with Alzheimer’s disease. J Clin Psychiatry. 75(3): 288. 2014. PMID: 24717382. 10.4088/JCP.13l08730 KQ4E2b, KQ5E2b24717382
402 Roalf, DR, Moberg, PJ, . Comparative accuracies of two common screening instruments for classification of Alzheimer’s disease, mild cognitive impairment, and healthy aging. Alzheimer’s & Dementia. 9(5): 529–37. 2013. PMID: 23260866. 10.1016/j.jalz.2012.10.001 KQ2E3c23260866
403 Roalf DR, Moore TM, Mechanic-Hamilton D, . Bridging cognitive screening tests in neurologic disorders: A crosswalk between the short Montreal Cognitive Assessment and Mini-Mental State Examination. Alzheimers Dement. 2017;13(8):947–52. PMID: 28238740. KQ2E3c28238740
404 Roalf, DR, Moore, TM, . Defining and validating a short form Montreal Cognitive Assessment (s-MoCA) for use in neurodegenerative disease. J Neurol Neurosurg Psychiatry. 87(12): 1303–1310. 2016. PMID: 27071646. 10.1136/jnnp-2015-312723 KQ2E3c27071646
405 Rockwood, K, Dai, D, . Patterns of decline and evidence of subgroups in patients with Alzheimer’s disease taking galantamine for up to 48 months. Int J Geriatr Psychiatry. 23(2): 207–214. 2008. PMID: 17621382. KQ4E2f, KQ5E2f17621382
406 Rockwood, K, Fay, S, . The ADAS-cog and clinically meaningful change in the VISTA clinical trial of galantamine for Alzheimer’s disease. Int J Geriatr Psychiatry. 25(2): 191–201. 2010. PMID: 19548273. KQ4E2f, KQ5E2f19548273
407 Rodriguez-Sanchez, E, Patino-Alonso, MC, . Effects of a psychological intervention in a primary health care center for caregivers of dependent relatives: a randomized trial. Gerontologist. 53(3): 397–406. 2013. PMID: 22899425. 10.1093/geront/gns086 KQ4E2c, KQ5E2c22899425
408 Rogers, SL, Doody, RS, . Long-term efficacy and safety of donepezil in the treatment of Alzheimer’s disease: final analysis of a US multicentre open-label study. Eur Neuropsychopharmacol. 10(3): 195–203. 2000. PMID: 10793322. KQ4E2f, KQ5E2f10793322
409 Rogers, SL, Farlow, MR, . A 24-week, double-blind, placebo-controlled trial of donepezil in patients with Alzheimer’s disease. Donepezil Study Group. Neurology. 50(1): 136–145. 1998. PMID: 9443470. KQ4E7c, KQ5E7c9443470
410 Rojas, GJ, Villar, V, . Efficacy of a cognitive intervention program in patients with mild cognitive impairment. Int Psychogeriatr. 25(5): 825–31. 2013. PMID: 23414646. 10.1017/S1041610213000045 KQ4E7c, KQ5E7c23414646
411 Rokstad AMM, Engedal K, Kirkevold O, . The impact of attending day care designed for home-dwelling people with dementia on nursing home admission: a 24-month controlled study. BMC Health Services Research. 2018;18(1):864. PMID: 30445937. KQ4E6b, KQ5E6b30445937
412 Rondanelli, M, Opizzi, A, . Effects of a diet integration with an oily emulsion of DHA-phospholipids containing melatonin and tryptophan in elderly patients suffering from mild cognitive impairment. Nutr Neurosci. 15(2): 46–54. 2012. PMID: 22334085. 10.1179/1476830511Y.0000000032 KQ4E3b, KQ5E3b22334085
413 Rosa IM, Henriques AG, Wiltfang J, . Putative Dementia Cases Fluctuate as a Function of Mini-Mental State Examination Cut-Off Points. Journal of Alzheimer’s Disease. 2018;61(1):157–67. PMID: 29125486. KQ2E7c29125486
414 Rosa IM, Henriques AG, Carvalho L, . Screening Younger Individuals in a Primary Care Setting Flags Putative Dementia Cases and Correlates Gastrointestinal Diseases with Poor Cognitive Performance. Dement Geriatr Cogn Disord. 2017;43(1–2):15–28. PMID: 27907913. KQ2E827907913
415 Rosell-Clari, V, Gonzalez, BV. Theory of Mind (ToM) and language: stimulating metalinguistic skills in people with dementia. Codas. 0(): 0. 2016. PMID: 27356191. 10.1590/2317-1782/20162015295 KQ4E5, KQ5E527356191
416 Roth, DL, Mittelman, MS, . Changes in social support as mediators of the impact of a psychosocial intervention for spouse caregivers of persons with Alzheimer’s disease. Psychol Aging. 20(4): 634–644. 2005. 10.1037/0882-7974.20.4.634 KQ4E2b, KQ5E2b16420138
417 Russo, G, Russo, MJ, . Utility of the Spanish version of the FTLD-modified CDR in the diagnosis and staging in frontotemporal lobar degeneration. J Neurol Sci. 344(1–2): 63–8. 2014. PMID: 25015844. 10.1016/j.jns.2014.06.024 KQ2E4e25015844
418 Sacco, G, Caillaud, C, . Exercise Plus Cognitive Performance over and above Exercise Alone in Subjects with Mild Cognitive Impairment. J Alzheimers Dis. 50(1): 19–25. 2015. 10.3233/JAD-150194 KQ4E2b, KQ5E2b
419 Salva, A. Health and nutritional promotion program for patients with dementia (Nutrialz Study): design and baseline data. J Nutr Health Aging. 14(1): 78. 2010. KQ4E5, KQ5E520162844
420 Sanchez, MA, Lourenco, RA. Screening for dementia: Brazilian version of the Informant Questionnaire on Cognitive Decline on the Elderly and its psychometric properties. Geriatr Gerontol Int. 13(3): 687–93. 2013. PMID: 23186020. 10.1111/j.1447-0594.2012.00966.x KQ2E3a23186020
421 Santos, Gd, Nunes, Pv, . Multidisciplinary rehabilitation program: effects of a multimodal intervention for patients with Alzheimer’s disease and cognitive impairment without dementia. Revista de psiquiatria clinica. 42(6): 153–156. 2015. 10.1590/0101-60830000000066 KQ4E3a, KQ5E3a
422 Satoh, S, Kajiwara, M, . Rivastigmine patch and massage for Alzheimer’s disease patients. Geriatr Gerontol Int. 13(2): 515–6. 2013. PMID: 23551354. 10.1111/ggi.12010 KQ4E2b, KQ5E2b23551354
423 Savulich, G, Piercy, T, . Cognitive Training Using a Novel Memory Game on an iPad in Patients with Amnestic Mild Cognitive Impairment (aMCI). International Journal of Neuropsychopharmacology. 20(8): 624–633. 2017. PMID: 28898959. 10.1093/ijnp/pyx040 KQ4E2c, KQ5E2c28898959
424 Scharre DW, Chang SI, Nagaraja HN, . Digitally translated Self-Administered Gerocognitive Examination (eSAGE): relationship with its validated paper version, neuropsychological evaluations, and clinical assessments. Alzheimers Res Ther. 2017;9(1):44. PMID: 28655351. KQ2E2d28655351
425 Scharre, DW, Chang, SI, . Self-administered Gerocognitive Examination (SAGE): a brief cognitive assessment Instrument for mild cognitive impairment (MCI) and early dementia. Alzheimer Dis Assoc Disord. 24(1): 64–71. 2010. PMID: 20220323. 10.1097/WAD.0b013e3181b03277 KQ2E3c20220323
426 Schinka, JA, Robinson, DC, . Cognitive change checklist: psychometric characteristics in community-dwelling older adults. American Journal of Geriatric Psychiatry. 20(12): 1070–4. 2012. PMID: 23032479. 10.1097/JGP.0b013e3182702c31 KQ2E3c23032479
427 Schmid, AA, Spangler-Morris, C, . The Home-Based Occupational Therapy Intervention in the Alzheimer’s Disease Multiple Intervention Trial (ADMIT). Occup Ther Ment Health. 31(1): 19–34. 2015. PMID: 26997685. 10.1080/0164212X.2014.1002963 KQ4E8, KQ5E826997685
428 Schmitter-Edgecombe, M, Dyck, DG. Cognitive rehabilitation multi-family group intervention for individuals with mild cognitive impairment and their care-partners. Journal of the International Neuropsychological Society. 20(9): 897–908. 2014. PMID: 25222630. 10.1017/S1355617714000782 KQ4E7c, KQ5E7c25222630
429 Schneider, LS, Olin, JT, . Validity and reliability of the Alzheimer’s Disease Cooperative Study-Clinical Global Impression of Change. The Alzheimer’s Disease Cooperative Study. Alzheimer Dis Assoc Disord. 11 Suppl 2(): S22–32. 1997. PMID: 9236949. KQ2E19236949
430 Schwenk, M, Sabbagh, M, . Sensor-based balance training with motion feedback in people with mild cognitive impairment. J Rehabil Res Dev. 53(6): 945–958. 2016. 10.1682/JRRD.2015.05.0089 KQ4E2c, KQ5E2c28475201
431 Seibert, Johannes, Tracik, Ferenc, . Effectiveness and tolerability of transdermal rivastigmine in the treatment of Alzheimer’s disease in daily practice. Neuropsychiatric Disease and Treatment Vol 8 2012, ArtID 141–147. 8. 2012. KQ4E2a, KQ5E2a
432 Sellami L, Meilleur-Durand S, Chouinard AM, . The Depistage Cognitif de Quebec: A New Clinician’s Tool for Early Recognition of Atypical Dementia. Dement Geriatr Cogn Disord. 2018;46(5–6):310–21. PMID: 30481754. KQ2E2d30481754
433 Sepe-Monti, Micaela, Vanacore, Nicola, . The Savvy Caregiver Program: A probe multicenter randomized controlled pilot trial in caregivers of patients affected by Alzheimer’s disease. J Alzheimers Dis. 54(3): 1235–1246. 2016. 10.3233/JAD-160235 KQ4E7c, KQ5E7c27567824
434 Servello A, Ettorre E, Cacciafesta M. Improvement in behavioral and psychological symptoms of dementia by rivastigmine patch in a group of Italian elderly patients with Alzheimer’s disease. Panminerva medica. 2017;59(3):275–7. PMID: 28665099. KQ4E2c, KQ5E2c28665099
435 Shaaban, Juwita, Aziz, Aniza Abdul, . Validation of the Malay version of Rowland Universal Dementia Assessment Scale (M_RUDAS) among elderly attending primary care clinic. International Medical Journal. 20(5): 555–558. 2013. KQ2E3a
436 Shaik, MA, Xu, X, . The reliability and validity of the informant AD8 by comparison with a series of cognitive assessment tools in primary healthcare. Int Psychogeriatr. 28(3): 443–52. 2016. PMID: 26489991. 10.1017/S1041610215001702 KQ2E526489991
437 Sheffrin, M, Miao, Y, . Weight Loss Associated with Cholinesterase Inhibitors in Individuals with Dementia in a National Healthcare System. J Am Geriatr Soc. 63(8): 1512–8. 2015. PMID: 26234945. 10.1111/jgs.13511 KQ5E7c26234945
438 Shelton, Jt, Lee, Jh, . Improving Prospective Memory in Healthy Older Adults and Individuals with Very Mild Alzheimer’s Disease. J Am Geriatr Soc. 64(6): 1307–1312. 2016. PMID: Pubmed 27321610. 10.1111/jgs.14134 KQ4E2b, KQ5E2b27321610
439 Shim, Y, Ryu, HJ, . Literacy Independent Cognitive Assessment: Assessing Mild Cognitive Impairment in Older Adults with Low Literacy Skills. Psychiatry Investig. 12(3): 341–8. 2015. PMID: 26207127. 10.4306/pi.2015.12.3.341 KQ2E6a26207127
440 Silva, Ana Rita, Pinho, Maria Salome, . It is not only memory: Effects of sensecam on improving well-being in patients with mild Alzheimer disease. Int Psychogeriatr. 29(5): 741–754. 2017. 10.1017/S104161021600243X KQ4E7c, KQ5E7c28124633
441 Silva, AR, Pinho, MS, . The Cognitive Effects of Wearable Cameras in Mild Alzheimer Disease - An Experimental Study. Curr Alzheimer Res. 14(12): 1270–1282. 2017. PMID: 28558637. 10.2174/1567205014666170531083015 KQ4E8, KQ5E828558637
442 Simon S, Hampstead B, Nucci M, . Cognitive and Brain Activity Changes After Mnemonic Strategy Training in Amnestic Mild Cognitive Impairment: evidence From a Randomized Controlled Tria. Frontiers in aging neuroscience. 2018;10. PMID: 30483113. KQ4E3a, KQ5E3a30483113
443 Sink, KM, Espeland, MA, . The LIFE Cognition Study: design and baseline characteristics. Clin Interv Aging. 9(): 1425–36. 2014. PMID: 25210447. 10.2147/CIA.S65381 KQ4E1b, KQ5E1b25210447
444 Skorga, P, Young, CF. Mini-Mental State Examination for the Detection of Alzheimer Disease and Other Dementias in People With Mild Cognitive Impairment. Clinical Nurse Specialist. 29(5): 265–7. 2015. PMID: 26258833. 10.1097/NUR.0000000000000150 KQ2E126258833
445 Smith, K, Flicker, L, . The KICA Carer: informant information to enhance the Kimberley Indigenous Cognitive Assessment. Int Psychogeriatr. 28(1): 101–7. 2016. PMID: 26272042. 10.1017/S1041610215001283 KQ2E4a26272042
446 Smith, KE. Assessment and prevalence of dementia in Indigenous Australians. School of Primary, Aboriginal and Rural Health Care. Doctor of Philosophy in Medicine. 2008. PMID: None. KQ2E4a
447 Sobol, Na, Hoffmann, K, . Effect of aerobic exercise on physical performance in patients with Alzheimer’s disease. Alzheimer’s & dementia. 2016. 10.1016/j.jalz.2016.05.004 KQ4E5, KQ5E5
448 Sogaard, R, Sorensen, J, . Early psychosocial intervention in Alzheimer’s disease: cost utility evaluation alongside the Danish Alzheimer’s Intervention Study (DAISY). BMJ Open. 4(1): e004105. 2014. PMID: 24435893. 10.1136/bmjopen-2013-004105 KQ4E5, KQ5E524435893
449 Sonali, N, Tripathi, M, . Clinical effectiveness of rivastigmine monotherapy and combination therapy in Alzheimer’s patients. CNS Neurosci Ther. 19(2): 91–7. 2013. PMID: Pubmed 23206182. 10.1111/cns.12036 KQ4E3a, KQ5E3a23206182
450 Sopina E, Sorensen J, Beyer N, . Cost-effectiveness of a randomised trial of physical activity in Alzheimer’s disease: a secondary analysis exploring patient and proxy-reported health-related quality of life measures in Denmark. BMJ Open. 2017;7(6):e015217. PMID: 28615271. KQ4E5, KQ5E528615271
451 Soysal, P, Usarel, C, . Attended With and Head-Turning Sign can be clinical markers of cognitive impairment in older adults. Int Psychogeriatr. 29(11): 1763–1769. 2017. PMID: 28660847. 10.1017/S1041610217001181 KQ2E3a28660847
452 Steinberg, M, Leoutsakos, JM, . Evaluation of a home-based exercise program in the treatment of Alzheimer’s disease: the Maximizing Independence in Dementia (MIND) study. Int J Geriatr Psychiatry. 24(7): 680–685. 2009. PMID: 19089875. KQ4E6c, KQ5E6c19089875
453 Stephenson, A, Seitz, DP, . Cholinesterase inhibitors and adverse pulmonary events in older people with chronic obstructive pulmonary disease and concomitant dementia: a population-based, cohort study. Drugs Aging. 29(3): 213–223. 2012. PMID: 22332932. KQ5E4b22332932
454 Stolley, JM, Reed, D, . Caregiving appraisal and interventions based on the progressively lowered stress threshold model. Am J Alzheimers Dis Other Demen. 17(2): 110–120. 2002. 10.1177/153331750201700211 KQ4E8, KQ5E811954669
455 Strandberg, Te, Kivipelto, M, . Health-related quality of life in a multidomain intervention trial to prevent cognitive decline (FINGER). Eur Geriatr Med. 8(2): 164–167. 2017. 10.1016/j.eurger.2016.12.005 KQ4E1b, KQ5E1b
456 Streater, A, Spector, A, . Maintenance Cognitive Stimulation Therapy (CST) in practice: study protocol for a randomized controlled trial. Trials [Electronic Resource]. 13(): 91. 2012. PMID: 22735077. 10.1186/1745-6215-13-91 KQ4E5, KQ5E522735077
457 Stubendorff, K, Larsson, V, . Treatment effect of memantine on survival in dementia with Lewy bodies and Parkinson’s disease with dementia: a prospective study. BMJ Open. 4(7): e005158. 2014. PMID: 24993765. 10.1136/bmjopen-2014-005158 KQ4E4b, KQ5E4b24993765
458 Sukontapol C, Kemsen S, Chansirikarn S, . The effectiveness of a cognitive training program in people with mild cognitive impairment: A study in urban community. Asian journal of psychiatry. 2018;35:61–6. PMID: 29787954. KQ4E3a, KQ5E3a29787954
459 Sumiyoshi T, Toyomaki A, Kawano N, . Reliability and validity of the California Verbal Learning Test-II - Japanese version. Psychiatry Clin Neurosci. 2017;71(6):417–8. PMID: 28317219. KQ2E3b28317219
460 Sungkarat S, Boripuntakul S, Kumfu S, . Tai Chi Improves Cognition and Plasma BDNF in Older Adults With Mild Cognitive Impairment: A Randomized Controlled Trial. Neurorehabil Neural Repair. 2018;32(2):142–9. PMID: 29353543. KQ4E3a, KQ5E3a29353543
461 Suominen, MH, Puranen, TM, . Nutritional Guidance Improves Nutrient Intake and Quality of Life, and May Prevent Falls in Aged Persons with Alzheimer Disease Living with a Spouse (NuAD Trial). Journal of Nutrition, Health & Aging. 19(9): 901–7. 2015. PMID: 26482691. 10.1007/s12603-015-0558-0 KQ4E6b, KQ5E6b26482691
462 Suttanon, P, Hill, KD, . Feasibility, safety and preliminary evidence of the effectiveness of a home-based exercise programme for older people with Alzheimer’s disease: a pilot randomized controlled trial. Clin Rehabil. 27(5): 427–38. 2013. PMID: 23117349. 10.1177/0269215512460877 KQ4E6c, KQ5E6c23117349
463 Szczesniak, D, Wojtynska, R, . Test Your Memory (TYM) as a screening instrument in clinical practice - the Polish validation study. Aging Ment Health. 17(7): 863–8. 2013. PMID: 23557247. 10.1080/13607863.2013.784957 KQ2E2d23557247
464 Tanaka, S, Honda, S, . Comparison between group and personal rehabilitation for dementia in a geriatric health service facility: single-blinded randomized controlled study. Psychogeriatrics:The Official Journal of the Japanese Psychogeriatric Society. 17(3): 177–185. 2017. PMID: 27612310. 10.1111/psyg.12212 KQ4E3b, KQ5E3b27612310
465 Tariot, P, Salloway, S, . Long-term safety and tolerability of donepezil 23 mg in patients with moderate to severe Alzheimer’s disease. BMC Res Notes. 5(): 283. 2012. PMID: 22681723. 10.1186/1756-0500-5-283 KQ4E4c, KQ5E4c22681723
466 Tariot, PN, Cummings, JL, . A randomized, double-blind, placebo-controlled study of the efficacy and safety of donepezil in patients with Alzheimer’s disease in the nursing home setting. J Am Geriatr Soc. 49(12): 1590–9. 2001. PMID: 11843990. KQ4E3b, KQ5E3b11843990
467 Tariot, PN, Farlow, MR, . Memantine treatment in patients with moderate to severe Alzheimer disease already receiving donepezil: a randomized controlled trial. JAMA. 291(3): 317–24. 2004. PMID: 14734594. 10.1001/jama.291.3.317 KQ4E4c, KQ5E4c14734594
468 Tariot, Pn. Cessation of donepezil is associated with clinical decline in patients with moderate-to-severe Alzheimer’s disease compared to continuation of donepezil or addition or substitution of memantine. Evid Based Med. 18(2): 62–3. 2013. 10.1136/eb-2012-100722 KQ4E5, KQ5E522736656
469 Tarraga, L, Boada, M, . A randomised pilot study to assess the efficacy of an interactive, multimedia tool of cognitive stimulation in Alzheimer’s disease. J Neurol Neurosurg Psychiatry. 77(10): 1116–21. 2006. PMID: 16820420. 10.1136/jnnp.2005.086074 KQ4E2a, KQ5E2a16820420
470 Teipel, SJ, Cavedo, E, . Predictors of cognitive decline and treatment response in a clinical trial on suspected prodromal Alzheimer’s disease. Neuropharmacology. 108(): 128–35. 2016. PMID: 26876309. 10.1016/j.neuropharm.2016.02.005 KQ4E2a, KQ5E2a26876309
471 ten Brinke, LF, Bolandzadeh, N, . Aerobic exercise increases hippocampal volume in older women with probable mild cognitive impairment: a 6-month randomised controlled trial. Br J Sports Med. 49(4): 248–54. 2015. PMID: 24711660. 10.1136/bjsports-2013-093184 KQ4E8, KQ5E824711660
472 Thavorn K, Gomes T, Camacho X, . Upper gastrointestinal bleeding in elderly adults with dementia receiving cholinesterase inhibitors: a population-based cohort study. J Am Geriatr Soc. 2014;62(2):382–4. PMID: 24521369. 10.1111/jgs.12670 KQ2E824521369
473 Thivierge, S, Jean, L, . A randomized cross-over controlled study on cognitive rehabilitation of instrumental activities of daily living in Alzheimer disease. American Journal of Geriatric Psychiatry. 22(11): 1188–99. 2014. PMID: 23871120. 10.1016/j.jagp.2013.03.008 KQ4E7c, KQ5E7c23871120
474 Thomas, A, Iacono, D, . Donepezil, rivastigmine, and vitamin E in Alzheimer disease: a combined P300 event-related potentials/neuropsychologic evaluation over 6 months. Clin Neuropharmacol. 24(1): 31–42. 2001. PMID: 11290880. KQ4E2a, KQ5E2a11290880
475 Thyrian, JR, Eichler, T, . Systematic, early identification of dementia and dementia care management are highly appreciated by general physicians in primary care - results within a cluster-randomized-controlled trial (DelpHi). J Multidiscip Healthc. 9(): 183–90. 2016. PMID: 27143912. 10.2147/JMDH.S96055 KQ4E5, KQ5E527143912
476 Tian, J, Shi, J, . Efficacy and Safety of an Herbal Therapy in Patients with Amnestic Mild Cognitive Impairment: A 24-Week Randomized Phase III Trial. Evidence-Based Complementary & Alternative Medicine: eCAM. 2017(): 4251747. 2017. PMID: 28596794. 10.1155/2017/4251747 KQ4E3a, KQ5E3a28596794
477 Tomata, Y, Sugiyama, K, . Predictive ability of a simple subjective memory complaints scale for incident dementia: Evaluation of Japan’s national checklist, the “Kihon Checklist”. Geriatr Gerontol Int. 17(9): 1300–1305. 2017. PMID: 27506749. 10.1111/ggi.12864 KQ2E127506749
478 Torkamani, M, McDonald, L, . A randomized controlled pilot study to evaluate a technology platform for the assisted living of people with dementia and their carers. J Alzheimers Dis. 41(2): 515–23. 2014. PMID: 24643137. 10.3233/JAD-132156 KQ4E7c, KQ5E7c24643137
479 Tsai, PF, Chang, JY, . A Pilot Cluster-Randomized Trial of a 20-Week Tai Chi Program in Elders With Cognitive Impairment and Osteoarthritic Knee: Effects on Pain and Other Health Outcomes. J Pain Symptom Manage. 2012. PMID: 23017610. KQ4E6c, KQ5E6c23017610
480 Tsutsumimoto, K, Doi, T, . Effects of group exercise programmes on quality of life in older adults with mild cognitive impairment: preliminary results from a randomized controlled trial. Psychogeriatrics:The Official Journal of the Japanese Psychogeriatric Society. 16(5): 327–8. 2016. PMID: 26757136. 10.1111/psyg.12165 KQ4E5, KQ5E526757136
481 Ukawa, S, Yuasa, M, . Randomised controlled pilot study in Japan comparing a home visit program using a Functioning Improvement Tool with a home visit with conversation alone. Australas J Ageing. 31(3): 187–9. 2012. PMID: Pubmed 22950591. 10.1111/j.1741-6612.2012.00589.x KQ4E2b, KQ5E2b22950591
482 Usarel C, Dokuzlar O, Aydin AE, . The AD8 (Dementia Screening Interview) is a valid and reliable screening scale not only for dementia but also for mild cognitive impairment in the Turkish geriatric outpatients. Int Psychogeriatr. 2018:1–7. PMID: 29923472. KQ2E3a29923472
483 Valencia N, Lehrner J. Screening for dementia with the Vienna Visuo-Constructional Test 3.0 screening (VVT 3.0 screening). Neuropsychiatr. 2018. PMID: 29987508. KQ2E2d29987508
484 van den Dungen, P, Moll van Charante, EP, . Case Finding of Mild Cognitive Impairment and Dementia and Subsequent Care; Results of a Cluster RCT in Primary Care. PLoS One. 11(6): e0156958. 2016. PMID: 27310616. 10.1371/journal.pone.0156958 KQ1E1, KQ3E127310616
485 van Der Putt, R, Dineen, C, . Effectiveness of acetylcholinesterase inhibitors: diagnosis and severity as predictors of response in routine practice. Int J Geriatr Psychiatry. 21(8): 755–760. 2006. PMID: 16906631. KQ5E2f16906631
486 Van Mierlo, LD, Meiland, FJ, . Evaluation of DEM-DISC, customized e-advice on health and social support services for informal carers and case managers of people with dementia; a cluster randomized trial. Int Psychogeriatr. 27(8): 1365–78. 2015. PMID: 25872457. 10.1017/S1041610215000423 KQ4E2b25872457
487 Van Mierlo, LD, Wouters, H, . Screening for Mild Cognitive Impairment and Dementia with Automated, Anonymous Online and Telephone Cognitive Self-Tests. J Alzheimers Dis. 56(1): 249–259. 2017. PMID: 27911296. 10.3233/JAD-160566 KQ2E3c27911296
488 Van Mierlo, LisaD, Meiland, FrankaJ, . Personalised caregiver support: Effectiveness of psychosocial interventions in subgroups of caregivers of people with dementia. Int J Geriatr Psychiatry. 27(1): 1–14. 2012. 10.1002/gps.2694 KQ4E2a, KQ5E2a21520288
489 van Uffelen, JG, Chin, Paw MJ A, . The effect of walking and vitamin B supplementation on quality of life in community-dwelling adults with mild cognitive impairment: a randomized, controlled trial. Qual Life Res. 16(7): 1137–1146. 2007. PMID: 17616840. KQ4E8, KQ5E817616840
490 van Uffelen, JG, Chinapaw, MJ, . Walking or vitamin B for cognition in older adults with mild cognitive impairment? A randomised controlled trial. Br J Sports Med. 42(5): 344–351. 2008. PMID: 18308888. KQ4E2b, KQ5E2b18308888
491 van Uffelen, JG, Hopman-Rock, M, . Protocol for Project FACT: a randomised controlled trial on the effect of a walking program and vitamin B supplementation on the rate of cognitive decline and psychosocial wellbeing in older adults with mild cognitive impairment [ISRCTN19227688]. BMC Geriatr. 5(): 18. 2005. PMID: 16375760. KQ4E8, KQ5E816375760
492 Vazquez Gonzalez, FL, Otero Otero, P, . A brief problem-solving indicated-prevention intervention for prevention of depression in nonprofessional caregivers. Psicothema. 25(1): 87–92. 2013. PMID: 23336549. 10.7334/psicothema2012.89 KQ4E8, KQ5E823336549
493 Ventura, T, De-la-Camara, C, . Usefulness of 2 questions about age and year of birth in the case-finding of dementia. J Am Med Dir Assoc. 14(8): 627.e7–12. 2013. PMID: 23773305. 10.1016/j.jamda.2013.05.006 KQ2E123773305
494 Vicente de Sousa O, Soares Guerra R, Sousa AS, . Impact of Nutritional Supplementation and a Psychomotor Program on Patients With Alzheimer’s Disease. American Journal of Alzheimer’s Disease & Other Dementias. 2017;32(6):329–41. PMID: 28446028. KQ4E6b, KQ5E6b28446028
495 Vidal, JS, Lacombe, JM, . Memantine therapy for Alzheimer disease in real-world practice: an observational study in a large representative sample of French patients. Alzheimer Dis Assoc Disord. 22(2): 125–130. 2008. PMID: 18525283. KQ5E118525283
496 Vidoni, EricD, Watts, AmberS, . Feasibility of a memory clinic-based physical activity prescription program. J Alzheimers Dis. 53(1): 161–170. 2016. 10.3233/JAD-160158 KQ4E2c, KQ5E2c27104905
497 Waelde, LC, Meyer, H, . Randomized Controlled Trial of Inner Resources Meditation for Family Dementia Caregivers. J Clin Psychol. 2017. PMID: 28263398. 10.1002/jclp.22470 KQ4E2b, KQ5E2b28263398
498 Waldron-Perrine, B, Axelrod, BN. Determining an appropriate cutting score for indication of impairment on the Montreal Cognitive Assessment. Int J Geriatr Psychiatry. 27(11): 1189–94. 2012. PMID: 22228412. 10.1002/gps.3768 KQ2E3c22228412
499 Wang, CS, Pai, MC, . Montreal Cognitive Assessment and Mini-Mental State Examination performance in patients with mild-to-moderate dementia with Lewy bodies, Alzheimer’s disease, and normal participants in Taiwan. Int Psychogeriatr. 25(11): 1839–48. 2013. PMID: 23919950. 10.1017/S1041610213001245 KQ2E2d23919950
500 Wang, LQ, Chien, WT, . An experimental study on the effectiveness of a mutual support group for family caregivers of a relative with dementia in mainland China. Contemp Nurse. 40(2): 210–24. 2012. PMID: 22554214. 10.5172/conu.2012.40.2.210 KQ4E3a, KQ5E3a22554214
501 Wang, T, Huang, Q, . Effects of memantine on clinical ratings, fluorodeoxyglucose positron emission tomography measurements, and cerebrospinal fluid assays in patients with moderate to severe Alzheimer dementia: a 24-week, randomized, clinical trial. J Clin Psychopharmacol. 33(5): 636–42. 2013. PMID: 23948786. 10.1097/JCP.0b013e31829a876a KQ4E3a23948786
502 Wawrziczny E, Larochette C, Papo D, . A Customized Intervention for Dementia Caregivers: A Quasi-Experimental Design. J Aging Health. 2018:10.1177/0898264318770056. PMID: 29665714. KQ4E2c, KQ5E2c29665714
503 Wei, XH, Ji, LL. Effect of handball training on cognitive ability in elderly with mild cognitive impairment. Neurosci Lett. 566(): 98–101. 2014. PMID: 24582900. 10.1016/j.neulet.2014.02.035 KQ4E3a, KQ5E3a24582900
504 Wei M, Shi J, Li T, . Diagnostic Accuracy of the Chinese Version of the Trail-Making Test for Screening Cognitive Impairment. J Am Geriatr Soc. 2018;66(1):92–9. PMID: 29135021. KQ2E3a29135021
505 Wesson, Jacqueline, Clemson, Lindy, . Measurement of functional cognition and complex everyday activities in older adults with mild cognitive impairment and mild dementia: Validity of the Large Allen’s Cognitive Level Screen. The American Journal of Geriatric Psychiatry. 25(5): 471–482. 2017. 10.1016/j.jagp.2016.11.021 KQ2E3c28238815
506 Whitebird, RR, Kreitzer, M, . Mindfulness-based stress reduction for family caregivers: a randomized controlled trial. Gerontologist. 53(4): 676–86. 2013. PMID: 23070934. 10.1093/geront/gns126 KQ4E2b23070934
507 Whitlatch CJ, Heid AR, Femia EE, . The Support, Health, Activities, Resources, and Education program for early stage dementia: Results from a randomized controlled trial. Dementia (London, England). 2017:10.1177/1471301217743033. PMID: 29171296. KQ4E2c, KQ5E2c29171296
508 Whitney, KA, Mossbarger, B, . Is the montreal cognitive assessment superior to the mini-mental state examination in detecting subtle cognitive impairment among middle-aged outpatient U.S. Military veterans?. Archives of Clinical Neuropsychology. 27(7): 742–8. 2012. PMID: 22763350. 10.1093/arclin/acs060 KQ2E3c22763350
509 Wilcock, J, Iliffe, S, . Tailored educational intervention for primary care to improve the management of dementia: the EVIDEM-ED cluster randomized controlled trial. Trials. 14(): 397. 2013. PMID: Pubmed 24257429. 10.1186/1745-6215-14-397 KQ4E6b, KQ5E6b24257429
510 Williamson JC, Larner AJ. MACE for the Diagnosis of Dementia and MCI: 3-Year Pragmatic Diagnostic Test Accuracy Study. Dement Geriatr Cogn Disord. 2018;45(5–6):300–7. PMID: 29996145. KQ2E4e29996145
511 Wilkinson, D, Roman, G, . The long-term efficacy and tolerability of donepezil in patients with vascular dementia. Int J Geriatr Psychiatry. 25(3): 305–313. 2010. PMID: 19623601. KQ5E2f19623601
512 Wilkinson, DG, Howe, I. Switching from donepezil to galantamine: a double-blind study of two wash-out periods. Int J Geriatr Psychiatry. 20(5): 489–91. 2005. PMID: 15852437. 10.1002/gps.1301 KQ4E2c15852437
513 Williams, K, Herman, R, . Reasoning Exercises in Assisted Living: a cluster randomized trial to improve reasoning and everyday problem solving. Clin Interv Aging. 9(): 981–96. 2014. PMID: 25028542. 10.2147/CIA.S62095 KQ4E6b25028542
514 Wiloth, S, Werner, C, . Motor-cognitive effects of a computerized game-based training method in people with dementia: a randomized controlled trial. Aging Ment Health. 1–12. 2017. PMID: 28682124. 10.1080/13607863.2017.1348472 KQ4E5, KQ5E528682124
515 Wimo, A, Gaudig, M, . The economic impact of galantamine vs placebo: an analysis based on functional capacity in a Swedish cohort study. J Med Econ. 15(5): 1019–24. 2012. PMID: 22519806. 10.3111/13696998.2012.680554 KQ4E5, KQ5E522519806
516 Wimo, A, Winblad, B, . Impact of donepezil treatment for Alzheimer’s disease on caregiver time. Curr Med Res Opin. 20(8): 1221–1225. 2004. PMID: 15324524. KQ4E5, KQ5E515324524
517 Wojtynska, R, Szczesniak, D. DemTect--effective to asses MCI and dementia--validation study of the Polish language version. Aging Ment Health. 20(5): 510–6. 2016. PMID: 25811731. 10.1080/13607863.2015.1023763 KQ2E2d25811731
518 Wolfsgruber, S, Jessen, F, . The CERAD neuropsychological assessment battery total score detects and predicts Alzheimer disease dementia with high diagnostic accuracy. American Journal of Geriatric Psychiatry. 22(10): 1017–28. 2014. PMID: 23759289. 10.1016/j.jagp.2012.08.021 KQ2E6a23759289
519 Wong, A, Fong, CH, . Computerized Cognitive Screen (CoCoSc): A Self-Administered Computerized Test for Screening for Cognitive Impairment in Community Social Centers. J Alzheimers Dis. 59(4): 1299–1306. 2017. PMID: 28731437. 10.3233/JAD-170196 KQ2E7b28731437
520 Wong A, Yiu S, Nasreddine Z, . Validity and reliability of two alternate versions of the Montreal Cognitive Assessment (Hong Kong version) for screening of Mild Neurocognitive Disorder. PLoS ONE [Electronic Resource]. 2018;13(5):e0196344. PMID: 29791452. KQ2E2d29791452
521 Wray, Lo, Wade, M, . A program to improve detection of undiagnosed dementia in primary care and its association with healthcare utilization. American journal of geriatric psychiatry. 22(11): 1282–91. 2014. 10.1016/j.jagp.2013.04.018 KQ1E2a, KQ3E2a23954037
522 Yang, SY, Shan, CL, . The Effects of Aerobic Exercise on Cognitive Function of Alzheimer’s Disease Patients. CNS Neurol Disord Drug Targets. 14(10): 1292–7. 2015. PMID: 26556080. KQ4E3a, KQ5E3a26556080
523 Yatabe, Yusuke, Hashimoto, Mamoru, . Efficacy of increasing donepezil in mild to moderate Alzheimer’s disease patients who show a diminished response to 5 mg donepezil: A preliminary study. Psychogeriatrics. 13(2): 88–93. 2013. 10.1111/psyg.12004 KQ4E2a, KQ5E2a23909965
524 Yeo S, Lee T, Sng W, . Effectiveness of a Personalized Brain-Computer Interface System for Cognitive Training in Healthy Elderly: a Randomized Controlled Trial. Journal of alzheimer’s disease. 2018;66(1):127–38. PMID: 30248056. KQ4E2c, KQ5E2c30248056
525 Yoon BK, Chin J, Kim JW, . Menopausal hormone therapy and mild cognitive impairment: a randomized, placebo-controlled trial. Menopause. 2018;25(8):870–6. PMID: 29846283. KQ4E7c, KQ5E7c29846283
526 Yoon, DH, Kang, D, . Effect of elastic band-based high-speed power training on cognitive function, physical performance and muscle strength in older women with mild cognitive impairment. Geriatr Gerontol Int. 17(5): 765–772. 2017. PMID: 27396580. 10.1111/ggi.12784 KQ4E7c, KQ5E7c27396580
527 Young, DK, Kwok, TC, . A single blind randomized control trial on support groups for Chinese persons with mild dementia. Clin Interv Aging. 9(): 2105–12. 2014. PMID: 25587218. 10.2147/CIA.S68687 KQ4E2c, KQ5E2c25587218
528 Young DK. Multicomponent intervention combining a cognitive stimulation group and tai chi to reduce cognitive decline among community-dwelling older adults with probable dementia: A multi-center, randomized controlled trial. Dementia (London, England). 2018:10.1177/1471301218814637. PMID: 30486656. KQ4E2c, KQ5E2c30486656
529 Young DK, Ng PY, Kwok T, . The effects of an expanded cognitive stimulation therapy model on the improvement of cognitive ability of elderly with mild stage Dementia living in a community - a randomized waitlist controlled trial. Aging Ment Health. 2018:1–8. PMID: 29781725. KQ4E2c, KQ5E2c29781725
530 Young KW. A Randomized Control Study on Psycho-Education Group on Improving Health-Related Quality of Life of Chinese Persons with Major Neurocognitive Disorder. Clinical Gerontologist. 2016;39(5):449–67. PMID: 29471772. KQ4E2c, KQ5E2c29471772
531 Young KW, Ng P, Kwok T, . The effects of holistic health group interventions on improving the cognitive ability of persons with mild cognitive impairment: a randomized controlled trial. Clinical Interventions In Aging. 2017;12:1543–52. PMID: 29026292. KQ4E2c, KQ5E2c29026292
532 Zainal, NH, Silva, E, . Psychometric Properties of Alzheimer’s Disease Assessment Scale-Cognitive Subscale for Mild Cognitive Impairment and Mild Alzheimer’s Disease Patients in an Asian Context. Ann Acad Med Singapore. 45(7): 273–83. 2016. PMID: 27523508. KQ2E2d27523508
533 Zauszniewski, JA, Lekhak, N, . Preliminary Evidence for Effectiveness of Resourcefulness Training in Women Dementia Caregivers. J Fam Med. 3(5). 2016. PMID: 27500286. KQ4E2c, KQ5E2c27500286
534 Zhang, J, Wang, Z, . The effects of CCRC on cognition and brain activity in aMCI patients: a pilot placebo controlled BOLD fMRI study. Curr Alzheimer Res. 11(5): 484–93. 2014. PMID: Pubmed 24801219. KQ4E6b, KQ5E6b24801219
535 Zhang, N, Wei, C, . The Effect of Memantine on Cognitive Function and Behavioral and Psychological Symptoms in Mild-to-Moderate Alzheimer’s Disease Patients. Dement Geriatr Cogn Disord. 40(1–2): 85–93. 2015. PMID: 26066622. 10.1159/000430808 KQ4E3a, KQ5E3a26066622
536 Zhang, Y-P, Miao, R, . Effects of DHA Supplementation on Hippocampal Volume and Cognitive Function in Older Adults with Mild Cognitive Impairment: a 12-Month Randomized, Double-Blind, Placebo-Controlled Trial. J Alzheimers Dis. 55(2): 497–507. 2017. 10.3233/JAD-160439 KQ4E3a, KQ5E3a27716665
537 Zhao, Q, Guo, Q, . The Shape Trail Test: application of a new variant of the Trail making test. PLoS ONE [Electronic Resource]. 8(2): e57333. 2013. PMID: 23437370. 10.1371/journal.pone.0057333 KQ2E3a23437370
538 Zhao, Q, Lv, Y, . Short-term delayed recall of auditory verbal learning test is equivalent to long-term delayed recall for identifying amnestic mild cognitive impairment. PLoS ONE [Electronic Resource]. 7(12): e51157. 2012. PMID: 23236445. 10.1371/journal.pone.0051157 KQ2E3a23236445
539 Zieschang, T, Schwenk, M, . Falls and Physical Activity in Persons With Mild to Moderate Dementia Participating in an Intensive Motor Training: Randomized Controlled Trial. Alzheimer Dis Assoc Disord. 2017. PMID: 28628488. 10.1097/wad.0000000000000201 KQ4E6c, KQ5E6c28628488
540 Zhu Y, Wu H, Qi M, . Effects of a specially designed aerobic dance routine on mild cognitive impairment. Clinical Interventions In Aging. 2018;13:1691–700. PMID: 30237705. KQ4E3a, KQ5E3a30237705
541 Zwingmann I, Michalowsky B, Esser A, . Identifying Unmet Needs of Family Dementia Caregivers: Results of the Baseline Assessment of a Cluster-Randomized Controlled Intervention Trial. Journal of Alzheimer’s Disease. 2018;19:19. PMID: 30584136. KQ4E2a, KQ5E2a30584136