# Appendix C List of Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

## KQ1 and KQ3

1. Fowler N, Perkins A, Gao S, . Risks and benefits of screening for dementia in primary care: the IU CHOICE trial. J Am Geriatr Soc. 2019; Article in Press.

## KQ2

1. Ayalon L. The IQCODE Versus a Single-Item Informant Measure to Discriminate Between Cognitively Intact Individuals and Individuals With Dementia or Cognitive Impairment. J Geriatr Psychiatry Neurol. 2011;24(3):168–73. PMID: 21856971. 10.1177/0891988711418506 21856971
2. Ball LJ, Ogden A, Mandi D, . The validation of a mailed health survey for screening of dementia of the Alzheimer’s type. J Am Geriatr Soc. 2001;49(6):798–802. PMID: 11454121. 10.1046/j.1532-5415.2001.49159.x 11454121
3. Borson S, Scanlan JM, Watanabe J, . Improving identification of cognitive impairment in primary care. Int J Geriatr Psychiatry. 2006;21(4):349–55. PMID: 16534774. 10.1002/gps.1470 16534774
4. Brodaty H, Pond D, Kemp NM, . The GPCOG: a new screening test for dementia designed for general practice. J Am Geriatr Soc. 2002;50(3):530–4. PMID: 11943052. 10.1046/j.1532-5415.2002.50122.x 11943052
  a. Brodaty H, Kemp NM, Low LF. Characteristics of the GPCOG, a screening tool for cognitive impairment. Int J Geriatr Psychiatry. 2004;19(9):870–4. PMID: 15352145. 10.1002/gps.1167 15352145
5. Buschke H, Kuslansky G, Katz M, . Screening for dementia with the memory impairment screen. Neurology. 1999;52(2):231–8. PMID: 9932936. 10.1212/WNL.52.2.231 9932936
6. Callahan CM, Unverzagt FW, Hui SL, . Six-item screener to identify cognitive impairment among potential subjects for clinical research. Med Care. 2002;40(9):771–81. PMID: 12218768. 10.1097/01.MLR.0000024610.33213.C8 12218768
7. Chan QL, Xu X, Shaik MA, . Clinical utility of the informant AD8 as a dementia case finding instrument in primary healthcare. J Alzheimers Dis Rep. 2016;49(1):121–7. PMID: 26444776. 10.3233/JAD-150390 26444776
  a. Chan QL, Shaik MA, Xu J, . The Combined Utility of a Brief Functional Measure and Performance-Based Screening Test for Case Finding of Cognitive Impairment in Primary Healthcare. J Am Med Dir Assoc. 2016;17(4):372.e9–11. PMID: 26857297. 10.1016/j.jamda.2015.12.095 26857297
8. Cook SE, Marsiske M, McCoy KJ. The use of the Modified Telephone Interview for Cognitive Status (TICS-M) in the detection of amnestic mild cognitive impairment. J Geriatr Psychiatry Neurol. 2009;22(2):103–9. PMID: 19417219. 10.1177/0891988708328214 19417219
9. Cruz-Orduna I, Bellon JM, Torrero P, . Detecting MCI and dementia in primary care: efficiency of the MMS, the FAQ and the IQCODE. Fam Pract. 2012;29(4):401–6. PMID: 22121012. 10.1093/fampra/cmr114 22121012
  a. Olazaran J, Torrero P, Cruz I, . Mild cognitive impairment and dementia in primary care: the value of medical history. Fam Pract. 2011;28(4):385–92. PMID: 21402661. 10.1093/fampra/cmr005 21402661
10. Cullen B, Fahy S, Cunningham CJ, . Screening for dementia in an Irish community sample using MMSE: a comparison of norm-adjusted versus fixed cut-points. Int J Geriatr Psychiatry. 2005;20(4):371–6. PMID: 15799072. 10.1002/gps.1291 15799072
  a. Kirby M, Bruce I, Radic A, . Mental disorders among the community-dwelling elderly in Dublin. Br J Psychiatry. 1997;171:369–72. PMID: 9373428. 10.1192/bjp.171.4.369 9373428
11. Cummings-Vaughn LA, Chavakula NN, Malmstrom TK, . Veterans Affairs Saint Louis University Mental Status examination compared with the Montreal Cognitive Assessment and the Short Test of Mental Status. J Am Soc Geriatr Dent. 2014;62(7):1341–6. PMID: 24916485. 10.1111/jgs.12874 24916485
12. Del Ser T, Sanchez-Sanchez F, Garcia de Yebenes MJ, . Validation of the seven-minute screen neurocognitive battery for the diagnosis of dementia in a Spanish population-based sample. Dement Geriatr Cogn Disord. 2006;22(5–6):454–64. PMID: 16988506. 10.1159/000095858 16988506
13. Donnelly K, Donnelly JP, Cory E. Primary care screening for cognitive impairment in elderly veterans. Am J Alzheimers Dis Other Demen. 2008;23(3):218–26. PMID: 18375531. 10.1177/1533317508315932 18375531
14. Ehreke L, Luck T, Luppa M, . Clock drawing test - screening utility for mild cognitive impairment according to different scoring systems: results of the Leipzig Longitudinal Study of the Aged (LEILA 75+). Int Psychogeriatr. 2011;23(10):1592–601. PMID: 21813037. 10.1017/S104161021100144X 21813037
15. Ehreke L, Luppa M, Luck T, . Is the clock drawing test appropriate for screening for mild cognitive impairment?--Results of the German study on Ageing, Cognition and Dementia in Primary Care Patients (AgeCoDe). Dement Geriatr Cogn Disord. 2009;28(4):365–72. PMID: 19887799. 10.1159/000253484 19887799
  a. Winblad B, Palmer K, Kivipelto M, . Mild cognitive impairment--beyond controversies, towards a consensus: report of the International Working Group on Mild Cognitive Impairment. J Intern Med. 2004;256(3):240–6. PMID: 15324367. 10.1111/j.1365-2796.2004.01380.x 15324367
16. Erkinjuntti T, Sulkava R, Wikstrom J, . Short Portable Mental Status Questionnaire as a screening test for dementia and delirium among the elderly. J Am Geriatr Soc. 1987;35(5):412–6. PMID: 3571790. 10.1111/j.1532-5415.1987.tb04662.x 3571790
17. Fillenbaum G, Heyman A, Williams K, . Sensitivity and specificity of standardized screens of cognitive impairment and dementia among elderly black and white community residents. J Clin Epidemiol. 1990;43(7):651–60. PMID: 2370572. 10.1016/0895-4356(90)90035-N 2370572
18. Fong TG, Jones RN, Rudolph JL, . Development and validation of a brief cognitive assessment tool: the sweet 16. Arch Intern Med. 2011;171(5):432–7. PMID: 21059967. 10.1001/archinternmed.2010.423 21059967
19. Fuchs A, Wiese B, Altiner A, . Cued Recall and Other Cognitive Tasks to Facilitate Dementia Recognition in Primary Care. J Am Geriatr Soc. 2012:130–5. PMID: 22150245. 10.1111/j.1532-5415.2011.03765.x 22150245
20. Gagnon M, Letenneur L, Dartigues JF, . Validity of the Mini-Mental State examination as a screening instrument for cognitive impairment and dementia in French elderly community residents. Neuroepidemiology. 1990;9(3):143–50. PMID: 2402325. 10.1159/000110764 2402325
21. Galvin JE, Roe CM, Powlishta KK, . The AD8: a brief informant interview to detect dementia. Neurology. 2005;65(4):559–64. PMID: 16116116. 10.1212/01.wnl.0000172958.95282.2a 16116116
22. Grut M, Fratiglioni L, Viitanen M, . Accuracy of the Mini-Mental Status Examination as a screening test for dementia in a Swedish elderly population. Acta Neurol Scand. 1993;87(4):312–7. PMID: 8503262. 10.1111/j.1600-0404.1993.tb05514.x 8503262
23. Heun R, Papassotiropoulos A, Jennssen F. The validity of psychometric instruments for detection of dementia in the elderly general population. Int J Geriatr Psychiatry. 1998;13(6):368–80. PMID: 9658272.9658272
  a. Heun R, Hardt J, Muller H, . Selection bias during recruitment of elderly subjects from the general population for psychiatric interviews. Eur Arch Psychiatry Clin Neurosci. 1997;247(2):87–92. PMID: 9177954.9177954
24. Holsinger T, Plassman BL, Stechuchak KM, . Screening for Cognitive Impairment: Comparing the Performance of Four Instruments in Primary Care. J Am Geriatr Soc. 2012;60(6):1027–36. PMID: 22646750. 10.1111/j.1532-5415.2012.03967.x 22646750
25. Hooijer C, Dinkgreve M, Jonker C, . Short screening tests for dementia in the elderly population. I. A comparison between AMTS, MMSE, MSQ and SPMSQ. Int J Geriatr Psychiatry. 1992;7(8):559–71. PMID: None. 10.1002/gps.930070805
26. Hsu JL, Fan YC, Huang YL, . Improved predictive ability of the Montreal Cognitive Assessment for diagnosing dementia in a community-based study. Alzheimers Res Ther. 2015;7(1):69. PMID: 26549573. 10.1186/s13195-015-0156-8 26549573
27. Jeong SK, Cho KH, Kim JM. The usefulness of the Korean version of modified Mini-Mental State Examination (K-mMMSE) for dementia screening in community dwelling elderly people. BMC Public Health. 2004;4:31. PMID: 15283869. 10.1186/1471-2458-4-31 15283869
28. Jorm AF, Broe GA, Creasy H, . Further data on the validity of the informant questionnaire on cognitive decline in the elderly (IQCODE). Int J Geriatr Psychiatry. 1996;11(2):131–9. PMID: None. 10.1002/(SICI)1099-1166(199602)11:2<131::AID-GPS294>3.0.CO;2-5
29. Juva K, Makela M, Erkinjuntti T, . Functional assessment scales in detecting dementia. Age Ageing. 1997;26(5):393–400. PMID: 9351484.9351484
30. Kahle-Wrobleski K, Corrada MM, Li B, . Sensitivity and specificity of the mini-mental state examination for identifying dementia in the oldest-old: the 90+ study. J Am Geriatr Soc. 2007;55(2):284–9. PMID: 17302668. 10.1111/j.1532-5415.2007.01049 17302668
31. Kaufer DI, Williams CS, Braaten AJ, . Cognitive screening for dementia and mild cognitive impairment in assisted living: comparison of 3 tests. J Am Med Dir Assoc. 2008;9(8):586–93. PMID: 19083293. 10.1016/j.jamda.2008.05.006 19083293
  a. Zimmerman S, Sloane PD, Williams CS, . Residential care/assisted living staff may detect undiagnosed dementia using the minimum data set cognition scale. J Am Geriatr Soc. 2007;55(9):1349–55. PMID: 17767676. 10.1111/j.1532-5415.2007.01289.x 17767676
32. Kay DW, Henderson AS, Scott R, . Dementia and depression among the elderly living in the Hobart community: the effect of the diagnostic criteria on the prevalence rates. Psychol Med. 1985;15(4):771–88. PMID: 4080881.4080881
33. Kirby M, Denihan A, Bruce I, . The clock drawing test in primary care: sensitivity in dementia detection and specificity against normal and depressed elderly. Int J Geriatr Psychiatry. 2001;16(10):935–40. PMID: 11607936.11607936
34. Kuslansky G, Buschke H, Katz M, . Screening for Alzheimer’s disease: the memory impairment screen versus the conventional three-word memory test. J Am Geriatr Soc. 2002;50(6):1086–91. PMID: 12110070. 10.1046/j.1532-5415.2002.50265.x 12110070
35. Lam LC, Tam CW, Lui VW, . Screening of mild cognitive impairment in Chinese older adults--a multistage validation of the Chinese abbreviated mild cognitive impairment test. Neuroepidemiology. 2008;30(1):6–12. PMID: 18204291. 10.1159/000113300 18204291
36. Lee JY, Dong WL, Cho SJ, . Brief screening for mild cognitive impairment in elderly outpatient clinic: validation of the Korean version of the Montreal Cognitive Assessment. J Geriatr Psychiatry Neurol. 2008;21(2):104–10. PMID: 18474719. 10.1177/0891988708316855 18474719
37. Lee KS, Kim EA, Hong CH, . Clock drawing test in mild cognitive impairment: quantitative analysis of four scoring methods and qualitative analysis. Dement Geriatr Cogn Disord. 2008;26(6):483–9. PMID: 18987468. 10.1159/000167879 18987468
38. Lipton RB, Katz MJ, Kuslansky G, . Screening for dementia by telephone using the memory impairment screen. J Am Geriatr Soc. 2003;51(10):1382–90. PMID: 14511157. 10.1046/j.1532-5415.2003.51455.x 14511157
39. Manly JJ, Schupf N, Stern Y, . Telephone-based identification of mild cognitive impairment and dementia in a multicultural cohort. Arch Neurol. 2011;68(5):607–14. PMID: 21555635. 10.1001/archneurol.2011.88 21555635
  a. Manly JJ, Bell-McGinty S, Tang MX, . Implementing diagnostic criteria and estimating frequency of mild cognitive impairment in an urban community. Arch Neurol. 2005;62(11):1739–46. PMID: 16286549. 10.1001/archneur.62.11.1739 16286549
  b. Tang MX, Cross P, Andrews H, . Incidence of AD in African-Americans, Caribbean Hispanics, and Caucasians in northern Manhattan. Neurology. 2001;56(1):49–56. PMID: 11148235. 10.1212/WNL.56.1.49 11148235
40. Mao HF, Chang LH, Tsai AY, . Diagnostic accuracy of Instrumental Activities of Daily Living for dementia in community-dwelling older adults. Age Ageing. 2018. PMID: 29528375. 10.1093/ageing/afy021 29528375
41. Markwick A, Zamboni G, de Jager CA. Profiles of cognitive subtest impairment in the Montreal Cognitive Assessment (MoCA) in a research cohort with normal Mini-Mental State Examination (MMSE) scores. J Clin Exp Neuropsychol. 2012;34(7):750–7. PMID: 22468719. 10.1080/13803395.2012.672966 22468719
42. McDowell I, Kristjansson B, Hill GB, . Community screening for dementia: the Mini Mental State Exam (MMSE) and Modified Mini-Mental State Exam (3MS) compared. J Clin Epidemiol. 1997;50(4):377–83. PMID: 9179095. 10.1016/S0895-4356(97)00060-7 9179095
43. Morales JM, Bermejo F, Romero M, . Screening of dementia in community-dwelling elderly through informant report. Int J Geriatr Psychiatry. 1997;12(8):808–16. PMID: 9283925.9283925
44. Ozer S, Noonan K, Burke M, . The validity of the Memory Alteration Test and the Test Your Memory test for community-based identification of amnestic mild cognitive impairment. Alzheimers Dement. 2016;12(9):987–95. PMID: 27149906. 10.1016/j.jalz.2016.03.014 27149906
45. Ranson JM, Kuźma E, Hamilton W, . Predictors of dementia misclassification when using brief cognitive assessments. Neurol Clin Pract. 2018;9(1):1–9. PMID: None. 10.1212/CPJ.0000000000000566
46. Rait G, Burns A, Baldwin R, . Validating screening instruments for cognitive impairment in older South Asians in the United Kingdom. Int J Geriatr Psychiatry. 2000;15(1):54–62. PMID: 10637405.10637405
47. Rait G, Morley M, Burns A, . Screening for cognitive impairment in older African-Caribbeans. Psychol Med. 2000;30(4):957–63. PMID: 11037103.11037103
48. Reischies FM, Geiselmann B. Age-related cognitive decline and vision impairment affecting the detection of dementia syndrome in old age. Br J Psychiatry. 1997;171:449–51. PMID: 9463604. 10.1192/bjp.171.5.449 9463604
49. Rideaux T, Beaudreau SA, Fernandez S, . Utility of the abbreviated Fuld Object Memory Evaluation and MMSE for detection of dementia and cognitive impairment not dementia in diverse ethnic groups. J Alzheimers Dis. 2012;31(2):371–86. PMID: 22555374. 10.3233/JAD-2012-112180 22555374
50. Saxton J, Morrow L, Eschman A, . Computer assessment of mild cognitive impairment. Postgrad Med. 2009;121(2):177–85. PMID: 19332976. 10.3810/pgm.2009.03.1990 19332976
51. Solomon PR, Brush M, Calvo V, . Identifying dementia in the primary care practice. Int Psychogeriatr. 2000;12(4):483–93. PMID: 11263715.11263715
52. Stein J, Luppa M, Kaduszkiewicz H, . Is the Short Form of the Mini-Mental State Examination (MMSE) a better screening instrument for dementia in older primary care patients than the original MMSE? Results of the German study on ageing, cognition, and dementia in primary care patients (AgeCoDe). Psychol Assess. 2015;27(3):895–904. PMID: 25822830. 10.1037/pas0000076 25822830
53. Swearer JM, Drachman DA, Li L, . Screening for dementia in “real world” settings: the cognitive assessment screening test: CAST. Clin Neuropsychol. 2002;16(2):128–35. PMID: 12221476. 10.1076/clin.16.2.128.13235 12221476
54. Tariq SH, Tumosa N, Chibnall JT, . Comparison of the Saint Louis University mental status examination and the mini-mental state examination for detecting dementia and mild neurocognitive disorder--a pilot study. Am J Geriatr Psychiatry. 2006;14(11):900–10. PMID: 17068312. 10.1097/01.JGP.0000221510.33817.86 17068312
  a. Malmstrom TK, Voss VB, Cruz-Oliver DM, . The Rapid Cognitive Screen (RCS): A Point-of-Care Screening for Dementia and Mild Cognitive Impairment. J Nutr Health Aging. 2015;19(7):741–4. PMID: 26193857. 10.1007/s12603-015-0564-2 26193857
55. Tokuhara KG, Valcour VG, Masaki KH, . Utility of the Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) for dementia in a Japanese-American population. Hawaii Med J. 2006;65(3):72–5. PMID: 16724448.16724448
56. Vannier-Nitenberg C, Dauphinot V, Bongue B, . Performance of cognitive tests, individually and combined, for the detection of cognitive disorders amongst community-dwelling elderly people with memory complaints: the EVATEM study. Eur J Neurol. 2016;23(3):554–61. PMID: 26518736. 10.1111/ene.12888 26518736
  a. Vannier-Nitenberg C, Dauphinot V, Bongue B, . Early detection of memory impairment in people over 65 years old consulting at Health Examination Centers for the French health insurance: the EVATEM protocol. BMC Geriatr. 2013;13:55. PMID: 23742705. 10.1186/1471-2318-13-55 23742705
57. Vercambre MN, Cuvelier H, Gayon YA, . Validation study of a French version of the modified telephone interview for cognitive status (F-TICS-m) in elderly women. Int J Geriatr Psychiatry. 2010;25(11):1142–9. PMID: 20054838. 10.10002/gps.2447 20054838
  a. Vercambre MN, Boutron-Ruault MC, Ritchie K, . Long-term association of food and nutrient intakes with cognitive and functional decline: a 13-year follow-up study of elderly French women. Br J Nutr. 2009;102(3):419–27. PMID: 19203415. 10.1017/S0007114508201959 19203415
58. Waite LM, Broe GA, Casey B, . Screening for Dementia Using an Informant Interview. Neuropsychology, development, and cognition Section B, Aging, neuropsychology and cognition. 1998;5(3):194–202. PMID: 25233059. 10.1076/anec.5.3.194.614 25233059
59. Wolf-Klein GP, Silverstone FA, Levy AP, . Screening for Alzheimer’s disease by clock drawing. J Am Geriatr Soc. 1989;37(8):730–4. PMID: 2754158. 10.1111/j.1532-5415.1989.tb02234.x 2754158

## KQ4 & KQ5

### AChEIs and Memantine

1. Agid Y, Dubois B, Anand R, . Efficacy and tolerability of rivastigmine in patients with dementia of the Alzheimer type. Curr Ther Res Clin Exp. 1998;59:837–45. PMID: None. 10.1016/S0011-393X(98)85048-0
2. Auchus AP, Brashear HR, Salloway S, . Galantamine treatment of vascular dementia: a randomized trial. Neurology. 2007;69(5):448–58. PMID: 17664404. 10.1212/01.wnl.0000266625.31615.f6 17664404
3. Bakchine S, Loft H. Memantine treatment in patients with mild to moderate Alzheimer’s disease: results of a randomised, double-blind, placebo-controlled 6-month study.[Republished from J Alzheimers Dis. 2007 Jul;11(4):471–9; PMID: 17656827]. J Alzheimers Dis. 2008;13(1):97–107. PMID: 18334761. 10.3233/JAD-2008-13110 18334761
4. Ballard C, Sauter M, Scheltens P, . Efficacy, safety and tolerability of rivastigmine capsules in patients with probable vascular dementia: the VantagE study. Curr Med Res Opin. 2008;24(9):2561–74. PMID: 18674411. 10.1185/03007990802328142 18674411
5. Black S, Roman GC, Geldmacher DS, . Efficacy and tolerability of donepezil in vascular dementia: positive results of a 24-week, multicenter, international, randomized, placebo-controlled clinical trial. Stroke. 2003;34(10):2323–30. PMID: 12970516. 10.1161/01.STR.0000091396.95360.E1 12970516
6. Brodaty H, Corey-Bloom J, Potocnik FC, . Galantamine prolonged-release formulation in the treatment of mild to moderate Alzheimer’s disease. Dement Geriatr Cogn Disord. 2005;20(2–3):120–32. PMID: 15990426. 10.1159/000086613 15990426
  a. Kavanagh S, Howe I, Brashear HR, . Long-term response to galantamine in relation to short-term efficacy data: pooled analysis in patients with mild to moderate Alzheimer’s disease. Curr Alzheimer Res. 2011;8(2):175–86. PMID: 21222607. 10.2174/156720511795256044 21222607
  b. Kavanagh S, Gaudig M, Van BB, . Galantamine and behavior in Alzheimer disease: analysis of four trials. Acta Neurol Scand. 2011;124(5):302–8. PMID: 21615354. 10.1111/j.1600-0404.2011.01525.x 21615354
7. Burns A, Rossor M, Hecker J, . The effects of donepezil in Alzheimer’s disease - results from a multinational trial. Dement Geriatr Cogn Disord. 1999;10(3):237–44. PMID: 10325453. 10.1159/000017126 10325453
8. Choi SH, Park KW, Na DL, . Tolerability and efficacy of memantine add-on therapy to rivastigmine transdermal patches in mild to moderate Alzheimer’s disease: a multicenter, randomized, open-label, parallel-group study. Curr Med Res Opin. 2011;27(7):1375–83. PMID: 21561398. 10.1185/03007995.2011.582484 21561398
9. Corey-Bloom J, Anand R, Veach J. A randomized trial evaluating the efficacy and safety of ENA 713 (rivastigmine tartrate), a new acetylcholinesterase inhibitor, in patients with mild to moderately severe Alzheimer’s disease. Int J Geriatr Psychopharmacol. 1998;1(2):55–65. PMID: None.
10. Doody RS, Ferris SH, Salloway S, . Donepezil treatment of patients with MCI: a 48-week randomized, placebo-controlled trial. Neurology. 2009;72(18):1555–61. PMID: 19176895. 10.1212/01.wnl.0000344650.95823.03 19176895
11. Dysken MW, Sano M, Asthana S, . Effect of vitamin E and memantine on functional decline in Alzheimer disease: the TEAM-AD VA cooperative randomized trial. JAMA. 2014;311(1):33–44. PMID: 24381967. 10.1001/jama.2013.282834 24381967
  a. Dysken MW, Guarino PD, Vertrees JE, . Vitamin E and memantine in Alzheimer’s disease: clinical trial methods and baseline data. Alzheimers Dement. 2014;10(1):36–44. PMID: 23583234. 10.1016/j.jalz.2013.01.014 23583234
12. Erkinjuntti T, Kurz A, Gauthier S, . Efficacy of galantamine in probable vascular dementia and Alzheimer’s disease combined with cerebrovascular disease: a randomised trial. Lancet. 2002;359(9314):1283–90. PMID: 11965273. 10.1016/S0140-6736(02)08267-3 11965273
  a. Bullock R, Erkinjuntti T, Lilienfeld S. Management of patients with Alzheimer’s disease plus cerebrovascular disease: 12-month treatment with Galantamine. Dement Geriatr Cogn Disord. 2004;17(1–2):29–34. PMID: 14560062. 10.1159/000074140 14560062
  b. Erkinjuntti T, Gauthier S, Bullock R, . Galantamine treatment in Alzheimer’s disease with cerebrovascular disease: responder analyses from a randomized, controlled trial (GAL-INT-6). J Psychopharmacol. 2008;22(7):761–8. PMID: 18308781. 10.1177/0269881107083028 18308781
  c. Erkinjuntti T, Kurz A, Small GW, . An open-label extension trial of galantamine in patients with probable vascular dementia and mixed dementia. Clin Ther. 2003;25(6):1765–82. PMID: 12860497. 10.1016/S0149-2918(03)80168-6 12860497
  d. Kavanagh S, Howe I, Brashear HR, . Long-term response to galantamine in relation to short-term efficacy data: pooled analysis in patients with mild to moderate Alzheimer’s disease. Curr Alzheimer Res. 2011;8(2):175–86. PMID: 21222607. 10.2174/156720511795256044 21222607
  e. Kavanagh S, Gaudig M, Van BB, . Galantamine and behavior in Alzheimer disease: analysis of four trials. Acta Neurol Scand. 2011;124(5):302–8. PMID: 21615354. 10.1111/j.1600-0404.2011.01525.x 21615354
  f. Kurz A. Non-cognitive benefits of galantamine (Reminyl-®) treatment in vascular dementia. Acta Neurol Scand. 2002;106(Suppl178):19–24. PMID: 12492788.12067323
  g. Small G, Erkinjuntti T, Kurz A, . Galantamine in the Treatment of Cognitive Decline in Patients with Vascular Dementia or Alzheimer’s Disease with Cerebrovascular Disease. CNS Drugs. 2003;17(12):905–14. PMID: 12962529. 10.2165/00023210-200317120-00004 12962529
13. Feldman H, Gauthier S, Hecker J, . A 24-week, randomized, double-blind study of donepezil in moderate to severe Alzheimer’s disease.[Erratum appears in Neurology 2001 Dec 11;57(11):2153]. Neurology. 2001;57(4):613–20. PMID: 11524468. 10.1212/WNL.57.4.613 11524468
14. Feldman HH, Lane R, Group S. Rivastigmine: a placebo controlled trial of twice daily and three times daily regimens in patients with Alzheimer’s disease. J Neurol Neurosurg Psychiatry. 2007;78(10):1056–63. PMID: 17353259. 10.1136/jnnp.2006.099424 17353259
15. Ferris S, Schneider L, Farmer M, . A double-blind, placebo-controlled trial of memantine in age-associated memory impairment (memantine in AAMI). Int J Geriatr Psychiatry. 2007;22(5):448–55. PMID: 17117395. 10.1002/gps.1711 17117395
16. Gill SS, Anderson GM, Fischer HD, . Syncope and its consequences in patients with dementia receiving cholinesterase inhibitors: a population-based cohort study. Arch Intern Med. 2009;169(9):867–73. PMID: 19433698. 10.1001/archinternmed.2009.43 19433698
17. Hager K, Baseman A, Nye J, . Effects of galantamine in a 2-year, randomized, placebo-controlled study in Alzheimer’s disease. Neuropsychiatr Dis Treat. 2014;10:391–401. PMID: 24591834. 10.2147/NDT.S57909 24591834
18. Hernandez RK, Farwell W, Cantor MD, . Cholinesterase inhibitors and incidence of bradycardia in patients with dementia in the veterans affairs new England healthcare system. J Am Geriatr Soc. 2009;57(11):1997–2003. PMID: 19793162. 10.1111/j.1532-5415.2009.02488.x 19793162
19. Herrmann N, Gauthier S, Boneva N, . A randomized, double-blind, placebo-controlled trial of memantine in a behaviorally enriched sample of patients with moderate-to-severe Alzheimer’s disease. Int Psychogeriatr. 2013;25(6):919–27. PMID: 23472619. 10.1017/S1041610213000239 23472619
20. Holmes C, Wilkinson D, Dean C, . The efficacy of donepezil in the treatment of neuropsychiatric symptoms in Alzheimer disease. Neurology. 2004;63(2):214–9. PMID: 15277611. 10.1212/01.WNL.0000129990.32253.7B 15277611
21. Ikeda M, Mori E, Matsuo K, . Donepezil for dementia with Lewy bodies: a randomized, placebo-controlled, confirmatory phase III trial. Alzheimers Res Ther. 2015;7(1):4. PMID: 25713599. 10.1186/s13195-014-0083-0 25713599
  a. Mori E, Ikeda M, Nagai R, . Long-term donepezil use for dementia with Lewy bodies: results from an open-label extension of Phase III trial. Alzheimers Res Ther. 2015;7(1):5. PMID: 25713600. 10.1186/s13195-014-0081-2 25713600
  b. Mori E, Ikeda M, Nakagawa M, . Pretreatment Cognitive Profile Likely to Benefit from Donepezil Treatment in Dementia with Lewy Bodies: Pooled Analyses of Two Randomized Controlled Trials. Dement Geriatr Cogn Disord. 2016;42(1–2):58–68. PMID: 27537084. 10.1159/000447586 27537084
  c. Mori E, Ikeda M, Nakai K, . Increased plasma donepezil concentration improves cognitive function in patients with dementia with Lewy bodies: An exploratory pharmacokinetic/pharmacodynamic analysis in a phase 3 randomized controlled trial. J Neurol Sci. 2016;366:184–90. PMID: 27288803. 10.1016/j.jns.2016.05.001 27288803
22. Krishnan KR, Charles HC, Doraiswamy PM, . Randomized, placebo-controlled trial of the effects of donepezil on neuronal markers and hippocampal volumes in Alzheimer’s disease. Am J Psychiatry. 2003;160(11):2003–11. PMID: 14594748. 10.1176/appi.ajp.160.11.2003 14594748
23. Mazza M, Capuano A, Bria P, . Ginkgo biloba and donepezil: a comparison in the treatment of Alzheimer’s dementia in a randomized placebo-controlled double-blind study. Eur J Neurol. 2006;13(9):981–5. PMID: 16930364. 10.1111/j.1468-1331.2006.01409.x 16930364
24. McKeith I, Del Ser T, Spano P, . Efficacy of rivastigmine in dementia with Lewy bodies: a randomised, double-blind, placebo-controlled international study. Lancet. 2000;356(9247):2031–6. PMID: 11145488. 10.1016/S0140-6736(00)03399-7 11145488
25. Mohs RC, Doody RS, Morris JC, . A 1-year, placebo-controlled preservation of function survival study of donepezil in AD patients. Neurology. 2001;57(3):481–8. PMID: 11502917. 10.1212/WNL.57.3.481 11502917
26. Mok V, Wong A, Ho S, . Rivastigmine in Chinese patients with subcortical vascular dementia. Neuropsychiatr Dis Treat. 2007;3(6):943–8. PMID: 19300631. 10.2147/NDT.S2221 19300631
27. Mori E, Ikeda M, Kosaka K. Donepezil for dementia with Lewy bodies: a randomized, placebo-controlled trial. Ann Neurol. 2012;72(1):41–52. PMID: 22829268. 10.1002/ana.23557 22829268
  a. Ikeda M, Mori E, Kosaka K, . Long-term safety and efficacy of donepezil in patients with dementia with Lewy bodies: results from a 52-week, open-label, multicenter extension study. Dement Geriatr Cogn Disord. 2013;36(3–4):229–41. PMID: 23949147. 10.1159/000351672 23949147
28. Orgogozo JM, Rigaud AS, Stoffler A, . Efficacy and safety of memantine in patients with mild to moderate vascular dementia: a randomized, placebo-controlled trial (MMM 300). Stroke. 2002;33(7):1834–9. PMID: 12105362. 10.1161/01.STR.0000020094.08790.49 12105362
29. Peskind ER, Potkin SG, Pomara N, . Memantine treatment in mild to moderate Alzheimer disease: a 24-week randomized, controlled trial. Am J Geriatr Psychiatry. 2006;14(8):704–15. PMID: 16861375. 10.1097/01.JGP.0000224350.82719.83 16861375
  a. Pomara N, Ott BR, Peskind E, . Memantine treatment of cognitive symptoms in mild to moderate Alzheimer disease: secondary analyses from a placebo-controlled randomized trial. Alzheimer Dis Assoc Disord. 2007;21(1):60–4. PMID: 17334274. 10.1097/WAD.0b013e318032cf29 17334274
30. Peters O, Fuentes M, Joachim L, . Combined treatment with memantine and galantamine-CR compared with galantamine-CR only in antidementia drug naive patients with mild-to-moderate Alzheimer’s disease. Alzheimers Dement (N Y). 2015;1(3):198–204. PMID: 29854939. 10.1016/j.trci.2015.10.001 29854939
31. Petersen RC, Thomas RG, Grundman M, . Vitamin E and donepezil for the treatment of mild cognitive impairment. NEJM. 2005;352(23):2379–88. PMID: 15829527. 10.1056/NEJMoa050151 15829527
  a. Lu PH, Edland SD, Teng E, . Donepezil delays progression to AD in MCI subjects with depressive symptoms. Neurology. 2009;72(24):2115–21. PMID: 19528519. 10.1212/WNL.0b013e3181aa52d3 19528519
32. Porsteinsson AP, Grossberg GT, Mintzer J, . Memantine treatment in patients with mild to moderate Alzheimer’s disease already receiving a cholinesterase inhibitor: a randomized, double-blind, placebo-controlled trial. Curr Alzheimer Res. 2008;5(1):83–9. PMID: 18288936. 10.2174/156720508783884576 18288936
  a. Atri A, Molinuevo J, Lemming O, . Memantine in patients with Alzheimer’s disease receiving donepezil: New analyses of efficacy and safety for combination therapy. Alzheimers Res Ther. 2013;5(6). PMID: 23336974. 10.1186/alzrt160 23336974
33. Raskind MA, Peskind ER, Wessel T, . Galantamine in AD: A 6-month randomized, placebo-controlled trial with a 6-month extension. The Galantamine USA-1 Study Group. Neurology. 2000;54(12):2261–8. PMID: 10881250. 10.1212/WNL.54.12.2261 10881250
  a. Kavanagh S, Howe I, Brashear HR, . Long-term response to galantamine in relation to short-term efficacy data: pooled analysis in patients with mild to moderate Alzheimer’s disease. Curr Alzheimer Res. 2011;8(2):175–86. PMID: 21222607. 10.2174/156720511795256044 21222607
  b. Raskind MA, Peskind ER, Truyen L, . The cognitive benefits of galantamine are sustained for at least 36 months: a long-term extension trial. Arch Neurol. 2004;61(2):252–6. PMID: 14967774. 10.1001/archneur.61.2.252 14967774
  c. Sano M, Wilcock GK, Van BB, . The effects of galantamine treatment on caregiver time in Alzheimer’s disease. Int J Geriatr Psychiatry. 2003;18(10):942–50. PMID: 14533127. 10.1002/gps.1000 14533127
  d. Winblad B, Jelic V, Kershaw P, . Effects of statins on cognitive function in patients with Alzheimer’s disease in galantamine clinical trials. Drugs Aging. 2007;24(1):57–61. PMID: 17233547. 10.2165/00002512-200724010-00004 17233547
34. Rockwood K, Fay S, Song X, . Attainment of treatment goals by people with Alzheimer’s disease receiving galantamine: a randomized controlled trial. CMAJ. 2006;174(8):1099–105. PMID: 16554498. 10.1503/cmaj.051432 16554498
  a. Rockwood K, Fay S, Jarrett P, . Effect of galantamine on verbal repetition in AD: a secondary analysis of the VISTA trial. Neurology. 2007;68(14):1116–21. PMID: 17404193. 10.1212/01.wnl.0000258661.61577.b7 17404193
35. Rockwood K, Mintzer J, Truyen L, . Effects of a flexible galantamine dose in Alzheimer’s disease: a randomised, controlled trial. J Neurol Neurosurg Psychiatry. 2001;71(5):589–95. PMID: 11606667. 10.1136/jnnp.71.5.589 11606667
  a. Kavanagh S, Howe I, Brashear HR, . Long-term response to galantamine in relation to short-term efficacy data: pooled analysis in patients with mild to moderate Alzheimer’s disease. Curr Alzheimer Res. 2011;8(2):175–86. PMID: 21222607. 10.2174/156720511795256044 21222607
  b. Kavanagh S, Gaudig M, Van BB, . Galantamine and behavior in Alzheimer disease: analysis of four trials. Acta Neurol Scand. 2011;124(5):302–8. PMID: 21615354. 10.1111/j.1600-0404.2011.01525.x 21615354
  c. Raskind MA, Peskind ER, Truyen L, . The cognitive benefits of galantamine are sustained for at least 36 months: a long-term extension trial. Arch Neurol. 2004;61(2):252–6. PMID: 14967774. 10.1001/archneur.61.2.252 14967774
36. Rogers SL, Doody RS, Mohs RC, . Donepezil improves cognition and global function in Alzheimer disease: a 15-week, double-blind, placebo-controlled study. Donepezil Study Group. Arch Intern Med. 1998;158(9):1021–31. PMID: 9588436. 10.1001/archinte.158.9.1021 9588436
  a. Geldmacher DS, Provenzano G, McRae T, . Donepezil is associated with delayed nursing home placement in patients with Alzheimer’s disease. J Am Geriatr Soc. 2003;51(7):937–44. PMID: 12834513. 10.1046/j.1365-2389.2003.51306.x 12834513
37. Rogers SL, Friedhoff LT. The efficacy and safety of donepezil in patients with Alzheimer’s disease: results of a US Multicentre, Randomized, Double-Blind, Placebo-Controlled Trial. The Donepezil Study Group. Dementia. 1996;7(6):293–303. PMID: 8915035. 10.1159/000106895 8915035
38. Rosler M, Anand R, Cicin-Sain A, . Efficacy and safety of rivastigmine in patients with Alzheimer’s disease: international randomised controlled trial.[Erratum appears in BMJ 2001 Jun 16;322(7300):1456]. BMJ. 1999;318(7184):633–8. PMID: 10066203. 10.1136/bmj.318.7184.633 10066203
  a. Erkinjuntti T, Skoog I, Lane R, . Rivastigmine in patients with Alzheimer’s disease and concurrent hypertension. Int J Clin Pract. 2002;56(10):791–6. PMID: 12510954.12510954
39. Salloway S, Ferris S, Kluger A, . Efficacy of donepezil in mild cognitive impairment: a randomized placebo-controlled trial. Neurology. 2004;63(4):651–7. PMID: 15326237. 10.1212/01.WNL.0000134664.80320.92 15326237
  a. Salloway S, Correia S, Richardson S. Key lessons learned from short-term treatment trials of cholinesterase inhibitors for amnestic MCI. Int Psychogeriatr. 2008;20(1):40–6. PMID: 17597552. 10.1017/S1041610207005650 17597552
40. Saxton J, Hofbauer RK, Woodward M, . Memantine and functional communication in Alzheimer’s disease: results of a 12-week, international, randomized clinical trial. J Alzheimers Dis. 2012;28(1):109–18. PMID: 21955815. 10.3233/JAD-2011-110947 21955815
41. Seltzer B, Zolnouni P, Nunez M, . Efficacy of donepezil in early-stage Alzheimer disease: a randomized placebo-controlled trial. Arch Neurol. 2004;61(12):1852–6. PMID: 15596605. 10.1001/archneur.61.12.1852 15596605
42. Tariot PN, Solomon PR, Morris JC, . A 5-month, randomized, placebo-controlled trial of galantamine in AD. The Galantamine USA-10 Study Group. Neurology. 2000;54(12):2269–76. PMID: 10881251. 10.1212/WNL.54.12.2269 10881251
  a. Aronson S, Van BB, Kavanagh S, . Optimal dosing of galantamine in patients with mild or moderate Alzheimer’s disease: post Hoc analysis of a randomized, double-blind, placebo-controlled trial. Drugs Aging. 2009;26(3):231–9. PMID: 19358618. 10.2165/00002512-200926030-00004 19358618
  b. Cummings JL, Schneider L, Tariot PN, . Reduction of behavioral disturbances and caregiver distress by galantamine in patients with Alzheimer’s disease. Am J Psychiatry. 2004;161(3):532–8. PMID: 14992980. 10.1176/appi.ajp.161.3.532 14992980
  c. Galasko D, Kershaw PR, Schneider L, . Galantamine Maintains Ability to Perform Activities of Daily Living in Patients with Alzheimer’s Disease. J Am Geriatr Soc. 2004;52(7):1070–6. PMID: 15209643. 10.1111/j.1532-5415.2004.52303.x 15209643
  d. Kavanagh S, Howe I, Brashear HR, . Long-term response to galantamine in relation to short-term efficacy data: pooled analysis in patients with mild to moderate Alzheimer’s disease. Curr Alzheimer Res. 2011;8(2):175–86. PMID: 21222607. 10.2174/156720511795256044 21222607
  e. Kavanagh S, Gaudig M, Van BB, . Galantamine and behavior in Alzheimer disease: analysis of four trials. Acta Neurol Scand. 2011;124(5):302–8. PMID: 21615354. 10.1111/j.1600-0404.2011.01525.x 21615354
  f. Winblad B, Jelic V, Kershaw P, . Effects of statins on cognitive function in patients with Alzheimer’s disease in galantamine clinical trials. Drugs Aging. 2007;24(1):57–61. PMID: 17233547. 10.2165/00002512-200724010-00004 17233547
43. Thavorn K, Gomes T, Camacho X, . Upper gastrointestinal bleeding in elderly adults with dementia receiving cholinesterase inhibitors: a population-based cohort study. J Am Geriatr Soc. 2014;62(2):382–4. PMID: 24521369. 10.1111/jgs.12670 24521369
44. Tune L, Tiseo PJ, Ieni J, . Donepezil HCl (E2020) maintains functional brain activity in patients with Alzheimer disease: results of a 24-week, double-blind, placebo-controlled study. Am J Geriatr Psychiatry. 2003;11(2):169–77. PMID: 12611746. 10.1097/00019442-200303000-00007 12611746
45. Wilcock G, Mobius HJ, Stoffler A. A double-blind, placebo-controlled multicentre study of memantine in mild to moderate vascular dementia (MMM500). Int Clin Psychopharmacol. 2002;17(6):297–305. PMID: 12409683. 10.1212/WNL.54.12.2269 12409683
46. Wilcock GK, Lilienfeld S, Gaens E. Efficacy and safety of galantamine in patients with mild to moderate Alzheimer’s disease: multicentre randomised controlled trial. Galantamine International-1 Study Group.[Erratum appears in BMJ 2001 Feb 17;322(7283):405]. BMJ. 2000;321(7274):1445–9. PMID: 11110737. 10.1136/bmj.321.7274.1445 11110737
  a. Joffres C, Bucks RS, Haworth J, . Patterns of clinically detectable treatment effects with galantamine: a qualitative analysis. Dement Geriatr Cogn Disord. 2003;15(1):26–33. PMID: 12457076. 10.1159/000066673 12457076
  b. Kavanagh S, Howe I, Brashear HR, . Long-term response to galantamine in relation to short-term efficacy data: pooled analysis in patients with mild to moderate Alzheimer’s disease. Curr Alzheimer Res. 2011;8(2):175–86. PMID: 21222607. 10.2174/156720511795256044 21222607
  c. Sano M, Wilcock GK, Van BB, . The effects of galantamine treatment on caregiver time in Alzheimer’s disease. Int J Geriatr Psychiatry. 2003;18(10):942–50. PMID: 14533127. 10.1002/gps.1000 14533127
  d. Winblad B, Jelic V, Kershaw P, . Effects of statins on cognitive function in patients with Alzheimer’s disease in galantamine clinical trials. Drugs Aging. 2007;24(1):57–61. PMID: 17233547. 10.2165/00002512-200724010-00004 17233547
47. Wilkinson D, Doody R, Helme R, . Donepezil in vascular dementia: A randomized, placebo-controlled study. Neurology. 2003;61(4):479–86. PMID: 12939421. 10.1212/01.WNL.0000078943.50032.FC 12939421
48. Wilkinson D, Fox NC, Barkhof F, . Memantine and brain atrophy in Alzheimer’s disease: a 1-year randomized controlled trial. J Alzheimers Dis. 2012;29(2):459–69. PMID: 22269160. 10.3233/JAD-2011-111616 22269160
49. Wilkinson D, Murray J. Galantamine: a randomized, double-blind, dose comparison in patients with Alzheimer’s disease. Int J Geriatr Psychiatry. 2001;16(9):852–7. PMID: 11571763. 10.1002/gps.409 11571763
50. Winblad B, Cummings J, Andreasen N, . A six-month double-blind, randomized, placebo-controlled study of a transdermal patch in Alzheimer’s disease--rivastigmine patch versus capsule. Int J Geriatr Psychiatry. 2007;22(5):456–67. PMID: 17380489. 10.1002/gps.1788 17380489
  a. Alva G, Grossberg GT, Schmitt FA, . Efficacy of rivastigmine transdermal patch on activities of daily living: item responder analyses. Int J Geriatr Psychiatry. 2011;26(4):356–63. PMID: 21312297. 10.1002/gps.2534 21312297
  b. Cummings JL, Ferris SH, Farlow MR, . Effects of rivastigmine transdermal patch and capsule on aspects of clinical global impression of change in Alzheimer’s disease: a retrospective analysis. Dement Geriatr Cogn Disord. 2010;29(5):406–12. PMID: 20502014. 10.1159/000296073 20502014
  c. Farlow MR, Grossberg GT, Meng X, . Rivastigmine transdermal patch and capsule in Alzheimer’s disease: influence of disease stage on response to therapy. Int J Geriatr Psychiatry. 2011;26(12):1236–43. PMID: 22068922. 10.1002/gps.2669 22068922
  d. Grossberg G, Meng X, Olin JT. Impact of rivastigmine patch and capsules on activities of daily living in Alzheimer’s disease. Am J Alzheimers Dis Other Demen. 2011;26(1):65–71. PMID: 21282280. 10.1177/1533317510391240 21282280
  e. Grossberg GT, Olin JT, Somogyi M, . Dose effects associated with rivastigmine transdermal patch in patients with mild-to-moderate Alzheimer’s disease. Int J Clin Pract. 2011;65(4):465–71. PMID: 21309961. 10.1111/j.1742-1241.2011.02641.x 21309961
  f. Lee JH, Sevigny J. Effects of body weight on tolerability of rivastigmine transdermal patch: a post-hoc analysis of a double-blind trial in patients with Alzheimer disease. Alzheimers Dis Assoc Disord. 2011;25(1):58–62. PMID: 20975519. 10.1097/WAD.0b013e3181f32829 20975519
51. Winblad B, Engedal K, Soininen H, . A 1-year, randomized, placebo-controlled study of donepezil in patients with mild to moderate AD. Neurology. 2001;57(3):489–95. PMID: 11502918. 10.1212/WNL.57.3.489 11502918

### Other Medications and Supplements

1. Aisen PS, Schafer KA, Grundman M, . Effects of rofecoxib or naproxen vs placebo on Alzheimer disease progression: a randomized controlled trial. JAMA. 2003;289(21):2819–26. PMID: 12783912. 10.1001/jama.289.21.2819 12783912
2. Aisen PS, Schneider LS, Sano M, . High-dose B vitamin supplementation and cognitive decline in Alzheimer disease: a randomized controlled trial. JAMA. 2008;300(15):1774–83. PMID: 18854539. 10.1001/jama.300.15.1774 18854539
3. Connelly PJ, Prentice NP, Cousland G, . A randomised double-blind placebo-controlled trial of folic acid supplementation of cholinesterase inhibitors in Alzheimer’s disease. Int J Geriatr Psychiatry. 2008;23(2):155–60. PMID: 17600848. 10.1002/gps.1856 17600848
4. de Jager CA, Oulhaj A, Jacoby R, . Cognitive and clinical outcomes of homocysteine-lowering B-vitamin treatment in mild cognitive impairment: a randomized controlled trial. Int J Geriatr Psychiatry. 2012;27(6):592–600. PMID: 21780182. 10.1002/gps.2758 21780182
5. de Jong D, Jansen R, Hoefnagels W, . No effect of one-year treatment with indomethacin on Alzheimer’s disease progression: a randomized controlled trial. PLoS One. 2008;3(1):e1475. PMID: 18213383. 10.1371/journal.pone.0001475 18213383
6. Dysken MW, Sano M, Asthana S, . Effect of vitamin E and memantine on functional decline in Alzheimer disease: the TEAM-AD VA cooperative randomized trial. JAMA. 2014;311(1):33–44. PMID: 24381967. 10.1001/jama.2013.282834 24381967
  a. Dysken MW, Guarino PD, Vertrees JE, . Vitamin E and memantine in Alzheimer’s disease: clinical trial methods and baseline data. Alzheimers Dement. 2014;10(1):36–44. PMID: 23583234. 10.1016/j.jalz.2013.01.014 23583234
7. Feldman HH, Doody RS, Kivipelto M, . Randomized controlled trial of atorvastatin in mild to moderate Alzheimer disease: LEADe. Neurology. 2010;74(12):956–64. PMID: 20200346. 10.1212/WNL.0b013e3181d6476a 20200346
  a. Jones RW, Kivipelto M, Feldman H, . The Atorvastatin/Donepezil in Alzheimer’s Disease Study (LEADe): design and baseline characteristics. Alzheimers Dement. 2008;4(2):145–53. PMID: 18631958. 10.1016/j.jalz.2008.02.001 18631958
8. Freund-Levi Y, Eriksdotter-Jonhagen M, Cederholm T, . Omega-3 fatty acid treatment in 174 patients with mild to moderate Alzheimer disease: OmegAD study: a randomized double-blind trial. Arch Neurol. 2006;63(10):1402–8. PMID: 17030655. 10.1001/archneur.63.10.1402 17030655
  a. Freund-Levi Y, Basun H, Cederholm T, . Omega-3 supplementation in mild to moderate Alzheimer’s disease: effects on neuropsychiatric symptoms. Int J Geriatr Psychiatry. 2008;23(2):161–9. PMID: 17582225. 10.1002/gps.1857 17582225
9. Henderson VW, Ala T, Sainani KL, . Raloxifene for women with Alzheimer disease: A randomized controlled pilot trial. Neurology. 2015;85(22):1937–44. PMID: 26537053. 10.1212/WNL.0000000000002171 26537053
10. Henderson VW, Paganini-Hill A, Miller BL, . Estrogen for Alzheimer’s disease in women: randomized, double-blind, placebo-controlled trial. Neurology. 2000;54(2):295–301. PMID: 10668686. 10.1212/WNL.54.2.295 10668686
11. Kwok T, Lee J, Law CB, . A randomized placebo controlled trial of homocysteine lowering to reduce cognitive decline in older demented people. Clinical nutrition (Edinburgh, Scotland). 2011;30(3):297–302. PMID: 21216507. 10.1016/j.clnu.2010.12.004 21216507
12. Lu PH, Masterman DA, Mulnard R, . Effects of testosterone on cognition and mood in male patients with mild Alzheimer disease and healthy elderly men. Arch Neurol. 2006;63(2):177–85. PMID: 16344336. 10.1001/archneur.63.2.nct50002 16344336
13. Moonen JE, Foster-Dingley JC, de Ruijter W, . Effect of Discontinuation of Antihypertensive Treatment in Elderly People on Cognitive Functioning--the DANTE Study Leiden: A Randomized Clinical Trial.[Erratum appears in JAMA Intern Med. 2016 Feb;176(2):284; PMID: 26830247]. JAMA Intern Med. 2015;175(10):1622–30. PMID: 26301603. 10.1001/jamainternmed.2015.4103 26301603
14. Mulnard RA, Cotman CW, Kawas C, . Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: A randomized controlled trial [Erratum appears in JAMA 2000 Nov 22–29;284(20):2597]. JAMA. 2000;283(8):1007–15. PMID: 10697060. 10.1001/jama.283.8.1007 10697060
15. Pasqualetti P, Bonomini C, Dal Forno G, . A randomized controlled study on effects of ibuprofen on cognitive progression of Alzheimer’s disease. Aging Clin Exp Res. 2009;21(2):102–10. PMID: 19448381.19448381
16. Petersen RC, Thomas RG, Grundman M, . Vitamin E and donepezil for the treatment of mild cognitive impairment. NEJM. 2005;352(23):2379–88. PMID: 15829527. 10.1056/NEJMoa050151 15829527
  a. Lu PH, Edland SD, Teng E, . Donepezil delays progression to AD in MCI subjects with depressive symptoms. Neurology. 2009;72(24):2115–21. PMID: 19528519. 10.1212/WNL.0b013e3181aa52d3 19528519
17. Phillips MA, Childs CE, Calder PC, . No Effect of Omega-3 Fatty Acid Supplementation on Cognition and Mood in Individuals with Cognitive Impairment and Probable Alzheimer’s Disease: A Randomised Controlled Trial. Int J Mol Sci. 2015;16(10):24600–13. PMID: 26501267. 10.3390/ijms161024600 26501267
18. Quinn JF, Raman R, Thomas RG, . Docosahexaenoic acid supplementation and cognitive decline in Alzheimer disease: a randomized trial. JAMA. 2010;304(17):1903–11. PMID: 21045096. 10.1001/jama.2010.1510 21045096
19. Sano M, Bell KL, Galasko D, . A randomized, double-blind, placebo-controlled trial of simvastatin to treat Alzheimer disease. Neurology. 2011;77(6):556–63. PMID: 21795660. 10.1212/WNL.0b013e318228bf11 21795660
20. Sano M, Ernesto C, Thomas RG, . A controlled trial of selegiline, alpha-tocopherol, or both as treatment for Alzheimer’s disease. The Alzheimer’s Disease Cooperative Study. NEJM. 1997;336(17):1216–22. PMID: 9110909. 10.1056/NEJM199704243361704 9110909
21. Shinto L, Quinn J, Montine T, . A randomized placebo-controlled pilot trial of omega-3 fatty acids and alpha lipoic acid in Alzheimer’s disease. J Alzheimers Dis. 2014;38(1):111–20. PMID: 24077434. 10.3233/JAD-130722 24077434
22. Simons M, Schwarzler F, Lutjohann D, . Treatment with simvastatin in normocholesterolemic patients with Alzheimer’s disease: A 26-week randomized, placebo-controlled, double-blind trial. Ann Neurol. 2002;52(3):346–50. PMID: 12205648. 10.1002/ana.10292 12205648
23. Sinn N, Milte CM, Street SJ, . Effects of n-3 fatty acids, EPA v. DHA, on depressive symptoms, quality of life, memory and executive function in older adults with mild cognitive impairment: a 6-month randomised controlled trial. Br J Nutr. 2012;107(11):1682–93. PMID: 21929835. 10.1017/S0007114511004788 21929835
24. Soininen H, West C, Robbins J, . Long-term efficacy and safety of celecoxib in Alzheimer’s disease. Dement Geriatr Cogn Dis. 2007;23(1):8–21. PMID: 17068392. 10.1159/000096588 17068392
25. Sparks DL, Sabbagh MN, Connor DJ, . Atorvastatin for the treatment of mild to moderate Alzheimer disease: preliminary results. Arch Neurol. 2005;62(5):753–7. PMID: 15883262. 10.1001/archneur.62.5.753 15883262
  a. Sparks DL, Connor DJ, Sabbagh MN, . Circulating cholesterol levels, apolipoprotein E genotype and dementia severity influence the benefit of atorvastatin treatment in Alzheimer’s disease: results of the Alzheimer’s Disease Cholesterol-Lowering Treatment (ADCLT) trial. Acta Neurol Scand. 2006;114:(Suppl 185):3–7. PMID: 16866904. 10.1111/j.1600-0404.2006.00690.x 16866904
  b. Sparks DL, Sabbagh M, Connor D, . Statin therapy in Alzheimer’s disease. Acta Neurol Scand. 2006;114:(Suppl 185):78–86. PMID: 16866915. 10.1111/j.1600-0404.2006.00689.x 16866915
26. Sun Y, Lu CJ, Chien KL, . Efficacy of multivitamin supplementation containing vitamins B6 and B12 and folic acid as adjunctive treatment with a cholinesterase inhibitor in Alzheimer’s disease: a 26-week, randomized, double-blind, placebo-controlled study in Taiwanese patients. Clin Ther. 2007;29(10):2204–14. PMID: 18042476. 10.1016/j.clinthera.2007.10.012 18042476
27. Valen-Sendstad A, Engedal K, Stray-Pedersen B, . Effects of hormone therapy on depressive symptoms and cognitive functions in women with Alzheimer disease: a 12 month randomized, double-blind, placebo-controlled study of low-dose estradiol and norethisterone. Am J Geriatr Psychiatry. 2010;18(1):11–20. PMID: 20094015. 10.1097/JGP.0b013e3181beaaf4 20094015
28. Wang PN, Liao SQ, Liu RS, . Effects of estrogen on cognition, mood, and cerebral blood flow in AD: a controlled study. Neurology. 2000;54(11):2061–6. PMID: 10851363. 10.1212/WNL.54.11.2061 10851363
29. Yurko-Mauro K, McCarthy D, Rom D, . Beneficial effects of docosahexaenoic acid on cognition in age-related cognitive decline. Alzheimers Dement. 2010;6(6):456–64. PMID: 20434961. 10.1016/j.jalz.2010.01.013 20434961

### Nonpharmacologic Patient-Level Interventions

1. Amieva H, Robert PH, Grandoulier AS, . Group and individual cognitive therapies in Alzheimer’s disease: the ETNA3 randomized trial. Int Psychogeriatr. 2016;28(5):707–17. PMID: 26572551. 10.1017/S1041610215001830 26572551
  a. Amieva H, Dartigues JF. ETNA3, a clinical randomized study assessing three cognitive-oriented therapies in dementia: rationale and general design. Rev Neurol (Paris). 2013;169(10):752–6. PMID: 24011983. 10.1016/j.neurol.2013.07.011 24011983
2. Baker LD, Frank LL, Foster-Schubert K, . Effects of aerobic exercise on mild cognitive impairment: a controlled trial. Arch Neurol. 2010;67(1):71–9. PMID: 20065132. 10.1001/archneurol.2009.307 20065132
3. Bae S, Lee S, Lee S, . The effect of a multicomponent intervention to promote community activity on cognitive function in older adults with mild cognitive impairment: A randomized controlled trial. Complement Ther Med. 2019;42:164–9. PMID: 30670238. 10.1016/j.ctim.2018.11.011 30670238
4. Bellantonio S, Kenny AM, Fortinsky RH, . Efficacy of a geriatrics team intervention for residents in dementia-specific assisted living facilities: effect on unanticipated transitions. J Am Geriatr Soc. 2008;56(3):523–8. PMID: 18179497. 10.1111/j.1532-5415.2007.01591.x 18179497
5. Belleville S, Hudon C, Bier N, . MEMO+: Efficacy, Durability and Effect of Cognitive Training and Psychosocial Intervention in Individuals with Mild Cognitive Impairment. J Am Geriatr Soc. 2018;66(4):655–63. PMID: 29313875. 10.1111/jgs.15192 29313875
  a. Bier N, Grenier S, Brodeur C, . Measuring the impact of cognitive and psychosocial interventions in persons with mild cognitive impairment with a randomized single-blind controlled trial: rationale and design of the MEMO+ study. Int Psychogeriatr. 2015;27(3):511–25. PMID: 25268968. 10.1017/S1041610214001902 25268968
6. Bergamaschi S, Arcara G, Calza A, . One-year repeated cycles of cognitive training (CT) for Alzheimer’s disease. Aging Clin Exp Res. 2013;25(4):421–6. PMID: 23784727. 10.1007/s40520-013-0065-2 23784727
7. Blumenthal JA, Smith PJ, Mabe S, . Lifestyle and neurocognition in older adults with cognitive impairments: A randomized trial. Neurology. 2018. PMID: 30568005. 10.1212/WNL.0000000000006784 30568005
8. Burgener SC, Yang Y, Gilbert R, . The effects of a multimodal intervention on outcomes of persons with early-stage dementia. Am J Alzheimers Dis Other Demen. 2008;23(4):382–94. PMID: 18453642. 10.1177/1533317508317527 18453642
9. Buschert VC, Friese U, Teipel SJ, . Effects of a newly developed cognitive intervention in amnestic mild cognitive impairment and mild Alzheimer’s disease: a pilot study. J Alzheimers Dis. 2011;25(4):679–94. PMID: 21483095. 10.3233/JAD-2011-100999 21483095
10. Cahn-Weiner DA, Malloy PF, Rebok GW, . Results of a randomized placebo-controlled study of memory training for mildly impaired Alzheimer’s disease patients. Appl Neuropsychol. 2003;10(4):215–23. PMID: 14690802. 10.1207/s15324826an1004_3 14690802
11. Cavallo M, Hunter EM, van der Hiele K, . Computerized structured cognitive training in patients affected by early-stage Alzheimer’s disease is feasible and effective: A randomized controlled study. Archives of clinical neuropsychology : the official journal of the National Academy of Neuropsychologists. 2016;31(8):868–76. PMID: 27600448. 10.1093/arclin/acw072 27600448
12. Chapman SB, Weiner MF, Rackley A, . Effects of cognitive-communication stimulation for Alzheimer’s disease patients treated with donepezil. J Speech Lang Hear Res. 2004;47(5):1149–63. PMID: 15603468. 10.1044/1092-4388(2004/085) 15603468
13. Cove J, Jacobi N, Donovan H, . Effectiveness of weekly cognitive stimulation therapy for people with dementia and the additional impact of enhancing cognitive stimulation therapy with a carer training program. Clin Interv Aging. 2014;9:2143–50. PMID: 25525349. 10.2147/CIA.S66232 25525349
14. Dawson NT. Examining the effects of a moderate-intensity home-based functional exercise intervention on cognition and function in individuals with dementia. Diss Abstr Int. 2016;76(12-A(E)):No Pagination Specified. PMID: None.
15. Doi T, Verghese J, Makizako H, . Effects of Cognitive Leisure Activity on Cognition in Mild Cognitive Impairment: Results of a Randomized Controlled Trial. J Am Med Dir Assoc. 2017;18(8):686–91. PMID: 28396179. 10.1016/j.jamda.2017.02.013 28396179
16. Duggleby W, Ploeg J, McAiney C, . Web-Based Intervention for Family Carers of Persons with Dementia and Multiple Chronic Conditions (My Tools 4 Care): Pragmatic Randomized Controlled Trial. J Med Internet Res. 2018;20(6):e10484. PMID: 29959111. 10.2196/10484 29959111
17. Fiatarone Singh MA, Gates N, Saigal N, . The Study of Mental and Resistance Training (SMART) study-resistance training and/or cognitive training in mild cognitive impairment: a randomized, double-blind, double-sham controlled trial. J Am Med Dir Assoc. 2014;15(12):873–80. PMID: 25444575. 10.1016/j.jamda.2014.09.010 25444575
  a. Gates NJ, Valenzuela M, Sachdev PS, . Study of Mental Activity and Regular Training (SMART) in at risk individuals: a randomised double blind, sham controlled, longitudinal trial. BMC Geriatr. 2011;11:19. PMID: 21510896. 10.1186/1471-2318-11-19 21510896
  b. Fiatarone Singh MA, Gates N, Saigal N, . Erratum: The study of mental and resistance training (smart) study-resistance training and/or cognitive training in mild cognitive impairment: a randomized, double-blind, double-sham controlled trial. J Am Med Dir Assoc 2014;15: 873–880. J Am Med Dir Assoc. 2016;17(8):765–6. PMID: None. 10.1016/j.jamda.2016.03.003 27470919
  c. Mavros Y, Gates N, Wilson GC, . Mediation of Cognitive Function Improvements by Strength Gains After Resistance Training in Older Adults with Mild Cognitive Impairment: Outcomes of the Study of Mental and Resistance Training. J Am Geriatr Soc. 2017;65(3):550–9. PMID: 28304092. 10.1111/jgs.14542 28304092
18. Greenaway MC, Duncan NL, Smith GE. The memory support system for mild cognitive impairment: randomized trial of a cognitive rehabilitation intervention. Int J Geriatr Psychiatry. 2012. PMID: 22678947. 10.1002/gps.3838 22678947
19. Herrera C, Chambon C, Michel BF, . Positive effects of computer-based cognitive training in adults with mild cognitive impairment. Neuropsychologia. 2012;50(8):1871–81. PMID: 22525705. 10.1016/j.neuropsychologia.2012.04.012 22525705
20. Ho RTH, Fong TCT, Chan WC, . Psychophysiological effects of Dance Movement Therapy and physical exercise on older adults with mild dementia: A randomized controlled trial. J Gerontol B Psychol Sci Soc Sci. 2018. PMID: 30496547. 10.1093/geronb/gby145 30496547
21. Hoffmann K, Sobol NA, Frederiksen KS, . Moderate-to-High Intensity Physical Exercise in Patients with Alzheimer’s Disease: A Randomized Controlled Trial. J Alzheimers Dis. 2016;50(2):443–53. PMID: 26682695. 10.3233/JAD-150817 26682695
  a. Hoffmann K, Frederiksen KS, Sobol NA, . Preserving cognition, quality of life, physical health and functional ability in Alzheimer’s disease: the effect of physical exercise (ADEX trial): rationale and design. Neuroepidemiology. 2013;41(3–4):198–207. PMID: 24135720. 10.1159/000354632 24135720
22. Holthoff VA, Marschner K, Scharf M, . Effects of physical activity training in patients with Alzheimer’s dementia: results of a pilot RCT study. PLoS One. 2015;10(4):e0121478. PMID: 25884637. 10.1371/journal.pone.0121478 25884637
23. Hong SG, Kim JH, Jun TW. Effects of 12-Week Resistance Exercise on Electroencephalogram Patterns and Cognitive Function in the Elderly With Mild Cognitive Impairment: A Randomized Controlled Trial. Clinical journal of sport medicine : official journal of the Canadian Academy of Sport Medicine. 2017. PMID: 28727639. 10.1097/jsm.0000000000000476 28727639
24. Hyer L, Scott C, Atkinson MM, . Cognitive training program to improve working memory in older adults with MCI. Clinical Gerontologist. 2016;39(5):410–27. PMID: 29471774. 10.1080/07317115.2015.1120257 29471774
25. Jelcic N, Cagnin A, Meneghello F, . Effects of lexical-semantic treatment on memory in early Alzheimer disease: an observer-blinded randomized controlled trial. Neurorehabil Neural Repair. 2012;26(8):949–56. PMID: 22460609. 10.1177/1545968312440146 22460609
26. Jeong JH, Na HR, Choi SH, . Group- and Home-Based Cognitive Intervention for Patients with Mild Cognitive Impairment: A Randomized Controlled Trial. Psychother Psychosom. 2016;85(4):198–207. PMID: 27230861. 10.1159/000442261 27230861
27. Jha A, Jan F, Gale T, . Effectiveness of a recovery-orientated psychiatric intervention package on the wellbeing of people with early dementia: a preliminary randomised controlled trial. Int J Geriatr Psychiatry. 2013;28(6):589–96. PMID: 22847712. 10.1002/gps.3863 22847712
28. Kallio EL, Ohman H, Hietanen M, . Effects of Cognitive Training on Cognition and Quality of Life of Older Persons with Dementia. J Am Geriatr Soc. 2018;66(4):664–70. PMID: 29345724. 10.1111/jgs.15196 29345724
29. Karssemeijer EGA, Aaronson JA, Bossers WJR, . The quest for synergy between physical exercise and cognitive stimulation via exergaming in people with dementia: a randomized controlled trial. Alzheimers Res Ther. 2019;11(1):3. PMID: 30611286. 10.1186/s13195-018-0454-z 30611286
  a. Karssemeijer EG, Bossers WJ, Aaronson JA, . The effect of an interactive cycling training on cognitive functioning in older adults with mild dementia: study protocol for a randomized controlled trial. BMC Geriatr. 2017;17(1):73. PMID: 28327083. 10.1186/s12877-017-0464-x 28327083
30. Kinsella GJ, Mullaly E, Rand E, . Early intervention for mild cognitive impairment: a randomised controlled trial. J Neurol Neurosurg Psychiatry. 2009;80(7):730–6. PMID: 19332424. 10.1136/jnnp.2008.148346 19332424
31. Kurz A, Thone-Otto A, Cramer B, . CORDIAL: cognitive rehabilitation and cognitive-behavioral treatment for early dementia in Alzheimer disease: a multicenter, randomized, controlled trial. Alzheimer Dis Assoc Disord. 2012;26(3):246–53. PMID: 21986341. 10.1097/WAD.0b013e318231e46e 21986341
32. Lam LC, Chau RC, Wong BM, . Interim follow-up of a randomized controlled trial comparing Chinese style mind body (Tai Chi) and stretching exercises on cognitive function in subjects at risk of progressive cognitive decline. Int J Geriatr Psychiatry. 2011;26(7):733–40. PMID: 21495078. 10.1002/gps.2602 21495078
33. Lamb SE, Sheehan B, Atherton N, . Dementia And Physical Activity (DAPA) trial of moderate to high intensity exercise training for people with dementia: randomised controlled trial. BMJ. 2018;361:K1675. PMID: 29769247. 10.1136/bmj.k1675 29769247
  a. Atherton N, Bridle C, Brown D, . Dementia and Physical Activity (DAPA) - an exercise intervention to improve cognition in people with mild to moderate dementia: study protocol for a randomized controlled trial. Trials. 2016;17:165. PMID: 27015659. 10.1186/s13063-016-1288-2 27015659
  b. Khan I, Petrou S, Khan K, . Does Structured Exercise Improve Cognitive Impairment in People with Mild to Moderate Dementia? A Cost-Effectiveness Analysis from a Confirmatory Randomised Controlled Trial: The Dementia and Physical Activity (DAPA) Trial. Pharmacoecon Open. 2018. PMID: 30206826. 10.1007/s41669-018-0097-9 30206826
  c. Lamb SE, Mistry D, Alleyne S, . Aerobic and strength training exercise programme for cognitive impairment in people with mild to moderate dementia: the DAPA RCT. Health Technol Assess. 2018;22(28):1–202. PMID: 29848412. 10.3310/hta22280 29848412
34. Lautenschlager NT, Cox KL, Flicker L, . Effect of physical activity on cognitive function in older adults at risk for Alzheimer disease: a randomized trial.[Erratum appears in JAMA. 2009 Jan 21;301(3):276]. JAMA. 2008;300(9):1027–37. PMID: 18768414. 10.1001/jama.300.9.1027 18768414
35. Lazarou I, Parastatidis T, Tsolaki A, . International Ballroom Dancing Against Neurodegeneration: A Randomized Controlled Trial in Greek Community-Dwelling Elders With Mild Cognitive impairment. Am J Alzheimers Dis Other Demen. 2017:1533317517725813. PMID: 28840742. 10.1177/1533317517725813 28840742
36. Liu-Ambrose T, Best JR, Davis JC, . Aerobic exercise and vascular cognitive impairment: A randomized controlled trial. Neurology. 2016;[Epub ahead of print]. PMID: 27760869. 10.1212/wnl.0000000000003332 27760869
  a. Barha CK, Hsiung GR, Best JR, . Sex Difference in Aerobic Exercise Efficacy to Improve Cognition in Older Adults with Vascular Cognitive Impairment: Secondary Analysis of a Randomized Controlled Trial. J Alzheimers Dis. 2017;60(4):1397–410. PMID: 29036816. 10.3233/JAD-170221 29036816
  b. Liu-Ambrose T, Eng JJ, Boyd LA, . Promotion of the mind through exercise (PROMoTE): a proof-of-concept randomized controlled trial of aerobic exercise training in older adults with vascular cognitive impairment. BMC Neurol. 2010;10:14. PMID: 20158920. 10.1186/1471-2377-10-14 20158920
37. Marshall A, Spreadbury J, Cheston R, . A pilot randomised controlled trial to compare changes in quality of life for participants with early diagnosis dementia who attend a ‘Living Well with Dementia’ group compared to waiting-list control. Aging Ment Health. 2015;19(6):526–35. PMID: 25196239. 10.1080/13607863.2014.954527 25196239
38. Morris JK, Vidoni ED, Johnson DK, . Aerobic exercise for Alzheimer’s disease: A randomized controlled pilot trial. PLoS One. 2017;12(2):e0170547. PMID: 28187125. 10.1371/journal.pone.0170547 28187125
  a. Vidoni ED, Van Sciver A, Johnson DK, . A community-based approach to trials of aerobic exercise in aging and Alzheimer’s disease. Contemp Clin Trials. 2012;33(6):1105–16. PMID: 22903151. 10.1016/j.cct.2012.08.002 22903151
39. Nousia A, Siokas V, Aretouli E, . Beneficial Effect of Multidomain Cognitive Training on the Neuropsychological Performance of Patients with Early-Stage Alzheimer’s Disease. Neural Plast. 2018;2018:2845176. PMID: 30123243. 10.1155/2018/2845176 30123243
40. Olazaran J, Muniz R, Reisberg B, . Benefits of cognitive-motor intervention in MCI and mild to moderate Alzheimer disease. Neurology. 2004;63(12):2348–53. PMID: 15623698. 10.1212/01.WNL.0000147478.03911.28 15623698
  a. Olazaran J, Muniz R. Cognitive intervention in the initial stages of Alzheimer’s disease. Res Pract Alzheimers Dis. 2006;11:376–80. PMID: None.
41. Orrell M, Aguirre E, Spector A, . Maintenance cognitive stimulation therapy for dementia: single-blind, multicentre, pragmatic randomised controlled trial. Br J Psychiatry. 2014;204(6):454–61. PMID: 24676963. 10.1192/bjp.bp.113.137414 24676963
  a. Aguirre E, Hoare Z, Spector A, . The effects of a Cognitive Stimulation Therapy [CST] programme for people with dementia on family caregivers’ health. BMC Geriatrics. 2014;14:31. PMID: 24628705. 10.1186/1471-2318-14-31 24628705
  b. Aguirre E, Spector A, Hoe J, . Maintenance Cognitive Stimulation Therapy (CST) for dementia: a single-blind, multi-centre, randomized controlled trial of Maintenance CST vs. CST for dementia. Trials. 2010;11:46. PMID: 20426866. 10.1186/1745-6215-11-46 20426866
  c. Orrell M, Hoe J, Charlesworth G, . Support at Home: Interventions to Enhance Life in Dementia (SHIELD) - evidence, development and evaluation of complex interventions. Programme Grants Appl Res. 2017;5(5). PMID: 28211659. 10.3310/pgfar05050 28211659
42. Orrell M, Yates L, Leung P, . The impact of individual Cognitive Stimulation Therapy (iCST) on cognition, quality of life, caregiver health, and family relationships in dementia: A randomised controlled trial. PLoS Med. 2017;14(3):e1002269. PMID: 28350796. 10.1371/journal.pmed.1002269 28350796
  a. Orgeta V, Leung P, Yates L, . Individual cognitive stimulation therapy for dementia: a clinical effectiveness and cost-effectiveness pragmatic, multicentre, randomised controlled trial. Health Technol Assess. 2015;19(64):1–108. PMID: 26292178. 10.3310/hta19640 26292178
  b. Orrell M, Yates LA, Burns A, . Individual Cognitive Stimulation Therapy for dementia (iCST): study protocol for a randomized controlled trial. Trials. 2012;13:172. PMID: 22998983. 10.1186/1745-6215-13-172 22998983
43. Pantoni L, Poggesi A, Diciotti S, . Effect of Attention Training in Mild Cognitive Impairment Patients with Subcortical Vascular Changes: The RehAtt Study. J Alzheimers Dis. 2017;60(2):615–24. PMID: 28869475. 10.3233/JAD-170428 28869475
  a. Salvadori E, Poggesi A, Valenti R, . The rehabilitation of attention in patients with mild cognitive impairment and brain subcortical vascular changes using the Attention Process Training-II. The RehAtt Study: rationale, design and methodology. Neurol Sci. 2016;37(10):1653–62. PMID: 27371187. 10.1007/s10072-016-2649-z 27371187
44. Pitkälä KH, Pöysti MM, Laakkonen ML, . Effects of the Finnish Alzheimer disease exercise trial (FINALEX): a randomized controlled trial. JAMA Intern Med. 2013;173(10):894–901. PMID: 23589097. 10.1001/jamainternmed.2013.359 23589097
  a. Ohman H, Savikko N, Strandberg T, . Effects of frequent and long-term exercise on neuropsychiatric symptoms in patients with Alzheimer’s disease - Secondary analyses of a randomized, controlled trial (FINALEX). Eur Geriatr Med. 2017;Date of Publication: October 16. PMID: None. 10.1016/j.eurger.2017.01.004
  b. Ohman H, Savikko N, Strandberg T, . Effects of Exercise on Functional Performance and Fall Rate in Subjects with Mild or Advanced Alzheimer’s Disease: Secondary Analyses of a Randomized Controlled Study. Dement Geriatr Cogn Disord. 2016;41(3–4):233–41. PMID: 27160164. 10.1159/000445712 27160164
  c. Ohman H, Savikko N, Strandberg TE, . Effects of Exercise on Cognition: The Finnish Alzheimer Disease Exercise Trial: A Randomized, Controlled Trial. J Am Geriatr Soc. 2016;64(4):731–8. PMID: 27037872. 10.1111/jgs.14059 27037872
  d. Pertilla N, Ohman H, Strandberg T, . Severity of frailty and the outcome of exercise intervention among participants with Alzheimer disease: a sub-group analysis of a randomized controlled trial. Eur Geriatr Med. 2016;7(2):117–21. PMID: None. 10.1016/j.eurger.2015.12.014
  e. Pitkala KH, Raivio MM, Laakkonen ML, . Exercise rehabilitation on home-dwelling patients with Alzheimer’s disease--a randomized, controlled trial. Study protocol. Trials. 2010;11:92. PMID: 20925948. 10.1186/1745-6215-11-92 20925948
  f. Pitkala K, Raivio M, Laakkonen M, . Exercise rehabilitation on home-dwelling patients with Alzheimer disease: A randomized, controlled trial. Baseline findings and feasibility. Eur Geriatr Med. 2011;2(6):338–43. PMID: None. 10.1016/j.eurger.2011.07.012
45. Quayhagen MP, Quayhagen M, Corbeil RR, . A dyadic remediation program for care recipients with dementia. Nurs Res. 1995;44(3):153–9. PMID: 7761291.7761291
46. Quinn C, Toms G, Jones C, . A pilot randomized controlled trial of a self-management group intervention for people with early-stage dementia (The SMART study). Int Psychogeriatr. 2016;28(5):787–800. PMID: 26674087. 10.1017/S1041610215002094 26674087
  a. Quinn C, Anderson D, Toms G, . Self-management in early-stage dementia: a pilot randomised controlled trial of the efficacy and cost-effectiveness of a self-management group intervention (the SMART study). Trials. 2014;15:74. PMID: 24606601. 10.1186/1745-6215-15-74 24606601
47. Rapp S, Brenes G, Marsh AP. Memory enhancement training for older adults with mild cognitive impairment: a preliminary study. Aging Ment Health. 2002;6(1):5–11. PMID: 11827617. 10.1080/13607860120101077 11827617
48. Richard E, Kuiper R, Dijkgraaf MG, . Vascular care in patients with Alzheimer’s disease with cerebrovascular lesions-a randomized clinical trial. J Am Geriatr Soc. 2009;57(5):797–805. PMID: 19484836.19484836
  a. Richard E, Van den HE, Moll van Charante EP, . Prevention of dementia by intensive vascular care (PreDIVA): a cluster-randomized trial in progress. Alzheimer Dis Assoc Disord. 2009;23(3):198–204. PMID: 19812459. 10.1097/WAD.0b013e31819783a4 19812459
49. Rovner BW, Casten RJ, Hegel MT, . Preventing Cognitive Decline in Black Individuals With Mild Cognitive Impairment: A Randomized Clinical Trial. JAMA Neurol. 2018. PMID: 30208380. 10.1001/jamaneurol.2018.2513 30208380
50. Schwenk M, Zieschang T, Oster P, . Dual-task performances can be improved in patients with dementia: a randomized controlled trial. Neurology. 2010;74(24):1961–8. PMID: 20445152. 10.1212/WNL.0b013e3181e39696 20445152
51. Shimada H, Makizako H, Doi T, . Effects of Combined Physical and Cognitive Exercises on Cognition and Mobility in Patients With Mild Cognitive Impairment: A Randomized Clinical Trial. J Am Med Dir Assoc. 2018;19(7):584–91. PMID: 29153754. 10.1016/j.jamda.2017.09.019 29153754
52. Siu MY, Lee DTF. Effects of tai chi on cognition and instrumental activities of daily living in community dwelling older people with mild cognitive impairment. BMC Geriatr. 2018;18(1):37. PMID: 29394884. 10.1186/s12877-018-0720-8 29394884
53. Straubmeier M, Behrndt E-M, Seidl H, . Non-pharmacological treatment in people with cognitive impairment: Results from the randomized controlled German Day Care Study. Dtsch. 2017;114(48):815–21. PMID: 29249224. 10.3238/arztebl.2017.0815 29249224
  a. Behrndt EM, Straubmeier M, Seidl H, . The German day-care study: multicomponent non-drug therapy for people with cognitive impairment in day-care centres supplemented with caregiver counselling (DeTaMAKS) - study protocol of a cluster-randomised controlled trial. BMC Health Serv Res. 2017;17(1):492. PMID: 28716141. 10.1186/s12913-017-2422-x 28716141
54. Suzuki T, Shimada H, Makizako H, . Effects of multicomponent exercise on cognitive function in WMS-LM older adults with amnestic mild cognitive impairment: a randomized controlled trial. BMC Neurol. 2012;12(1):128. PMID: 23113898. 10.1186/1471-2377-12-128 23113898
  a. Suzuki T, Shimada H, Makizako H, . A randomized controlled trial of multicomponent exercise in older adults with mild cognitive impairment. PLoS One. 2013;8(4):e61483. PMID: 23585901. 10.1371/journal.pone.0061483 23585901
55. Train the Brain Consortium. Randomized trial on the effects of a combined physical/cognitive training in aged MCI subjects: the Train the Brain study. Sci. 2017;7:39471. PMID: 28045051. 10.1038/srep39471 28045051
56. Troyer AK, Murphy KJ, Anderson ND, . Changing everyday memory behaviour in amnestic mild cognitive impairment: a randomised controlled trial. Neuropsychol Rehabil. 2008;18(1):65–88. PMID: 17943615. 10.1080/09602010701409684 17943615
57. Tsantali E, Economidis D, Rigopoulou S. Testing the benefits of cognitive training vs. Cognitive stimulation in mild Alzheimer’s disease: A randomised controlled trial. Brain Impair. 2017;18(2):188–96. PMID: None. 10.1017/BrImp.2017.6
58. Tsolaki M, Kounti F, Agogiatou C, . Effectiveness of nonpharmacological approaches in patients with mild cognitive impairment. Neurodegener Dis. 2011;8(3):138–45. PMID: 21135531. 10.1159/000320575 21135531
59. Venturelli M, Lanza M, Muti E, . Positive effects of physical training in activity of daily living-dependent older adults. Exp Aging Res. 2010;36(2):190–205. PMID: 20209421. 10.1080/03610731003613771 20209421
60. Vidovich MR, Lautenschlager NT, Flicker L, . The PACE study: a randomized clinical trial of cognitive activity strategy training for older people with mild cognitive impairment. Am J Geriatr Psychiatry. 2015;23(4):360–72. PMID: 24801607. 10.1016/j.jagp.2014.04.002 24801607
  a. Vidovich MR, Lautenschlager NT, Flicker L, . The PACE study: a randomised clinical trial of cognitive activity (CA) for older adults with mild cognitive impairment (MCI). Trials. 2009;10:114. PMID: 20003398. 10.1186/1745-6215-10-114 20003398
61. Vreugdenhil A, Cannell J, Davies A, . A community-based exercise programme to improve functional ability in people with Alzheimer’s disease: a randomized controlled trial. Scand J Caring Sci. 2012;26(1):12–9. PMID: 21564154. 10.1111/j.1471-6712.2011.00895.x 21564154
62. Wolfs CAG, Kessels A, Dirksen CD, . Integrated multidisciplinary diagnostic approach for dementia care: Randomised controlled trial. Br J Psychiatry. 2008;192(4):300–5. PMID: 18378994. 10.1192/bjp.bp.107.035204 18378994

### Caregiver and Caregiver-Patient Dyad Interventions

1. Barnes CJ, Markham C. A pilot study to evaluate the effectiveness of an individualized and cognitive behavioural communication intervention for informal carers of people with dementia: The Talking Sense programme. Int J Lang Commun Disord. 2018;53(3):615–27. PMID: 29460337. 10.1111/1460-6984.12375 29460337
2. Bass DM, Clark PA, Looman WJ, . The Cleveland Alzheimer’s managed care demonstration: outcomes after 12 months of implementation. Gerontologist. 2003;43(1):73–85. PMID: 12604748. 10.1093/geront/43.1.73 12604748
  a. Bass DM, Judge KS, Snow AL, . A controlled trial of Partners in Dementia Care: veteran outcomes after six and twelve months. Alzheimers Res Ther. 2014;6(1):9. PMID: 24764496. 10.1186/alzrt242 24764496
3. Belle SH, Burgio L, Burns R, . Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial.[Summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I39; PMID: 17116914]. Ann Int Med. 2006;145(10):727–38. PMID: 17116917. 10.7326/0003-4819-145-10-200611210-00005 17116917
  a. Basu R, Hochhalter AK, Stevens AB. The Impact of the REACH II Intervention on Caregivers’ Perceived Health. J Appl Gerontol. 2015;34(5):590–608. PMID: 24652899. 10.1177/0733464813499640 24652899
  b. Elliott AF, Burgio LD, DeCoster J. Enhancing caregiver health: findings from the resources for enhancing Alzheimer’s caregiver health II intervention. J Am Geriatr Soc. 2010;58(1):30–7. PMID: 20122038. 10.1111/j.1532-5415.2009.02631.x 20122038
  c. Hatch DJ, DeHart WB, Norton MC. Subjective stressors moderate effectiveness of a multi-component, multi-site intervention on caregiver depression and burden. Int J Geriatr Psychiatry. 2014;29(4):406–13. PMID: 23983230. 10.1002/gps.4019 23983230
4. Berwig M, Heinrich S, Spahlholz J, . Individualized support for informal caregivers of people with dementia - effectiveness of the German adaptation of REACH II. BMC Geriatr. 2017;17(1):286. PMID: 29233097. 10.1186/s12877-017-0678-y 29233097
  a. Heinrich S, Berwig M, Simon A, . German adaptation of the Resources for Enhancing Alzheimer’s Caregiver Health II: study protocol of a single-centred, randomised controlled trial. BMC Geriatr. 2014;14:21. PMID: 24520910. 10.1186/1471-2318-14-21 24520910
5. Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer’s disease. Nurs Res. 1995;44(3):166–72. PMID: 7761293. 10.1097/00006199-199505000-00007 7761293
  a. Bass DM, McClendon MJ, Brennan PF, . The buffering effect of a computer support network on caregiver strain. J Aging Health. 1998;10(1):20–43. PMID: 10182416. 10.1177/089826439801000102 10182416
6. Bruvik FK, Allore HG, Ranhoff AH, . The effect of psychosocial support intervention on depression in patients with dementia and their family caregivers: an assessor-blinded randomized controlled trial. Dement Geriatr Cogn Dis Extra. 2013;3(1):386–97. PMID: 24348500. 10.1159/000355912 24348500
7. Burgio L, Stevens A, Guy D, . Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. 2003;43(4):568–79. PMID: 12937335.12937335
  a. Gitlin LN, Belle SH, Burgio LD, . Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. 2003;18(3):361–74. PMID: 14518800. 10.1037/0882-7974.18.3.361 14518800
  b. Wisniewski SR, Belle SH, Coon DW, . The Resources for Enhancing Alzheimer’s Caregiver Health (REACH): project design and baseline characteristics. Psychol Aging. 2003;18(3):375–84. PMID: 14518801. 10.1037/0882-7974.18.3.375 14518801
8. Callahan CM, Boustani MA, Unverzagt FW, . Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. 2006;295(18):2148–57. PMID: 16684985. 10.1001/jama.295.18.2148 16684985
9. Chang BL. Cognitive-behavioral intervention for homebound caregivers of persons with dementia. Nurs Res. 1999;48(3):173–82. PMID: 10337848. 10.1097/00006199-199905000-00007 10337848
10. Charlesworth G, Shepstone L, Wilson E, . Befriending carers of people with dementia: randomised controlled trial. BMJ. 2008;336(7656):1295–7. PMID: 18505757. 10.1136/bmj.39549.548831.AE 18505757
  a. Charlesworth G, Shepstone L, Wilson E, . Does befriending by trained lay workers improve psychological well-being and quality of life for carers of people with dementia, and at what cost? A randomised controlled trial. Health Technol Assess. 2008;12(4):iii, v–iii, 78. PMID: 18284895.18284895
11. Chien WT, Lee IY. Randomized controlled trial of a dementia care programme for families of home-resided older people with dementia. J Adv Nurs. 2011;67(4):774–87. PMID: 21198803. 10.1111/j.1365-2648.2010.05537.x 21198803
12. Chien WT, Lee YM. A disease management program for families of persons in Hong Kong with dementia. Psychiatr Serv. 2008;59(4):433–6. PMID: 18378844. 10.1176/ps.2008.59.4.433 18378844
13. Chu H, Yang CY, Liao YH, . The effects of a support group on dementia caregivers’ burden and depression. J Aging Health. 2011;23(2):228–41. PMID: 20847363. 10.1177/0898264310381522 20847363
14. Chu P, Edwards J, Levin R, . The use of clinical case management for early state Alzheimer’s patients and their families. Am J Alzheimers Dis Other Demen. 2000;15(5):284–90. PMID: None. 10.1177/153331750001500506
15. Connell CM, Janevic MR. Effects of a telephone-based exercise intervention for dementia caregiving wives: A randomized controlled trial. J Appl Gerontol. 2009;28(2):171–94. PMID: 21709757. 10.1177/0733464808326951 21709757
16. Coon DW, Thompson L, Steffen A, . Anger and depression management: psychoeducational skill training interventions for women caregivers of a relative with dementia. Gerontologist. 2003;43(5):678–89. PMID: 14570964. 10.1093/geront/43.5.678 14570964
17. Cristancho-Lacroix V, Wrobel J, Cantegreil-Kallen I, . A web-based psychoeducational program for informal caregivers of patients with Alzheimer’s disease: a pilot randomized controlled trial. J Med Internet Res. 2015;17(5):e117. PMID: 25967983. 10.2196/jmir.3717 25967983
  a. Cristancho-Lacroix V, Kerherve H, de Rotrou J, . Evaluating the efficacy of a web-based program (diapason) for informal caregivers of patients with Alzheimer’s disease: protocol for a randomized clinical trial. JMIR Res Protoc. 2013;2(2):e55. PMID: 24317497. 10.2196/resprot.2978 24317497
18. De Rotrou J, Cantegreil I, Faucounau V, . Do patients diagnosed with Alzheimer’s disease benefit from a psycho-educational programme for family caregivers? A randomised controlled study. Int J Geriatr Psychiatry. 2011;26(8):833–42. PMID: 20922772. 10.1002/gps.2611 20922772
19. Ducharme FC, Levesque LL, Lachance LM, . “Learning to become a family caregiver” efficacy of an intervention program for caregivers following diagnosis of dementia in a relative. Gerontologist. 2011;51(4):484–94. PMID: 21383112. 10.1093/geront/gnr014 21383112
  a. Ducharme F, Lachance L, Levesque L, . Persistent and delayed effects of a psycho-educational program for family caregivers at disclosure of dementia diagnosis in a relative: a six-month follow-up study. Healthy Aging Res. 2012;1(2). PMID: None. 10.12715/har.2012.1.2
  b. Ducharme F, Lachance L, Levesque L, . Maintaining the potential of a psycho-educational program: efficacy of a booster session after an intervention offered family caregivers at disclosure of a relative’s dementia diagnosis. Aging Ment Health. 2015;19(3):207–16. PMID: 24943996. 10.1080/13607863.2014.922527 24943996
20. Duggleby W, Ploeg J, McAiney C, . Web-Based Intervention for Family Carers of Persons with Dementia and Multiple Chronic Conditions (My Tools 4 Care): Pragmatic Randomized Controlled Trial. J Med Internet Res. 2018;20(6):e10484. PMID: 29959111. 10.2196/10484 29959111
  a. Duggleby W, Ploeg J, McAiney C, . Web-Based Intervention for Family Carers of Persons with Dementia and Multiple Chronic Conditions (My Tools 4 Care): Pragmatic Randomized Controlled Trial. J Med Internet Res. 2018;20(6):e10484. PMID: 29959111. 10.2196/10484 29959111
21. Eloniemi-Sulkava U, Notkola IL, Hentinen M, . Effects of supporting community-living demented patients and their caregivers: a randomized trial. J Am Geriatr Soc. 2001;49(10):1282–7. PMID: 11890485. 10.1046/j.1532-5415.2001.49255.x 11890485
22. Eloniemi-Sulkava U, Saarenheimo M, Laakkonen ML, . Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. J Am Geriatr Soc. 2009;57(12):2200–8. PMID: 20121986. 10.1111/j.1532-5415.2009.02564.x 20121986
23. Finkel S, Czaja SJ, Schulz R, . E-care: a telecommunications technology intervention for family caregivers of dementia patients. Am J Geriatr Psychiatry. 2007;15(5):443–8. PMID: 17463195. 10.1097/JGP.0b013e3180437d87 17463195
24. Fortinsky RH, Kulldorff M, Kleppinger A, . Dementia care consultation for family caregivers: collaborative model linking an Alzheimer’s association chapter with primary care physicians. Aging Ment Health. 2009;13(2):162–70. PMID: 19347683. 10.1080/13607860902746160 19347683
25. Fung W, Chien W. The effectiveness of a mutual support group for family caregivers of a relative with dementia. Arch Psychiatr Nurs. 2002;16(3):134–44. PMID: 12037799. 10.1053/apnu.2002.32951 12037799
26. Gallagher-Thompson D, Coon DW, Solano N, . Change in indices of distress among Latino and Anglo female caregivers of elderly relatives with dementia: site-specific results from the REACH national collaborative study. Gerontologist. 2003;43(4):580–91. PMID: 12937336. 10.1093/geront/43.4.580 12937336
  a. Gitlin LN, Belle SH, Burgio LD, . Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. 2003;18(3):361–74. PMID: 14518800. 10.1037/0882-7974.18.3.361 14518800
  b. Wisniewski SR, Belle SH, Coon DW, . The Resources for Enhancing Alzheimer’s Caregiver Health (REACH): project design and baseline characteristics. Psychol Aging. 2003;18(3):375–84. PMID: 14518801. 10.1037/0882-7974.18.3.375 14518801
27. Gallagher-Thompson D, Gray HL, Dupart T, . Effectiveness of cognitive/behavioral small group intervention for reduction of depression and stress in non-Hispanic White and Hispanic/Latino women dementia family caregivers: Outcomes and mediators of change. J Ration Emot Cogn Behav Ther. 2008;26(4):286–303. PMID: 25067886. 10.1007/s10942-008-0087-4 25067886
28. Gallagher-Thompson D, Wang PC, Liu W, . Effectiveness of a psychoeducational skill training DVD program to reduce stress in Chinese American dementia caregivers: results of a preliminary study. Aging Ment Health. 2010;14(3):263–73. PMID: 20425645. 10.1080/13607860903420989 20425645
29. Garand L, Rinaldo DE, Alberth MM, . Effects of problem solving therapy on mental health outcomes in family caregivers of persons with a new diagnosis of mild cognitive impairment or early dementia: a randomized controlled trial. Am J Geriatr Psychiatry. 2014;22(8):771–81. PMID: 24119856. 10.1016/j.jagp.2013.07.007 24119856
30. Gaugler JE, Reese M, Mittelman MS. Effects of the NYU caregiver intervention-adult child on residential care placement. Gerontologist. 2013;53(6):985–97. PMID: 23339050. 10.1093/geront/gns193 23339050
  a. Gaugler JE, Reese M, Mittelman MS. Effects of the Minnesota Adaptation of the NYU Caregiver Intervention on Depressive Symptoms and Quality of Life for Adult Child Caregivers of Persons with Dementia. Alzheimers Res Ther. 2015;23(11):1179–92. PMID: 26238226. 10.1016/j.jagp.2015.06.007 26238226
  b. Gaugler JE, Reese M, Mittelman MS. Effects of the Minnesota Adaptation of the NYU Caregiver Intervention on Primary Subjective Stress of Adult Child Caregivers of Persons With Dementia. Gerontologist. 2016;56(3):461–74. PMID: 25628299. 10.1093/geront/gnu125 25628299
  c. Gaugler JE, Reese M, Mittelman MS. Process Evaluation of the NYU Caregiver Intervention-Adult Child. Gerontologist. 2018;58(2):e107–e17. PMID: 29562359. 10.1093/geront/gnx048 29562359
  d. Gaugler JE, Reese M, Mittelman MS. The Effects of a Comprehensive Psychosocial Intervention on Secondary Stressors and Social Support for Adult Child Caregivers of Persons With Dementia. Innov Aging. 2018;2(2):igy015. PMID: 30009268. 10.1093/geroni/igy015 30009268
31. Gitlin LN, Arthur P, Piersol C, . Targeting Behavioral Symptoms and Functional Decline in Dementia: A Randomized Clinical Trial. J Am Geriatr Soc. 2018;66(2):339–45. PMID: 29192967. 10.1111/jgs.15194 29192967
32. Gitlin LN, Corcoran M, Winter L, . A randomized, controlled trial of a home environmental intervention: effect on efficacy and upset in caregivers and on daily function of persons with dementia. Gerontologist. 2001;41(1):4–14. PMID: 11220813. 10.1093/geront/41.1.4 11220813
  a. Gitlin LN, Mann WC, Vogel WB, . A non-pharmacologic approach to address challenging behaviors of Veterans with dementia: description of the tailored activity program-VA randomized trial. BMC Geriatr. 2013;13:96. PMID: 24060106. 10.1186/1471-2318-13-96 24060106
33. Gitlin LN, Winter L, Burke J, . Tailored activities to manage neuropsychiatric behaviors in persons with dementia and reduce caregiver burden: a randomized pilot study. Am J Geriatr Psychiatry. 2008;16(3):229–39. PMID: 18310553. 10.1097/JGP.0b013e318160da72 18310553
34. Gitlin LN, Winter L, Corcoran M, . Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. 2003;43(4):532–46. PMID: 12937332. 10.1093/geront/43.4.532 12937332
  a. Gitlin LN, Belle SH, Burgio LD, . Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. 2003;18(3):361–74. PMID: 14518800. 10.1037/0882-7974.18.3.361 14518800
  b. Wisniewski SR, Belle SH, Coon DW, . The Resources for Enhancing Alzheimer’s Caregiver Health (REACH): project design and baseline characteristics. Psychol Aging. 2003;18(3):375–84. PMID: 14518801. 10.1037/0882-7974.18.3.375 14518801
35. Gitlin LN, Winter L, Dennis MP, . A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. JAMA. 2010;304(9):983–91. PMID: 20810376. 10.1001/jama.2010.1253 20810376
  a. Gitlin LN, Rose K. Impact of caregiver readiness on outcomes of a nonpharmacological intervention to address behavioral symptoms in persons with dementia. Int J Geriatr Psychiatry. 2016;31(9):1056–63. PMID: 26833933. 10.1002/gps.4422 26833933
36. Gitlin LN, Winter L, Dennis MP, . Targeting and managing behavioral symptoms in individuals with dementia: a randomized trial of a nonpharmacological intervention. J Am Geriatr Soc. 2010;58(8):1465–74. PMID: 20662955. 10.1111/j.1532-5415.2010.02971.x 20662955
37. Graff MJ, Vernooij-Dassen MJ, Thijssen M, . Community based occupational therapy for patients with dementia and their care givers: randomised controlled trial. BMJ. 2006;333(7580):1196. PMID: 17114212. 10.1136/bmj.39001.688843.BE 17114212
  a. Graff MJ, Vernooij-Dassen MJ, Thijssen M, . Effects of community occupational therapy on quality of life, mood, and health status in dementia patients and their caregivers: a randomized controlled trial. J Gerontol. 2007;62(9):1002–9. PMID: 17895439. 10.1093/gerona/62.9.1002 17895439
38. Hebert R, Levesque L, Vezina J, . Efficacy of a psychoeducative group program for caregivers of demented persons living at home: a randomized controlled trial. J Gerontol B Psychol Sci Soc Sci. 2003;58(1):S58–S67. PMID: 12496309. 10.1093/geronb/58.1.S58 12496309
39. Hepburn KW, Lewis M, Narayan S, . Partners in Caregiving: A Psychoeducation Program Affecting Dementia Family Caregivers’ Distress and Caregiving Outlook. Clin Gerontol. 2005;29(1):53–69. PMID: None. 10.1300/J018v29n01_05
40. Hirano A, Suzuki Y, Kuzuya M, . Influence of regular exercise on subjective sense of burden and physical symptoms in community-dwelling caregivers of dementia patients: a randomized controlled trial. Arch Gerontol Geriatr. 2011;53(2):e158–e63. PMID: 20850878. 10.1016/j.archger.2010.08.004 20850878
41. Jansen AP, van Hout HP, Nijpels G, . Effectiveness of case management among older adults with early symptoms of dementia and their primary informal caregivers: A randomized clinical trial. Int J Nurs Stud. 2011;48(8):933–43. PMID: 21356537. 10.1016/j.ijnurstu.2011.02.004 21356537
  a. Jansen AP, van Hout HP, van Marwijk HW, . (Cost)-effectiveness of case-management by district nurses among primary informal caregivers of older adults with dementia symptoms and the older adults who receive informal care: design of a randomized controlled trial [ISCRTN83135728]. BMC Public Health. 2005;5:133. PMID: 16343336. 10.1186/1471-2458-5-133 16343336
42. Joling KJ, van Marwijk HW, Smit F, . Does a family meetings intervention prevent depression and anxiety in family caregivers of dementia patients? A randomized trial. PLoS One. 2012;7(1):e30936. PMID: 22303473. 10.1371/journal.pone.0030936 22303473
  a. Joling KJ, van Marwijk HW, van der Horst HE, . Effectiveness of family meetings for family caregivers on delaying time to nursing home placement of dementia patients: a randomized trial. PLoS One. 2012;7(8):e42145. PMID: 22876304. 10.1371/journal.pone.0042145 22876304
43. Judge KS, Yarry SJ, Looman WJ, . Improved Strain and Psychosocial Outcomes for Caregivers of Individuals with Dementia: Findings from Project ANSWERS. Gerontologist. 2013;53(2):280–92. PMID: 22899427. 10.1093/geront/gns076 22899427
  a. Dawson NT, Powers SM, Krestar M, . Predictors of self-reported psychosocial outcomes in individuals with dementia. Gerontologist. 2013;53(5):748–59. PMID: 23107792. 10.1093/geront/gns137 23107792
  b. Judge KS, Yarry SJ, Orsulic-Jeras S. Acceptability and feasibility results of a strength-based skills training program for dementia caregiving dyads. Gerontologist. 2010;50(3):408–17. PMID: 19808841. 10.1093/geront/gnp138 19808841
44. King AC, Baumann K, O’Sullivan P, . Effects of Moderate-Intensity Exercise on Physiological, Behavioral, and Emotional Responses to Family Caregiving. J Gerontol A Biol Sci Med Sci. 2002;57(1):M26–M36. PMID: 11773209. 10.1093/gerona/57.1.M26 11773209
  a. Castro CM, Wilcox S, O’Sullivan P, . An exercise program for women who are caring for relatives with dementia. Psychosom Med. 2002;64(3):458–68. PMID: 12021419.12021419
45. Koivisto AM, Hallikainen I, Valimaki T, . Early psychosocial intervention does not delay institutionalization in persons with mild Alzheimer disease and has impact on neither disease progression nor caregivers’ well-being: ALSOVA 3-year follow-up. Int J Geriatr Psychiatry. 2016;31(3):273–83. PMID: 26177825. 10.1002/gps.4321 26177825
46. Kurz A, Wagenpfeil S, Hallauer J, . Evaluation of a brief educational program for dementia carers: the AENEAS study. Int J Geriatr Psychiatry. 2010;25(8):861–9. PMID: 19946869. 10.1002/gps.2428 19946869
47. Kwok T, Wong B, Ip I, . Telephone-delivered psychoeducational intervention for Hong Kong Chinese dementia caregivers: a single-blinded randomized controlled trial. Clin Interv Aging. 2013;8:1191–7. PMID: 24072965. 10.2147/CIA.S48264 24072965
48. Laakkonen ML, Kautiainen H, Holtta E, . Effects of Self-Management Groups for People with Dementia and Their Spouses--Randomized Controlled Trial. J Am Geriatr Soc. 2016;64(4):752–60. PMID: 27060101. 10.1111/jgs.14055 27060101
  a. Laakkonen ML, Holtta EH, Savikko N, . Psychosocial group intervention to enhance self-management skills of people with dementia and their caregivers: study protocol for a randomized controlled trial. Trials. 2012;13:133. PMID: 22871107. 10.1186/1745-6215-13-133 22871107
  b. Laakkonen M-L, Savikko N, Holtta E, . Self-management groups for people with dementia and their spousal caregivers. A randomized, controlled trial. Baseline findings and feasibility. Eur Geriatr Med. 2013;4(6):389–93. PMID: None. 10.1016/j.eurger.2013.09.006
49. Lam LC, Lee JS, Chung JC, . A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. 2010;25(4):395–402. PMID: 19606455. 10.1002/gps.2352 19606455
50. Leach M, Francis A, Ziaian T. Transcendental Meditation for the improvement of health and wellbeing in community-dwelling dementia caregivers : a randomised wait-list controlled trial. BMC Complement Altern Med. 2015;15:145. PMID: 25952550. 10.1186/s12906-015-0666-8 25952550
  a. Leach MJ, Francis A, Ziaian T. Improving the health and well-being of community-dwelling caregivers of dementia sufferers: study protocol of a randomized controlled trial of structured meditation training. J Altern Complement Med. 2014;20(2):136–41. PMID: 24044373. 10.1089/act.2014.20302 24044373
51. Livingston G, Barber J, Rapaport P, . Clinical effectiveness of a manual based coping strategy programme (START, STrAtegies for RelaTives) in promoting the mental health of carers of family members with dementia: pragmatic randomised controlled trial. BMJ. 2013;347:f6276. PMID: 24162942. 10.1136/bmj.f6276 24162942
  a. Livingston G, Barber J, Rapaport P, . START (STrAtegies for RelaTives) study: a pragmatic randomised controlled trial to determine the clinical effectiveness and cost-effectiveness of a manual-based coping strategy programme in promoting the mental health of carers of people with dementia. Health Technol Assess. 2014;18(61):1–242. PMID: 25300037. 10.3310/hta18610 25300037
52. LoGiudice D, Waltrowicz W, Brown K, . Do memory clinics improve the quality of life of carers? A randomized pilot trial. Int J Geriatr Psychiatry. 1999;14(8):626–32. PMID: 10489653. 10.1002/(SICI)1099-1166(199908)14:8<626::AID-GPS990>3.0.CO;2-5 10489653
53. Losada A, Marquez-Gonzalez M, Romero-Moreno R. Mechanisms of action of a psychological intervention for dementia caregivers: effects of behavioral activation and modification of dysfunctional thoughts. Int J Geriatr Psychiatry 2010:1119–27. PMID: 21061414. 10.1002/gps.2648 21061414
54. Marriott A, Donaldson C, Tarrier N, . Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer’s disease. Br J Psychiatry. 2000;176:557–62. PMID: 10974962. 10.1192/bjp.176.6.557 10974962
55. Martin-Carrasco M, Dominguez-Panchon AI, Gonzalez-Fraile E, . Effectiveness of a psychoeducational intervention group program in the reduction of the burden experienced by caregivers of patients with dementia: the EDUCA-II randomized trial. Alzheimer Dis Assoc Disord. 2014;28(1):79–87. PMID: 24113563. 10.1097/WAD.0000000000000003 24113563
56. Martin-Carrasco M, Martin MF, Valero CP, . Effectiveness of a psychoeducational intervention program in the reduction of caregiver burden in Alzheimer’s disease patients’ caregivers. Int J Geriatr Psychiatry. 2009;24(5):489–99. PMID: 18949763. 10.1002/gps.2142 18949763
57. Martin-Cook K, Davis BA, Hynan LS, . A randomized, controlled study of an Alzheimer’s caregiver skills training program. Am J Alzheimers Dis Other Demen. 2005;20(4):204–10. PMID: 16136843. 10.1177/153331750502000411 16136843
58. Martindale-Adams J, Nichols LO, Burns R, . A trial of dementia caregiver telephone support. The Canadian journal of nursing research = Revue canadienne de recherche en sciences infirmieres. 2013;45(4):30–48. PMID: 24617278. 10.1177/084456211304500404 24617278
59. Mavandadi S, Wright EM, Graydon MM, . A randomized pilot trial of a telephone-based collaborative care management program for caregivers of individuals with dementia. Psychol Serv. 2017;14(1):102–11. PMID: 28134558. 10.1037/ser0000118 28134558
60. Meeuwsen EJ, Melis RJ, Van Der Aa GC, . Effectiveness of dementia follow-up care by memory clinics or general practitioners: randomised controlled trial. BMJ. 2012;344:e3086. PMID: 22589500. 10.1136/bmj.e3086 22589500
61. Menn P, Holle R, Kunz S, . Dementia care in the general practice setting: a cluster randomized trial on the effectiveness and cost impact of three management strategies. Value Health. 2012;15(6):851–9. PMID: 22999135. 10.1016/j.jval.2012.06.007 22999135
  a. Holle R, Grassel E, Ruckdaschel S, . Dementia care initiative in primary practice: study protocol of a cluster randomized trial on dementia management in a general practice setting. BMC Health Serv Res. 2009;9:91. PMID: 19500383. 10.1186/1472-6963-9-91 19500383
62. Mittelman MS, Roth DL, Coon DW, . Sustained benefit of supportive intervention for depressive symptoms in caregivers of patients with Alzheimer’s disease. Am J Psychiatry. 2004;161(5):850–6. PMID: 15121650. 10.1176/appi.ajp.161.5.850 15121650
  a. Gaugler JE, Roth DL, Haley WE, . Can counseling and support reduce burden and depressive symptoms in caregivers of people with Alzheimer’s disease during the transition to institutionalization? Results from the New York University caregiver intervention study. J Am Geriatr Soc. 2008;56(3):421–8. PMID: 18179495. 10.1111/j.1532-5415.2007.01593.x 18179495
  b. Haley WE, Bergman EJ, Roth DL, . Long-term effects of bereavement and caregiver intervention on dementia caregiver depressive symptoms. Gerontologist. 2008;48(6):732–40. PMID: 19139247.19139247
  c. Mittelman MS, Ferris SH, Shulman E, . A comprehensive support program: effect on depression in spouse-caregivers of AD patients. Gerontologist. 1995;35(6):792–802. PMID: 8557206. 10.1093/geront/35.6.792 8557206
  d. Mittelman MS, Ferris SH, Shulman E, . A family intervention to delay nursing home placement of patients with Alzheimer disease. A randomized controlled trial. JAMA. 1996;276(21):1725–31. PMID: 8940320. 10.1001/jama.1996.03540210033030 8940320
  e. Mittelman MS, Ferris SH, Steinberg G, . An intervention that delays institutionalization of Alzheimer’s disease patients: treatment of spouse-caregivers. Gerontologist. 1993;33(6):730–40. PMID: 8314099. 10.1093/geront/33.6.730 8314099
  f. Mittelman MS, Haley WE, Clay OJ, . Improving caregiver well-being delays nursing home placement of patients with Alzheimer disease. Neurology. 2006;67(9):1592–9. PMID: 17101889. 10.1212/01.wnl.0000242727.81172.91 17101889
  g. Mittelman MS, Roth DL, Clay OJ, . Preserving health of Alzheimer caregivers: impact of a spouse caregiver intervention. Am J Geriatr Psychiatry. 2007;15(9):780–9. PMID: 17804831. 10.1097/JGP.0b013e31805d858a 17804831
  h. Mittelman MS, Roth DL, Haley WE, . Effects of a caregiver intervention on negative caregiver appraisals of behavior problems in patients with Alzheimer’s disease: results of a randomized trial. J Gerontol B Psychol Sci Soc Sci. 2004;59(1):27–34. PMID: 14722336. 10.1093/geronb/59.1.P2714722336 14722336
63. Nourhashemi F, Andrieu S, Gillette-Guyonnet S, . Effectiveness of a specific care plan in patients with Alzheimer’s disease: cluster randomised trial (PLASA study). BMJ. 2010;340:c2466. PMID: 20522656. 10.1136/bmj.c2466 20522656
64. Nunez-Naveira L, Alonso-Bua B, de Labra C, . UnderstAID, an ICT Platform to Help Informal Caregivers of People with Dementia: A Pilot Randomized Controlled Study. Biomed Res Int. 2016;2016:5726465. PMID: 28116300. 10.1155/2016/5726465 28116300
65. Ostwald SK, Hepburn KW, Caron W, . Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. 1999;39(3):299–309. PMID: 10396888. 10.1093/geront/39.3.299 10396888
  a. Hepburn KW, Tornatore J, Center B, . Dementia family caregiver training: affecting beliefs about caregiving and caregiver outcomes. J Am Geriatr Soc. 2001;49(4):450–7. PMID: 11347790. 10.1046/j.1532-5415.2001.49090.x 11347790
66. Pillemer K, Jill SJ. Peer support for Alzheimer’s caregivers: Is it enough to make a difference? Res Aging. 2002;24(2):171–92. PMID: None. 10.1177/0164027502242001
67. Prick AE, de Lange J, Twisk J, . The effects of a multi-component dyadic intervention on the psychological distress of family caregivers providing care to people with dementia: a randomized controlled trial. Int Psychogeriatr. 2015;27(12):2031–44. PMID: 26004290. 10.1017/S104161021500071X 26004290
  a. Prick AE, de Lange J, Scherder E, . Home-based exercise and support programme for people with dementia and their caregivers: study protocol of a randomised controlled trial. BMC Public Health. 2011;11:894. PMID: 22117691. 10.1186/1471-2458-11-894 22117691
  b. Prick AE, de Lange J, Scherder E, . The effects of a multicomponent dyadic intervention on the mood, behavior, and physical health of people with dementia: a randomized controlled trial. Clin Interv Aging. 2016;11:383–95. PMID: 27099480. 10.2147/CIA.S95789 27099480
  c. Prick AE, de Lange J, Scherder E, . The Effects of a Multicomponent Dyadic Intervention With Physical Exercise on the Cognitive Functioning of People With Dementia: A Randomized Controlled Trial. J Aging Phys Act. 2017:1–14. PMID: 28120631. 10.1123/japa.2016-0038 28120631
  d. Prick AE, de Lange J, van ‘t Leven N, . Process evaluation of a multicomponent dyadic intervention study with exercise and support for people with dementia and their family caregivers. Trials. 2014;15:401. PMID: 25336121. 10.1186/1745-6215-15-401 25336121
68. Roberts J, Browne G, Milne C, . Problem-solving counseling for caregivers of the cognitively impaired: effective for whom? Nurs Res. 1999;48(3):162–72. PMID: 10337847.10337847
69. Samus QM, Johnston D, Black BS, . A multidimensional home-based care coordination intervention for elders with memory disorders: the maximizing independence at home (MIND) pilot randomized trial. Am J Geriatr Psychiatry. 2014;22(4):398–414. PMID: 24502822. 10.1016/j.jagp.2013.12.175 24502822
  a. Amjad H, Wong SK, Roth DL, . Health Services Utilization in Older Adults with Dementia Receiving Care Coordination: The MIND at Home Trial. Health Serv Res. 2018;53(1):556–79. PMID: 28083879. 10.1111/1475-6773.12647 28083879
  b. Tanner JA, Black BS, Johnston D, . A randomized controlled trial of a community-based dementia care coordination intervention: effects of MIND at Home on caregiver outcomes. Am J Geriatr Psychiatry. 2015;23(4):391–402. PMID: 25260557. 10.1016/j.jagp.2014.08.002 25260557
70. Schoenmakers B, Buntinx F, DeLepeleire J. Supporting family carers of community-dwelling elder with cognitive decline: a randomized controlled trial. Int J Family Med. 2010;2010:184152. PMID: 22332005. 10.1155/2010/184152 22332005
71. Spalding-Wilson KN, Guzman-Velez E, Angelica J, . A novel two-day intervention reduces stress in caregivers of persons with dementia. Alzheimers Dement (N Y). 2018;4:450–60. PMID: 30258974. 10.1016/j.trci.2018.08.004 30258974
72. Spijker A, Wollersheim H, Teerenstra S, . Systematic care for caregivers of patients with dementia: a multicenter, cluster-randomized, controlled trial. Am J Geriatr Psychiatry. 2011:521–31. PMID: 21358385. 10.1097/JGP.0b013e3182110599 21358385
73. Steffen AM, Gant JR. A telehealth behavioral coaching intervention for neurocognitive disorder family carers. Int J Geriatr Psychiatry. 2016;31(2):195–203. PMID: 26077904. 10.1002/gps.4312 26077904
74. Teri L, Gibbons LE, McCurry SM, . Exercise plus behavioral management in patients with Alzheimer disease: a randomized controlled trial. JAMA. 2003;290(15):2015–22. PMID: 14559955. 10.1001/jama.290.15.2015 14559955
75. Teri L, McCurry SM, Logsdon R, . Training community consultants to help family members improve dementia care: a randomized controlled trial. Gerontologist. 2005;45(6):802–11. PMID: 16326662. 10.1093/geront/45.6.802 16326662
76. Thyrian JR, Hertel J, Wucherer D, . Effectiveness and Safety of Dementia Care Management in Primary Care: A Randomized Clinical Trial. JAMA Psychiatry. 2017;74(10):996–1004. PMID: 28746708. 10.1001/jamapsychiatry.2017.2124 28746708
77. Tremont G, Davis JD, Papandonatos GD, . Psychosocial telephone intervention for dementia caregivers: A randomized, controlled trial. Alzheimers Dement. 2015;11(5):541–8. PMID: 25074341. 10.1016/j.jalz.2014.05.1752 25074341
  a. Tremont G, Davis J, Papandonatos GD, . A telephone intervention for dementia caregivers: background, design, and baseline characteristics. Contemp Clin Trials. 2013;36(2):338–47. PMID: 23916916. 10.1016/j.cct.2013.07.011 23916916
  b. Tremont G, Davis JD, Ott BR, . Randomized Trial of the Family Intervention: Telephone Tracking-Caregiver for Dementia Caregivers: Use of Community and Healthcare Resources. J Am Geriatr Soc. 2017;65(5):924–30. PMID: 28008609. 10.1111/jgs.14684 28008609
78. Ulstein ID, Sandvik L, Wyller TB, . A one-year randomized controlled psychosocial intervention study among family carers of dementia patients--effects on patients and carers. Dement Geriatr Cogn Dis Extra. 2007;24(6):469–75. PMID: 17986818. 10.1159/000110740 17986818
79. Vickrey BG, Mittman BS, Connor KI, . The effect of a disease management intervention on quality and outcomes of dementia care: a randomized, controlled trial. Ann Int Med. 2006;145(10):713–26. PMID: 17116916. 10.7326/0003-4819-145-10-200611210-00004 17116916
  a. Duru OK, Ettner SL, Vassar SD, . Cost evaluation of a coordinated care management intervention for dementia. Am J Manag Care. 2009;15(8):521–8. PMID: 19670955.19670955
80. Voigt-Radloff S, Graff M, Leonhart R, . A multicentre RCT on community occupational therapy in Alzheimer’s disease: 10 sessions are not better than one consultation. BMJ Open. 2011;1(1):e000096. PMID: 22021760. 10.1136/bmjopen-2011-000096 22021760
  a. Voigt-Radloff S, Graff M, Leonhart R, . WHEDA study: effectiveness of occupational therapy at home for older people with dementia and their caregivers--the design of a pragmatic randomised controlled trial evaluating a Dutch programme in seven German centres. BMC Geriatr. 2009;9:44. PMID: 19799779. 10.1186/1471-2318-9-44 19799779
81. Waldorff FB, Buss DV, Eckermann A, . Efficacy of psychosocial intervention in patients with mild Alzheimer’s disease: the multicentre, rater blinded, randomised Danish Alzheimer Intervention Study (DAISY). BMJ. 2012;345:e4693. PMID: 22807076. 10.1136/bmj.e4693 22807076
  a. Phung KTT, Waldorff FB, Buss DV, . A three-year follow-up on the efficacy of psychosocial interventions for patients with mild dementia and their caregivers: The multicentre, rater-blinded, randomised Danish Alzheimer Intervention Study (DAISY). BMJ Open. 2013. PMID: 24270834. 10.1136/bmjopen-2013-003584 24270834
  b. Sogaard R, Sorensen J, Waldorff FB, . Cost analysis of early psychosocial intervention in Alzheimer’s disease. Dement Geriatr Cogn Disord. 2014;37(3–4):141–53. PMID: 24157706. 10.1159/000355368 24157706
  c. Waldemar G, Waldorff FB, Buss DV, . The Danish Alzheimer intervention study: rationale, study design and baseline characteristics of the cohort. Neuroepidemiology. 2011;36(1):52–61. PMID: 21196773. 10.1159/000322942 21196773
82. Wang L-Q, Chien W-T. Randomised controlled trial of a family-led mutual support programme for people with dementia. Journal of clinical nursing. 2011;20(15–16):2362–6. PMID: 21752121. 10.1111/j.1365-2702.2011.03746.x 21752121
83. Williams VP, Bishop-Fitzpatrick L, Lane JD, . Video-based coping skills to reduce health risk and improve psychological and physical well-being in Alzheimer’s disease family caregivers. Psychosom Med. 2010;72(9):897–904. PMID: 20978227. 10.1097/PSY.0b013e3181fc2d09 20978227
84. Wilz G, Reder M, Meichsner F, . The Tele.TAnDem Intervention: Telephone-based CBT for Family Caregivers of People With Dementia. Gerontologist. 2018;58(2):e118–e29. PMID: 29190357. 10.1093/geront/gnx183 29190357
  a. Meichsner F, Topfer NF, Reder M, . Telephone-Based Cognitive Behavioral Intervention Improves Dementia Caregivers’ Quality of Life. Am J Alzheimers Dis Other Demen. 2019:1533317518822100. PMID: 30636429. 10.1177/1533317518822100 30636429
  b. Soellner R, Reder M, Machmer A, . The Tele.TAnDem intervention: study protocol for a psychotherapeutic intervention for family caregivers of people with dementia. BMC Nurs. 2015;14:11. PMID: 28428730. 10.1186/s12912-015-0059-9 28428730
  c. Topfer NF, Wilz G. Tele.TAnDem increases the psychosocial resource utilization of dementia caregivers. GeroPsych (Bern). 2018;31(4):173–83. 10.1024/1662-9647/a000197
85. Wilz G, Soellner R. Evaluation of a Short-Term Telephone-Based Cognitive Behavioral Intervention for Dementia Family Caregivers. Clin Gerontol. 2016;39(1):25–47. PMID: None. 10.1080/07317115.2015.1101631
  a. Wilz G, Meichsner F, Soellner R. Are psychotherapeutic effects on family caregivers of people with dementia sustainable? Two-year long-term effects of a telephone-based cognitive behavioral intervention. Aging Ment Health. 2017;21(7):774–81. PMID: 26954588. 10.1080/13607863.2016.1156646 26954588
86. Winter L, Gitlin LN. Evaluation of a telephone-based support group intervention for female caregivers of community-dwelling individuals with dementia. Am J Alzheimers Dis Other Demen. 2006;21(6):391–7. PMID: 17267370. 10.1177/1533317506291371 17267370
87. Wright LK, Litaker M, Laraia MT, . Continuum of care for Alzheimer’s disease: a nurse education and counseling program. Issues Ment Health Nurs. 2001;22(3):231–52. PMID: 11885210. 10.1080/01612840117980 11885210
88. Xiao LD, De Bellis A, Kyriazopoulos H, . The Effect of a Personalized Dementia Care Intervention for Caregivers From Australian Minority Groups. Am J Alzheimers Dis Other Demen. 2016;31(1):57–67. PMID: 25805891. 10.1177/1533317515578256 25805891