# Appendix B Literature Flow Diagram

Appendix B Figure 1 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles for the review. There were 21,018 citations identified through literature databases. An additional 71 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, 365 citations were from the most recent (2014) USPSTF review. After duplicates were removed, 11,644 unique citations were screened at the title/abstract stage. The full-text of 966 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=0), Key Question 2 (k=59), Key Question 3 (k=0), Key Question 4 (k=224), and Key Question 5 (k=98). Reasons for excluding the other articles are available in Appendix D.