# Appendix A Literature Search Strategies

Key:

- / = MeSH subject heading
- * = truncation
- * preceding a word = major focus
- $ = truncationLL
- ab = word in abstract
- exp = explode
- fs = MeSH subheading
- hw = subject heading word
- id = identifier
- kf = keyword heading [word not phrase indexed]
- kw = keyword
- md = methodology
- mp = mapping alias (searches within: Title (TI), Abstract (AB), Subject Headings Word (HW), Table of Contents Titles/Headings (TC), Original Title (OT), Test & Measures (TM), and Key Phrase Identifiers (ID) fields)
- pt = publication type
- ti = word in title

## Cochrane Central Register of Controlled Trials (CENTRAL)

#1 | dementia:ti,kw or alzheimer*:kw
#2 | (cognitive next impairment*):ti,kw
#3 | (cognitive next decline):ti,kw
#4 | (cognitive next loss):ti,kw
#5 | (cognitive next disorder*):ti,kw
#6 | (cognition next disorder*):ti,kw
#7 | ^448^ ^–#6^
#8 | (screen* or instrument or instruments):ti,ab,kw
#9 | (assess* or tool* or test* or evaluat* or questionnaire*):ti,kw
#10 | #8 or #9
#11 | #7 and #10
#12 | (sensitivit* or specificit*):ti,ab,kw
#13 | “ROC Curve”:ti,ab,kw
#14 | “predictive value”:ti,ab,kw
#15 | accuracy:ti,ab,kw
#16 | (False next Negative*):ti,ab,kw
#17 | (False next positive*):ti,ab,kw
#18 | (Diagnostic next Error*):ti,ab,kw
#19 | Reproducibility:ti,ab,kw
#20 | (Reference next Value*):ti,ab,kw
#21 | (Reference next standard*):ti,ab,kw
#22 | (Observer next Variation*):ti,ab,kw
#23 | {or #12-#22}
#24 | #7 and #23
#25 | statin*:ti,ab,kw
#26 | (antihypertensive* or diuretic* or (beta next blocker*) or (alpha next blocker*) or (ace next inhibitor*) or “calcium channel” or vasodilator*):ti,ab,kw
#27 | (nsaid* or nonsteroidal):ti,ab,kw
#28 | aspirin:ti,ab,kw
#29 | (hormone* or estrogen* or estradiol or Medroxyprogesterone or Progesterone or androgen* or testosterone or Dehydroepiandrosterone or Norethindrone):ti,ab,kw
#30 | (cholinesterase or donepezil or galantamine):ti,ab,kw
#31 | memantine:ti,ab,kw
#32 | (folic or folate or “vitamin b” or bl or b2 or b6 or b12):ti,ab,kw
#33 | (antioxidant* or “vitamin e” or “ascorbic acid” or ascorbate or “vitamin c” or “beta carotene”):ti,ab,kw
#34 | (omega* or “fatty acid” or “fatty acids” or linolenic or “mediterranean diet”):ti,ab,kw
#35 | (exercis* or “physical activity” or “physical training” or “strength training” or “resistance training” or “aerobic training” or “cardiovascular training” or “endurance training” or “flexibility training” or relaxation or walking or yoga or “tai chi” or danc*):ti,ab,kw
#36 | (caregiv* or carer* or “self help” or “family therapy” or “social support” or “skills training” or education):ti,ab,kw
#37 | (counsel* or psychotherapy or (behavio* next therap*) or (cognitive next therap*)):ti,ab,kw
#38 | (engage* or “cognitive exercise” or “cognitive exercises”):ti,ab,kw
#39 | (“case management” or “care management”):ti,ab,kw
#40 | (multicomponent or multidisciplinary or multimodal):ti,ab,kw
#41 | (“multi component” or “multi disciplinary” or “multi modal”):ti,ab,kw
#42 | {or #25-#41}
#43 | #7 and #42
#44 | #11 or #24 or #43 Publication Year from 2012 to 2017

## Dementia/Mild cognitive impairment

### Screening trials

#### Ovid Medline, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

1 | Dementia/
2 | Alzheimer Disease/
3 | Dementia, Vascular/
4 | Dementia, Multi-Infarct/
5 | Frontotemporal Lobar Degeneration/
6 | Lewy Body Disease/
7 | dementia.ti.
8 | Neurocognitive Disorders/
9 | Cognition Disorders/
10 | Cognitive Dysfunction/
11 | cognitive impairment*.ti.
12 | cognitive decline.ti.
13 | cognitive loss.ti.
14 | cognitive disorder*.ti.
15 | cognitive dysfunction*.ti.
16 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
17 | Mass screening/
18 | screen*.ti,ab.
19 | 17 or 18
20 | 16 and 19
21 | *Dementia/di
22 | *Alzheimer Disease/di
23 | *Neurocognitive Disorders/di
24 | *Cognition Disorders/di
25 | *Cognitive Dysfunction/di
26 | 20 or 21 or 22 or 23 or 24 or 25
27 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
28 | meta-analysis as topic/ (17142)
29 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt.
30 | random*.ti,ab.
31 | control groups/ or double-blind method/ or single-blind method/ (184630)
32 | clinical trial*.ti,ab.
33 | controlled trial*.ti,ab.
34 | (metaanaly* or meta analy*).ti,ab.
35 | 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36 | 26 and 35
37 | Animals/ not (Humans/ and Animals/)
38 | 36 not 37
39 | limit 38 to (english language and yr="2012 -Current")
40 | remove duplicates from 39

## Dementia/Mild cognitive impairment

### Test performance of screening instruments

#### Ovid Medline, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

1 | Dementia/
2 | Alzheimer Disease/
3 | Dementia, Vascular/
4 | Dementia, Multi-Infarct/
5 | Frontotemporal Lobar Degeneration/
6 | Lewy Body Disease/
7 | dementia.ti.
8 | Neurocognitive Disorders/
9 | Cognition Disorders/
10 | Cognitive Dysfunction/
11 | cognitive impairment*.ti.
12 | cognitive decline.ti.
13 | cognitive loss.ti.
14 | cognitive disorder*.ti.
15 | cognitive dysfunction*.ti.
16 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
17 | Mass screening/
18 | neuropsychological tests/ or mental navigation tests/
19 | (screen* or instrument or instruments).ti,ab.
20 | (assess* or tool* or test* or evaluat* or questionnaire*).ti,kf.
21 | 17 or 18 or 19 or 20
22 | “Sensitivity and Specificity”/
23 | “Predictive Value of Tests”/
24 | ROC Curve/
25 | Receiver operat*.ti,ab.
26 | (sensitivit* or specificit*).ti,ab.
27 | predictive value.ti,ab.
28 | accuracy.ti,ab.
29 | False Negative Reactions/
30 | False Positive Reactions/
31 | Diagnostic Errors/
32 | “Reproducibility of Results”/
33 | Reference Values/
34 | Reference Standards/
35 | Observer Variation/
36 | Psychometrics/
37 | Psychometric$.ti,ab.
38 | 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37
39 | 16 and 21 and 38
40 | Animals/ not (Humans/ and Animals/)
41 | 39 not 40
42 | limit 41 to (english language and yr="2012 -Current")
43 | remove duplicates from 42

## Dementia/Mild cognitive impairment

### Screening harms

#### Ovid Medline, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

1 | Dementia/
2 | Alzheimer Disease/
3 | Dementia, Vascular/
4 | Dementia, Multi-Infarct/
5 | Frontotemporal Lobar Degeneration/
6 | Lewy Body Disease/
7 | dementia.ti.
8 | Neurocognitive Disorders/
9 | Cognition Disorders/
10 | Cognitive Dysfunction/
11 | cognitive impairment*.ti.
12 | cognitive decline.ti.
13 | cognitive loss.ti.
14 | cognitive disorder*.ti.
15 | cognitive dysfunction*.ti.
16 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
17 | Mass screening/
18 | screen*.ti,ab.
19 | 17 or 18
20 | 16 and 19
21 | *Dementia/di
22 | *Alzheimer Disease/di
23 | *Neurocognitive Disorders/di
24 | *Cognition Disorders/di
25 | *Cognitive Dysfunction/di
26 | 20 or 21 or 22 or 23 or 24 or 25
27 | adverse effects.fs.
28 | adverse*.ti,ab.
29 | harm*.ti,ab.
30 | Anxiety/
31 | anxiety.ti,ab.
32 | Depression/
33 | depression.ti,ab.
34 | Depressive Disorder/
35 | labeling.ti,ab.
36 | labelling.ti,ab.
37 | labeled.ti,ab.
38 | labelled.ti,ab.
39 | Stress, Psychological/
40 | 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39
41 | 26 and 40
42 | Animals/ not (Humans/ and Animals/)
43 | 41 not 42
44 | limit 43 to (english language and yr="2012 -Current")
45 | remove duplicates from 44

## Dementia/Mild cognitive impairment

### Treatment trials

#### Ovid Medline, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

1 | Dementia/
2 | Alzheimer Disease/
3 | Dementia, Vascular/
4 | Dementia, Multi-Infarct/
5 | Frontotemporal Lobar Degeneration/
6 | Lewy Body Disease/
7 | dementia.ti.
8 | Neurocognitive Disorders/
9 | Cognition Disorders/
10 | Cognitive Dysfunction/
11 | cognitive impairment*.ti.
12 | cognitive decline.ti.
13 | cognitive loss.ti.
14 | cognitive disorder*.ti.
15 | cognitive dysfunction*.ti.
16 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
17 | Hydroxymethylglutaryl-CoA Reductase Inhibitors/
18 | statin*.mp.
19 | lovastatin.mp.
20 | simvastatin.mp.
21 | cerivastatin.mp.
22 | atorvastatin.mp.
23 | rosuvastatin.mp.
24 | pravastatin.mp.
25 | fluvastatin.mp.
26 | 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25
27 | Antihypertensive Agents/
28 | Antihypertensive*.ti,ab.
29 | Diuretics/
30 | Diuretic*.ti,ab.
31 | exp Adrenergic beta-Antagonists/
32 | Adrenergic beta Antagonist*.ti,ab.
33 | beta blocker*.ti,ab.
34 | exp Adrenergic alpha-Antagonists/
35 | Adrenergic alpha Antagonist*.ti,ab.
36 | alpha blocker*.ti,ab.
37 | Angiotensin-Converting Enzyme Inhibitors/
38 | ace inhibitor*.ti,ab.
39 | Angiotensin Converting Enzyme Inhibitor*.ti,ab.
40 | Calcium Channel Blockers/
41 | Calcium Channel Blocker*.ti,ab.
42 | Vasodilator Agents/
43 | Vasodilator*.ti,ab.
44 | 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43
45 | Aspirin/
46 | aspirin*.ti,ab.
47 | 45 or 46
48 | Anti-Inflammatory Agents, Non-Steroidal/
49 | Nonsteroidal Anti Inflammatory Agent*.ti,ab.
50 | Non steroidal Anti Inflammatory Agent*.ti,ab.
51 | Nonsteroidal Antiinflammatory Agent*.ti,ab.
52 | Non steroidal Antiinflammatory Agent*.ti,ab.
53 | NSAID*.ti,ab.
54 | Diclofenac/
55 | Diclofenac.ti,ab.
56 | Ibuprofen/
57 | Ibuprofen.ti,ab.
58 | Indomethacin/
59 | Indomethacin.ti,ab.
60 | Ketoprofen/
61 | Ketoprofen.ti,ab.
62 | Ketorolac/
63 | Ketorolac.ti,ab.
64 | Naproxen/
65 | Naproxen.ti,ab.
66 | Piroxicam/
67 | Piroxicam.ti,ab.
68 | Salicylates/
69 | Salicylate*.ti,ab.
70 | Sulindac/
71 | Sulindac.ti,ab.
72 | Cyclooxygenase Inhibitors/
73 | Cyclooxygenase Inhibitor*.ti,ab.
74 | Cyclooxygenase 2 Inhibitors/
75 | Cyclooxygenase 2 Inhibitor*.ti,ab.
76 | COX 2 Inhibitor*.ti,ab.
77 | 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76
78 | Gonadal Steroid Hormones/
79 | Hormone Replacement Therapy/
80 | Estrogen Replacement Therapy/
81 | Estradiol/
82 | Estrogens/
83 | “Estrogens, Conjugated (USP)”/
84 | Medroxyprogesterone Acetate/
85 | Progesterone/
86 | Progesterone Congeners/
87 | Androgens/
88 | Testosterone/
89 | Dehydroepiandrosterone/
90 | Dehydroepiandrosterone Sulfate/
91 | Norethindrone/
92 | Hormone Replacement Therapy.ti,ab.
93 | estrogen*.ti,ab.
94 | Estradiol.ti,ab.
95 | Medroxyprogesterone.ti,ab.
96 | Progesterone.ti,ab.
97 | Androgen*.ti,ab.
98 | Testosterone.ti,ab.
99 | Dehydroepiandrosterone.ti,ab.
100 | Norethindrone.ti,ab.
101 | 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100
102 | Cholinesterase inhibitors/
103 | Cholinesterase Inhibitor*.ti,ab.
104 | Anticholinesterase*.ti,ab.
105 | Galantamine/
106 | Galantamine.ti,ab.
107 | rivastigmine.ti,ab.
108 | donepezil.ti,ab.
109 | 102 or 103 or 104 or 105 or 106 or 107 or 108
110 | Memantine/
111 | Memantine.ti,ab.
112 | 110 or 111
113 | folic acid/
114 | folic acid.ti,ab.
115 | folate.ti,ab.
116 | Vitamin B Complex/
117 | Thiamine/
118 | Thiamine.ti,ab.
119 | Thiamin.ti,ab.
120 | Thiamine Monophosphate/
121 | Thiamine Pyrophosphate/
122 | Thiamine Triphosphate/
123 | Vitamin B 1.ti,ab.
124 | Vitamin B1.ti,ab.
125 | Riboflavin/
126 | Riboflavin.ti,ab.
127 | Vitamin B 2.ti,ab.
128 | Vitamin B2.ti,ab.
129 | Vitamin B 6/
130 | Vitamin B 6.ti,ab.
131 | Vitamin B6.ti,ab.
132 | Pyridoxine/
133 | Pyridoxine.ti,ab.
134 | Vitamin B 12/
135 | Vitamin B 12.ti,ab.
136 | Vitamin B12.ti,ab.
137 | Cobamides/
138 | Hydroxocobalamin/
139 | Cobalamin.ti,ab.
140 | Cyanocobalamin.ti,ab.
141 | Cobamides.ti,ab.
142 | Hydroxocobalamin.ti,ab.
143 | 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136 or 137 or 138 or 139 or 140 or 141 or 142
144 | Antioxidants/
145 | Antioxidant*.ti,ab.
146 | Vitamin E/
147 | Vitamin E.ti,ab.
148 | alpha-Tocopherol/
149 | Tocopherols/
150 | Tocopherol*.ti,ab.
151 | Ascorbic acid/
152 | Ascorbic acid.ti,ab.
153 | Vitamin C.ti,ab.
154 | ascorbate.ti,ab.
155 | beta carotene/
156 | beta carotene.ti,ab.
157 | 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 or 156
158 | fatty acids, omega-3/ or alpha-linolenic acid/ or docosahexaenoic acids/ or neuroprostanes/ or eicosapentaenoic acid/
159 | Omega 3.ti,ab.
160 | n 3 Fatty Acid*.ti,ab.
161 | Linolenic Acids/
162 | Linolenic Acid*.ti,ab.
163 | Fatty Acids, Essential/
164 | Dietary Fats, Unsaturated/
165 | Fish Oils/
166 | fish oil*.ti,ab.
167 | diet* fatty acid*.ti,ab.
168 | Diet, Mediterranean/
169 | Mediterranean diet*.ti,ab.
170 | 158 or 159 or 160 or 161 or 162 or 163 or 164 or 165 or 166 or 167 or 168 or 169
171 | Exercise/
172 | Exercise Therapy/
173 | Exercise Movement Techniques/
174 | Physical Fitness/
175 | Cardiorespiratory Fitness/
176 | Physical Conditioning, Human/
177 | Walking/
178 | Stair Climbing/
179 | Circuit-Based Exercise/
180 | Resistance Training/
181 | exercis*.ti,ab.
182 | physical activity.ti,ab.
183 | physical training.ti,ab.
184 | strength training.ti,ab.
185 | resistance training.ti,ab.
186 | aerobic training.ti,ab.
187 | cardiovascular training.ti,ab.
188 | endurance training.ti,ab.
189 | flexibility training.ti,ab.
190 | Relaxation/
191 | Relaxation Therapy/
192 | relaxation.ti,ab.
193 | Tai Ji/
194 | Tai Chi.ti,ab.
195 | walking.ti,ab.
196 | Yoga/
197 | yoga.ti,ab.
198 | Dancing/
199 | (dancing or dance).ti,ab.
200 | 171 or 172 or 173 or 174 or 175 or 176 or 177 or 178 or 179 or 180 or 181 or 182 or 183 or 184 or 185 or 186 or 187 or 188 or 189 or 190 or 191 or 192 or 193 or 194 or 195 or 196 or 197 or 198 or 199
201 | Caregivers/
202 | caregiver*.ti,ab.
203 | caregiving.ti,ab.
204 | (carer or carers).ti,ab.
205 | Self-Help Groups/
206 | self help.ti,ab.
207 | care giver*.ti,ab.
208 | Family Therapy/
209 | family therapy.ti,ab.
210 | Social Support/
211 | social support*.ti,ab.
212 | skills training.ti,ab.
213 | Health Education/
214 | health education.ti,ab.
215 | education.fs.
216 | education, continuing/ or education, medical, continuing/ or education, nursing, continuing/
217 | 201 or 202 or 203 or 204 or 205 or 206 or 207 or 208 or 209 or 210 or 211 or 212 or 213 or 214 or 215 or 216
218 | Counseling/
219 | Directive Counseling/
220 | Cognitive Therapy/
221 | cognitive therap*.ti,ab.
222 | psychotherapy/ or psychotherapy, brief/
223 | Behavior Therapy/
224 | behavio* therap*.ti,ab.
225 | psychotherap*.ti,ab.
226 | counsel*.ti,ab.
227 | 218 or 219 or 220 or 221 or 222 or 223 or 224 or 225 or 226
228 | (cognitive* adj3 engage*).ti,ab.
229 | (creative* adj3 engage*).ti,ab.
230 | (cognitive* adj3 stimulat*).ti,ab.
231 | cognitive training.ti,ab.
232 | cognitive intervention*.ti,ab.
233 | group reminiscence.ti,ab.
234 | reality orientation.ti,ab.
235 | Reality Therapy/
236 | reality therapy.ti,ab.
237 | cognitive exercis*.ti,ab.
238 | 228 or 229 or 230 or 231 or 232 or 233 or 234 or 235 or 236 or 237
239 | Case Management/
240 | Patient Care Management/
241 | care manage*.ti,ab.
242 | case manage*.ti,ab.
243 | 239 or 240 or 241 or 242
244 | ((multicomponent or multi component or multidisciplinary or multi disciplinary or multimodal or multi modal) adj3 (treatment* or program* or intervention*)).ti,ab.
245 | 26 or 44 or 47 or 77 or 101 or 109 or 112 or 143 or 157 or 170 or 200 or 217 or 227 or 238 or 243 or 244
246 | 16 and 245
247 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
248 | meta-analysis as topic/
249 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt.
250 | random*.ti,ab.
251 | control groups/ or double-blind method/ or single-blind method/
252 | clinical trial*.ti,ab.
253 | controlled trial*.ti,ab.
254 | (metaanaly* or meta analy*).ti,ab.
255 | 247 or 248 or 249 or 250 or 251 or 252 or 253 or 254
256 | 246 and 255
257 | Animals/ not (Humans/ and Animals/)
258 | 256 not 257
259 | limit 258 to (english language and yr="2012 -Current")
260 | remove duplicates from 259

## Dementia/Mild cognitive impairment

### Treatment harms

#### Ovid Medline, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

1 | Dementia/
2 | Alzheimer Disease/
3 | Dementia, Vascular/
4 | Dementia, Multi-Infarct/
5 | Frontotemporal Lobar Degeneration/
6 | Lewy Body Disease/
7 | dementia.ti.
8 | Neurocognitive Disorders/
9 | Cognition Disorders/
10 | Cognitive Dysfunction/
11 | cognitive impairment*.ti.
12 | cognitive decline.ti.
13 | cognitive loss.ti.
14 | cognitive disorder*.ti.
15 | cognitive dysfunction*.ti.
16 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
17 | Hydroxymethylglutaryl-CoA Reductase Inhibitors/
18 | statin*.mp.
19 | lovastatin.mp.
20 | simvastatin.mp.
21 | cerivastatin.mp.
22 | atorvastatin.mp.
23 | rosuvastatin.mp.
24 | pravastatin.mp.
25 | fluvastatin.mp.
26 | 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25
27 | Antihypertensive Agents/
28 | Antihypertensive*.ti,ab.
29 | Diuretics/
30 | Diuretic*.ti,ab.
31 | exp Adrenergic beta-Antagonists/
32 | Adrenergic beta Antagonist*.ti,ab.
33 | beta blocker*.ti,ab.
34 | exp Adrenergic alpha-Antagonists/
35 | Adrenergic alpha Antagonist*.ti,ab.
36 | alpha blocker*.ti,ab.
37 | Angiotensin-Converting Enzyme Inhibitors/
38 | ace inhibitor*.ti,ab.
39 | Angiotensin Converting Enzyme Inhibitor*.ti,ab.
40 | Calcium Channel Blockers/
41 | Calcium Channel Blocker*.ti,ab.
42 | Vasodilator Agents/
43 | Vasodilator*.ti,ab.
44 | 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43
45 | Aspirin/
46 | aspirin*.ti,ab.
47 | 45 or 46
48 | Anti-Inflammatory Agents, Non-Steroidal/
49 | Nonsteroidal Anti Inflammatory Agent*.ti,ab.
50 | Non steroidal Anti Inflammatory Agent*.ti,ab.
51 | Nonsteroidal Antiinflammatory Agent*.ti,ab.
52 | Non steroidal Antiinflammatory Agent*.ti,ab.
53 | NSAID*.ti,ab.
54 | Diclofenac/
55 | Diclofenac.ti,ab.
56 | Ibuprofen/
57 | Ibuprofen.ti,ab.
58 | Indomethacin/
59 | Indomethacin.ti,ab.
60 | Ketoprofen/
61 | Ketoprofen.ti,ab.
62 | Ketorolac/
63 | Ketorolac.ti,ab.
64 | Naproxen/
65 | Naproxen.ti,ab.
66 | Piroxicam/
67 | Piroxicam.ti,ab.
68 | Salicylates/
69 | Salicylate*.ti,ab.
70 | Sulindac/
71 | Sulindac.ti,ab.
72 | Cyclooxygenase Inhibitors/
73 | Cyclooxygenase Inhibitor*.ti,ab.
74 | Cyclooxygenase 2 Inhibitors/
75 | Cyclooxygenase 2 Inhibitor*.ti,ab.
76 | COX 2 Inhibitor*.ti,ab.
77 | 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76
78 | Gonadal Steroid Hormones/
79 | Hormone Replacement Therapy/
80 | Estrogen Replacement Therapy/
81 | Estradiol/
82 | Estrogens/
83 | “Estrogens, Conjugated (USP)”/
84 | Medroxyprogesterone Acetate/
85 | Progesterone/
86 | Progesterone Congeners/
87 | Androgens/
88 | Testosterone/
89 | Dehydroepiandrosterone/
90 | Dehydroepiandrosterone Sulfate/
91 | Norethindrone/
92 | Hormone Replacement Therapy.ti,ab.
93 | estrogen*.ti,ab.
94 | Estradiol.ti,ab.
95 | Medroxyprogesterone.ti,ab.
96 | Progesterone.ti,ab.
97 | Androgen*.ti,ab.
98 | Testosterone.ti,ab.
99 | Dehydroepiandrosterone.ti,ab.
100 | Norethindrone.ti,ab.
101 | 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100
102 | Cholinesterase inhibitors/
103 | Cholinesterase Inhibitor*.ti,ab.
104 | Anticholinesterase*.ti,ab.
105 | Galantamine/
106 | Galantamine.ti,ab.
107 | rivastigmine.ti,ab.
108 | donepezil.ti,ab.
109 | 102 or 103 or 104 or 105 or 106 or 107 or 108
110 | Memantine/
111 | Memantine.ti,ab.
112 | 110 or 111
113 | folic acid/
114 | folic acid.ti,ab.
115 | folate.ti,ab.
116 | Vitamin B Complex/
117 | Thiamine/
118 | Thiamine.ti,ab.
119 | Thiamin.ti,ab.
120 | Thiamine Monophosphate/
121 | Thiamine Pyrophosphate/
122 | Thiamine Triphosphate/
123 | Vitamin B 1.ti,ab.
124 | Vitamin B1.ti,ab.
125 | Riboflavin/
126 | Riboflavin.ti,ab.
127 | Vitamin B 2.ti,ab.
128 | Vitamin B2.ti,ab.
129 | Vitamin B 6/
130 | Vitamin B 6.ti,ab.
131 | Vitamin B6.ti,ab.
132 | Pyridoxine/
133 | Pyridoxine.ti,ab.
134 | Vitamin B 12/
135 | Vitamin B 12.ti,ab.
136 | Vitamin B12.ti,ab.
137 | Cobamides/
138 | Hydroxocobalamin/
139 | Cobalamin.ti,ab.
140 | Cyanocobalamin.ti,ab.
141 | Cobamides.ti,ab.
142 | Hydroxocobalamin.ti,ab.
143 | 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136 or 137 or 138 or 139 or 140 or 141 or 142
144 | Antioxidants/
145 | Antioxidant*.ti,ab.
146 | Vitamin E/
147 | Vitamin E.ti,ab.
148 | alpha-Tocopherol/
149 | Tocopherols/
150 | Tocopherol*.ti,ab.
151 | Ascorbic acid/
152 | Ascorbic acid.ti,ab.
153 | Vitamin C.ti,ab.
154 | ascorbate.ti,ab.
155 | beta carotene/
156 | beta carotene.ti,ab.
157 | 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 or 156
158 | fatty acids, omega-3/ or alpha-linolenic acid/ or docosahexaenoic acids/ or neuroprostanes/ or eicosapentaenoic acid/
159 | Omega 3.ti,ab.
160 | n 3 Fatty Acid*.ti,ab.
161 | Linolenic Acids/
162 | Linolenic Acid*.ti,ab.
163 | Fatty Acids, Essential/
164 | Dietary Fats, Unsaturated/
165 | Fish Oils/
166 | fish oil*.ti,ab.
167 | diet* fatty acid*.ti,ab.
168 | Diet, Mediterranean/
169 | Mediterranean diet*.ti,ab.
170 | 158 or 159 or 160 or 161 or 162 or 163 or 164 or 165 or 166 or 167 or 168 or 169
171 | Exercise/
172 | Exercise Therapy/
173 | Exercise Movement Techniques/
174 | Physical Fitness/
175 | Cardiorespiratory Fitness/
176 | Physical Conditioning, Human/
177 | Walking/
178 | Stair Climbing/
179 | Circuit-Based Exercise/
180 | Resistance Training/
181 | exercis*.ti,ab.
182 | physical activity.ti,ab.
183 | physical training.ti,ab.
184 | strength training.ti,ab.
185 | resistance training.ti,ab.
186 | aerobic training.ti,ab.
187 | cardiovascular training.ti,ab.
188 | endurance training.ti,ab.
189 | flexibility training.ti,ab.
190 | Relaxation/
191 | Relaxation Therapy/
192 | relaxation.ti,ab.
193 | Tai Ji/
194 | Tai Chi.ti,ab.
195 | walking.ti,ab.
196 | Yoga/
197 | yoga.ti,ab.
198 | Dancing/
199 | (dancing or dance).ti,ab.
200 | 171 or 172 or 173 or 174 or 175 or 176 or 177 or 178 or 179 or 180 or 181 or 182 or 183 or 184 or 185 or 186 or 187 or 188 or 189 or 190 or 191 or 192 or 193 or 194 or 195 or 196 or 197 or 198 or 199
201 | Caregivers/
202 | caregiver*.ti,ab.
203 | caregiving.ti,ab.
204 | (carer or carers).ti,ab.
205 | Self-Help Groups/
206 | self help.ti,ab.
207 | care giver*.ti,ab.
208 | Family Therapy/
209 | family therapy.ti,ab.
210 | Social Support/
211 | social support*.ti,ab.
212 | skills training.ti,ab.
213 | Health Education/
214 | health education.ti,ab.
215 | education.fs.
216 | education, continuing/ or education, medical, continuing/ or education, nursing, continuing/
217 | 201 or 202 or 203 or 204 or 205 or 206 or 207 or 208 or 209 or 210 or 211 or 212 or 213 or 214 or 215 or 216
218 | Counseling/
219 | Directive Counseling/
220 | Cognitive Therapy/
221 | cognitive therap*.ti,ab.
222 | psychotherapy/ or psychotherapy, brief/
223 | Behavior Therapy/
224 | behavio* therap*.ti,ab.
225 | psychotherap*.ti,ab.
226 | counsel*.ti,ab.
227 | 218 or 219 or 220 or 221 or 222 or 223 or 224 or 225 or 226
228 | (cognitive* adj3 engage*).ti,ab.
229 | (creative* adj3 engage*).ti,ab.
230 | (cognitive* adj3 stimulat*).ti,ab.
231 | cognitive training.ti,ab.
232 | cognitive intervention*.ti,ab.
233 | group reminiscence.ti,ab.
234 | reality orientation.ti,ab.
235 | Reality Therapy/
236 | reality therapy.ti,ab.
237 | cognitive exercis*.ti,ab.
238 | 228 or 229 or 230 or 231 or 232 or 233 or 234 or 235 or 236 or 237
239 | Case Management/
240 | Patient Care Management/
241 | care manage*.ti,ab.
242 | case manage*.ti,ab.
243 | 239 or 240 or 241 or 242
244 | ((multicomponent or multi component or multidisciplinary or multi disciplinary or multimodal or multi modal) adj3 (treatment* or program* or intervention*)).ti,ab.
245 | 26 or 44 or 47 or 77 or 101 or 109 or 112 or 143 or 157 or 170 or 200 or 217 or 227 or 238 or 243 or 244
246 | 16 and 245
247 | safety/
248 | safety.ti,ab.
249 | adverse event*.ti,ab.
250 | adverse effects.fs.
251 | adverse effect*.ti,ab.
252 | adverse outcome*.ti,ab.
253 | side effect*.ti,ab.
254 | product surveillance, postmarketing/
255 | “Drug-Related Side Effects and Adverse Reactions”/
256 | Long Term Adverse Effects/
257 | Adverse reaction*.ti,ab.
258 | Adverse drug reaction*.ti,ab.
259 | drug toxicity/
260 | drug toxicity.ti,ab.
261 | Harm*.ti,ab.
262 | 247 or 248 or 249 or 250 or 251 or 252 or 253 or 254 or 255 or 256 or 257 or 258 or 259 or 260 or 261
263 | case-control studies/
264 | retrospective studies/
265 | cohort studies/
266 | longitudinal studies/
267 | follow-up studies/
268 | prospective studies/
269 | Cross-Sectional Studies/
270 | cohort.ti,ab.
271 | longitudinal.ti,ab.
272 | follow up.ti,ab.
273 | followup.ti,ab.
274 | prospective*.ti,ab.
275 | retrospective*.ti,ab.
276 | comparison group*.ti,ab.
277 | control group*.ti,ab.
278 | observational.ti,ab.
279 | nonrandom*.ti,ab.
280 | database*.ti,ab.
281 | population*.ti,ab.
282 | cross sectional.ti,ab.
283 | 263 or 264 or 265 or 266 or 267 or 268 or 269 or 270 or 271 or 272 or 273 or 274 or 275 or 276 or 277 or 278 or 279 or 280 or 281 or 282
284 | 246 and 262 and 283
285 | Animals/ not (Humans/ and Animals/)
286 | 284 not 285
287 | limit 286 to (english language and yr="2012 -Current")
288 | remove duplicates from 287

## Dementia/Mild cognitive impairment

### Screening

#### PsycInfo

1 | Dementia/
2 | Dementia with Lewy bodies/
3 | Senile Dementia/
4 | Vascular Dementia/
5 | Alzheimer’s Disease/
6 | Cognitive Impairment/
7 | cognitive impairment$.ti.
8 | cognitive decline.ti.
9 | cognitive loss.ti.
10 | cognitive disorder$.ti.
11 | or/1–10
12 | Screening/
13 | Health Screening/
14 | Screening Tests/
15 | (screen$ or instrument or instruments).ti,ab,id.
16 | 12 or 13 or 14 or 15
17 | 11 and 16
18 | treatment outcome.md.
19 | experiment controls/
20 | controlled trial$.ti,ab,id,hw.
21 | clinical trial$.ti,ab,id,hw.
22 | random$.ti,ab,id,hw.
23 | placebo$.ti,ab,id,hw.
24 | meta analy$.ti,ab,hw,id.
25 | metaanaly$.ti,ab,hw,id.
26 | or/18–25 (238994)
27 | Psychometrics/
28 | Test Validity/
29 | Interrater Reliability/
30 | validity.ti,ab,id.
31 | reliability.ti,ab,id.
32 | psychometrics.ti,ab,id.
33 | Receiver operat$.ti,ab,id.
34 | ROC curve$.ti,ab,id.
35 | sensitivit$.ti,ab,id.
36 | specificit$.ti,ab,id.
37 | predictive value.ti,ab,id.
38 | accuracy.ti,ab,id.
39 | false positive$.ti,ab,id.
40 | false negative$.ti,ab,id.
41 | miss rate$.ti,ab,id.
42 | error rate$.ti,ab,id.
43 | or/27–42
44 | Anxiety/
45 | Anxiety Disorders/
46 | “Depression (Emotion)”/
47 | Labeling/ (2507)
48 | Psychological Stress/
49 | adverse$.ti,ab,id.
50 | harm$.ti,ab,id.
51 | anxiety.ti,ab,id.
52 | depression.ti,ab,id.
53 | (labeling or labelling or labeled or labelled).ti,ab,id.
54 | or/44–53
55 | 17 and (26 or 43 or 54)
56 | 17 and 55
57 | limit 56 to (english language and yr="2012 -Current")

## Dementia/Mild cognitive impairment

### Treatment

#### PsycInfo

1 | Dementia/
2 | Dementia with Lewy bodies/
3 | Senile Dementia/
4 | Vascular Dementia/
5 | Alzheimer’s Disease/
6 | Cognitive Impairment/
7 | cognitive impairment$.ti.
8 | cognitive decline.ti.
9 | cognitive loss.ti.
10 | cognitive disorder$.ti.
11 | or/1–10
12 | (multicomponent$ or multidisciplinary or multimodal or multi component or multi disciplinary or multi modal).mp.
13 | (case management or care management).mp.
14 | (cognitive training or cognitive intervention$ or counseling or cognitive therapy).mp.
15 | (reminiscence or reality therapy).mp.
16 | (Cognitive$ adj3 engage$).mp.
17 | (behavio$ therap$ or cognitive behavio$ therap$ or psychotherapy).mp.
18 | (Caregiv$ or carer).mp.
19 | support group$.mp.
20 | (self help or family therapy or social support).mp.
21 | (health education or continuing education).mp.
22 | (exercis$ or physical activity).mp.
23 | ((physical or strength or resistance or aerobic or cardiovascular or endurance or flexibility) adj training).mp.
24 | (relaxation or tai chi or walking or yoga or dancing or dance).mp.
25 | (Caregiv$ or carer).mp.
26 | (self help or family therapy or social support or support group*).mp.
27 | (health education or continuing education or skills training).mp.
28 | (behavio$ therap$ or cognitive behavio$ therap$ or psychotherapy).mp.
29 | (cognitive training or cognitive intervention$ or counseling or cognitive therap$).mp.
30 | (Cognitive$ adj3 (engage$ or stimulat$)).mp.
31 | (creative adj4 engage$).mp.
32 | (creative adj3 engage$).mp.
33 | (reminiscence or reality therapy or reality orientation).mp.
34 | (case management or care management).mp.
35 | (multicomponent or multidisciplinary or multimodal or multi component or multi disciplinary or multi modal).mp.
36 | or/12–35
37 | 11 and 36
38 | treatment outcome.md.
39 | experiment controls/
40 | controlled trial$.ti,ab,id,hw.
41 | clinical trial$.ti,ab,id,hw.
42 | random$.ti,ab,id,hw.
43 | placebo$.ti,ab,id,hw.
44 | meta analy$.ti,ab,hw,id.
45 | metaanaly$.ti,ab,hw,id.
46 | or/38–45
47 | 37 and 46
48 | Anxiety/
49 | Anxiety Disorders/
50 | “Depression (Emotion)”/
51 | Psychological Stress/
52 | exp “side effects (treatment)”/
53 | safety.ti,ab,id.
54 | adverse$.ti,ab,id.
55 | harm$.ti,ab,id.
56 | anxiety.ti,ab,id.
57 | depression.ti,ab,id.
58 | or/48–57
59 | 37 and 58
60 | 47 or 59
61 | limit 60 to (english language and yr="2012 -Current")

#### PubMed, publisher-supplied records

#26 (https://www.ncbi.nlm.nih.gov/pubmed) | #25 AND English[Language] AND (“2012”[Date - Publication] : “3000”[Date - Publication])
#25 (https://www.ncbi.nlm.nih.gov/pubmed) | #24 AND publisher[sb]
#24 (https://www.ncbi.nlm.nih.gov/pubmed) | #5 OR #7 OR #23
#23 (https://www.ncbi.nlm.nih.gov/pubmed) | #1 AND #22
#22 (https://www.ncbi.nlm.nih.gov/pubmed) | #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21
#21 (https://www.ncbi.nlm.nih.gov/pubmed) | (exercis*[tiab] OR “physical activity”[tiab] OR “physical training”[tiab] OR “strength training”[tiab] OR “resistance training”[tiab] OR “aerobic training”[tiab] OR “cardiovascular training”[tiab] OR “endurance training”[tiab] OR “flexibility training”[tiab] OR relaxation[tiab] OR walking[tiab] OR yoga[tiab] OR “tai chi”[tiab] OR danc*[tiab]
#20 (https://www.ncbi.nlm.nih.gov/pubmed) | multicomponent[tiab] OR multidisciplinary[tiab] OR multimodal[tiab] OR “multi component”[tiab] OR “multi disciplinary”[tiab] OR “multi modal”[tiab]
#19 (https://www.ncbi.nlm.nih.gov/pubmed) | “case management”[tiab] OR “care management”[tiab]
#18 (https://www.ncbi.nlm.nih.gov/pubmed) | engage*[tiab] OR “cognitive exercise”[tiab] OR “cognitive exercises”[tiab]
#17 (https://www.ncbi.nlm.nih.gov/pubmed) | counsel*[tiab] OR psychotherapy[tiab] OR behavio* therap*[tiab] OR cognitive therapy*[tiab]
#16 (https://www.ncbi.nlm.nih.gov/pubmed) | caregiv*[tiab] OR carer*[tiab] OR “self help”[tiab] OR “family therapy”[tiab] OR “social support”[tiab] OR “skills training”[tiab] OR education[tiab]
#15 (https://www.ncbi.nlm.nih.gov/pubmed) | omega*[tiab] OR “fatty acid”[tiab] OR “fatty acids”[tiab] OR linolenic[tiab] OR “mediterranean diet”[tiab]
#14 (https://www.ncbi.nlm.nih.gov/pubmed) | antioxidant*[tiab] OR “vitamin e”[tiab] OR “ascorbic acid”[tiab] OR ascorbate[tiab] OR “vitamin c”[tiab] OR “beta carotene”[tiab]
#13 (https://www.ncbi.nlm.nih.gov/pubmed) | folic[tiab] OR folate[tiab] OR “vitamin b”[tiab] OR bl[tiab] OR b2[tiab] OR b6[tiab] OR b12[tiab]
#12 (https://www.ncbi.nlm.nih.gov/pubmed) | cholinesterase[tiab] OR donepezil[tiab] OR galantamine[tiab] OR memantine[tiab]
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | hormone*[tiab] OR estrogen*[tiab] OR estradiol[tiab] OR Medroxyprogesterone[tiab] OR Progesterone[tiab] OR androgen*[tiab] OR testosterone[tiab] OR Dehydroepiandrosterone[tiab] OR Norethindrone[tiab]
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | aspirin[tiab]
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | nsaid*[tiab] OR nonsteroidal[tiab]
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | statin*[tiab] OR antihypertensive*[tiab] OR diuretic*[tiab] OR beta blocker*[tiab] OR alpha blocker*[tiab] OR ace inhibitor*[tiab] OR “calcium channel”[tiab] OR vasodilator*[tiab]
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | #1 AND #6
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | sensitivit*[tiab] OR “ROC Curve”[tiab] OR “predictive value”[tiab] OR accuracy[tiab] OR false negative*[tiab] OR false positive*[tiab] OR diagnostic error*[tiab] OR reproducibility[tiab] OR reference value*[tiab] OR reference value*[tiab] OR reference standard*[tiab] OR observer variation*[tiab]
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | #3 OR #4
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | (cognitive[ti] AND screen*[ti])
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | #1 AND #2
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | screen*[tiab] OR instrument[tiab] OR instruments[tiab] OR assess*[ti] OR tool*[ti] OR test*[ti] OR evaluat*[ti] OR questionnaire*[ti]
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | dementia[ti] OR “cognitive impairment”[ti] OR “cognitively impaired”[ti] OR “cognitive impairments”[ti] OR “cognitive loss”[ti] OR “cognitive decline”[ti] OR “cognitive disorder”[ti] OR “cognitive disorders”[ti] OR mci[ti]

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Condition | KQs 1–3: Any cognitive impairment (mild cognitive impairment^*^ or dementia^†^); KQs 4, 5: Mild cognitive impairment^*^ or mild to moderate dementia^†^ | KQs 4, 5: Severe dementia
Populations | KQs 1–3: Community-dwelling older adults (including those residing in independent living facilities) age ≥65 years (or studies with a mean age ≥65 years) without a current diagnosis of mild cognitive impairment or dementia; informal caregivers taking some responsibility for the care of the patient, such as a spouse, partner, relative, or friend; KQs 4–5: Community-dwelling older adults (including those residing in independent living facilities) age ≥65 years (or studies with a mean age ≥65 years) with a current diagnosis of mild cognitive impairment or dementia; informal caregivers taking some responsibility for the care of the patient, such as a spouse, partner, relative, or friend | - Studies comprised exclusively of persons diagnosed with depression or psychosis, alcohol use disorder, HIV/AIDS, Down syndrome, posttraumatic brain injury, metabolic disorders, Parkinson’s disease, Huntington’s disease, or stroke; - Persons living in special settings outside of the community (e.g., hospitals, nursing or care homes, rehabilitation centers, other long-term care facilities); - Professional caregivers who are formally or professionally trained and paid a salary
Settings | Primary care outpatient settings (ambulatory care), home, residential care facilities, assisted living facilities, and adult foster care | All KQs: Hospitals, intermediate care facilities (e.g., nursing homes, rehabilitation facilities, subacute care facilities), emergency departments, or other settings not generalizable to primary care; KQs 1–3: Studies in which participants are recruited from memory, dementia, geropsychiatry, or neurology clinics
Screening | Screening instruments that can be delivered in primary care in ≤10 minutes by the clinician or ≤20 minutes by the patient; informant instruments | Screening instruments that take >10 minutes for clinician administration or >20 minutes for self-administration; biomarkers (cerebrospinal fluid, blood plasma, urine) or imaging (computed tomography, magnetic resonance imaging, positron emission tomography)
Interventions | - Use of medications approved by the U.S. Food and Drug Administration (alone or in combination) for the treatment of dementia:; ○ Acetylcholinesterase inhibitors (donepezil, galantamine, rivastigmine); ○ NMDA (N-methyl-D-aspartate) receptor antagonists (memantine); - Use of other medications or dietary supplements:; ○ Medications aimed at cardiovascular risk reduction for treatment of vascular dementia (antiplatelet medications, antihypertension medications, HMG-CoA reductase inhibitors); ○ Nonsteroidal anti-inflammatory drugs (ibuprofen, naproxen, indomethacin, celecoxib); ○ Gonadal steroids (estrogen, progesterone, testosterone); ○ Vitamins, minerals, and antioxidants (B vitamins and folate, vitamins C and E, beta-carotene, omega-3 fatty acids); - Cessation of medications that may be contributing to cognitive impairment (e.g., anticholinergic medications, benzodiazepines); - Nonpharmacologic interventions aimed primarily at the patient, including cognitive training, rehabilitation, or stimulation, with or without motor skills training interventions; exercise interventions; nutrition counseling; multidisciplinary care interventions involving assessment and care coordination; and education-only interventions; - Nonpharmacologic interventions aimed primarily at the caregiver or caregiver-patient dyad | - Treatments for symptom management (e.g., agitation, psychosis, depression) of dementia (i.e., antipsychotics, antiepileptics, antidepressants, selective serotonin reuptake inhibitors); - Medications not approved by the U.S. Food and Drug Administration for the treatment of dementia or not available in the United States (e.g., tacrine); - Herbal supplements (e.g., ginkgo biloba); - Medical foods or fluids or nutrition therapy (e.g., meal replacement therapy); - Experimental or emerging therapies (e.g., amyloid disease-modifying treatments); - Interventions aimed at noncognitive symptom management (e.g., music, light, pet, reminiscence, or psychodynamic interpersonal therapy; nighttime home monitoring systems; Snoezelen® multisensory environments); - Respite care or day care interventions
Comparisons | KQs 1, 3: No screening, usual care; KQ 2: Reference standard (clinical assessment or neuropsychologic testing with explicit diagnostic criteria, with or without expert consensus/conference); KQs 3–5:; - No intervention; - Usual care; - Wait list; - Attention control; - Minimal intervention | KQs 4, 5: Active intervention
Outcomes | KQs 1, 4:; Decisionmaking outcomes:; - For patients and family/caregivers: Health care, legal, and financial planning (e.g., advanced directives); safety planning; living arrangements; - For clinicians: Health care planning, including advanced directives; patient and caregiver education; safety planning; monitored medication use; screening and diagnostic decisions (e.g., cancer screening); and other treatment or management decisions; Patient-related outcomes:; - Health-related quality of life; - Incident dementia; - Overall dementia severity; - Cognitive function; - Physical function (e.g., activities of daily living, instrumental activities of daily living); - Global function; - Dementia-related symptoms/behaviors (e.g., neuropsychiatric disturbances, insomnia, depression, agitation, verbal aggression, apathy); - Safety (falls, other accidents); - Unanticipated health care utilization (emergency use/hospitalizations); - Institutionalizations/nursing home admissions; - Medication adherence/compliance/errors; Family/caregiver-related outcomes: (a priori defined as primary or secondary outcomes in the trial); - Health-related quality of life; - Global stress/distress; - Caregiver burden; - Depression; - Anxiety; Societal outcomes: Safety (e.g., automobile accidents); KQ 2: Sensitivity, specificity, likelihood ratios, positive and negative predictive values, area under the curve; KQ 3: Paradoxical effects (unwanted or unexpected direction of effects of outcomes), psychological harms (depression, anxiety), and harms due to labeling (psychological harms, insurance status, loss of driving privileges); KQ 5: Serious adverse events (e.g., death, serious adverse drug reactions), adverse reactions from medications, unexpected medical attention (e.g., emergency department visits, hospitalizations), paradoxical effects (unwanted or unexpected direction of effects of outcomes), and psychological harms (depression, anxiety) | KQs 1, 4:; Decisionmaking outcomes: Cost-related outcomes; Patient-related outcomes: Cost-related outcomes; patient satisfaction (other than health-related quality of life); biomarker protein levels, brain matter volume, and brain cell activity level; function markers (e.g., Timed Up and Go Test, 6-meter timed walk, Functional Reach Test); Family/caregiver-related outcomes: Cost-related outcomes; family/caregiver satisfaction (other than caregiver burden and health-related quality of life); Societal outcomes: Cost-related outcomes; KQ 2: Cost-related outcomes; KQs 3, 5: Patient or family/caregiver dissatisfaction (other than psychological harms or patient adherence)
Timing of outcome assessment | KQs 1, 4: ≥3 months after baseline; KQs 3, 5: No minimum followup | KQs 1, 4: <3 months after baseline
Countries | Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries that are not categorized as “Very High” on the 2014 Human Development Index
Study designs | KQs 1, 4: Randomized, controlled trials; nonrandomized, controlled trials; KQ 2: Diagnostic accuracy studies; KQs 3, 5: Randomized, controlled trials; nonrandomized, controlled trials; open-label extensions of KQ 4 trials; cohort or case-control studies | KQs 1, 4: Observational studies; KQ 2: Case-control studies; KQ 3, 5: Case series, case reports; KQ 5: Cohort or case-control studies with <1,000 participants
Publication language | English | Languages other than English
Study quality | Fair- or good-quality studies | Poor-quality studies (according to design-specific USPSTF criteria)

* Mild cognitive impairment is distinguished from dementia by virtue of causing cognitive impairment that is not severe enough to interfere with independence in daily function, although the nomenclature, definitions, and criteria may vary within the included body of evidence.

† Includes major dementia syndromes due to Alzheimer’s disease, vascular dementia, frontotemporal dementia, dementia with Lewy bodies, and dementia of mixed etiology.

Abbreviations: KQ = key question; USPSTF = United States Preventive Services Task Force

Appendix A Table 2 Study Design–Specific Quality Rating Criteria^*^

Study Design | Adapted Quality Criteria
Cohort studies, adapted from Newcastle-Ottawa Scale^110^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) I^111^ and II^112^ instrument | Patient Selection; - Was a consecutive or random sample of patients enrolled?; - Did the study avoid inappropriate exclusions?; Index Test; - Were the index test results interpreted without knowledge of the reference standard results?; - If a threshold was used, was it prespecified or was a range of values presented?; Reference Standard; - Is the reference standard likely to correctly classify the target condition?; - Were the reference standard results interpreted without knowledge of the index test?; - Were staff trained in the use of the reference standard?; - Was fidelity of the reference standard monitored or reported?; Flow and Timing; - Was there an appropriate interval between the index test and reference standard?; - Did all patients receive a reference standard?; - Did all patients receive the same reference standard?; ○ Were all patients included in the analysis?
Randomized clinical trials, adapted from U.S. Preventive Services Task Force Manual^109^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* All randomized clinical trials were classified as good, fair, or poor according to the USPSTF Procedure Manual^109^

Appendix A Table 3 Assessment Scales Commonly Used in Included Trials

Domain/Scale | Description | Number of items; range; direction | Clinical Interpretation
Global Cognitive Function | Memory, orientation, language, praxis, etc.
Alzheimer’s Disease Assessment Scale-cognitive subscale (ADAS-Cog-11)^463,^ ^464^ | - Cognitive subscale of the ADAS that includes 11 tasks that include both subject-completed tests and observer-based assessments; - Specific tasks include word recall, naming objects and fingers, commands, constructional praxis, ideational praxis, orientation, word recognition, and language; - Most sensitive in moderate-stage patients, but not those in mild stage | 11; 0–70; higher scores worse | Interpretation of score: ^464^; No impairment: 0; Severe impairment: 70; Interpretation of change: ^107^; A change of 4 points or more on the ADAS-Cog scale is considered a clinically important improvement for mild to moderate dementia
Mini-Mental State Exam (MMSE)^465^ | - Clinician administered patient evaluation; - Assesses 5 cognitive domains: orientation, memory (registration and recall), attention/calculation, language, and visuospatial abilities | 11; 0–30; higher scores better | Interpretation of score: ^465^; No impairment: 30; Severe impairment: 0; Interpretation of change: ^107^; A change of 3 points or more is considered clinically important
Global Function | Summary outcome assessment of overall severity of condition | | Any improvement in global function is considered clinical improvement; however, results depend on an individual physician’s perception.
Clinician’s Interview-Based Impression of Change with Caregiver Input (CIBIC+)^466^ | - Clinician rated (with caregiver input), based on semi-structured interview covering change in cognition, behavior, function | NA (unstructured interview); 1–7; higher scores worse | Interpretation of score: ^466^; Marked improvement: 1; Moderate improvement: 2; Minimal improvement: 3; No change: 4; Minimal worsening: 5; Moderate worsening: 6; Marked worsening: 7
Clinical Dementia Rating (CDR)/CDR-Sum of Boxes (CDR-SB)^467^ | - Clinician administered semi-structured interview of patient and a reliable collateral source (e.g., family member); - Characterizes six domains of cognitive functional performance applicable to ADRD: memory, orientation, judgement & problem solving, community affairs, home & hobbies, and personal care | CDR: 6; 0–3; higher scores worse; CDR-SB: 6; 0–18; higher scores worse | Interpretation of score: ^467^; CDR:; No dementia: 0; Questionable dementia: 0.5; Mild dementia: 1; Moderate dementia: 2; Severe dementia: 3
Global Deterioration Scale (GDS)^468^ | - Clinician rated based on cognitive change only; - Provides caregivers an overview of the stages of cognitive function from a primary degenerative dementia such as AD | NA (unstructured interview); 1–7; higher scores worse | Interpretation of score: ^468^; No decline: 1; Very mild cognitive decline: 2; Mild cognitive decline (MCI): 3; Moderate cognitive decline: 4; Moderately severe cognitive decline: 5; Severe cognitive decline: 6; Very severe cognitive decline: 7
Physical Function | Activities of daily living (ADLs) and Instrumental activities of daily living (IADLs)
Alzheimer’s Disease Cooperative Study Activities of Daily Living (ADCS-ADL_23_) (23-item version)^469^ | - Informant rated interview developed to evaluate ADL abilities over time and detect changes in patients with mild-to-moderate AD, such as using household appliances, choosing clothes to wear, bathing, and toileting | 23; 0–78; higher scores better | Interpretation of score: ^469^; Higher scores indicate less functional impairment
Disability Assessment for Dementia (DAD)^470^ | - Administered through an interview with the caregiver/informant; - Intended specifically for the assessment of basic ADLs (hygiene, dressing, continence, and eating) and IADLs (meal preparation, telephoning, going on an outing, finance and correspondence, leisure, and housework) in patients with AD. Each activity is evaluated according to three executive factors: initiation, planning-organization, and performance | 40; 0–100; higher scores better | Interpretation of score: ^470^; Higher scores indicate less functional disability
Lawton & Brody Instrumental Activities of Daily Living Scale (Lawton IADL)^471^ | - Information obtained through self-report or surrogate report; - Measures 8 domains of function: ability to use telephone, shopping, food preparation, housekeeping, laundry, mode of transportation, responsibility for own medications, and ability to handle finances | 8; 0–8-point scale; higher scores better | Interpretation of score: ^471^; Low function, dependent: 0; High function, independent: 8
Patient Mental Health and Neuropsychiatric Symptoms | Depression and composite neuropsychiatric symptom scores
Cornell Scale for Depression in Dementia (CSDD)^472^ | - Information obtained from interview of a caregiver/informant as well as form direct observation and interview of the patient; - Designed to assess major depression in elderly people with dementia based on mood-related signs, behavioral disturbance, physical signs, cyclic functions, and ideational disturbance | 19; 0–38; higher scores worse | Interpretation of score: ^472^; Absence of significant depression symptoms: <6; Probable depression: ≥10; Definite major depression: ≥18
Geriatric Depression Scale (GDS)/GDS-15 item (GDS-15)^473^ | - Designed to detect depression in the elderly, assessment is based on self-report | GDS: 30; 0–30; higher scores worse; GDS-15: 15; 0–15; higher scores worse | Interpretation of score:; GDS:; Normal: 0–9; Mild depression: 10–19; Severe depression: ≥20; GDS-15:; Normal: 0–5; Presence of depression (indicates further evaluation needed): 6–10; Definite depression: ≥11
Neuropsychiatric Inventory (NPI-10^474^ or NPI-12^475^) | - NPI-10: Caregiver/informant interview of 10 behavioral symptom domains rated on a scale based on frequency and severity (delusions, hallucinations, agitation/aggression, dysphoria, anxiety, euphoria, apathy, disinhibition, irritability/lability, and aberrant motor behavior); - NPI-12: Caregiver/informant interview of 10 behavioral symptom domains (delusions, hallucinations, agitation/aggression, dysphoria, anxiety, euphoria, apathy, disinhibition, irritability/lability, and aberrant motor behavior) and 2 neurovegetative domains (sleep and appetite) rated on a scale based on frequency and severity | NPI-10: 10; 0–120; higher scores worse; NPI-12: 12; 0–144; higher scores worse | Higher scores indicate more behavioral disturbance for both NPI and RMBPC. Unclear interpretation of specific scores.
Revised Memory and Behavior Problems Checklist (RMBPC) (Total Number of Behavioral and Memory Problems or Total Frequency of Memory and Behavioral Problems)^476^ | - Caregiver-administered paper-and-pencil measure; - Portion of the RMBPC focused on the frequency and total number of problematic behaviors (memory-related problems, depression, and disruptive behaviors) in patients with dementia | RMBPC (Total): 24; 0–24; higher scores worse; RMBPC (Frequency): 24; 0–96; higher scores worse | Higher scores indicate more behavioral disturbance for both NPI and RMBPC. Unclear interpretation of specific scores.
Caregiver Depressive Symptomatology
Center for Epidemiologic Studies – Depression Scale (CES-D)^477^ | - Short self-report scale designed to measure depressive symptomatology in caregivers; - Scores represent depressed affect, absence of positive affect or anhedonia, somatic activity or inactivity, and interpersonal challenges | 20; 0–60; higher scores worse | Interpretation of score:^354,^ ^477^; Clinically significant depression: ≥16
Beck Depression Inventory (BDI-I, II)^478^ | - Self-rated scale that evaluates key symptoms of depression including mood, pessimism, sense of failure, self-dissatisfaction, guilt, punishment, self-dislike, self-accusation, suicidal ideas, crying, irritability, social withdrawal, indecisiveness, body image change, work difficulty, insomnia, fatigability, loss of appetite, weight loss, somatic preoccupation, and loss of libido | 21; 0–63; higher scores worse | Interpretation of score:; Minimal depression: 0–13; Mild depression: 14–19; Moderate depression: 20–28; Severe depression: 29–63
Caregiver Burden
Zarit Burden Interview-22 item (Zarit-22)^479^ | - Caregiver-rated or clinician-administered interview; - Measures perceived social, physical, financial, and emotional burden of caregiving | 22; 0–88; higher scores worse | Higher scores indicate greater caregiver burden for Zarit-22 and RMBPC. Unclear interpretation of specific scores.
Revised Memory and Behavior Problems Checklist (RMBPC) – Total caregiver reaction to problem behaviors^476^ | - Caregiver-administered paper-and-pencil measure; - Portion of the RMBPC focused on the caregiver’s reaction to problematic behaviors (memory-related problems, depression, and disruptive behaviors) in patients with dementia | 24; 0–96; higher scores worse | Higher scores indicate greater caregiver burden for Zarit-22 and RMBPC. Unclear interpretation of specific scores.
Patient and Caregiver Quality of Life
Quality of Life in Alzheimer’s Disease (QOL-AD)^480^ | - Patients and caregivers typically complete the QOL-AD separately; - 13-items that measure the domains of physical condition, mood, memory, functional abilities, interpersonal relationships, ability to participate in meaningful activities, financial situation, and global assessments of self as a whole and QOL as a whole | 13; 13–52; higher scores better | Higher scores indicate better quality of life for all listed QOL instruments. Unclear interpretation of specific scores.
Dementia Quality of Life (DEMQOL)^481^ | - Patient- or proxy-reported; - Addresses 5 domains: daily activities and looking after yourself, health and well-being, cognitive functioning, social relationships and self-concept | 28; 28–112; higher scores better | Higher scores indicate better quality of life for all listed QOL instruments. Unclear interpretation of specific scores.
EuroQOL-5 dimensions (EQ-5D)^482^ | - Patient- or proxy-reported health-related quality of life; - Has 2 core components: a description of the respondent’s own health using a health state classification system with 5 dimensions (mobility, self-care, usual activities, pain/discomfort, and anxiety/depression) and a rating on a visual analog thermometer scale | 5; 0–100; higher scores better | Higher scores indicate better quality of life for all listed QOL instruments. Unclear interpretation of specific scores.
Short Form Health Survey – 36 Item (SF-36)/Short Form Health Survey –12 Item (SF-12)^483^ | - Patient- or proxy-reported (patient); self-administered (caregiver); - Organized into 8 multi-item scales including physical functioning; role limitations due to physical health (Role functioning/physical); role limitations due to emotional problems (Role functioning/emotional); energy/fatigue (vitality); emotional well-being (mental health); social functioning; pain; general health | SF-36: 36; 0–100; higher scores better; SF-12: 12; 0–100; higher scores better | Higher scores indicate better quality of life for all listed QOL instruments. Unclear interpretation of specific scores.