# References

1 Chou R, Cottrell EB, Wasson N, . Screening for hepatitis C virus infection in adults: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 Jan 15;158(2):101–8. doi: 10.7326/0003-4819-158-2-201301150-00574. PMID: 23183613.23183613
2 Chou R, Cottrell E, Wasson N, . Screening for Hepatitis C Virus Infection in Adults. Comparative Effectiveness Review no. 69. (prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 12(13)-EHC090-EF. Rockville, MD: Agency for Healthcare Research and Quality. November 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed June 25, 2019.
3 Cottrell EB, Chou R, Wasson N, . Reducing risk for mother-to-infant transmission of hepatitis C virus: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 Jan 15;158(2):109–13. doi: 10.7326/0003-4819-158-2-201301150-00575. PMID: 23437438.23437438
4 Chou R, Hartung D, Rahman B, . AHRQ comparative effectiveness reviews. Treatment for Hepatitis C Virus Infection in Adults. Rockville (MD): Agency for Healthcare Research and Quality (US); 2012.
5 Chou R, Hartung D, Rahman B, . Comparative effectiveness of antiviral treatment for hepatitis C virus infection in adults: a systematic review. Ann Intern Med. 2013 Jan 15;158(2):114–23. doi: 10.7326/0003-4819-158-2-201301150-00576. PMID: 23437439.23437439
6 Moyer VA, U. S. Preventive Services Task Force. Screening for hepatitis C virus infection in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Sep 03;159(5):349–57. doi: 10.7326/0003-4819-159-5-201309030-00672. PMID: 23798026.23798026
7 U. S. Preventive Services Task Force. Screening for hepatitis c virus infection in adults: recommendation statement. Ann Intern Med. 2004;140(6):462–4. doi: 10.7326/0003-4819-140-6-200403160-00013.15023712
8 Rein DB, Smith BD, Wittenborn JS, . The cost-effectiveness of birth-cohort screening for hepatitis C antibody in U.S. primary care settings. Ann Intern Med. 2012 Feb 21;156(4):263–70. doi: 10.7326/0003-4819-156-4-201202210-00378. PMID: 22056542.22056542
9 Liu S, Cipriano LE, Holodniy M, . Cost-effectiveness analysis of risk-factor guided and birth-cohort screening for chronic hepatitis C infection in the United States. PLoS ONE. 2013;8(3):e58975. doi: 10.1371/journal.pone.0058975. PMID: 23533595.23533595
10 Centers for Disease Control and Prevention. Viral Hepatitis. Hepatitis C Information: Hepatitis C Questions and Answers for Health Professionals. Atlanta GA: U.S. Department of Health & Human Services; 2017. https://www.cdc.gov/hepatitis/hcv/hcvfaq.htm. Accessed June 25, 2019.
11 Germer JJ, Mandrekar JN, Bendel JL, . Hepatitis C virus genotypes in clinical specimens tested at a national reference testing laboratory in the United States. J Clin Microbiol. 2011 Aug;49(8):3040–3. doi: 10.1128/jcm.00457-11. PMID: 21613437.21613437
12 Manos MM, Shvachko VA, Murphy RC, . Distribution of hepatitis C virus genotypes in a diverse US integrated health care population. J Med Virol. 2012 Nov;84(11):1744–50. doi: 10.1002/jmv.23399. PMID: 22997077.22997077
13 Edlin BR, Eckhardt BJ, Shu MA, . Toward a more accurate estimate of the prevalence of hepatitis C in the United States. Hepatology. 2015 Nov;62(5):1353–63. doi: 10.1002/hep.27978. PMID: 26171595.26171595
14 Rosenberg ES, Hall EW, Sullivan PS, . Estimation of state-level prevalence of hepatitis C virus infection, US States and District of Columbia, 2010. Clin Infect Dis. 2017 Apr 26;64(11):1573–81. doi: 10.1093/cid/cix202. PMID: 28449115.28449115
15 Armstrong GL, Wasley A, Simard EP, . The prevalence of hepatitis c virus infection in the United States, 1999 through 2002. Ann Intern Med. 2006 May 2006;144(10):705–14. PMID: 1670258616702586
16 Hofmeister MG, Rosenthal EM, Barker LK, . Estimating prevalence of hepatitis C virus infection in the United States, 2013-2016. Hepatology. 2019 Nov 6;69(3):1020–31. doi: 10.1002/hep.30297. PMID: 30398671.30398671
17 Smith BD, Morgan RL, Beckett GA, . Recommendations for the identification of chronic hepatitis C virus infection among persons born during 1945-1965. MMWR. 2012 Aug 17;61(RR-4):1–32. PMID: 22895429.22895429
18 Denniston MM, Jiles RB, Drobeniuc J, . Chronic hepatitis C virus infection in the United States, National Health and Nutrition Examination Survey 2003 to 2010. Ann Intern Med. 2014 Mar 4;160(5):293–300. doi: 10.7326/m13-1133. PMID: 24737271.24737271
19 Ly KN, Xing J, Klevens RM, . Causes of death and characteristics of decedents with viral hepatitis, United States, 2010. Clin Infect Dis. 2014 Jan;58(1):40–9. doi: 10.1093/cid/cit642. PMID: 24065331.24065331
20 Centers for Disease Control and Prevention. Surveillance for viral hepatitis – United States, 2016. 2018. https://www.cdc.gov/hepatitis/statistics/2016surveillance/commentary.htm. Accessed June 25, 2019.
21 Zibbell JE, Iqbal K, Patel RC, . Increases in hepatitis C virus infection related to injection drug use among persons aged ≤30 years - Kentucky, Tennessee, Virginia, and West Virginia, 2006-2012. MMWR. 2015 May 08;64(17):453–8. PMID: 25950251.25950251
22 Squires JE, Balistreri WF. Hepatitis C virus infection in children and adolescents. Hepatol Commun. 2017;1(2):87–98. doi: 10.1002/hep4.1028.29404447
23 Centers for Disease Control and Prevention. Hepatitis C virus infection among adolescents and young adults: Massachusetts, 2002-2009. MMWR. 2011 May 6;60(17):537–41. PMID: 21544042.21544042
24 Koneru A, Nelson N, Hariri S, . Increased hepatitis C virus (HCV) detection in women of childbearing age and potential risk for vertical transmission - United States and Kentucky, 2011-2014. MMWR. 2016 Jul 22;65(28):705–10. doi: 10.15585/mmwr.mm6528a2. PMID: 27442053.27442053
25 Ly KN, Jiles RB, Teshale EH, . Hepatitis C virus infection among reproductive-aged women and children in the United States, 2006 to 2014. Ann Intern Med. 2017 Jun 06;166(11):775–82. doi: 10.7326/m16-2350. PMID: 28492929.28492929
26 Ly KN, Hughes EM, Jiles RB, . Rising mortality associated with hepatitis C virus in the United States, 2003–2013. Clin Infect Dis. 2016;62(10):1287–8. doi: 10.1093/cid/ciw111.26936668
27 Centers for Disease Control and Prevention. Viral hepatitis. Statistics & surveillance: 2015 surveillance. Atlanta, GA; 2017. https://www.cdc.gov/hepatitis/statistics/2015surveillance/commentary.htm. Accessed June 20, 2017.
28 Foster GR, Goldin RD, Thomas HC. Chronic hepatitis C virus infection causes a significant reduction in quality of life in the absence of cirrhosis. Hepatology. 1998 Jan;27(1):209–12. doi: 10.1002/hep.510270132. PMID: 9425939.9425939
29 Kenny-Walsh E. Clinical outcomes after hepatitis C infection from contaminated anti-D immune globulin. Irish Hepatology Research Group. N Engl J Med. 1999 Apr 22;340(16):1228–33. doi: 10.1056/nejm199904223401602. PMID: 10210705.10210705
30 Koff RS. Impaired health-related quality of life in chronic hepatitis C: the how, but not the why. Hepatology. 1999 Jan;29(1):277–9. doi: 10.1002/hep.510290127. PMID: 9862878.9862878
31 Rodger AJ, Jolley D, Thompson SC, . The impact of diagnosis of hepatitis C virus on quality of life. Hepatology. 1999 Nov;30(5):1299–301. PMID: 10534353.10534353
32 Rowan PJ, Al-Jurdi R, Tavakoli-Tabasi S, . Physical and psychosocial contributors to quality of life in veterans with hepatitis C not on antiviral therapy. J Clin Gastroenterol. 2005;39(8):731–6. PMID: 16082286.16082286
33 Cacoub P, Comarmond C, Domont F, . Extrahepatic manifestations of chronic hepatitis C virus infection. Ther Adv Infect Dis. 2016 Feb;3(1):3–14. doi: 10.1177/2049936115585942. PMID: 26862398.26862398
34 Bialek SR, Terrault NA. The changing epidemiology and natural history of hepatitis C virus infection. Clin Liver Dis. 2006 Nov;10(4):697–715. doi: 10.1016/j.cld.2006.08.003. PMID: 17164113.17164113
35 El-Serag HB. Epidemiology of viral hepatitis and hepatocellular carcinoma. Gastroenterology. 2012 May;142(6):1264–73.e1. doi: 10.1053/j.gastro.2011.12.061. PMID: 22537432.22537432
36 Cholankeril G, Ahmed A. Alcoholic liver disease replaces hepatitis C virus infection as the leading indication for liver transplantation in the United States. Clin Gastroenterol Hepatol. 2018;16(8):1356–8.29199144
37 Goldberg D, Ditah IC, Saeian K, . Changes in the prevalence of hepatitis C virus infection, nonalcoholic steatohepatitis, and alcoholic liver disease among patients with cirrhosis or liver failure on the waitlist for liver transplantation. Gastroenterology. 2017 Apr;152(5):1090–9.e1. doi: 10.1053/j.gastro.2017.01.003. PMID: 28088461.28088461
38 Freeman AJ, Dore GJ, Law MG, . Estimating progression to cirrhosis in chronic hepatitis C virus infection. Hepatology. 2001 Oct;34(4 Pt 1):809–16. doi: 10.1053/jhep.2001.27831. PMID: 11584380.11584380
39 McCaughan GW, George J. Fibrosis progression in chronic hepatitis C virus infection. Gut. 2004;53(3):318–21. PMID: 14960506.14960506
40 Dienstag JL, Ghany MG, Morgan TR, . A prospective study of the rate of progression in compensated, histologically advanced chronic hepatitis C. Hepatology. 2011 Aug;54(2):396–405. doi: 10.1002/hep.24370. PMID: 21520194.21520194
41 Seeff LB. Natural history of chronic hepatitis C. Hepatology. 2002 Nov;36(5 Suppl 1):S35–46. doi: 10.1053/jhep.2002.36806. PMID: 12407575.12407575
42 Barrett S, Goh J, Coughlan B, . The natural course of hepatitis C virus infection after 22 years in a unique homogenous cohort: spontaneous viral clearance and chronic HCV infection. Gut. 2001 Sep;49(3):423–30. PMID: 11511566.11511566
43 Harris HE, Ramsay ME, Andrews N, . Clinical course of hepatitis C virus during the first decade of infection: cohort study. BMJ. 2002 Feb 23;324(7335):450–3. PMID: 11859045.11859045
44 Seeff LB, Miller RN, Rabkin CS, . 45-year follow-up of hepatitis C virus infection in healthy young adults. Ann Intern Med. 2000 Jan 18;132(2):105–11. PMID: 10644270.10644270
45 Thomas DL. Hepatitis C epidemiology: injecting new tools in the field. Hepatology. 2000 Mar;31(3):790–1. doi: 10.1002/hep.510310336. PMID: 10706576.10706576
46 Wiese M, Berr F, Lafrenz M, . Low frequency of cirrhosis in a hepatitis C (genotype 1b) single-source outbreak in germany: a 20-year multicenter study. Hepatology. 2000 Jul;32(1):91–6. doi: 10.1053/jhep.2000.8169. PMID: 10869294.10869294
47 Wiese M, Grüngreiff K, Güthoff W, . Outcome in a hepatitis C (genotype 1b) single source outbreak in Germany—a 25-year multicenter study. J Hepatol. 2005;43(4):590–8. PMID: 16237783.16237783
48 Butt AA, Yan P, Lo Re V, 3rd, . Liver fibrosis progression in hepatitis C virus infection after seroconversion. JAMA Intern Med. 2015 Feb;175(2):178–85. doi: 10.1001/jamainternmed.2014.6502. PMID: 25485735.25485735
49 Thein HH, Yi Q, Dore GJ, . Estimation of stage-specific fibrosis progression rates in chronic hepatitis C virus infection: a meta-analysis and meta-regression. Hepatology. 2008;48(2):418–31. doi: 10.1002/hep.22375. PMID: 18563841.18563841
50 Wiese M, Fischer J, Lobermann M, . Evaluation of liver disease progression in the German hepatitis C virus (1b)-contaminated anti-D cohort at 35 years after infection. Hepatology. 2014 Jan;59(1):49–57. doi: 10.1002/hep.26644. PMID: 23929603.23929603
51 Kielland KB, Delaveris GJ, Rogde S, . Liver fibrosis progression at autopsy in injecting drug users infected by hepatitis C: a longitudinal long-term cohort study. J Hepatol. 2014 Feb;60(2):260–6. doi: 10.1016/j.jhep.2013.09.022. PMID: 24096048.24096048
52 Goldberg E, Chopra S, O’Donovan D. Vertical transmission of hepatitis C virus. 2018. https://www.uptodate.com/contents/vertical-transmission-of-hepatitis-c-virus. Accessed June 25, 2019.
53 Hagan H, Pouget ER, Des Jarlais DC, . Meta-regression of hepatitis C virus infection in relation to time since onset of illicit drug injection: the influence of time and place. Am J Epidemiol. 2008;168(10):1099–109. doi: 10.1093/aje/kwn237. PMID: 18849303.18849303
54 Alter H. Discovery of non-A, non-B hepatitis and identification of its etiology. Am J Med. 1999;107(6B):16S–20S. PMID: 10653450.10653450
55 Kaur S, Rybicki L, Bacon BR, . Performance characteristics and results of a large-scale screening program for viral hepatitis and risk factors associated with exposure to viral hepatitis B and C: results of the National Hepatitis Screening Survey. National Hepatitis Surveillance Group. Hepatology. 1996 Nov;24(5):979–86. doi: 10.1002/hep.510240501. PMID: 8903363.8903363
56 Yawn BP, Gazzuola L, Wollan PC, . Development and maintenance of a community-based hepatitis C registry. Am J Manage Care. 2002 Mar;8(3):253–61. PMID: 11915975.11915975
57 Alter MJ. Epidemiology of hepatitis C. Hepatology. 1997 Sep;26(3 Suppl 1):62s–5s. doi: 10.1002/hep.510260711. PMID: 9305666.9305666
58 Schreiber GB, Busch MP, Kleinman SH, . The risk of transfusion-transmitted viral infections. The Retrovirus Epidemiology Donor Study. N Engl J Med. 1996 Jun 27;334(26):1685–90. doi: 10.1056/nejm199606273342601. PMID: 8637512.8637512
59 Spradling PR, Rupp L, Moorman AC, . Hepatitis B and C virus infection among 1.2 million persons with access to care: factors associated with testing and infection prevalence. Clin Infect Dis. 2012 Oct;55(8):1047–55. doi: 10.1093/cid/cis616. PMID: 22875876.22875876
60 Denniston MM, Klevens RM, McQuillan GM, . Awareness of infection, knowledge of hepatitis C, and medical follow-up among individuals testing positive for hepatitis C: National Health and Nutrition Examination Survey 2001-2008. Hepatology. 2012 Jun;55(6):1652–61. doi: 10.1002/hep.25556. PMID: 22213025.22213025
61 White PJ, Abubakar I. Hepatitis C virus treatment as prevention in people who inject drugs. Lancet Infect Dis. 2018 Apr;18(4):379. doi: 10.1016/s1473-3099(18)30130-0. PMID: 29582763.29582763
62 The National Academies of Science Engineering and Medicine. A National Strategy for the Elimination of Hepatitis B and C: Phase Two Report; 2017.
63 Department of Health and Human Services USA. National Viral Hepatitis Action Plan 2017-2020. 2017. https://www.hhs.gov/sites/default/files/National%20Viral%20Hepatitis%20Action%20Plan%202017-2020.pdf. Accessed June 26, 2019.
64 Tran TT, Ahn J, Reau NS. ACG clinical guideline: liver disease and pregnancy. Am J Gastroenterol. 2016 Feb;111(2):176–94; quiz 96. doi: 10.1038/ajg.2015.430. PMID: 26832651.26832651
65 American Association for the Study of Liver Diseases, Infectious Diseases Society of America. HCV Guidance: Recommendations for Testing, Managing, and Treating Hepatitis C. HCV Testing and Linkage to Care. 2017. http://www.hcvguidelines.org/full-report/hcv-testing-and-linkage-care. Accessed June 25, 2019.
66 Swain M, Lai MY, Shiffman ML, . Durability of sustained virological response (SVR) after treatment with peginterferon alfa-2A (40KD) (PEGASYS) alone or in combination with ribavirin (COPEGUS): results of an ongoing long-term follow-up study. Hepatology. 2004;40(4 Suppl 1):400A–1A.
67 Swain MG, Lai MY, Shiffman ML, . A sustained virologic response is durable in patients with chronic hepatitis C treated with peginterferon alfa-2a and ribavirin. Gastroenterology. 2010 Nov. 2010;139(5):1593–601. doi: 10.1053/j.gastro.2010.07.009. PMID: 20637202.20637202
68 Pearlman BL, Traub N. Sustained virologic response to antiviral therapy for chronic hepatitis C virus infection: a cure and so much more. Clin Infect Dis. 2011 Apr 1;52(7):889–900. doi: 10.1093/cid/cir076. PMID: 21427396.21427396
69 Backus LI, Boothroyd DB, Phillips BR, . A sustained virologic response reduces risk of all-cause mortality in patients with hepatitis C. Clin Gastroenterol Hepatol. 2011;9:509–16. doi: 10.1016/j.cgh.2011.03.004. PMID: 21397729.21397729
70 Morgan TR, Ghany MG, Kim H-Y, . Outcome of sustained virological responders with histologically advanced chronic hepatitis C. Hepatology. 2010 Sep;52(3):833–44. PMID: 20564351.20564351
71 van der Meer AJ, Veldt BJ, Feld JJ, . Association between sustained virological response and all-cause mortality among patients with chronic hepatitis C and advanced hepatic fibrosis. JAMA. 2012 Dec 26;308(24):2584–93. doi: 10.1001/jama.2012.144878. PMID: 23268517.23268517
72 Kimer N, Dahl EK, Gluud LL, . Antiviral therapy for prevention of hepatocellular carcinoma in chronic hepatitis C: systematic review and meta-analysis of randomised controlled trials. BMJ Open. 2012;2(5):e001313. doi: 10.1136/bmjopen-2012-001313. PMID: 23089208.23089208
73 Falade-Nwulia O, Suarez-Cuervo C, Nelson DR, . Oral direct-acting agent therapy for hepatitis C virus infection: a systematic review. Ann Intern Med. 2017 May 02;166(9):637–48. doi: 10.7326/m16-2575. PMID: 28319996.28319996
74 American Association for the Study of Liver Diseases, Infectious Diseases Society of America. HCV Guidance: Recommendations for Testing, Managing, and Treating Hepatitis C. Initial Treatment of HCV Infection. 2017. https://www.hcvguidelines.org/treatment-naive. Accessed June 25, 2019.
75 Reau N. Pangenotypic regimens and the next generation hepatitis C virus therapy. Clin Liver Dis. 2017;9(6):131–3.
76 U.S. Food & Drug Administration. FDA approves two hepatitis C drugs for pediatric patients. 2017. https://www.fda.gov/news-events/press-announcements/fda-approves-two-hepatitis-c-drugs-pediatric-patients. Accessed June 25, 2019.
77 U.S. Food & Drug Administration. FDA approves first treatment for all genotypes of hepatitis C in pediatric patients. 2019. https://www.fda.gov/news-events/press-announcements/fda-approves-first-treatment-all-genotypes-hepatitis-c-pediatric-patients. Accessed June 24, 2019.
78 Arora S, Thornton K, Murata G, . Outcomes of treatment for hepatitis C virus infection by primary care providers. N Engl J Med. 2011 Jun 9;364(23):2199–207. doi: 10.1056/NEJMoa1009370. PMID: 21631316.21631316
79 Kattakuzhy S, Gross C, Emmanuel B, . Expansion of treatment for hepatitis C virus infection by task shifting to community-based nonspecialist providers: a nonrandomized clinical trial. Ann Intern Med. 2017 Sep 05;167(5):311–8. doi: 10.7326/M17-0118. PMID: 28785771.28785771
80 Chou R, Wasson N. Blood tests to diagnose fibrosis or cirrhosis in patients with chronic hepatitis C virus infection: a systematic review. Ann Intern Med. 2013 Jun 04;158(11):807–20. doi: 10.7326/0003-4819-158-11-201306040-00005. PMID: 23732714.23732714
81 Friedrich-Rust M, Ong MF, Martens S, . Performance of transient elastography for the staging of liver fibrosis: a meta-analysis. Gastroenterology. 2008 Apr;134(4):960–74. doi: 10.1053/j.gastro.2008.01.034. PMID: 18395077.18395077
82 Cartwright EJ, Rentsch C, Rimland D. Hepatitis C virus screening practices and seropositivity among US veterans born during 1945 - 1965. BMC Res Notes. 2014 Jul 14;7:449. doi: 10.1186/1756-0500-7-449. PMID: 25023159.25023159
83 EASL. EASL recommendations on treatment of hepatitis C 2018. 2018. https://easl.eu/publication/easl-recommendations-treatment-of-hepatitis-c/. Accessed June 25, 2019.
84 World Health Organization. Guidelines for the screening, care and treatment of persons with chronic hepatitis C infection. 2016. http://www.who.int/hepatitis/publications/hepatitis-c-guidelines-2016/en. Accessed June 25, 2019.
85 Canadian Task Force on Preventive Health Care. Hepatitis C (2017) Summary of recommendations for clinicians and policy-makers. 2017. https://canadiantaskforce.ca/guidelines/published-guidelines/hepatitis-c/. Accessed June 25, 2019.
86 Shah H, Bilodeau M, Burak KW, . The management of chronic hepatitis C: 2018 guideline update from the Canadian Association for the Study of the Liver. CMAJ. 2018 Jun 4;190(22):E677–E87. doi: 10.1503/cmaj.170453. PMID: 29866893.29866893
87 Centers for Disease Control and Prevention. Viral Hepatitis. Hepatitis C Information: Testing Recommendations for Hepatits C Virus Infection. Atlanta, GA: U.S. Department of Health & Human Services; 2015. https://www.cdc.gov/hepatitis/hcv/guidelinesc.htm. Accessed June 25, 2019.
88 The American Congress of Obstetricians and Gynecologists. Routine Tests During Pregnancy 2017. https://www.acog.org/Patients/FAQs/Routine-Tests-During-Pregnancy#why. Accessed June 25, 2019.
89 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD; 2016. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed June 25, 2019.
90 Chou R, Hartung D, Rahman B, . Treatment for Hepatitis C Virus Infection in Adults. Comparative Effectiveness Review no. 76. (Prepared by Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 12(13)-EHC113-EF. Rockville, MD: Agency for Healthcare Research and Quality. November 2012. https://effectivehealthcare.ahrq.gov/sites/default/files/pdf/hepatitis-c_research.pdf. Accessed June 25, 2019.
91 Chou R, Clark EC, Helfand M. Screening for hepatitis C virus infection: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(6):465–79. PMID: 15023713.15023713
92 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta‐analysis. Stat Med. 2002;21(11):1539–58.12111919
93 Miller JJ. The inverse of the Freeman–Tukey double arcsine transformation. Am Stat. 1978;32(4):138.
94 Gunn RA, Murray PJ, Brennan CH, . Evaluation of screening criteria to identify persons with hepatitis C virus infection among sexually transmitted disease clinic clients: results from the San Diego Viral Hepatitis Integration Project. Sex Transm Dis. 2003 Apr;30(4):340–4. PMID: 12671556.12671556
95 McGinn T, O’Connor-Moore N, Alfandre D, . Validation of a hepatitis C screening tool in primary care. Arch Intern Med. 2008 Oct 13;168(18):2009–13. doi: 10.1001/archinte.168.18.2009. PMID: 18852403.18852403
96 Nguyen MT, Herrine SK, Laine CA, . Description of a new hepatitis C risk assessment tool. Arch Intern Med. 2005 Sep 26;165(17):2013–8. doi: 10.1001/archinte.165.17.2013. PMID: 16186472.16186472
97 Zuniga IA, Chen JJ, Lane DS, . Analysis of a hepatitis C screening programme for US veterans. Epidemiol Infect. 2006 Apr;134(2):249–57. doi: 10.1017/s095026880500498x. PMID: 16490127.16490127
98 Zuure F, Davidovich U, Kok G, . Evaluation of a risk assessment questionnaire to assist hepatitis C screening in the general population. Euro Surveill. 2010 Apr 15;15(15):19539. PMID: 20429995.20429995
99 Tomaszewski KJ, Deniz B, Tomanovich P, . Comparison of current US risk strategy to screen for hepatitis C virus with a hypothetical targeted birth cohort strategy. Am J Public Health. 2012 Nov;102(11):e101–6. doi: 10.2105/AJPH.2011.300488. PMID: 22813094.22813094
100 Anderson EM, Mandeville RP, Hutchinson SJ, . Evaluation of a general practice based hepatitis C virus screening intervention. Scott Med J. 2009 Aug;54(3):3–7. doi: 10.1258/rsmsmj.54.3.3. PMID: 19728405.19728405
101 Coughlan B, Sheehan J, Carr A, . Evaluation of a brief group based psychological/educational treatment programme for women with an iatrogenic chronic hepatitis C virus infection. J Clin Psychol Med Settings. 2004;11(4):303–14.
102 Fabris P, Tositti G, Giordani MT, . Assessing patients’ understanding of hepatitis C virus infection and its impact on their lifestyle. Aliment Pharmacol Ther. 2006 Apr 15;23(8):1161–70. doi: 10.1111/j.1365-2036.2006.02882.x. PMID: 16611277.16611277
103 Trepka MJ, Zhang G, Leguen F, . Benefits and adverse effects of hepatitis C screening: early results of a screening program. J Public Health Manag Pract. 2007 May–Jun;13(3):263–9. doi: 10.1097/01.PHH.0000267684.23529.2c. PMID: 17435493.17435493
104 Mast EE, Hwang LY, Seto DS, . Risk factors for perinatal transmission of hepatitis C virus (HCV) and the natural history of HCV infection acquired in infancy. J Infect Dis. 2005 Dec 1;192(11):1880–9. doi: 10.1086/497701. PMID: 16267758.16267758
105 Gibb DM, Goodall RL, Dunn DT, . Mother-to-child transmission of hepatitis C virus: evidence for preventable peripartum transmission. Lancet. 2000 Sep 9;356(9233):904–7. PMID: 11036896.11036896
106 Tovo PA, European Paediatric Hepatitis C Virus Network. A significant sex-but not elective cesarean section-effect on mother-to-child transmission of hepatitis C virus infection. J Infect Dis. 2005 Dec 1;192(11):1872–9. doi: 10.1086/497695. PMID: 16267757.16267757
107 Resti M, Azzari C, Galli L, . Maternal drug use is a preeminent risk factor for mother-to-child hepatitis C virus transmission: results from a multicenter study of 1372 mother-infant pairs. J Infect Dis. 2002 Mar 1;185(5):567–72. doi: 10.1086/339013. PMID: 11865412.11865412
108 Ceci O, Margiotta M, Marello F, . Vertical transmission of hepatitis C virus in a cohort of 2,447 HIV-seronegative pregnant women: a 24-month prospective study. J Pediatr Gastroenterol Nutr. 2001 Nov;33(5):570–5. PMID: 11740231.11740231
109 Conte D, Fraquelli M, Prati D, . Prevalence and clinical course of chronic hepatitis C virus (HCV) infection and rate of HCV vertical transmission in a cohort of 15,250 pregnant women. Hepatology. 2000 Mar;31(3):751–5. doi: 10.1002/hep.510310328. PMID: 10706568.10706568
110 Garland SM, Tabrizi S, Robinson P, . Hepatitis C-role of perinatal transmission. Aust N Z J Obstet Gynaecol. 1998 Nov;38(4):424–7. PMID: 9890224.9890224
111 La Torre A, Biadaioli R, Capobianco T, . Vertical transmission of HCV. Acta Obstet Gynecol Scand. 1998 Oct;77(9):889–92. PMID: 9808375.9808375
112 McMenamin MB, Jackson AD, Lambert J, . Obstetric management of hepatitis C-positive mothers: analysis of vertical transmission in 559 mother-infant pairs. Am J Obstet Gynecol. 2008 Sep;199(3):315.e1–5. doi: 10.1016/j.ajog.2008.05.021. PMID: 18771997.18771997
113 Okamoto M, Nagata I, Murakami J, . Prospective reevaluation of risk factors in mother-to-child transmission of hepatitis C virus: high virus load, vaginal delivery, and negative anti-NS4 antibody. J Infect Dis. 2000 Nov;182(5):1511–4. doi: 10.1086/315883. PMID: 11023474.11023474
114 Pembrey L, European Paediatric Hepatitis C Virus Network. Effects of mode of delivery and infant feeding on the risk of mother-to-child transmission of hepatitis C virus. European Paediatric Hepatitis C Virus Network. BJOG. 2001 Apr;108(4):371–7. PMID: 11305543.11305543
115 Resti M, Azzari C, Mannelli F, . Mother to child transmission of hepatitis C virus: prospective study of risk factors and timing of infection in children born to women seronegative for HIV-1. Tuscany Study Group on hepatitis C virus infection. BMJ. 1998 Aug 15;317(7156):437–41. PMID: 9703524.9703524
116 Spencer JD, Latt N, Beeby PJ, . Transmission of hepatitis C virus to infants of human immunodeficiency virus-negative intravenous drug-using mothers: rate of infection and assessment of risk factors for transmission. J Viral Hepat. 1997;4(6):395–409. PMID: 9430360.9430360
117 Syriopoulou V, Nikolopoulou G, Daikos GL, . Mother to child transmission of hepatitis C virus: rate of infection and risk factors. Scand J Infect Dis. 2005;37(5):350–3. doi: 10.1080/00365540510032105. PMID: 16051571.16051571
118 Tajiri H, Miyoshi Y, Funada S, . Prospective study of mother-to-infant transmission of hepatitis C virus. Pediatr Infect Dis J. 2001 Jan;20(1):10–4. PMID: 11176560.11176560
119 Zanetti AR, Tanzi E, Newell ML. Mother-to-infant transmission of hepatitis C virus. J Hepatol. 1999;31: Suppl 1:96–100. PMID: 10622569.10622569
120 Zanetti AR, Tanzi E, Romano L, . A prospective study on mother-to-infant transmission of hepatitis C virus. Intervirology. 1998;41(4–5):208–12. doi: 10.1159/000024938. PMID: 10213898.10213898
121 Lin HH, Kao JH, Hsu HY, . Absence of infection in breast-fed infants born to hepatitis C virus-infected mothers. J Pediatr. 1995 Apr;126(4):589–91. PMID: 7535353.7535353
122 Moriya T, Sasaki F, Mizui M, . Transmission of hepatitis C virus from mothers to infants: its frequency and risk factors revisited. Biomed Pharmacother. 1995;49(2):59–64. PMID: 7605903.7605903
123 Pipan C, Amici S, Astori G, . Vertical transmission of hepatitis C virus in low-risk pregnant women. Eur J Clin Microbiol Infect Dis. 1996 Feb;15(2):116–20. PMID: 8801082.8801082
124 Tanzi M, Bellelli E, Benaglia G, . The prevalence of HCV infection in a cohort of pregnant women, the related risk factors and the possibility of vertical transmission. Eur J Epidemiol. 1997 Jul;13(5):517–21. PMID: 9258562.9258562
125 Jacobson IM, McHutchison JG, Dusheiko G, . Telaprevir for previously untreated chronic hepatitis C virus infection. N Engl J Med. 2011 Jun 23;364(25):2405–16. doi: 10.1056/NEJMoa1012912. PMID: 21696307.21696307
126 Poordad F, McCone J, Jr., Bacon BR, . Boceprevir for untreated chronic HCV genotype 1 infection. N Engl J Med. 2011 Mar 31;364(13):1195–206. doi: 10.1056/NEJMoa1010494. PMID: 21449783.21449783
127 Azzaroli F, Accogli E, Nigro G, . Interferon plus ribavirin and interferon alone in preventing hepatocellular carcinoma: a prospective study on patients with HCV related cirrhosis. World J Gastroenterol. 2004 Nov 1;10(21):3099–102. PMID: 15457551.15457551
128 Bernardinello E, Cavalletto L, Chemello L, . Long-term clinical outcome after beta-interferon therapy in cirrhotic patients with chronic hepatitis C. TVVH Study Group. Hepatogastroenterology. 1999 Nov–Dec;46(30):3216–22. PMID: 10626189.10626189
129 Bruix J, Poynard T, Colombo M, . Maintenance therapy with peginterferon alfa-2b does not prevent hepatocellular carcinoma in cirrhotic patients with chronic hepatitis C. Gastroenterology. 2011 Jun;140(7):1990–9. doi: 10.1053/j.gastro.2011.03.010. PMID: 21419770.21419770
130 Fartoux L, Degos F, Trepo C, . Effect of prolonged interferon therapy on the outcome of hepatitis C virus-related cirrhosis: a randomized trial. Clin Gastroenterol Hepatol. 2007 Apr;5(4):502–7. doi: 10.1016/j.cgh.2006.10.016. PMID: 17261383.17261383
131 Nishiguchi S, Shiomi S, Nakatani S, . Prevention of hepatocellular carcinoma in patients with chronic active hepatitis C and cirrhosis. Lancet. 2001 Jan 20;357(9251):196–7. doi: 10.1016/s0140-6736(00)03595-9. PMID: 11213099.11213099
132 Valla DC, Chevallier M, Marcellin P, . Treatment of hepatitis C virus-related cirrhosis: a randomized, controlled trial of interferon alfa-2b versus no treatment. Hepatology. 1999 Jun;29(6):1870–5. doi: 10.1002/hep.510290616. PMID: 10347132.10347132
133 Lok AS, Everhart JE, Wright EC, . Maintenance peginterferon therapy and other factors associated with hepatocellular carcinoma in patients with advanced hepatitis C. Gastroenterology. 2011 Mar;140(3):840–9; quiz e12. doi: 10.1053/j.gastro.2010.11.050. PMID: 21129375.21129375
134 Soga K, Shibasaki K, Aoyagi Y. Effect of interferon on incidence of hepatocellular carcinoma in patients with chronic hepatitis C. Hepatogastroenterology. 2005 Jul–Aug;52(64):1154–8. PMID: 16001651.16001651
135 Younossi ZM, Stepanova M, Afdhal N, . Improvement of health-related quality of life and work productivity in chronic hepatitis C patients with early and advanced fibrosis treated with ledipasvir and sofosbuvir. J Hepatol. 2015 Aug;63(2):337–45. doi: 10.1016/j.jhep.2015.03.014. PMID: 25795586.25795586
136 Younossi ZM, Stepanova M, Feld J, . Sofosbuvir and velpatasvir combination improves patient-reported outcomes for patients with HCV infection, without or with compensated or decompensated cirrhosis. Clin Gastroenterol Hepatol. 2017 Mar;15(3):421–30.e6. doi: 10.1016/j.cgh.2016.10.037. PMID: 27847279.27847279
137 Dore GJ, Conway B, Luo Y, . Efficacy and safety of ombitasvir/paritaprevir/r and dasabuvir compared to IFN-containing regimens in genotype 1 HCV patients: the MALACHITE-I/II trials. J Hepatol. 2016 Jan;64(1):19–28. doi: 10.1016/j.jhep.2015.08.015. PMID: 26321288.26321288
138 Ng X, Nwankwo C, Arduino JM, . Patient-reported outcomes in individuals with hepatitis C virus infection treated with elbasvir/grazoprevir. Patient Prefer Adherence. 2018;12:2631–8. doi: 10.2147/PPA.S172732. PMID: 30587935.30587935
139 Feld JJ, Jacobson IM, Hezode C, . Sofosbuvir and velpatasvir for HCV genotype 1, 2, 4, 5, and 6 infection. N Engl J Med. 2015 Dec 31;373(27):2599–607. doi: 10.1056/NEJMoa1512610. PMID: 26571066.26571066
140 Younossi ZM, Stepanova M, Feld J, . Sofosbuvir/velpatasvir improves patient-reported outcomes in HCV patients: results from ASTRAL-1 placebo-controlled trial. J Hepatol. 2016;65(1):33–9. doi: 10.1016/j.jhep.2016.02.042. PMID: 26956698.26956698
141 Abergel A, Asselah T, Metivier S, . Ledipasvir-sofosbuvir in patients with hepatitis C virus genotype 5 infection: an open-label, multicentre, single-arm, phase 2 study. Lancet Infect Dis. 2016b Apr;16(4):459–64. doi: 10.1016/S1473-3099(15)00529-0. PMID: 26803446.26803446
142 Abergel A, Metivier S, Samuel D, . Ledipasvir plus sofosbuvir for 12 weeks in patients with hepatitis C genotype 4 infection. Hepatology. 2016a Oct;64(4):1049–56. doi: 10.1002/hep.28706. PMID: 27351341.27351341
143 Asselah T, Lee SS, Yao BB, . Efficacy and safety of glecaprevir/pibrentasvir in patients with chronic hepatitis C virus genotype 5 or 6 infection (ENDURANCE-5,6): an open-label, multicentre, phase 3b trial. Lancet Gastroenterol Hepatol. 2019 Jan;4(1):45–51. doi: 10.1016/S2468-1253(18)30341-8. PMID: 30393106.30393106
144 Brown A, Hezode C, Zuckerman E, . Efficacy and safety of 12 weeks of elbasvir +/- grazoprevir +/- ribavirin in participants with hepatitis C virus genotype 2, 4, 5 or 6 infection: the C-SCAPE study. J Viral Hepat. 2018 05;25(5):457–64. doi: 10.1111/jvh.12801. PMID: 29152828.29152828
145 Chuang WL, Chien RN, Peng CY, . Ledipasvir/sofosbuvir fixed-dose combination tablet in Taiwanese patients with chronic genotype 1 hepatitis C virus. J Gastroenterol Hepatol. 2016;31(7):1323–9. PMID: 26841930.26841930
146 Everson GT, Towner WJ, Davis MN, . Sofosbuvir with velpatasvir in treatment-naive noncirrhotic patients with genotype 1 to 6 hepatitis C virus infection: A randomized trial. Ann Intern Med. 2015 Dec 01;163(11):818–26. doi: 10.7326/M15-1000. PMID: 26551051.26551051
147 Foster GR, Afdhal N, Roberts SK, . Sofosbuvir and velpatasvir for HCV genotype 2 and 3 infection. N Engl J Med. 2015 Dec 31;373(27):2608–17. doi: 10.1056/NEJMoa1512612. PMID: 26575258.26575258
148 Gane EJ, Hyland RH, An D, . Efficacy of ledipasvir and sofosbuvir, with or without ribavirin, for 12 weeks in patients with HCV genotype 3 or 6 infection. Gastroenterology. 2015 Nov;149(6):1454–61.e1. doi: 10.1053/j.gastro.2015.07.063. PMID: 26261007.26261007
149 Grebely J, Conway B, Cunningham EB, . Paritaprevir, ritonavir, ombitasvir, and dasabuvir with and without ribavirin in people with HCV genotype 1 and recent injecting drug use or receiving opioid substitution therapy. Int J Drug Policy. 2018b Dec;62:94–103. doi: 10.1016/j.drugpo.2018.10.004. PMID: 30384028.30384028
150 Grebely J, Dalgard O, Conway B, . Sofosbuvir and velpatasvir for hepatitis C virus infection in people with recent injection drug use (SIMPLIFY): an open-label, single-arm, phase 4, multicentre trial. Lancet Gastroenterol Hepatol. 2018a 03;3(3):153–61. doi: 10.1016/S2468-1253(17)30404-1. PMID: 29310928.29310928
151 Kumada H, Chayama K, Rodrigues L, Jr., . Randomized phase 3 trial of ombitasvir/paritaprevir/ritonavir for hepatitis C virus genotype 1b-infected Japanese patients with or without cirrhosis. Hepatology. 2015 Oct;62(4):1037–46. doi: 10.1002/hep.27972. PMID: 26147154.26147154
152 Kumada H, Suzuki Y, Karino Y, . The combination of elbasvir and grazoprevir for the treatment of chronic HCV infection in Japanese patients: a randomized phase II/III study. J Gastroenterol. 2017 Apr;52(4):520–33. doi: 10.1007/s00535-016-1285-y. PMID: 27873094.27873094
153 Kwo P, Gitlin N, Nahass R, . Simeprevir plus sofosbuvir (12 and 8 weeks) in hepatitis C virus genotype 1-infected patients without cirrhosis: OPTIMIST-1, a phase 3, randomized study. Hepatology. 2016 Aug;64(2):370–80. doi: 10.1002/hep.28467. PMID: 26799692.26799692
154 Lawitz E, Sulkowski MS, Ghalib R, . Simeprevir plus sofosbuvir, with or without ribavirin, to treat chronic infection with hepatitis C virus genotype 1 in non-responders to pegylated interferon and ribavirin and treatment-naive patients: the COSMOS randomised study. Lancet. 2014a Nov 15;384(9956):1756–65. doi: 10.1016/S0140-6736(14)61036-9. PMID: 25078309.25078309
155 Lawitz E, Makara M, Akarca US, . Efficacy and safety of ombitasvir, paritaprevir, and ritonavir in an open-label study of patients with genotype 1b chronic hepatitis C virus infection with and without cirrhosis. Gastroenterology. 2015 Oct;149(4):971–80.e1. doi: 10.1053/j.gastro.2015.07.001. PMID: 26170136.26170136
156 Lim YS, Ahn SH, Lee KS, . A phase IIIb study of ledipasvir/sofosbuvir fixed-dose combination tablet in treatment-naive and treatment-experienced Korean patients chronically infected with genotype 1 hepatitis C virus. Hepatol Int. 2016;10(6):947–55. PMID: 27198664.27198664
157 Nelson DR, Cooper JN, Lalezari JP, . All-oral 12-week treatment with daclatasvir plus sofosbuvir in patients with hepatitis C virus genotype 3 infection: ALLY-3 phase III study. Hepatology. 2015 Apr;61(4):1127–35. doi: 10.1002/hep.27726. PMID: 25614962.25614962
158 Pianko S, Flamm SL, Shiffman ML, . Sofosbuvir plus velpatasvir combination therapy for treatment-experienced patients with genotype 1 or 3 hepatitis C virus infection: a randomized trial. Ann Intern Med. 2015 Dec 01;163(11):809–17. doi: 10.7326/M15-1014. PMID: 26551263.26551263
159 Pott-Junior H, Bricks G, Grandi G, . Sofosbuvir in combination with daclatasvir or simeprevir for 12 weeks in noncirrhotic subjects chronically infected with hepatitis C virus genotype 1: a randomized clinical trial. Clin Microbiol Infect. 2019 Jun 12;25(3):365–71. doi: 10.1016/j.cmi.2018.06.007. PMID: 29906601.29906601
160 Sulkowski M, Hezode C, Gerstoft J, . Efficacy and safety of 8 weeks versus 12 weeks of treatment with grazoprevir (MK-5172) and elbasvir (MK-8742) with or without ribavirin in patients with hepatitis C virus genotype 1 mono-infection and HIV/hepatitis C virus co-infection (C-WORTHY): a randomised, open-label phase 2 trial. Lancet. 2015 Mar 21;385(9973):1087–97. doi: 10.1016/s0140-6736(14)61793-1. PMID: 25467560.25467560
161 Sulkowski MS, Gardiner DF, Rodriguez-Torres M, . Daclatasvir plus sofosbuvir for previously treated or untreated chronic HCV infection. N Engl J Med. 2014 Jan 16;370(3):211–21. doi: 10.1056/NEJMoa1306218. PMID: 24428467.24428467
162 Waked I, Shiha G, Qaqish RB, . Ombitasvir, paritaprevir, and ritonavir plus ribavirin for chronic hepatitis C virus genotype 4 infection in Egyptian patients with or without compensated cirrhosis (AGATE-II): a multicentre, phase 3, partly randomised open-label trial. Lancet Gastroenterol Hepatol. 2016;1(1):36–44. PMID: 28404110.28404110
163 Wei L, Xie Q, Hou JL, . Ledipasvir/sofosbuvir for treatment-naive and treatment-experienced Chinese patients with genotype 1 HCV: an open-label, phase 3b study. Hepatol Int. 2018 Mar;12(2):126–32. doi: 10.1007/s12072-018-9856-z. PMID: 29637511.29637511
164 Wei L, Jia JD, Wang FS, . Efficacy and safety of elbasvir/grazoprevir in participants with hepatitis C virus genotype 1, 4, or 6 infection from the Asia-Pacific region and Russia: final results from the randomized C-CORAL study. J Gastroenterol Hepatol. 2019a Jan;34(1):12–21. doi: 10.1111/jgh.14509. PMID: 30311701.30311701
165 Wei L, Lim SG, Xie Q, . Sofosbuvir-velpatasvir for treatment of chronic hepatitis C virus infection in Asia: a single-arm, open-label, phase 3 trial. Lancet Gastroenterol Hepatol. 2019b Feb;4(2):127–34. doi: 10.1016/S2468-1253(18)30343-1. PMID: 30555048.30555048
166 Zeuzem S, Ghalib R, Reddy KR, . Grazoprevir-elbasvir combination therapy for treatment-naive cirrhotic and noncirrhotic patients with chronic hepatitis C virus genotype 1, 4, or 6 infection: a randomized trial. Ann Intern Med. 2015 Jul 07;163(1):1–13. doi: 10.7326/M15-0785. PMID: 25909356.25909356
167 Zeuzem S, Foster GR, Wang S, . Glecaprevir-pibrentasvir for 8 or 12 weeks in HCV genotype 1 or 3 infection. N Engl J Med. 2018 01 25;378(4):354–69. doi: 10.1056/NEJMoa1702417. PMID: 29365309.29365309
168 Carrat F, Fontaine H, Dorival C, . Clinical outcomes in patients with chronic hepatitis C after direct-acting antiviral treatment: a prospective cohort study. Lancet. 2019 Feb 11doi: 10.1016/s0140-6736(18)32111-1. PMID: 30765123.30765123
169 Butt AA, Yan P, Shuaib A, . Direct-acting antiviral therapy for HCV Infection is associated with a reduced risk of cardiovascular disease events. Gastroenterology. 2019 Nov 13;156(4):987–96. doi: 10.1053/j.gastro.2018.11.022. PMID: 30445009.30445009
170 Li DK, Ren Y, Fierer DS, . The short-term incidence of hepatocellular carcinoma is not increased after hepatitis C treatment with direct-acting antivirals: an ERCHIVES study. Hepatology. 2018 Jun;67(6):2244–53. doi: 10.1002/hep.29707. PMID: 29205416.29205416
171 Jonas MM, Squires RH, Rhee SM, . Pharmacokinetics, safety, and efficacy of glecaprevir/pibrentasvir in adolescents with chronic HCV: part 1 of the DORA study. Hepatology. 2019 Jun 29doi: 10.1002/hep.30840. PMID: 31254392.31254392
172 Younossi ZM, Stepanova M, Balistreri W, . Health-related quality of life in adolescent patients with hepatitis C genotype 1 treated with sofosbuvir and ledipasvir. J Pediatr Gastroenterol Nutr. 2018 Jan;66(1):112–6. doi: 10.1097/MPG.0000000000001754. PMID: 28957984.28957984
173 Wirth S, Rosenthal P, Gonzalez-Peralta RP, . Sofosbuvir and ribavirin in adolescents 12-17 years old with hepatitis C virus genotype 2 or 3 infection. Hepatology. 2017 Oct;66(4):1102–10. doi: 10.1002/hep.29278. PMID: 28543053.28543053
174 Younossi ZM, Stepanova M, Schwarz KB, . Quality of life in adolescents with hepatitis C treated with sofosbuvir and ribavirin. J Viral Hepat. 2018 Apr;25(4):354–62. doi: 10.1111/jvh.12830. PMID: 29193603.29193603
175 Balistreri WF, Murray KF, Rosenthal P, . The safety and effectiveness of ledipasvir-sofosbuvir in adolescents 12-17 years old with hepatitis C virus genotype 1 infection. Hepatology. 2017 Aug;66(2):371–8. doi: 10.1002/hep.28995. PMID: 27997679.27997679
176 Yakoot M, El-Shabrawi MH, AbdElgawad MM, . Dual sofosbuvir/daclatasvir therapy in adolescent patients with chronic hepatitis C infection. J Pediatr Gastroenterol Nutr. 2018 Jul;67(1):86–9. doi: 10.1097/mpg.0000000000001968. PMID: 29570560.29570560
177 Kwo PY, Lawitz EJ, McCone J, . Efficacy of boceprevir, an NS3 protease inhibitor, in combination with peginterferon alfa-2b and ribavirin in treatment-naive patients with genotype 1 hepatitis C infection (SPRINT-1): an open-label, randomised, multicentre phase 2 trial. Lancet. 2010 Aug 28;376(9742):705–16. doi: 10.1016/s0140-6736(10)60934-8. PMID: 20692693.20692693
178 Hezode C, Forestier N, Dusheiko G, . Telaprevir and peginterferon with or without ribavirin for chronic HCV infection. N Engl J Med. 2009 Apr 30;360(18):1839–50. doi: 10.1056/NEJMoa0807650. PMID: 19403903.19403903
179 Kumada H, Toyota J, Okanoue T, . Telaprevir with peginterferon and ribavirin for treatment-naive patients chronically infected with HCV of genotype 1 in Japan. J Hepatol. 2012 Jan;56(1):78–84. doi: 10.1016/j.jhep.2011.07.016. PMID: 21827730.21827730
180 McHutchison JG, Everson GT, Gordon SC, . Telaprevir with peginterferon and ribavirin for chronic HCV genotype 1 infection. N Engl J Med. 2009 Apr 30;360(18):1827–38. doi: 10.1056/NEJMoa0806104. PMID: 19403902.19403902
181 Lagging M, Langeland N, Pedersen C, . Randomized comparison of 12 or 24 weeks of peginterferon alpha-2a and ribavirin in chronic hepatitis C virus genotype 2/3 infection. Hepatology. 2008 Jun;47(6):1837–45. doi: 10.1002/hep.22253. PMID: 18454508.18454508
182 Manns M, Zeuzem S, Sood A, . Reduced dose and duration of peginterferon alfa-2b and weight-based ribavirin in patients with genotype 2 and 3 chronic hepatitis C. J Hepatol. 2011 Sep;55(3):554–63. doi: 10.1016/j.jhep.2010.12.024. PMID: 21237227.21237227
183 Shiffman ML, Suter F, Bacon BR, . Peginterferon alfa-2a and ribavirin for 16 or 24 weeks in HCV genotype 2 or 3. N Engl J Med. 2007 Jul 12;357(2):124–34. doi: 10.1056/NEJMoa066403. PMID: 17625124.17625124
184 Yu ML, Dai CY, Huang JF, . A randomised study of peginterferon and ribavirin for 16 versus 24 weeks in patients with genotype 2 chronic hepatitis C. Gut. 2007 Apr;56(4):553–9. doi: 10.1136/gut.2006.102558. PMID: 16956917.16956917
185 Afdhal N, Zeuzem S, Kwo P, . Ledipasvir and sofosbuvir for untreated HCV genotype 1 infection. N Engl J Med. 2014 May 15;370(20):1889–98. doi: 10.1056/NEJMoa1402454. PMID: 24725239.24725239
186 Andreone P, Colombo MG, Enejosa JV, . ABT-450, ritonavir, ombitasvir, and dasabuvir achieves 97% and 100% sustained virologic response with or without ribavirin in treatment-experienced patients with HCV genotype 1b infection. Gastroenterology. 2014 Aug;147(2):359–65.e1. doi: 10.1053/j.gastro.2014.04.045. PMID: 24818763.24818763
187 Feld JJ, Kowdley KV, Coakley E, . Treatment of HCV with ABT-450/r-ombitasvir and dasabuvir with ribavirin. N Engl J Med. 2014 Apr 24;370(17):1594–603. doi: 10.1056/NEJMoa1315722. PMID: 24720703.24720703
188 Ferenci P, Bernstein D, Lalezari J, . ABT-450/r-ombitasvir and dasabuvir with or without ribavirin for HCV. N Engl J Med. 2014 May 22;370(21):1983–92. doi: 10.1056/NEJMoa1402338. PMID: 24795200.24795200
189 Hezode C, Asselah T, Reddy KR, . Ombitasvir plus paritaprevir plus ritonavir with or without ribavirin in treatment-naive and treatment-experienced patients with genotype 4 chronic hepatitis C virus infection (PEARL-I): a randomised, open-label trial. Lancet. 2015 Jun 20;385(9986):2502–9. doi: 10.1016/S0140-6736(15)60159-3. PMID: 25837829.25837829
190 Kowdley KV, Gordon SC, Reddy KR, . Ledipasvir and sofosbuvir for 8 or 12 weeks for chronic HCV without cirrhosis. N Engl J Med. 2014a May 15;370(20):1879–88. doi: 10.1056/NEJMoa1402355. PMID: 24720702.24720702
191 Kowdley KV, Lawitz E, Poordad F, . Phase 2b trial of interferon-free therapy for hepatitis C virus genotype 1. N Engl J Med. 2014b Jan 16;370(3):222–32. doi: 10.1056/NEJMoa1306227. PMID: 24428468.24428468
192 Lalezari J, Sullivan JG, Varunok P, . Ombitasvir/paritaprevir/r and dasabuvir plus ribavirin in HCV genotype 1-infected patients on methadone or buprenorphine. J Hepatol. 2015 Aug;63(2):364–9. doi: 10.1016/j.jhep.2015.03.029. PMID: 25839406.25839406
193 Lawitz E, Poordad FF, Pang PS, . Sofosbuvir and ledipasvir fixed-dose combination with and without ribavirin in treatment-naive and previously treated patients with genotype 1 hepatitis C virus infection (LONESTAR): an open-label, randomised, phase 2 trial. Lancet. 2014b Feb 08;383(9916):515–23. doi: 10.1016/S0140-6736(13)62121-2. PMID: 24209977.24209977
194 Poordad F, Felizarta F, Asatryan A, . Glecaprevir and pibrentasvir for 12 weeks for hepatitis C virus genotype 1 infection and prior direct-acting antiviral treatment. Hepatology. 2017 Aug;66(2):389–97. doi: 10.1002/hep.29081. PMID: 28128852.28128852
195 Ahmed OA, Kaisar HH, Badawi R, . Efficacy and safety of sofosbuvir-ledipasvir for treatment of a cohort of Egyptian patients with chronic hepatitis C genotype 4 infection. Infect Drug Resist. 2018;11:295–8. doi: 10.2147/IDR.S153060. PMID: 29535545.29535545
196 Asselah T, Kowdley KV, Zadeikis N, . Efficacy of glecaprevir/pibrentasvir for 8 or 12 weeks in patients with hepatitis C virus genotype 2, 4, 5, or 6 infection without cirrhosis. Clin Gastroenterol Hepatol. 2018 Mar;16(3):417–26. doi: 10.1016/j.cgh.2017.09.027. PMID: 28951228.28951228
197 Chayama K, Suzuki F, Karino Y, . Efficacy and safety of glecaprevir/pibrentasvir in Japanese patients with chronic genotype 1 hepatitis C virus infection with and without cirrhosis. J Gastroenterol. 2018:557–65. PMID: 28948366.28948366
198 Sperl J, Horvath G, Halota W, . Efficacy and safety of elbasvir/grazoprevir and sofosbuvir/pegylated interferon/ribavirin: a phase III randomized controlled trial. J Hepatol. 2016;65 PMID: 27542322.27542322
199 Toyoda H, Chayama K, Suzuki F, . Efficacy and safety of glecaprevir/pibrentasvir in Japanese patients with chronic genotype 2 hepatitis C virus infection. Hepatology. 2018;67(2):505–13. PMID: 28865152.28865152
200 Effect of interferon-alpha on progression of cirrhosis to hepatocellular carcinoma: a retrospective cohort study. International Interferon-alpha Hepatocellular Carcinoma Study Group. Lancet. 1998 May 23;351(9115):1535–9. PMID: 10326535.10326535
201 Abdel Ghaffar TY, Naghi SE, Gawad MA, . Safety and efficacy of combined sofosbuvir/daclatasvir treatment of children and adolescents with chronic hepatitis C genotype 4. J Viral Hepat. 2019 Oct 31;26(2):263–70. doi: 10.1111/jvh.13032. PMID: 30380158.30380158
202 El-Karaksy H, Mogahed EA, Abdullatif H, . Sustained viral response in genotype 4 chronic hepatitis C virus-infected children and adolescents treated with sofosbuvir/ledipasvir. J Pediatr Gastroenterol Nutr. 2018 Nov;67(5):626–30. doi: 10.1097/mpg.0000000000002101. PMID: 30216203.30216203
203 Leung DH, Wirth S, Yao BB, . Ombitasvir/paritaprevir/ritonavir with or without dasabuvir and with or without ribavirin for adolescents with HCV genotype 1 or 4. Hepatol Commun. 2018 Nov;2(11):1311–9. doi: 10.1002/hep4.1250. PMID: 30411078.30411078
204 Arase Y, Ikeda K, Suzuki F, . Long-term outcome after interferon therapy in elderly patients with chronic hepatitis C. Intervirology. 2007;50(1):16–23. doi: 10.1159/000096308. PMID: 17164553.17164553
205 Butt AA, Yan P, Simon TG, . Effect of paritaprevir/ritonavir/ombitasvir/dasabuvir and ledipasvir/sofosbuvir regimens on survival compared with untreated hepatitis C virus-infected persons: results from ERCHIVES. Clin Infect Dis. 2017 Sep 15;65(6):1006–11. doi: 10.1093/cid/cix364. PMID: 28903508.28903508
206 Cozen ML, Ryan JC, Shen H, . Nonresponse to interferon-alpha based treatment for chronic hepatitis C infection is associated with increased hazard of cirrhosis. PLoS One. 2013;8(4):e61568. doi: 10.1371/journal.pone.0061568. PMID: 23637856.23637856
207 Dieperink E, Pocha C, Thuras P, . All-cause mortality and liver-related outcomes following successful antiviral treatment for chronic hepatitis C. Dig Dis Sci. 2014 Apr;59(4):872–80. doi: 10.1007/s10620-014-3050-5. PMID: 24532254.24532254
208 Imazeki F, Yokosuka O, Fukai K, . Favorable prognosis of chronic hepatitis C after interferon therapy by long-term cohort study. Hepatology. 2003 Aug;38(2):493–502. doi: 10.1053/jhep.2003.50329. PMID: 12883494.12883494
209 Innes HA, Hutchinson SJ, Allen S, . Excess liver-related morbidity of chronic hepatitis C patients, who achieve a sustained viral response, and are discharged from care. Hepatology. 2011 Nov;54(5):1547–58. doi: 10.1002/hep.24561. PMID: 22045672.22045672
210 Kasahara A, Tanaka H, Okanoue T, . Interferon treatment improves survival in chronic hepatitis C patients showing biochemical as well as virological responses by preventing liver-related death. J Viral Hepat. 2004 Mar;11(2):148–56. PMID: 14996350.14996350
211 Maruoka D, Imazeki F, Arai M, . Long-term cohort study of chronic hepatitis C according to interferon efficacy. J Gastroenterol Hepatol. 2012 Feb;27(2):291–9. doi: 10.1111/j.1440-1746.2011.06871.x. PMID: 21793911.21793911
212 Singal AG, Dharia TD, Malet PF, . Long-term benefit of hepatitis C therapy in a safety net hospital system: a cross-sectional study with median 5-year follow-up. BMJ Open. 2013 Sep 3;3(9):e003231. doi: 10.1136/bmjopen-2013-003231. PMID: 24002983.24002983
213 Yoshida H, Arakawa Y, Sata M, . Interferon therapy prolonged life expectancy among chronic hepatitis C patients. Gastroenterology. 2002 Aug;123(2):483–91. PMID: 12145802.12145802
214 Yu M, Lin S-M, Chuang W-L, . A sustained virological response to interferon or interferon/ribavirin reduces hepatocellular carcinoma and improves survival in chronic hepatitis C: a nationwide, multicentre study in Taiwan. Antivir Ther. 2006;11(8):985–94. PMID: 17302368.17302368
215 El-Serag HB, Kramer J, Duan Z, . Racial differences in the progression to cirrhosis and hepatocellular carcinoma in HCV-infected veterans. Am J Gastroenterol. 2014 Sep;109(9):1427–35. doi: 10.1038/ajg.2014.214. PMID: 25070058.25070058
216 Tseng CW, Chang TT, Tzeng SJ, . Association of sustained virologic response with reduced progression to liver cirrhosis in elderly patients with chronic hepatitis C. Clin Interv Aging. 2016;11:327–34. doi: 10.2147/CIA.S97242. PMID: 27051280.27051280
217 Asahina Y, Tsuchiya K, Tamaki N, . Effect of aging on risk for hepatocellular carcinoma in chronic hepatitis C virus infection. Hepatology. 2010 Aug;52(2):518–27. doi: 10.1002/hep.23691. PMID: 20683951.20683951
218 Dohmen K, Kawano A, Takahashi K, . The incidence and risk factors for the development of hepatocellular carcinoma after peginterferon plus ribavirin therapy for chronic hepatitis C. Hepatogastroenterology. 2013 Nov–Dec;60(128):2034–8. PMID: 24719946.24719946
219 Ikeda K, Saitoh S, Arase Y, . Effect of interferon therapy on hepatocellular carcinogenesis in patients with chronic hepatitis type C: A long-term observation study of 1,643 patients using statistical bias correction with proportional hazard analysis. Hepatology. 1999 Apr;29(4):1124–30. doi: 10.1002/hep.510290439. PMID: 10094956.10094956
220 Imai Y, Kawata S, Tamura S, . Relation of interferon therapy and hepatocellular carcinoma in patients with chronic hepatitis C. Osaka hepatocellular carcinoma prevention study group. Ann Intern Med. 1998 Jul 15;129(2):94–9. PMID: 9669992.9669992
221 Ioannou GN, Green PK, Berry K. HCV eradication induced by direct-acting antiviral agents reduces the risk of hepatocellular carcinoma. J Hepatol. 2018 Sep 5;68(1):25–32. doi: 10.1016/j.jhep.2017.08.030. PMID: 28887168.28887168
222 Izumi N, Yasuhiro A, Kurosaki M, . Development of hepatocellular carcinoma after interferon therapy in chronic hepatitis C. Is it possible to reduce the incidence by ribanirin and IFN combination therapy? Intervirology. 2005;48(1):59–63. doi: 10.1159/000082096. PMID: 15785091.15785091
223 Kasahara A, Hayashi N, Mochizuki K, . Risk factors for hepatocellular carcinoma and its incidence after interferon treatment in patients with chronic hepatitis C. Osaka Liver Disease Study Group. Hepatology. 1998 May;27(5):1394–402. doi: 10.1002/hep.510270529. PMID: 9581697.9581697
224 Kurokawa M, Hiramatsu N, Oze T, . Effect of interferon alpha-2b plus ribavirin therapy on incidence of hepatocellular carcinoma in patients with chronic hepatitis. Hepatol Res. 2009 May;39(5):432–8. doi: 10.1111/j.1872-034X.2008.00477.x. PMID: 19207583.19207583
225 Lee SH, Jin YJ, Shin JY, . Assessment of hepatocellular carcinoma risk based on peg-interferon plus ribavirin treatment experience in this new era of highly effective oral antiviral drugs. Medicine. 2017 Jan;96(1):e5321. doi: 10.1097/MD.0000000000005321. PMID: 28072684.28072684
226 Okanoue T, Itoh Y, Kirishima T, . Transient biochemical response in interferon therapy decreases the development of hepatocellular carcinoma for five years and improves the long-term survival of chronic hepatitis C patients. Hepatol Res. 2002 May;23(1):62–77. PMID: 12084557.12084557
227 Osaki Y, Ueda Y, Marusawa H, . Decrease in alpha-fetoprotein levels predicts reduced incidence of hepatocellular carcinoma in patients with hepatitis C virus infection receiving interferon therapy: a single center study. J Gastroenterol. 2012 Apr;47(4):444–51. doi: 10.1007/s00535-011-0505-8. PMID: 22105231.22105231
228 Tanaka H, Tsukuma H, Kasahara A, . Effect of interferon therapy on the incidence of hepatocellular carcinoma and mortality of patients with chronic hepatitis C: a retrospective cohort study of 738 patients. Int J Cancer. 2000 Sep 1;87(5):741–9. PMID: 10925370.10925370
229 Tateyama M, Yatsuhashi H, Taura N, . Alpha-fetoprotein above normal levels as a risk factor for the development of hepatocellular carcinoma in patients infected with hepatitis C virus. J Gastroenterol. 2011 Jan;46(1):92–100. doi: 10.1007/s00535-010-0293-6. PMID: 20711614.20711614
230 Yoshida H, Shiratori Y, Moriyama M, . Interferon therapy reduces the risk for hepatocellular carcinoma: national surveillance program of cirrhotic and noncirrhotic patients with chronic hepatitis C in Japan. IHIT Study Group. Inhibition of hepatocarcinogenesis by Interferon Therapy. Ann Intern Med. 1999 Aug 3;131(3):174–81. PMID: 10428733.10428733
231 Sinn DH, Paik SW, Kang P, . Disease progression and the risk factor analysis for chronic hepatitis C. Liver Int. 2008 Dec;28(10):1363–9. doi: 10.1111/j.1478-3231.2008.01860.x. PMID: 18710426.18710426
232 Braks RE, Ganne-Carrie N, Fontaine H, . Effect of sustained virological response on long-term clinical outcome in 113 patients with compensated hepatitis C-related cirrhosis treated by interferon alpha and ribavirin. World J Gastroenterol. 2007 Nov 14;13(42):5648–53. PMID: 17948941.17948941
233 Bruno S, Stroffolini T, Colombo M, . Sustained virological response to interferon-alpha is associated with improved outcome in HCV-related cirrhosis: a retrospective study. Hepatology. 2007 Mar;45(3):579–87. doi: 10.1002/hep.21492. PMID: 17326216.17326216
234 Cardoso AC, Moucari R, Figueiredo-Mendes C, . Impact of peginterferon and ribavirin therapy on hepatocellular carcinoma: incidence and survival in hepatitis C patients with advanced fibrosis. J Hepatol. 2010 May;52(5):652–7. doi: 10.1016/j.jhep.2009.12.028. PMID: 20346533.20346533
235 Fernández-Rodríguez CM, Alonso S, Martinez SM, . Peginterferon plus ribavirin and sustained virological response in HCV-related cirrhosis: outcomes and factors predicting response. Am J Gastroenterol. 2010;105(10):2164. doi: 10.1038/ajg.2010.294. PMID: 20700116.20700116
236 Hasegawa E, Kobayashi M, Kawamura Y, . Efficacy and anticarcinogenic activity of interferon for hepatitis C virus-related compensated cirrhosis in patients with genotype 1b low viral load or genotype 2. Hepatol Res. 2007 Oct;37(10):793–800. doi: 10.1111/j.1872-034X.2007.00140.x. PMID: 17593231.17593231
237 Shiratori Y, Ito Y, Yokosuka O, . Antiviral therapy for cirrhotic hepatitis C: association with reduced hepatocellular carcinoma development and improved survival. Ann Intern Med. 2005 Jan 18;142(2):105–14. PMID: 15657158.15657158
238 Veldt BJ, Heathcote EJ, Wedemeyer H, . Sustained virologic response and clinical outcomes in patients with chronic hepatitis C and advanced fibrosis. Ann Intern Med. 2007 Nov 20;147(10):677–84. PMID: 18025443.18025443
239 Coverdale SA, Khan MH, Byth K, . Effects of interferon treatment response on liver complications of chronic hepatitis C: 9-year follow-up study. Am J Gastroenterol. 2004;99(4):ajg2004123. doi: 10.1111/j.1572-0241.2004.04085.x. PMID: 15089895.15089895
240 Zibbell JE, Asher AK, Patel RC, . Increases in acute hepatitis C virus infection related to a growing opioid epidemic and associated injection drug use, United States, 2004 to 2014. Am J Public Health. 2018;108(2):175–81. doi: 10.2105/ajph.2017.304132. PMID: 29267061.29267061
241 Suryaprasad AG, White JZ, Xu F, . Emerging epidemic of hepatitis C virus infections among young nonurban persons who inject drugs in the United States, 2006-2012. Clin Infect Dis. 2014 Nov 15;59(10):1411–9. doi: 10.1093/cid/ciu643. PMID: 25114031.25114031
242 Watts T, Stockman L, Martin J, . Increased risk for mother-to-infant transmission of hepatitis C virus among medicaid recipients - Wisconsin, 2011-2015. MMWR. 2017 Oct 27;66(42):1136–9. doi: 10.15585/mmwr.mm6642a3. PMID: 29072864.29072864
243 Rosenberg ES, Rosenthal EM, Hall EW, . Prevalence of hepatitis C virus infection in US states and the District of Columbia, 2013 to 2016. JAMA Netw Open. 2018;1(8):e186371–e.30646319
244 Coffin PO, Scott JD, Golden MR, . Cost-effectiveness and population outcomes of general population screening for hepatitis C. Clin Infect Dis. 2012 May;54(9):1259–71. doi: 10.1093/cid/cis011. PMID: 22412061.22412061
245 McEwan P, Ward T, Yuan Y, . The impact of timing and prioritization on the cost-effectiveness of birth cohort testing and treatment for hepatitis C virus in the United States. Hepatology. 2013 Jul;58(1):54–64. doi: 10.1002/hep.26304. PMID: 23389841.23389841
246 McGarry LJ, Pawar VS, Panchmatia HR, . Economic model of a birth cohort screening program for hepatitis C virus. Hepatology. 2012 May;55(5):1344–55. doi: 10.1002/hep.25510. PMID: 22135116.22135116
247 Barocas JA, Tasillo A, Eftekhari Yazdi G, . Population-level outcomes and cost-effectiveness of expanding the recommendation for age-based hepatitis c testing in the United States. Clin Infect Dis. 2018 Aug 1;67(4):549–56. doi: 10.1093/cid/ciy098. PMID: 29420742.29420742
248 Eckman MH, Ward JW, Sherman KE. Cost effectiveness of universal screening for hepatitis c virus infection in the era of direct-acting, pangenotypic treatment regimens. Clin Gastroenterol Hepatol. 2018 Sep 8doi: 10.1016/j.cgh.2018.08.080. PMID: 30201597.30201597
249 Assoumou SA, Tasillo A, Leff JA, . Cost-effectiveness of one-time hepatitis c screening strategies among adolescents and young adults in primary care settings. Clin Infect Dis. 2018 Jan 18;66(3):376–84. doi: 10.1093/cid/cix798. PMID: 29020317.29020317
250 Chaillon A, Rand EB, Reau N, . Cost-effectiveness of universal hepatitis c virus screening of pregnant women in The United States. Clin Infect Dis. 2019 Jan 28doi: 10.1093/cid/ciz063. PMID: 30689769.30689769
251 Tasillo A, Eftekhari Yazdi G, Nolen S, . Short-term effects and long-term cost-effectiveness of universal hepatitis C testing in prenatal care. Obstet Gynecol. 2019 Feb;133(2):289–300. doi: 10.1097/aog.0000000000003062. PMID: 30633134.30633134
252 The Royal Australian and New Zealand College of Obstetricians and Gynaecologists. Management of Hepatitis C in Pregnacy. 2016. https://www.ranzcog.edu.au/RANZCOG_SITE/media/RANZCOG-MEDIA/Women’s%20Health/Statement%20and%20guidelines/Clinical%20-%20Gynaecology/Management-of-Hepatitis-C-in-Pregnancy-(C-Obs-51).pdf?ext=.pdf. Accessed June 25, 2019.
253 Midgard H, Hajarizadeh B, Cunningham EB, . Changes in risk behaviours during and following treatment for hepatitis C virus infection among people who inject drugs: The ACTIVATE study. Int J Drug Policy. 2017 Sep;47:230–8. doi: 10.1016/j.drugpo.2017.05.040. PMID: 28633998.28633998
254 Alavi M, Spelman T, Matthews GV, . Injecting risk behaviours following treatment for hepatitis C virus infection among people who inject drugs: the Australian trial in acute hepatitis C. Int J Drug Policy. 2015 Oct;26(10):976–83. doi: 10.1016/j.drugpo.2015.05.003. PMID: 26115881.26115881
255 Butt AA, Yan P, Shaikh OS, . Hepatitis B reactivation and outcomes in persons treated with directly acting antiviral agents against hepatitis C virus: results from ERCHIVES. Aliment Pharmacol Ther. 2018a Feb;47(3):412–20. doi: 10.1111/apt.14426. PMID: 29181838.29181838
256 Hickman M, De Angelis D, Vickerman P, . Hepatitis C virus treatment as prevention in people who inject drugs: testing the evidence. Curr Opin Infect Dis. 2015 Dec;28(6):576–82. doi: 10.1097/QCO.0000000000000216. PMID: 26524330.26524330
257 Scott N, Hellard M, McBryde ES. Modeling hepatitis C virus transmission among people who inject drugs: assumptions, limitations and future challenges. Virulence. 2016;7(2):201–8. doi: 10.1080/21505594.2015.1085151. PMID: 26305706.26305706
258 Martin NK, Foster GR, Vilar J, . HCV treatment rates and sustained viral response among people who inject drugs in seven UK sites: real world results and modelling of treatment impact. J Viral Hepat. 2015 Apr;22(4):399–408. doi: 10.1111/jvh.12338. PMID: 25288193.25288193
259 Martin NK, Vickerman P, Grebely J, . Hepatitis C virus treatment for prevention among people who inject drugs: modeling treatment scale-up in the age of direct-acting antivirals. Hepatology. 2013 Nov;58(5):1598–609. doi: 10.1002/hep.26431. PMID: 23553643.23553643
260 Waziry R, Hajarizadeh B, Grebely J, . Hepatocellular carcinoma risk following direct-acting antiviral HCV therapy: a systematic review, meta-analyses, and meta-regression. J Hepatol. 2017 Dec;67(6):1204–12. doi: 10.1016/j.jhep.2017.07.025. PMID: 28802876.28802876
261 Jakobsen JC, Nielsen EE, Feinberg J, . Direct-acting antivirals for chronic hepatitis C. Cochrane Database Syst Rev. 2017 06 06;6:CD012143. doi: 10.1002/14651858.CD012143.pub3. PMID: 28585310.28585310
262 Cacoub P, Desbois AC, Comarmond C, . Impact of sustained virological response on the extrahepatic manifestations of chronic hepatitis C: a meta-analysis. Gut. 2018 Apr 27:2025–34. doi: 10.1136/gutjnl-2018-316234. PMID: 29703790.29703790
263 Simmons B, Saleem J, Heath K, . Long-term treatment outcomes of patients infected with hepatitis C virus: a systematic review and meta-analysis of the survival benefit of achieving a sustained virological response. Clin Infect Dis. 2015 Sep 01;61(5):730–40. doi: 10.1093/cid/civ396. PMID: 25987643.25987643
264 Bang C, Song I. Impact of antiviral therapy on hepatocellular carcinoma and mortality in patients with chronic hepatitis C: systematic review and meta-analysis. BMC Gastroenterol. 2017;17(1):46. doi: 10.1186/s12876-017-0606-9. PMID: 28376711.28376711
265 MDLinx Gastrogenterology, Saleh N. HCV cures will now come as generics. 2018. https://www.mdlinx.com/gastroenterology/article/2869. Accessed June 24, 2019.
266 Saag MS. Editorial commentary: getting smart in how we pay for HCV drugs: KAOS vs CONTROL. Clin Infect Dis. 2015 Jul 15;61(2):169–70. doi: 10.1093/cid/civ221. PMID: 25778748.25778748
267 American Association for the Study of Liver Diseases, Infectious Diseases Society of America. HCV Guidance: Recommendations for Testing, Managing, and Treating Hepatitis C. Overview of Cost, Reimbursement, and Cost-Effectiveness Considerations for Hepatitis C Treatment Regimens. 2017. https://www.hcvguidelines.org/evaluate/cost. Accessed June 25, 2019.
268 Hill A, Khoo S, Fortunak J, . Minimum costs for producing hepatitis C direct-acting antivirals for use in large-scale treatment access programs in developing countries. Clin Infect Dis. 2014 Apr;58(7):928–36. doi: 10.1093/cid/ciu012. PMID: 24399087.24399087
269 Wolff TA, Krist AH, LeFevre M, . Update on the methods of the U.S. Preventive Services Task Force: linking intermediate outcomes and health outcomes in prevention. Am J Prev Med. 2018 Jan;54(1s1):S4–S10. doi: 10.1016/j.amepre.2017.08.032. PMID: 29254525.29254525
270 Yek C, de la Flor C, Marshall J, . Effectiveness of direct-acting antiviral therapy for hepatitis C in difficult-to-treat patients in a safety-net health system: a retrospective cohort study. BMC Med. 2017 Nov 20;15(1):204. doi: 10.1186/s12916-017-0969-3. PMID: 29151365.29151365
271 Su F, Green PK, Berry K, . The association between race/ethnicity and the effectiveness of direct antiviral agents for hepatitis C virus infection. Hepatology. 2017 Feb;65(2):426–38. doi: 10.1002/hep.28901. PMID: 27775854.27775854
272 Cory TJ, Mu Y, Gong Y, . Sofosbuvir + velpatasvir + voxilaprevir for the treatment of hepatitis C infection. Expert Opin Pharmacother. 2018 May;19(7):749–57. doi: 10.1080/14656566.2018.1459567. PMID: 29634360.29634360
273 Centers for Disease Control and Prevention. Surveillance for Viral Hepatitis – United States, 2016. 2016. https://www.cdc.gov/hepatitis/statistics/2016surveillance/pdfs/2016HepSurveillanceRpt.pdf. Accessed June 25, 2019.
274 Hajarizadeh B, Cunningham EB, Reid H, . Direct-acting antiviral treatment for hepatitis C among people who use or inject drugs: a systematic review and meta-analysis. Lancet Gastroenterol Hepatol. 2018;3(11):754–67. PMID: 30245064.30245064
275 Simmons B, Saleem J, Hill A, . Risk of late relapse or reinfection with hepatitis C virus after achieving a sustained virological response: a systematic review and meta-analysis. Clin Infect Dis. 2016 Mar 15;62(6):683–94. doi: 10.1093/cid/civ948. PMID: 26787172.26787172
276 Indolfi G, Serranti D, Resti M. Direct-acting antivirals for children and adolescents with chronic hepatitis C. Lancet Child Adolesc Health. 2018 Apr;2(4):298–304. doi: 10.1016/s2352-4642(18)30037-3. PMID: 30169301.30169301
277 Flori N, Funakoshi N, Duny Y, . Pegylated interferon-alpha2a and ribavirin versus pegylated interferon-alpha2b and ribavirin in chronic hepatitis C : a meta-analysis. Drugs. 2013 Mar;73(3):263–77. doi: 10.1007/s40265-013-0027-1. PMID: 23436591.23436591