# Acknowledgments

The authors acknowledge Christina Bougatsos, MPH. The authors also thank the Agency for Healthcare Research and Quality Medical Officer, Iris Mabry-Hernandez, MD, MPH; as well as members of the U.S. Preventive Services Task Force.