# Chapter 4 Discussion

## Summary of Review Findings

This report updates prior reviews on HCV screening and treatments in adults, and interventions to prevent mother-to-child transmission.^2,3,90^ It expands upon the prior reviews by adding evidence on adolescents and addressing the benefits and harms of currently recommended all-oral, DAA regimens. As in the prior USPSTF review,^2^ we found no direct evidence on the clinical benefits of screening for HCV versus not screening or on the yield of repeat screening. We also found no new evidence to better evaluate harms of screening; the prior review included studies suggesting potential negative psychological and social effects of screening, but the quality of the evidence was poor. Other evidence reviewed for this update is summarized in Table 23.

Table 23 Summary of Evidence

KQ | Number of Studies (k); Number of participants (n); Study Designs | Summary of Findings | Consistency and Precision | Overall quality | Body of Evidence Limitations | EPC Assessment of Strength of Evidence for KQ | Applicability
KQ 1a. Benefits of screening | No studies | --- | --- | --- | --- | --- | ---
KQ 1b. Prenatal screening and vertical transmission | No studies | --- | --- | --- | --- | --- | ---
KQ 2. Screening strategies | No studies | --- | --- | --- | --- | --- | ---
KQ 3. Screening strategies and yield | Prior review: k=5 studies (n=8,044); New evidence: k=1 study (n=5,917) | The prior review included 5 studies that found risk-based screening associated with sensitivities of >90% and numbers needed to screen to identify 1 case of HCV infection of <20.; One new study found that perfect application of risk-based guidelines would identify 82% of HCV cases with a number needed to screen to identify one case of HCV infection of 14.6, while applying a birth cohort strategy would result in 76% of cases identified a number needed to screen of 28.7. | Reasonable consistent and precise. | Fair | Studies were retrospective and in some studies significant proportions of patients were not tested. No studies of the yield of one-time versus repeat screening, alternative screening strategies in different risk groups, or the yield of currently recommended screening versus expanded screening strategies. | Low | Most studies conducted in high-prevalence settings. One study assumed perfect application of risk-based screening, which has not been attainable.
KQ 4. Harms of screening | Prior review: k=5 studies (n=288); New evidence: No new studies | Poor-quality evidence from the prior review suggested potential negative psychological and social effects of screening.; No new studies on harms of screening were identified. | Low consistency and precision | Poor | Small sample sizes, no unscreened comparison group, reliance on retrospective recall, poorly defined outcomes. | Low | Studies were conducted in the era of interferon-based treatments
KQ 5. Effectiveness of interventions to prevent vertical transmission | Prior review: k=4 studies (n=1,724); New evidence: k=1 study (n=1,301) | Mode of delivery and risk of mother-to-infant transmission (5 studies, 1 new): No clear association; Prolonged rupture of membrane (1 study from prior review): Adjusted OR 9.3, 95% CI, 1.5 to 180; Internal fetal monitoring (1 study from prior review): Adjusted OR 6.7, 95% CI, 1.1 to 35.9; Breastfeeding (3 studies, 1 new): No clear association | Mode of delivery: Inconsistent; some imprecision; Rupture of membranes and fetal monitoring: Unable to assess consistency, imprecise; Fetal monitoring: NA; imprecise; Breastfeeding: Inconsistent; some imprecision | Fair | All studies were observational. Most studies from prior review were poor-quality and didn’t perform statistical adjustment for potential confounders and were excluded. Prolonged rupture of membranes and internal monitoring only evaluated in 1 study each. | Low | Studies were conducted in the U.S. or Europe; One study excluded women who were HIV positive; in the remaining 4 studies, HIV infection rates ranged from 5% to 15%
KQ 6. Effect of treatment on health outcomes - Adults | Prior review: NA (outdated regimens); New evidence: k=37 (34 trials [n=4,434], 2 pooled analyses [n=2,706], and 3 observational studies [n=58,892]) | Two pooled analyses of 3 and 4 trials each and data from 3 other trials not included in pooled analyses found small, short-term improvements in quality of life scale scores after compared with before DAA therapy.; In 31 DAA trials reporting short-term (<1 year) mortality, there were no deaths in 21 trials; mortality was low in the remaining 10 trials (0.4% [17/3,848] overall.); Two large observational studies found use of both DAA associated with lower rates of cardiovascular events and hepatocellular cancer. These associations were not found in a third, smaller observational study with shorter duration of followup. | Consistent, imprecise | Fair | Trials reporting quality of life and function were not randomized, used an open-label design, and did not have a non-DAA comparison group.; Trials provided short-term followup, and were not designed to assess health outcomes. Event rates for mortality were low across studies, and other health outcomes were not widely reported.; Evidence on long-term clinical outcomes was limited to 3 observational studies. | Low | Trials did not enroll a high proportion of patients with cirrhosis at baseline and evaluated current DAA regimens.; Evidence on effects on hepatocellular cancer and cardiovascular events was primarily derived from a VA database that included few female subjects (3-4%).
KQ 6. Effect of treatment on health outcomes - Adolescents | k=3 (3 trials [n=230] in 5 publications) | There were no deaths in 3 trials of DAA regimens reporting short-term mortality.; Sofosbuvir with ledipasvir or ribavirin and glecaprevir with pibrentasvir were associated with small improvements in Pediatric Quality of Life Inventory scores compared to baseline. | Cannot determine (for quality of life); imprecise | Fair | Trials were not designed to assess long-term health outcomes.; The only evidence on quality of life outcomes is based on a post-hoc analysis of trial data. | Low | One trial evaluated a DAA regimen not FDA-approved for use in adolescents.
KQ 7. Effect of treatment on SVR - Adults | Prior review: NA (outdated regimens); New evidence: k=49 trials (n=10,181; 27 multi-arm trials and 22 single arm trials) | DAA vs. placebo (1 RCT): SVR 99% vs. 0%, RR 231.6, 95% CI, 14.6 to 3680; DAA vs. telaprevir (2 RCTs): SVR 98% vs. 80%, RR 1.22 (95% CI, 1.09 to 1.37) and 99% vs. 66%, RR 1.50 (95% CI, 1.22 to 1.85); In 49 trials, SVR rates with DAA therapies ranged from 95% to 100% across genotypes. Estimates were consistent in subgroup analyses based on study quality, geographic setting, fibrosis status, prior treatment experience, and other factors. Results were also similar in trials that stratified patients according to age, sex, race or ethnicity, or treatment-experience. | Consistent; precise | Good | All studies were industry-funded. Most DAA trials did not include a non-DAA comparison group. Evidence was most robust for genotype 1 and more limited for genotypes 2 through 6. | High | SVR rates based on currently recommended DAA regimens. Trials did not enroll a high proportion of patients with cirrhosis at baseline.; Most trials enrolled predominantly white participants. Persons with current or recent drug use excluded from most trials.; Most trials were conducted in the U.S. or Europe or were multinational.
KQ 7. Effect of treatment on SVR - Adolescents | Prior review: NA; k=7 single arm trials (n=348) | In seven trials, the SVR rate ranged from 97% to 100%. Rates were similar when stratified according to DAA treatment regimen, genotype and treatment history. | Consistent; imprecise | Fair | Evidence in adolescents with genotype 2 and 4 infection was very limited (n=20); Four trials were industry funded. | Fair | Three trials evaluated DAA regimens not FDA-approved for use in adolescents.; Four trials were multinational (primarily U.S. and Europe) and three were conducted in Egypt.
KQ 8. Harms – Adults: DAA vs. placebo | k=4 trials (n=2,113) | Pooled adverse event rates, DAA versus placebo:; - Any adverse event (4 trials): RR 1.12, 95% CI, 1.02 to 1.24, I^2^=46; - Serious adverse events (4 trials): RR 1.90, 95% CI, 0.73 to 4.95, I^2^=0%; - Withdrawal due to adverse events (4 trials): RR 0.47, 95% CI, 0.14 to 1.58, I^2^=14%; - Headache (4 trials): RR 1.12, 95% CI, 0.91 to 1.37, I^2^=0%; - Nausea (3 trials): RR 1.42, 95% CI, 1.00 to 2.03, I^2^=10%; - Diarrhea (2 trials): RR 1.53, 95% CI, 0.88 to 2.68, I^2^=29%; - Fatigue (3 trials): RR 1.05, 95% CI, 0.78 to 1.40; I^2^=32%; - Anemia (1 trial): RR 2.21, 95% CI, 0.11 to 46 | Consistent; precise | Fair | Most trials did not have a non-DAA comparison group. Reporting of methods used to assess and define was suboptimal. Trials did not report long-term follow-up. | Moderate | See KQ 7
KQ 8. Harms – Adults: DAA vs. other treatment | k=2 trials (n=459) | Pooled adverse event rates, DAA versus other treatment:; - Any adverse event (2 trials): RR 0.65, 95% CI, 0.50 to 0.84, I^2^=87%; - Serious adverse events (2 trials): RR 0.08, 95% CI, 0.02 to 0.34, I^2^=0%; - Headache (2 trials): RR 0.78, 95% CI, 0.58 to 1.04; I^2^=0%; - Withdrawal due to adverse events (2 trials): RR 0.06, 95% CI, 0.01 to 0.29, I^2^=0%; - Fatigue (2 trials): RR 0.37, 95% CI, 0.21 to 0.63, I^2^=32%; - Headache (2 trials): RR 0.70, 95% CI, 0.52 to 0.95; I^2^=0%; - Nausea (2 trials): RR 0.31, 95% CI, 0.16 to 0.59, I2=65%; - Anemia (2 trials): RR 0.09, 95% CI, 0.04 to 0.23, I^2^=41%; - Rash (2 trials): RR 0.19, 95% CI, 0.06 to 0.58, I^2^=48% | Consistent; precise | Fair | Most trials did not have a non-DAA comparison group. Reporting of methods used to assess and define was suboptimal. Trials did not report long-term follow-up. | Moderate | See KQ 7
KQ 8. Harms of treatment – Adults: Overall | Prior review: NA (outdated regimens); New evidence: k=49 trials (n=10,181) | Pooled adverse events rates for currently recommended DAA regimens were:; - Any adverse event (44 trials): 73.3%, 95% CI, 68.0% to 78.1%; I^2^=95%; - Serious adverse events (44 trials): 1.9%, 95% CI, 1.5% to 2.4%; I^2^=33%; - Withdrawal due to adverse events (44 trials): 0.4%, 95% CI, 0.3% to 0.6%; I^2^=0%; - Anemia (13 trials): 2.4%, 95% CI, 0.9% to 6.3%; I^2^=85%; - Fatigue (37 trials): 18.4%, 95% CI, 15.6% to 21.7%; I^2^=90%; - Headache (42 trials): 18.7%, 95% CI, 15.6% to 22.2%; I^2^=90%; - Insomnia (18 trials): 8.1%, 95% CI, 6.7% to 9.9%; I^2^=58%; - Nausea (36 trials): 11.1%; 95% CI, 9.1% to 13.5%, I^2^=82%; - Diarrhea (19 trials): 8.7%, 95% CI, 7.0% to 10.8%; I^2^=69%; - Vomiting (6 trials): 5.8%, 95% CI, 3.4% to 9.7%; I^2^=43%; - Rash (17 trials): 5.4%, 95% CI, 4.1% to 7.1%; I^2^=70% | Consistent; precise | Fair | Estimates were without a non-DAA comparison group. Reporting of methods used to assess and define was suboptimal. Trials did not report long-term follow-up. | Moderate | See KQ 7
KQ 8. Harms of treatment – Adolescents | Prior review: NA; New evidence: k=7 trials (n=348) | Five trials reported no withdrawals due to adverse events.; There was one serious adverse event (grade 3 joint injury) in 1 trial.; The rate of any adverse event was 27% in one trial and 71 to 87% in four trials.; Specific adverse event rates were:; - Headache (7 trials): 3 to 48%; - Fatigue (7 trials): 5 to 53%; - Gastrointestinal adverse events (5 trials): 3 to 28%; - Insomnia (1 trial): 23% | Inconsistent; imprecise | Fair | Trials did not have a non-DAA comparison group. There was high variability in adverse event rates, with no clear trends when results were stratified according to regimen.; Reporting of methods used to assess harms was suboptimal and long-term followup (>48 weeks) was not reported | Fair | See KQ 6 - Adolescents
KQ 9. Association between SVR and health outcomes | Prior review: 19 studies (n=30,692); New evidence: k=30 (n=116,659 [n=26,191 from studies included in the prior report + n=90,468 from new studies]) | Pooled estimates for health outcomes for SVR versus no SVR, in studies in which <25% of the population had cirrhosis at baseline:; - All-cause mortality (13 studies, 5 new): HR 0.40, 95% CI, 0.28 to 0.56; I^2^=52%; - Liver mortality (4 studies, 0 new): HR 0.11, 95% CI, 0.04 to 0.27; I^2^=0%; - Cirrhosis (4 cohorts reported in 3 studies, all new): HR 0.36, 95% CI, 0.33 to 0.40; I^2^=0%); - Hepatocellular carcinoma (20 studies, 16 new): HR 0.29, 95% CI, 0.23 to 0.38; I^2^=19%; Estimates were consistent in analyses stratified according to duration of follow-up, geographic setting, and level of statistical adjustment for potential confounders. | Consistent, precise | Fair | Studies are observational and susceptible to confounding. Some studies appeared to evaluate overlapping patient populations.; About half (k=13) of the studies did not address four pre-specified potential confounders in analyses (age, sex, fibrosis stage, and genotype). | Fair | Most studies evaluated SVR after interferon-based therapy; evidence on SVR after DAA therapy was limited to two studies, one of which reported imprecise estimates. Studies did not enroll a high proportion of patients with cirrhosis at baseline. Patients primarily received interferon-containing therapy.; Six of seven U.S. studies conducted in VA populations. Over half of studies conducted in Asia, though results similar in U.S./Europe studies.

Abbreviations: ARD = adjusted risk difference; CI = confidence interval; DAA = direct acting antiviral; EPC = Evidence-based Practice Center; FDA = US Food and Drug Administration; HCV = hepatitis C virus; HR = hazard ratio; KQ = Key Question; NA = not applicable; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; SVR = sustained virologic response; U.S. = United States; VA = Veterans Affairs

Since the prior USPSTF recommendation, there has been a major shift in antiviral therapy to use of all-oral DAA regimens without interferon.^74^ At the time of the prior review, standard antiviral therapy for HCV infection for genotype 1 infection was transitioning to boceprevir or telaprevir with pegylated interferon and ribavirin (SVR rates 68% to 72%); for genotypes 2 and 3 standard therapy was pegylated interferon plus ribavirin (SVR rates 68% to 78%).^90^ New evidence indicates that SVR rates with currently recommended all-oral DAA regimens are substantially higher than with prior therapies. Pooled SVR rates ranged from 95.5 percent to 98.9 percent across genotypes; for the three most common genotypes in the United States (1, 2, and 3), pooled SVR rates ranged from 95.5 percent to 98.9 percent. Evidence was most robust for genotype 1 infection (32 trials), the most frequent genotype in the United States (approximately 75%), followed by genotype 4 infection (10 trials); data were limited for other genotypes (4 to 6 trials each). SVR estimates generally exceeded 95 percent when analyses were stratified according to DAA regimen, study quality, inclusion of patients with cirrhosis at baseline (with the exception of genotype 3 infection, which was associated with a lower SVR rate in one trial that included patients with cirrhosis),^165^ geographic setting, prior experience with older antiviral regimens, and use of ribavirin. Few trials directly compared a current DAA regimen versus placebo or an older antiviral regimen, but those available supported high DAA regimen effectiveness. In one trial of patients with mixed genotype infection, the SVR rate was 99 percent with sofosbuvir / velpatasvir and 0 percent with placebo,^139^ and in two trials of patients with mixed genotype infection the SVR rate was 98 percent to 99 percent with ombitasvir / paritaprevir / ritonavir / dasabuvir (with or without ribavirin) and 66 percent to 80 percent with telaprevir / pegylated interferon / ribavirin.^137^ Evidence on DAA regimens in adolescents is limited but indicates SVR rates similar to those observed in adults (97% to 100%).^171,173,175,176,201–203^ Some trials of DAA regimens in adolescents evaluated regimens that are not FDA-approved for use in adolescents but that are recommended in adults.

Evidence also indicates that current DAA regimens are associated with fewer harms than older interferon-containing therapies; the duration of treatment is also shorter at 12 weeks (8 weeks for glecaprevir / pibrentasvir or ledipasvir / sofosbuvir in persons with genotype 1 infection who are non-black, HIV-uninfected, and whose HCV RNA level is under 6 million IU/mL)^74^ compared with prior interferon-containing regimens (24 to 48 weeks). The prior review found therapies with interferon associated with rates of serious adverse events of 8.5 percent to 16 percent and withdrawal due to adverse events of 12 percent to 15 percent.^90^ Interferon-based therapies were also associated with high rates of fatigue (51% to 64%), depression (19% to 22%), influenza-like symptoms (19% to 40%), and other adverse events. Boceprevir and telaprevir containing regimens were associated with increased risk of hematological adverse events compared with pegylated interferon plus ribavirin. Four new randomized trials found DAA regimens associated with slightly increased risk of any adverse event (ARD 8%, for a number needed to harm [NNH] of approximately 13) and nausea (ARD 4%, for a NNH of approximately 25) versus placebo, with no difference in risk of serious adverse events, withdrawal due to adverse events, or specific adverse events (e.g., diarrhea, fatigue, headache, or anemia).^139,151,164,187^ Two trials found DAA regimens associated with decreased risk of any adverse event versus triple therapy with telaprevir (ARD −34%, for a number needed to avoid harm [NNAH] of approximately 3), serious adverse events (ARD −8%, NNAH approximately 12), withdrawal due to adverse events (ARD −9%, NNAH approximately 11), and specific adverse events (NNAH for fatigue, nausea, anemia, and rash ranged from approximately 3 to 6).^137^ Across DAA trials, the pooled rate of any adverse event was relatively high at 73.3 percent, but rates of serious adverse events and withdrawal due to adverse events were low (1.9% and 0.4%, respectively) relative to older interferon-containing regimens. Pooled rates of specific adverse events ranged from 2.4 percent for anemia to 18.4 percent for headache, also lower than observed with interferon-containing therapies. Ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin was generally associated with increased rates of adverse events compared with the same regimen without ribavirin, with a marked increase in risk of anemia (pooled rates 8.3% vs. 0.8%). All DAA trials in this report excluded patients with HBV coinfection, and no cases of HBV reactivation were reported. One cohort study of VA patients with HCV infection treated with a DAA regimen (n=34,632) that did not meet inclusion criteria reported an HBV reactivation rate of 30.0 per 1,000 person-years.^255^ Eleven percent of patients in this cohort were surface antigen of HBV-positive at baseline. The HBV reactivation rate with DAA therapy was similar to the reactivation rate with pegylated interferon plus ribavirin (25.4 per 1,000 person-years, p=0.8).

Direct evidence on the effects of antiviral therapy on clinical outcomes is limited. Although several randomized trials found interferon therapy associated with decreased risk of HCC compared with no antiviral therapy, they did not meet inclusion criteria for this report because they focused on patients with cirrhosis at baseline or used a non-standard (i.e. indefinite duration of treatment) regimen.^127–134^ Trials of DAA therapies were not designed to assess effects on mortality or other long-term clinical outcomes. Ten DAA trials reported improvements in some quality of life and functional outcomes following treatment compared with prior to treatment, but differences were small, studies were open-label, and there was no non-DAA comparison group, making it difficult to interpret more subjective outcomes like these.^135–137^ Large cohort studies conducted on a large national VA database in which approximately 20 percent of patients had cirrhosis at baseline found DAA therapy associated with reduced risk of cardiovascular events, HCC, and mortality versus no therapy after adjusting for potential confounders, with effects similar to or stronger than interferon-based therapy.^169,170^ A French study found no association between DAA therapy versus no antiviral therapy in risk of all-cause mortality or HCC in the subgroup of patients without cirrhosis at baseline, but there were few events, and estimates were imprecise.^168^ In this study, when patients with cirrhosis (approximately 33% of the population) were included in the analysis, DAA therapy was associated with decreased risk of all-cause mortality (adjusted HR 0.48, 95% CI, 0.33 to 0.70), liver-related mortality (adjusted HR 0.39, 95% CI, 0.21 to 0.71), and HCC (adjusted HR 0.66, 95% CI, 0.46 to 0.93).

No study evaluated effects of DAA therapies on behaviors associated with HCV acquisition. There was limited evidence that interferon-based therapies are not associated with increased injection drug use behaviors, and may be associated with reductions in some behaviors.^253,254^ No study evaluated effects of DAA therapy on HCV transmission.^256^ Such studies would be difficult to design and carry out, but assessments of potential transmission effects could be informed by modeling studies.^257,258^ One study that modeled effects on transmission risk estimated that among PWID, decreasing HCV prevalence in half within 15 years would require increasing the proportion of patients treated 2- to 15-fold, depending on the baseline HCV prevalence.^259^

In lieu of limited direct evidence on the effects of antiviral therapy on clinical outcomes, cohort studies of SVR after antiviral therapy versus no SVR may help to understand potential clinical effects. Our findings of a consistent association between SVR after antiviral therapy and improved clinical outcomes were consistent with the prior review.^90^ Moreover, our findings may be more applicable to screening because we excluded previously utilized studies in which a high proportion of patients had cirrhosis at baseline. SVR after antiviral therapy (primarily interferon-based therapy) was associated with decreased risk of all-cause mortality (pooled adjusted HR 0.40, 95% CI, 0.28 to 0.56), liver mortality (pooled adjusted HR 0.11, 95% CI, 0.04 to 0.27), cirrhosis (pooled adjusted HR 0.36, 95% CI, 0.33 to 0.40), and HCC (pooled adjusted HR 0.29, 95% CI, 0.23 to 0.38). Evidence was most robust for all-cause-mortality and HCC (reported in 13 and 20 studies, respectively), and less robust for liver mortality and cirrhosis (reported in 4 studies each). Findings were consistent when studies were stratified according to how well they adjusted for potential confounders, duration of followup, and geographic setting (United States or Europe vs. Asia), though effects on mortality were stronger in studies with longer followup. Although most studies on the association between SVR after antiviral therapy and clinical outcomes evaluated interferon-based therapy, results were similar in two studies of SVR after DAA therapy,^205,221^ with one study showing similar effects of DAA and interferon regimens on HCC risk. Estimates from a third study of SVR after DAA therapy were very imprecise. This is consistent with a recent systematic review that found no evidence for differential hepatocellular occurrence or recurrence risk following SVR from DAA or interferon-based therapy, though most studies in that review evaluated patients with cirrhosis or a history of HCC.^260^

Our findings regarding the benefits and harms of current DAA regimens were consistent with a recent systematic review that also reported high SVR rates (greater than 95%) in patients with HCV genotype 1 infection without cirrhosis, high SVR rates but limited evidence for other HCV genotypes, low rates of serious adverse events and treatment discontinuation rates, and higher adverse event rates with ribavirin.^73^ Our results are also consistent with a systematic review that found insufficient evidence from clinical trials to determine effects of DAA regimens on HCV-related mortality and morbidity;^261^ unlike that review, we also evaluated the indirect chain of evidence linking DAA therapy with clinical outcomes. Our review is consistent with prior reviews that found a consistent association between an SVR after antiviral therapy and reduced risk of mortality and HCC.^72,260,262–264^ Our review differs from prior reviews in focusing on populations more likely to be identified by screening, by excluding studies in which a high proportion of patients had cirrhosis, and by restricting inclusion to currently recommended DAA regimens. One review on effects of antiviral therapy on extrahepatic manifestations of HCV infection found SVR after antiviral therapy associated with increased likelihood of cryoglobulinemia vasculitis remission and malignant B-cell lymphoproliferative disease response, outcomes not considered in our review because they relate to symptomatic and uncommon conditions.^262^ It also found attaining SVR associated with reduced risk of insulin resistance and a protective effect on diabetes incidence; we restricted analysis of the association between SVR versus no SVR to mortality and long-term hepatic outcomes and did not identify any studies on the effects of DAA therapy versus no therapy on diabetes.

New evidence on interventions to reduce the risk of mother-to-infant transmission of HCV was limited and did not change the conclusion from the prior review that no intervention has been clearly demonstrated to reduce risk.^3^ All studies were observational; in addition, we excluded most of the studies in the prior review because they were poor quality and did not conduct multivariate analyses. Studies on the effects of cesarean versus vaginal delivery (5 studies, 1 new)^107^ and breastfeeding versus no breastfeeding (3 studies, 1 new)^107^ continued to show inconsistent effects on risk of mother-to-child transmission. Although use of internal fetal monitoring and prolonged rupture of membranes were both associated with markedly increased risk of mother-to-child transmission, each was evaluated in only 1 study.^104^

Evidence to determine the yield of alternative screening strategies remains limited. Although one new study found that risk-based screening would identify slightly more HCV cases and require testing of fewer patients than birth cohort screening, this was based on a retrospective analysis and the assumption of perfect implementation of risk-based testing, which has not been attained in clinical practice.^99^ Modeling studies suggest that expanded screening strategies may be cost-effective in the general population as well as in pregnant females. Two studies found expanded screening of all persons 18 years and older associated with incremental cost-effectiveness ratios under $30,000/QALY compared with birth cohort screening, despite different assumptions regarding utilities associated with chronic HCV virus infection states, costs of DAA therapy, and rates of linkage to care. In most sensitivity analyses, incremental cost-effectiveness ratios remained less than $50,000/QALY.^247,248^ Another study found routine HCV screening of persons 15 to 30 years of age associated with incremental cost-effectiveness ratios less than $50,000/QALY under certain scenarios.^249^ Two modeling studies found routine prenatal screening associated with incremental cost-effectiveness ratios of $50,000/QALY versus current practice, though there was more variability in estimates ($2,826/QALY and $41,000/QALY).^250,251^ Both studies assumed that antiviral treatment was withheld until after childbirth and did not attempt to model effects on neonatal costs or outcomes. A factor complicating interpretation of the cost-effectiveness analyses are marked differences in base-case assumptions regarding costs of DAA therapy (range approximately $25,000 [similar to the current cost of a full course of therapy with a generic DAA regimen]^265^ to over $100,000), though expanded HCV screening appeared cost-effective even in analyses that assumed high DAA therapy costs. Costs of DAA therapy are expected to decline further,^266–268^ which would further enhance the cost-effectiveness of expanded screening strategies.

## Limitations

Our report has potential limitations. Because there were few trials of current DAA regimens versus placebo or older antiviral therapies, we utilized non-randomized trials of DAA therapies, including trials without a non-DAA therapy comparison group. Pooled SVR rates derived from such trials were considered highly informative because SVR rates are very objective, and SVR rates without treatment are close to zero. However, more subjective outcomes such as quality of life, function, and adverse events are more difficult to interpret in the absence of randomization or a comparison group. SVR is a well-established marker for sustained viral clearance (HCV infection cure) but is an intermediate (non-clinical) outcome. There was little evidence directly evaluating effects of antiviral therapies versus no antiviral therapy on clinical outcomes, due in part to the long duration required to evaluate effects on mortality and other long-term sequelae of HCV infection and ethical considerations related to withholding recommended treatment in randomized trials. Therefore, we included cohort studies on the association between SVR versus antiviral therapy versus no SVR and effects on clinical outcomes. Because such studies are susceptible to residual confounding if other factors associated with achieving an SVR also predict better outcomes, we restricted inclusion to studies that reported multivariate risk estimates and performed stratified analyses based on the degree to which studies adjusted for potential confounders.^269^ No trial of DAA therapy was conducted in screen-detected patients, and few trials reported presence or severity of baseline symptoms. In order to evaluate effectiveness of DAA therapies in populations likely to be identified by screening, we focused on studies in which patients with cirrhosis, who are more likely to be symptomatic, were excluded, or in which the proportion with cirrhosis was small. Although we included trials of patients previously treated with interferon-based therapies or boceprevir or telaprevir with pegylated interferon and ribavirin, who would not be identified by screening, such patients may be asymptomatic or mildly asymptomatic, and SVR rates were similar in treatment-naïve and -experienced patients. Trials of DAA therapy could overestimate SVR rates compared with typical clinical practice. However, observational studies, including a study of difficult to treat persons in a safety net health system, report SVR rates of 90 percent, or only modestly lower than observed in the trials.^270,271^ We did not assess effects of counseling or immunizations on clinical outcomes in persons diagnosed with HCV infection, though prior reviews found no evidence to estimate effects,^91^ and no study evaluated effects of DAA treatments on HCV transmission. We excluded studies of patients coinfected with HBV or HIV and with advanced renal disease since management of these conditions was determined to be outside the scope of screening. We excluded non-English language articles, which could result in language bias, though we identified no non-English language studies that would have met inclusion criteria. We did not search for studies published only as abstracts. We did not formally assess for publication bias using graphical or statistical methods to detect small sample effects due to the small number of randomized trials meeting inclusion criteria; the usefulness of such methods when assessing event rates (rather than risk estimates) is uncertain.

## Emerging Issues/Next Steps

All DAA regimens currently recommended were approved by the FDA since the prior review. DAA regimens continue to evolve and treatment guidelines are regularly updated.^74^ Several newer DAA regimens are pangenotypic, meaning that they are effective across all genotypes,^75^ and most currently recommended DAA regimens do not require use of ribavirin. Although three pangenotypic regimens (glecaprevir / pibrentasvir, sofosbuvir / velpatasvir, and sofosbuvir / velpatasvir / voxilaprevir) have been approved by the FDA, one regimen (sofosbuvir / velpatasvir / voxilaprevir) was developed for use in previously treated persons with resistant virus.^272^ Advantages of pangenotypic regimens include elimination of the need for genotyping and simplified selection of therapy. Costs of current DAA regimens has been a barrier to treatment but competition and negotiated pricing have reduced prices.^266,267^ Another issue is the shift towards management of HCV infection in primary care settings rather than in specialty settings, potentially facilitating access to treatment. Initial studies indicate that treatment in primary care settings is associated with similar outcomes as treatment in specialty settings, though more data are needed.^78,79^

## Relevance for Priority Populations, Particularly Racial/Ethnic Minorities and Older Adults

In the 2003 to 2010 NHANES survey, persons 40 to 49 years of age (OR 6.0, 95% CI, 3.2 to 11.1) and those 50 to 59 years of age (OR 9.5, 95% CI, 5.3 to 16.8) were more likely to have HCV infection than persons 20 to 39 years of age.^18^ Subgroup analyses from trials of currently recommended DAA therapies indicate similar effectiveness in older (over 55 or over 65 years of age) versus younger adults (Table 13). Older patients who acquired HCV infection as a young adult are more likely to have more advanced disease due to longer duration of infection, and the HCV-related mortality rate is highest in persons 55 to 74 years of age. Therefore, antiviral therapy may have greater impact on clinical outcomes in older patients.^273^

Subgroup analyses from trials of current DAA therapies also indicate similar effectiveness among different racial and ethnic groups. An analysis of the national VA ERCHIVES database (n=21,095) that did not meet inclusion criteria found that SVR rates with DAA regimens were similar in black patients (90%), Hispanic patients (86%), white patients (90%), and Asian/Pacific Islander/American Indian/Alaska Native patients (91%).^271^ However, black patients and Hispanic patients were less likely to achieve SVR than white patients after adjusting for baseline characteristics (OR 0.77, p<0.001 and OR 0.76, p<0.007, respectively).

Most trials of DAA therapies have excluded persons with current drug use or those receiving treatment for opioid use disorder. However, five trials included in this report of persons with current or recent use of methadone or buprenorphine for opioid use disorder reported SVR rates that ranged from 90 to 100 percent.^149,150,167,192^ This is consistent with a systematic review that included observational studies, which found a pooled SVR rate of DAA treatment of almost 90 percent among patients with current or recent injection drug use.^274^ A systematic review of 57 studies found a 5-year HCV reinfection rate of 10.67 percent in PWID following SVR, compared with 0.95 percent in non-PWID, indicating the need for followup after treatment in this population.^275^ Current guidelines do not consider ongoing injection drug use a contraindication to DAA therapy.^74^

Although DAA therapy appears similarly effective in adolescents and adults, only three antiviral therapies (ledipasvir / sofosbuvir, sofosbuvir / ribavirin, and glecaprevir / pibrentasvir) are FDA-approved for use in adolescents. Though DAA treatment options in this population are currently limited, a number of trials of DAA regimens in adolescents are ongoing.^276^

Antiviral therapy is currently not recommended in pregnancy. However, prenatal screening could identify HCV-infected women who could benefit from treatment following pregnancy, facilitate testing of infants, and potentially prevent HCV transmission during subsequent pregnancies. Identification of HCV-infected women prior to pregnancy in order to initiate antiviral therapy could be a strategy to reduce risk of mother-to-child transmission, but has not yet been studied.

## Future Research

Research is needed to better understand the association between use of current DAA therapy and clinical outcomes. Long-term randomized trials of treatment versus no treatment would be ethically challenging and difficult to carry out. Rather, large cohort studies that measure important confounders could be highly informative for addressing this question. Trials and cohort studies that measure effects on quality of life, function, and extrahepatic effects of HCV infection (e.g., renal function, cardiovascular effects, or diabetes) would also be helpful for understanding effects of DAA regimens on shorter-term clinical outcomes. Studies on the association between SVR after DAA therapy and clinical outcomes would help to verify the link between SVR and clinical outcomes with current therapies. Additional studies would be helpful for confirming the effectiveness of DAA regimens in adolescents and to identify additional regimens that could be used in this population.^276^ Studies are also needed to understand risks of HCV reinfection following DAA therapy and optimal treatment strategies. Research is also needed to identify labor management practices (e.g., prolonged rupture of membranes or use of internal fetal monitoring) and other strategies (e.g., identification and treatment of HCV infection prior to pregnancy) on risk of mother-to-child transmission. Well-designed prospective studies are needed to understand the effects of different HCV screening strategies, including repeat screening, on diagnostic yield.

## Conclusions

The USPSTF previously determined that HCV screening is highly accurate. Currently recommended all-oral DAA regimens are associated with very high SVR rates (95.5% to 98.9% across genotypes) and few harms relative to older antiviral therapies. An SVR after antiviral therapy is associated with improved clinical outcomes compared with no SVR after adjusting for potential confounders. Direct evidence on the benefits of HCV screening remains unavailable; direct evidence on the effects of antiviral therapy on clinical outcomes remains limited but indicates improved long-term outcomes.