# Chapter 3 Results

A total of 7,170 new references from electronic database searches and manual searches of recently published studies were reviewed, and 700 full-text papers were evaluated for inclusion. We included a total of 97 studies (reported in 94 publications). Eighty-four studies were newly identified as part of this update, and 13 were carried forward from the previous review. Included studies and quality ratings are described in Appendix B.

## Key Question 1a Does Screening for HCV Infection in Pregnant and Nonpregnant Adolescents and Adults Without Known Abnormal Liver Enzyme Levels Reduce HCV-Related Mortality and Morbidity or Affect Quality of Life?

As in the prior USPSTF review, no study directly assessed effects of HCV screening versus no screening on clinical outcomes such as HCV-related mortality and morbidity or quality of life.

## Key Question 1b Does Prenatal Screening for HCV Infection Reduce Risk of Vertical Transmission of HCV Infection?

As in the prior USPSTF review, no study assessed effects of prenatal HCV screening versus no screening on risk of vertical transmission of HCV infection.

## Key Question 2 What Is the Effectiveness of Different Risk- or Prevalence-Based Methods for Screening for HCV Infection on Clinical Outcomes?

As in the prior USPSTF review, no study directly assessed the effectiveness of different risk- or prevalence-based methods for HCV screening on clinical outcomes.

## Key Question 3 What Is the Yield (Number of New Diagnoses per Tests Performed) of One-Time vs. Repeat Screening or Alternative Screening Strategies for HCV Infection, and How Does the Screening Yield Vary in Different Risk Groups?

### Summary

- The prior USPSTF review included five studies that found screening strategies that targeted multiple risk factors associated with sensitivities of more than 90 percent and numbers needed to screen to identify one case of HCV infection of less than 20. More narrowly targeted screening strategies were associated with numbers needed to screen of less than two, but missed up to two-thirds of infected patients.
- One new study found that applying risk-based guidelines perfectly would result in 24.7 percent of the population tested and 82 percent of HCV cases identified (number needed to screen 14.6), compared with 45 percent of the population tested and 76 percent of HCV cases identified with birth cohort screening (number needed to screen 28.7), but assumed perfect implementation of risk-based testing.

### Evidence

The prior USPSTF review included five poor quality studies^94–98^ that found screening strategies that targeted multiple risk factors associated with sensitivities of more than 90 percent and numbers needed to screen to identify one case of HCV infection of less than 20.^2^ More narrowly targeted screening strategies were associated with numbers needed to screen of less than two, but missed up to two-thirds of infected patients.

One new study that retrospectively applied screening criteria to patients in the 2003 to 2006 National Health and Nutrition Examination Survey (NHANES) database compared the yield of risk-based HCV screening (based on then-current AASLD guidelines) versus birth cohort screening.^99^ It found that applying risk-based guidelines perfectly would result in 24.7 percent of the general population tested and identify 82 percent of the HCV exposed population, with a number needed to screen to identify one case of HCV infection of 14.6. Applying the birth cohort strategy would result in 45 percent of the general population tested and identify 76 percent of the HCV exposed population, with a number needed to screen to identify one case of 28.7. Although this analysis suggests that the two strategies would identify a similar proportion of HCV infected persons, it would require perfect implementation of risk-based testing, which has not occurred in actual practice.

No study evaluated the yield of one-time versus repeat screening, the yield of alternative screening strategies in different risk groups, or the yield of currently recommended screening (i.e., 1945 to 1965 birth cohort plus risk-based screening) versus expanded screening strategies. Studies that modeled effects of alternative screening strategies are addressed in Contextual Question 2.

## Key Question 4 What Are the Harms of Screening for HCV Infection (e.g., Anxiety and Labeling)?

The prior USPSTF review included five studies^31,100–103^ of persons with HCV infection that suggested potential negative psychological and social effects of screening, but the quality of evidence was assessed as poor due to small sample sizes and methodological shortcomings, included no unscreened comparison group, reliance on retrospective recall, and poorly defined outcomes.^2^ All of the studies were conducted in the context of treatment with older interferon-containing regimens. No new study meeting inclusion criteria evaluated harms associated with HCV screening.

## Key Question 5 What Are the Effects of Interventions During Labor and Delivery or the Perinatal Period on Risk of Vertical Transmission of HCV Infection?

### Summary

- Five observational studies (four included in the prior USPSTF review) found no clear association between the mode of delivery and risk of mother-to-infant transmission of HCV infection, after adjustment for potential confounders.
- One observational study included in the prior USPSTF review found prolonged (longer than 6 hours) rupture of membranes associated with increased risk for HCV transmission versus less prolonged (6 hours or less) rupture after adjusting for maternal demographic characteristics, HCV RNA level, intravenous drug use, and smoking status during pregnancy (adjusted OR 9.3, 95% CI, 1.5 to 180).^104^ No new study evaluated this association.
- One observational study included in the prior USPSTF review found internal fetal monitoring associated with increased risk of mother-to-infant transmission of HCV infection versus external monitoring, after adjustment for maternal demographic characteristics, HCV viral load, intravenous drug use history, and smoking status in pregnancy (adjusted OR 6.7, 95% CI, 1.1 to 35.9).^104^ No new study evaluated this association.
- Three observational studies (two included in the prior USPSTF review) found no clear association between breastfeeding and risk of mother-to-infant transmission of HCV infection after adjustment for potential confounders; in the two good quality studies adjusted OR estimates were close to 1.^105–107^

### Evidence

#### Mode of Delivery

The prior USPSTF review^2^ included 14 observational studies in 16 publications (sample sizes of 56 to 1,034 mother-infant pairs) that found no clear association between the mode of delivery (vaginal vs. cesarean delivery) and risk of mother-to-infant transmission of HCV.^104–106,108–120^ Twelve studies found no statistically significant association between the mode of delivery and risk of HCV transmission;^104–106,109–112,114–120^ most estimates were imprecise, and findings were inconsistent, with point estimates that favored vaginal delivery in some studies and cesarean delivery in others. Most of the studies included in the prior review did not meet inclusion criteria for the current review: eight were rated poor quality^109,111–113,116–120^ and ten did not conduct multivariate analyses.^109–120^ No study reported baseline characteristics according to mode of delivery or matched women on key potential confounders.

Restricting inclusion to the four studies (total 1,717 mother-infant pairs) in the prior review that met current inclusion criteria (fair or good quality and multivariate analysis performed) resulted in a similar conclusion of no clear association between the mode of delivery and risk of HCV transmission (Table 6, Appendix B Table 1).^104–106,108^ One of the studies was conducted in the United States^104^ and the other three in Europe. Although one fair quality study (424 mother-infant pairs) found elective cesarean associated with decreased risk of HCV transmission versus vaginal delivery or emergent (after onset of labor) cesarean after adjusting for HIV status and breastfeeding (adjusted OR 0.0, 95% CI, 0.0 to 0.87),^105^ the other three studies, including two good quality studies,^104,106^ found no association between the mode of delivery and HCV transmission risk. One good quality study (1,034 mother-infant pairs) found no statistically significant association between the mode of delivery and risk of HCV transmission, though there was a trend towards higher risk with elective cesarean versus vaginal or emergent (after onset of labor) cesarean, after adjusting for infant sex, prematurity, and breastfeeding status (adjusted OR 1.59, 95% CI, 0.88 to 2.86),^106^ and another good quality study (181 mother-infant pairs) found no association between the mode of delivery (elective cesarean, emergent cesarean or vaginal) and risk of mother-to-infant transmission in univariate analysis; mode of delivery was excluded from the multivariate model.^104^ The fourth, fair quality study (78 mother-infant pairs) found no association between cesarean (not specified as elective or emergent) versus vaginal delivery and risk of transmission (data not reported).^108^

Table 6 Mode of Delivery and Mother-to-Infant Transmission of HCV Infection

Author year Quality | N | Elective Cesarean or Cesarean not specified | Vaginal/Emergent Cesarean | Comments/Results; (95% CI)
Ceci 2001^108^; Fair | 78^*^ | No association (data NR) | No association (data NR) | No significant association in multivariate analysis (data NR)
Gibb 2000^105^; Fair | 424^†^ | 0/31 (0%) | 29/393 (7.4%) | OR 0 (0 to 0.87), p=0.04, adjusted for HIV status and breastfeeding
Mast 2005^104^; Good | 188^*^ | 0/12 (0%) | 7/169 (4.1%) | RR 0.87 (0.05 to 14); Excluded from multivariate analyses due to lack of significance in univariate analysis
Resti 2002^107^; Good | 1,301^‡^ | 22/337 (5.8%) | 73/924 (7.9%) | OR for vaginal delivery 1.17 (0.92 to 1.41), unadjusted^§^; OR for vaginal delivery 1.20 (0.93 to1.55), adjusted for maternal HCV RNA status, maternal HIV status, injection drug use, type of feeding^§^
Tovo 2005^106^; EPHN; Good | 1,034^*^ | NR | NR | OR 1.57 (0.88 to 2.83), p=0.13, unadjusted; OR 1.59 (0.88 to 2.86), p=0.13 adjusted for sex, mode of delivery, prematurity, and breastfeeding
Total | 3,025 | -- | -- | --

* 0% HIV coinfected.

† 5% HIV coinfected.

‡ 14% HIV coinfected.

§ Study appears to have reversed reference standard; Calculation to adjust reference standard gives unadjusted OR for vaginal delivery (ref): 0.85 (0.71 to 1.09); Adjusted OR for vaginal delivery (ref): 0.83 (0.65 to 1.08).

Abbreviations: CI = confidence interval; EPHN = European Paediatric Hepatitis C Virus Network; HCV = hepatitis C virus; NR = not reported; OR = odds ratio; RR = relative risk.

One additional Italian study (1,301 mother-infant pairs) not included in the prior USPSTF review also found no statistically significant association between the mode of delivery (cesarean vs. vaginal delivery) and risk of mother-to-infant transmission of HCV infection (adjusted OR 0.83, 95% CI, 0.65 to 1.08). Cesarean deliveries were not specified as elective or emergent^107^ (Table 6, Appendix B Tables 1-3). The study was rated good quality (Table 6; Appendix B Table 4).

#### Rupture of Membranes

Evidence on the association between duration of rupture of membranes during labor and risk of HCV transmission is limited. The prior USPSTF review included one good quality United States cohort study (189 mother-infant pairs) that found prolonged rupture (longer than 6 hours) of membranes associated with increased risk for HCV transmission versus less prolonged rupture (6 hours or less) after adjusting for maternal demographic characteristics, HCV RNA level, intravenous drug use, and smoking status during pregnancy (adjusted OR 9.3, 95% CI, 1.5 to 180)^104^ (Table 7; Appendix B Tables 1-3). However, there were only 7 cases of perinatal HCV infection, and the estimate was very imprecise. A smaller (63 mother-infant pairs) Australian study^116^ included in the prior USPSTF review found that mean duration of membrane rupture was longer in mothers in whom HCV transmission occurred compared with those in whom transmission did not occur, but did not meet current inclusion criteria because it did not attempt to adjust for potential confounders and was rated poor quality. We identified no new studies on the association between the duration of rupture of membranes and risk of HCV transmission that met inclusion criteria.

Table 7 Duration of Membrane Rupture and Mother-to-Infant Transmission of HCV Infection

Author year Quality | N | Duration of Membrane Rupture (hours) | Comments/Results; (95% CI)
Mast 2005^104^; Good | 189^*^ | <1 vs. 1 to 5 vs. 6 to 12 vs. ≥13: 0/53 vs. 1/59 (1.7%) vs. 4/40 (10%) vs. 2/30 (6.7%), p=0.02 | Membrane rupture >6 hours; OR, 9.3 (1.5 to 179.7), adjusted for maternal demographic characteristics, HCV RNA level, fetal monitoring, history of IVDU, and cigarette smoking during pregnancy.
Total | 189 | -- | --

* 0% HIV coinfected.

Abbreviations: CI = confidence interval; HCV = hepatitis c virus; IVDU = intravenous drug use; OR = odds ratio; RNA = ribonucleic acid.

#### Fetal Monitoring

Evidence on the association between use of fetal monitoring methods during labor and risk of HCV transmission is limited. The prior USPSTF review included one good quality U.S.-based study (188 mother-infant pairs) that found internal fetal monitoring associated with increased risk of mother-to-infant transmission of HCV infection versus external monitoring, after adjustment for maternal demographic characteristics, HCV viral load, intravenous drug use history, and smoking status in pregnancy (adjusted OR 6.7, 95% CI, 1.1 to 35.9)^104^ (Table 8; Appendix B Tables 1-3). However, there were only 7 cases of perinatal HCV infection and the estimate was imprecise. Although the prior USPSTF review included two other studies on the association between fetal monitoring and risk of HCV transmission, neither met current inclusion criteria because they did not report adjusted risk estimates.^112,114^ One of the studies^112^ did not compare internal fetal monitoring to no internal monitoring and the other study^114^ found no association between internal fetal monitoring and transmission risk (relative risk [RR] 1.24, 95% CI, 0.70 to 2.2). We identified no new studies on the association between the use of fetal monitoring methods and risk of HCV transmission that met inclusion criteria.

Table 8 Fetal Monitoring and Risk of Mother-to-Infant Transmission of HCV Infection

Author year; Quality | N | Fetal Monitoring During Delivery | Comments/Results; (95% CI)
Mast 2005^104^; Good | 188^*^ | Internal vs. external: 3/16 (18.8%) vs. 4/165 (2.4%), | RR 7.7 (1.9 to 31.6), p=0.02, unadjusted; Internal fetal monitoring, OR 6.7 (1.1 to 35.9), adjusted for maternal demographic characteristics, HCV RNA level, history of IVDU, and cigarette smoking during pregnancy.
Total | 188 | -- | --

* 0% HIV coinfected.

Abbreviations: CI = confidence interval; IVDU = intravenous drug use; HCV = hepatitis C virus; OR = odds ratio; RNA = ribonucleic acid; RR = relative risk.

#### Breastfeeding

The prior USPSTF review^2^ included 14 observational studies^104–106,109,111,115–124^ (total of 2,971 mother-infant pairs) that found no association between breastfeeding by women infected with HCV and risk of transmission to infants. No study reported a statistically significant association, though some estimates were very imprecise due to few cases of HCV transmission. Most of the studies included in the prior review did not meet inclusion criteria for the current review: ten were rated poor quality,^108–114,116–120^ and twelve did not conduct multivariate analyses.^104,108–120^

Restricting the analysis to the two studies^105,106^ in the prior review that meet current inclusion criteria (fair or good quality and multivariate analysis performed) resulted in a similar conclusion of no association between breastfeeding and risk of HCV transmission (Table 9; Appendix B Tables 1-3).^104–106,108^ One large (1,034 mother-infant pairs) European study found no association between breastfeeding by HCV-infected women without HIV infection and risk of HCV transmission to infants (followed until at least 18 months of age), after adjusting for infant sex, prematurity, and mode of delivery (adjusted OR 0.92, 95% CI, 0.50 to 1.70). A fair quality European study (414 mother-infant pairs) also found no association between breastfeeding and risk of HCV transmission to infants (duration of followup 24 months), after adjusting for HIV status (5% of mothers were HIV-infected) and mode of delivery (adjusted OR 1.52, 95% CI, 0.35 to 5.12). Although the point estimate was consistent with increased risk associated with breastfeeding, the estimate was imprecise.

Table 9 Breastfeeding and Risk of Mother-to-Infant Transmission of HCV Infection

Author year; Quality | N | Breast Fed | Formula Fed | Comments/Results; (95% CI)
Gibb 2000^105^; Fair | 414^*^ | 7.7% (2.2 to 17.8) | 6.7% (3.7 to 10.6) | OR 1.52 (0.35 to 5.12), adjusted for HIV status and mode of delivery
Resti 2002^107^; Good | 1,281^†^ | 22/360 (6.1%) | 73/921 (7.9%) | OR 0.86 (0.61 to 1.10); OR 0.95 (0.58 to 1.40), adjusted for maternal HCV RNA status, maternal HIV-1 status, maternal IVDU, type of feeding, mode of delivery
Tovo 2005^106^; EPHN; Good | 1,034^‡^ | NR | NR | OR 0.88 (0.48 to 1.61), unadjusted; OR 0.92 (0.50 to 1.70), adjusted for sex, prematurity, and mode of delivery
Total | 3,645 | -- | -- | --

* 5% HIV coinfected.

† 14% HIV coinfected.

‡ 0% HIV coinfected.

Abbreviations: CI = confidence interval; EPHN = European Paediatric Hepatitis C Virus Network; HCV = hepatitis C virus; IVDU = intravenous drug use; NR = not reported; OR = odds ratio; RNA = ribonucleic acid.

One additional good quality Italian cohort study^107^ (1,281 mother-infant pairs) not included in the prior systematic review also found no association between breastfeeding and risk of HCV transmission to infants, after adjusting for maternal HCV viral load, HIV status (14% of mothers were HIV-infected), injection drug use, and mode of delivery (adjusted OR 0.95, 95% CI, 0.58 to 1.40) (Table 9; Appendix B Tables 1-4). Duration of followup was 24 months.

## Key Question 6 What Is the Effectiveness of Currently Recommended Antiviral Treatments in Improving Health Outcomes in Patients With HCV Infection?

### Summary

#### Adults

- The prior review included no randomized trials or observational studies on the effects of then-current antiviral regimens on long-term (e.g., more than 2 years) clinical outcomes; no new randomized trial evaluated effects of current DAA regimens on long-term clinical outcomes.
- Ten new trials reported quality of life and functional outcomes before and after treatment with a current DAA regimen.
  ○ A pooled analysis of four trials found sofosbuvir / velpatasvir associated with an average improvement of 5.5 to 6.1 points (0 to 100 scale) on 26 measures related to quality of life or function at 24 weeks (12 weeks post-treatment) in persons without cirrhosis.
  ○ A pooled analysis of three trials found sofosbuvir / ledipasvir associated with small but statistically significant improvements from baseline to 24 weeks (12 weeks post-treatment) on multiple quality of life and functional domains in persons with no to mild fibrosis at baseline.
  ○ Three trials of DAA regimens not included in the pooled analyses (two trials of ombitasvir / paritaprevir / ritonavir / dasabuvir and one trial of elbasvir / grazoprevir) found DAA use associated with small changes from baseline to 12 weeks post-treatment on the 36-Item Short Form Health Survey (SF-36) physical (improvement 0.5 to 1.4 points) or mental component (improvement 2.5 to 3.0 points) summary scales (0 to 100 scale).
- Thirty-one trials reported mortality 12 to 36 weeks following completion of therapy with a DAA regimen. Twenty-one trials reported no deaths; in the other ten trials, there were 17 deaths (0.4% [17/3,848] overall).
- Three large (n=34,206; 17,836; and 6,850) cohort studies evaluated the association between use of DAA regimens, interferon-based treatment, and no antiviral therapy and risk of cardiovascular events and HCC.
  ○ One retrospective study (n=34,206) found DAA therapy and interferon-based therapy each associated with similarly decreased risk of cardiovascular events relative to no therapy (incidence per 1,000 person-years 16.3 for DAA therapy, 23.5 for interferon-based therapy, and 30.4 for no therapy; p<0.001 for DAA therapy or interferon-based therapy vs. no therapy).
  ○ One study (n=17,836) found no difference between interferon-based treatment versus DAA therapy in risk of HCC (incidence rate per 1,000 person-years of followup 7.48 vs. 7.92; p=0.72); both regimens were associated with lower incidence of HCC than no therapy.
  ○ One study (n=6,850) found no difference between DAA therapy versus no antiviral therapy and risk of HCC (adjusted HR 1.02, 95% CI, 0.40 to 2.61) among persons without known cirrhosis at baseline after 33 months followup; effects on all-cause mortality favored DAA therapy, but the difference was not statistically significant (adjusted HR 0.74, 95% CI, 0.43 to 1.28).

#### Adolescents

- Three trials of DAA therapy in adolescents found quality of life improved from baseline based on Pediatric Quality of Life Inventory scores.
- Three short-term trials of DAA regimens in adolescents reported no deaths.

### Evidence

#### Adults

The prior review identified no randomized trials or observational studies on the effects of then-current antiviral regimens (triple therapy with telaprevir or boceprevir, pegylated interferon, and ribavirin or dual therapy with pegylated interferon and ribavirin) for chronic HCV infection on long-term (more than 2 year) clinical outcomes.^5,90^ Two trials in the prior review reported short-term mortality with triple therapy versus dual therapy, but events were few and estimates were imprecise, with no clear differences.^125,126^ There were a total of 9 deaths in over 1,700 persons across the two trials.

No new randomized trial evaluated effects of current DAA regimens on long-term clinical outcomes. Randomized trials of older (non-DAA) antiviral therapy versus no antiviral therapy that evaluated long-term clinical outcomes did not meet inclusion criteria because they enrolled persons with cirrhosis at baseline,^127–132^ utilized non-standard therapy (indefinite treatment with interferon),^133^ or were rated poor quality (not clearly randomized).^134^

Ten trials reported quality of life and functional outcomes before and after receipt of current DAA regimens; seven trials were included in two pooled analyses^135,136^ and three additional trials (reported in 2 publications) not in the pooled analyses also reported these outcomes (Appendix B Tables 5, 10 and 11).^137,138^ One trial of sofosbuvir / velpatasvir that reported quality of life and functional outcomes was included in a pooled analysis and is not reported separately here.^139,140^ The trials were all open-label and none reported comparisons of DAA therapy versus placebo or non-DAA therapy.

Thirty-one trials (in 28 publications)^139,141–167^ reported short-term mortality with current DAA regimens (Appendix B Tables 10 and 11). A multicenter prospective cohort study conducted in France^168^ and two retrospective cohort studies^169,170^ based on a national Veterans Affairs (VA) database, Electronically Retrieved Cohort of HCV Infected Veterans (ERCHIVES), evaluated the association between treatment with a DAA regimen versus no treatment and other clinical outcomes (cardiovascular outcomes and HCC) after adjusting for potential confounders (Appendix B Table 5).

##### Quality of Life and Function

Ten trials reported quality of life and functional outcomes before and after treatment with a current DAA regimen (Appendix B Tables 5, 10, and 11). Seven trials were included in two post-hoc pooled analyses: one analysis^135^ included three trials (n=1,005) of sofosbuvir / ledipasvir and one analysis^136^ included four trials (n=1,701) of sofosbuvir / velpatasvir. The trials varied with regard to whether antiviral therapy was administered with or without ribavirin. Two additional trials (reported in 1 publication, n=309 and 148) of ombitasvir / paritaprevir / ritonavir / dasabuvir (with or without ribavirin)^137^ and one additional trial of elbasvir / grazoprevir (n=129) also reported quality of life or function.^138^ All studies used an open-label design, and the quality of life and functional measures assessed in the trials differed. In addition, the trials included in the pooled analyses lacked a non-DAA regimen comparison group.

A pooled analysis of four trials found sofosbuvir / velpatasvir associated with an average improvement of 5.5 to 6.1 points on 26 measures related to quality of life or function at 24 weeks (12 weeks post-treatment) in persons without cirrhosis.^136^ Changes from baseline were not statistically significant. Findings were similar when the regimen was administered with or without ribavirin. The average improvement was based on 26 outcomes derived from the SF-36, the Functional Assessment of Chronic Illness Therapy-Fatigue (FACIT-F), the Chronic Liver Disease Questionnaire-HCV version (CLDQ-HCV), and the Work Productivity Activity Index: Specific Health Problem (WPAI-SHP) measures, standardized to a 0 to 100 scale.

A pooled analysis of three trials found sofosbuvir / ledipasvir associated with statistically significant improvements from baseline to 24 weeks (12 weeks post-treatment) on multiple quality of life and functional domains in persons with no to mild fibrosis at baseline.^135^ Estimates were similar when sofosbuvir / ledipasvir was administered with or without ribavirin. Mean differences were less than 3 points on the 0 to 100 SF-36 physical and mental component summary scales, 10 to 11 points on the 0 to 160 FACIT-F scale, 0.5 to 0.6 points on the CLDQ-HCV, less than 0.1 point on the 0 to 1 WPAI-SHP scales, and 0.04 to 0.05 points on the six-dimensional health state short-form (SF-6D) health utility scale; the latter measure was derived from the SF-36 instrument.

Three trials not included in pooled analyses also reported small improvements in some measures of quality of life or function.^137,138^ Two trials found ombitasvir / paritaprevir / ritonavir / dasabuvir associated with small changes from baseline to 12 weeks post-treatment on the SF-36 physical (improvement 0.5 to 1.4 points) or mental component (improvement 2.5 to 3.0 points) summary scales.^137^ Estimates were similar when the regimen was administered with or without ribavirin and among treatment-naïve and -experienced patients. In both trials, there were no statistically significant differences between the DAA regimen versus telaprevir / pegylated interferon / ribavirin on the SF-36 (differences ‒1.1 to ‒1.5 points on the mental component and ‒1.3 to +0.9 points on the physical component summary scales). Changes from baseline following treatment with ombitasvir / paritaprevir / ritonavir / dasabuvir on the WPAI-SHP scale were also very small. Another trial found elbasvir / grazoprevir use associated with small but statistically significant improvements from baseline in SF-36 mental and physical component scores (mean change of 2 points each).^138^ There was no effect of elbasvir / grazoprevir on patient fatigue, based on FACIT-F scale score.

##### Mortality

Thirty-one trials (in 28 publications; n=21 to 558; total N=3,848) reported mortality 12 to 36 weeks following completion of therapy with a DAA regimen (Appendix B Tables 10 and 11).^139,141–167^ The trials were not designed or powered to assess mortality, and 21 studies reported no deaths. There were 17 deaths in the remaining ten studies (0.4% overall). The regimens evaluated in these trials were sofosbuvir / velpatasvir (8 deaths in 884 patients; 0.9%),^139,146,147,150^ ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (4 deaths in 187 patients; 2%),^149,162^ grazoprevir / elbasvir (2 deaths in 732 patients; 0.3%),^164,166^ glecaprevir / pibrentasvir (2 deaths in 1,172 patients; 0.2%),^167^ and sofosbuvir / daclatasvir (one death in 115 patients; 0.9%).^167^ Ten of the 17 deaths were reported in three trials that enrolled persons reporting recent injection drug use (26% to 66% at baseline) or use of opioid substitution therapy (3% to 85% at baseline).^149,150,167^

##### Other Clinical Outcomes

Three large, fair-quality cohort studies evaluated the association between antiviral treatment versus no treatment and clinical outcomes (cardiovascular events, HCC, or all-cause mortality).^168–170^ Two studies^169,170^ were conducted using the VA ERCHIVES database, and one study^168^ was conducted in France.

Two large (n=17,836 and 34,206), retrospective analyses of VA patients evaluated the association between use of DAA regimens, interferon-based treatment, and no antiviral therapy and risk of cardiovascular events and HCC (Appendix B Tables 5 and 6).^169,170^ The studies included primarily male (3 to 4% female), HCV-infected veterans. Mean age ranged from 54 to 62 years; approximately 20 percent of the population had cirrhosis at baseline. One study found DAA therapy and interferon-based therapy each associated with decreased risk of cardiovascular events, including acute myocardial infarction, congestive heart failure, and stroke (incidence rate per 1,000 person-years of followup: 16.3 for DAA therapy, 23.5 for interferon-based therapy, and 30.4 for no therapy; p<0.001 for DAA therapy vs. no therapy and for interferon-based therapy vs. no therapy).^169^ The proportion of patients with at least 5 years followup was 82% for interferon-based therapy, 3.7% for DAA therapy, and 43% for no therapy (mean followup not reported). The other study found no difference between interferon-based treatment versus DAA therapy in risk of HCC (incidence rate per 1,000 person-years of followup 7.48 vs. 7.92; p=0.72).^170^ Both types of antiviral therapy regimens were associated with lower incidence of HCC than no therapy (incidence rate per 1,000 person years 10.90). The mean duration of followup was 7.4 years for persons treated with interferon-based therapy and 1.1 years for persons treated with DAA therapy (mean not reported for untreated patients).

A third, smaller (n=6,850) study conducted in France found no difference between DAA therapy versus no antiviral therapy in risk of HCC (adjusted HR 1.02, 95% CI, 0.40 to 2.61) in persons not known to have cirrhosis at baseline after a median of 33 months followup.^168^ Effects on all-cause mortality favored DAA therapy, but the difference was not statistically significant (adjusted HR 0.74, 95% CI, 0.43 to 1.28). There were too few events to estimate effects on liver-related mortality or decompensated cirrhosis. Some differences between this analysis and the VA studies described above include availability of results for the subgroup of persons without cirrhosis at baseline, a much higher proportion of female patients (approximately 50%), restriction to DAA therapy, prospective design, and similar duration of followup in treated and untreated patients.

No study evaluated effects of treatment with DAA regimens on risk of HCV transmission.

#### Adolescents

Data on health outcomes associated with DAA regimens in adolescents is available from one fair quality, open-label trial^171^ and post-hoc, before-after analyses of two other fair quality trials (Appendix B Tables 7 and 8).^172,173^ The studies included a total of 200 patients, mean age was 14 to 15 years, the proportion of females ranged from 40 to 63 percent, and patients did not have known cirrhosis. The studies utilized ledipasvir and sofosbuvir in adolescents with genotype 1 infection,^172^ sofosbuvir and ribavirin in adolescents with genotype 2 or 3 infection,^173^ and glecaprevir / pibrentasvir in patients with genotype 1, 2, 3 or 4 infection.^171^ Quality of life was assessed based on change from baseline on the Pediatric Quality of Life Inventory.^174^ The Pediatric Quality of Life Inventory comprises four domains: Physical, Emotional, Social and School Functioning, and the total score is determined by averaging the scores from each of the four domains. In adolescents with genotype 1 infection treated with ledipasvir and sofosbuvir, caregiver-reported total quality of life scores were significantly improved from baseline at 24 weeks post-treatment (0-100 scale; mean change 5.2 points; p=0.009). However, there was no significant change in patients’ self-reported total scores (mean change 1.9 points; p=0.12). Only the Emotional Functioning domain was rated as significantly improved from baseline by both caregivers (mean change 9.32 points, p<0.001) and patients (mean change 3.66, p=0.04).^172^ In adolescents with genotype 2 or 3 infection treated with sofosbuvir and ribavirin, scores improved on the self-reported Social Functioning score by 4.8 points (p=0.02) and on the parent-proxy-reported School Functioning score by 13.0 points (p=0.0065). Adolescents treated with glecaprevir / pibrentasvir also experienced a small improvement in total quality of life score (mean change 2.3 points) though the statistical significance (p-value not reported) and timing of the assessment in this study is unclear.

Three studies of DAA regimens (sample sizes 30 to 100; total N=182) reported no deaths, but were not designed to assess long-term clinical outcomes (duration of followup ≤48 weeks; Appendix B Tables 7 and 8). Two of the studies evaluated DAA regimens FDA-approved for use in adolescents (ledipasvir and sofosbuvir^175^ and sofosbuvir and ribavirin^173^) and one study evaluated a DAA regimen currently recommended for use in adults but not FDA-approved for use in adolescents (sofosbuvir and daclatasvir^176^).

## Key Question 7 What Is the Effectiveness of Currently Recommended Antiviral Treatments in Achieving a SVR in Patients With HCV Infection?

### Summary

#### Adults

- The prior review found triple therapy with telaprevir or boceprevir associated with higher likelihood of SVR than dual therapy with pegylated interferon and ribavirin in persons with genotype 1 infection. SVR rates were 68 percent to 72 percent with triple therapy and 38 percent to 46 percent with dual therapy.
- One new randomized trial found sofosbuvir / velpatasvir associated with very high likelihood of SVR versus placebo in persons with mixed genotype (1, 2, 4, 5, or 6) infection (99% vs. 0%, RR 231.6, 95% CI, 14.6 to 3,680).^139^ Across genotypes, the SVR rate with sofosbuvir / velpatasvir ranged from 97 percent to 100 percent.
- Two new randomized trials found ombitasvir / paritaprevir / ritonavir / dasabuvir (with or without ribavirin) associated with increased likelihood of SVR versus telaprevir / pegylated interferon / ribavirin in persons with genotype 1 infection who were treatment-naïve (98% vs. 80%, RR 1.22, 95% CI, 1.08 to 1.37) or who had previously received interferon therapy (99% vs. 66%, RR 1.50, 95% CI, 1.22 to 1.85).^137^
- Forty-nine new trials found current DAA regimens associated with pooled SVR rates that ranged from 95.5 percent to 98.9 percent:
  ○ Genotype 1 infection (32 trials): Pooled SVR 97.7 percent (95% CI, 96.6% to 98.4%, I^2^=82%)
  ○ Genotype 2 infection (5 trials): Pooled SVR 98.9 percent (95% CI, 97.5% to 99.5%, I^2^=4%)
  ○ Genotype 3 infection (6 trials): Pooled SVR 95.5 percent (95% CI, 91.6% to 97.7%; I^2^=66%)
  ○ Genotype 4 infection (10 trials): Pooled SVR 98.2 percent (95% CI, 94.7% to 99.4%; I^2^=50%)
  ○ Genotype 5 infection (4 trials): Pooled SVR 96.0 percent (95% CI, 88.3% to 98.7%; I^2^=0%)
  ○ Genotype 6 infection (5 trials): Pooled SVR 98.2 percent (95% CI, 95.4% to 99.3%, I^2^=0%).
  ○ Mixed genotype 1 to 6 (2 trials): Pooled SVR 95.4% (95% CI, 89.4% to 98.1%; I^2^=0%).
- SVR estimates were consistent in analyses stratified by DAA regimen, study quality, inclusion of persons with cirrhosis at baseline, and geographic setting; and when analyses were restricted to trials that utilized ribavirin as recommended or to treatment-naïve patients.
- SVR estimates were similar in trials that stratified patients according to age (17 trials, primarily using a 55- or 65-year threshold), sex (17 trials), race or ethnicity (11 trials), or treatment-experience (five trials).

#### Adolescents

- Seven new trials (total N=348) reported SVR rates of 97 percent to 100 percent with DAA regimens in adolescents with HCV infection.
  ○ Four trials evaluated DAA regimens currently recommended and FDA-approved for use in adolescents (ledipasvir / sofosbuvir, sofosbuvir / ribavirin or glecaprevir / pibrentasvir) and three trials evaluated DAA regimens currently recommended for adults but not FDA-approved for use in adolescents.
  ○ Results were consistent across genotypes and in treatment-naïve and -experienced patients.

### Evidence

#### Adults

The prior review found higher SVR rates in persons with HCV genotype 1 infection treated with triple therapy with telaprevir or boceprevir plus pegylated interferon and ribavirin than with dual therapy with pegylated interferon and ribavirin.^5,90^ Findings were consistent for a 48-week boceprevir regimen (2 trials, SVR rates 70% vs. 38%, RR 1.8, 95% CI, 1.6 to 2.1),^126,177^ a 24-week, fixed-duration telaprevir regimen (3 trials, SVR rates 68% vs. 46%, RR 1.5, 95% CI, 1.3 to 1.8),^178–180^ and a 24- or 48-week, response-guided telaprevir regimen (1 trial, SVR rate 72% vs. 44%, RR 1.6, 95% CI, 1.4 to 1.9).^125^ The prior review also included 5 trials of dual therapy with pegylated interferon and ribavirin for genotype 2 or 3 infection that reported pooled SVR rates of 78 percent (95% CI, 67% to 88%) for 24 weeks of treatment and 68 percent (56% to 78%) for 12 to 16 weeks of therapy.^181–184^ None of the studies in the prior review evaluated current DAA regimens.

Forty-nine new trials (in 44 publications) reported effects of current DAA treatment regimens on SVR in patients with HCV infection (Table 10; Appendix B Tables 10 and 11).^137,139,141–167,185–199^ Sample sizes ranged from 20 to 706 (total N=10,181), mean age ranged from 45 to 68 years, and the proportion of female participants ranged from 18 to 64 percent. Twenty-four trials (in 20 publications) were multinational (primarily United States, Australia and/or Europe),^137,139,143,144,149,150,155,158,160,164,166,167,185–189,191,196,198^ 11 (in 10 publications) were conducted in the United States and/or Canada,^146,147,153,154,157,161,190,192–194^ eight in Asia,^145,151,152,156,163,165,197,199^ two in France,^141,142^ two in Egypt,^162,195^ and one each in Brazil,^159^ and New Zealand.^148^ The eight trials conducted in Asia did not report race. In the other studies, among those that reported race, the majority of participants were white (range 60 to 100%)^139,141,142,146,147,153–155,157,158,160–162,166,185–188,190–194^ with the exception of one study conducted in New Zealand in which 16 percent of participants were white^148^ and one study conducted primarily in Asian countries in which 28% of participants were white.^164^ Twenty-one trials (in 19 publications) enrolled patients with genotype 1 infection,^137,145,149,151–156,159–161,163,167,185–188,190–194,197^ one trial genotype 2,^147,199^ three trials genotype 3,^147,157,158,167^ three trials genotype 4,^141,162,189,195,200^ one trial each for genotypes 5^142,143^ and 6,^143,148^ and nine trials mixed genotypes (three trials genotypes 1 through 6;^146,150,165^ one trial genotypes 1, 2, 4 and 6;^139^ two trials genotypes 2 through 6;^144,196^ two trials genotypes 1, 4 and 6;^166,198^ and one trial genotypes 1 and 4^164^). Thirty-one trials (in 28 publications) excluded patients with cirrhosis^137,144,146,147,154,155,159–162,167,186,188–194,196,197,199^ or reported results in the subgroup of patients without cirrhosis.^139,147,149,150,164,165,185,198^ For trials that enrolled patients with cirrhosis, inclusion was restricted to trials in which the proportion of patients with cirrhosis was less than 20 percent, with the exception of one trial of grazoprevir / elbasvir that had a slightly higher proportion (22%).^166^ All trials excluded patients with HBV infection. Five trials (in 4 publications) enrolled patients with a history of receiving methadone or buprenorphine for opioid use disorder.^149,150,167,192^ The other trials excluded patients with recent or current substance use or did not describe substance use.

Table 10 Trials of Sustained Virologic Response With Direct Acting Antiviral Regimens in Adults

Author year; Study name | Treatment Regimen | Primary genotype(s) | Mean age (years) | Proportion female gender | Proportion with cirrhosis | Proportion treatment-naïve | SVR
Chayama 2018^197^; CERTAIN-1 | Glecapravir + pibrentasvir | 1 | 64 | 64% | Unclear | 73% | 99% (128/129)
Poordad 2017^194^; MAGELLAN-1 | Glecapravir + pibrentasvir | 1 | 58 | 18% | 0% | 0% | 92% (46/50)
Zeuzem 2018^167^; ENDURANCE-1 | Glecapravir + pibrentasvir | 1 | 53 | 51% | 0% | 62% | 99% (663/667)
Kumada 2017^152^; (Part 2 only) | Grazoprevir + elbasvir | 1 | 61 | 62% | 0%^*^ | 66% | 97% (219/227)
Sulkowski 2015^160^; C-WORTHY | Grazoprevir + elbasvir | 1 | 51 | 51% | 0% | 100% | 95% (122/129)
Zeuzem 2015^166^; C-EDGE | Grazoprevir + elbasvir | 1 | 52 | 46% | 22% | 100% | 95% (273/288)
Kowdley 2014a^190^; ION-3 | Ledipasvir + sofosbuvir | 1 | 53 | 41% | 0% | 100% | 95% (408/431)
Afdhal 2014^185^; ION-1 | Ledipasvir + sofosbuvir | 1 | 52 | 41% | 0%^*^ | 100% | 100% (357/357)
Chuang 2016^145^ | Ledipasvir + sofosbuvir | 1 | 55 | 58% | 12% | 49% | 98% (83/85)
Lawitz 2014b^193^; LONESTAR | Ledipasvir + sofosbuvir | 1 | 48 | 38% | 0% | 100% | 97% (58/60)
Lim 2016^156^ | Ledipasvir + sofosbuvir | 1 | 54 | 61% | 9% | 100% | 100% (46/46)
Wei 2018^163^ | Ledipasvir + sofosbuvir | 1 | 47 | 50% | 16% | 52% | 100% (206/206)
Grebely 2018b^149^; D3FEAT | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1 | 48 | 23% | 0%^*^ | 100% | 91% (73/80)
Lalezari 2015^192^ | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1 | 48 | 34% | 0% | 95% | 97% (37/38)
Kwo 2016^153^; OPTIMIST-1 | Simeprevir + sofosbuvir | 1 | 56 | 47% | 0% | 74% | 97% (150/155)
Lawitz 2014a^154^; COSMOS | Simeprevir + sofosbuvir | 1 | 56 | 29% | 0% | 0% | 95% (61/64)
Pott-Junior 2019^159^ | Simeprevir + sofosbuvir | 1 | 53 | 48% | 0% | 60% | 93% (56/60)
Pott-Junior 2019^159^ | Sofosbuvir + daclatasvir | 1 | 56 | 52% | 0% | 60% | 100% (65/65)
Sulkowski 2014^161^; A1444040 Study | Sofosbuvir + daclatasvir | 1 | 55 | 50% | 13% | 100% | 98% (80/82)
Everson 2015^146^ | Sofosbuvir + velpatasvir | 1 | 49 | 39% | 0% | 100% | 100% (28/28)
Feld 2015^139^; ASTRAL-1 | Sofosbuvir + velpatasvir | 1 | 54 | 40% | 0%^*^ | 68% | 98% (251/255)
Ferenci 2014^188^; PEARL IV | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1a | 51 | 35% | 0% | 100% | 92% (282/305)
Kowdley 2014b^191^; AVIATOR | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1a | 50 | 42% | 0% | 75% | 86% (183/212)
Feld 2014^187^; SAPPHIRE-1 | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1a | 49 | 43% | Unclear | 100% | 95% (307/322)
Lawitz 2015^155^; PEARL-1 | Ombitasvir + paritaprevir + ritonavir | 1b | 55 | 51% | 0% | 51% | 93% (76/82)
Andreone 2014^186^; PEARL-II | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1b | 54 | 46% | 0% | 0% | 98% (176/179)
Feld, 2014^187^; SAPPHIRE-1 | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1b | 49 | 43% | Unclear | 100% | 98% (148/151)
Ferenci 2014^188^; PEARL III | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1b | 48 | 54% | 0% | 100% | 99% (416/419)
Kowdley 2014b^191^; AVIATOR | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 1b | 50 | 47% | 0% | 68% | 100% (113/113)
Kumada 2015^151^; GIFT-1 | Ombitasvir + paritaprevir + ritonavir | 1b | 61 | 63% | 0% | 65% | 94.9% (204/215)
Toyoda 2018^199^; CERTAIN-2 | Glecapravir + pibrentasvir | 2 | 57 | 53% | 0% | 83% | 98% (88/90)
Feld 2015^139^; ASTRAL-1 | Sofosbuvir + velpatasvir | 2 | 54 | 60% | 0%^*^ | 68% | 100% (93/93)
Foster 2015^147^; ASTRAL-2 | Sofosbuvir + velpatasvir | 2 | 57 | 36% | 14% | 86% | 99% (133/134)
Zeuzem 2018^167^; ENDURANCE-3 | Glecapravir + pibrentasvir | 3 | 47 | 41% | 0% | 100% | 95% (149/157)
Nelson 2015^157^; ALLY-3 | Sofosbuvir + daclatasvir | 3 | 55 | 41% | 0% | 59% | 96% (105/109)
Zeuzem 2018^167^; ENDURANCE-3 | Sofosbuvir + daclatasvir | 3 | 49 | 55% | 0% | 100% | 97% (111/115)
Everson 2015^146^ | Sofosbuvir + velpatasvir | 3 | 50 | 37% | 0% | 100% | 93% (25/27)
Foster 2015^147^; ASTRAL-3 | Sofosbuvir + velpatasvir | 3 | 49 | 39% | 0%^*^ | 74% | 97% (191/197)
Pianko 2015^158^ | Sofosbuvir + velpatasvir | 3 | 55 | 34% | 0% | 0% | 100% (53/53)
Brown 2018^144^; C-SCAPE | Grazoprevir + elbasvir | 4 | 52 | 58% | 0% | 100% | 90% (9/10)
Zeuzem 2015^166^; C-EDGE | Grazoprevir + elbasvir | 4 | 52 | 46% | 20% | 100% | 100% (18/18)
Abergel 2016a^142^ | Ledipasvir + sofosbuvir | 4 | 52 | 50% | 5% | 100% | 96% (21/22)
Ahmed 2018^195^ | Ledipasvir + sofosbuvir | 4 | 51 | 35% | Unclear | 100% | 99% (99/100)
Hezode 2015^189^; PEARL I | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 4 | 48 | 29% | 0% | 46% | 100% (91/91)
Waked 2016^162^; AGATE-II | Ombitasvir + paritaprevir + ritonavir + dasabuvir | 4 | 49 | 30% | 2% | 100% | 94% (94/100)
Feld 2015^139^; ASTRAL-1 | Sofosbuvir + velpatasvir | 4 | 54 | 60% | 0%^*^ | 68% | 100% (89/89)
Asselah 2019^143^; ENDURANCE-5 | Glecapravir + pibrentasvir | 5 | 68 | 57% | 13% | 83% | 96% (22/23)
Abergel 2016b^141^ | Ledipasvir + sofosbuvir | 5 | 61 | 48% | 14% | 100% | 95% (20/21)
Feld 2015^139^; ASTRAL-1 | Sofosbuvir + velpatasvir | 5 | 54 | 60% | 0%^*^ | 68% | 97% (28/29)
Asselah 2019^143^; ENDURANCE-6 | Glecapravir + pibrentasvir | 6 | 54 | 52% | 10% | 93% | 98% (60/61)
Gane 2015^148^ | Ledipasvir + sofosbuvir | 6 | 51 | 36% | Unclear | 92% | 96% (24/25)
Feld 2015^139^; ASTRAL-1 | Sofosbuvir + velpatasvir | 6 | 54 | 60% | 0%^*^ | 68% | 100% (35/35)
Grebely 2018a^150^; SIMPLIFY | Sofosbuvir + velpatasvir | 1, 3 | 48 | 28% | 0%^*^ | NR | 95% (82/86)
Wei 2019b^165^ | Sofosbuvir + velpatasvir | 1, 3, 6 | 45 | 47% | 18% | 82% | 97% (362/375)
Wei 2019a^164^; C-CORAL | Grazoprevir + elbasvir | 1, 4 | 48 | 56% | 19% | 100% | 94% (459/486)
Sperl 2016^198^; C-EDGE | Grazoprevir + elbasvir | 1, 4, 6 | 48 | 57% | 17% | 78% | 99% (128/129)
Asselah 2018^196^; SURVEYOR II Part 4 | Glecapravir + pibrentasvir | 2, 4-6 | 52 | 52% | 0% | 87% | 97% (196/203)
Everson 2015^146^ | Sofosbuvir + velpatasvir | 2; 4-6 | 54 | 32% | 0% | 100% | 95% (21/22)

* Results for subgroup with no cirrhosis.

Abbreviations: NR = not reported; SVR = sustained virologic response. Study names are not acronyms.

Thirteen trials (in 11 publications) evaluated ombitasvir / paritaprevir / ritonavir / dasabuvir, with or without ribavirin,^137,149,151,155,162,186–189,191,192^ ten trials ledipasvir / sofosbuvir,^141,142,145,148,156,163,185,190,193,195^ eight trials (in 6 publications) glecaprevir / pibrentasvir,^143,167,194,196,197,199^ seven trials (in 6 publications) sofosbuvir / velpatasvir,^139,146,147,150,158,165^ six trials elbasvir / grazoprevir,^144,152,160,164,166,198^ four trials daclatasvir / sofosbuvir.^157,159,161,167^ and three trials simeprevir / sofosbuvir.^153,154,159^ One trial compared a current DAA regimen versus placebo,^139^ two trials (reported in one publication) compared a current DAA regimen versus a regimen with telaprevir,^137^ and two trials (reported in one publication) compared a current DAA regimen versus an older, not currently recommended, DAA regimen.^147^ Five other trials randomized patients to a DAA regimen versus placebo with delayed DAA therapy, but only reported SVR rates following active treatment.^151,152,164,166,187^ The other trials did not compare a current DAA regimen to placebo or an older antiviral regimen. The duration of treatment was 12 weeks in all trials except for seven trials (in 5 publications)^143,167,196,197,199^ which evaluated 8 or 12 weeks of glecaprevir / pibrentasvir and two trials which evaluated 8 or 12 weeks of ledipasvir / sofosbuvir.^191,193^ Fourteen trials (in 12 publications) evaluated the same DAA regimen with and without ribavirin;^137,144,154,158,160,161,185,186,188,191,193,194^ of these, six trials (in 4 publications^137,186,188,191^) evaluated ombitasvir / paritaprevir / ritonavir / dasabuvir, two trials^185,193^ ledipasvir / sofosbuvir, two trials^144,160^ elbasvir / grazoprevir, and one trial each evaluated simeprevir / sofosbuvir,^154^ sofosbuvir / velpatasvir,^158^ glecaprevir / pibrentasvir,^194^ and daclatasvir / sofosbuvir.^161^ Twenty-one trials did not vary duration of treatment or use of ribavirin.^141,142,145,146,148–150,153,155–157,159,162–165,189,190,192,195,198^ Thirty-two trials (in 30 publications) enrolled treatment-naïve populations or reported results stratified according to prior treatment status,^137,141,142,144–146,149,151–153,155–157,159–167,185,188–191,193,195,198^ five trials only enrolled treatment-experienced patients,^137,154,158,186,194^ and 11 trials (in 10 publications) enrolled a mix of treatment-naïve and -experienced patients but did not stratify results according to treatment status.^139,143,147,148,150,187,192,196,197,199^ In trials of mixed populations, the proportion of treatment-naïve patients ranged from 52 to 95 percent. SVR was measured 12 weeks after the end of treatment in all trials except for one trial that assessed SVR at 14 weeks post-treatment^166^ and four trials (in 3 publications) that reported 12- and 24-week post-treatment SVR rates.^167,191,192^ In the latter trials, 12- and 24-week SVR rates were identical or very similar.

Twenty-seven trials (in 24 publications^137,139,144,146,147,151–154,158–161,166,167,185–191,193,194^) had multiple DAA treatment arms, and 22 trials (in 21 publications^141–143,145,148–150,155–157,162–165,167,192,195–199^) were single-arm studies (Appendix B Tables 10 and 11). Among the trials with multiple treatment arms, 20 (in 18 publications^137,144,146,147,153,154,158–161,167,185,186,189–191,193,194^) used an open-label design. In the open-label trials, treatment allocation was random in 11 trials (in 9 publications^137,147,153,159,167,185,186,190,194^); in the other trials patients were allocated to treatment based on genotype (4 trials^144,146,160,161^), prior treatment status (1 trial^191^), or clinical characteristics (e.g., fibrosis stage).^154,158,189,193^ Thirteen trials were rated good quality,^137,139,141,146,152,159,162,164,166,187–189,191^ and the remainder were rated fair quality. Frequent methodological limitations included unclear randomization or enrollment methods (e.g., unclear if the trial enrolled consecutive patients meeting inclusion criteria, or a random sample). Loss to followup was low across all trials (range 0 to 3%). All of the trials were industry-funded.

##### SVR Rates in Comparative Trials

###### DAA Regimen vs. Placebo

One randomized trial (n=706) compared sofosbuvir / velpatasvir versus placebo in persons with HCV infection (genotypes 1, 2, 4, 5, or 6; Table 11).^139^ Genotype 1 infection was present in 53 percent of patients, 32 percent of patients had previously received interferon therapy, and 19 percent had cirrhosis at baseline. Sofosbuvir / velpatasvir was associated with an SVR rate of 99 percent (618/624), compared with no cases of SVR among 116 patients randomized to placebo (RR 231.6, 95% CI, 14.6 to 3680). Across genotypes, the SVR rate with sofosbuvir / velpatasvir ranged from 97 percent to 100 percent.

Table 11 Sustained Virologic Response in Comparative Trials of Direct Acting Antiviral Regimens in Adults

Comparison | Author year Study name | Treatment Regimen | Primary genotype(s) | Mean age (years) | Proportion female gender | Proportion with cirrhosis | Proportion treatment-naïve | SVR
DAA vs. Placebo | Feld 2015^139^; ASTRAL-1 | Sofosbuvir + velpatasvir; Placebo | Mixed | 54 | 60% | 19% | 72% | 99% (618/624) vs. 0% (0/116); RR 232 (95% CI, 14.6 to 3680)
DAA vs. Telaprevir-containing Regimens | Dore 2016^137^; MALACHITE-1 | Ombitasvir + paritaprevir + ritonavir + dasabuvir; Telaprevir + pegylated interferon + ribavirin | 1 | 46 | 55% | 0% | 100% | 98% (81/83) vs. 80% (60/75); RR 1.22 (95% CI, 1.08 to 1.37)
DAA vs. Telaprevir-containing Regimens | Dore 2016^137^; MALACHITE-1 | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin; Telaprevir + pegylated interferon + ribavirin | 1 | 46 | 47% | 0% | 100% | 98% (150/153) vs. 80% (60/75); RR 1.23 (95% CI, 1.09 to 1.38)
DAA vs. Telaprevir-containing Regimens | Dore 2016^137^; MALACHITE-2 | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin; Telaprevir + pegylated interferon + ribavirin | 1 | 47 | 46% | 0% | 0% | 99% (100/101) vs. 66% (31/47); RR 1.50 (95% CI, 1.22 to 1.85)
DAA vs. Non-recommended DAA | Foster 2015^147^; ASTRAL-2 | Sofosbuvir + velpatasvir; Sofosbuvir + ribavirin | 2 | 57 | 41% | 14% | 85% | 99% (133/134) vs. 94% (124/132); RR 1.06 (95% CI, 1.01 to 1.11)
DAA vs. Non-recommended DAA | Foster 2015^147^; ASTRAL-3 | Sofosbuvir + velpatasvir; Sofosbuvir + ribavirin | 3 | 49 | 38% | 0%* | 74% | 97% (191/197) vs. 87% (163/187); RR 1.11 (95% CI, 1.05 to 1.18)

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; SVR = sustained virologic response; RR = relative risk. Study names are not acronyms.

###### DAA Regimen vs. Telaprevir-Containing Regimen

Two randomized trials (reported in one publication) compared ombitasvir / paritaprevir / ritonavir / dasabuvir (with or without ribavirin) for 12 weeks versus telaprevir (12 weeks) / pegylated interferon / ribavirin (24 or 48 weeks) for genotype 1 infection (Table 11).^137^ One trial (n=311) enrolled treatment-naïve patients, and the other (n=148) enrolled patients previously treated with pegylated interferon and ribavirin. In treatment- naïve patients, ombitasvir / paritaprevir / ritonavir / dasabuvir was associated with increased likelihood of SVR versus telaprevir / pegylated interferon / ribavirin (98% vs. 80%, RR 1.22, 95% CI, 1.08 to 1.37). SVR rates were similar in genotype 1a patients who received ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (97%) and genotype 1b patients who received the same regimen with or without ribavirin (98 to 99%). In the other trial, ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin was associated with increased likelihood of SVR versus telaprevir / pegylated interferon / ribavirin in treatment-experienced patients (99% vs. 66%, RR 1.50, 95% CI, 1.22 to 1.85). SVR rates were similar for genotype 1a (100%) and 1b (99%) infection.

###### DAA Regimen vs. Non-Recommended DAA Regimen

Two randomized trials (reported in one publication) compared sofosbuvir / velpatasvir for 12 weeks versus sofosbuvir / ribavirin for 24 weeks.^147^ One trial (n=269) enrolled patients with genotype 2 infection (14 to 15% prior interferon therapy, 14% cirrhosis) and one trial (n=280) enrolled patients with genotype 3 infection (26% prior interferon therapy and 29 to 30% cirrhosis; results reported for non-cirrhosis subgroup). Sofosbuvir / velpatasvir was associated with increased likelihood of SVR for genotype 2 infection (99% vs. 94%, RR 1.06, 95% CI, 1.01 to 1.11) and for genotype 3 infection (non-cirrhosis subgroup, 97% vs. 87%, RR 1.11, 95% CI, 1.05 to 1.18).

##### Pooled SVR Rates by Genotype

###### Genotype 1

Thirty-two trials (total N=6,055) reported SVR rates associated with seven different DAA regimens in persons with genotype 1 infection.^137,139,145,146,149,151–156,159–161,163–167,185–188,190–194,197,198^ Across DAA regimens, the pooled SVR rate was 97.7 percent (95% CI, 96.6% to 98.4%; I^2^=82%) (Figure 2). Although statistical heterogeneity was present, the SVR rate was 91 percent or higher in all of the trials. The most frequently evaluated regimen was ombitasvir / paritaprevir / ritonavir, with or without dasabuvir or ribavirin (11 trials).^137,139,149,151,155,186,188,191,192^ The pooled SVR rate with this regimen was 93.7 percent (95% CI, 89.0% to 96.5%; I^2^=77%) for genotype 1a infection (5 trials), 98.2 percent (95% CI, 96.4% to 99.1%; I^2^=68%) for genotype 1b infection (8 trials), and 93.2 percent (95% CI, 87.0% to 96.6%, I^2^=27%) for non-subtyped genotype 1 infection (2 trials). Ledipasvir / sofosbuvir was evaluated in six trials,^145,156,163,185,190,193^ with a pooled SVR rate of 99.4 percent (95% CI, 95.2% to 99.9%, I^2^=89%), and elbasvir / grazoprevir was evaluated in five trials^152,160,164,166,198^ with pooled SVR rate of 96.7 percent (95% CI, 95.0% to 97.8%; I^2^=55%). Four other antiviral regimens were evaluated in two or three trials each; pooled SVR rates ranged from 95.7 percent to 99.0 percent for these regimens (Table 12).

Figure 2 Key Question 7: Direct Acting Antiviral Regimens and Pooled Sustained Virologic Response Rates, Genotype 1

Abbreviations: CI = confidence interval; NR = not reported; SVR = sustained virologic response; Tx = treatment; U.S. = United States.

Figure 2 is a forest plot examining sustained virologic response rates for genotype 1 comparing 9 direct acting antiviral regimens. The proportion for 6 studies in the ledipasvir/sofosbuvir subgroup is 0.994 (95% confidence interval 0.952 to 0.999) with an I-squared value of 88.7%. The proportion for the 3 studies in the simeprevir/sofosbuvir subgroup is 0.957 (95% confidence interval 0.926 to 0.975) with an I-squared value of 0.0%. The proportion for the 3 studies in the sofosbuvir/velpatasvir subgroup is 0.990 (95% confidence interval 0.954 to 0.998) with an I-squared value of 26.6%. The proportion for the 5 studies in the elbasvir/grazoprevir subgroup is 0.967 (95% confidence interval 0.950 to 0.978) with an I-squared value of 54.6%. The proportion for the 2 studies in the sofosbuvir/daclatasvir subgroup is 0.986 (95% confidence interval 0.947 to 0.997) with an I-squared value of 45.3%. The proportion for the 3 studies in the glecaprevir/pibrentasvir subgroup is 0.986 (95% confidence interval 0.941 to 0.997) with an I-squared value of 77.9%. The proportion for the 2 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.932 (95% confidence interval 0.870 to 0.966) with an I-squared value of 26.7%. The proportion for the 5 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir genotype 1a subgroup is 0.937 (95% confidence interval 0.890 to 0.965) with an I-squared value of 77.2%. The proportion for the 8 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir genotype 1b subgroup is 0.982 (95% confidence interval 0.964 to 0.991) with an I-squared value of 68.5%. The overall proportion is 0.977 (95% confidence interval 0.966 to 0.984) with an I-squared value of 81.623%.

Table 12 Sustained Virologic Response Rates With Direct Acting Antiviral Regimens in Adults by Genotype

Analysis | Number of trials | Pooled sustained virologic response rate (95% CI) | I^2^ | p for interaction
Genotype 1 infection | 32 (in 30 publications)^*^,^137,139,145,146,149,151–156,159–161,163–167,185–188,190–194,197,198^ | 97.7% (96.6% to 98.4%) | 82% | --
- Ledipasvir / sofosbuvir | 6^145,156,163,185,190,193^ | 99.4% (95.2% to 99.9%) | 89% | 0.005 (regimens)
- Simeprevir / sofosbuvir | 3^153,154,159^ | 95.7% (92.6% to 97.5%) | 0% | --
- Sofosbuvir / velpatasvir | 3^139,146,165^ | 99.0% (95.4% to 99.8%) | 27% | --
- Sofosbuvir / daclatasvir | 2^159,161^ | 98.6% (94.7% to 99.7%) | 45% | --
- Glecaprevir / pibrentasvir | 3^167,194,197^ | 98.6% (94.1% to 99.7%) | 78% | --
- Elbasvir / grazoprevir | 5^152,160,164,166,198^ | 96.7% (95.0% to 97.8%) | 55% | --
- Ombitasvir / paritaprevir / ritonavir / dasabuvir (genotype 1, not sub-typed) | 2^149,192^ | 93.2% (87.0% to 96.6%) | 27% | --
- Ombitasvir / paritaprevir / ritonavir / dasabuvir^†^ (genotype 1a) | 5 (in 4 publications)^137,187,188,191^ | 93.7% (89.0% to 96.5%) | 77% | --
- Ombitasvir / paritaprevir / ritonavir / dasabuvir^‡^ (genotype 1b) | 8 (in 7 publications)^137,151,155,186–188,191^ | 98.2% (96.4% to 99.1%) | 68% | --
- Good quality | 12^*^ (in 10 publications)^137,139,146,152,159,164,166,187,188,191^ | 97.2% (95.2% to 98.4%) | 82% | 0.42 (quality)
- Fair quality | 20^145,149,151,153–156,160,161,163,165,167,185,186,190,192–194,197,198^ | 97.9% (96.7% to 98.7%) | 76% | --
- Cirrhosis excluded | 22 (in 20 publications)^§^,^137,139,146,149,151–155,159,160,167,185,186,188,190–194^ | 97.1% (95.7% to 98.1%) | 82% | 0.22 (cirrhosis)
- Some cirrhosis (<20% of population) | 8^145,156,161,163–166,198^ | 98.7% (97.1% to 99.4%) | 38% | --
- U.S. or Canada | 8^146,153,154,161,190,192–194^ | 96.6% (93.1% to 98.4%) | 82% | 0.48 (geographic setting)
- Multinational | 17^†^,^137–139,149,151,155,160,164–167,185–188,191,198^ | 97.7% (96.4% to 98.6%) | 89% | --
- Other geographic setting | 7^145,151,152,156,159,163,197^ | 98.3% (96.1% to 99.2%) | 28% | --
Use of ribavirin and/or dasabuvir as recommended^║^ | 26 (in 25 publications)^*^,^137,139,145,146,152–154,156,159–161,163–166,185,187,188,190–193,197,198^ | 98.3% (97.4% to 98.9%) | 60% | --
- Treatment-naïve | 24 (in 23 publications)^*^,^137,139,145,146,151–156,159–161,163,164,166,185,187,188,190–193^ | 97.4% (96.1% to 98.3%) | 80% | --
Genotype 2 infection | 5^139,147,165,196,199^ | 98.9% (97.5% to 99.5%) | 4% | --
- Sofosbuvir / velpatasvir | 3^139,147,165^ | 99.6% (97.6% to 99.95%) | 0% | 0.06 (regimens)
- Glecaprevir / pibrentasvir | 2^196,199^ | 97.9% (95.0% to 99.1%) | 0%
- Good quality | 1^139^ | 100% (96.1% to 100%) | -- | 0.99 (quality)
- Fair quality | 4^147,164,196,199^ | 98.6% (97.0% to 99.4%) | 0%
- Cirrhosis excluded | 3^139,196,199^ | 98.5% (96.4% to 99.4%) | 36% | 0.37 (cirrhosis)
- Some cirrhosis (<20% of population) | 2^147,164^ | 99.5% (96.5% to 99.9%) | 0%
- U.S. or Canada | 1^147^ | 99.2% (94.9% to 99.9%) | -- | 0.62 (geographic setting)
- Multinational | 3^139,164,196^ | 99.0% (97.0% to 99.7%) | 33% | --
- Other geographic setting | 1^199^ | 97.8% (91.6% to 99.4%) | 4% | --
- Treatment-naïve | 1^139^ | 100% (95.4% to 100%) | -- | --
Genotype 3 infection | 6^146,147,157,158,165,167^ | 95.5% (91.6% to 97.7%) | 66% | --
- Sofosbuvir / velpatasvir^║^ | 4^146,147,158,165^ | 95.6% (87.1% to 98.6%) | 82% | 0.78 (regimens)
- Sofosbuvir / daclatasvir | 2^157,167^ | 96.4% (93.0% to 98.2%) | 0% | --
- Glecaprevir / pibrentasvir | 1^167^ | 94.9% (90.2% to 97.8%) | --
- Good quality | 1^146^ | 93.2% (66.8% to 99.0%) | -- | 0.66 (quality)
- Fair quality | 5^147,157,158,164,167^ | 95.7% (91.6% to 97.8%) | 70% | --
- Cirrhosis excluded | 5^146,147,157,158,167^ | 96.4% (94.6% to 97.5%) | 14% | 0.01 (cirrhosis)
- Some cirrhosis (<20% of population) | 1^165^ | 85.7% (76.5% to 91.7%) | -- | --
- U.S. or Canada | 3^146,147,157^ | 96.3% (91.4% to 98.4%) | 0% | 0.55 (geographic setting)
- Multinational | 3^158,164,167^ | 94.5% (88.2% to 97.6%) | 80%
- Use of ribavirin as recommended | 5^146,147,157,164,167^ | 95.2% (91.4% to 97.3%) | 0% | --
- Treatment-naïve | 5 (in 4 publications)^146,147,157,167^ | 96.1% (94.5% to 97.3%) | 14% | --
Genotype 4 infection | 10^139,142,144,162,164,166,189,195,196,198^ | 98.2% (94.7% to 99.4%) | 50% | --
- Ledipasvir / sofosbuvir | 2^142,195^ | 98.4% (93.7% to 99.6%) | 25% | 0.14 (regimens)
- Sofosbuvir / velpatasvir | 1^139^ | 100% (95.9% to 100%) | -- | --
- Elbasvir / grazoprevir | 4^144,164,166,198^ | 97.3% (83.2% to 99.6%) | 0% | --
- Glecaprevir / pibrentasvir | 1^196^ | 93.5% (82.1% to 98.6%) | -- | --
- Ombitasvir / paritaprevir / ritonavir / dasabuvir | 2^162,189^ | 98.7% (72.7% to 99.95%) | 88% | --
- Good quality | 5^139,162,164,166,189^ | 99.1% (94.0% to 99.9%) | 72% | 0.31 (quality)
- Fair quality | 5^142,144,195,196,198^ | 97.0% (89.1% to 99.2%) | -- | --
- Cirrhosis excluded | 4^139,144,189,196^ | 98.3% (94.4% to 99.5%) | 0% | 0.52 (cirrhosis)
- Some cirrhosis (<20% of population) | 5^142,162,164,166,198^ | 96.5% (86.5% to 99.2%) | 0% | --
- U.S. or Canada | 0 | -- | -- | --
- Europe / Australia / New Zealand | 1^142^ | 96.3% (61.1% to 99.8%) | -- | 0.67 (geographic setting)
- Multinational | 7^139,144,164,166,189,196,198^ | 98.8% (94.6% to 99.7%) | 45% | --
- Other | 2^162,195^ | 97.3% (88.0% to 99.4%) | 73% | --
- Treatment-naïve | 8^139,142,144,162,164,166,189,195^ | 98.3% (94.5% to 99.5%) | 52% | --
Genotype 5 infection | 4^139,141,143,196^ | 96.0% (88.3% to 98.7%) | 0% | --
- Ledipasvir / sofosbuvir | 1^141^ | 95.2% (76.2% to 99.9%) | -- | 0.99 (regimens)
- Sofosbuvir / velpatasvir | 1^139^ | 96.6% (82.2% to 99.9%) | -- | --
- Glecaprevir / pibrentasvir | 2^143,196^ | 96.0% (76.4% to 99.4%) | 0% | --
- Good quality | 2^139,141^ | 96.0% (85.4% to 99.0%) | 0% | 1.00 (quality)
- Fair quality | 2^143,196^ | 96.0% (76.4% to 99.4%) | 0% | --
- Cirrhosis excluded | 2^139,196^ | 96.8% (80.4% to 99.6%) | 0% | 0.79 (cirrhosis)
- Some cirrhosis (<20% of population) | 2^141,143^ | 95.4% (83.6% to 98.9%) | 0% | --
- U.S. or Canada | 0 | -- | -- | --
- Europe / Australia / New Zealand | 1^141^ | 95.2% (72.9% to 99.3%) | -- | 0.85 (geographic setting)
- Multinational | 3^139,143,196^ | 96.3% (86.4% to 99.1%) | 0% | --
- Treatment-naïve | 2^139,141^ | 95.6% (83.9% to 98.9%) | 0% | --
Genotype 6 infection | 5^139,143,148,165,196^ | 98.2% (95.4% to 99.3%) | 0%
- Ledipasvir / sofosbuvir | 1^148^ | 96.0% (79.6% to 99.9%) | --% | 0.37 (regimens)
- Sofosbuvir / velpatasvir | 2^139,165^ | 99.2% (94.9% to 99.9%) | 0% | --
- Glecaprevir / pibrentasvir | 2^143,196^ | 97.2% (89.4% to 99.3%) | 42% | --
- Good quality | 1^139^ | 100% (90% to 100%) | -- | <0.001 (quality)
- Fair quality | 4^143,148,164,196^ | 97.9% (94.6% to 99.2%) | 4% | --
- Cirrhosis excluded | 2^139,196^ | 97.8% (85.8% to 99.7%) | 63% | 0.66 (cirrhosis)
- Some cirrhosis (<20% of population) | 2^143,164^ | 98.7% (95.1% to 99.7%) | 0% | --
- Cirrhosis status unclear/not reported | 1^148^ | 96.0% (76.4% to 99.4%) | -- | --
- U.S. or Canada | 0 | -- | -- | --
- Europe / Australia / New Zealand | 1^148^ | 96.0% (76.4% to 99.4%) | -- | 0.43 (geographic setting)
- Multinational | 4^139,143,165,196^ | 98.5% (95.5% to 99.5%) | 0% | --
- Treatment-naïve | 2^139,148^ | 98.4% (89.6% to 99.8%) | 35% | --
Mixed genotype^¶^ | 2^146,150^ | 95.4% (89.4% to 98.1%) | 0% | --
- Sofosbuvir / velpatasvir | 2^146,150^ | 95.4% (89.4% to 98.1%) | 0% | --

* Two trials reported results for genotype 1a and 1b separately (Feld 2014^187^, Kowdley 2014b^191^).

† One trial omitted dasabuvir (Kowdley 2014b^191^).

‡ Two trials omitted dasabuvir (Kowdley 2014b^191^, Lawitz 2015^155^).

§ One trial reported results for genotype 1a and 1b separately (Kowdley 2014b^191^).

║ Regimens administered with or without ribavirin.

¶ All patients were treatment-naïve.

Abbreviations: CI = confidence interval; U.S. = United States.

Results were similar for trials rated good quality (pooled SVR 97.2%, 95% CI, 95.2% to 98.4%) or fair quality (pooled SVR 97.9%, 95% CI, 96.7% to 98.7%), for trials that excluded patients with cirrhosis (pooled SVR 97.1%, 95% CI, 95.7% to 98.1%) or included some (less than 20% of sample) patients with cirrhosis (pooled SVR 98.7%, 95% CI, 97.1% to 99.4%), and when the analysis was restricted to trials conducted in the United States and Canada (pooled SVR 96.6%, 95% CI, 93.1% to 98.4%) (Table 12). Results were also similar when the analysis was restricted to trials that used ribavirin as recommended or did not omit dasabuvir in combination with ombitasvir / paritaprevir / ritonavir (pooled SVR 98.3%, 95% CI, 97.4% to 98.9%) or when the analysis was restricted to treatment-naïve patients (pooled SVR 97.4%, 95% CI, 96.1% to 98.3%).

###### Genotype 2

Five trials (total N=526) reported SVR rates associated with two different DAA regimens in persons with genotype 2 infection (pooled SVR 98.9%, 95% CI, 97.5% to 99.5%; I^2^=4%) (Figure 3).^139,147,165,196,199^ Three trials evaluated sofosbuvir / velpatasvir (pooled SVR 99.6%, 95% CI, 97.6% to 99.95%, I^2^=0%),^139,147,164^ and two trials evaluated glecaprevir / pibrentasvir (pooled SVR 97.9%, 95% CI, 95.0% to 99.1%, I^2^=0%).^196,199^ Estimates were similar when trials were stratified according to quality, geographic setting, or enrollment of some patients with cirrhosis (Table 12). SVR rates were also similar in trials that were restricted to treatment-experienced patients^164,196,199^ or enrolled a mix of treatment-naïve and treatment-experienced patients;^139,147^ one mixed population trial reported an SVR of 100% (95% CI, 95.4% to 100%) in the subgroup of treatment-naïve patients.^139^

Figure 3 Key Question 7: Direct Acting Antiviral Regimens and Pooled Sustained Virologic Response Rates, Genotype 2

Abbreviations: CI = confidence interval; SVR = sustained virologic response; Tx = treatment; U.S. = United States.

Figure 3 is a forest plot examining sustained virologic response rates for genotype 2 comparing 2 direct acting antiviral regimens. The proportion for 3 studies in the sofosbuvir/velpatasvir subgroup is 0.996 (95% confidence interval 0.976 to 0.9995) with an I-squared value of 0.0%. The proportion for the 2 studies in the glecaprevir/pibrentasvir subgroup is 0.979 (95% confidence interval 0.950 to 0.991) with an I-squared value of 0.0%. The overall proportion is 0.989 (95% confidence interval 0.975 to 0.995) with an I-squared value of 3.554%.

###### Genotype 3

Six trials (total N=742) reported SVR rates associated with three different DAA regimens in persons with genotype 3 infection (pooled SVR 95.5%, 95% CI, 91.6% to 97.7%; I^2^=66%) (Figure 4).^146,147,157,158,165,167^ Estimates were similar for sofosbuvir / velpatasvir (4 trials; pooled SVR 95.6%, 95% CI, 87.1% to 98.6%; I^2^=82%)^146,147,158,165^ sofosbuvir / daclatasvir (2 trials; pooled SVR 96.4%, 95% CI, 93.0% to 98.2%, I^2^=0%),^157,167^ and glecaprevir / pibrentasvir (one trial, SVR 94.9%, 95% CI, 90.2% to 97.8%).^167^

Figure 4 Key Question 7: Direct Acting Antiviral Regimens and Pooled Sustained Virologic Response Rates, Genotype 3

Abbreviations: CI = confidence interval; NZ = New Zealand; SVR = sustained virologic response; Tx = treatment; U.S. = United States.

Figure 4 is a forest plot examining sustained virologic response rates for genotype 3 comparing 3 direct acting antiviral regimens. The proportion for 4 studies in the sofosbuvir/velpatasvir subgroup is 0.956 (95% confidence interval 0.871 to 0.986) with an I-squared value of 82.3%. The proportion for the 2 studies in the sofosbuvir/daclatasvir subgroup is 0.964 (95% confidence interval 0.930 to 0.982) with an I-squared value of 0.0%. The proportion for the 1 study in the glecaprevir/pibrentasvir subgroup is 0.949 (95% confidence interval 0.902 to 0.978). The overall proportion is 0.955 (95% confidence interval 0.916 to 0.977) with an I-squared value of 65.604%.

The SVR rate was higher in five trials that excluded patients with cirrhosis (pooled SVR 96.4%, 95% CI, 94.6% to 97.5%) than in one trial^165^ that included some patients with cirrhosis (SVR 85.7%, 95% CI, 76.5% to 91.7%; p for interaction=0.01). Results were similar when trials were stratified according to study quality or when the analysis was restricted to trials conducted in the United States or Canada (Table 12). Results were also similar when the analysis excluded results from one trial^158^ of sofosbuvir / velpatasvir plus ribavirin (ribavirin is not required with this regimen; pooled SVR 95.2%, 95% CI, 91.4% to 97.3%) and when the analysis was restricted to treatment-naïve patients (pooled SVR 96.1%, 95% CI, 94.5% to 97.3%) (Table 12).

###### Genotype 4

Ten trials (total N=485) reported SVR rates associated with five different DAA regimens in persons with genotype 4 infection (pooled SVR 98.2%, 95% CI, 94.7% to 99.4%; I^2^=50%) (Figure 5).^139,142,144,162,164,166,189,195,196,198^ Estimates were similar for elbasvir / grazoprevir (4 trials, pooled SVR 97.3%, 95% CI, 83.2% to 99.6%, I^2^=0%),^138,144,164,166,198^ ombitasvir / paritaprevir / ritonavir with ribavirin (2 trials, pooled SVR 98.7%, 95% CI, 72.7% to 99.95%; I^2^=88%),^162,189^ and ledipasvir / sofosbuvir (2 trials, pooled SVR 98.4%, 95% CI, 93.7% to 99.6%, I^2^=25%)^142,195^ (Table 12). One trial each evaluated sofosbuvir / velpatasvir (SVR 100%, 95% CI, 95.9% to 100%)^139^ and glecaprevir / pibrentasvir (SVR 93.5%, 95% CI, 82.1% to 98.6%).^196^

Figure 5 Key Question 7: Direct Acting Antiviral Regimens and Sustained Virologic Response Rates, Genotype 4

Abbreviations: CI = confidence interval; SVR = sustained virologic response; Tx = treatment.

Figure 5 is a forest plot examining sustained virologic response rates for genotype 4 comparing 5 direct acting antiviral regimens. The proportion for 2 studies in the ledipasvir/sofosbuvir subgroup is 0.984 (95% confidence interval 0.937 to 0.996) with an I-squared value of 24.6%. The proportion for the 1 study in the sofosbuvir/velpatasvir subgroup is 1.000 (95% confidence interval 0.959 to 1.000). The proportion for 4 studies in the elbasvir/grazoprevir subgroup is 0.973 (95% confidence interval 0.832 to 0.996) with an I-squared value of 0.0%. The proportion for 1 study in the glecaprevir/pibrentasvir subgroup is 0.935 (95% confidence interval 0.821 to 0.986). The proportion for 2 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.987 (95% confidence interval 0.727 to 0.9995) with an I-squared value of 87.5%. The overall proportion is 0.982 (95% confidence interval 0.947 to 0.994) with an I-squared value of 50.294%.

Results were similar when the analysis was restricted to trials that were rated good quality (pooled SVR 96.5%, 95% CI, 86.5.0% to 99.2%), when trials were stratified according to whether they were restricted to patients without cirrhosis (pooled SVR 98.3%, 95% CI, 94.4% to 99.5%) or included some patients with cirrhosis (pooled SVR 99.1%, 95% CI, 91.2% to 99.9%), and when trials were stratified according to geographic setting (Table 12). Results were also similar when the analysis was restricted to treatment-naïve patients (pooled SVR 98.3%, 95% CI, 94.5% to 99.5%).

###### Genotype 5

Four trials (total N=75) reported SVR rates associated with three different DAA regimens in patients with genotype 5 infection (pooled SVR 96.0%, 95% CI, 88.3% to 98.7%; I^2^=0%; Figure 6).^139,141,143,196^ Estimates were similar for glecaprevir / pibrentasvir (2 trials, pooled SVR 96.0%, 95% CI, 76.4% to 99.4%; I^2^=0%),^143,196^ ledipasvir / sofosbuvir (1 trial, SVR 95.2%, 95% CI, 76.2% to 99.9%),^141^ and sofosbuvir / velpatasvir (1 trial, SVR 96.6%, 95% CI, 82.2% to 99.9%).^139^ Estimates were similar when trials were stratified according to study quality, inclusion of patients with cirrhosis, and geographic setting (Table 12). Results were also similar when the analysis was restricted to treatment-naïve patients (pooled SVR 95.6%, 95% CI, 83.9% to 98.9%).

Figure 6 Key Question 7: Direct Acting Antiviral Regimens and Sustained Virologic Response Rates, Genotype 5

Abbreviations: CI = confidence interval; SVR = sustained virologic response; Tx = treatment.

Figure 6 is a forest plot examining sustained virologic response rates for genotype 5 comparing 3 direct acting antiviral regimens. The proportion for 1 study in the ledipasvir/sofosbuvir subgroup is 0.952 (95% confidence interval 0.762 to 0.999). The proportion for the 1 study in the sofosbuvir/velpatasvir subgroup is 0.966 (95% confidence interval 0.822 to 0.999). The proportion for the 2 studies in the glecaprevir/pibrentasvir subgroup is 0.960 (95% confidence interval 0.765 to 0.994) with an I-squared value of 0.000%. The overall proportion is 0.960 (95% confidence interval 0.883 to 0.987) with an I-squared value of 0.000%.

###### Genotype 6

Five trials (total N=229) reported SVR rates associated with three different DAA regimens in persons with genotype 6 infection (pooled SVR 98.2%, 95% CI, 95.4% to 99.3%, I^2^=0%) (Figure 7).^139,143,148,165,196^ Estimates were similar for glecaprevir / pibrentasvir (2 trials, pooled SVR 97.2%, 95% 89.4% to 99.3%; I^2^=42%),^143,196^ sofosbuvir / velpatasvir (2 trials, pooled SVR 99.2%, 95% CI, 94.9% to 99.9%; I^2^=0%)^139,165^ and ledipasvir / sofosbuvir (1 trial, SVR 96.0%, 95% CI, 79.6% to 99.9%).^148^ Results were similar when analyses were stratified according to quality, enrollment of some patients with cirrhosis, and geographic setting (Table 12). Results were also similar when the analysis was restricted to treatment-naïve patients (pooled SVR 98.4%, 95% CI, 89.6% to 99.8%).

Figure 7 Key Question 7: Direct Acting Antiviral Regimens and Sustained Virologic Response Rates, Genotype 6

Abbreviations: CI = confidence interval; SVR = sustained virologic response; Tx = treatment.

Figure 7 is a forest plot examining sustained virologic response rates for genotype 6 comparing 3 direct acting antiviral regimens. The proportion for 1 study in the ledipasvir/sofosbuvir subgroup is 0.960 (95% confidence interval 0.796 to 0.999). The proportion for the 2 studies in the sofosbuvir/velpatasvir subgroup is 0.992 (95% confidence interval 0.949 to 0.999) with an I-squared value of 0.0%. The proportion for the 2 studies in the glecaprevir/pibrentasvir subgroup is 0.972 (95% confidence interval 0.894 to 0.993) with an I-squared value of 42.1%. The overall proportion is 0.982 (95% confidence interval 0.954 to 0.993) with an I-squared value of 0.000%.

###### Mixed Genotypes

Two trials (total N=108) reported SVR rates associated with sofosbuvir / velpatasvir in persons with mixed genotype 1 to 6 infections (pooled SVR 95.4%, 95% CI, 89.4% to 98.1%; I^2^=0%) (Figure 8).^146,150^ Both trials were restricted to patients without cirrhosis. In one trial^146^ patients were treatment-naïve, and in the other trial prior treatment status was not reported.^150^

Figure 8 Key Question 7: Direct Acting Antiviral Regimens and Sustained Virologic Response Rates, Mixed Genotypes

Abbreviations: CI = confidence interval; SVR = sustained virologic response; Tx = treatment; U.S. = United States.

Figure 8 is a forest plot examining sustained virologic response rates of studies including mixed genotypes. The proportion for 2 studies of sofosbuvir/velpatasvir is 0.954 (95% confidence interval 0.894 to 0.981) with an I-squared value of 0.0%.

###### Subgroup Analyses

Nineteen trials (in 18 publications) reported analyses stratified according to demographic characteristics.^139,145,147,149,150,152,156,157,164–167,185–187,190,191,198^ SVR rates were similar when patients were stratified according to age in 17 trials, according to sex in 17 trials, and according to race or ethnicity in 11 trials (Table 13). One trial found SVR rates were slightly higher in persons with body mass index (BMI) less than 30 kg/m^2^ versus 30 kg/m^2^ or more (97% vs. 92%) and in persons with diabetes versus no diabetes (100% vs. 96%).^187^

Table 13 Sustained Virologic Response Rates With Direct Acting Antiviral Regimens in Adults in Subgroups

Author year; Study name | Intervention(s) | Age | Sex/Gender | Race/Ethnicity | Other characteristics
Afdhal 2014^185^; ION-1 | A. Ledipasvir + sofosbuvir; B. Ledipasvir + sofosbuvir + ribavirin | <65 years: 99% (196/197) vs. 100% (189/189); ≥65 years: 100% (15/15) vs. 100% (22/22) | Male gender: 99% (125/126) vs. 100% (124/124); Female gender: 100% (86/86) vs. 100% (87/87) | Black: 100% (24/24) vs. 100% (26/26); Non-Black: 99.5% (187.188) vs. 100% (184/184); Hispanic: 100% (26/26) vs. 100% (19/19) | NR
Andreone 2014^186^; PEARL-2 | A. Ombitasvir + paritaprevir + ritonavir + dasabuvir; B. Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | NR | Male gender: 100% (54/54) vs. 95% (41/43); Female gender: 100% (37/37) vs. 98% (44/45) | Black: 100% (5/5) vs. 100% (3/3); Other: 100% (86/86) vs. 97% (82/85) | NR
Chuang 2016^145^ | Ledipasvir + sofosbuvir | <65: 100% (35/35); ≥65: 100% (7/7) | Male gender: 100% (13/13); Female gender: 100% (29/29) | NR | [underlined: BMI]; <25: 100% (26/26); ≥25: 100% (16/16)
Feld 2014^187^; SAPPHIRE-1 | A. Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin; B. Placebo followed by open-label ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | <55 years: 97% (280/290); ≥55 years: 96% (175/183) | Male gender: 95% (258/271); Female gender: 98% (197/202) | Black: 96% (27/28); Non-Black: 96% (428/445) | [underlined: BMI]; <30: 97% (390/402); ≥30: 92% (65/71); [underlined: Diabetes]; Yes: 100% (19/19); No: 96% (436/454)
Feld 2015; ASTRAL-1^139^ | Sofosbuvir + velpatasvir | <65 years: 99% (609/615); ≥65 years: 100% (113/113) | Male gender: 99% (426/431); Female gender: 99.7% (296/297) | Black: 98% (64/65); White: 99% (570/575); Other: 100% (84/84) | [underlined: BMI]; <30: 99% (568/573); ≥30: 99% (154/155)
Foster 2015^147^; ASTRAL-3 | A. Sofosbuvir + velpatasvir; B. Sofosbuvir + ribavirin | <65 years: 95% (257/270) vs. 81% (210/261); ≥65 years: 100% (7/7) vs. 79% (11/14) | Male gender: 94% (159/170) vs. 76% (132/175); Female gender: 98% (105/107) vs. 88% (89/101) | Black: 100% (3/3) vs. 100% (1/1); White: 95% (238/250) vs. 78% (187/239); Other: 96% (23/24) vs. 94% (32/34) | NR
Grebely 2018a^150^; SIMPLIFY | Sofosbuvir + velpatasvir | ≤41 years: 93% (26/28); >41 years: 95% (71/75) | [underlined: Male gender: 92% (68/74)]; [underlined: Female gender: 100% (29/29)] | [underlined: NR] | No current opioid substitution therapy: 93% (54/58); Current opioid substitution therapy: 96% (43/45)
Grebely 2018b^149^; D3FEAT | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | ≤54 years: 89% (59/66); >54 years: 95% (20/21) | [underlined: Male gender: 91% (61/67)]; [underlined: Female gender: 90% (18/20)] | [underlined: NR] | No current opioid substitution therapy: 96% (25/26); Current opioid substitution therapy: 89% (54/61)
Kowdley 2014a^190^; ION-3 | Ledipasvir + sofosbuvir | [underlined: 8-week intervention group]; <65 years: 94% (185/196); ≥65 years: 90% (17/19); [underlined: 12-week intervention group]; <65 years: 95% (189/199); ≥65 years: 100% (17/17) | [underlined: 8-week intervention group]; Male: 92% (119/130); Female: 98% (83/85); [underlined: 12-week intervention group]; Male gender: 95% (122/128); Female gender: 96% (84/85) | [underlined: 8-week intervention group]; Black: 91% (41/45); Non-black: 95% (161/170); Hispanic: 100% (13/13); Non-Hispanic: 94% (187/200); [underlined: 12-week intervention group]; Black: 95% (40/42); Non-black: 95% (165/173); Hispanic: 93% (13/14); Non-Hispanic: 96% (193/202) | NR
Kowdley 2014b^191^; AVIATOR | A. Ombitasvir + paritaprevir + ritonavir + dasabuvir; B. Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | NR | NR | Black: 100% (13/13) vs. 100% (13/13); Non-black: 86% (57/66) vs. 96% (63/66) | NR
Kumada 2017^152^ | Elbasvir + grazoprevir | <65 years: 99% (122/123); 65-74 years: 93% (70/75); ≥75 years: 93% (27/29) | Male gender: 98% (85/87); Female gender: 96% (134/140) | NR | NR
Lim 2016^156^ | Ledipasvir + sofosbuvir | <65 years: 100% (33/33); ≥65 years: 10% (13/13) | NR | NR | NR
Nelson 2015^157^; ALLY-3 | Daclatasvir + sofosbuvir | <65 years: 90% (128/142); ≥65 years: 70% (7/10) | Male gender: 86% (77/90); Female gender: 94% (58/62) | NR | NR
Sperl 2016^198^; C-EDGE H2H | Elbasvir + grazoprevir | ≤40 years: 100% (37/37); 41-50 years: 100% (31/31); 51-60 years: 98% (40/41); 61-70 years: 100% (20/20) | Male gender: 100% (55/55); Female gender: 99% (73/74) | NR | NR
Wei 2019a^164^; C-CORAL | Elbasvir + grazoprevir | <65 years: 95% (420/444); ≥65 years: 93% (39/42) | Male gender: 96% (207/216); Female gender: 93% (252/270) | Hispanic/Latino: 100% (5/5); Non-Hispanic/Latino: 94% (454/481) | NR
Wei 2019b^165^ | Sofosbuvir + velpatasvir | <65 years: 96% (340/353); ≥65 years: 100% (22/22) | Male gender: 94% (186/197); Female gender: 99% (176/178) | NR | NR
Zeuzem 2015; C-EDGE ^166^ | Grazoprevir + elbasvir | <65: 94% (270/287); ≥65: 100% (29/29) | Male gender: 93% (159/171); Female gender: 97% (140/145) | Asian: 94% (51/54); Black: 97% (57/59); White: 94% (180/191); Other: 92% (11/12) | NR
Zeuzem 2018^167^; ENDURANCE-1 | Glecaprevir + pibrentasvir | [underlined: 8-week intervention group]; <65 years: 99% (306/309); ≥65 years: 100% (42/42); [underlined: 12-week intervention group]; <65 years: 99.7% (316/317); ≥65 years: 100% (35/35) | [underlined: 8-week intervention group]; Male gender: 99% (165/167); Female gender: 99% (183/184); [underlined: 12-week intervention group]; Male gender: 100% (176/176); Female gender: 99% (175/176) | [underlined: 8-week intervention group]; Black race: 100% (14/14); Other race: 99% (334/337); [underlined: 12-week intervention group]; Black race: 92% (12/13); Other race: 100% (339/339) | [underlined: 8-week intervention group]; No current opioid substitution therapy: 99% (336/339); Current opioid substitution therapy: 100% (12/12); [underlined: 12-week intervention group]; No current opioid substitution therapy: 100% (336/336); Current opioid substitution therapy: 94% (15/16)
Zeuzem 2018^167^; ENDURANCE-3 | A. Glecaprevir 300 mg + pibrentasvir 120 mg, 8 weeks; B. Glecaprevir 300 mg + pibrentasvir 120 mg, 12 weeks; 3. Sofosbuvir 400 mg + daclatasvir 60 mg. 12 weeks | Age <65 years: 95% (144/152) vs. 95% (213/224) vs. 96% (107/111); Age ≥65 years: 100% (5/5) vs. 100% (9/9) vs. 100% (4/4) | Male gender: 93% (86/92) vs. 93% (112/121) vs. 92% (48/52); Female gender: 97% (63/65) vs. 98% (110/112) vs. 100% (63/63) | Black race: 100% (3/3) vs. 100% (4/4) vs. 75% (3/4); Not Black race: 95% (146/154) vs. (218/229) vs. 97% (108/111) | No current opioid substitution therapy: 94% (119/126) vs. 96% (188/195) vs. 96% (94/98); Current opioid substitution therapy: 97% (30/31) vs. 90% (34/38) vs. 100% (17/17)

Abbreviations: BMI = body mass index; CI = confidence interval; NR = not reported. Study names are not acronyms.

Nine trials found SVR rates were similar when analyses were stratified according to whether patients were treatment-experienced or treatment-naïve.^151–153,155,159,163,165,167,198^ Five trials (in 4 publications)^149,150,167,192^ of patients with current or recent use of methadone or buprenorphine for opioid use disorder reported SVR rates ranging from 89 to 100 percent. The other trials excluded patients with current or recent opioid use or did not report opioid use status.

#### Adolescents

Seven trials evaluated the effects of DAA regimens on SVR in adolescents with HCV infection (Appendix B Tables 7 and 8).^171,173,175,176,201–203^ Sample sizes ranged from 30 to 100 (total N=348), mean age ranged from 12 to 15 years, and the proportion of female participants ranged from 35 to 66 percent. Four studies^171,173,175,203^ were multinational (primarily conducted in the United States, Europe and/or Australia), and three were conducted in Egypt.^176,201,202^ In the four multinational studies, the majority (75% or more) of participants were white.^171,173,175,203^ The three Egyptian studies^176,201,202^ enrolled genotype 4 patients, one multinational study enrolled patients with genotype 1,^175^ and three multinational studies enrolled mixed genotypes.^171,173,203^ Patients with cirrhosis were excluded in two trials and cirrhosis/fibrosis stage inclusion criteria was not reported in a third trial. In the other four trials, enrollment of patients with cirrhosis was permitted, but two of these did not conduct liver biopsy or other testing for cirrhosis at baseline. Fibrosis stage was F0-F1 in 68 to 96 percent of the population in five studies;^171,176,201–203^ fibrosis stage was unknown in over half of participants in the other two studies. The proportion of treatment-naïve patients ranged from 66 to 100 percent. In the six trials that included treatment-experienced patients, prior HCV treatment was interferon with or without ribavirin in three trials^171,202,203^ and was unclear in three trials.^173,175,176^ Four trials evaluated DAA regimens currently recommended and FDA-approved for use in adolescents: ledipasvir and sofosbuvir (2 trials),^175,202^ sofosbuvir and ribavirin (1 trial)^173^ and glecaprevir / pibrentasvir (1 trial).^171^ Three trials evaluated DAA regimens currently recommended for adults but not FDA-approved for use in adolescents: sofosbuvir and daclatasvir (2 trials)^176,201^ and ombitasvir / paritaprevir / ritonavir / dasabuvir and weight-based ribavirin (one trial).^203^ One study was rated good quality,^176^ and the others fair quality, primarily due to unclear patient enrollment methods (Appendix B Table 9).

SVR was assessed at 12-weeks post-treatment. Therapy was administered for 12 weeks in all trials with the exception of sofosbuvir / ribavirin which was administered for 12 (genotype 2) or 24 (genotype 3) weeks in one trial, and glecaprevir / pibrentasvir which was administered for 8 weeks for 94 percent of the study population in one trial.^171^ Across all studies, the rate of SVR ranged from 97 to 100 percent (Table 14; Appendix B Tables 7 and 8). Results were similar for specific genotypes (genotype 1 [N=31]: 98% to 100%; genotype 2 [N=13]: 100%; genotype 3 [N=39]: 97%; and, genotype 4 [N=7]: 98 to 100%), though the number of adolescents with genotype 2 or 4 infection was very small. In two studies, SVR rates were 98 percent to 100 percent for both treatment-naïve and treatment-experienced patients.^175,203^

Table 14 Sustained Virologic Response Rates With Direct Acting Antiviral Regimens in Adolescents With HCV Infection

Author year; Country; Quality | Population characteristics | Antiviral treatment regimen | SVR, total population | SVR, subgroups
Abdel Ghaffar 2019^201^; Egypt; Fair | n=40; Mean age 12 years 38% female; Race NR; Fibrosis stage F0: 35%; F1: 38%; F2 and F3: 15%; Genotype 4: 100% (mixed 4 and 1a: 13%; mixed 4 and 1b: 15%); Treatment naïve: 100% | Sofosbuvir 200 to 400 mg + daclatasvir 30 to 60 mg | 98% (39/40) | NR
Balistreri 2017^175^; Multinational; Fair | n=100; Mean age 15 years; 63% female; 90% white; 7% black; 2% Asian; 1% NR; Fibrosis stage F0-F3: 42%; F4:1%;; NR/unknown: 57%; Genotype 1a: 81%; 1b: 19%; Treatment naïve: 80%; Treatment experienced 20% (prior treatment unclear; presumably IFN or pegylated IFN + ribavirin) | Ledipasvir 90 mg + sofosbuvir 400 mg* | 98% (98/100) | Treatment-naïve: 98% (78/80); Treatment-experienced: 100% (20/20)
El-Karaksy^202^ 2018; Egypt; Fair | n=40; Mean age 14 years; 35% female; Race NR; Fibrosis stage F0: 55%; F0 and F1: 13%; F1: 13%; F1 and F2: 5%; F3: 10%; F4: 5%; Genotype 4: 100%; Treatment-naïve: 75% | Ledipasvir 90 mg + sofosbuvir 400 mg* | 100% (40/40) | NR
Jonas 2019^171^; DORA; Multinational; Fair | n=48; Median age 14 years; 55% female; 75% white; 9% black; 13% Asian; 4% mixed race; Fibrosis stage F0-F1: 96%; F2: 2%; F3: 2%; Genotype 1a: 51%; 1b: 28%; 2: 6%; 3: 9%; 4: 6%; no genotype 5 or 6 enrolled; HIV coinfection: 4%; Treatment-naïve: 77%; Treatment-experienced: 23% (pegylated IFN + ribavirin) | Glecaprevir 300 mg + pibrentasvir 120 mg | 100% (47/47) | NR
Leung 2018^203^; Multinational; Fair | n=38; Median age 15 years; 66% female; 76% white; 13% black; 8% Asian; 3% mixed race; Fibrosis stage (30/38 patients): F0 and F1: 90%; F2: 3%; F3: 3%; F4: 3%; Genotype 1a: 42%; 1b: 40%; 4: 18%; Treatment naïve: 66% | Ombitasvir 25 mg + paritaprevir 150 mg + ritonavir 100 mg + dasabuvir 250 mg 2x/day + weight-based ribavirin | 100% (38/38) | Genotype 1a: 100% (16/16); Genotype 1b: 100% (15/15); Genotype 4: 100% (7/7); Treatment naïve: 100% (25/25); Treatment experienced: 100% (13/13)
Wirth 2017^173^; Multinational; Fair | n=52; Median age 15 years; 40% female; 90% white; 4% black; 2% Asian; 2% Hawaiian/Pacific Islander; 2% other; Fibrosis stage NR; 40% no cirrhosis; 60% cirrhosis presence unknown; Genotype 2: 25%; Genotype 3: 75%; Treatment-naive: 83% | Sofosbuvir 400 mg + weight-based ribavirin* | 98% (51/52) | Genotype 2: 100% (13/13); Genotype 3: 97% (38/39)
Yakoot 2018^176^; Egypt; Good | n=30; Mean age 13 years; 43% female; Race NR; Fibrosis stage F0: 17%; F1: 53%; F2: 27%; F3: 3%; Genotype 4: 100%; Treatment naïve: 73% | Sofosbuvir + daclatasvir | 97% (29/30) | NR

Abbreviations: IFN = interferon; NR = not reported; SVR = sustained virologic response.

## Key Question 8 What Are the Harms of Currently Recommended Antiviral Treatments?

### Summary

- The prior review found triple therapy with boceprevir or telaprevir plus pegylated interferon and ribavirin or dual therapy with pegylated interferon and ribavirin associated with high rates of adverse events:
  ○ Serious adverse events: Pooled rates 8.5 to 16 percent
  ○ Withdrawal due to adverse event: Pooled rates 12 to 15 percent
  ○ Fatigue: Pooled rates 51 to 64 percent
  ○ Influenza-like symptoms: Pooled rates 19 to 40 percent
  ○ Depression: Pooled rates 19 to 22 percent
  ○ Headache: Pooled rates 42 to 52 percent
  ○ Myalgia: Pooled rates 18 to 26 percent
- The prior review found triple therapy with boceprevir associated with increased risk of thrombocytopenia (3.8% vs. 1.4%, RR 3.2, 95% CI, 1.4 to 2.8) and neutropenia (33% vs. 18%, RR 1.8, 95% CI, 1.5 to 2.3) versus dual therapy, and telaprevir associated with increased risk of anemia (52% vs. 39%, RR 1.3, 95% CI, 1.1 to 1.3). Triple therapy with telaprevir was also associated with increased risk of rash versus dual therapy (49% vs. 35%, RR 1.4, 95% CI, 1.1 to 1.7) and boceprevir with increased risk of dysgeusia (35% vs. 13%, RR 2.5, 95% CI, 2.0 to 3.2).
- Four new randomized trials found current DAA regimens associated with slightly increased risk of any adverse event versus placebo (pooled RR 1.12, 95% CI, 1.02 to 1.24, I^2^=46%; adjusted risk difference [ARD] 8%, 95% CI, 2% to 15%) and nausea (pooled RR 1.42, 95% CI, 1.00 to 2.03, I^2^=10%, ARD 4%, 95% CI, −3% to 10%). There were no differences between DAA therapy versus placebo in risk of serious adverse events, withdrawal due to adverse events, diarrhea, fatigue, headache, or anemia.
- Two new randomized trials found ombitasvir / paritaprevir / ritonavir / dasabuvir with or without ribavirin associated with decreased risk of any adverse event (RR 0.65, 95% CI, 0.50 to 0.84, I^2^=87%; ARD −34%, 95% CI, −51% to −16%), serious adverse events (RR 0.08, 95% CI, 0.02 to 0.34, I^2^=0%; ARD −8%, 95% CI, −15% to −1%), withdrawal due to adverse events (RR 0.06, 95% CI, 0.01 to 0.29, I^2^=0%; ARD −9%, 95% CI, −14% to −3%), fatigue (RR 0.37, 95% CI, 0.21 to 0.63, I^2^=32%; ARD −18%, 95% CI, −27% to −10%), headache (RR 0.70, 95% CI, 0.52 to 0.95; ARD −0.10, 95% CI, −0.20 to −0.01), nausea (RR 0.31, 95% CI, 0.16 to 0.59, I^2^=65%; ARD −28%, 95% CI, −37% to −19%), anemia (RR 0.09, 95% CI, 0.04 to 0.23, I^2^=41%; ARD −37%, 95% CI, −46% to −28%), and rash (RR 0.19, 95% CI, 0.06 to 0.58, I^2^=48%; ARD −17%, 95% CI, −24% to −9%) versus telaprevir / pegylated interferon / ribavirin.
- Forty-nine new trials reported the proportion of patients on DAA regimens with adverse events:
  ○ Any adverse event (44 trials): 73.3 percent (95% CI, 68.0% to 78.1%, I^2^=95%)
  ○ Serious adverse events (44 trials): 1.9 percent (95% CI, 1.5% to 2.4%, I^2^=33%)
  ○ Withdrawal due to adverse events (44 trials): 0.4 percent (95% CI, 0.3% to 0.6%, I^2^=0%)
  ○ Anemia (13 trials): 2.4 percent (95% CI, 0.9% to 6.3%, I^2^=85%)
  ○ Fatigue (37 trials): 18.4 percent (95% CI, 15.6% to 21.7%, I^2^=90%)
  ○ Headache (42 trials): 18.7 percent (95% CI, 15.6% to 22.2%, I^2^=90%)
  ○ Insomnia (18 trials): 8.1 percent (95% CI, 6.7% to 9.9%, I^2^=60%)
  ○ Nausea (36 trials): 11.1 percent (95% CI, 9.1% to 13.5%, I^2^=82%)
  ○ Diarrhea (19 trials): 8.7 percent (95% CI, 7.0% to 10.8%, I^2^=69%)
  ○ Vomiting (6 trials): 5.8 percent (95% CI, 3.4% to 9.7%, I^2^=43%)
  ○ Rash (17 trials): 5.4 percent (95% CI, 4.1% to 7.1%, I^2^=70%)
- There was some variability by DAA regimens in adverse events estimates; estimates were generally higher for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin than without ribavirin.
- Adverse event estimates were generally similar when trials were stratified according to baseline cirrhosis status (excluded or included up to 20%) and prior antiviral therapy experience.

### Evidence

#### Adults

The prior Agency for Healthcare Research and Quality review found no difference between triple therapy with boceprevir or telaprevir plus pegylated interferon and ribavirin versus dual therapy with pegylated interferon and ribavirin in risk of serious adverse events (pooled event rates ranged from 8.5% to 16%) or withdrawal due to adverse events (pooled event rates 12% to 15%).^5,90^ There were also no differences in rates of fatigue (pooled event rates 51% to 64%), influenza-like symptoms (pooled event rates 19% to 40%), depression (pooled event rates 19% to 22%), headache (pooled event rates 42% to 52%), or myalgia (pooled event rates 18% to 26%), but these adverse events occurred frequently with all regimens. Triple therapy was associated with increased risk of hematological adverse events versus dual therapy. Boceprevir was associated with increased risk of thrombocytopenia (3.8% vs. 1.4%, RR 3.2, 95% CI, 1.4 to 2.8) and neutropenia (33% vs. 18%, RR 1.8, 95% CI, 1.5 to 2.3), and telaprevir was associated with increased risk of anemia (52% vs. 39%, RR 1.3, 95% CI, 1.1 to 1.3). Triple therapy with telaprevir was also associated with increased risk of rash versus dual therapy (49% vs. 35%, RR 1.4, 95% CI, 1.1 to 1.7) and boceprevir with increased risk of dysgeusia versus dual therapy (35% vs. 13%, RR 2.5, 95% CI, 2.0 to 3.2).

Forty-nine new trials (in 44 publications) of DAA regimens without interferon reported the proportion of patients who experienced adverse events (Table 15; Appendix B Tables 10 and 11).^137,139,141–167,185–199^ One DAA trial^158^ included in the SVR analysis was excluded from pooled analyses of adverse events because a high proportion of patients had cirrhosis (about 40%) and adverse event rates were not reported separately for persons without cirrhosis. Eleven trials (in 9 publications) of ombitasvir / paritaprevir / ritonavir / dasabuvir included ribavirin, which is recommended for treatment of genotype 1a and 4 infections.^137,149,162,186–189,191,192^ Regimens containing ribavirin were otherwise excluded from the adverse event analyses. Eight trials (in 6 publications) reporting adverse events compared a current DAA regimen versus placebo,^139,151,164,187^ triple therapy with telaprevir,^137^ or an older DAA regimen.^147^ Reporting of methods used to assess harms was suboptimal, with few details regarding use of active versus passive assessment or definitions of harms. Trial characteristics are described in more detail in KQ 7.

Table 15 Adverse Events With Direct Acting Antiviral Regimens in Adults

Author year | Treatment Regimen(s) | Comparison | Any adverse event | Serious adverse events^*^ | Withdrawal due to adverse events | Headache | Fatigue | Gastrointestinal | Anemia | Insomnia | Rash
Feld 2014^139^; SAPPHIRE-1 | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | DAA vs. Placebo | 86% (414/473) vs. 73% (116/158); RR 1.19 (95% CI, 1.08 to 1.32) | 2% (10/473) vs. 0% (0/158); RR 7.04 (95% CI, 0.42 to 120) | 0.6% (3/473) vs. 0.6% (1/158); RR 1.00 (95% CI, 0.10 to 9.56) | 33% (156/473) vs. 27% (42/158); RR 1.24 (95% CI, 0.93 to 1.66) | 35% (164/473) vs. 28% (45/158); RR 1.22 (95% CI, 0.92 to 1.60) | Nausea: 24% (112/473) vs. 13% (21/158); RR 1.78 (95% CI, 1.16 to 2.74); Diarrhea: 14% (65/473) vs. 7% (11/158); RR 1.97 (95% CI, 1.07 to 3.64) | NR | 14% (66/473) vs. 8% (12/158); RR 1.84 (95% CI, 1.02 to 3.31) | 11% (51/473) vs. (9/158); RR 1.89 (95% CI, 0.95 to 3.76)
Feld 2015^139^; ASTRAL-1 | Sofosbuvir + velpatasvir | DAA vs. Placebo | 78% (485/624) vs. 77% (89/116); RR 1.01 (95% CI, 0.91 to 1.13) | 2% (15/624) vs. 0% (0/116); RR 5.80 (95% CI, 0.35 to 96) | 0.2% (1/624) vs. 2% (2/116); RR 0.09 (95% CI, 0.01 to 1.02) | 29% (182/624) vs. 28% (33/116); RR 1.03 (95% CI, 0.75 to 1.40) | 20% (126/624) vs. 20% (23/116); RR 1.02 (95% CI, 0.68 to 1.52) | Nausea: 12% (75/624) vs. 11% (13/116); RR 1.07 (95% CI, 0.62 to 1.87); Diarrhea: 8% (48/624) vs. 7% (8/116); RR 1.12 (95% CI, 0.54 to 2.30) | NR | 8% (50/624) vs. 9% (11/116); RR 0.84 (95% CI, 0.45 to 1.57 | NR
Kumada 2015^151^; GIFT-1 (Substudy 1) | Ombitasvir + paritaprevir + ritonavir | DAA vs. Placebo | 69% (148/215) vs. 57% (60/106); RR 1.22 (95% CI, 1.01 to 1.47) | 3% (7/215) vs. 2% (2/106); RR 1.73 (95% CI, 0.36 to 8.16) | 0.9% (2/215) vs. 0% (0/106); RR 2.48 (95% CI, 0.12 to 51) | 9% (19/215) vs. 9% (10/106); RR 0.94 (95% CI, 0.45 to 1.94) | NR | Nausea: 4% (9/215) vs. 4% (4/106); RR 1.11 (95% CI, 0.35 to 3.52) | NR | NR | NR
Wei 2019a^164^; C-CORAL | Elbasvir + grazoprevir | DAA vs. Placebo | 47% (230/486) vs. 50% (62/123) | 2% (8/486) vs. 2% (2/123) | 0.6% (3/486) vs. 2% (2/123) | 6% (27/486) vs. 5% (6/123) | 5% (22/486) vs. 7% (9/123) | NR | NR | NR | NR
Dore 2016^137^; MALACHITE-1 | Ombitasvir + paritaprevir mg + ritonavir + dasabuvir | DAA vs. telaprevir / pegylated interferon / ribavirin | 49% (41/83) vs. 100% (37/37); RR 0.50 (95% CI, 0.40 to 0.62) | 0% (0/83) vs. 11% (4/37); RR 0.05 (95% CI, 0.003 to 0.91) | 0% (0/83) vs. (3/37); RR 0.07 (95% CI, 0.003 to 1.25) | 19% (16/83) 30% (11/37); RR 0.65 (95% CI, 0.33 to 1.26) | 5% (4/83) vs. 30% (11/37); RR 0.16 (95% CI, 0.06 to 0.48) | Nausea: 8% (7/83) vs. 41% (15/37); RR 0.21 (95% CI, 0.09 to 0.47) | 1% (1/83) vs. 46% (17/37); RR 0.03 (95% CI, 0.004 to 0.19) | NR | 0% (0/83) vs. (8/37); RR 0.03 (95% CI, 0.002 to 0.45)
Dore 2016^137^; MALACHITE-1 | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | DAA vs. telaprevir / pegylated interferon / ribavirin | 75% (115/153) 97% vs. (37/38); RR 0.77 (95% CI, 0.69 to 0.86) | 0.7% (1/153) vs. (5/38); RR 0.05 (95% CI, 0.01 to 0.41) | 1% (1/153) vs. (3/38); RR 0.08 (95% CI, 0.01 to 0.75) | 27% (41/153) vs. 32% (12/38); RR 0.85 (95% CI, 0.50 to 1.45) | 14% (21/153) vs. 32% (12/38); RR 0.43 (95% CI, 0.24 to 0.80) | Nausea: 21% (32/153) vs. 39% (15/38); RR 0.53 (95% CI, 0.32 to 0.87) | 7% (10/153) vs. 45% (17/38); RR 0.15 (95% CI, 0.07 to 0.29) | NR | 8% (12/153) vs. (9/38); RR 0.33 (95% CI, 0.15 to 0.73)
Dore 2016^137^; MALACHITE-2 | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | DAA vs. telaprevir / pegylated interferon / ribavirin | 62% (63/101) vs. (43/47); RR 0.68 (95% CI, 0.57 to 0.81) | 1% (1/101) vs. (2/47); RR 0.23 (95% CI, 0.02 to 2.50) | 0% (0/101) vs. 11% (5/47); RR 0.04 (95% CI, 0.002 to 0.76) | 29% (29/101) vs. 45% (21/47); RR 0.64 (95% CI, 0.41 to 1.00) | 12% (12/101) vs. 25% (12/47); RR 0.47 (95% CI, 0.23 to 0.96) | Nausea: 10% (10/101) vs. 43% (20/47); RR 0.23 (95% CI, 0.12 to 0.46) | 3% (3/101) vs. 34% (16/47); RR 0.09 (95% CI, 0.03 to 0.38) | 6% (6/101) vs. 21% (10/47); RR 0.28 (95% CI, 0.11 to 0.72) | 3% (3/101) vs. (8/47); RR 0.17 (95% CI, 0.05 to 0.63)
Abergel 2016a^142^ | Ledipasvir + sofosbuvir | NA | 71% (31/44) | 0% (0/44) | 0% (0/44) | 25% (11/44) | 20% (9/44) | Nausea: 9% (4/44); Diarrhea: 9% (4/44) | NR | NR | NR
Abergel 2016b^141^ | Ledipasvir + sofosbuvir | NA | 80% (33/41) | 2% (1/41) | 0% (0/41) | 27% (11/41) | 10% (4/41) | Diarrhea: 7% (3/41) | NR | NR | NR
Afdhal 2014^185^; ION-1 | Ledipasvir + sofosbuvir | NA | 79% (169/214) | 0.5% (1/214) | 0% (0/214) | 25% (53/214) | 21% (44/214) | Nausea: 11% (24/214); Diarrhea: 11% (24/214) | 0% | 8% (17/214) | 7% (16/214)
Ahmed 2018^195^; Egypt | Ledipasvir + sofosbuvir | NA | 26% (26/100) | NR | NR | 2% (2/100) | 18% (18/100) | Diarrhea: 1% (1/100) | NR | 2% (2/100) | NR
Andreone 2014^186^; PEARL II | Ombitasvir + paritaprevir + ritonavir + dasabuvir | NA | 77.9% (74/95) | 3% (3/95) | 0% (0/95) | 23% (22/95) | 16% (15/95) | Nausea: 6% (6/95); Diarrhea: 13% (12/95) | 0% (0/95) | NR | 1% (1/95)
Asselah 2018^196^; SURVEYOR | Glecaprevir + pibrentasvir | NA | 63% (128/203) | 1% (2/203) | 0% (0/203) | 18% (37/203) | 14% (28/203) | Nausea: 11% (23/203) | NR | NR | NR
Asselah 2019^143^; ENDURANCE 5 and 6 | Glecaprevir + pibrentasvir | NA | 55% (46/84) | 6% (5/84) | 0% (0/84) | 13% (11/84) | 13% (11/84) | NR | NR | NR | NR
Brown 2018^144^; C-SCAPE | Elbasvir + grazoprevir | NA | 79% (15/19) | 0% (0/19) | 5% (1/19) | 26% (5/19) | 16% (3/19) | Nausea: 5% (1/19) | NR | NR | NR
Chayama 2018^197^ | Glecaprevir + pibrentasvir | NA | 57% (74/129) | 0% (0/129) | 0% (0/129) | 5% (6/129) | NR | NR | NR | NR | 2% (3/129)
Chuang 2016^145^ | Ledipasvir + sofosbuvir | NA | 60% (51/60) | NR | 1% (1/85) | 14% (12/85) | 9% (8/85) | Nausea: 6% (5/85) | NR | NR | NR
Everson 2015^146^; (Part A) | Sofosbuvir + velpatasvir | NA | 70% (54/77) | 1% (1/77) | 0% (0/77) | 18% (14/77) | 18% (14/77) | Nausea: 10% (8/77); Diarrhea: 9% (7/77) | NR | 6% (5/77) | 5% (4/77)
Ferenci 2014^188^; PEARL III | Ombitasvir + paritaprevir + ritonavir + dasabuvir | NA | 67% (140/209) | 2% (4/209) | 0% (0/209) | 23% (49/209) | 23% (48/209) | Nausea: 4% (9/209); Diarrhea: 6% (13/209) | NR | NR | 3% (8/209)
Ferenci 2014^188^; PEARL IV | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | NA | 92% (92/100) | 3.0% (3/100) | 0% (0/100) | 25% (25/100) | 46% (46/100) | Nausea: 21% (21/100); Diarrhea: 14% (14/100) | NR | NR | 5% (5/100)
Foster 2015^147^; ASTRAL-2 and ASTRAL-3 | Sofosbuvir + velpatasvir | NA | 82% (337/411) | 2% (7/411) | 0.2% (1/411) | 28% (114/411) | 22% (91/411) | Nausea: 15% (60/411) | NR | 9% (37/411) | NR
Gane 2015^148^ | Ledipasvir + sofosbuvir | NA | 92% (46/50) | 10% (5/50) | 2% (1/50) | 24% (12/50) | 22% (11/50) | Nausea: 18% (9/50); Diarrhea: 12% (6/50); Vomiting: 6% (3/50) | NR | NR | NR
Grebely 2018a^150^; SIMPLIFY | Sofosbuvir + velpatasvir | NA | 83% (85/103) | 7% (7/103) | 1% (1/103) | 18% (19/103) | 22% (23/103) | Nausea: 14% (14/103); Vomiting: 4% (4/103); Diarrhea: 4% (4/103) | NR | 9% (9/103) | NR
Grebely 2018b^149^; D3FEAT | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | NA | 61% (53/87) | 6% (5/87) | 0% (0/87) | 5% (12/87) | 10% (25/87) | Nausea: 8% (20/87); Vomiting: 4% (11/87) | 5% (12/87) | 4% (11/87) | NR
Hezode 2015^189^; PEARL I | Ombitasvir + paritaprevir + ritonavir + ribavirin | NA | 88% (80/91) | 0% | 0% (0/87) | 31% (28/91) | 15% (14/91) | Nausea: 14% (13/91); Diarrhea: 11% (9/81) | NR | 13% (12/91) | NR
Kowdley 2014b^191^; AVIATOR | Ombitasvir + paritaprevir + ritonavir + dasabuvir | NA | NR | 3% (2/79) | 0% (0/79) | 19% (15/79) | 20% (16/79) | Nausea: 3% (2/79); Diarrhea: 16% (13/79) | 9% (7/79) | NR | NR
Kowdley 2014b^191^; AVIATOR | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | NA | NR | 1% (1/79) | 3% (2/79) | 27% (21/79) | 28% (22/79) | Nausea: % 1% (1/79); Diarrhea: 13% (10/79) | 9% (7/79) | NR | NR
Kowdley 2014a^190^; ION-3 | Ledipasvir + sofosbuvir | NA | 67% (355/431) | 2% (9/431) | 0.5% (2/431) | 15% (63/431) | 22% (94/431) | Nausea: 9% (39/431); Diarrhea: 6% (24/431) | 0.7% (3/431) | 6% (26/431) | 1% (3/215)
Kumada 2015^151^ | Ombitasvir + paritaprevir + ritonavir | NA | 69% (148/215) | 3% (7/215) | 0.9% (2/215) | 9% (19/215) | NR | Nausea: 4% (9/215) | NR | NR | NR
Kumada 2017^152^; (Part 2 only) | Elbasvir + grazoprevir | NA | 96% (219/227) | 5% (11/227) | 1% (3/227) | NR | NR | NR | NR | NR | NR
Kwo 2016^153^; OPTIMIST-1 | Simeprevir + sofosbuvir | NA | 66% (103/155) | 1% (1/155) | 0% (0/155) | 14% (22/155) | 12% (19/155) | 15% (23/155) | NR | NR | 6% (10/155)
Lalezari 2015^192^ | Ombitasvir + paritaprevir + ritonavir + dasabuvir + ribavirin | NA | 92% (35/38) | 8% (3/38) | 3% (1/38) | 32% (12/38) | 47% (18/38) | Nausea: 50% (19/38); Vomiting: 11% (4/38) | 11% (4/38) | 19% (7/38) | 16% (6/38)
Lawitz 2014a^154^; COSMOS | Simeprevir + sofosbuvir | NA | 79% (11/14) | 0% (0/14) | 0% (0/14) | NR | NR | NR | 0% (0/14) | NR | 7% (1/14)
Lawitz 2014b^193^; LONESTAR | Ledipasvir + sofosbuvir | NA | 45% (17/39) | 3% (1/39) | 0% (0/39) | 5% (2/39) | NR | Nausea: 8% (3/39) | NR | NR | 3% (1/39)
Lawitz 2015^155^; PEARL 1 | Ombitasvir + paritaprevir + ritonavir | NA | 93% (76/82) | 2% (2/82) | 0% (0/82) | 29% (24/82) | 7% (6/82) | Nausea: 10% (8/82); Diarrhea: 7% (6/82) | NR | NR | NR
Lim 2016^156^ | Ledipasvir + sofosbuvir | NA | 49% (46/93) | 3% (3/93) | 1% (1/93) | 8% (7/93) | 8% (7/93) | NR | NR | NR | NR
Nelson 2015^157^; ALLY-3 | Sofosbuvir + daclatasvir | NA | NR | 0.7% (1/152) | NR | 20% (30/152) | 19% (29/152) | Nausea: 12% (18/152); Diarrhea: 9% (13/152) | NR | 6% (9/152) | NR
Poordad 2017^194^; MAGELLAN-1 | Glecapravir + pibrentasvir | NA | 82% (23/28) | 4% (1/28) | 0% (0/28) | 32% (9/28) | 18% (5/28) | Nausea: 18% (5/28) | NR | 0% (0/28) | NR
Pott-Junior 2019^159^; Group A | Sofosbuvir + daclatasvir | NA | NR | NR | NR | 15% (10/65) | 23% (15/65) | Nausea: 6% (4/65); Vomiting: 2% (1/65) | NR | 6% (4/65) | 2% (1/65)
Pott-Junior 2019^159^; Group B | Simeprevir + sofosbuvir | NA | NR | NR | NR | 28% (17/60) | 28% (17/60) | Nausea: 13% (8/60); Vomiting: 5% (3/60) | NR | 10% (6/60) | 10% (6/60)
Sperl 2016^198^; C-EDGE Head-2-Head | Elbasvir + grazoprevir | NA | 52% (67/129) | 0.8% (1/129) | 0.8% (1/129) | NR | NR | NR | NR | NR | NR
Sulkowski 2014^161^; A1444040 Study | Sofosbuvir + daclatasvir | NA | 93% (38/41) | 2% (1/41) | 0% (0/141) | 34% (14/41) | 39% (16/41) | Nausea: 20% (8/41); Vomiting: 2% (1/41); Diarrhea: 5% (2/41) | NR | 10% (4/41) | NR
Sulkowski 2015^160^; C-WORTHY | Elbasvir + grazoprevir | NA | 56% (24/43; drug-related adverse events) | 0% (0/44) | 0% (0/44) | 35% (15/43) | 23% (10/43) | Nausea: 16% (7/43); Diarrhea: 12% (5/43) | NR | NR | NR
Toyoda 2018^199^; CERTAIN-2 | Glecaprevir + pibrentasvir | NA | 48% (43/90) | 2% (2/90) | 1% (1/90) | 7% (6/90) | NR | Nausea: 3% (3/90) | 0% (0/90) | NR | NR
Waked 2016^162^; AGATE-II | Ombitasvir + paritaprevir + ritonavir + ribavirin | NA | 80% (80/100) | 2% (2/100) | 0% (0/100) | 41% (41/100) | 35% (35/100) | Dyspepsia: 17% (17/100) | NR | 9% (9/100) | NR
Wei 2018^163^ | Ledipasvir + sofosbuvir | NA | 58% (120/206) | 1% (3/206) | 0% (0/206) | NR | NR | NR | NR | NR | NR
Wei 2019b^165^ | Sofosbuvir + velpatasvir | NA | 50% (189/375) | 1% (3/375) | 0% (0/375) | 5% (18/375) | NR | NR | NR | NR | NR
Zeuzem 2015^166^; C-EDGE | Elbasvir + grazoprevir | NA | 71% (175/246) | 3% (7/246) | 0.8% (2/246) | NR | NR | NR | NR | NR | NR
Zeuzem 2018^167^; ENDURANCE-1 | Glecaprevir + pibrentasvir | NA | 64% (450/703) | 1% (9/703) | 0.1% (1/703) | 18% (130/703) | 11% (74/703) | Nausea: 7% (48/703) | NR | NR | NR
Zeuzem 2018^167^; ENDURANCE-3 (Glecaprevir + pibrentasvir arm) | Glecaprevir + pibrentasvir | NA | 71% (275/390) | 2% (8/390) | 0.8% (3/390) | 23% (91/390) | 16% (64/390) | Nausea: 13% (51/390) | NR | NR | NR
Zeuzem 2018^167^; ENDURANCE-3 (Sofosbuvir + daclatasvir arm) | Sofosbuvir + daclatasvir | NA | 70% (80/115) | 2% (2/115) | 0.9% (1/115) | 20% (23/115) | 14% (16/115) | Nausea: 13% (15/115) | NR | NR | NR

* Serious adverse events listed in Appendix B Table 12

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; NA = not applicable; NR = not reported; RR = relative risk. Study names are not acronyms.

##### Adverse Events in Comparative Trials

###### DAA Regimen vs. Placebo

Four randomized trials (total N=2,113) reported adverse events associated with current DAA regimens versus placebo.^139,151,164,187^ Each trial evaluated a different DAA regimen: sofosbuvir / velpatasvir (n=706),^139^ ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (n=477),^187^ ombitasvir / paritaprevir / dasabuvir (n=321),^151^ and elbasvir / grazoprevir (n=609)^164^ (Table 15, Appendix B Tables 10 and 11). The trials of sofosbuvir / velpatasvir and elbasvir / grazoprevir enrolled people with mixed genotype (1, 2, 4, 5, and/or 6) infections, and the other trials enrolled persons with genotype 1 infection. One trial enrolled treatment-naïve patients;^164^ in the remaining trials, approximately one-third of patients had previously received interferon therapy. In two trials,^139,164^ approximately 19 percent of patients had cirrhosis at baseline, and the other two trials restricted enrollment to persons without cirrhosis. All trials used a double-blind design.

DAA therapy was associated with slightly increased risk of any adverse event versus placebo that was of borderline statistical significance (4 trials, RR 1.12, 95% CI, 1.02 to 1.24, I^2^=46%; ARD 8%, 95% CI, 8% to 15%; Figure 9).^139,151,164,187^ Among patients randomized to DAA therapy, the proportion reporting any adverse event ranged from 47 percent to 86 percent. There were no differences between DAA therapy versus placebo in risk of serious adverse events (4 trials, RR 1.90, 95% CI, 0.73 to 4.95, I^2^=0%; Figure 10) or withdrawal due to adverse events (4 trials, RR 0.47, 95% CI, 0.14 to 1.58, I^2^=14%; Figure 11), though there were few events and estimates were imprecise.^139,151,164,187^ Among patients randomized to DAA therapy, the proportion with serious adverse events ranged from 2.0 percent to 3.3 percent, and the proportion who withdrew due to adverse events ranged from 0.2 percent to 0.9 percent. DAA therapy was associated with increased risk of nausea versus placebo (3 trials, RR 1.42, 95% CI, 1.00 to 2.03, I^2^=10%; ARD 4%, 95% CI, -3% to 10%; Figure 12).^139,151,187^ The point estimate was similar for diarrhea, but the difference was not statistically significant (2 trials, RR 1.53, 95% CI, 0.88 to 2.68, I^2^=29%; Figure 13).^139,187^ There were no differences between DAA therapy versus placebo in risk of fatigue (3 trials, RR 1.05, 95% CI, 0.78 to 1.40; I^2^=32%; Figure 14)^139,164,187^ or headache (four trials, RR 1.12, 95% CI, 0.92 to 1.37, I^2^=0%; Figure 15).^139,151,164,187^ One trial^139^ found no difference between sofosbuvir / velpatasvir versus placebo in risk of anemia (0.3% vs. 0%, RR 2.21, 95% CI, 0.11 to 46); no cases of anemia were reported in the other three trials.

Figure 9 Key Question 8: Direct Acting Antiviral Regimens vs. Placebo, Any Adverse Events

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 9 is a forest plot examining any adverse events comparing direct acting antiviral regimens versus placebo with 4 subgroups. The Mantel-Haenszel risk ratio for 1 study in the ombitasvir/paritaprevir/ritonavir subgroup is 1.22 (95% confidence interval 1.01 to 1.47) with Z score value of 2.02. The Mantel-Haenszel risk ratio for the 1 study in the ombitasvir/paritaprevir/ritonavir/dasabuvir/ribavirin subgroup is 1.19 (95% confidence interval 1.08 to 1.32) with Z score value of 3.45. The Mantel-Haenszel risk ratio for the 1 study in the sofosbuvir/velpatasvir subgroup is 1.01 (95% confidence interval 0.91 to 1.13) with Z score value of 0.23. The Mantel-Haenszel risk ratio for the 1 study in the elbasvir/grazoprevir subgroup is 1.12 (95% confidence interval 0.89 to 1.40) with Z score value of 0.97. The overall Mantel-Haenszel risk ratio is 1.12 (95% confidence interval 1.02 to 1.24) with Z score value of 2.36.

Figure 10 Key Question 8: Direct Acting Antiviral Regimens vs. Placebo, Serious Adverse Events

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 10 is a forest plot examining serious adverse events comparing direct acting antiviral regimens versus placebo with 4 subgroups. The Mantel-Haenszel risk ratio for 1 study in the ombitasvir/paritaprevir/ritonavir subgroup is 1.73 (95% confidence interval 0.36 to 8.16) with Z score value of 0.69. The Mantel-Haenszel risk ratio for the 1 study in the ombitasvir/paritaprevir/ritonavir/dasabuvir/ribavirin subgroup is 7.04 (95% confidence interval 0.42 to 119.53) with Z score value of 1.35. The Mantel-Haenszel risk ratio for the 1 study in the sofosbuvir/velpatasvir subgroup is 5.80 (95% confidence interval 0.35 to 96.32) with Z score value of 1.23. The Mantel-Haenszel risk ratio for the 1 study in the elbasvir/grazoprevir subgroup is 1.01 (95% confidence interval 0.22 to 4.71) with Z score value of 0.02. The overall Mantel-Haenszel risk ratio is 1.90 (95% confidence interval 0.73 to 4.95) with Z score value of 1.31.

Figure 11 Key Question 8: Direct Acting Antivirals Regimens vs. Placebo, Withdrawals Due to Adverse Events

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 11 is a forest plot examining withdrawals due to adverse events comparing direct acting antiviral regimens versus placebo with 4 subgroups. The Mantel-Haenszel risk ratio for 1 study in the ombitasvir/paritaprevir/ritonavir subgroup is 2.48 (95% confidence interval 0.12 to 51.14) with Z score value of 0.59. The Mantel-Haenszel risk ratio for the 1 study in the ombitasvir/paritaprevir/ritonavir/dasabuvir/ribavirin subgroup is 1.00 (95% confidence interval 0.10 to 9.56) with Z score value of 0.00. The Mantel-Haenszel risk ratio for the 1 study in the sofosbuvir/velpatasvir subgroup is 0.09 (95% confidence interval 0.01 to 1.02) with Z score value of 1.95. The Mantel-Haenszel risk ratio for the 1 study in the elbasvir/grazoprevir subgroup is 0.38 (95% confidence interval 0.06 to 2.25) with Z score value of 1.07. The overall Mantel-Haenszel risk ratio is 0.47 (95% confidence interval 0.14 to 1.58) with Z score value of 1.23.

Figure 12 Key Question 8: Direct Acting Antivirals Regimens vs. Placebo, Nausea

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test.

Figure 12 is a forest plot examining nausea comparing direct acting antiviral regimens versus placebo with 3 subgroups. The Mantel-Haenszel risk ratio for 1 study in the ombitasvir/paritaprevir/ritonavir subgroup is 1.11 (95% confidence interval 0.35 to 3.52) with Z score value of 0.18. The Mantel-Haenszel risk ratio for the 1 study in the ombitasvir/paritaprevir/ritonavir/dasabuvir/ribavirin subgroup is 1.78 (95% confidence interval 1.16 to 2.74) with Z score value of 2.63. The Mantel-Haenszel risk ratio for the 1 study in the sofosbuvir/velpatasvir subgroup is 1.07 (95% confidence interval 0.62 to 1.87) with Z score value of 0.25. The overall Mantel-Haenszel risk ratio is 1.42 (95% confidence interval 1.00 to 2.03) with Z score value of 1.94.

Figure 13 Key Question 8: Direct Acting Antiviral Regimens vs. Placebo, Diarrhea

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test.

Figure 13 is a forest plot examining diarrhea comparing direct acting antiviral regimens versus placebo with 2 subgroups. The Mantel-Haenszel risk ratio for 1 study in the ombitasvir/paritaprevir/ritonavir/dasabuvir/ribavirin subgroup is 1.97 (95% confidence interval 1.07 to 3.64) with Z score value of 2.17. The Mantel-Haenszel risk ratio for the 1 study in the sofosbuvir/velpatasvir subgroup is 1.12 (95% confidence interval 0.54 to 2.30) with Z score value of 0.30. The overall Mantel-Haenszel risk ratio is 1.53 (95% confidence interval 0.88 to 2.68) with Z score value of 1.50.

Figure 14 Key Question 8: Direct Acting Antiviral Regimens vs. Placebo, Fatigue

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 14 is a forest plot examining fatigue comparing direct acting antiviral regimens versus placebo with 3 subgroups. The Mantel-Haenszel risk ratio for 1 study in the ombitasvir/paritaprevir/ritonavir/dasabuvir/ribavirin subgroup is 1.22 (95% confidence interval 0.92 to 1.60) with Z score value of 1.40. The Mantel-Haenszel risk ratio for the 1 study in the sofosbuvir/velpatasvir subgroup is 1.02 (95% confidence interval 0.68 to 1.52) with Z score value of 0.09. The Mantel-Haenszel risk ratio for the 1 study in the elbasvir/grazoprevir subgroup is 0.62 (95% confidence interval 0.29 to 1.31) with Z score value of 1.26. The overall Mantel-Haenszel risk ratio is 1.05 (95% confidence interval 0.78 to 1.40) with Z score value of 0.32.

Figure 15 Key Question 8: Direct Acting Antiviral Regimens vs. Placebo, Headache

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 15 is a forest plot examining headache comparing direct acting antiviral regimens versus placebo with 4 subgroups. The Mantel-Haenszel risk ratio for 1 study in the ombitasvir/paritaprevir/ritonavir subgroup is 0.94 (95% confidence interval 0.45 to 1.94) with Z score value of 0.18. The Mantel-Haenszel risk ratio for 1 study in the ombitasvir/paritaprevir/ritonavir/dasabuvir/ribavirin subgroup is 1.24 (95% confidence interval 0.93 to 1.66) with Z score value of 1.46. The Mantel-Haenszel risk ratio for the 1 study in the sofosbuvir/velpatasvir subgroup is 1.03 (95% confidence interval 0.75 to 1.40) with Z score value of 0.16. The Mantel-Haenszel risk ratio for the 1 study in the elbasvir/grazoprevir subgroup is 1.14 (95% confidence interval 0.48 to 2.70) with Z score value of 0.30. The overall Mantel-Haenszel risk ratio is 1.12 (95% confidence interval 0.92 to 1.37) with Z score value of 1.12.

###### DAA Regimen vs. Telaprevir / Pegylated Interferon / Ribavirin

Two randomized trials (reported in one publication) compared ombitasvir / paritaprevir / ritonavir / dasabuvir with or without ribavirin for 12 weeks versus triple therapy with telaprevir (12 weeks) / pegylated interferon / ribavirin (24 or 48 weeks) in patients with genotype 1 infection.^137^ One trial (n=311) enrolled treatment-naïve patients, and one trial (n=148) enrolled patients previously treated with pegylated interferon and ribavirin. The DAA regimen was associated with decreased risk of any adverse event (RR 0.65, 95% CI, 0.50 to 0.84, I^2^=87%; ARD −34%, 95% CI, −51% to −16%; Figure 16), serious adverse events (RR 0.08, 95% CI, 0.02 to 0.34, I^2^=0%; ARD −8%, 95% CI, −15% to −1%; Figure 17), withdrawal due to adverse events (RR 0.06, 95% CI, 0.01 to 0.29, I^2^=0%; ARD −9%, 95% CI, −14% to −3%; Figure 18), fatigue (RR 0.37, 95% CI, 0.21 to 0.63, I^2^=32%; ARD −18%, 95% CI, −27% to −10%; Figure 19), headache (RR 0.70, 95% CI, 0.52 to 0.95, I^2^=0%; ARD −0.10, 95% CI, −0.20 to −0.01; Figure 20), nausea (RR 0.31, 95% CI, 0.16 to 0.59, I^2^=65%; ARD −28%, 95% CI, −37% to −19%; Figure 21), anemia (RR 0.09, 95% CI, 0.04 to 0.23, I^2^=41%; ARD −37%, 95% CI, −46% to −28%; Figure 22), and rash (RR 0.19, 95% CI, 0.06 to 0.58, I^2^=48%; ARD −17%, 95% CI, −24% to −9%; Figure 23) versus the telaprevir regimen. The association between DAA therapy versus telaprevir and risk of any adverse event was less pronounced when ribavirin was included with DAA therapy (2 trials, RR 0.74, 95% CI, 0.65 to 0.84, I^2^=43%; Figure 16) than without ribavirin (1 trial, RR 0.50, 95% CI, 0.40 to 0.62; p for interaction=0.003). There was no interaction between prior antiviral treatment experience and risk estimates for any adverse event.

Figure 16 Key Question 8: Direct Acting Antiviral Regimens vs. Telaprevir, Any Adverse Events

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 16 is a forest plot examining any adverse events comparing direct acting antiviral regimens versus telaprevir with 2 subgroups. The Mantel-Haenszel risk ratio for 2 studies in the ribavirin subgroup is 0.74 (95% confidence interval 0.65 to 0.84) with Z score value of 4.56. The Mantel-Haenszel risk ratio for 1 study in the no ribavirin subgroup is 0.50 (95% confidence interval 0.40 to 0.62) with Z score value of 6.18. The overall Mantel-Haenszel risk ratio is 0.65 (95% confidence interval 0.50 to 0.84) with Z score value of 3.29.

Figure 17 Key Question 8: Direct Acting Antiviral Regimens vs. Telaprevir, Serious Adverse Events

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 17 is a forest plot examining serious adverse events comparing direct acting antiviral regimens versus telaprevir with 2 subgroups. The Mantel-Haenszel risk ratio for 2 studies in the ribavirin subgroup is 0.10 (95% confidence interval 0.02 to 0.48) with Z score value of 2.88. The Mantel-Haenszel risk ratio for 1 study in the no ribavirin subgroup is 0.05 (95% confidence interval 0.00 to 0.91) with Z score value of 2.02. The overall Mantel-Haenszel risk ratio is 0.08 (95% confidence interval 0.02 to 0.34) with Z score value of 3.49.

Figure 18 Key Question 8: Direct Acting Antiviral Regimens vs. Telaprevir, Withdrawal Due to Adverse Events

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 18 is a forest plot examining withdrawal due to adverse events comparing direct acting antiviral regimens versus telaprevir with 2 subgroups. The Mantel-Haenszel risk ratio for 2 studies in the ribavirin subgroup is 0.06 (95% confidence interval 0.01 to 0.37) with Z score value of 3.06. The Mantel-Haenszel risk ratio for 1 study in the no ribavirin subgroup is 0.07 (95% confidence interval 0.00 to 1.25) with Z score value of 1.81. The overall Mantel-Haenszel risk ratio is 0.06 (95% confidence interval 0.01 to 0.29) with Z score value of 3.56.

Figure 19 Key Question 8: Direct Acting Antiviral Regimens vs. Telaprevir, Fatigue

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 19 is a forest plot examining fatigue comparing direct acting antiviral regimens versus telaprevir with 2 subgroups. The Mantel-Haenszel risk ratio for 2 studies in the ribavirin subgroup is 0.45 (95% confidence interval 0.28 to 0.71) with Z score value of 3.37. The Mantel-Haenszel risk ratio for 1 study in the no ribavirin subgroup is 0.16 (95% confidence interval 0.06 to 0.48) with Z score value of 3.31. The overall Mantel-Haenszel risk ratio is 0.37 (95% confidence interval 0.21 to 0.63) with Z score value of 3.67.

Figure 20 Key Question 8: Direct Acting Antiviral Regimens vs. Telaprevir, Headache

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 20 is a forest plot examining headache comparing direct acting antiviral regimens versus telaprevir with 2 subgroups. The Mantel-Haenszel risk ratio for 2 studies in the ribavirin subgroup is 0.72 (95% confidence interval 0.51 to 1.01) with Z score value of 1.89. The Mantel-Haenszel risk ratio for 1 study in the no ribavirin subgroup is 0.65 (95% confidence interval 0.33 to 1.26) with Z score value of 1.28. The overall Mantel-Haenszel risk ratio is 0.70 (95% confidence interval 0.52 to 0.95) with Z score value of 2.27.

Figure 21 Key Question 8: Direct Acting Antiviral Regimens vs. Telaprevir, Nausea

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 21 is a forest plot examining nausea comparing direct acting antiviral regimens versus telaprevir with 2 subgroups. The Mantel-Haenszel risk ratio for 2 studies in the ribavirin subgroup is 0.36 (95% confidence interval 0.16 to 0.82) with Z score value of 2.44. The Mantel-Haenszel risk ratio for 1 study in the no ribavirin subgroup is 0.21 (95% confidence interval 0.09 to 0.47) with Z score value of 3.80. The overall Mantel-Haenszel risk ratio is 0.31 (95% confidence interval 0.16 to 0.59) with Z score value of 3.57.

Figure 22 Key Question 8: Direct Acting Antiviral Regimens vs. Telaprevir, Anemia

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 22 is a forest plot examining anemia comparing direct acting antiviral regimens versus telaprevir with 2 subgroups. The Mantel-Haenszel risk ratio for 2 studies in the ribavirin subgroup is 0.13 (95% confidence interval 0.07 to 0.23) with Z score value of 6.72. The Mantel-Haenszel risk ratio for 1 study in the no ribavirin subgroup is 0.03 (95% confidence interval 0.00 to 0.19) with Z score value of 3.61. The overall Mantel-Haenszel risk ratio is 0.09 (95% confidence interval 0.04 to 0.23) with Z score value of 5.31.

Figure 23 Key Question 8: Direct Acting Antiviral Regimens vs. Telaprevir, Rash

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; df = degrees of freedom; M-H = Mantel-Haenszel test. Study names are not acronyms.

Figure 23 is a forest plot examining rash comparing direct acting antiviral regimens versus telaprevir with 2 subgroups. The Mantel-Haenszel risk ratio for 2 studies in the ribavirin subgroup is 0.28 (95% confidence interval 0.14 to 0.54) with Z score value of 3.74. The Mantel-Haenszel risk ratio for 1 study in the no ribavirin subgroup is 0.03 (95% confidence interval 0.00 to 0.45) with Z score value of 2.51. The overall Mantel-Haenszel risk ratio is 0.19 (95% confidence interval 0.06 to 0.58) with Z score value of 2.95.

##### Pooled Adverse Event Rates for DAA Regimens

###### Any Adverse Event

Forty-four trials (in 41 publications, total N=8,045) reported the proportion of patients reporting any adverse event with eight different DAA regimens.^137,139,141–156,159–167,185–190,192–199^ Across regimens, the pooled rate for any adverse event was 73.3% (95% CI, 68.0% to 78.1%, I^2^=95%; Figure 24). Stratified by antiviral regimen, the rate of any adverse event ranged from 62.3% (95% CI, 56.1% to 68.1%) for glecaprevir / pibrentasvir (7 trials) to 82.7% (95% CI, 58.5% to 94.2%) for sofosbuvir / daclatasvir (2 trials). The rate of any adverse event was higher in trials of ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (10 trials [in 8 publications] pooled event rate 81.1%, 95% CI, 74.2% to 86.5%; I^2^=87%) than without ribavirin (6 trials, pooled event rate 75.1%, 95% CI, 62.3% to 84.6%; I^2^=92%) (Table 16). The proportion of patients with any adverse event was similar when trials were stratified according to whether they excluded patients with cirrhosis (24 trials, pooled event rate 75.5%, 95% CI, 69.0% to 81.1%) or included some patients with cirrhosis (19 trials, pooled event rate 72.4%, 95% CI, 64.6% to 79.0%; p for interaction=0.52), and there was no interaction between prior treatment experience status and rates of any adverse event (p for interaction=0.76).

Figure 24 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Any Adverse Event

Abbreviations: CI = confidence interval; Tx = treatment; U.S. = United States.

Figure 24 is a forest plot examining pooled rates for any adverse event comparing 8 direct acting antiviral regimens. The proportion for 10 studies in the ledipasvir/sofosbuvir subgroup is 0.694 (95% confidence interval 0.548 to 0.809) with an I-squared value of 95.3%. The proportion for the 2 studies in the simeprevir/sofosbuvir subgroup is 0.675 (95% confidence interval 0.600 to 0.741) with an I-squared value of 0.0%. The proportion for the 6 studies in the sofosbuvir/velpatasvir subgroup is 0.746 (95% confidence interval 0.635 to 0.832) with an I-squared value of 96.4%. The proportion for the 6 studies in the elbasvir/grazoprevir subgroup is 0.791 (95% confidence interval 0.500 to 0.868) with an I-squared value of 98.0%. The proportion for the 2 studies in the sofosbuvir/daclatasvir subgroup is 0.827 (95% confidence interval 0.585 to 0.942) with an I-squared value of 90.5%. The proportion for the 7 studies in the glecaprevir/pibrentasvir subgroup is 0.623 (95% confidence interval 0.561 to 0.681) with an I-squared value of 77.7%. The proportion for the 6 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.751 (95% confidence interval 0.623 to 0.846) with an I-squared value of 91.6%. The proportion for the 10 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.811 (95% confidence interval 0.742 to 0.865) with an I-squared value of 87.2%. The overall proportion is 0.733 (95% confidence interval 0.680 to 0.781) with an I-squared value of 94.712%.

Table 16 Pooled Rates With Direct Acting Antiviral Regimens in Adults for Any Adverse Event, Serious Adverse Events, and Withdrawals Due to Adverse Events

Analysis | Any adverse event: Pooled rate (95% CI); I^2^; number of studies (k) | Serious adverse events: Pooled rate (95% CI); I^2^; number of studies (k) | Withdrawal due to adverse event: Pooled rate (95% CI): I^2^; number of studies (k)
All studies | 73.3% (68.0% to 78.1%); I^2^=95%; k=44^137,139,141–156,159–167,185–190,192–199^ | 1.9% (1.5% to 2.4%); I^2^=33%; k=44^137,139,141–144,146–157,160–167,185–194,196–199^ | 0.4% (0.3% to 0.6%); I^2^=0%; k=44^137,139,141–156,160,161,163–167,185–194,196–199^
- Ledipasvir / sofosbuvir | 69.4% (54.8% to 80.9%); I^2^=95%; k=10^141,142,145,148,156,163,185,190,193,195^ | 2.0% (1.0% to 3.9%); I^2^=47%; k=8^141,142,148,156,163,185,190,193^ | 0.4% (0.2% to 1.0%); I^2^=0%; k=9^141,142,145,148,156,163,185,190,193^
- Simeprevir / sofosbuvir | 67.5% (60.0% to 74.1%); I^2^=0%; k=2^153,156^ | 0.6% (0.1% to 4.1%); I^2^=0%; k=2^153,156^ | 0% (0% to 21.6%); I^2^=0%; k=2^*^,^153,156^
- Sofosbuvir / daclatasvir | 82.7% (58.5% to 94.2%); I^2^=90%; k=2^161,167^ | 1.3% (0.5% to 3.4%); I^2^=0%; k=3^157,161,167^ | 0.6% (0.1% to 4.4%); I^2^=0%; k=2^161,167^
- Sofosbuvir / velpatasvir | 74.6% (63.5% to 83.2%); I^2^=96%; k=6^139,146,147,150,165^ | 1.9% (0.1% to 4.1%); I^2^=57%; k=6^139,146,147,150,165^ | 0.2% (0.1% to 0.6%); I^2^=0%; k=6^139,146,147,150,165^
- Glecaprevir / pibrentasvir | 62.3% (56.1% to 68.1%); I^2^=78%; k=7^143,167,194,196,197,199^ | 1.7% (1.0% to 2.8%); I^2^=51%; k=7^143,167,194,196,197,199^ | 0.3% (0.1% to 0.9%); I^2^=0%; k=7^143,167,194,196,197,199^
- Elbasvir / grazoprevir | 79.1% (50.0% to 86.8%); I^2^=98%; k=6^144,152,160,164,166,198^ | 2.1% (1.1% to 3.9%); I^2^=42%; k=6^144,152,160,164,166,198^ | 0.9% (0.5% to 1.6%); I^2^=0%; k=6^144,152,160,164,166,198^
- Ombitasvir / paritaprevir / ritonavir / dasabuvir | 75.1% (62.3% to 84.6%); I^2^=92%; k=6^137,151,155,186,188^ | 1.9% (1.2% to 3.2%); I^2^=31%; k=7^137,151,155,186,188,191^ | 0.1% (0% to 4.0%); I^2^=0%; k=7^137,151,155,186,188,191^
- Ombitasvir / paritaprevir / ritonavir / dasabuvir/ ribavirin | 81.1% (74.2% to 86.5%); I^2^=87%; k=10^137,149,162,186–189,192^ | 2.1% (1.5% to 3.0%); I^2^=26%; k=11^137,149,162,186–189,191,192^ | 0.6% (0.3% to 1.1%); I^2^=11%; k=11^137,149,162,186–189,191,192^
- Patients with cirrhosis excluded | 75.5% (69.0% to 81.1%); I^2^=94%; k=24^137,144,146,151–155,160,167,186–190,192–194,196,197,199^ | 1.8% (1.3% to 2.5%); I^2^=22%; k=23^144,146,151–154,160,167,186–194,196,197,199^ | 0.5% (0.3% to 0.7%); I^2^=14%; k=23^144,146,151–155,160,167,186–194,196,197,199^
- Some patients (<20% of sample) with cirrhosis | 72.4% (64.6% to 79.0%); I^2^=95%; k=19^139,141–143,145,147–150,156,161–166,185,198^ | 2.0% (1.4% to 2.7%); I^2^=51%; k=21^137,139,141–143,147–150,156,157,161–166,185,198^ | 0.3% (0.2% to 0.6%); I^2^=0%; k=21^137,139,141,143,145,147–150,156,161,162,164–166,185,198^
- Treatment-naïve | 74.0% (66.6% to 80.2%); I^2^=95%; k=23^137,141,142,144–146,148,149,156,160–162,164,166,167,185,187–190,193,195^ | 1.8% (1.4% to 2.4%); I^2^=16%; k=24^137,141,142,144,146,148,149,156,157,160–162,164,166,167,185,187–191,193^ | 0.5% (0.3% to 0.8%); I^2^=0%; k=23^137,141,142,144–146,148,149,156,160–162,164,166,167,185,187–191,193^
- Treatment-experienced | 76.6% (61.5% to 87.0%); I^2^=72%; k=5^137,154,186,189,194^ | 1.7% (0.7% to 4.0%); I^2^=0%; k=5^137,154,186,189,194^ | 0.5% (0.1% to 2.1%); I^2^=0%; k=5^*^,^137,154,186,189,194^
- Mixed treatment-naïve and experienced | 71.0% (62.0% to 78.6%); I^2^=96.0%; k=17^139,143,147,148,151–153,155,163,165,192,196–199^ | 1.9% (1.4% to 2.6%); I^2^=51%; k=17^139,143,147,148,151–153,155,163,165,192,196–199^ | 0.3% (0.2% to 0.5%); I^2^=8%; k=17^139,143,147,148,151–153,155,163,165,167,192,196–199^

* No events reported

Abbreviation: CI = confidence interval.

###### Serious Adverse Events

Forty-four trials (in 40 publications, total N=8,070) reported the proportion of patients reporting serious adverse events with eight different DAA regimens.^137,139,141–144,146–157,160–167,185–194,196–199^ Across regimens, the pooled rate for serious adverse events was 1.9 percent (95% CI, 1.5% to 2.4%, I^2^=33%; Figure 25). Stratified by antiviral regimen, the rate of any adverse event ranged from 0.6 percent (95% CI, 0.1% to 4.1%, I^2^=0%) for simeprevir / sofosbuvir (2 trials) to 2.1 percent for elbasvir / grazoprevir (6 trials, 95% CI, 1.1% to 3.9%, I^2^=42%) and ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (11 trials, 95% CI, 1.5% to 3.0%, I^2^=26%) (Table 16). The rate of serious adverse events for ombitasvir / paritaprevir / ritonavir / dasabuvir without ribavirin (7 trials, pooled event rate 1.9%, 95% CI, 1.2% to 3.2%, I^2^=31%) was similar to the rate with ribavirin. Estimates were similar when trials were stratified according to whether they excluded patients with cirrhosis (23 trials, pooled event rate 1.8%, 95% CI, 1.3% to 2.5%) or included some patients with cirrhosis (21 trials, pooled event rate 2.0%, 95% CI, 1.4% to 2.7%; p for interaction=0.69), and there was no interaction between prior treatment experience status and rates of serious adverse events (p for interaction=0.96).

Figure 25 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Serious Adverse Events

Abbreviations: CI = confidence interval; Tx = treatment; U.S. = United States

Figure 25 is a forest plot examining pooled rates for serious adverse events comparing 8 direct acting antiviral regimens. The proportion for 8 studies in the ledipasvir/sofosbuvir subgroup is 0.020 (95% confidence interval 0.010 to 0.039) with an I-squared value of 47.0%. The proportion for the 2 studies in the simeprevir/sofosbuvir subgroup is 0.006 (95% confidence interval 0.001 to 0.041) with an I-squared value of 0.0%. The proportion for the 6 studies in the sofosbuvir/velpatasvir subgroup is 0.019 (95% confidence interval 0.001 to 0.041) with an I-squared value of 57.0%. The proportion for the 6 studies in the elbasvir/grazoprevir subgroup is 0.021 (95% confidence interval 0.011 to 0.039) with an I-squared value of 41.6%. The proportion for the 3 studies in the sofosbuvir/daclatasvir subgroup is 0.013 (95% confidence interval 0.005 to 0.034) with an I-squared value of 0.0%. The proportion for the 7 studies in the glecaprevir/pibrentasvir subgroup is 0.017 (95% confidence interval 0.010 to 0.028) with an I-squared value of 50.6%. The proportion for the 7 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.019 (95% confidence interval 0.012 to 0.032) with an I-squared value of 31.2%. The proportion for the 11 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.021 (95% confidence interval 0.015 to 0.030) with an I-squared value of 26.4%. The overall proportion is 0.019 (95% confidence interval 0.015 to 0.024) with an I-squared value of 32.712%.

###### Withdrawal Due to Adverse Events

Forty-four trials (in 40 publications, total N=8,060) reported the proportion of patients who withdrew due to adverse events with eight different DAA regimens.^137,139,141–156,160–167,185–194,196–199^ Across regimens, there were a total of 35 withdrawals due to adverse events, with a pooled rate of 0.4 percent (95% CI, 0.3% to 0.6%, I^2^=0%; Figure 26). The proportion of patients who withdrew due to adverse events was less than or equal to 1 percent for all regimens (Table 16).

Figure 26 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Withdrawal Due to Adverse Events

Abbreviations: CI = confidence interval; NR = not reported; Tx = treatment; U.S. = United States.

Figure 26 is a forest plot examining pooled rates for withdrawal due to adverse events comparing 8 direct acting antiviral regimens. The proportion for 9 studies in the ledipasvir/sofosbuvir subgroup is 0.004 (95% confidence interval 0.002 to 0.010) with an I-squared value of 0.0%. The proportion for the 2 studies in the simeprevir/sofosbuvir subgroup is 0.000 (95% confidence interval 0.000 to 0.216) with an I-squared value of 0.0%. The proportion for the 6 studies in the sofosbuvir/velpatasvir subgroup is 0.002 (95% confidence interval 0.001 to 0.006) with an I-squared value of 0.0%. The proportion for the 6 studies in the elbasvir/grazoprevir subgroup is 0.009 (95% confidence interval 0.005 to 0.016) with an I-squared value of 0.0%. The proportion for the 2 studies in the sofosbuvir/daclatasvir subgroup is 0.006 (95% confidence interval 0.001 to 0.044) with an I-squared value of 0.0%. The proportion for the 7 studies in the glecaprevir/pibrentasvir subgroup is 0.003 (95% confidence interval 0.001 to 0.009) with an I-squared value of 0.0%. The proportion for the 7 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.001 (95% confidence interval 0.000 to 0.040) with an I-squared value of 0.0%. The proportion for the 11 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.006 (95% confidence interval 0.003 to 0.011) with an I-squared value of 11.2%. The overall proportion is 0.004 (95% confidence interval 0.003 to 0.006) with an I-squared value of 0.000%.

###### Anemia

Thirteen trials (in 9 publications, total N=1,555) reported the proportion of patients with anemia with five different DAA regimens.^137,149,154,185,186,190–192,199^ Across regimens, the pooled rate for anemia was 2.4 percent (95% CI, 0.9% to 6.3%, I^2^=85%; Figure 27). The rate of anemia was much higher in trials of ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (6 trials, pooled event rate 8.3%, 95% CI, 5.8% to 11.8%, I^2^=49%) than the same regimen without ribavirin (3 trials, pooled event rate 0.8%, 95% CI, 0.2% to 3.1%, I^2^=0%) or with other regimens (pooled event rates <0.5%) (Table 17).

Figure 27 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Anemia

Abbreviations: CI = confidence interval; Tx = treatment; U.S. = United States.

Figure 27 is a forest plot examining pooled rates for anemia comparing 5 direct acting antiviral regimens. The proportion for 2 studies in the ledipasvir/sofosbuvir subgroup is 0.005 (95% confidence interval 0.002 to 0.014) with an I-squared value of 43.9%. The proportion for the 1 study in the simeprevir/sofosbuvir subgroup is 0.000 (95% confidence interval 0.000 to 0.232). The proportion for the 1 study in the glecaprevir/pibrentasvir subgroup is 0.000 (95% confidence interval 0.000 to 0.040). The proportion for the 3 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.008 (95% confidence interval 0.002 to 0.031) with an I-squared value of 0.0%. The proportion for the 6 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.083 (95% confidence interval 0.058 to 0.118) with an I-squared value of 48.6%. The overall proportion is 0.024 (95% confidence interval 0.009 to 0.063) with an I-squared value of 85.194%.

Table 17 Pooled Rates With Direct Acting Antiviral Regimens in Adults for Anemia, Fatigue, Headache, and Insomnia

Analysis | Anemia: Pooled rate (95% CI); I^2^; number of studies (k) | Fatigue: Pooled rate (95% CI); I^2^; number of studies (k) | Headache: Pooled rate (95% CI): I^2^; number of studies (k) | Insomnia: Pooled rate (95% CI); I^2^; number of studies (k)
All studies | 2.4% (0.9% to 6.3%); I^2^=85%; k=13^137,149,154,185,186,190–192,199^ | 18.4% (15.6% to 21.7%); I^2^=90%; k=37^137,139,141–150,153,155–157,159–162,164,167,185–192,194–196^ | 18.7% (15.6% to 22.2%); I^2^=90%; k=42^137,139,141–151,153,155–157,159–162,164,165,167,185–197,199^ | 8.1% (6.7% to 9.9%); I^2^=60%; k=18^139,146,147,149,150,157,159–162,185,187,189,190,192,194,195^
- Ledipasvir / sofosbuvir | 0.5% (0.2% to 1.4%); I^2^=44%; k=2^185,190^ | 16.2% (12.2% to 21.0%); I^2^=67%; k=8^141,142,145,148,156,185,190,195^ | 13.7% (8.4% to 21.5%); I^2^=85%; k=9^141,142,145,148,156,185,190,193,195^ | 6.0% (4.5% to 8.0%); I^2^=58%; k=3^185,190,195^
- Simeprevir / sofosbuvir | 0% (0% to 23.2%); k=1^*^,^154^ | 18.4% (9.8% to 31.8%; I^2^=86%); k=2^153,159^ | 19.5% (11.7% to 30.8%); I^2^=81%; k=2^153,159^ | 10.0% (3.8% to 20.5%); k=1^159^
- Sofosbuvir / velpatasvir | -- | 20.8% (17.9% to 24.0%); I^2^=44%; k=5^139,146,147,150^ | 18.0% (10.8% to 28.5%); I^2^=96%; k=6^139,146,147,150,165^ | 8.3% (6.7% to 10.2%); I^2^=32%; k=5^139,146,147,150^
- Sofosbuvir / daclatasvir | -- | 21.7% (14.9% to 30.7%); I^2^=72%; k=4^157,159,160,167^ | 20.6% (16.8% to 25.1%); I^2^=41%; k=4^157,159,161,167^ | 6.6% (4.1% to 10.3%); I^2^=0%; k=3^157,159,161^
- Glecaprevir / pibrentasvir | 0% (0% to 4.0%); k=1^199^ | 13.3% (10.8% to 16.3%; I^2^=54%); k=5^143,167,194,196^ | 14.7% (9.4% to 22.2%) I^2^=87%; k=7^143,167,194,196,197,199^ | 0% (0% to 12.3%); k=1^194^
- Elbasvir / grazoprevir | -- | 10.9% (4.3% to 25.1%; I^2^=88%); k=3^144,160,164^ | 17.1% (6.1% to 39.5%) I^2^=94%; k=3^144,160,164^ | 7.0% (2.3% to 19.5%); k=1^160^
- Ombitasvir / paritaprevir / ritonavir / dasabuvir | 0.8% (0.2% to 3.1%); I^2^=0%%; k=3^137,186,191^ | 15.8% (9.1% to 26.1%); 91%; k=6^137,155,186,188,191^ | 20.7% (15.6% to 26.9%); I^2^=83%; k=7^137,151,155,186,188,191^ | --
- Ombitasvir / paritaprevir / ritonavir / dasabuvir / ribavirin | 8.3% (5.8% to 11.8%); I^2^=49%; k=6^137,149,186,191,192^ | 26.9% (20.5% to 34.4%); I^2^=88%; k=11^137,149,162,186–189,191,192^ | 27.7% (24.0% to 31.6%); I^2^=62%; k=11^137,149,162,187–189,191,192^ | 12.2% (9.4% to 15.7%); I^2^=37%; k=6^137,149,162,187,189,192^
- Patients with cirrhosis excluded | 2.2% (0.6% to 7.3%); I^2^=81%; k=6^154,186,190–192,199^ | 20.2% (16.0% to 25.3%); I^2^=92%; k=18^144,146,153,155,159,160,167,186–192,194,196^ | 19.6% (15.6% to 24.4%); I^2^=87%; k=22^144,146,151,153,155,159,160,167,186–194,196,197,199^ | 8.9% (7.0% to 11.4%); I^2^=70%; k=10^146,157,159,161,162,187,189,190,192,194^
- Some cirrhosis (≤20%) | 2.9% (0.7% to 11.0%); I^2^=92%; k=4^137,149,185^ | 16.7% (13.1% to 21.2%); I^2^=90%; k=18^137,139,141–143,145,147–150,156,157,161,162,164,185^ | 19.1% (14.9% to 24.1%); I^2^=94%; k=19^137,139,141–143,145,147–150,156,157,161,162,164,165,185^ | 8.2% (6.3% to 10.5%); I^2^=16%; k=8^139,147,149,150,160,185,194^
- Treatment-naïve | 2.2% (0.7% to 6.7%); I^2^=90%; k=6^137,149,185,190,191^ | 18.1% (14.5% to 22.2%); I^2^=92%; k=24^141,142,144–146,148,149,156,157,160–162,164,167,185,187–191,195^ | 21.1% (16.8% to 26.2%); I^2^=92%; k=24^137,141,142,144–146,148,149,156,157,160,162,164,167,185,187–191,193,195^ | 8.0% (5.9% to 10.7%); I^2^=71.5%; k=9^146,149,160,162,185,187,189,190,195^
- Treatment-experienced | 3.6% (0.8% to 14.5%); I^2^=0%; k=3^137,154,186^ | 23.2% (14.7% to 34.6%); I^2^=51%; k=4^137,186,189,194^ | 23.5% (14.4% to 35.8%); I^2^=0%; k=4^137,186,189,194^ | 8.1% (4.6% to 13.7%); I^2^=66%; k=4^137,161,189,194^
- Mixed treatment-naïve and experienced | 2.1% (0.2% to 18.1%); I^2^=89%; k=2^192,199^ | 17.6% (12.8% to 23.7%) I^2^=87%; k=11^139,143,147,148,153,155,159,164,192,196^ | 14.5% (10.6% to 19.5%); I^2^=93%; k=15^139,143,147,148,151,153,155,159,167,192,196,197,199^ | 8.3% (5.9% to 11.4%); I^2^=53%; k=6^139,147,157,159,192^

Abbreviation: CI = confidence interval.

* No events reported

###### Fatigue

Thirty-seven trials (in 33 publications, total N=7,571) reported the proportion of patients with fatigue with eight different DAA regimens.^137,139,141–150,153,155–157,159–162,164,167,185–192,194–196^ Across regimens, the pooled rate for fatigue was 18.4 percent (95% CI, 15.6% to 21.7%, I^2^=90%; Figure 28). Stratified by antiviral regimen, rates of fatigue ranged from 10.9 percent (95% CI, 4.3% to 25.1%, I^2^=88%) for elbasvir / grazoprevir (3 trials) to 26.9 percent (95% CI, 20.5% to 34.4%, I^2^=88%) for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (11 trials) (Table 17). The rate of fatigue was higher for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin than the same regimen without ribavirin (6 trials, pooled event rate 15.8%, 95% CI, 9.1% to 26.1%, I^2^=91%). Estimates were similar when trials were stratified according to whether they excluded patients with cirrhosis (18 trials, pooled event rate 20.2%, 95% CI, 16.0% to 25.3%, I^2^=92%) or included some patients with cirrhosis (18 trials, pooled event rate 16.7%, 95% CI, 13.1% to 21.2%; p for interaction=0.27) and there was no interaction between prior treatment status and rates of fatigue (p for interaction=0.54).

Figure 28 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Fatigue

Abbreviations: CI = confidence interval; NR = not reported; Tx = Treatment; U.S. = United States.

Figure 28 is a forest plot examining pooled rates for fatigue comparing 8 direct acting antiviral regimens. The proportion for 8 studies in the ledipasvir/sofosbuvir subgroup is 0.162 (95% confidence interval 0.122 to 0.210) with an I-squared value of 67.0%. The proportion for the 2 studies in the simeprevir/sofosbuvir subgroup is 0.184 (95% confidence interval 0.098 to 0.318) with an I-squared value of 86.2%. The proportion for the 5 studies in the sofosbuvir/velpatasvir subgroup is 0.208 (95% confidence interval 0.179 to 0.240) with an I-squared value of 44.5%. The proportion for the 3 studies in the elbasvir/grazoprevir subgroup is 0.109 (95% confidence interval 0.043 to 0.251) with an I-squared value of 87.9%. The proportion for the 4 studies in the sofosbuvir/daclatasvir subgroup is 0.217 (95% confidence interval 0.149 to 0.307) with an I-squared value of 72.3%. The proportion for the 5 studies in the glecaprevir/pibrentasvir subgroup is 0.133 (95% confidence interval 0.108 to 0.163) with an I-squared value of 54.1%. The proportion for the 6 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.158 (95% confidence interval 0.091 to 0.261) with an I-squared value of 90.9%. The proportion for the 11 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.269 (95% confidence interval 0.205 to 0.344) with an I-squared value of 87.7%. The overall proportion is 0.187 (95% confidence interval 0.156 to 0.217) with an I-squared value of 89.506%.

###### Headache

Forty-two trials (in 38 publications, total N=7,790) reported the proportion of patients with headache with 8 different DAA regimens.^137,139,141–151,153,155–157,159–162,164,165,167,185–197,199^ Across regimens, the pooled rate for headache was 18.7 percent (95% CI, 15.6% to 22.2%, I^2^=90%; Figure 29). Stratified by antiviral regimen, rates of headache ranged from 13.7 percent (95% CI, 8.4% to 21.5%, I^2^=85%) for ledipasvir / sofosbuvir (9 trials) to 27.7 percent (95% CI, 24.0% to 31.6%, I^2^=62%) for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (11 trials) (Table 17). The rate of headache was higher for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin than the same regimen without ribavirin (7 trials, pooled event rate 20.7%, 95% CI, 15.6% to 26.9%, I^2^=83%). Estimates were similar when trials were stratified according to whether they excluded patients with cirrhosis (22 trials, pooled event rate 19.6%, 95% CI, 15.6% to 24.4%) or included some patients with cirrhosis (19 trials, pooled event rate 19.1%, 95% CI, 14.9% to 24.1%; p for interaction=0.88), and there was no interaction between prior treatment experience status and rates of headache (p for interaction=0.11)

Figure 29 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Headache

Abbreviations: CI = confidence interval; Tx = treatment; U.S. = United States.

Figure 29 is a forest plot examining pooled rates for headache comparing 8 direct acting antiviral regimens. The proportion for 9 studies in the ledipasvir/sofosbuvir subgroup is 0.137 (95% confidence interval 0.084 to 0.215) with an I-squared value of 85.3%. The proportion for the 2 studies in the simeprevir/sofosbuvir subgroup is 0.195 (95% confidence interval 0.117 to 0.308) with an I-squared value of 81.4%. The proportion for the 6 studies in the sofosbuvir/velpatasvir subgroup is 0.180 (95% confidence interval 0.108 to 0.285) with an I-squared value of 96.4%. The proportion for the 3 studies in the elbasvir/grazoprevir subgroup is 0.171 (95% confidence interval 0.061 to 0.395) with an I-squared value of 93.5%. The proportion for the 4 studies in the sofosbuvir/daclatasvir subgroup is 0.206 (95% confidence interval 0.168 to 0.251) with an I-squared value of 41.2%. The proportion for the 7 studies in the glecaprevir/pibrentasvir subgroup is 0.147 (95% confidence interval 0.094 to 0.222) with an I-squared value of 86.7%. The proportion for the 7 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.207 (95% confidence interval 0.156 to 0.269) with an I-squared value of 83.2%. The proportion for the 11 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.277 (95% confidence interval 0.240 to 0.316) with an I-squared value of 62.2%. The overall proportion is 0.187 (95% confidence interval 0.156 to 0.222) with an I-squared value of 90.436%.

###### Insomnia

Eighteen trials (in 17 publications, total N=3,517) reported the proportion of patients with insomnia with eight different DAA regimens.^139,146,147,149,150,157,159–162,185,187,189,190,192,194,195^ Across regimens, the pooled rate for insomnia was 8.1 percent (95% CI, 6.7% to 9.9%, I^2^=60%; Figure 30). Stratified by antiviral regimen, rates of insomnia ranged from 6.0% (95% CI, 4.5% to 8.0%; I^2^=58%) for ledipasvir / sofosbuvir (3 trials) to 12.2% (95% CI, 9.4% to 15.7%; I^2^=37%) for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (6 trials) (Table 17). The only trial of glecaprevir / pibrentasvir reported no cases of insomnia.^160^ Estimates were similar when trials were stratified according to whether they excluded patients with cirrhosis (10 trials, pooled event rate 8.9%, 95% CI, 7.0% to 11.4%) or included some patients with cirrhosis (8 trials, pooled event rate 8.2%, 95% CI, 6.3% to 10.5%; p for interaction=0.63), and there was no interaction between prior treatment experience status and rates of insomnia (p for interaction=0.99)

Figure 30 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Insomnia

Abbreviations: CI = confidence interval; Tx = treatment; U.S. = United States.

Figure 30 is a forest plot examining pooled rates for insomnia comparing 7 direct acting antiviral regimens. The proportion for 3 studies in the ledipasvir/sofosbuvir subgroup is 0.060 (95% confidence interval 0.045 to 0.080) with an I-squared value of 58.2%. The proportion for the 1 study in the simeprevir/sofosbuvir subgroup is 0.100 (95% confidence interval 0.038 to 0.205). The proportion for the 5 studies in the sofosbuvir/velpatasvir subgroup is 0.083 (95% confidence interval 0.067 to 0.102) with an I-squared value of 32.4%. The proportion for the 1 study in the elbasvir/grazoprevir subgroup is 0.070 (95% confidence interval 0.015 to 0.191). The proportion for the 3 studies in the sofosbuvir/daclatasvir subgroup is 0.066 (95% confidence interval 0.041 to 0.103) with an I-squared value of 0.0%. The proportion for the 1 study in the glecaprevir/pibrenasvir subgroup is 0.000 (95% confidence interval 0.000 to 0.123). The proportion for the 6 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.122 (95% confidence interval 0.094 to 0.157) with an I-squared value of 37.4%. The overall proportion is 0.081 (95% confidence interval 0.067 to 0.099) with an I-squared value of 60.013%.

###### Gastrointestinal Adverse Events

Thirty-six trials (in 34 publications, total N=6,145) reported the proportion of patients with nausea on eight different DAA regimens.^137,139,142,144–151,153,157,159–162,167,185,186,188–196,199^ Across regimens, the pooled rate for nausea was 11.1 percent (95% CI, 9.1% to 13.5%, I^2^=82%; Figure 31). Stratified by antiviral regimen, rates of nausea ranged from 6.5 percent (95% CI, 4.3% to 9.7%, I^2^=70%) for ombitasvir / paritaprevir / ritonavir / dasabuvir without ribavirin (7 trials) to 15.2 percent (95% CI, 9.6% to 23.2%, I^2^=90%) for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (11 trials) (Table 18). Estimates were similar when trials were stratified according to whether they excluded patients with cirrhosis (21 trials, pooled event rate 10.6%, 95% CI, 8.2% to 13.5%) or included some patients with cirrhosis (14 trials, pooled event rate 12.9%, 95% CI, 9.6% to 17.1%; p for interaction=0.31), and there was no interaction between prior treatment experience status and rates of nausea (p for interaction=0.63).

Figure 31 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Nausea

Abbreviations: CI = confidence interval; NR = not reported; Tx = Treatment; U.S. = United States.

Figure 31 is a forest plot examining pooled rates for nausea comparing 8 direct acting antiviral regimens. The proportion for 7 studies in the ledipasvir/sofosbuvir subgroup is 0.084 (95% confidence interval 0.057 to 0.121) with an I-squared value of 60.0%. The proportion for the 2 studies in the simeprevir/sofosbuvir subgroup is 0.144 (95% confidence interval 0.103 to 0.198) with an I-squared value of 0.0%. The proportion for the 5 studies in the sofosbuvir/velpatasvir subgroup is 0.129 (95% confidence interval 0.110 to 0.151) with an I-squared value of 13.1%. The proportion for the 2 studies in the elbasvir/grazoprevir subgroup is 0.129 (95% confidence interval 0.066 to 0.237) with an I-squared value of 19.4%. The proportion for the 4 studies in the sofosbuvir/daclatasvir subgroup is 0.121 (95% confidence interval 0.091 to 0.158) with an I-squared value of 31.9%. The proportion for the 5 studies in the glecaprevir/pibrentasvir subgroup is 0.093 (95% confidence interval 0.064 to 0.134) with an I-squared value of 79.2%. The proportion for the 7 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.065 (95% confidence interval 0.043 to 0.097) with an I-squared value of 69.8%. The proportion for the 11 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.152 (95% confidence interval 0.096 to 0.233) with an I-squared value of 90.0%. The overall proportion is 0.111 (95% confidence interval 0.091 to 0.135) with an I-squared value of 82.548%.

Table 18 Pooled Rates With Direct Acting Antiviral Regimens in Adults for Nausea, Diarrhea, Vomiting, and Rash

Analysis | Nausea: Pooled rate (95% CI); I^2^; number of studies (k) | Diarrhea: Pooled rate (95% CI); I^2^; number of studies (k) | Vomiting: Pooled rate (95% CI); I^2^; number of studies (k) | Rash: Pooled rate (95% CI): I^2^; number of studies (k)
All studies | 11.1% (9.1% to 13.5%); I^2^=82%; k=36^137,139,142,144–151,153,157,159–162,167,185,186,188–196,199^ | 8.9% (7.0% to 10.8%); I^2^=69%; k=19^139,141,142,146,148,150,155,157,160,161,185–191,195^ | 5.8% (3.4% to 9.7%); I^2^=43%; k=6^148–150,159,161,192^ | 5.4% (4.1% to 7.1%); I^2^=70%, k=17^137,146,153,154,158–160,185–188,190,192,193,197^
- Ledipasvir / sofosbuvir | 8.4% (5.7% to 12.1%); I^2^=60%; k=7^142,145,148,185,190,193,195^ | 6.8% (4.2% to 10.9%); I^2^=72%; k=6^141,142,148,185,190,195^ | 6.0% (1.9% to 17.0%); k=1^148^ | 3.3% (1.8% to 8.8%); I^2^=80%; k=3^185,190,193^
- Simeprevir / sofosbuvir | 14.4% (10.3% to 19.8%); I^2^=0%; k=2^153,159^ | -- | 5.0% (1.6% to 14.4%); k=1^159^ | 7.4% (4.7% to 11.6%); I^2^=0%; k=3^153,154,159^
- Sofosbuvir / daclatasvir | 12.1% (9.1% to 15.8%); I^2^=32%; k=4^157,159,161,167^ | 7.8% (4.7% to 12.5%); I^2^=0%; k=2^157,161^ | 1.9% (0.5% to 7.2%); I^2^=0%; k=2^159,161^ | 1.5% (0.2% to 10.1%); k=1^159^
- Sofosbuvir / velpatasvir | 12.9% (11.0% to 15.0%); I^2^=13%; k=5^139,146,147,150^ | 7.3% (5.7% to 9.4%); I^2^=17%; k=3^139,146,150^ | 3.9% (1.5% to 9.9%); k=1^150^ | 8.3% (4.9% to 13.7%); I^2^=45%; k=2^146,158^
- Glecaprevir / pibrentasvir | 9.3% (6.4% to 13.4%); I^2^=79%; k=5^167,194,196,199^ | -- | -- | 2.3% (0.5% to 6.6%); k=1^197^
- Elbasvir / grazoprevir | 12.9% (6.6% to 23.7%); I^2^=19%; k=2^144,160^ | 11.6% (4.9% to 25.0%); k=1^160^ | -- | 4.7% (1.2% to 16.8%); k=1^160^
- Ombitasvir / paritaprevir / ritonavir / dasabuvir | 6.5% (4.3% to 9.7%); I^2^=70%; k=7^137,151,155,186,188,191^ | 11.1% (7.7% to 15.9%); I^2^=72%; k=5^155,186,188,191^ | -- | 2.6% (1.0% to 6.7%); I^2^=66%; k=4^137,186,188^
- Ombitasvir / paritaprevir / ritonavir / dasabuvir/ ribavirin | 15.2% (9.6% to 23.2%); I^2^=90%; k=11^137,149,162,186–189,191,192^ | 10.9% (7.8% to 14.9%); I^2^=73%; k=6^186–189,191^ | 12.0% (7.4% to 18.9%); I^2^=0%; k=2^149,192^ | 7.6% (5.5% to 10.3%); I^2^=57%; k=7^137,186–188,192^
- Patients with cirrhosis excluded | 10.6% (8.2% to 13.5%); I^2^=89%; k=21^144,146,151,153,155,160,167,186–194,196,199^ | 10.1% (7.9% to 12.8%); I^2^=80%; k=10^146,155,160,186–191^ | 5.2% (2.1% to 12.4%); I^2^=65%; k=2^159,192^ | 5.2% (3.8% to 7.0%); I^2^=68%; k=13^146,153,154,159,160,186–188,190,192,193,197^
- Some patients (<20% of sample) with cirrhosis | 12.9% (9.6% to 17.1%); I^2^=43%; k=14^137,139,142,145,147–150,157,161,162,185^ | 8.0% (5.8% to 10.9%); I^2^=0.8%; k=8^139,141,142,148,150,157,161,185^ | 6.1% (3.2% to 11.4%); I^2^=51%; k=4^148–150,161^ | 6.2% (3.7% to 10.1%); I^2^=49%; k=4^137,158,185^
- Treatment-naïve | 11.8% (9.0% to 15.2%); I^2^=86%; k=22^137,142,144–146,148,149,157,160–162,167,185,187–191,193,195^ | 9.0% (7.0% to 11.3%); I^2^=77%; k=15^141,142,146,148,157,160,161,185,187–191,195^ | 9.6% (5.3% to 16.8%); I^2^=51%; k=3^148,149,161^ | 5.2% (3.6% to 7.3%); I^2^=74%; k=9^137,146,154,160,185,187,188,190^
- Treatment-experienced | 12.2% (7.2% to 20.1%); I^2^=0%; k=4^137,186,189,194^ | 10.2% (5.3% to 18.7%); I^2^=0%; k=2^186,189^ | -- | 4.8% (2.8% to 8.2%); I^2^=50%; k=5^137,154,158,186,197^
- Mixed treatment-naïve and experienced | 9.6% (6.6% to 13.6%); I^2^=86%; k=12^139,147,148,151,153,155,159,167,192,196,199^ | 8.60% (5.0% to 14.6%); I^2^=4.8%; k=3^139,148,155^ | 4.2% (2.1% to 8.6%); I^2^=54%; k=3^148,159,192^ | 7.6% (4.2% to 13.6%); I^2^=47%; k=3^153,159,192^

Abbreviation: CI = confidence interval.

Nineteen trials (in 18 publications, total N=2,960) of six different DAA regimens reported the proportion of patients with diarrhea.^141,142,146,148,150,155,157,160,161,185–191,195^ Across regimens, the pooled rate of diarrhea was 8.7 percent (95% CI, 7.0% to 10.8%, I^2^=69%; Figure 32). Stratified by antiviral regimen, rates of diarrhea ranged from 6.8 percent (95% CI, 4.2% to 10.9%, I^2^=72%) for ledipasvir / sofosbuvir (6 trials) to 11.6 percent (95% CI, 4.9% to 25.0%) for elbasvir / grazoprevir (1 trial) (Table 18). The rate of diarrhea was similar for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (6 trials, pooled event rate 10.9%, 95% CI, 7.8% to 14.9%, I^2^=73%) and the same regimen without ribavirin (5 trials, pooled event rate 11.1%, 95% CI, 7.7% to 15.9%, I^2^=72%). Estimates were similar when trials were stratified according to whether they excluded patients with cirrhosis (10 trials, pooled event rate 10.1%, 95% CI, 7.9% to 12.8%) or included some patients with cirrhosis (8 trials, pooled event rate 8.0%, 95% CI, 5.8% to 10.9%; p for interaction=0.25), and there was no interaction between prior treatment experience status and rates of diarrhea (p for interaction=0.92).

Figure 32 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Diarrhea

Abbreviations: CI = confidence interval; NR = not reported; Tx = treatment; U.S. = United States.

Figure 32 is a forest plot examining pooled rates for diarrhea comparing 6 direct acting antiviral regimens. The proportion for 6 studies in the ledipasvir/sofosbuvir subgroup is 0.068 (95% confidence interval 0.042 to 0.109) with an I-squared value of 71.5%. The proportion for the 3 studies in the sofosbuvir/velpatasvir subgroup is 0.073 (95% confidence interval 0.057 to 0.094) with an I-squared value of 17.3%. The proportion for the 1 study in the elbasvir/grazoprevir subgroup is 0.116 (95% confidence interval 0.049 to 0.250). The proportion for the 2 studies in the sofosbuvir/daclatasvir subgroup is 0.078 (95% confidence interval 0.047 to 0.125) with an I-squared value of 0.0%. The proportion for the 5 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.111 (95% confidence interval 0.077 to 0.159) with an I-squared value of 71.5%. The proportion for the 6 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.109 (95% confidence interval 0.078 to 0.149) with an I-squared value of 72.7%. The overall proportion is 0.087 (95% confidence interval 0.070 to 0.108) with an I-squared value of 69.408%.

Six trials (total N=444) of five different DAA regimens reported the proportion of patients with vomiting.^148–150,159,161,192^ Across regimens, the pooled rate of vomiting was 5.8 percent (95% CI, 3.4% to 9.7%, I^2^=43%; Figure 33). Stratified by antiviral regimen, rates of vomiting ranged from 1.9 percent (95% CI, 0.5% to 7.2%, I^2^=0%) for sofosbuvir / daclatasvir (2 trials) to 12.0 percent (2 trials, 95% CI, 7.4% to 18.9%; I^2^=0%) with ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin.

Figure 33 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Vomiting

Abbreviations: CI = confidence interval; Tx = treatment; U.S. = United States.

Figure 33 is a forest plot examining pooled rates for vomiting comparing 5 direct acting antiviral regimens. The proportion for 1 study in the ledipasvir/sofosbuvir subgroup is 0.060 (95% confidence interval 0.019 to 0.170). The proportion for the 1 study in the simeprevir/sofosbuvir subgroup is 0.050 (95% confidence interval 0.016 to 0.144). The proportion for the 1 study in the sofosbuvir/velpatasvir subgroup is 0.039 (95% confidence interval 0.015 to 0.099). The proportion for the 2 studies in the sofosbuvir/daclatasvir subgroup is 0.019 (95% confidence interval 0.005 to 0.072) with an I-squared value of 0.0%. The proportion for the 2 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.120 (95% confidence interval 0.074 to 0.189) with an I-squared value of 0.0%. The overall proportion is 0.058 (95% confidence interval 0.034 to 0.097) with an I-squared value of 42.843%.

###### Rash

Seventeen trials (in 15 publications, total N=2,256) reported the proportion of patients with rash on eight different DAA regimens.^137,146,153,154,158–160,185–188,190,192,193,197^ Across regimens, the pooled rate for rash was 5.4 percent (95% CI, 4.1% to 7.1%, I^2^=70%; Figure 34). Stratified by antiviral regimen, rates of rash ranged from 1.5 percent (95% CI, 0.2% to 10.1%) for sofosbuvir / daclatasvir (1 trial) to 8.3 percent (95% CI, 4.9% to 13.7%, I^2^=45%) for sofosbuvir / velpatasvir (2 trials) (Table 18). The rate of rash was higher for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin (7 trials, pooled event rate 7.6%, 95% CI, 5.5% to 10.3%, I^2^=57%) than the same regimen without ribavirin (4 trials, event rate 2.6%, 95% CI, 1.0% to 6.7%, I^2^=66%). Estimates were similar when trials were stratified according to whether they excluded patients with cirrhosis (13 trials, pooled event rate 5.2%, 95% CI, 3.8% to 7.0%) or included some patients with cirrhosis (4 trials, pooled event rate 6.2%, 95% CI, 3.7% to 10.1%; p for interaction=0.56), and there was no interaction between prior treatment experience status and rates of rash (p for interaction=0.49).

Figure 34 Key Question 8: Direct Acting Antiviral Regimens and Pooled Rates for Rash

Abbreviations: CI = confidence interval; Tx = treatment; U.S. = United States.

Figure 34 is a forest plot examining pooled rates for rash comparing 8 direct acting antiviral regimens. The proportion for 3 studies in the ledipasvir/sofosbuvir subgroup is 0.033 (95% confidence interval 0.018 to 0.088) with an I-squared value of 80.3%. The proportion for the 3 studies in the simeprevir/sofosbuvir subgroup is 0.074 (95% confidence interval 0.047 to 0.116) with an I-squared value of 0.0%. The proportion for the 2 studies in the sofosbuvir/velpatasvir subgroup is 0.083 (95% confidence interval 0.049 to 0.137) with an I-squared value of 44.9%. The proportion for the 1 study in the elbasvir/grazoprevir subgroup is 0.047 (95% confidence interval 0.012 to 0.168). The proportion for the 1 study in the sofosbuvir/daclatasvir subgroup is 0.015 (95% confidence interval 0.002 to 0.101). The proportion for the 1 study in the glecaprevir/pibrentasvir subgroup is 0.023 (95% confidence interval 0.005 to 0.066). The proportion for the 4 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir subgroup is 0.026 (95% confidence interval 0.010 to 0.067) with an I-squared value of 65.7%. The proportion for the 7 studies in the ombitasvir/paritaprevir/ritonavir/dasabuvir + ribavirin subgroup is 0.076 (95% confidence interval 0.055 to 0.103) with an I-squared value of 57.0%. The overall proportion is 0.054 (95% confidence interval 0.041 to 0.071) with an I-squared value of 69.599%.

###### HBV Infection Reactivation

All trials but one^195^ excluded persons coinfected with HBV infection, and no cases of HBV reactivation were reported.

#### Adolescents

Seven trials of DAA regimens in adolescents reported harms (Table 19; Appendix B Tables 7-9).^171,173,175,176,201–203^ Study characteristics were described in detail in KQ 7; four trials evaluated regimens FDA-approved for use in adolescents (ledipasvir and sofosbuvir,^175,202^ sofosbuvir and ribavirin,^173^ or glecaprevir / pibrentasvir^171^), and three trials evaluated DAA regimens recommended in adults but not approved in children (sofosbuvir and daclatasvir^176,201^ or ombitasvir / paritaprevir / ritonavir / dasabuvir^203^). Methods for reporting and assessing harms were generally not well described.

Table 19 Adverse Events With Direct Acting Antiviral Regimens in Adolescents

Author, year; Country; Quality | Antiviral treatment regimen | Any adverse event | Serious adverse events | Withdrawal due to adverse events | Headache | Fatigue | Gastrointestinal | Insomnia
Abdel Ghaffar 2019^201^; Egypt; Fair | Sofosbuvir 200-400 mg + daclatasvir 30-60 mg | NR | NR | NR | 3% (1/40) | 5% (2/40) | Vomiting: 3% (1/40) | NR
Balistreri 2017^175^; Multinational; Fair | Ledipasvir 90 mg + sofosbuvir 400 mg^*^ | 71% (71/100) | 0% (0/100) | 0% (0/100) | 27% (27/100) | 13% (13/100) | Nausea: 11% (11/100); Vomiting: 11% (11/100) | NR
El-Karaksy 2018^202^; Egypt; Fair | Ledipasvir 90 mg + sofosbuvir 400 mg^*^ | NR | NR | NR | 48% (19/40) | 53% (21/40) | Nausea: 28% (11/40); Diarrhea: 23% (9/40) | 23% (9/40)
Jonas 2019^171^; DORA; Multinational; Fair | Glecaprevir 300 mg + pibrentasvir 120 mg | 87% (41/47) | 0% (0/47) | 0% (0/47) | 17% (8/47) | 11% (5/47) | NR | NR
Leung 2018^203^; Multinational; Fair | Ombitasvir 25 mg + paritaprevir 150 mg + ritonavir 100 mg + dasabuvir 250 mg 2x/day + weight-based ribavirin | 84% (32/38) | 0% (0/38) | 0% (0/38) | 21% (8/38) | 18% (7/38) | NR | NR
Wirth 2017^173^; Multinational; Fair | Sofosbuvir 400 mg + weight-based ribavirin^*^ | 81% (41/52) | 2% (1/52) | 0% (0/52) | 23% (12/52) | 12% (6/52) | Nausea: 27% (14/52); Diarrhea: 6% (3/52) | NR
Yakoot 2018^176^; Egypt; Good | Sofosbuvir + daclatasvir | 27% (8/30) | 0% (0/30) | 0% (0/30) | 10% (3/30) | 13% (4/30) | Nausea: 10% (3/30) | NR

* Currently recommended regimen.

Abbreviation: NR = not reported.

Five trials reported no withdrawals due to adverse events,^171,173,175,176,203^, and one of five trials reported a single serious adverse event (a grade 3 joint injury) in adolescents treated with sofosbuvir plus ribavirin.^173^ The rate of any adverse event was 27 percent in one study of sofosbuvir and daclatasvir (not FDA-approved for use in adolescents)^176^ and 71 to 87 percent in four trials of other regimens.^171,173,175,203^ Rates of specific adverse events ranged from 3 to 48 percent for headache (7 trials),^171,173,175,176,201–203^ 5 to 53 percent for fatigue (7 trials),^171,173,175,176,201–203^ and 3 to 28 percent for gastrointestinal (nausea, vomiting, or diarrhea) adverse events (5 trials).^173,175,176,201,202^ One trial of ledipasvir and sofosbuvir reported insomnia in 23 percent (9/40) of participants.^202^ Stratification by DAA regimen did not appear to explain the observed variability in adverse event estimates, though assessments were limited by the small number of trials and methodological limitations.

## Key Question 9 What Is the Association Between Experiencing SVR Following Antiviral Treatment and Reduction in Risk of HCV-Related Adverse Health Outcomes?

### Summary

- The prior review included 10 studies of patients in which less than 25 percent had cirrhosis at baseline that found SVR after interferon-based antiviral therapy associated with decreased risk of all-cause mortality (7 studies, adjusted HR 0.12 to 0.71), liver-related mortality (5 studies, adjusted HR 0.04 to 0.22), and HCC (4 studies, adjusted HR 0.12 to 0.36) versus no SVR.
- Including studies published since the prior review, SVR after antiviral therapy was associated with decreased risk of all-cause mortality, liver mortality, cirrhosis, and HCC versus no SVR in studies in which less than 25 percent of the population had cirrhosis at baseline.
  ○ All-cause mortality (13 studies): Pooled adjusted HR 0.40 (95% CI, 0.28 to 0.56, I^2^=52%).^69,168,204–214^
  ○ Liver mortality (4 studies): Pooled adjusted HR 0.11 (95% CI, 0.04 to 0.27, I^2^=0%).^204,208,210,213^
  ○ Cirrhosis (4 cohorts reported in 3 studies): Pooled HR 0.36 (95% CI, 0.33 to 0.40; I^2^=0%).^206,215,216^
  ○ HCC (20 studies): Pooled adjusted HR 0.29 (95% CI, 0.23 to 0.38; I^2^=19%).^168,204,207,211,214,215,217–230^
- Estimates favored SVR in all studies and results were consistent when studies with potentially overlapping populations were excluded from analyses, when the analysis was restricted to studies that adjusted at a minimum for age, sex, genotype, and baseline fibrosis, and in stratified analyses based on duration of followup and geographic setting. For all-cause mortality, the effect of SVR was stronger in studies with followup longer than 5 years.
- All studies except for three evaluated SVR after interferon-based therapy; results were similar from two studies of SVR after DAA therapy, and estimates from a third study of SVR after DAA therapy were very imprecise.

### Evidence

The prior review included 19 cohort studies that consistently found an SVR after interferon-based antiviral therapy associated with decreased risk of all-cause mortality (10 studies, adjusted HR ranged from 0.07 to 0.39), liver-related mortality (9 studies, adjusted HR 0.04 to 0.27), and HCC (11 studies, adjusted hazards ratios 0.12 to 0.71) versus no SVR after 3 to 9 years of followup. Six studies in the prior review evaluated populations of patients with cirrhosis at baseline, and in three other studies the proportion of patients with cirrhosis at baseline ranged from 30 to 70 percent. When results were restricted to 10 studies in which less than 25 percent of persons had cirrhosis at baseline, results also indicated an association between SVR after antiviral therapy and decreased risk of all-cause mortality (7 studies, adjusted HR 0.12 to 0.71), liver-related mortality (5 studies, adjusted HR 0.04 to 0.22), and HCC (4 studies, adjusted HR 0.12 to 0.36). The largest study (n=16,864), which also had the fewest methodological shortcomings, found SVR after antiviral therapy in a predominantly male, VA population associated with lower risk of all-cause mortality versus no SVR after a median of 3.8 years (adjusted HR 0.70, 95% CI, 0.59 to 0.83, 0.64, 95% CI, 0.46 to 0.88, and 0.51, 95% CI, 0.35 to 0.73, for genotypes 1, 2, and 3, respectively).^69^

Thirty cohort studies (30 publications) reported associations between achieving SVR following antiviral treatment versus no SVR and clinical outcomes (Appendix B Tables 14 and 15).^69,168,204–231^ Nine of the studies were included in the prior report;^69,204,208–211,213,214,222^ nine other studies^70,232–238^ from the prior review were excluded because more than 25 percent of the populations had cirrhosis at baseline, and one study^239^ from the prior review was excluded because it did not report usable data.

Sample sizes ranged from 131 to 50,886 (total N=116,659), mean age ranged from 42 to 69 years, and the proportion of female participants ranged from 1 to 56 percent with five studies including samples that were less than 10 percent female.^69,205,207,215,221^ The proportion of patients with cirrhosis at baseline ranged from 0 percent to 21 percent. Seventeen studies were conducted in Japan,^204,208,210,211,213,217–220,222–224,226–230^ seven in the United States,^69,205–207,212,215,221^ two in South Korea,^225,231^ two in Taiwan,^214,216^ one in France,^168^ and one in the United Kingdom.^209^ All of the U.S.-based studies except for one^212^ were conducted in VA populations. Several Japanese studies also appeared to evaluate overlapping or partially overlapping populations (Table 20; Appendix B Tables 14 and 15). None of the studies conducted in Asian countries reported race; among studies in the United States and the United Kingdom, white patients comprised 38 to 92 percent of the study population, black patients comprised 8 to 43 percent of the population, and Hispanic patients comprised 0.4 to 14 percent of the population. When genotype was reported, genotype 1 was generally the most common (36% to 89%), with genotype 2 the second most common (6% to 52%). One study reported that 52 percent of patients were genotype 2,^231^ and two studies reported large proportions (54% and 55%) of ‘non-genotype 1’ patients, but did not otherwise specify genotype.^209,214^

Table 20 Studies on the Association Between Sustained Virologic Response After Antiviral Therapy vs. No Sustained Virologic Response and Clinical Outcomes

Author year; Country | Duration of followup | N, by treatment response | Percent with Cirrhosis | Percent with Genotype 1 | Statistical adjustments for age, sex, fibrosis, genotype
Arase 2007^204^; Japan^*^ | 7.4 years (mean) | SVR: 140; No SVR: 360 | 14% | 60% | Yes
Asahina 2010^217^; Japan^†^ | 7.5 years (mean) | SVR: 686; No SVR: 1,356 | 5% | 70% | Yes
Backus 2011^69^; U.S.^‡^ | 3.8 years (median) | SVR: 7,434; No SVR: 9,430 | 13% | 72% | Yes
Butt 2017^205^; U.S.^‡^ | 1.5 years | SVR: 6,371; No SVR: 599 | 15% | 85% | Yes
Carrat 2019^168^ | 2.8 years (median) | SVR: 3,286; No SVR: 146; Unknown SVR: 1,089 | 0% (subgroup) | 67% | Yes
Cozen 2013^206^; U.S.^‡^ | 10 years (mean) | SVR: 112; No SVR: 91; Relapse: 43; Early treatment discontinuation or unknown: 44 | 5% | 67% | Yes in San Francisco VA cohort Partial in UCSF cohort
Dieperink 2014^207^; U.S.^‡^ | 7.5 years (median) | SVR: 222; No SVR: 314 | 21% | 70% | Yes
Dohmen 2013^218^; Japan | 4.8 years (median) | SVR: 285; No SVR: 189 | NR | 67% | Partial
El-Serag 2014^215^; U.S.^‡^ | 5.2 years (mean) | SVR: 7,577; No SVR: 8,767 | NR | 55% | Yes
Ikeda 1999^219^; Japan^*^ | 5.4 years (median) | SVR: 606; No SVR: 585 | 0% | 67% | Yes
Imai 1998^220^; Japan | 4 years (median) | SVR: 151; Relapse: 120; No SVR: 148 | 8% | NR | Partial
Imazeki 2003^208^; Japan^§^ | 8.2 years (mean) | SVR: 116; No SVR: 239 | 13% | 74% | Partial
Innes 2011^209^; U.K. | 5.3 years (mean) | SVR: 560; No SVR: 655 | 14% | 36% | Yes
Ioannou 2018^221^; U.S.^║^ | 6.1 years (mean) | SVR: 28,655; No SVR: 23,231 | 17% | 77% | Yes
Izumi 2005^222^; Japan^†^ | Unclear | SVR: 155; No SVR: 340 | 1% | 50% | Unclear
Kasahara 1998^223^; Japan^¶^ | 3.1 years (mean) | SVR: 313; Relapse: 304; No SVR: 405 | 0% | 58% | Yes
Kasahara 2004^210^; Japan^¶^ | 5.7 years (mean) | SVR: 738; No SVR: 1,930 | 4% | NR | Partial
Kurokawa 2009^224^; Japan^¶^ | 3 years (median) | SVR: 139; No SVR: 264 | 2% | 73% | Partial
Lee 2017^225^; South Korea | 2.6 years (median) | SVR: 306; No SVR: 183 | 13% | 51% | Yes
Maruoka 2012^211^; Japan^§^ | 9.9 years (mean) | SVR: 221; No SVR: 356 | 10% | 73% | Yes
Okanoue 2002^226^; Japan | 5.6 years (mean) | SVR: 426; Relapse: 358; No SVR: 586 | 4% | NR | Partial
Osaki 2012^227^; Japan | 4.1 years (median) | SVR: 185; No SVR: 197 | 0% | 60% | Partial
Singal 2013^212^; U.S. | 5 years (median) | SVR: 83; No SVR: 159 | 21% | 68% | Yes
Sinn 2008^231^; South Korea | 4.6 years (median) | SVR: 296; No SVR: 194 | Unclear | 46% | No
Tanaka 2000^228^; Japan | 4.8 years (mean) | SVR: 175; Relapse: 165; No SVR: 254 | 3% | 75% | Yes
Tateyama 2011^229^; Japan | 8.2 years (mean) | SVR: 139; No SVR: 234 | 17% | 72% | Yes
Tseng 2016^216^; Taiwan | 5.5 years (mean) | SVR: 95; No SVR: 50 | NR | 61% | Partial
Yoshida 1999^230^; Japan^#^ | 4.3 years (mean) | SVR: 789; No SVR: 1,568 | 10% | 70% | Partial
Yoshida 2002^213^; Japan^#^ | 5.4 years (mean) | SVR: 817; No SVR: 1,613 | 10% | NR | Partial
Yu 2006^214^; Taiwan | 5.2 years (mean) | SVR: 715; No SVR: 342 | 16% | 46% | Yes

* Study populations overlap.

† Study populations overlap.

‡ Study population appears to overlap with Ioannou 2018.

§ Study populations overlap.

║ Study population appears to overlap with Backus 2011, Butt 2017, Cozen 2013, Dieperink 2014, and El-Serag 2014.

¶ Study populations likely overlap.

# Study populations appear to overlap.

Abbreviations: NR = not reported; SVR = sustained virologic response; UCSF = University of California, San Francisco; U.K. = United Kingdom; U.S. = United States; VA = Veterans Affairs.

Three studies were prospective,^168,218,224^ and the others were either retrospective cohort studies or analyzed a prospectively collected dataset retrospectively. Twenty-six studies, including all of the studies carried forward from the prior USPSTF review, evaluated the association between SVR and clinical outcomes following treatment exclusively with interferon-based treatments.^69,204,206–214,216–220,222–231^ Three studies focused on DAAs,^168,205,221^ one study evaluated interferon-based treatments and DAAs,^221^ and one study did not report what type of treatment was administered (likely primarily interferon-based therapies, given study date).^215^ Average followup ranged from 1.5 to 10 years in all studies except for one study that described followup of at least a year.^231^

Twenty studies evaluated the outcome HCC,^168,204,207,211,214,215,217–230^ thirteen studies all-cause mortality,^69,168,204–214^ seven liver-related mortality,^204,207–210,213,214^ four cohorts (in three publications) cirrhosis,^206,215,216^ and one study liver transplantation.^207^ Two studies evaluated composite outcomes related to mortality and liver outcomes,^206,231^ and one study assessed liver-related hospital episodes.^209^

All studies were rated fair quality (Appendix B Table 16). Although studies had to perform statistical analyses on potential confounders, 13 studies did not address all four pre-specified factors (age, sex, fibrosis stage, and genotype).^206,208,210,213,216,218,220,222,224,226,227,230,231^ No study matched patients who achieved SVR with patients who did not achieve SVR on potential confounders. Studies did not report baseline characteristics according to SVR status or reported large baseline differences between groups. Other methodological shortcomings included failure to report missing data or attrition and unclear masking of outcome assessors.

#### All-Cause Mortality

SVR after antiviral therapy was associated with decreased risk of all-cause mortality versus no SVR (13 studies, pooled HR 0.40, 95% CI, 0.28 to 0.56, I^2^=52%) (Figure 35).^69,168,204–214^ Results favored SVR in all studies except for one^168^ which reported an imprecise estimate (HR 1.36, 95% CI 0.15 to 12.35). In the other studies, the HRs ranged from 0.11 to 0.66. Findings were similar when three studies^206–208^ with potentially overlapping populations were excluded from the analysis (pooled HR 0.37, 95% CI, 0.25 to 0.56). The estimate was slightly weaker in ten “fully adjusted” studies (defined as study methods controlled for age, sex, fibrosis stage, and genotype at a minimum; pooled HR 0.42, 95% CI, 0.29 to 0.62) than studies with partial adjustment (pooled HR 0.29, 95% CI, 0.15 to 0.55), but the difference was not statistically significant (p for interaction=0.34) (Table 21). Trials with longer duration of followup (more than 5 years) reported a stronger association between SVR after antiviral therapy and reduced risk of all-cause mortality (pooled HR 0.33, 95% CI, 0.24 to 0.46) than those with shorter followup (pooled HR 0.64, 95% CI, 0.56 to 0.74; p for interaction=0.003). In stratified analyses, there was no association between geographic setting (United States or Europe vs. Asia, p for interaction=0.10) or the proportion of patients with cirrhosis at baseline (more than 10% vs. 0 to 10%, p for interaction=0.58) and risk of all-cause mortality following SVR (Table 21). Patients received interferon therapy without a DAA in all studies, with the exception of one^205^ U.S. study conducted in a VA population and one French study^168^ in which patients received DAA therapy. The VA study found an SVR after DAA therapy associated with decreased risk or mortality compared with no SVR (adjusted HR 0.57, 95% CI, 0.33 to 0.99), though duration of followup was relatively short (1.5 years);^205^ the estimate from the French study was very imprecise (adjusted HR 1.36, 95% CI, 0.15 to 12.35).^168^

Figure 35 Key Question 9: Association of Sustained Virologic Response With All-Cause Mortality

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; HR = hazard ratio; IFN = interferon; NR = not reported; SVR = sustained virologic response; U.S. = United States.

Figure 35 is a forest plot examining all-cause mortality comparing sustained virologic response with no sustained virologic response. The hazard ratio for 13 studies is 0.40 (95% confidence interval 0.28 to 0.56) with an I-squared value of 52.1%.

Table 21 Pooled Estimates on the Association Between Sustained Virologic Response After Antiviral Therapy vs. No Sustained Virologic Response and Clinical Outcomes

Outcome | Adjusted HR (95% CI) | I^2^ | Number of studies | p for interaction
All-cause mortality | 0.40 (0.28 to 0.56) | 52% | 13^69,168,204–214^ | --
- Exclude overlapping studies | 0.37 (0.25 to 0.56) | 62% | 10^69,168,204,205,209–214^ | --
- Fully adjusted^*^ | 0.42 (0.29 to 0.62) | 55% | 10^69,168,204–207,209,211,212,214^ | 0.34
- Partially adjusted | 0.29 (0.15 to 0.55) | 0% | 3^208,210,213^ | --
- Duration >5 years | 0.33 (0.24 to 0.46) | 0% | 9^204,206–211,213,214^ | 0.003
- Duration <5 years | 0.64 (0.56 to 0.74) | 58% | 4^69,168,205,212^ | --
- U.S./Europe | 0.50 (0.32 to 0.8) | 54% | 7^69,168,205–207,209,212^ | 0.10
- Asia | 0.29 (0.19 to 0.45) | 0% | 6^204,208,210,211,213,214^ | --
- Cirrhosis 0-10% | 0.32 (0.18 to 0.60) | 0% | 4^168,206,211,213^ | 0.58
- Cirrhosis >10% | 0.41 (0.28 to 0.62) | 56% | 9^69,204,205,207–210,212,214^ | --
Liver mortality ^†^ | 0.11 (0.04 to 0.27) | 0% | 4^204,208,210,213^ | --
- Fully adjusted^*^ | 0.13 (0.03 to 0.59) | -- | 1^204^ | 0.79
- Partially adjusted | 0.10 (0.03 to 0.30) | 0% | 3^208,210,213^ | --
- Cirrhosis 0-10% | 0.13 (0.03 to 0.61) | -- | 1^213^ | 0.82
- Cirrhosis >10% | 0.10 (0.03 to 0.30) | 0% | 3^204,208,210^ | --
Cirrhosis ^‡^ | 0.36 (0.33 to 0.40) | 0% | 4^206,215,216^ | --
- Exclude overlapping studies | 0.36 (0.33 to 0.40) | 0% | 3^206,215,216^ | --
- Fully adjusted^*^ | 0.36 (0.33 to 0.40) | 0% | 2^206,215^ | 0.76
- Partially adjusted | 0.31 (0.12 to 0.78) | 0% | 2^206,216^ | --
- U.S./Europe | 0.36 (0.33 to 0.40) | 0% | 3^206,215^ | 0.71
- Asia | 0.29 (0.10 to 0.76) | -- | 1^216^ | --
- Cirrhosis 0 to 10% | 0.36 (0.13 to 1.03) | 0% | 2^206^ | 0.99
- Cirrhosis unclear | 0.36 (0.33 to 0.40) | 0% | 2^215,216^ | --
Hepatocellular carcinoma | 0.29 (0.23 to 0.38) | 19% | 20^168,204,207,211,214,215,217–230^ | --
- Exclude overlapping studies | 0.25 (0.18 to 0.34) | 34% | 16^168,204,211,214,217,218,220,221,223–230^ | --
- Fully adjusted^*^ | 0.30 (0.27 to 0.34) | 0% | 13^168,204,207,211,214,215,217,219,221,223,225,228,229^ | 0.26
- Partially adjusted | 0.26 (0.16 to 0.42) | 51% | 7^218,220,222,224,226,227,230^ | --
- Duration >5 years | 0.30 (0.27 to 0.34) | 23% | 10^204,207,211,214,215,217,221,226,229^ | 0.18
- Duration <5 years | 0.29 (0.16 to 0.52) | 17% | 9^168,218,220,223–225,227,228,230^ | --
- U.S./Europe | 0.32 (0.28 to 0.36) | 0% | 4^168,207,215,221^ | 0.37
- Asia | 0.24 (0.18 to 0.33) | 34% | 16^204,211,214,217–220,222–230^ | --
- Cirrhosis 0 to 10% | 0.22 (0.16 to 0.31) | 0% | 11^168,211,217,220,222–224,226–228,230^ | 0.08
- Cirrhosis >10% | 0.31 (0.27 to 0.35) | 7% | 7^204,207,214,219,221,225,229^ | --

* Study accounted for age, sex, fibrosis stage, and HCV genotype in analysis.

† All studies conducted in Asia and had duration >5 years.

‡ All studies had duration >5 years.

Abbreviations: CI = confidence interval; HR = hazard ratio; U.S. = United States.

#### Liver Mortality

SVR after antiviral therapy was associated with decreased risk of liver mortality versus no SVR (4 studies, pooled HR 0.11, 95% CI, 0.04 to 0.27, I^2^=0%) (Figure 36).^204,208,210,213^ Estimates favored SVR in all studies, and HRs ranged from 0.05 to 0.13. All of the studies were conducted in Asia in patients who received interferon therapy without a DAA with duration of followup longer than 5 years. Estimates were very similar when studies were stratified according to whether they were fully or partially adjusted or whether the proportion of patients with cirrhosis at baseline was 0 to 10 percent or over 10 percent, with HR estimates ranging from 0.10 to 0.13 (Table 21).

Figure 36 Key Question 9: Association of Sustained Virologic Response With Liver Mortality

Abbreviations: CI = confidence interval; GT1 = genotype 1; HR = hazard ratio; IFN = interferon; NR = not reported; SVR = sustained virologic response.

Figure 36 is a forest plot examining liver mortality comparing sustained virologic response with no sustained virologic response. The hazard ratio for 4 studies is 0.11 (95% confidence interval 0.04 to 0.27) with an I-squared value of 0.0%.

#### Cirrhosis

SVR after antiviral therapy was associated with decreased risk of cirrhosis versus no SVR (4 cohorts reported in 3 studies, pooled HR 0.36, 95% CI, 0.33 to 0.40; I^2^=0%) (Figure 37).^206,215,216^ Estimates favored SVR in all studies, with HRs ranging from 0.29 to 0.43. Three cohorts were from the United States and one^216^ from Asia. All patients received treatment with interferon therapy without a DAA, or the antiviral regimen was not reported^215^ but likely to be interferon therapy based on the study date. Estimates were very similar when studies were stratified according to whether they were fully or partially adjusted or the proportion of patients with cirrhosis at baseline (Table 21).

Figure 37 Key Question 9: Association of Sustained Virologic Response With Cirrhosis

Abbreviations: CI = confidence interval; HR = hazard ratio; IFN = interferon; NR = not reported; SVR = sustained virologic response; U.S. = United States.

Figure 37 is a forest plot examining cirrhosis comparing sustained virologic response with no sustained virologic response. The hazard ratio for 4 studies is 0.36 (95% confidence interval 0.33 to 0.40) with an I-squared value of 0.0%.

#### Hepatocellular Carcinoma

SVR after antiviral therapy was associated with decreased risk of HCC versus no SVR (20 studies, pooled HR 0.29, 95% CI, 0.23 to 0.38; I^2^=19%) (Figure 38).^168,204,207,211,214,215,217–230^ Estimates favored SVR in all studies, and HRs ranged from 0.06 to 0.41. Findings were similar when four studies with potentially overlapping populations^207,215,219,222^ were excluded from the analysis (pooled HR 0.25, 95% CI, 0.18 to 0.34). Pooled estimates were similar for four studies conducted in the United States and Europe (pooled HR 0.32, 95% CI, 0.28 to 0.36)^168,207,215,221^ and 16 studies conducted in Asia (pooled HR 0.24, 95% CI, 0.18 to 0.33; p for interaction=0.37). Pooled estimates were also very similar when studies were stratified according to whether they were fully or partially adjusted, the duration of followup (longer or shorter than 5 years), or the proportion of patients with cirrhosis at baseline (greater or less than 10%) (Table 21). Patients received or were likely to have received interferon therapy without a DAA in all studies except for one VA study^221^ of DAA-only therapy, DAA plus interferon, or interferon-only therapy and one French study^168^ of DAA-only therapy. Like the other studies, the VA study found SVR after antiviral therapy associated with decreased risk of HCC versus no SVR (adjusted HR 0.39, 95% CI, 0.35 to 0.43). Estimates were similar when the analysis was stratified according to receipt of a DAA-only regimen (adjusted HR 0.29, 95% CI, 0.23 to 0.37), a DAA plus interferon (adjusted HR 0.48, 95% CI, 0.32 to 0.73), or interferon-only (adjusted HR 0.32, 95% CI, 0.28 to 0.37). The French study was also consistent with an association between SVR after DAA therapy and decreased risk of HCC, though the estimate was imprecise and not statistically significant (adjusted HR 0.22, 95% CI, 0.03 to 1.76).^168^

Figure 38 Key Question 9: Association of Sustained Virologic Response With Hepatocellular Carcinoma

Abbreviations: CI = confidence interval; DAA = direct acting antiviral; HCC = hepatocellular carcinoma; HR = hazard ratio; IFN = interferon; NR = not reported; SVR = sustained virologic response; U.S. = United States.

Figure 38 is a forest plot examining hepatocellular carcinoma comparing sustained virologic response with no sustained virologic response. The hazard ratio for 20 studies is 0.29 (95% confidence interval 0.23 to 0.38) with an I-squared value of 18.7%.

## Contextual Question 1 Based on Population Level Estimates, What Are Recent Trends in the Epidemiology, Prevalence, and Incidence of HCV Infection in the United States, Including in Primary Care Settings, Over the Past 5 to 10 Years?

The incidence of HCV infection increased 3.5-fold from 2010 to 2016, rising each year during that period.^20^ The annual increase was 20 percent from 2012 to 2013, 2.6 percent in 2014, 11 percent in 2015, and 22 percent in 2016. An estimated 41,200 new HCV infections occurred in 2016.

The increase in HCV incidence in the United States has primarily been concentrated among young persons and PWID.^20^ From 2004 to 2010, the proportion of cases of acute HCV infection reporting injection drug use in each year ranged from 59 percent to 72 percent; since 2011, the proportion has been at least 75 percent in each year (84% in 2014).^240^ Acute HCV incidence in persons 18 to 29 years of age increased from 0.4 cases per 100,000 in 2004 to 2.0 cases per 100,000 in 2014 and in persons 30 to 39 years of age from 0.4 cases per 100,000 to 1.7 cases per 100,000 over the same time period.^240^ Among persons 40 to 49 years of age, the incidence of acute HCV infection increased slightly from 0.5 to 0.7 cases per 100,000, and in persons 50 to 59 years of age incidence was unchanged at 0.2 cases per 100,000. The increase in acute HCV incidence in young persons was greater in nonurban counties (13% annually) than in urban counties (5% annually).^241^ Similar trends in acute HCV incidence have been reported in specific regions in the United States. One study found a 364 percent increase between 2006 and 2012 in HCV infection among persons 12 to 29 years of age living in the Appalachian region of the United States.^21,22^ Another study found that new cases of HCV infection among persons 15 to 24 years of age in Massachusetts nearly doubled from 2002 to 2009.^23^

Recent trends towards increased HCV prevalence among reproductive aged (15 to 44 years) females have also been observed.^24,25^ Analyses of national laboratory databases (reasons for testing not available) estimate that the number of reproductive aged females with acute and past or present HCV infection doubled from 2006 to 2014,^25^ with an increase of 22 percent from 2011 to 2014.^24^ Among pregnant females who underwent testing from 2011 to 2014, 0.73 percent had HCV infection.^25^ Over the same time period there was a 68 percent increase (from 0.19% to 0.32%) in the proportion of infants born to HCV-infected females.^24^ Similar trends have been observed in several states. For example, in Kentucky, the rate of HCV detection among females of childbearing age increased 21 percent from 2011 to 2014 (from 139 to 169 per 100,000), and the proportion of infants born to HCV-infected females increased from 0.71 percent to 1.59 percent.^24^ In Wisconsin Medicaid recipients, the prevalence of HCV infection increased from 0.27 percent in 2011 to 0.52 percent in 2015.^242^ Nationally, 29,000 females with HCV infection are estimated to give birth each year, resulting in 1,700 infected infants.^25^

Within the United States., there are geographic variations in trends regarding incidence and prevalence of HCV infection. From 2004 to 2014, six states (Kansas, Maine, New Jersey, Wisconsin, Ohio, and Massachusetts) reported increases in HCV incidence of 1,000 percent or higher.^240^ A positive correlation was observed between increases in acute HCV infection incidence at the state level and increases in the proportion of treatment admissions reporting opioid injection drug use. Nine states (California, Texas, Florida, New York, Pennsylvania, Ohio, Michigan, Tennessee, and North Carolina) account for over half (51.9%) of persons living with HCV infection; five of these states are in the Appalachian region.^243^

Population level estimates of HCV prevalence based on the 2013 to 2016 NHANES data of noninstitutionalized civilians in the United States and incorporating estimates from four additional populations not included in NHANES (incarcerated persons, unsheltered homeless persons, active duty military personnel, and nursing home residents) indicate approximately 4.1 (range 3.4 to 4.9) million persons positive for HCV antibody and 2.4 (range 2.0 to 2.8) million persons chronically infected.^16^ This is lower than an earlier estimate of total HCV prevalence that used 2003 to 2010 NHANES data (4.6 million positive for HCV antibody and 3.5 with chronic infection),^13^ but there were differences in estimation methods, making it difficult to assess time trends. Based on NHANES data alone, the prevalence of chronic HCV infection decreased slightly in 2013 to 2016 to 0.84 percent (95% CI, 0.75% to 0.96%) from 1.0 percent (95% CI, 0.8 to 1.2%) in 2003 to 2010.^18^ Factors influencing the observed trends include declines in prevalence due to mortality primarily in the 1945 to 1965 birth cohort and use of more effective antiviral therapies, offset by the higher incidence of acute HCV infection in younger persons primarily related to injection drug use. Data to determine how recent trends in the epidemiology of acute HCV infection among young white persons have impacted the epidemiology of chronic HCV infection are not yet available.

## Contextual Question 2 What Are the Effects of Different Risk- or Prevalence-Based Methods for Screening for HCV Infection in Modeling Studies?

The USPSTF previously reviewed two modeling studies that found birth-cohort screening of all persons in the United States born between 1945 and 1965 to be cost-effective compared with risk-based screening.^8,9^ Although one analysis assumed rates of progression to cirrhosis and mortality substantially higher than observed in longitudinal cohorts,^8^ the other study utilized more conservative estimates consistent with natural history data.^9^ Several other cost-effectiveness analyses also found birth cohort screening in the general U.S. population to be cost-effective compared with risk based screening alone.^244–246^ All of these analyses were based on treatment with outdated antiviral regimens (i.e., no all DAA regimens), reducing relevance to current practice, and did not compare expanded screening strategies versus currently recommended screening (risk-based plus birth cohort screening).

Five studies published since the prior USPSTF modeled the cost-effectiveness of HCV screening in U.S. settings based on use of DAA regimens (Table 22). Two studies evaluated cost-effectiveness of screening in the general adult population,^247,248^ one focused on screening persons 15 to 30 years of age,^249^ and two evaluated cost-effectiveness of prenatal HCV screening.^250,251^ The analyses generally found expanded HCV screening strategies associated with incremental cost-effectiveness ratios of less than $50,000/quality adjusted life year (QALY), though there was variability in the screening strategies compared and cost-effectiveness estimates, due in part to differences in the assumptions used in each model.

Table 22 Hepatitis C Cost-Effectiveness Analyses

Screening population | Author year | Screening strategies | HCV prevalence (range) | Background testing rates | Antiviral therapy costs (range) | HCV infection utilities (range) | Rates of linkage to care | Incremental cost-effectiveness ratios | Comments
General adult population | Barocas 2018^247^ | A: ≥18 years; B: ≥30 years; C: ≥40 years; D: Birth cohort | NR (incidence in PWID 12 cases/100 person-years) | Per 100 person-years; PWID: 33.1; Non-PWID: 2.6 to 2.7 | $69,078 ($0 to $114,000) | F0 to F3: 0.94 (0.0 to 1.0); F4: 0.75 (0.6 to 0.9); Decompensated: 0.60 (0.48 to 0.75) | <30 years: 17.9%; ≥30 years: 28.9% | A: $28,000/QALY; B: Dominated; C: Dominated; D: Reference | HCV Cost-Effectiveness model. All screening strategies included risk-based screening; model included reinfection
General adult population | Eckman 2018^248^ | A: ≥18 years; B: Birth cohort; C: No screening | Birth cohort: 2.6%; Non-birth cohort: 0.29% | Not included in model | $24,270 ($24,270 to $74,760) | F0 to F3: 0.79 (NR); F4: 0.79 (NR); Decompensated: 0.72 (NR); Post-transplant: 0.75 (NR); HCC: 0.72 (NR) | 100% | A: $11,378/QALY; B: Reference; C: Dominated | Screening strategies did not include risk-based screening; model did not include reinfection
15 to 30 years old | Assoumou 2018^249^ | 9 1-time HCV screening strategies in 15 to 30 year olds vs. risk-based testing | NR (incidence 15.6/100 person-years) | PWID: 5%; Non-PWID: 3% | $71,950 to $137,820 ($26,480 to $206,730) | F0 to F3: NR; F4: 0.62 (0.55 to 0.75); Decompensated: 0.48 (0.40-0.60) | 53% | Counselor-initiated, routine rapid testing: $71,000/QALY; Physician-ordered, counselor-performed targeted rapid testing: $40,000/QALY; Counselor-initiated, targeted rapid testing: $44,000/QALY; Other screening strategies: Dominated; Risk-based testing: Reference | Hepatitis C Cost-Effectiveness model. Screening strategies varied with respect to routine vs. expanded targeted vs. current risk-based screening; counselor/tester vs. physician-initiated; rapid vs. standard test. Counselor-initiated, routine rapid testing associated with greater average QALY gain (0.007 to 0.11) compared with the other two non-dominated strategies and below $100,000/QALY willingness-to-pay threshold
Prenatal screening | Chaillon 2019^250^ | A: Prenatal screening; B: Risk-based screening | 0.73% | 5% per year | $25,000 (no range reported) | F0: 0.93 (0.83 to 1.0); F1, F2: 0.86 (0.78 to 0.94); F3: 0.83 (0.78 to 0.89); F4: 0.81 (0.68 to 0.89); Decompensated cirrhosis: 0.70 (0.56 to 0.79); HCC: 0.67 (0.56 to 0.78); Post-transplant: 0.71 (0.69 to 0.79) | Appears to be 100% | A: $2,826/QALY; B: Reference | Costs and effects on neonate not modelled; antiviral therapy administered postpartum; model did not appear to include reinfection
Prenatal screening | Tasillo 2019^251^ | A: Prenatal screening; B: Current practice | 0.38% | During pregnancy: 14%; No risk behaviors: 4 per 100 person-years; With risk behavior: 40 per 100 person-years | No cirrhosis: $39,600 ($19,800 to $59,400); Cirrhosis: $68,773 ($47,833 to $89,712) | F0 to F3: 0.94 (0.94 to 1.0); F4: 0.75 (NR); Decompensated cirrhosis: 0.60 (NR) | Linked to care: 25%; Initiated treatment if linked: 92% | A: $41,000/QALY; B: Reference | HCV Cost-Effectiveness model. Costs and effects on neonate not modelled; antiviral therapy offered 6 months postpartum

Abbreviations: HCC = hepatocellular carcinoma; HCV = hepatitis C virus; NR = not reported; PWID = people who inject drugs; QALY = quality-adjusted life year.

One analysis by Barocas et al. of HCV screening in the general adult population utilized the Hepatitis C Cost-Effectiveness (HEP-CE) model, an individual-based, stochastic Monte Carlo simulation model with an embedded Markov state transition matrix.^247^ It compared one time “standard of care” birth cohort screening of all U.S. persons born between 1945 and 1965 versus one time screening of all persons at least 18, at least 30, or at least 40 years of age. All screening strategies included targeted screening of high-risk persons. The model assumed that all cases of incident HCV infection were related to injection drug use (12 cases per 100 person-years), with background (not related to screening) testing rates of 33 percent in PWID and 2.6 percent to 27 percent in other persons. Treatment was based on sofosbuvir / velpatasvir at a cost of $23,026 per month ($0 to $38,000 in sensitivity analyses), with an SVR rate in persons without cirrhosis of 99 percent (50 to 99% in sensitivity analyses) and in persons with cirrhosis of 93 percent (93 to 96% in sensitivity analyses).

The model estimated that compared with birth cohort screening, the 18 and over strategy would identify 256,000 additional cases of HCV infection and lead to 280,000 additional cures and 4,400 fewer cases of HCC over the cohort lifetime, with an incremental cost-effectiveness ratio of $28,193/QALY. More cures than additional cases of HCV infection occurred in the model because of reinfections. Among persons with HCV infection, the 18 and over strategy was associated with an average increase in life expectancy of 0.68 years (0.63 QALY) compared with standard of care screening. The 18 and over strategy dominated (less costly and more effective or lower incremental cost-effectiveness ratio) the 30 and over or 40 and over strategies in the base analysis and remained associated with incremental cost-effectiveness ratios of less than $40,000/QALY in one-way sensitivity analyses that assumed reduced linkage to care, absence of mortality benefit from SVR, higher HCV treatment costs ($130,000), lower HCV prevalence, or greater restrictions on HCV treatment (i.e., restricting treatment to persons with more advanced fibrosis), compared with the base case assumptions. The 18 and over strategy was less cost-effective in scenarios in which antiviral treatment was assumed to be half as effective ($53,500/QALY), when fibrosis progression was assumed to be half as rapid ($65,500/QALY), and when testing was assumed to be twice as inefficient (i.e., need to screen twice as many patients to identify the same number of HCV-infected persons, $44,100/QALY). In some sensitivity analyses (e.g., high treatment costs, less rapid fibrosis progression, lower HCV prevalence, lower rates of linkage to care, greater treatment restrictions), the 30 and over strategy was more cost-effective than the 18 and over strategy. The 30 and over strategy performed best relative to the 18 and over strategy in the decreased fibrosis ($42,800/QALY vs. $65,500/QALY) and inefficient testing ($33,900/QALY vs. $44,100/QALY) scenarios. The 40 and over strategy was dominated in all sensitivity analyses. An analysis of screening in the general adult population by Eckman et al. compared one-time screening of all persons 18 years or older with screening of persons born between 1945 to 1965 (birth cohort screening) or no screening in a 2-stage Markov simulation model.^248^ Unlike the cost-effectiveness analysis by Barocas et al.,^247^ screening strategies did not include risk-based screening. The Eckman et al. analysis also assumed lower utilities for chronic HCV infection without cirrhosis (0.79, compared with 0.94 in the other analysis), lower costs of DAA therapy ($24,270 vs. $69,078 for a full 12 week course), and higher rates of linkage to care (100% vs. 18% to 29%). It did not model HCV incidence (including reinfection) following successful treatment with antiviral therapy. Despite these differences, the Eckman et al. analysis also found expanded HCV screening to be cost-effective compared with birth cohort screening.

In the Eckman et al. analysis, screening all persons 18 years of age and older was associated with an average gain of 0.0022 QALYs compared with birth cohort screening, and 0.0101 QALYs compared with no screening. The incremental cost-effectiveness of the 18 and older strategy versus birth cohort screening was $11,378/QALY, and the 18 and older strategy dominated no screening. In sensitivity analysis, the incremental cost-effectiveness ratio of the 18 and older strategy versus birth cohort screening exceeded $50,000/QALY when the HCV prevalence in the non-birth cohort was less than 0.07 percent (base case 0.29%) or when the monthly cost of antiviral therapy exceeded $28,000. Cost-effectiveness estimates were also sensitive to the age at time of HCV infection (older age at acquisition associated with lower cost-effectiveness).

An analysis based on the HEP-CE model (used in the study by Barocas et al.) estimated effects of nine one-time screening strategies in U.S. persons, focusing on the population 15 to 30 years of age.^249^ The screening strategies differed on three factors: 1) routine (screen all persons) versus expanded targeted testing (validated HCV screening checklist used to identify high-risk persons) versus current practice (risk-based testing in persons perceived to be at high risk, without the checklist), 2) rapid finger stick versus venipuncture, and 3) screening ordered by physician versus by counselor or tester using standing orders. Testing rates were assumed to be lower with physician ordering and receipt of results higher with rapid testing. Current practice screening rates were assumed to be 5 percent in PWID and 3 percent otherwise. The model was based on treatment with sofosbuvir / ledipasvir or sofosbuvir / velpatasvir with the cost of a course of treatment ranging from $71,950 to $137,820 and SVR rates of 93 percent to 99 percent, depending on cirrhosis status and genotype.

The model found that strategies involving rapid testing dominated strategies involving venipuncture testing. Compared with current practice, counselor-initiated, routine rapid testing identified more cases (20% vs. 5%), resulted in a greater number of patients achieving SVR (18% vs. 2%), and resulted in fewer HCV-related deaths (34% to 31%), with an incremental cost-effectiveness ratio of $71,000/QALY. In probabilistic sensitivity analyses, the incremental cost-effectiveness ratio with this strategy remained below $100,000/QALY unless the prevalence of injection drug use was less than 0.59 percent, the HCV prevalence in PWID was less than 16 percent, the reinfection rate was more than 26 cases per 100 person-years, or reflex confirmatory testing was performed following all reactive venipuncture tests. Although physician-ordered, counselor-performed, expanded targeted rapid testing ($40,000/QALY) and counselor-initiated, expanded targeted testing ($44,000/QALY) were more cost-effective than counselor-initiated, routine rapid testing, average gains in QALYs were lower with these strategies than with the counselor-initiated, routine rapid testing strategy (incremental differences 0.0008 to 0.0011 QALYs).

Two studies focused on prenatal HCV screening.^250,251^ An analysis by Tasillo et al. evaluated prenatal screening using the HEP-CE model.^251^ The analysis compared universal one-time screening during pregnancy versus current practice (14% screened during pregnancy); both strategies lifetime testing that occurred following pregnancy. The model assumed that therapy with a DAA regimen would be offered 6 months postpartum, with a base cost of $39,600 for glecaprevir / pibrentasvir (for persons without cirrhosis) and $68,773 for sofosbuvir / velpatasvir (for persons with cirrhosis). The analysis did not include neonatal outcomes in cost-effectiveness estimates or model the lifetime of neonates born with HCV infection, but estimated the proportion of neonates identified as exposed to HCV infection. HCV prevalence in pregnancy was assumed to be 0.38 percent; assumptions regarding HCV incidence, utilities associated with HCV infection, and rates of linkage to care were similar to the study by Barocas et al. on HCV screening in the general adult population.

The Tasillo et al. analysis found prenatal screening associated with earlier diagnosis and time to cure of HCV infection, with 27 percent of cases achieving SVR within 5 years and 36 percent within 10 years (compared with 16% and 37%, respectively, with current practice). Prenatal screening was associated with a 16 percent reduction in HCV-attributable mortality over the lifetime of the cohort, and average gains of 0.002 QALYs in the entire cohort and 0.0.5 QALYs in HCV-infected persons compared with current practice, with an incremental cost-effectiveness ratio of $41,000/QALY. The incremental cost-effectiveness ratio was $83,000/QALY when prevalence was half (0.18%) of the base case assumption (0.18%) and less than or equal to $50,000/QALY when HCV testing rates were higher (50%) in PWID, when treatment initiation rates were lower (64.5%), and when neonatal testing costs were considered. The incremental cost-effectiveness ratio was $168,000/QALY when the rate of fibrosis progression was reduced by half (average time to cirrhosis, 70 years) and $137,000/QALY when HCV infection before cirrhosis had no associated cost or decrease in quality of life. Prenatal screening increased the identification of neonates exposed to HCV at birth from 44 percent to 92 percent.

An analysis by Chaillon et al. also evaluated prenatal screening versus risk-based screening, using a closed cohort Markov model.^250^ The analysis assumed antiviral treatment after pregnancy with a DAA regimen (base cost $25,000 for a full treatment course) and a background testing and linkage rate of 5 percent per year; it did not model costs or effects on the neonate. Compared with the analysis by Tasillo et al., base case assumptions in Chaillon et al. included higher HCV prevalence (0.73% vs. 0.38%), lower antiviral treatment costs ($25,000 vs. $39,600 in persons with cirrhosis and $68,773 in persons without cirrhosis), and lower utilities for F1 to F3 fibrosis in HCV-infected persons (0.83-0.86 vs. 0.94). In addition, the model appeared to assume that all persons diagnosed with HCV infection would be linked to care and receive treatment.

In the Chaillon et al. analysis, prenatal screening was estimated to result in the detection and treatment of 7,000 additional females, with an average gain of 0.019 QALY and an incremental cost-effectiveness ratio of $2,826/QALY, compared with risk-based screening. Incremental cost-effectiveness ratios remained below $5,000/QALY in sensitivity analyses based on alternative treatment eligibility scenarios, lower HCV prevalence rates (0.03% to 0.04%), lower fibrosis progression rates (21% cirrhosis at 35 years), lower SVR (85%), higher baseline rates of diagnosis and linkage to care (40%), higher loss to followup (50% per year), and higher background testing (20% per year). Screening was estimated to result in detection and treatment of an estimated 300 children born to mothers infected by HCV.

Identification and treatment of HCV infection prior to pregnancy could result in the additional benefit of reducing the risk of mother-to-child transmission following successful treatment.^252^ However, we identified no study on the cost-effectiveness of screening strategies aimed at women prior to pregnancy.

## Contextual Question 3 What Is the Effect of Antiviral Treatments on Behavioral Outcomes?

No trial of DAA therapy included in this report reported behavioral outcomes. Two open-label studies of HCV-infected PWID found receipt of interferon-based therapy associated with reductions in some self-reported drug and substance use behaviors.^253,254^ A non-randomized study (n=124) found interferon-based therapy associated with reduced likelihood of injection drug use equipment sharing (adjusted OR 0.85, 95% CI, 0.74 to 0.99) compared with no treatment at median followup of 1.8 years after adjusting for age, sex, housing status, education level, employment status, and social functioning level, but no effect on injection drug use in the last 30 days (adjusted OR 1.06, 95% CI, 0.93 to 1.21).^254^ A before-after analysis of persons with current or past injection drug use (n=93) found decreased likelihood of injection drug use (unadjusted OR 0.89, 95% CI, 0.83 to 0.95) and alcohol use (unadjusted OR 0.56, 95% CI, 0.40 to 0.77) 24 weeks after completing interferon-based therapy compared with prior to therapy, but no difference in likelihood of injection drug use equipment sharing (unadjusted OR 0.87, 95% CI, 0.70 to 1.07).^253^