# Chapter 2 Methods

## Key Questions and Analytic Framework

This systematic review followed a standard protocol in accordance with USPSTF procedures.^89^ The scope and Key Questions (KQs) for this report were determined by the USPSTF and informed by evidence gaps identified from the prior reviews.^1–3,5,90^ Three additional contextual questions on recent epidemiologic trends in HCV infection, modeling analyses, and behavioral effects of current antiviral therapies were requested by the USPSTF. The KQs and Contextual Questions are shown below. Investigators created an analytic framework incorporating the KQs and outlining the patient populations, interventions, outcomes, and potential adverse effects, as well as the direct and indirect pathways from screening to health outcomes (Figure 1).

Figure 1 Analytic Framework and Key Questions

1a Does screening for hepatitis C virus (HCV) infection in pregnant and nonpregnant adolescents and adults without known abnormal liver enzyme levels reduce HCV-related mortality and morbidity or affect quality of life?
1b Does prenatal screening for HCV infection reduce risk of vertical transmission of HCV infection?
2 What is the effectiveness of different risk- or prevalence-based methods for screening for HCV infection on clinical outcomes?
3 What is the yield (number of new diagnoses per tests performed) of one-time versus repeat screening or alternative screening strategies for HCV infection, and how does the screening yield vary in different risk groups?
4 What are the harms of screening for HCV infection (e.g., anxiety and labeling)?
5 What are the effects of interventions during labor and delivery or the perinatal period on risk of vertical transmission of HCV infection?
6 What is the effectiveness of currently recommended antiviral treatments in improving health outcomes in patients with HCV infection?
7 What is the effectiveness of currently recommended antiviral treatments in achieving a sustained virologic response in patients with HCV infection?
8 What are the harms of currently recommended antiviral treatments?
9 What is the association between experiencing sustained virologic response following antiviral treatment and reduction in risk of HCV-related adverse health outcomes?

Note: The numbers in the figure correspond to the numbers of the Key Questions.

* Includes persons without abnormal laboratory values. Adolescents are defined as those ages 12 to 17 years. Excludes persons living with HIV, transplant recipients, and patients with renal failure.

^†^ Defined as HCV antibody testing with confirmatory HCV RNA testing as indicated.

^‡^ Includes interventions that may affect vertical transmission of HCV, such as cesarean delivery, amniocentesis, fetal monitoring, management of ruptured membranes, breastfeeding, and antiviral treatment.

Abbreviations: HCV = hepatitis C virus; SVR = sustained virologic response.

The analytic framework depicts the relationship between the populations, interventions, outcomes, and harms of screening for hepatitis C virus (HCV) infection. The far left of the framework describes the target population for screening as asymptomatic, nonpregnant and pregnant adults and adolescents. (A footnote indicates these are individuals without abnormal lab values. Adolescents are defined as those 12 to 17 years of age. Also noted is that those with HIV, transplant recipients, and patients with renal failure are excluded.) To the right of the population is a line that represents HCV screening and leads to either HCV positive or HCV negative populations. (A footnote describes that screening includes HCV antibody testing with confirmatory HCV RNA testing as indicated.) A subsequent arrow indicates assessment of harms of screening (Key Question 3). From the HCV positive population, an arrow leads to disease staging and, in pregnancy, represents the effectiveness of interventions for HCV positive persons during labor and delivery or in the perinatal period on risk of vertical transmission of HCV infection (Key Question 4). (A footnote specifies that these are interventions that may affect the vertical transmission of HCV, such as Caesarian section, amniocentesis, fetal monitoring, or others, as well as antiviral treatment.) This line also represents the effectiveness of antiviral treatment in improving mortality, morbidity, quality of life (Key Question 5), and in improving the intermediate outcome of SVR rates (Key Question 6), as well as harms associated with antiviral treatments (Key Question 7). A dotted line represents the examination of the association between SVR rates and the reduction in risk of adverse health outcomes associated with HCV infection (Key Question 8). An overarching arrow symbolizing Key Question 1 spans directly from screening, including prenatal screening, to the health outcomes mentioned above. In addition, this line represents the effectiveness of different risk- or prevalence-based methods for screening for HCV infection on the health outcomes (Key Question 2).

Key differences between this report and the prior reviews are inclusion of adolescents in addition to adults; evaluation of new all-oral, DAA regimens. We also removed previously reviewed questions on harms of liver biopsy, given its reduced role in evaluation of patients with HCV infection, and on effects of counseling or immunizations in persons with HCV infection, given limited evidence and likely small magnitude of effects relative to antiviral treatments. This report focuses on effects of treatments in populations more likely to be identified by screening (i.e., asymptomatic and without advanced liver disease), and excludes poor quality studies (e.g., cohort studies that did not perform statistical adjustment) that were included in prior USPSTF reviews. We did not re-review the diagnostic accuracy of HCV screening, which the prior review found to be highly accurate.^91^

### Key Questions

1a Does screening for HCV infection in pregnant and nonpregnant adolescents and adults without known abnormal liver enzyme levels reduce HCV-related mortality and morbidity or affect quality of life?
1b Does prenatal screening for HCV infection reduce risk of vertical transmission of HCV infection?
2 What is the effectiveness of different risk- or prevalence-based methods for screening for HCV infection on clinical outcomes?
3 What is the yield (number of new diagnoses per tests performed) of one-time versus repeat screening or alternative screening strategies for HCV infection, and how does the screening yield vary in different risk groups?
4 What are the harms of screening for HCV infection (e.g., anxiety and labeling)?
5 What are the effects of interventions during labor and delivery or the perinatal period on risk of vertical transmission of HCV infection?
6 What is the effectiveness of currently recommended antiviral treatments in improving health outcomes in patients with HCV infection?^*^
7 What is the effectiveness of currently recommended antiviral treatments in achieving a SVR in patients with HCV infection?^*^
8 What are the harms of currently recommended antiviral treatments?^*^
9 What is the association between experiencing SVR following antiviral treatment and reduction in risk of HCV-related adverse health outcomes?

* Subpopulations of interest for KQs 6, 7, and 8 include those defined by age, race/ethnicity, sex, drug use, receipt of medications for treatment of opioid use disorder, stage of disease, HCV genotype, and pregnancy status (including nonpregnant women of childbearing age).

### Contextual Questions

Three Contextual Questions were also requested by the USPSTF to help inform the report. Contextual Questions are addressed by narratively summarizing key evidence; they are not reviewed using systematic review methodology.

1. Based on population level estimates, what are recent trends in the epidemiology, prevalence, and incidence of HCV infection in the United States, including in primary care settings, over the past 5 to 10 years?
2. What are the effects of different risk- or prevalence-based methods for screening for HCV infection in modeling studies?
3. What is the effect of antiviral treatments on behavioral outcomes?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through February 8, 2019), and Ovid MEDLINE (1946 through February 8, 2019) for relevant studies. Search strategies are available in Appendix A1. We also searched ClinicalTrials.gov for ongoing studies, and reviewed the reference lists of relevant review articles and studies meeting inclusion criteria. We also carried forward studies in the prior USPSTF report that met inclusion criteria for this update.^2,90^ Ongoing surveillance was conducted to identify major studies published since February 2019 that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on November 22, 2019 and identified no studies affecting review conclusions.

## Study Selection

Two reviewers independently evaluated each study to determine its inclusion eligibility based on predetermined inclusion and exclusion criteria developed for each KQ (Appendix A2).

The target population for screening was asymptomatic, pregnant and nonpregnant adolescents (ages 12 to 17 years) and adults without prior HCV infection. For treatment, the target population was persons with HCV infection likely to be identified by screening. However, no trial enrolled screen-detected patients, and trials did not report presence of symptoms. To evaluate patients more likely to be asymptomatic and identified by screening, we restricted inclusion of antiviral treatment studies to those in which up to 20 percent of participants had cirrhosis at baseline. For antiviral regimens with few studies meeting this threshold and for studies on the association between SVR after antiviral therapy and clinical outcomes, we permitted a threshold up to 25 percent. We included studies of patients previously treated with interferon-based therapy (interferon or pegylated interferon with or without ribavirin) or boceprevir or telaprevir with pegylated interferon and ribavirin, because data indicate similar SVR rates in these treatment-experienced compared with treatment-naive patients.^73^ Included interventions were HCV screening and alternative screening strategies; mode of delivery, labor management strategies, and breastfeeding practices; currently recommended (including alternative) DAA regimens for evaluation of clinical outcomes, SVR rates and harms; and DAA regimens or interferon-based treatment for evaluation of mortality and long-term clinical outcomes.^74^ For analysis of SVR rates, we included studies in which ribavirin or dasabuvir was not used as recommended (e.g., ombitasvir / paritaprevir / ritonavir / dasabuvir that omitted ribavirin for genotype 1a infection or used ribavirin for genotype 1b infection, or did not include dasabuvir for genotype 1 infection) (Tables 2 and 3), because SVR rates were similar to recommended regimens with these variations, but performed sensitivity analyses without them. For analysis of adverse events, we restricted inclusion to trials in which ribavirin was administered as recommended. DAA regimens were restricted to recommended doses and durations. We excluded trials that focused on persons coinfected with HIV or HBV infection, transplant patients, or with advanced renal disease.

For KQs on screening and treatment, we included randomized trials. For questions on screening, perinatal (labor and delivery or breastfeeding) interventions, effects of DAA regimens on clinical outcomes, and the association between SVR after antiviral therapy and clinical outcomes, we also included cohort studies that reported risk estimates adjusted for potential confounders. We included trials of current DAA regimens versus placebo, an older antiviral regimen, or another DAA regimen (including regimens not currently recommended). We also included trials of DAA regimens without one of these comparisons, because there were few comparative trials. Clinical trials were defined as studies in which patients were prospectively allocated to treatment by the study investigator using pre-defined inclusion criteria and followup methods. Included outcomes were mortality, morbidity (e.g., cirrhosis, hepatic decompensation, liver transplant, extrahepatic manifestations of HCV infection), quality of life, HCV transmission, harms (e.g., labeling, anxiety, drug-related and treatment-related harms), screening yield (number of new diagnoses per tests performed), and perinatal transmission. We restricted inclusion to English-language articles, and we excluded studies published only as abstracts. Studies of non-human subjects were excluded, and studies had to report original data. The selection of literature is summarized in the literature flow diagram (Appendix A3), and Appendix A4 provides a list of included studies. Appendix A5 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We constructed evidence tables summarizing the data from each study. One investigator abstracted details about the study design, patient population, setting, interventions, analysis, followup, and results. A second investigator reviewed abstracted data for accuracy. Two investigators independently applied criteria developed by the USPSTF^89^ to rate the quality of each study as good, fair, or poor (Appendix A6). Discrepancies were resolved through a consensus process. In accordance with the USPSTF Procedure Manual, we excluded studies rated poor quality due to important methodological shortcomings that severely undermine their reliability;^89^ this applied to studies utilized in the prior USPSTF review that were rated poor quality and were excluded in the current report.

## Data Synthesis

We performed a random effects meta-analysis to summarize the proportion of patients experiencing SVR and adverse events with current DAA regimens. We used a generalized linear mixed effects model with a logit link, allowing the inclusion of studies in which the proportion of patients with the event were 0 percent or 100 percent. We combined arms of comparable interventions within the same study so each study was represented once in a meta-analysis, in order to avoid overweighting. For SVR, we performed separate analyses for each genotype (1 through 6); for adverse events, results were pooled across genotypes. For SVR and adverse events, analyses were stratified according to DAA regimen. Subgroup and sensitivity analyses were performed on geographic settings (United States or Europe, multinational, or other), fibrosis stage (cirrhosis excluded or some [up to 20% of patients] with cirrhosis), prior treatment status (naïve or experienced to interferon-based therapies, boceprevir or telaprevir), and quality. For SVR, we performed sensitivity analysis by excluding studies in which ribavirin or dasabuvir was not used as recommended. For analyses of adverse events, we excluded trials of ribavirin-containing regimens except for ombitasvir / paritaprevir / ritonavir / dasabuvir with ribavirin, which is recommended for genotype 1b infection.

We also performed a random effects meta-analysis of adjusted hazard ratios (HRs) of SVR after antiviral therapy versus no SVR on clinical outcomes (mortality, liver-related mortality, cirrhosis, and HCC) using a linear mixed effects model. In some cases the adjusted HR for SVR versus no SVR had to be calculated from other estimates (e.g., from adjusted HRs for SVR and no SVR vs. no treatment). In these situations we calculated the adjusted HR for SVR versus no SVR based on the HRs for SVR versus no treatment and no SVR versus no treatment and their reported CIs, assuming a correlation of 0 between the two HRs. Because HRs are typically positively correlated, this assumption results in more conservative (i.e., wider) CIs for the calculated HR. Subgroup analysis were performed on duration of study (5 years or less vs. more than 5 years), geographic setting (United States/Europe vs. Asia) and whether the study had full adjustment of confounding variables (age, sex, fibrosis stage and genotype) or did not adjust for one or more of these populations. We also performed sensitivity analysis by excluding studies with potential overlapping populations in order to ensure that results were not sensitive to double counting of patients.

For all meta-analyses, statistical heterogeneity was assessed using the variance parameter of the random effects, the Cochran Q-test and I^2^ statistic.^92^ For pooled proportions of SVR and adverse events, the Cochran Q-test and I^2^ statistic were based on the Freeman-Tukey double arcsine transformed proportions.^93^ All meta-analyses were conducted using SAS 9.4 (SAS Institute Inc., Cary, NC, USA.) and forest plots were created using Stata/SE 14.0 (StataCorp, College Station, TX).

We also conducted random effects meta-analysis on adverse events with DAA regimens versus placebo and DAA regimens versus telaprevir / pegylated interferon / ribavirin using RevMan 5.3.5 (the Nordic Cochrane Centre, Copenhagen). Analyses were stratified by DAA regimen. There were too few trials evaluating these comparisons to conduct additional sensitivity or subgroup analyses

We assessed the aggregate internal validity (quality) of the body of evidence for each KQ (“good”, “fair”, “poor”) using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and directness of evidence in the Summary of Evidence.^89^ We determined aggregate internal validity using the totality of evidence (new studies identified for the update plus studies carried forward from the prior USPSTF report).

## Expert Review and Public Comment

The draft research plan was posted for public comment from September 21 to October 18, 2017. In response to public comments, the USPSTF modified the research plan before finalizing to clarify the following: screening settings include emergency departments and settings that offer integrated services for primary care and behavioral health care; subpopulations of interest include drug use, persons using medication-assisted therapies, and nonpregnant women of childbearing age; morbidity outcomes include extrahepatic manifestations of HCV infection, such as depression and diabetes; health outcomes include perinatal HCV transmission; and the population for antiviral treatment includes persons with a METAVIR fibrosis stage of 0 to 3. The USPSTF also added a KQ on the yield of repeat HCV screening and revised Contextual Question 3 to address the effects of antiviral treatment on both positive and negative behaviors pertaining to HCV risk.

A draft version of this report was reviewed by content experts, USPSTF members, Agency for Healthcare Research and Quality Medical Officers, and collaborative partners. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report when appropriate. Additionally, a draft of this report was posted for public comment on the USPSTF Web site from August 27, 2019 to September 23, 2019. Comments were received from 11 commenters during this public comment period; minor editorial changes were made to the report based on these comments, but no changes were made to the results or conclusions.