# Chapter 1 Introduction and Background

## Purpose

The purpose of this report is to systematically review the evidence on screening for hepatitis C virus (HCV) infection in asymptomatic adults and adolescents without known liver enzyme abnormalities. This report updates prior (2013) U.S. Preventive Services Task Force (USPSTF) reviews on screening for HCV infection^1,2^ and prenatal screening,^2,3^ and a comparative effectiveness review on antiviral treatments.^4,5^ Although prior reports focused on benefits and harms of screening and treatment in adults, this report expands the population to include adolescents. For treatments, this report focuses on currently recommended direct acting antiviral (DAA) therapies and interventions to potentially reduce risk of mother-to-child transmission. It will be used by the USPSTF to update its 2013 recommendation on screening for HCV infection in adults and potentially inform a new recommendation on HCV screening in adolescents.

In 2013, the USPSTF recommended screening for HCV infection in adults at high risk for infection and recommended offering one-time screening for HCV infection in adults born between 1945 and 1965 (“birth cohort” screening) (B Recommendation).^6^ This recommendation represented a change from the prior (2004) USPSTF recommendation, which found insufficient evidence to recommend for or against HCV screening in adults at high risk for infection (I recommendation); the 2004 USPSTF recommendation did not address birth cohort screening and recommended against HCV screening in persons not at increased risk (D recommendation).^7^ The USPSTF did not issue a recommendation specifically on prenatal HCV screening, but noted that antiviral therapies were contraindicated during pregnancy and found inadequate evidence that labor management and breastfeeding strategies in HCV-infected persons are effective at reducing risk for mother-to-child transmission.

The basis for the change in the 2013 USPSTF recommendation was evidence that newer antiviral therapies are more effective than prior therapies in achieving the intermediate outcome of sustained virologic response (SVR) and evidence showing that SVR after antiviral therapy is associated with improved clinical outcomes (all-cause and liver-related mortality and hepatocellular carcinoma [HCC]), with few serious treatment-related harms that generally resolve after treatment discontinuation.^6^ The USPSTF also considered the prevalence of HCV infection in high-risk persons (e.g., ≥50% in persons who inject drugs [PWID]) and in persons born between 1945 and 1965 (3% to 4%), and modeling studies that indicated cost-effectiveness of the birth cohort screening strategy.^8,9^ The USPSTF found few serious adverse events with liver biopsy performed for the diagnostic evaluation of persons with HCV infection and noted that fewer biopsies were being performed due to the availability of accurate noninvasive tests for evaluating liver fibrosis. The USPSTF had previously found that screening tests are highly accurate for diagnosing HCV infection (overall sensitivity 94% and specificity 97%).^7^

## Condition Background

### Condition Definition

HCV is a single-stranded, positive-sense ribonucleic acid (RNA) virus of the family Flaviviridae. HCV infection can range from mild and self-limited to a serious, lifelong illness that can result in cirrhosis, liver failure, and HCC.^10^ In most cases (78% to 85%), acute HCV leads to chronic HCV.^10^ HCV is primarily acquired by exposures to infected blood, with injection drug use the strongest risk factor. In the United States, approximately 70 to 77 percent of HCV infections are caused by genotype 1 (subtypes 1a or 1b), 13 to 16 percent by genotype 2, 12 percent by genotype 3, and less than 5 percent by genotypes 4, 5, or 6 combined.^11,12^

### Prevalence and Burden of Disease/Illness

HCV is the most common chronic bloodborne pathogen in the United States. The number of U.S. residents with past or current HCV infection (positive for anti-HCV antibody) is estimated at 4.1 million (range 3.4 million to 4.9 million); of these, an estimated 2.4 million (range 2.0 million to 2.8 million) are currently infected, defined as having HCV detectable in the blood (viremia).^10,13,14^ Approximately three-quarters (78% to 85%) of those who test positive for anti-HCV antibody have chronic infection;^10,15^ those with anti-HCV antibody but no viremia are considered to have cleared the infection. The estimated prevalence of chronic HCV infection during the years 2013 to 2016 was approximately 1.0 percent (95% confidence interval [CI], 0.8 to 1.1%).^16^ Persons born between 1945 and 1965 comprise approximately 27 percent of the U.S. population but account for approximately three-quarters of all HCV infection,^16^ and are at 6.0- to 9.5-fold increased risk of having HCV infection compared with younger adults.^17,18^ Males are at increased risk for HCV infection compared with females (odds ratio [OR] 1.6, 95% CI, 1.1 to 2.4), and non-Hispanic black persons are at increased risk compared with 62 other races/ethnicities (OR 1.6, 95% CI, 1.1 to 2.3), excluding American Indian/Alaska Natives.^18^ American Indian/Alaska Natives, who are often not included in national seroprevalence surveys, have higher HCV-related mortality than non-Hispanic black persons.^19^ Reported cases of acute HCV infection increased approximately 3.5-fold from 2010 through 2016.^20^ After adjusting for under-ascertainment and under-reporting, an estimated 41,200 (95% CI, 32,600 to 140,600) new HCV infections occurred in the United States in 2016.^20^ The increase in acute HCV incidence has most impacted young, white PWID living in non-urban areas.^21–23^

Data also indicate an increase in the number of reproductive aged women (15 to 44 years of age) with HCV infection.^24,25^ An estimated 29,000 females with HCV infection give birth annually in the United States, resulting in 1,700 cases of infected infants.^25^ Trends in HCV epidemiology, prevalence, and incidence are discussed in more detail in Contextual Question 1.

### Etiology and Natural History

HCV infection is a leading cause of complications from chronic liver disease. The number of deaths due to HCV infection ranged from 18,650 to 19,629 from 2012 to 2015 (4.9 to 5.0 deaths/100,000) and decreased to 18,153 in 2016 (4.5 deaths/100,000).^20^ Despite likely underestimation, HCV-related mortality exceeds mortality associated with 60 other nationally notifiable infectious conditions combined.^26^ According to the Centers for Disease Control and Prevention, of every 100 persons infected with HCV, approximately 60-70 will develop chronic liver disease, 5 to 20 will develop cirrhosis over a period of 20 to 30 years, and 1 to 5 will die from the consequences of liver cancer or cirrhosis.^27^ HCV without cirrhosis is associated with worse quality of life and symptoms (e.g., fatigue) compared with not having HCV infection.^28–32^ Other extrahepatic manifestations of HCV infection include mixed cryogloblinemias, non-Hodgkin lymphoma, type II diabetes mellitus and insulin resistance, cardiovascular disease, and renal disease.^33^

The natural course of chronic HCV infection varies. Some patients with chronic HCV infection have only mild liver disease after decades of infection or never develop histologic evidence of liver disease.^34^ In other patients, inflammation and fibrosis of the liver may progress to cirrhosis, which can lead to end-stage liver disease or HCC. In persons with cirrhosis due to HCV infection, the annual incidence of HCC is 1 to 4 percent.^35^ Once cirrhosis develops, patients have a much higher risk of death, and some may benefit from liver transplantation. Until recently, chronic HCV was the leading indication for liver transplantation in the United States.^36,37^ The number of HCV-related liver transplants in the United States declined from a peak of 1,905 in 2014 to 1,535 in 2016.^36^ Well-established predictors of advanced fibrosis in those with chronic HCV infection include older age at infection, longer duration of infection, male sex, concomitant HIV or hepatitis B virus (HBV) infection, and greater alcohol use.^34,38,39^ Other factors that may be associated with increased risk of fibrosis include insulin resistance, hepatic steatosis, higher viral load, and the presence of certain human leukocyte antigen (HLA) class II polymorphisms. Once a person develops advanced (METAVIR stage 3) fibrosis, the risk of progression to cirrhosis is around 10 percent per year.^40^

Estimating the proportion of patients in the general population with HCV infection who progress to cirrhosis is difficult because the time of acquisition is often unclear and important endpoints often do not occur until after decades of infection; in addition, reasons for the variability in progression are not completely understood.^41^ Six retrospective cohort studies of HCV-infected adults with known time of infection (based on an identified exposure, often to contaminated blood products during young adulthood) reported cirrhosis in 0 to 10 percent of patients after at least 10 years of followup.^29,42–48^ Studies of community cohorts estimate cirrhosis in an average of 7 percent of persons after 20 years of HCV infection, with rates about twice as high in clinical and referral cohorts.^38,49^ One study of females infected by contaminated batches of anti-D immunoglobulin in 1980 found that approximately 14 percent of those who remained viremic had cirrhosis after 35 years.^50^ Other studies suggest that progression to cirrhosis may accelerate after 20 years of chronic infection.^47,51^

Mother-to-child (vertical) transmission is believed to be the main route of HCV infection acquisition in children. In a meta-analysis of the risk of vertical HCV infection, the pooled transmission rate was 5.8 percent among females with HCV monoinfection and 10.8 percent among those with HCV/HIV coinfection.^52^

### Risk Factors

HCV is primarily acquired via percutaneous exposures to infected blood. The strongest risk factor for HCV infection is injection drug use. The prevalence of HCV infection in PWID varies widely depending on age, duration of injection drug use, and other factors (such as availability and use of needle exchange programs).^53^ Recent surveys of active PWID indicate that approximately one third of those aged 18 to 30 years are HCV-infected. Older PWID typically have a higher prevalence (approximately 70% to 90%) of HCV infection.^27^ Although large population-based studies^54–56^ report independent associations between HCV infection and some high-risk sexual behaviors (multiple sexual partners, unprotected sex, and/or sex with a person infected with HCV infection or using injection drugs), the efficiency of transmission via sexual contact appears to be low; high-risk sexual behaviors may be a marker for unacknowledged drug use or other risk factors. Transfusions prior to 1992 are a risk factor for HCV infection but are no longer an important source of infection due to the implementation of effective screening programs for donated blood.^57,58^

### Rationale for Screening/Screening Strategies

Screening for HCV infection in asymptomatic adults who have no history of liver disease or known liver enzyme abnormalities may identify infected patients at earlier stages of disease, before they develop serious or irreversible liver damage. Studies estimate that around 50 percent (range 43 to 72%) of persons in the United States with chronic HCV infection are unaware of their status.^18,57–60^ Antiviral treatment, has become increasingly effective at achieving sustained aviremia (clearance of HCV infection). Screening for HCV infection might also help prevent transmission by decreasing high-risk injection drug use and other risky behaviors in those who test positive or through successful treatment of HCV,^61^ and could identify those who might benefit from hepatitis A or HBV vaccinations, alcohol cessation counseling, identification and management of extrahepatic manifestations, or other interventions. Screening is an important component of the National Academies of Sciences, Engineering, and Medicine report on eliminating HCV as a public health problem by the year 2030.^62^ Shorter-term goals of the National Viral Hepatitis Action Plan are to increase the proportion of persons aware of their positive HCV infection status to 66 percent and to decrease the number of HCV-related deaths by 25 percent by the year 2020.^63^

Although prenatal HCV infection could identify infected females, a challenge is the lack of antiviral therapies proven to be effective for reducing risk of perinatal transmission and approved for use in pregnancy.^1^ Older antiviral therapies were contraindicated in pregnancy due to teratogenic risks. Due to the lack of data on safety of newer DAA regimens during pregnancy and breastfeeding, clinical practice guidelines do not recommend antiviral therapy during pregnancy.^64,65^ However, even in the absence of antiviral therapy proven to be safe and effective during pregnancy, identification of HCV infection during pregnancy could facilitate decision making around the management and use of interventions during labor and delivery or in the perinatal period that might reduce risk of perinatal transmission, and identify females who could benefit from antiviral treatment later and infants who should be tested for HCV infection. A potential alternative strategy for preventing mother-to-child transmission is identification and treatment of HCV infection prior to pregnancy.^24^

### Interventions/Treatment

The goal of antiviral treatment for chronic HCV infection is to prevent the long-term health complications associated with HCV infection, such as cirrhosis, hepatic decompensation, and liver cancer. However, it is extremely difficult to design and carry out clinical trials long and large enough to provide direct evidence related to these outcomes. The SVR rate, typically defined as the proportion of patients who experience a decline in HCV RNA to undetectable levels 12 or 24 weeks following completion of antiviral treatment, is the standard marker of successful treatment in clinical trials. Most studies now focus on SVR at 12 weeks. Long-term recurrence of hepatitis C viremia occurs in less than one percent of patients with an SVR at 12 or 24 weeks of therapy; therefore, an SVR is considered equivalent to a cured infection.^66–68^ Studies have consistently found an association between achieving an SVR after antiviral therapy and reductions in mortality, liver failure, and cancer, though such analyses are susceptible to residual confounding.^69–72^

A major advance in antiviral treatment for HCV infection has been the development and adoption of all-oral DAA regimens without interferon. Such regimens are associated with substantially higher SVR rates than previous antiviral regimens, shorter duration of treatment (8 to 12 weeks instead of 24 to 48 weeks), and improved tolerability.^73^ SVR rates with older antiviral regimens are shown in Table 1. DAA regimens are highly effective for HCV genotype 1 infection, the most common genotype in the United States and historically associated with lower SVR rates when treated with interferon-only regimens.

Table 1 Sustained Virologic Response Rates in Older Antiviral Regimens

Treatment | Sustained virologic response rate
Placebo | <2
Interferon monotherapy | 6 to 16
Interferon plus ribavirin | 33 to 41
Pegylated interferon alone | 25 to 39
Pegylated interferon plus ribavirin | 39 to 43 (genotypes 1 and 4); 76 to 83 (genotypes 2 and 3)
Boceprevir or telaprevir plus pegylated interferon and ribavirin | 68 to 72 (genotype 1)

Source: ^91^ ^,^ ^277^

Given the rapid pace of development for HCV antiviral therapies, guidance for antiviral therapy for HCV is rapidly evolving (Tables 2 and 3).^74^ Several newer DAA regimens are pangenotypic,^75^ meaning that they are effective across all common genotypes, and most currently recommended regimens do not require use of ribavirin. Whereas antiviral therapy was previously reserved for patients with more advanced fibrosis, the American Association for the Study of Liver Disease (AASLD) and the Infectious Diseases Society of America (IDSA) now recommend treatment for all patients with chronic HCV, except those with short life expectancies that cannot be remediated by treating HCV, by transplantation, or by other directed therapy.^65^ The U.S. Food and Drug Administration (FDA) recently approved three HCV regimens for children 12 to 17 years of age (Table 4).^76,77^ Although HCV antiviral therapy has traditionally most frequently been administered in specialty settings, studies have demonstrated similar SVR rates without any negative impacts on safety in community-based and primary care settings.^78,79^

Table 2 Currently Recommended Direct Acting Antivirals and Alternative Regimens for Treatment Naïve Adults With HCV Infection Without Cirrhosis

Recommended or Alternative | Regimen | Duration of Treatment (weeks) | Genotype
Recommended Regimens | Glecaprevir 300 mg + pibrentasvir 120 mg | 8 | 1a, 1b, 2, 3, 4, 5, 6
Recommended Regimens | Ledipasvir 90 mg + sofosbuvir 400 mg | 8 | 1a, 1b
Recommended Regimens | Ledipasvir 90 mg + sofosbuvir 400 mg | 12 | 1a, 1b, 4, 5, 6
Recommended Regimens | Elbasvir 50 mg + grazoprevir 100 mg | 12 | 1a, 1b, 4
Recommended Regimens | Sofosbuvir 400 mg + velpatasvir 100 mg | 12 | 1a, 1b, 2, 3, 4, 5, 6
Alternative Regimens | Daclatasvir 60 mg + sofosbuvir 400 mg | 12 | 1a, 1b, 2, 3
Alternative Regimens | Paritaprevir 150 mg + ritonavir 100 mg + ombitasvir 25 mg + weight-based ribavirin | 12 | 4
Alternative Regimens | Simeprevir 150 mg + sofosbuvir 400 mg | 12 | 1a, 1b
Alternative Regimens | Elbasvir 50 mg + grazoprevir 100 mg + weight-based ribavirin | 16 | 1a
Alternative Regimens | Paritaprevir 150 mg + ritonavir 100 mg + ombitasvir 25 mg + dasabuvir ER 600 mg or dasabuvir 250 mg 2x/day + weight-based ribavirin | 12 | 1a
Alternative Regimens | Paritaprevir 150 mg + ritonavir 100 mg + ombitasvir 25 mg + dasabuvir ER 600 mg or dasabuvir 250 mg 2x/day | 12 | 1b

Source: AASLD/IDSA, available at: https://www.hcvguidelines.org/treatment-naive

Note: Recommended regimens are those that are favored for most patients in a given group, based on optimal efficacy, favorable tolerability and toxicity profiles, and treatment duration. Alternative regimens are those that are effective but, relative to recommended regimens, have potential disadvantages, limitations for use in certain patient populations, or less supporting data than recommended regimens. In certain situations, an alternative regimen may be an optimal regimen for an individual patient.

Abbreviations: AASLD = American Association for the Study of Liver Diseases; ER = extended release; IDSA = Infectious Disease Society of America.

Table 3 Currently Recommended Antiviral Regimens for Treatment-Experienced Adults With HCV Infection Without Cirrhosis

Recommended or Alternative | Regimen | Duration of treatment (weeks) | Genotype
Recommended Regimens | Glecaprevir 300 mg + pibrentasvir 120 mg | 8 | 1a, 1b, 2, 4, 5, 6
Recommended Regimens | Same as above | 12 | 1
Recommended Regimens | Elbasvir 50 mg + grazoprevir 100 mg | 12 | 1a, 1b, 4
Recommended Regimens | Ledipasvir 90 mg + sofosbuvir 400 mg | 12 | 1a, 1b, 4, 5, 6
Recommended Regimens | Sofosbuvir 400 mg + velpatasvir 100 mg | 12 | 1a, 1b, 2, 3, 4, 5, 6
Recommended Regimens | Sofosbuvir 400 mg + velpatasvir 100mg + voxilaprevir 100mg | 12 | 1a
Alternative Regimens | Daclatasvir 60 mg + sofosbuvir 400 mg | 12 | 1a, 1b, 2, 3
Alternative Regimens | Elbasvir 50 mg + grazoprevir 100 mg + ribavirin | 12 | 1b
Alternative Regimens | Same as above | 12 to 16 | 1a
Alternative Regimens | Same as above | 16 | 1a, 4
Alternative Regimens | Ledipasvir 90 mg + sofosbuvir 400 mg + ribavirin | 12 | 1a, 1b
Alternative Regimens | Simeprevir 150 mg + sofosbuvir 400 mg | 12 | 1a, 1b
Alternative Regimens | Ombitasvir 25 mg + paritaprevir 150 mg + ritonavir 100 mg + dasabuvir ER 600 mg or dasabuvir 250 mg 2x/day | 12 | 1b
Alternative Regimens | Ombitasvir 25 mg + paritaprevir 150 mg + ritonavir 100 mg + dasabuvir ER 600 mg or dasabuvir 250 mg 2x/day + weight-based ribavirin | 12 | 1a
Alternative Regimens | Ombitasvir 25 mg + paritaprevir 150 mg + ritonavir 100 mg + weight-based ribavirin | 12 | 4
Alternative Regimens | Sofosbuvir 400 mg + velpatasvir 100mg + voxilaprevir 100mg | 12 | 3
Alternative Regimens | Glecaprevir 300 mg + pibrentasvir 120 mg | 16 | 3

Source: AASLD/IDSA, available at: https://www.hcvguidelines.org/treatment-experienced, up to date as of June 1, 2019.

Note 1: Recommended regimens are those that are favored for most patients in a given group, based on optimal efficacy, favorable tolerability and toxicity profiles, and treatment duration. Alternative regimens are those that are effective but, relative to recommended regimens, have potential disadvantages, limitations for use in certain patient populations, or less supporting data than recommended regimens. In certain situations, an alternative regimen may be an optimal regimen for an individual patient.

Note 2: Table does not list regimens for those with prior DAA treatment experience.

Abbreviations: AASLD = American Association for the Study of Liver Diseases; ER = extended release; IDSA = Infectious Disease Society of America.

Table 4 Currently Recommended Antiviral Regimens for Adolescents Age .12 Years or Weighing at Least 35 kg, Without Cirrhosis or With Compensated Cirrhosis

Regimen^*^ | Duration of treatment (weeks) | Genotype
Ledipasvir 90 mg + sofosbuvir 400 mg for patients who are treatment-naive without cirrhosis or with compensated cirrhosis, or treatment-experienced without cirrhosis | 12 | 1
Sofosbuvir 400 mg + weight-based ribavirin for patients who are treatment-naive or treatment-experienced without cirrhosis or with compensated cirrhosis | 12 | 2
Sofosbuvir 400 mg + weight-based ribavirin for patients who are treatment-naive or treatment-experienced^†^ without cirrhosis or with compensated cirrhosis | 24 | 3
Ledipasvir 90 mg + sofosbuvir 400 mg for patients who are treatment-naive or treatment-experienced without cirrhosis or with compensated cirrhosis | 12 | 4, 5, 6

Source: AASLD/IDSA https://www.hcvguidelines.org/unique-populations/children

Note: Recommended regimens are those that are favored for most patients in a given group, based on optimal efficacy, favorable tolerability and toxicity profiles, and treatment duration.

* Glecaprevir + pibrentasvir approved by the U.S. Food and Drug Administration in April 2019 for children 12 to 17 years of age for genotypes 1 through 6, but has not been incorporated in the AASLD recommendations as of June 1, 2019.

Abbreviations: AASLD = American Association for the Study of Liver Diseases; IDSA = Infectious Disease Society of America.

Recommendations regarding the diagnostic workup and pretreatment assessment for HCV are also evolving. Whereas liver biopsy was previously recommended in all patients with HCV infection in order to determine the severity of fibrosis, the AASLD-IDSA guideline currently also recommends blood tests or transient elastography as noninvasive options for fibrosis assessment.^65,74,80,81^ Given the availability of noninvasive tests to stage HCV infection, rates of biopsy have declined substantially, though precise data on current biopsy rates are lacking.

### Current Clinical Practice/Recommendations of Other Groups

U.S.-based screening guidelines are summarized in Table 5. All are consistent in recommending HCV screening in persons born between 1945 and 1965 and in persons with risk factors for HCV infection. Data on rates of birth cohort screening are limited, though a study of U.S. veterans found an increased rate of testing in this age group compared with other age groups.^82^

Table 5 United States Screening Guidelines

Group | Recommendation
AASLD-IDSA^65^ | One-time HCV testing is recommended for persons born between 1945 and 1965 (regardless of country of birth) without prior ascertainment of risk.; Other persons should be screened for risk factors for HCV infection, and one-time testing should be performed for all persons with behaviors, exposures, and conditions associated with an increased risk of HCV infection; All persons with active HCV infection should be linked to a clinician who is prepared to provide comprehensive management
CDC^87^ | Persons for whom HCV testing Is recommended:; Adults born from 1945 through 1965 should be tested once (without prior ascertainment of HCV risk factors); HCV testing is recommended for those who:; - Currently inject drugs; - Ever injected drugs, including those who injected once or a few times many years ago; - Have certain medical conditions, including persons:; ○ who received clotting factor concentrates produced before 1987; ○ who were ever on long-term hemodialysis; ○ with persistently abnormal ALT levels; ○ who have HIV infection; - Were prior recipients of transfusions or organ transplants, including persons who:; ○ were notified that they received blood from a donor who later tested positive for HCV infection; ○ received a transfusion of blood, blood components, or an organ transplant before July 1992; - HCV- testing based on a recognized exposure is recommended for:; ○ Healthcare, emergency medical, and public safety workers after needle sticks, sharps, or mucosal exposures to HCV-positive blood; ○ Children born to HCV-positive women; Note: For persons who might have been exposed to HCV within the past 6 months, testing for HCV RNA or follow-up testing for HCV antibody is recommended.

Abbreviations: AASLD-IDSA = American Association for the Study of Liver Diseases-Infectious Diseases Society of America; ALT = alanine aminotransferase; CDC = Centers for Disease Control and Prevention; HCV = hepatitis C virus; RNA = ribonucleic acid.

Guidelines from the European Association for the Study of the Liver (EASL)^83^ and the World Health Organization (WHO)^84^ are generally consistent with the above screening guidance. In 2017, the Canadian Task Force on Preventive Health Care recommended against screening for HCV in adults not at elevated risk (including persons born between 1945 and 1965 or other birth cohorts).^85^ The Canadian recommendation was based on the reasoning that most persons with HCV infection have risk factors that can be identified using risk-based guidelines. However, the Canadian Association for the Study of the Liver recommends screening of high-risk persons and persons born between 1945 and 1975.^86^

The CDC^87^ and the American College of Obstetricians and Gynecologists^88^ recommend offering HCV screening to pregnant people with risk factors.