# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 Key Question 5: Evidence Table of Interventions to Prevent Mother-to-Infant Transmission of HCV Infection - Study Characteristics

Appendix B Table 2 Key Question 5: Evidence Table of Interventions to Prevent Mother-to-Infant Transmission of HCV Infection - Study Outcomes

Appendix B Table 3 Key Question 5: Evidence Table of Interventions to Prevent Mother-to-Infant Transmission of HCV Infection - Additional Study Outcomes

Appendix B Table 4 Key Question 5: Quality Assessment of Studies of Interventions to Prevent Mother-to-Infant Transmission of HCV Infection

Appendix B Table 5 Key Question 6: Evidence Table of Observational Studies of Direct Acting Antiviral Therapy on Health Outcomes in Adults

Appendix B Table 6 Key Question 6: Quality Assessment of Observational Studies of Direct Acting Antiviral Therapy on Health Outcomes in Adults

Appendix B Table 7 Key Questions 6-8: Direct Acting Antiviral Therapy in Adolescents - Study Characteristics

Appendix B Table 8 Key Questions 6-8: Direct Acting Antiviral Therapy in Adolescents - Effectiveness and Harms

Appendix B Table 9 Key Questions 6-8: Quality Assessment of Studies of Direct Acting Antiviral Therapy in Adolescents

Appendix B Table 10 Key Questions 6-8: Direct Acting Antiviral Therapy in Adults - Study Characteristics

Appendix B Table 11 Key Questions 6-8: Direct Acting Antiviral Therapy in Adults - Sustained Virologic Response Outcomes

Appendix B Table 12 Key Questions 6-8: Direct Acting Antiviral Therapy in Adults - Clinical Outcomes and Adverse Events

Appendix B Table 13 Key Questions 6-8: Quality Assessment of Studies of Direct Acting Antiviral Therapy in Adults

Appendix B Table 14 Key Question 9: Association of Sustained Virologic Response and Clinical Outcomes - Study Characteristics

Appendix B Table 15 Key Question 9: Association of Sustained Virologic Response and Clinical Outcomes - Intervention Characteristics and Results

Appendix B Table 16 Key Question 9: Quality Assessment of Studies of the Association Between Sustained Virologic Response After Antiviral Therapy and Clinical Outcomes