# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Key Questions 1-4

#### Database: Ovid MEDLINE(R) 1996 to February Week 1 2019

1. Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/
2. (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3. 1 or 2
4. Mass Screening/ or Population Surveillance/ or Sentinel Surveillance/ or Seroepidemiologic Studies/ or Prenatal Diagnosis/ or Neonatal Screening/ or Infectious Disease Transmission, Vertical/ or Disease Transmission, Infectious/ or tm.fs. or transmi*.ti,ab. or ((public* or communit* or universal* or widespread or open* or unrestricted or group* or adult* or adolescen* or pregnan* or antibod*) adj3 (screen* or test* or surveillance)).ti,ab.
5. 3 and 4
6. limit 5 to yr="2012 -Current"
7. 6 and (random* or control* or trial or cohort or group*).ti,ab.
8. limit 6 to (clinical trial, all or comparative study or randomized controlled trial)
9. 7 or 8
10. limit 9 to (english language and humans)

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials February 2019

1. Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/
2. (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3. 1 or 2
4. Mass Screening/ or Population Surveillance/ or Sentinel Surveillance/ or Seroepidemiologic Studies/ or Prenatal Diagnosis/ or Neonatal Screening/ or Infectious Disease Transmission, Vertical/ or Disease Transmission, Infectious/ or tm.fs. or transmi*.ti,ab. or ((public* or communit* or universal* or widespread or open* or unrestricted or group* or adult* or adolescen* or pregnan* or antibod*) adj3 (screen* or test* or surveillance)).ti,ab.
5. 3 and 4
6. limit 5 to yr="2012 -Current"

### Key Question 5

#### Database: Ovid MEDLINE(R) 1996 to February Week 1 2019

1. Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/
2. (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3. 1 or 2
4. Infectious Disease Transmission, Vertical/ or Pregnancy Complications, Infectious/
5. Maternal-Fetal Exchange/
6. exp Breast Feeding/ or (breastfeed or breast feed* or breastfed or breast fed or breast milk).ti,ab.
7. (pregnan* or mother or maternal or child* or infan* or neonat* or prenatal or perinatal).ti,ab.
8. and tm.fs.
9. 3 and (4 or 5 or 6 or 8)
10. (random$ or control$ or trial or cohort or group* or compar*).ti,ab.
11. limit 9 to (clinical trial, all or comparative study or randomized controlled trial)
12. 9 and 10
13. 11 or 12
14. limit 13 to yr="2012 -Current"
15. limit 14 to (english language and humans)

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials Feburary 2019

1. Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/
2. (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3. 1 or 2
4. Infectious Disease Transmission, Vertical/ or Pregnancy Complications, Infectious/
5. Maternal-Fetal Exchange/
6. exp Breast Feeding/ or (breastfeed or breast feed* or breastfed or breast fed or breast milk).ti,ab.
7. (pregnan* or mother or maternal or child* or infan* or neonat* or prenatal or perinatal).ti,ab.
8. 7 and tm.fs.
9. 3 and (4 or 5 or 6 or 8)
10. limit 9 to yr="2012 -Current"

### Key Questions 6-7

#### Database: Ovid MEDLINE(R) 1946 to February Week 1 2019

1. (Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/) and dt.fs.
2. (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3. 1 or 2
4. Antiviral Agents/ad, tu
5. (daclatasvir or dasabuvir or elbasvir or glecaprevir or grazoprevir or ledipasvir or ombitasvir or paritaprevir or pibrentasvir or ribavirin or simeprevir or sofosbuvir or velpatasvir or voxilaprevir).ti,ab,kw
6. 4 or 5
7. 3 and 6
8. 7 not (transplant* or HIV or “hepatitis B”).ti.
9. limit 8 to yr="2012 -Current”
10. 9 and exp Clinical Studies as Topic/
11. limit 9 to (clinical trial, all or meta analysis or randomized controlled trial or systematic reviews)
12. 9 and (random* or control* or trial or “systematic review” or “meta-analysis” or metaanalysis).ti,ab.
13. 10 or 11 or 12
14. limit 13 to (english language and humans)

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials February 2019

1 (Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/) and dt.fs.
2 (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3 1 or 2
4 Antiviral Agents/ad, tu [Administration & Dosage, Therapeutic Use]
5 (daclatasvir or dasabuvir or elbasvir or glecaprevir or grazoprevir or ledipasvir or ombitasvir or paritaprevir or pibrentasvir or ribavirin or simeprevir or sofosbuvir or velpatasvir or voxilaprevir).mp.
6 4 or 5
7 3 and 6
8 7 not (transplant* or HIV or “hepatitis B”).ti.
9 limit 8 to yr=“2012 -Current”

### Key Question 8

#### Database: Ovid MEDLINE(R) 1996 to February Week 1 2019

1. (Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/) and dt.fs.
2. (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3. 1 or 2
4. Antiviral Agents/ad, tu [Administration & Dosage, Therapeutic Use]
5. (daclatasvir or dasabuvir or elbasvir or glecaprevir or grazoprevir or ledipasvir or ombitasvir or paritaprevir or pibrentasvir or ribavirin or simeprevir or sofosbuvir or velpatasvir or voxilaprevir).mp.
6. 4 or 5
7. 3 and 6
8. 7 not (transplant* or HIV or “hepatitis B”).ti.
9. limit 8 to yr="2012 -Current"
10. 9 and exp Clinical Studies as Topic/
11. limit 9 to (clinical trial, all or meta analysis or randomized controlled trial or systematic reviews)
12. 9 and (random* or control* or trial or “systematic review” or “meta-analysis” or metaanalysis).ti,ab.
13. 10 or 11 or 12
14. limit 13 to (english language and humans)
15. 9 not 14
16. 15 and (ae or co or mo or po or to or ct).fs.
17. 15 and (adverse or safety or harm* or complication* or “side-effect*” or “treatment emerg*”).ti,ab.
18. 16 or 17
19. limit 18 to (english language and humans)

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials February 2019

10 (Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/) and dt.fs.
11 (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
12 1 or 2
13 Antiviral Agents/ad, tu [Administration & Dosage, Therapeutic Use]
14 (daclatasvir or dasabuvir or elbasvir or glecaprevir or grazoprevir or ledipasvir or ombitasvir or paritaprevir or pibrentasvir or ribavirin or simeprevir or sofosbuvir or velpatasvir or voxilaprevir).mp.
15 4 or 5
16 3 and 6
17 7 not (transplant* or HIV or “hepatitis B”).ti.
18 limit 8 to yr="2012 -Current"

### Key Question 9

#### Database: Ovid MEDLINE(R) 1996 to February Week 1 2019

1. (Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/) and dt.fs.
2. (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3. 1 or 2
4. Antiviral Agents/ad, tu [Administration & Dosage, Therapeutic Use]
5. (daclatasvir or dasabuvir or elbasvir or glecaprevir or grazoprevir or ledipasvir or ombitasvir or paritaprevir or pibrentasvir or ribavirin or simeprevir or sofosbuvir or velpatasvir or voxilaprevir).mp.
6. 4 or 5
7. 3 and 6
8. sustained virologic response/
9. (“sustained virologic response” or svr).ti,ab.
10. 8 or 9
11. 7 and 10
12. Liver Cirrhosis/
13. Liver Transplantation/
14. (cirrho* or transplant* or decompensat* or morbidity or mortality or death*).ti,ab.
15. 11 and (12 or 13 or 14)
16. limit 15 to yr="2012 -Current"
17. limit 16 to (english language and humans)

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials February 2019

1. (Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/) and dt.fs.
2. (“Hepatitis C” or hepacivirus* or HCV).ti,ab.
3. 1 or 2
4. Antiviral Agents/ad, tu [Administration & Dosage, Therapeutic Use]
5. (daclatasvir or dasabuvir or elbasvir or glecaprevir or grazoprevir or ledipasvir or ombitasvir or paritaprevir or pibrentasvir or ribavirin or simeprevir or sofosbuvir or velpatasvir or voxilaprevir).mp.
6. 4 or 5
7. 3 and 6
8. sustained virologic response/
9. (“sustained virologic response” or svr).ti,ab.
10. 8 or 9
11. 7 and 10
12. Liver Cirrhosis/
13. Liver Transplantation/
14. (cirrho* or transplant* or decompensat* or morbidity or mortality or death*).ti,ab.
15. 11 and (12 or 13 or 14)
16. limit 15 to yr="2012 -Current"

### All Key Questions

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews 2005 to February 6, 2019

1. (“Hepatitis C” or hepacivirus* or HCV).ti.
2. (daclatasvir or dasabuvir or elbasvir or glecaprevir or grazoprevir or ledipasvir or ombitasvir or paritaprevir or pibrentasvir or ribavirin or simeprevir or sofosbuvir or velpatasvir or voxilaprevir).ti,ab.
3. 1 and 2
4. screen*.mp. [mp=title, short title, abstract, full text, keywords, caption text]
5. 1 and 4
6. 3 or 5
7. limit 6 to full systematic reviews

## Appendix A2 Inclusion and Exclusion Criteria

PICOTS | Inclusion Criteria | Exclusion Criteria
Populations | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Screening in pregnant adolescents and adults (KQs 1–4) Asymptomatic, pregnant and nonpregnant adolescents (ages 12 to 17 years) and adults without prior HCV infection; Labor and delivery and perinatal interventions (KQ 5) Pregnant adolescents and adults with HCV infection; Antiviral treatment (KQs 6–8) Persons with screen-detected or asymptomatic HCV infection (patients with a METAVIR fibrosis stage of 0–3, if symptom status is NR); persons with no prior antiviral treatment; includes pregnant women; Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Persons with HCV infection being treated with antiviral therapy | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Persons with known abnormal liver function tests, hepatitis B virus infection, or HIV infection; children age <12 years; Screening in pregnant adolescents and adults (KQs 1–4) Persons with known abnormal liver function tests, hepatitis B virus infection, or HIV infection; Labor and delivery and perinatal interventions (KQ 5); Other populations; Antiviral treatment (KQs 6–8) Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Persons who are coinfected with the hepatitis B virus or HIV, transplant patients, persons with renal failure
Interventions | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Screening in pregnant adolescents and adults (KQs 1–4) Screening; Labor and delivery and perinatal interventions (KQ 5) Mode of delivery, labor management strategies, breastfeeding practices; Antiviral treatment (KQs 6–8) Currently recommended direct acting antiviral regimens^*^; Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Direct acting antiviral regimens or other antiviral treatment | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Screening in pregnant adolescents and adults (KQs 1–4) Labor and delivery and perinatal interventions (KQ 5) Other interventions; Antiviral treatment (KQs 6–8) Interferon-based treatment and other nonrecommended regimens^*^
Comparisons | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Screening in pregnant adolescents and adults (KQs 1–4) Screening vs. no screening, one screening method vs. another, screening interval comparisons; Labor and delivery and perinatal interventions (KQ 5) Elective cesarean delivery vs. vaginal or emergency cesarean delivery, internal fetal monitoring vs. no monitoring, longer vs. shorter duration of rupture of membranes, breastfeeding vs. no breastfeeding; Antiviral treatment (KQs 6–8) Another direct acting antiviral regimen or older antiviral regimen; includes clinical trials without a comparison group; Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Persons who experience a sustained virologic response vs. those who do not | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Screening in pregnant adolescents and adults (KQs 1–4) Labor and delivery and perinatal interventions (KQ 5) Other comparisons
Outcomes | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Mortality, morbidity (e.g., cirrhosis, hepatic decompensation, liver transplant, extrahepatic manifestations of HCV infection), quality of life, HCV transmission, harms (e.g., labeling, anxiety, drug-related harms), screening yield (number of new diagnoses per tests performed) (KQ 3); Screening in pregnant adolescents and adults (KQs 1–4) Perinatal transmission, mortality, morbidity, quality of life, harms (e.g., labeling, anxiety, drug-related harms), screening yield (number of new diagnoses per tests performed) (KQ 3); Labor and delivery and perinatal interventions (KQ 5) Perinatal transmission of HCV infection; Antiviral treatment (KQs 6–8) Sustained virologic response (KQ 7); morbidity (e.g., cirrhosis, hepatic decompensation, liver transplant, extrahepatic manifestations of HCV infection), mortality, quality of life, HCV transmission (KQ 6), harms of treatment (KQ 8); behavioral outcomes will be included for Contextual Question 3; Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Morbidity (e.g., cirrhosis, hepatic decompensation, liver transplant), mortality | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Other outcomes, including intermediate outcomes; Screening in pregnant adolescents and adults (KQs 1–4) Labor and delivery and perinatal interventions (KQ 5) Other outcomes; Antiviral treatment (KQs 6–8) Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Histologic outcomes, liver function tests
Setting | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Screening in pregnant adolescents and adults (KQs 1–4) U.S. primary care, obstetrics/gynecology, emergency department, and primary care–applicable settings, including settings that offer integrated services for primary care and behavioral health care (e.g., substance use treatment clinics); Labor and delivery and perinatal interventions (KQ 5) U.S. labor and delivery settings; Antiviral treatment (KQs 6–8) Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Clinical settings in which HCV antiviral treatments are prescribed
Study design | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Screening in pregnant adolescents and adults (KQs 1–4) Labor and delivery and perinatal interventions (KQ 5) RCTs, controlled observational studies; Antiviral treatment (KQs 6–8) RCTs and uncontrolled clinical trials; for harms and clinical outcomes (KQ 6), will also include large cohort and case-control studies; will consider good-quality systematic reviews of clinical trials; Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Cohort studies | Screening in nonpregnant adolescents and adults (KQs 1a, 2–4) Screening in pregnant adolescents and adults (KQs 1–4) Uncontrolled studies; Labor and delivery and perinatal interventions (KQ 5) Antiviral treatment (KQs 6–8) Case reports, studies not reporting original data; Association between improvements in sustained virologic response and clinical outcomes (KQ 9) Case-control studies, case reports, studies not reporting original data

* For clinical outcomes (KQs 6 and 9), previously recommended regimens will be used.

Abbreviations: HCV = hepatitis C virus; KQ = Key Question; NR = not reported; PICOTS = population, interventions, comparisons, outcomes, setting, study design; RCTs = randomized controlled trials; U.S. = United States.

## Appendix A3 Literature Flow Diagram

*Other sources include prior reports, reference lists of relevant articles, systematic reviews, etc.

^†^ Some studies were included for multiple KQs.

Abbreviation: KQ = Key Question.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 7,170 citations were identified through literature database searches, prior reports, reference lists of relevant articles, systematic reviews, and other sources. Seven hundred articles were reviewed at the full-text level after excluding 6,470 abstracts and background articles. From the 700 full-text articles reviewed, 123 were prior report includes excluded for this review for the following reasons: excluded population (10), excluded intervention (43), excluded outcome (4), inadequate duration (3), poor quality (24), insufficient statistical analyses (1), outdated medication (37) and 483 were new records excluded for the following reasons: excluded population (110), excluded intervention (91), excluded outcome (49), excluded comparator (12), excluded study design for Key Question (85), not a study (63), systematic review or meta-analysis used as a source document to identify individual studies (53), excluded country (4), poor quality (7), or insufficient statistical analyses (9). After excluding these studies, 97 studies in 94 publications were included that provide evidence for the Key Questions as follows: 1 new study for Key Question 3, 1 new study and 4 previously included studies for Key Question 5, 40 new studies (in 36 publications) or Key Question 6, 56 new studies (in 53 publications) for Key Question 7, 56 new studies (in 53 publications) for Key Question 8, 21 new studies and 9 previously included studies for Key Question 9. No evidence met inclusion criteria for Key Questions 1, 2 or 4.

## Appendix A4 List of Included Studies

Abdel Ghaffar TY, Naghi SE, Gawad MA, . Safety and efficacy of combined sofosbuvir/daclatasvir treatment of children and adolescents with chronic hepatitis C genotype 4. J Viral Hepat. 2019;26(2):263–70. doi: 10.1111/jvh.13032. PMID: 30380158.30380158
Abergel A, Asselah T, Metivier S, . Ledipasvir-sofosbuvir in patients with hepatitis C virus genotype 5 infection: an open-label, multicentre, single-arm, phase 2 study. Lancet Infect Dis. 2016b;16(4):459–64. doi: 10.1016/S1473-3099(15)00529-0. PMID: 26803446.26803446
Abergel A, Metivier S, Samuel D, . Ledipasvir plus sofosbuvir for 12 weeks in patients with hepatitis C genotype 4 infection. Hepatology. 2016a;64(4):1049–56. doi: 10.1002/hep.28706. PMID: 27351341.27351341
Afdhal N, Zeuzem S, Kwo P, . Ledipasvir and sofosbuvir for untreated HCV genotype 1 infection. N Engl J Med. 2014;370(20):1889–98. doi: 10.1056/NEJMoa1402454. PMID: 24725239.24725239
Ahmed OA, Kaisar HH, Badawi R, . Efficacy and safety of sofosbuvir-ledipasvir for treatment of a cohort of Egyptian patients with chronic hepatitis C genotype 4 infection. Infect Drug Resist. 2018;11:295–8. doi: 10.2147/IDR.S153060. PMID: 29535545.29535545
Andreone P, Colombo MG, Enejosa JV, . ABT-450, ritonavir, ombitasvir, and dasabuvir achieves 97% and 100% sustained virologic response with or without ribavirin in treatment-experienced patients with HCV genotype 1b infection. Gastroenterology. 2014;147(2):359–65.e1. doi: 10.1053/j.gastro.2014.04.045. PMID: 24818763.24818763
Arase Y, Ikeda K, Suzuki F, . Long-term outcome after interferon therapy in elderly patients with chronic hepatitis C. Intervirology. 2007;50(1):16–23. doi: 10.1159/000096308. PMID: 17164553.17164553
Asahina Y, Tsuchiya K, Tamaki N, . Effect of aging on risk for hepatocellular carcinoma in chronic hepatitis C virus infection. Hepatology. 2010;52(2):518–27. doi: 10.1002/hep.23691. PMID: 20683951.20683951
Asselah T, Kowdley KV, Zadeikis N, . Efficacy of glecaprevir/pibrentasvir for 8 or 12 weeks in patients with hepatitis C virus genotype 2, 4, 5, or 6 infection without cirrhosis. Clin Gastroenterol Hepatol. 2018;16(3):417–26. doi: 10.1016/j.cgh.2017.09.027. PMID: 28951228.28951228
Asselah T, Lee SS, Yao BB, . Efficacy and safety of glecaprevir/pibrentasvir in patients with chronic hepatitis C virus genotype 5 or 6 infection (ENDURANCE-5,6): an open-label, multicentre, phase 3b trial. Lancet Gastroenterol Hepatol. 2019;4(1):45–51. doi: 10.1016/S2468-1253(18)30341-8. PMID: 30393106.30393106
Backus LI, Boothroyd DB, Phillips BR, . A sustained virologic response reduces risk of all-cause mortality in patients with hepatitis C. Clin Gastroenterol Hepatol. 2011;9:509–16. doi: 10.1016/j.cgh.2011.03.004. PMID: 21397729.21397729
Balistreri WF, Murray KF, Rosenthal P, . The safety and effectiveness of ledipasvir-sofosbuvir in adolescents 12-17 years old with hepatitis C virus genotype 1 infection. Hepatology. 2017;66(2):371–8. doi: 10.1002/hep.28995. PMID: 27997679.27997679
Brown A, Hezode C, Zuckerman E, . Efficacy and safety of 12 weeks of elbasvir +/- grazoprevir +/- ribavirin in participants with hepatitis C virus genotype 2, 4, 5 or 6 infection: the C-SCAPE study. J Viral Hepat. 2018;25(5):457–64. doi: 10.1111/jvh.12801. PMID: 29152828.29152828
Butt AA, Yan P, Shuaib A, . Direct-acting antiviral therapy for HCV Infection is associated with a reduced risk of cardiovascular disease events. Gastroenterology. 2019;156(4):987–96. doi: 10.1053/j.gastro.2018.11.022. PMID: 30445009.30445009
Butt AA, Yan P, Simon TG, . Effect of paritaprevir/ritonavir/ombitasvir/dasabuvir and ledipasvir/sofosbuvir regimens on survival compared with untreated hepatitis C virus-infected persons: results from ERCHIVES. Clin Infect Dis. 2017;65(6):1006–11. doi: 10.1093/cid/cix364. PMID: 28903508.28903508
Carrat F, Fontaine H, Dorival C, . Clinical outcomes in patients with chronic hepatitis C after direct-acting antiviral treatment: a prospective cohort study. Lancet. 2019 doi: 10.1016/s0140-6736(18)32111-1. PMID: 30765123.30765123
Ceci O, Margiotta M, Marello F, . Vertical transmission of hepatitis C virus in a cohort of 2,447 HIV-seronegative pregnant women: a 24-month prospective study. J Pediatr Gastroenterol Nutr. 2001;33(5):570–5. PMID: 11740231.11740231
Chayama K, Suzuki F, Karino Y, . Efficacy and safety of glecaprevir/pibrentasvir in Japanese patients with chronic genotype 1 hepatitis C virus infection with and without cirrhosis. J Gastroenterol. 2018:557–65. PMID: 28948366.28948366
Chuang WL, Chien RN, Peng CY, . Ledipasvir/sofosbuvir fixed-dose combination tablet in Taiwanese patients with chronic genotype 1 hepatitis C virus. J Gastroenterol Hepatol. 2016;31(7):1323–9. PMID: 26841930.26841930
Cozen ML, Ryan JC, Shen H, . Nonresponse to interferon-alpha based treatment for chronic hepatitis C infection is associated with increased hazard of cirrhosis. PLoS One. 2013;8(4):e61568. doi: 10.1371/journal.pone.0061568. PMID: 23637856.23637856
Dieperink E, Pocha C, Thuras P, . All-cause mortality and liver-related outcomes following successful antiviral treatment for chronic hepatitis C. Dig Dis Sci. 2014;59(4):872–80. doi: 10.1007/s10620-014-3050-5. PMID: 24532254.24532254
Dohmen K, Kawano A, Takahashi K, . The incidence and risk factors for the development of hepatocellular carcinoma after peginterferon plus ribavirin therapy for chronic hepatitis C. Hepatogastroenterology. 2013;60(128):2034–8. PMID: 24719946.24719946
Dore GJ, Conway B, Luo Y, . Efficacy and safety of ombitasvir/paritaprevir/r and dasabuvir compared to IFN-containing regimens in genotype 1 HCV patients: the MALACHITE-I/II trials. J Hepatol. 2016;64(1):19–28. doi: 10.1016/j.jhep.2015.08.015. PMID: 26321288.26321288
El-Karaksy H, Mogahed EA, Abdullatif H, . Sustained viral response in genotype 4 chronic hepatitis C virus-infected children and adolescents treated with sofosbuvir/ledipasvir. J Pediatr Gastroenterol Nutr. 2018;67(5):626–30. doi: 10.1097/mpg.0000000000002101. PMID: 30216203.30216203
El-Serag HB, Kramer J, Duan Z, . Racial differences in the progression to cirrhosis and hepatocellular carcinoma in HCV-infected veterans. Am J Gastroenterol. 2014;109(9):1427–35. doi: 10.1038/ajg.2014.214. PMID: 25070058.25070058
Everson GT, Towner WJ, Davis MN, . Sofosbuvir with velpatasvir in treatment-naive noncirrhotic patients with genotype 1 to 6 hepatitis C virus infection: A randomized trial. Ann Intern Med. 2015;163(11):818–26. doi: 10.7326/M15-1000. PMID: 26551051.26551051
Feld JJ, Jacobson IM, Hezode C, . Sofosbuvir and velpatasvir for HCV genotype 1, 2, 4, 5, and 6 infection. N Engl J Med. 2015;373(27):2599–607. doi: 10.1056/NEJMoa1512610. PMID: 26571066.26571066
Feld JJ, Kowdley KV, Coakley E, . Treatment of HCV with ABT-450/r-ombitasvir and dasabuvir with ribavirin. N Engl J Med. 2014;370(17):1594–603. doi: 10.1056/NEJMoa1315722. PMID: 24720703.24720703
Ferenci P, Bernstein D, Lalezari J, . ABT-450/r-ombitasvir and dasabuvir with or without ribavirin for HCV. N Engl J Med. 2014;370(21):1983–92. doi: 10.1056/NEJMoa1402338. PMID: 24795200.24795200
Foster GR, Afdhal N, Roberts SK, . Sofosbuvir and velpatasvir for HCV genotype 2 and 3 infection. N Engl J Med. 2015;373(27):2608–17. doi: 10.1056/NEJMoa1512612. PMID: 26575258.26575258
Gane EJ, Hyland RH, An D, . Efficacy of ledipasvir and sofosbuvir, with or without ribavirin, for 12 weeks in patients with HCV genotype 3 or 6 infection. Gastroenterology. 2015;149(6):1454–61.e1. doi: 10.1053/j.gastro.2015.07.063. PMID: 26261007.26261007
Gibb DM, Goodall RL, Dunn DT, . Mother-to-child transmission of hepatitis C virus: evidence for preventable peripartum transmission. Lancet. 2000;356(9233):904–7. PMID: 11036896.11036896
Grebely J, Conway B, Cunningham EB, . Paritaprevir, ritonavir, ombitasvir, and dasabuvir with and without ribavirin in people with HCV genotype 1 and recent injecting drug use or receiving opioid substitution therapy. Int J Drug Policy. 2018b;62:94–103. doi: 10.1016/j.drugpo.2018.10.004. PMID: 30384028.30384028
Grebely J, Dalgard O, Conway B, . Sofosbuvir and velpatasvir for hepatitis C virus infection in people with recent injection drug use (SIMPLIFY): an open-label, single-arm, phase 4, multicentre trial. Lancet Gastroenterol Hepatol. 2018a;3(3):153–61. doi: 10.1016/S2468-1253(17)30404-1. PMID: 29310928.29310928
Hezode C, Asselah T, Reddy KR, . Ombitasvir plus paritaprevir plus ritonavir with or without ribavirin in treatment-naive and treatment-experienced patients with genotype 4 chronic hepatitis C virus infection (PEARL-I): a randomised, open-label trial. Lancet. 2015;385(9986):2502–9. doi: 10.1016/S0140-6736(15)60159-3. PMID: 25837829.25837829
Ikeda K, Saitoh S, Arase Y, . Effect of interferon therapy on hepatocellular carcinogenesis in patients with chronic hepatitis type C: A long-term observation study of 1,643 patients using statistical bias correction with proportional hazard analysis. Hepatology. 1999;29(4):1124–30. doi: 10.1002/hep.510290439. PMID: 10094956.10094956
Imai Y, Kawata S, Tamura S, . Relation of interferon therapy and hepatocellular carcinoma in patients with chronic hepatitis C. Osaka hepatocellular carcinoma prevention study group. Ann Intern Med. 1998;129(2):94–9. PMID: 9669992.9669992
Imazeki F, Yokosuka O, Fukai K, . Favorable prognosis of chronic hepatitis C after interferon therapy by long-term cohort study. Hepatology. 2003;38(2):493–502. doi: 10.1053/jhep.2003.50329. PMID: 12883494.12883494
Innes HA, Hutchinson SJ, Allen S, . Excess liver-related morbidity of chronic hepatitis C patients, who achieve a sustained viral response, and are discharged from care. Hepatology. 2011;54(5):1547–58. doi: 10.1002/hep.24561. PMID: 22045672.22045672
Ioannou GN, Green PK, Berry K. HCV eradication induced by direct-acting antiviral agents reduces the risk of hepatocellular carcinoma. J Hepatol. 2018;68(1):25–32. doi: 10.1016/j.jhep.2017.08.030. PMID: 28887168.28887168
Izumi N, Yasuhiro A, Kurosaki M, . Development of hepatocellular carcinoma after interferon therapy in chronic hepatitis C. Is it possible to reduce the incidence by ribanirin and IFN combination therapy? Intervirology. 2005;48(1):59–63. doi: 10.1159/000082096. PMID: 15785091.15785091
Jonas MM, Squires RH, Rhee SM, . Pharmacokinetics, safety, and efficacy of glecaprevir/pibrentasvir in adolescents with chronic HCV: part 1 of the DORA study. Hepatology. 2019 doi: 10.1002/hep.30840. PMID: 31254392.31254392
Kasahara A, Hayashi N, Mochizuki K, . Risk factors for hepatocellular carcinoma and its incidence after interferon treatment in patients with chronic hepatitis C. Osaka Liver Disease Study Group. Hepatology. 1998;27(5):1394–402. doi: 10.1002/hep.510270529. PMID: 9581697.9581697
Kasahara A, Tanaka H, Okanoue T, . Interferon treatment improves survival in chronic hepatitis C patients showing biochemical as well as virological responses by preventing liver-related death. J Viral Hepat. 2004;11(2):148–56. PMID: 14996350.14996350
Kowdley KV, Gordon SC, Reddy KR, . Ledipasvir and sofosbuvir for 8 or 12 weeks for chronic HCV without cirrhosis. N Engl J Med. 2014a;370(20):1879–88. doi: 10.1056/NEJMoa1402355. PMID: 24720702.24720702
Kowdley KV, Lawitz E, Poordad F, . Phase 2b trial of interferon-free therapy for hepatitis C virus genotype 1. N Engl J Med. 2014b;370(3):222–32. doi: 10.1056/NEJMoa1306227. PMID: 24428468.24428468
Kumada H, Chayama K, Rodrigues L, Jr., . Randomized phase 3 trial of ombitasvir/paritaprevir/ritonavir for hepatitis C virus genotype 1b-infected Japanese patients with or without cirrhosis. Hepatology. 2015;62(4):1037–46. doi: 10.1002/hep.27972. PMID: 26147154.26147154
Kumada H, Suzuki Y, Karino Y, . The combination of elbasvir and grazoprevir for the treatment of chronic HCV infection in Japanese patients: a randomized phase II/III study. J Gastroenterol. 2017;52(4):520–33. doi: 10.1007/s00535-016-1285-y. PMID: 27873094.27873094
Kurokawa M, Hiramatsu N, Oze T, . Effect of interferon alpha-2b plus ribavirin therapy on incidence of hepatocellular carcinoma in patients with chronic hepatitis. Hepatol Res. 2009;39(5):432–8. doi: 10.1111/j.1872-034X.2008.00477.x. PMID: 19207583.19207583
Kwo P, Gitlin N, Nahass R, . Simeprevir plus sofosbuvir (12 and 8 weeks) in hepatitis C virus genotype 1-infected patients without cirrhosis: OPTIMIST-1, a phase 3, randomized study. Hepatology. 2016;64(2):370–80. doi: 10.1002/hep.28467. PMID: 26799692.26799692
Lalezari J, Sullivan JG, Varunok P, . Ombitasvir/paritaprevir/r and dasabuvir plus ribavirin in HCV genotype 1-infected patients on methadone or buprenorphine. J Hepatol. 2015;63(2):364–9. doi: 10.1016/j.jhep.2015.03.029. PMID: 25839406.25839406
Lawitz E, Makara M, Akarca US, . Efficacy and safety of ombitasvir, paritaprevir, and ritonavir in an open-label study of patients with genotype 1b chronic hepatitis C virus infection with and without cirrhosis. Gastroenterology. 2015;149(4):971–80.e1. doi: 10.1053/j.gastro.2015.07.001. PMID: 26170136.26170136
Lawitz E, Poordad FF, Pang PS, . Sofosbuvir and ledipasvir fixed-dose combination with and without ribavirin in treatment-naive and previously treated patients with genotype 1 hepatitis C virus infection (LONESTAR): an open-label, randomised, phase 2 trial. Lancet. 2014b;383(9916):515–23. doi: 10.1016/S0140-6736(13)62121-2. PMID: 24209977.24209977
Lawitz E, Sulkowski MS, Ghalib R, . Simeprevir plus sofosbuvir, with or without ribavirin, to treat chronic infection with hepatitis C virus genotype 1 in non-responders to pegylated interferon and ribavirin and treatment-naive patients: the COSMOS randomised study. Lancet. 2014a;384(9956):1756–65. doi: 10.1016/S0140-6736(14)61036-9. PMID: 25078309.25078309
Lee SH, Jin YJ, Shin JY, . Assessment of hepatocellular carcinoma risk based on peg-interferon plus ribavirin treatment experience in this new era of highly effective oral antiviral drugs. Medicine. 2017;96(1):e5321. doi: 10.1097/MD.0000000000005321. PMID: 28072684.28072684
Leung DH, Wirth S, Yao BB, . Ombitasvir/paritaprevir/ritonavir with or without dasabuvir and with or without ribavirin for adolescents with HCV genotype 1 or 4. Hepatol Commun. 2018;2(11):1311–9. doi: 10.1002/hep4.1250. PMID: 30411078.30411078
Li DK, Ren Y, Fierer DS, . The short-term incidence of hepatocellular carcinoma is not increased after hepatitis C treatment with direct-acting antivirals: an ERCHIVES study. Hepatology. 2018;67(6):2244–53. doi: 10.1002/hep.29707. PMID: 29205416.29205416
Lim YS, Ahn SH, Lee KS, . A phase IIIb study of ledipasvir/sofosbuvir fixed-dose combination tablet in treatment-naive and treatment-experienced Korean patients chronically infected with genotype 1 hepatitis C virus. Hepatol Int. 2016;10(6):947–55. PMID: 27198664.27198664
Maruoka D, Imazeki F, Arai M, . Long-term cohort study of chronic hepatitis C according to interferon efficacy. J Gastroenterol Hepatol. 2012;27(2):291–9. doi: 10.1111/j.1440-1746.2011.06871.x. PMID: 21793911.21793911
Mast EE, Hwang LY, Seto DS, . Risk factors for perinatal transmission of hepatitis C virus (HCV) and the natural history of HCV infection acquired in infancy. J Infect Dis. 2005;192(11):1880–9. doi: 10.1086/497701. PMID: 16267758.16267758
Nelson DR, Cooper JN, Lalezari JP, . All-oral 12-week treatment with daclatasvir plus sofosbuvir in patients with hepatitis C virus genotype 3 infection: ALLY-3 phase III study. Hepatology. 2015;61(4):1127–35. doi: 10.1002/hep.27726. PMID: 25614962.25614962
Ng X, Nwankwo C, Arduino JM, . Patient-reported outcomes in individuals with hepatitis C virus infection treated with elbasvir/grazoprevir. Patient Prefer Adherence. 2018;12:2631–8. doi: 10.2147/PPA.S172732. PMID: 30587935.30587935
Okanoue T, Itoh Y, Kirishima T, . Transient biochemical response in interferon therapy decreases the development of hepatocellular carcinoma for five years and improves the long-term survival of chronic hepatitis C patients. Hepatol Res. 2002;23(1):62–77. PMID: 12084557.12084557
Osaki Y, Ueda Y, Marusawa H, . Decrease in alpha-fetoprotein levels predicts reduced incidence of hepatocellular carcinoma in patients with hepatitis C virus infection receiving interferon therapy: a single center study. J Gastroenterol. 2012;47(4):444–51. doi: 10.1007/s00535-011-0505-8. PMID: 22105231.22105231
Pianko S, Flamm SL, Shiffman ML, . Sofosbuvir plus velpatasvir combination therapy for treatment-experienced patients with genotype 1 or 3 hepatitis C virus infection: a randomized trial. Ann Intern Med. 2015;163(11):809–17. doi: 10.7326/M15-1014. PMID: 26551263.26551263
Poordad F, Felizarta F, Asatryan A, . Glecaprevir and pibrentasvir for 12 weeks for hepatitis C virus genotype 1 infection and prior direct-acting antiviral treatment. Hepatology. 2017;66(2):389–97. doi: 10.1002/hep.29081. PMID: 28128852.28128852
Pott-Junior H, Bricks G, Grandi G, . Sofosbuvir in combination with daclatasvir or simeprevir for 12 weeks in noncirrhotic subjects chronically infected with hepatitis C virus genotype 1: a randomized clinical trial. Clin Microbiol Infect. 2019;25(3):365–71. doi: 10.1016/j.cmi.2018.06.007. PMID: 29906601.29906601
Resti M, Azzari C, Galli L, . Maternal drug use is a preeminent risk factor for mother-to-child hepatitis C virus transmission: results from a multicenter study of 1372 mother-infant pairs. J Infect Dis. 2002;185(5):567–72. doi: 10.1086/339013. PMID: 11865412.11865412
Singal AG, Dharia TD, Malet PF, . Long-term benefit of hepatitis C therapy in a safety net hospital system: a cross-sectional study with median 5-year follow-up. BMJ Open. 2013;3(9):e003231. doi: 10.1136/bmjopen-2013-003231. PMID: 24002983.24002983
Sinn DH, Paik SW, Kang P, . Disease progression and the risk factor analysis for chronic hepatitis C. Liver Int. 2008;28(10):1363–9. doi: 10.1111/j.1478-3231.2008.01860.x. PMID: 18710426.18710426
Sperl J, Horvath G, Halota W, . Efficacy and safety of elbasvir/grazoprevir and sofosbuvir/pegylated interferon/ribavirin: a phase III randomized controlled trial. J Hepatol. 2016;65 PMID: 27542322.27542322
Sulkowski M, Hezode C, Gerstoft J, . Efficacy and safety of 8 weeks versus 12 weeks of treatment with grazoprevir (MK-5172) and elbasvir (MK-8742) with or without ribavirin in patients with hepatitis C virus genotype 1 mono-infection and HIV/hepatitis C virus co-infection (C-WORTHY): a randomised, open-label phase 2 trial. Lancet. 2015;385(9973):1087–97. doi: 10.1016/s0140-6736(14)61793-1. PMID: 25467560.25467560
Sulkowski MS, Gardiner DF, Rodriguez-Torres M, . Daclatasvir plus sofosbuvir for previously treated or untreated chronic HCV infection. N Engl J Med. 2014;370(3):211–21. doi: 10.1056/NEJMoa1306218. PMID: 24428467.24428467
Tanaka H, Tsukuma H, Kasahara A, . Effect of interferon therapy on the incidence of hepatocellular carcinoma and mortality of patients with chronic hepatitis C: a retrospective cohort study of 738 patients. Int J Cancer. 2000;87(5):741–9. PMID: 10925370.10925370
Tateyama M, Yatsuhashi H, Taura N, . Alpha-fetoprotein above normal levels as a risk factor for the development of hepatocellular carcinoma in patients infected with hepatitis C virus. J Gastroenterol. 2011;46(1):92–100. doi: 10.1007/s00535-010-0293-6. PMID: 20711614.20711614
Tomaszewski KJ, Deniz B, Tomanovich P, . Comparison of current US risk strategy to screen for hepatitis C virus with a hypothetical targeted birth cohort strategy. Am J Public Health. 2012;102(11):e101–6. doi: 10.2105/AJPH.2011.300488. PMID: 22813094.22813094
Tovo PA, European Paediatric Hepatitis C Virus Network. A significant sex-but not elective cesarean section-effect on mother-to-child transmission of hepatitis C virus infection. J Infect Dis. 2005;192(11):1872–9. doi: 10.1086/497695. PMID: 16267757.16267757
Toyoda H, Chayama K, Suzuki F, . Efficacy and safety of glecaprevir/pibrentasvir in Japanese patients with chronic genotype 2 hepatitis C virus infection. Hepatology. 2018;67(2):505–13. PMID: 28865152.28865152
Tseng CW, Chang TT, Tzeng SJ, . Association of sustained virologic response with reduced progression to liver cirrhosis in elderly patients with chronic hepatitis C. Clin Interv Aging. 2016;11:327–34. doi: 10.2147/CIA.S97242. PMID: 27051280.27051280
Waked I, Shiha G, Qaqish RB, . Ombitasvir, paritaprevir, and ritonavir plus ribavirin for chronic hepatitis C virus genotype 4 infection in Egyptian patients with or without compensated cirrhosis (AGATE-II): a multicentre, phase 3, partly randomised open-label trial. Lancet Gastroenterol Hepatol. 2016;1(1):36–44. PMID: 28404110.28404110
Wei L, Jia JD, Wang FS, . Efficacy and safety of elbasvir/grazoprevir in participants with hepatitis C virus genotype 1, 4, or 6 infection from the Asia-Pacific region and Russia: final results from the randomized C-CORAL study. J Gastroenterol Hepatol. 2019a;34(1):12–21. doi: 10.1111/jgh.14509. PMID: 30311701.30311701
Wei L, Lim SG, Xie Q, . Sofosbuvir-velpatasvir for treatment of chronic hepatitis C virus infection in Asia: a single-arm, open-label, phase 3 trial. Lancet Gastroenterol Hepatol. 2019b;4(2):127–34. doi: 10.1016/S2468-1253(18)30343-1. PMID: 30555048.30555048
Wei L, Xie Q, Hou JL, . Ledipasvir/sofosbuvir for treatment-naive and treatment-experienced Chinese patients with genotype 1 HCV: an open-label, phase 3b study. Hepatol Int. 2018;12(2):126–32. doi: 10.1007/s12072-018-9856-z. PMID: 29637511.29637511
Wirth S, Rosenthal P, Gonzalez-Peralta RP, . Sofosbuvir and ribavirin in adolescents 12-17 years old with hepatitis C virus genotype 2 or 3 infection. Hepatology. 2017;66(4):1102–10. doi: 10.1002/hep.29278. PMID: 28543053.28543053
Yakoot M, El-Shabrawi MH, AbdElgawad MM, . Dual sofosbuvir/daclatasvir therapy in adolescent patients with chronic hepatitis C infection. J Pediatr Gastroenterol Nutr. 2018;67(1):86–9. doi: 10.1097/mpg.0000000000001968. PMID: 29570560.29570560
Yoshida H, Arakawa Y, Sata M, . Interferon therapy prolonged life expectancy among chronic hepatitis C patients. Gastroenterology. 2002;123(2):483–91. PMID: 12145802.12145802
Yoshida H, Shiratori Y, Moriyama M, . Interferon therapy reduces the risk for hepatocellular carcinoma: national surveillance program of cirrhotic and noncirrhotic patients with chronic hepatitis C in Japan. IHIT Study Group. Inhibition of hepatocarcinogenesis by Interferon Therapy. Ann Intern Med. 1999;131(3):174–81. PMID: 10428733.10428733
Younossi ZM, Stepanova M, Afdhal N, . Improvement of health-related quality of life and work productivity in chronic hepatitis C patients with early and advanced fibrosis treated with ledipasvir and sofosbuvir. J Hepatol. 2015;63(2):337–45. doi: 10.1016/j.jhep.2015.03.014. PMID: 25795586.25795586
Younossi ZM, Stepanova M, Balistreri W, . Health-related quality of life in adolescent patients with hepatitis C genotype 1 treated with sofosbuvir and ledipasvir. J Pediatr Gastroenterol Nutr. 2018;66(1):112–6. doi: 10.1097/MPG.0000000000001754. PMID: 28957984.28957984
Younossi ZM, Stepanova M, Feld J, . Sofosbuvir and velpatasvir combination improves patient-reported outcomes for patients with HCV infection, without or with compensated or decompensated cirrhosis. Clin Gastroenterol Hepatol. 2017;15(3):421–30.e6. doi: 10.1016/j.cgh.2016.10.037. PMID: 27847279.27847279
Younossi ZM, Stepanova M, Schwarz KB, . Quality of life in adolescents with hepatitis C treated with sofosbuvir and ribavirin. J Viral Hepat. 2018;25(4):354–62. doi: 10.1111/jvh.12830. PMID: 29193603.29193603
Yu M, Lin S-M, Chuang W-L, . A sustained virological response to interferon or interferon/ribavirin reduces hepatocellular carcinoma and improves survival in chronic hepatitis C: a nationwide, multicentre study in Taiwan. Antivir Ther. 2006;11(8):985–94. PMID: 17302368.17302368
Zeuzem S, Foster GR, Wang S, . Glecaprevir-pibrentasvir for 8 or 12 weeks in HCV genotype 1 or 3 infection. N Engl J Med. 2018;378(4):354–69. doi: 10.1056/NEJMoa1702417. PMID: 29365309.29365309
Zeuzem S, Ghalib R, Reddy KR, . Grazoprevir-elbasvir combination therapy for treatment-naive cirrhotic and noncirrhotic patients with chronic hepatitis C virus genotype 1, 4, or 6 infection: a randomized trial. Ann Intern Med. 2015;163(1):1–13. doi: 10.7326/M15-0785. PMID: 25909356.25909356

## Appendix A5 List of Excluded Studies With Reasons for Exclusion

Abad S, Vega A, Hernandez E, . Universal sustained viral response to the combination of ombitasvir/paritaprevir/ritonavir and dasabuvir with/without ribavirin in patients on hemodialysis infected with hepatitis C virus genotypes 1 and 4. Am J Nephrol. 2017;45(3):267–72. doi: 10.1159/000454819. PMID: 28166520. Excluded for ineligible study design for Key Question.28166520
Abad S, Vega A, Rincon D, . Effectiveness of direct-acting antivirals in hepatitis C virus infection in haemodialysis patients. Nefrologia. 2017;37(2):158–63. doi: 10.1016/j.nefro.2016.10.003. PMID: 27914803. Excluded for ineligible population.27914803
Abdel-Aziz AM, Ibrahim MA, El-Sheikh AA, . Effect of sofosbuvir plus daclatasvir in hepatitis C virus genotype-4 patients: promising effect on liver fibrosis. J Clin Exp Hepatol. 2018;8(1):15–22. doi: 10.1016/j.jceh.2017.06.006. PMID: 29743792. Excluded for ineligible population.29743792
Abdel-Moneim A, Abood A, Abdel-Gabaar M, . Effectiveness of sofosbuvir/pegylated-interferon plus ribavirin in treatment of hepatitis C virus genotype 4 patients. Clin Exp Hepatol. 2018;4(3):191–6. doi: 10.5114/ceh.2018.78123. PMID: 30324144. Excluded for ineligible intervention.30324144
Abdel-Moneim A, Aboud A, Abdel-Gabaar M, . Efficacy and safety of sofosbuvir plus daclatasvir with or without ribavirin: large real-life results of patients with chronic hepatitis C genotype 4. Hepatol Int. 2018;12(4):348–55. doi: 10.1007/s12072-018-9868-8. PMID: 29754329. Excluded for ineligible population.29754329
Abd-Elsalam S, Badawi R, Elnawasany S, . Sofosbuvir, pegylated interferon and ribavirin in treatment of an Egyptian cohort with hepatitis C virus infection in real life clinical practice. Infect Disord Drug Targets. 2018;12:12. doi: 10.2174/1871526518666180912121835. PMID: 30207250. Excluded for ineligible intervention.30207250
Abergel A, Hezode C, Leroy V, . Peginterferon alpha-2b plus ribavirin for treatment of chronic hepatitis C with severe fibrosis: a multicentre randomized controlled trial comparing two doses of peginterferon alpha-2b. J Viral Hepat. 2006;13(12):811–20. doi: 10.1111/j.1365-2893.2006.00768.x. PMID: 17109680. Excluded for outdated medication.17109680
Abouelkheir Abdalla D, Ali Elhadidy T, Besheer T, . Respiratory adverse effects of sofosbuvir-based regimens for treatment of chronic hepatitis C virus. Egypt J Chest Dis Tuberc. 2016;10. Excluded for ineligible intervention.
Adler H, Lambert JS. Daclatasvir for the treatment of hepatitis C virus infection. Expert Rev Gastroenterol Hepatol. 2014;8(7):725–38. doi: 10.1586/17474124.2014.925798. PMID: 24882552. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.24882552
Afdhal N, Reddy KR, Nelson DR, . Ledipasvir and sofosbuvir for previously treated HCV genotype 1 infection. N Engl J Med. 2014;370(16):1483–93. doi: 10.1056/NEJMoa1316366. PMID: 24725238. Excluded for ineligible population.24725238
Aghemo A, Prati GM, Rumi MG, . Sustained virological response prevents the development of insulin resistance in patients with chronic hepatitis C. Hepatology. 2012;56(5):1681–7. doi: 10.1002/hep.25867. PMID: 22619107. Excluded for ineligible population.22619107
Ahmed OA, Elsebaey MA, Fouad MHA, . Outcomes and predictors of treatment response with sofosbuvir plus daclatasvir with or without ribavirin in Egyptian patients with genotype 4 hepatitis C virus infection. Infect Drug Resist. 2018;11:441–5. doi: 10.2147/IDR.S160593. PMID: 29628768. Excluded for ineligible population.29628768
Ahn SH, Lim YS, Lee KS, . A phase 3b study of sofosbuvir plus ribavirin in treatment-naive and treatment-experienced Korean patients chronically infected with genotype 2 hepatitis C virus. J Viral Hepat. 2016;23(5):358–65. doi: 10.1111/jvh.12499. PMID: 26864153. Excluded for ineligible intervention.26864153
Airoldi J, Berghella V. Hepatitis C and pregnancy. Obstet Gynecol Surv. 2006;61(10):666–72. doi: 10.1097/01.ogx.0000238671.13495.33. PMID: 16978426. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.16978426
Akahane T, Kurosaki M, Itakura J, . Real-world efficacy and safety of sofosbuvir + ribavirin for hepatitis C genotype 2: a nationwide multicenter study by the Japanese Red Cross Liver Study Group. Hepatol Res. 2018;01:01. doi: 10.1111/hepr.13246. PMID: 30171740. Excluded for ineligible intervention.30171740
Akiyama MJ, Kaba F, Rosner Z, . Hepatitis C screening of the “Birth Cohort” (born 1945-1965) and younger inmates of New York City jails. Am J Public Health. 2016;106(7):1276–7. doi: 10.2105/AJPH.2016.303163. PMID: 27196656. Excluded for ineligible study design for Key Question.27196656
Akiyama MJ, Kaba F, Rosner Z, . Correlates of hepatitis C virus infection in the targeted testing program of the New York City jail system. Public Health Rep. 2017;132(1):41–7. doi: 10.1177/0033354916679367. PMID: 28005477. Excluded for ineligible study design for Key Question.28005477
Akuta N, Kobayashi M, Suzuki F, . Liver fibrosis and body mass index predict hepatocarcinogenesis following eradication of hepatitis C virus RNA by direct-acting antivirals. Oncology. 2016;91(6):341–7. doi: 10.1159/000450551. PMID: 27694754. Excluded for ineligible comparator.27694754
Akuta N, Suzuki F, Seko Y, . Efficacy and anticarcinogenic activity of ribavirin combination therapy for hepatitis C virus-related compensated cirrhosis. Intervirology. 2013;56(1):37–45. doi: 10.1159/000342746. PMID: 23037768. Excluded for ineligible population.23037768
Alavi M, Spelman T, Matthews GV, . Injecting risk behaviours following treatment for hepatitis C virus infection among people who inject drugs: the Australian trial in acute hepatitis C. Int J Drug Policy. 2015;26(10):976–83. doi: 10.1016/j.drugpo.2015.05.003. PMID: 26115881. Excluded for ineligible study design for Key Question.26115881
Alfaleh FZ, Alswat K, Helmy A, . The natural history and long-term outcomes in patients with chronic hepatitis C genotype 4 after interferon-based therapy. Liver Int. 2013;33(6):871–83. doi: 10.1111/liv.12127. PMID: 23490034. Excluded for poor quality.23490034
Almario CV, Vega M, Trooskin SB, . Examining hepatitis C virus testing practices in primary care clinics. J Viral Hepat. 2012;19(2):e163–9. doi: 10.1111/j.1365-2893.2011.01539.x. PMID: 22239514. Excluded for ineligible outcome.22239514
Alqahtani SA, Afdhal N, Zeuzem S, . Safety and tolerability of ledipasvir/sofosbuvir with and without ribavirin in patients with chronic hepatitis C virus genotype 1 infection: analysis of phase III ION trials. Hepatology. 2015;62(1):25–30. doi: 10.1002/hep.27890. PMID: 25963890. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.25963890
American College of Obstetricians and Gynecologists’ Committee on Gynecological Practice. Committee opinion no. 655: hepatitis B, hepatitis C, and human immunodeficiency virus infections in obstetrician-gynecologists. Obstet Gynecol. 2016;127(2):e70–4. doi: 10.1097/AOG.0000000000001315. PMID: 26942390. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26942390
Ampuero J, Reddy KR, Romero-Gomez M. Hepatitis C virus genotype 3: meta-analysis on sustained virologic response rates with currently available treatment options. World J Gastroenterol. 2016;22(22):5285–92. doi: 10.3748/wjg.v22.i22.5285. PMID: 27298572. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27298572
Anderson EM, Mandeville RP, Hutchinson SJ, . Evaluation of a general practice based hepatitis C virus screening intervention. Scott Med J. 2009;54(3):3–7. doi: 10.1258/rsmsmj.54.3.3. PMID: 19728405. Excluded for poor quality.19728405
Anderson ES, Galbraith JW, Deering LJ, . Continuum of care for hepatitis C virus among patients diagnosed in the emergency department setting. Clin Infect Dis. 2017;64(11):1540–6. doi: 10.1093/cid/cix163. PMID: 28207069. Excluded for ineligible outcome.28207069
Anderson ES, Pfeil SK, Deering LJ, . High-impact hepatitis C virus testing for injection drug users in an urban ED. Am J Emerg Med. 2016;34(6):1108–11. doi: 10.1016/j.ajem.2016.03.004. PMID: 27037135. Excluded for ineligible study design for Key Question.27037135
Andriulli A, Cursaro C, Cozzolongo R, . Early discontinuation of ribavirin in HCV-2 and HCV-3 patients responding to peg-interferon alpha-2a and ribavirin. J Viral Hepat. 2009;16(1):28–35. doi: 10.1111/j.1365-2893.2008.01044.x. PMID: 18761603. Excluded for outdated medication.18761603
Anonymous. Corrections to: “Ledipasvir-sofosbuvir with or without ribavirin to treat patients with HCV genotype 1 infection and cirrhosis non-responsive to previous protease-inhibitor therapy: a randomised, double-blind, phase 2 trial (SIRIUS)” [Lancet Infect Dis (2015), 15: 397-404]. Lancet Infect Dis. 2015;15(7):761. doi: 10.1016/S1473-3099(15)00111-5. PMID: 26122440. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26122440
Anonymous. Erratum: simeprevir with pegylated interferon alfa 2a plus ribavirin in treatment-naive patients with chronic hepatitis C virus genotype 1 infection (QUEST-1): a phase 3, randomised, double-blind, placebo-controlled trial. Lancet. 2016;387(10030):1816. Excluded for not a study: letter, editorial, non-systematic review article, no original data.
Anonymous. Correction: ombitasvir, paritaprevir, and ritonavir plus ribavirin for chronic hepatitis C virus genotype 4 infection in Egyptian patients with or without compensated cirrhosis (AGATE-II): a multicentre, phase 3, partly randomised open-label trial. Lancet Gastroenterol Hepatol. 2016;1(1):e1. Excluded for not a study: letter, editorial, non-systematic review article, no original data.28404119
Aqel B, Leise M, Vargas HE, . Multicenter experience using ledipasvir/sofosbuvir +/- RBV to treat HCV GT 1 relapsers after simeprevir and sofosbuvir treatment. Ann Hepatol. 2018;17(5):815–21. doi: 10.5604/01.3001.0012.3142. PMID: 30145562. Excluded for ineligible population.30145562
Aqel BA, Pungpapong S, Leise M, . Multicenter experience using simeprevir and sofosbuvir with or without ribavirin to treat hepatitis C genotype 1 in patients with cirrhosis. Hepatology. 2015;62(4):1004–12. doi: 10.1002/hep.27937. PMID: 26096332. Excluded for ineligible population.26096332
Arora S, O’Brien C, Zeuzem S, . Treatment of chronic hepatitis C patients with persistently normal alanine aminotransferase levels with the combination of peginterferon alpha-2a (40 kDa) plus ribavirin: impact on health-related quality of life. J Gastroenterol Hepatol. 2006;21(2):406–12. doi: 10.1111/j.1440-1746.2005.04059.x. PMID: 16509866. Excluded for ineligible outcome.16509866
Asahina Y, Itoh Y, Ueno Y, . Ledipasvir-sofosbuvir for treating Japanese patients with chronic hepatitis C virus genotype 2 infection. Liver Int. 2018;38(9):1552–61. doi: 10.1111/liv.13685. PMID: 29297980. Excluded for ineligible population.29297980
Ascione A, De Luca M, Tartaglione MT, . Peginterferon alfa-2a plus ribavirin is more effective than peginterferon alfa-2b plus ribavirin for treating chronic hepatitis C virus infection. Gastroenterology. 2010;138(1):116–22. doi: 10.1053/j.gastro.2009.10.005. PMID: 19852964. Excluded for outdated medication.19852964
Asselah T. Sofosbuvir-based interferon-free therapy for patients with HCV infection. J Hepatol. 2013;59(6):1342–5. doi: 10.1016/j.jhep.2013.07.023. PMID: 23891655. Excluded for ineligible study design for Key Question.23891655
Asselah T, Hezode C, Qaqish RB, . Ombitasvir, paritaprevir, and ritonavir plus ribavirin in adults with hepatitis C virus genotype 4 infection and cirrhosis (AGATE-I): a multicentre, phase 3, randomised open-label trial. Lancet Gastroenterol Hepatol. 2016;1(1):25–35. doi: 10.1016/S2468-1253(16)30001-2. PMID: 28404108. Excluded for ineligible population.28404108
Asselah T, Tran T, Alves K, . Efficacy and safety of glecaprevir/pibrentasvir in patients with HCV genotype 5 or 6 infection: The ENDURANCE-5,6 study. J Hepatol. 2018;68:S39. doi: 10.1016/s0168-8278(18)30294-0. Excluded for not a study: letter, editorial, non-systematic review article, no original data.
Atsukawa M, Tsubota A, Toyoda H, . Efficacy and safety of ombitasvir/paritaprevir/ritonavir and ribavirin for chronic hepatitis patients infected with genotype 2a in Japan. Hepatol Res. 2018;28:28. doi: 10.1111/hepr.13292. PMID: 30485638. Excluded for ineligible population.30485638
Attia D, El Saeed K, Elakel W, . The adverse effects of interferon-free regimens in 149 816 chronic hepatitis C treated Egyptian patients. Aliment Pharmacol Ther. 2018;47(9):1296–305. doi: 10.1111/apt.14538. PMID: 29504152. Excluded for ineligible population.29504152
Aziz H, Aziz M, Gill ML. Analysis of host and viral-related factors associated to direct acting antiviral response in hepatitis C virus patients. Viral Immunol. 2018;31(3):256–63. doi: 10.1089/vim.2017.0124. PMID: 29664710. Excluded for ineligible intervention.29664710
Azzaroli F, Accogli E, Nigro G, . Interferon plus ribavirin and interferon alone in preventing hepatocellular carcinoma: a prospective study on patients with HCV related cirrhosis. World J Gastroenterol. 2004;10(21):3099–102. PMID: 15457551. Excluded for ineligible population.15457551
Babatin MA, AlGhamdi AS, Assiri AM, . Treatment efficacy of ledipasvir/sofosbuvir for 8 weeks in non-cirrhotic chronic hepatitis C genotype 4 patients. Saudi J Gastroentero. 2019;25(1):55–60. doi: 10.4103/sjg.SJG_189_18. PMID: 30117490. Excluded for ineligible intervention.30117490
Backus LI, Belperio PS, Shahoumian TA, . Comparative effectiveness of ledipasvir/sofosbuvir +/- ribavirin vs. ombitasvir/paritaprevir/ritonavir + dasabuvir +/- ribavirin in 6961 genotype 1 patients treated in routine medical practice. Aliment Pharmacol Ther. 2016;44(4):400–10. doi: 10.1111/apt.13696. PMID: 27291852. Excluded for ineligible study design for Key Question.27291852
Bang C, Song I. Impact of antiviral therapy on hepatocellular carcinoma and mortality in patients with chronic hepatitis C: systematic review and meta-analysis. BMC Gastroenterol. 2017;17(1):46. doi: 10.1186/s12876-017-0606-9. PMID: 28376711. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.28376711
Barron J, Xie Y, Wu SJ, . Treatment of chronic hepatitis C infection with sofosbuvir-based regimens in a commercially insured patient population. Am Health Drug Benefits. 2016;9(6):327–35. PMID: 27924186. Excluded for ineligible study design for Key Question.27924186
Bassiony MM, Yousef A, Yousef U, . Major depressive disorder and generalized anxiety disorder and response to treatment in hepatitis C patients in Egypt. Int J Psychiatry Med. 2015;50(2):147–62. doi: 10.1177/0091217415605029. PMID: 26405268. Excluded for ineligible intervention.26405268
Basu P, Shah NJ, Aloysius MM, Brown RS Jr.. Interferon ineligible naïve chronic hepatitis C genotype I subjects treated with simeprevir and sofosbuvir in special population (psychiatric). A clinical pilot study; Inspire C study; interim results. HPB (Oxford). 2015;S2(17):46. Excluded for ineligible comparator.
Bell AM, Wagner JL, Barber KE, . Elbasvir/Grazoprevir: a review of the latest agent in the fight against hepatitis C. Int J Hepatol. 2016;2016:3852126. doi: 10.1155/2016/3852126. PMID: 27403342. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27403342
Belperio PS, Shahoumian TA, Loomis TP, . Real-world effectiveness of daclatasvir plus sofosbuvir and velpatasvir/sofosbuvir in hepatitis C genotype 2 and 3. J Hepatol. 2019;70(1):15–23. doi: 10.1016/j.jhep.2018.09.018. PMID: 30266283. Excluded for ineligible study design for Key Question.30266283
Berden FA, Aaldering BR, Groenewoud H, . Identification of the best direct-acting antiviral regimen for patients with hepatitis C virus genotype 3 infection: a systematic review and network meta-analysis. Clin Gastroenterol Hepatol. 2017;15(3):349–59. doi: 10.1016/j.cgh.2016.10.034. PMID: 27840182. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27840182
Bernardinello E, Cavalletto L, Chemello L, . Long-term clinical outcome after beta-interferon therapy in cirrhotic patients with chronic hepatitis C. TVVH Study Group. Hepatogastroenterology. 1999;46(30):3216–22. PMID: 10626189. Excluded for ineligible population.10626189
Bernstein D, Kleinman L, Barker CM, . Relationship of health-related quality of life to treatment adherence and sustained response in chronic hepatitis C patients. Hepatology. 2002;35(3):704–8. doi: 10.1053/jhep.2002.31311. PMID: 11870387. Excluded for outdated medication.11870387
Bezemer G, Van Gool AR, Verheij-Hart E, . Long-term effects of treatment and response in patients with chronic hepatitis C on quality of life. An international, multicenter, randomized, controlled study. BMC Gastroenterol. 2012;12:11. doi: 10.1186/1471-230X-12-11. PMID: 22292521. Excluded for ineligible intervention.22292521
Bini EJ, Mehandru S. Sustained virological response rates and health-related quality of life after interferon and ribavirin therapy in patients with chronic hepatitis C virus infection and persistently normal alanine aminotransferase levels. Aliment Pharmacol Ther. 2006;23(6):777–85. doi: 10.1111/j.1365-2036.2006.02819.x. PMID: 16556180. Excluded for ineligible outcome.16556180
Bonkovsky HL, Woolley JM. Reduction of health-related quality of life in chronic hepatitis C and improvement with interferon therapy. The Consensus Interferon Study Group. Hepatology. 1999;29(1):264–70. doi: 10.1002/hep.510290124. PMID: 9862876. Excluded for ineligible outcome.9862876
Boyd SD, Harrington P, Komatsu TE, . HCV genotype 4, 5 and 6: Distribution of viral subtypes and sustained virologic response rates in clinical trials of approved direct-acting antiviral regimens. J Viral Hepat. 2018;25(8):969–75. doi: 10.1111/jvh.12896. PMID: 29577495. Excluded for ineligible study design for Key Question.29577495
Braks RE, Ganne-Carrie N, Fontaine H, . Effect of sustained virological response on long-term clinical outcome in 113 patients with compensated hepatitis C-related cirrhosis treated by interferon alpha and ribavirin. World J Gastroenterol. 2007;13(42):5648–53. PMID: 17948941. Excluded for ineligible population.17948941
Bronowicki JP, Ouzan D, Asselah T, . Effect of ribavirin in genotype 1 patients with hepatitis C responding to pegylated interferon alfa-2a plus ribavirin. Gastroenterology. 2006;131(4):1040–8. doi: 10.1053/j.gastro.2006.07.022. PMID: 17030174. Excluded for ineligible intervention.17030174
Bronowicki JP, Pol S, Thuluvath PJ, . Randomized study of asunaprevir plus pegylated interferon-alpha and ribavirin for previously untreated genotype 1 chronic hepatitis C. Antivir Ther. 2013;18(7):885–93. doi: 10.3851/IMP2660. PMID: 23804631. Excluded for ineligible intervention.23804631
Brook RA, Kleinman NL, Su J, . Absenteeism and productivity among employees being treated for hepatitis C. Am J Manag Care. 2011;17(10):657–64. PMID: 22106459. Excluded for ineligible outcome.22106459
Bruix J, Poynard T, Colombo M, . Maintenance therapy with peginterferon alfa-2b does not prevent hepatocellular carcinoma in cirrhotic patients with chronic hepatitis C. Gastroenterology. 2011;140(7):1990–9. doi: 10.1053/j.gastro.2011.03.010. PMID: 21419770. Excluded for ineligible population.21419770
Bruno G, Saracino A, Fabrizio C, . Safety and effectiveness of a 12-week course of sofosbuvir and simeprevir+/-ribavirin in HCV-infected patients with or without HIV infection: a multicentre observational study. Int J Antimicrob Agents. 2017;49(3):296–301. doi: 10.1016/j.ijantimicag.2016.11.030. PMID: 28163136. Excluded for ineligible study design for Key Question.28163136
Bruno S, Stroffolini T, Colombo M, . Sustained virological response to interferon-alpha is associated with improved outcome in HCV-related cirrhosis: a retrospective study. Hepatology. 2007;45(3):579–87. doi: 10.1002/hep.21492. PMID: 17326216. Excluded for ineligible population.17326216
Buti M, Calleja JL, Lens S, . Simeprevir in combination with sofosbuvir in treatment-naive and -experienced patients with hepatitis C virus genotype 4 infection: a Phase III, open-label, single-arm study (PLUTO). Aliment Pharmacol Ther. 2017;45(3):468–75. doi: 10.1111/apt.13883. PMID: 27896822. Excluded for ineligible intervention.27896822
Buti M, Dominguez-Hernandez R, Casado MA, . Healthcare value of implementing hepatitis C screening in the adult general population in Spain. PLoS One. 2018;13(11):e0208036. doi: 10.1371/journal.pone.0208036. PMID: 30485377. Excluded for ineligible study design for Key Question.30485377
Buti M, Flisiak R, Kao JH, . Alisporivir with peginterferon/ribavirin in patients with chronic hepatitis C genotype 1 infection who failed to respond to or relapsed after prior interferon-based therapy: FUNDAMENTAL, a Phase II trial. J Viral Hepat. 2015;22(7):596–606. doi: 10.1111/jvh.12360. PMID: 25412795. Excluded for ineligible intervention.25412795
Butt AA, Ren Y, Marks K, . Do directly acting antiviral agents for HCV increase the risk of hepatic decompensation and decline in renal function? Results from ERCHIVES. Aliment Pharmacol Ther. 2017;45(1):150–9. doi: 10.1111/apt.13837. PMID: 27813162. Excluded for ineligible study design for Key Question.27813162
Butt AA, Yan P, Marks K, . Adding ribavirin to newer DAA regimens does not affect SVR rates in HCV genotype 1 infected persons: results from ERCHIVES. Aliment Pharmacol Ther. 2016;44(7):728–37. doi: 10.1111/apt.13748. PMID: 27459341. Excluded for ineligible study design for Key Question.27459341
Butt AA, Yan P, Shaikh OS, . Hepatitis B reactivation and outcomes in persons treated with directly acting antiviral agents against hepatitis C virus: results from ERCHIVES. Aliment Pharmacol Ther. 2018a;47(3):412–20. doi: 10.1111/apt.14426. PMID: 29181838. Excluded for ineligible study design for Key Question.29181838
Cacoub P, Desbois AC, Comarmond C, . Impact of sustained virological response on the extrahepatic manifestations of chronic hepatitis C: a meta-analysis. Gut. 2018:2025–34. doi: 10.1136/gutjnl-2018-316234. PMID: 29703790. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.29703790
Cacoub P, Lidove O, Maisonobe T, . Interferon-alpha and ribavirin treatment in patients with hepatitis C virus-related systemic vasculitis. Arthritis Rheum. 2002;46(12):3317–26. doi: 10.1002/art.10699. PMID: 12483738. Excluded for ineligible intervention.12483738
Cardoso AC, Moucari R, Figueiredo-Mendes C, . Impact of peginterferon and ribavirin therapy on hepatocellular carcinoma: incidence and survival in hepatitis C patients with advanced fibrosis. J Hepatol. 2010;52(5):652–7. doi: 10.1016/j.jhep.2009.12.028. PMID: 20346533. Excluded for ineligible population.20346533
Caroleo B, Colangelo L, Perticone M, . Efficacy and safety of elbasvir-grazoprevir fixed dose in the management of polytreated HCV patients: evidence from real-life clinical practice. J Clin Pharmacol. 2018;58(10):1248–53. doi: 10.1002/jcph.1135. PMID: 29746724. Excluded for ineligible outcome.29746724
Cha RR, Lee SS, Lee CM, . Clinical features and outcomes of patients with genotype 3 hepatitis C virus infection in Korea: a retrospective observational study. Medicine. 2016;95(6):e2755. doi: 10.1097/MD.0000000000002755. PMID: 26871824. Excluded for ineligible population.26871824
Chahine EB, Sucher AJ, Hemstreet BA. Sofosbuvir/velpatasvir: the first pangenotypic direct-acting antiviral combination for hepatitis C. Ann Pharmacother. 2017;51(1):44–53. doi: 10.1177/1060028016668897. PMID: 27609942. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27609942
Chamorro-de-Vega E, Gimenez-Manzorro A, Rodriguez-Gonzalez CG, . Effectiveness and safety of ombitasvir-paritaprevir/ritonavir and dasabuvir with or without ribavirin for HCV genotype 1 infection for 12 weeks under routine clinical practice. Ann Pharmacother. 2016;50(11):901–8. doi: 10.1177/1060028016659306. PMID: 27422641. Excluded for ineligible population.27422641
Chan HLY, Tsang OTY, Hui YT, . Real-life efficacy and safety of paritaprevir/ ritonavir, ombitasvir and dasabuvir combination with or without ribavirin in difficult-to-treat genotype 1 chronic hepatitis C patients in Hong Kong. J Gastroenterol Hepatol. 2016;31(378). Excluded for ineligible population.
Chang KC, Ye YH, Wu CK, . Risk factors for development of hepatocellular carcinoma in patients with chronic hepatitis C without sustained response to combination therapy. J Formos Med Assoc. 2018;117(11):1011–8. doi: 10.1016/j.jfma.2017.11.008. PMID: 29254684. Excluded for ineligible population.29254684
Chang SC, Yang SS, Chang CC, . Assessment of health-related quality of life in antiviral-treated Taiwanese chronic hepatitis C patients using SF-36 and CLDQ. Health Qual Life Outcomes. 2014;12:97. doi: 10.1186/1477-7525-12-97. PMID: 24941994. Excluded for ineligible intervention.24941994
Chayama K, Notsumata K, Kurosaki M, . Randomized trial of interferon- and ribavirin-free ombitasvir/paritaprevir/ritonavir in treatment-experienced hepatitis C virus-infected patients. Hepatology. 2015;61(5):1523–32. doi: 10.1002/hep.27705. PMID: 25644279. Excluded for ineligible intervention.25644279
Chen J, Shi J, Xie WF, . Meta-analysis: amantadine may lower the efficacy of pegylated interferon plus ribavirin in treatment-naive hepatitis C genotype 1 patients. Int J Infect Dis. 2012;16(10):e748–52. doi: 10.1016/j.ijid.2012.06.002. PMID: 22836046. Excluded for ineligible intervention.22836046
Cheng PN, Chiu YC, Chien SC, . Real-world effectiveness and safety of sofosbuvir plus daclatasvir with or without ribavirin for genotype 2 chronic hepatitis C in Taiwan. J Formos Med Assoc. 2018;11:11. doi: 10.1016/j.jfma.2018.09.016. PMID: 30316677. Excluded for ineligible population.30316677
Cho Y, Cho EJ, Lee JH, . Sofosbuvir-based therapy for patients with chronic hepatitis C: early experience of its efficacy and safety in Korea. Clin Mol Hepatol. 2015;21(4):358–64. doi: 10.3350/cmh.2015.21.4.358. PMID: 26770924. Excluded for ineligible study design for Key Question.26770924
Chopp S, Vanderwall R, Hult A, . Simeprevir and sofosbuvir for treatment of hepatitis C infection. Am J Health Syst Pharm. 2015;72(17):1445–55. PMID: 26294237. Excluded for ineligible study design for Key Question.26294237
Chung W, Kim KA, Jang ES, . Cost-effectiveness of sofosbuvir plus ribavirin therapy for hepatitis C virus genotype 2 infection in South Korea. J Gastroenterol Hepatol. 2018;21:21. doi: 10.1111/jgh.14554. PMID: 30462841. Excluded for ineligible outcome.30462841
Conte D, Fraquelli M, Prati D, . Prevalence and clinical course of chronic hepatitis C virus (HCV) infection and rate of HCV vertical transmission in a cohort of 15,250 pregnant women. Hepatology. 2000;31(3):751–5. doi: 10.1002/hep.510310328. PMID: 10706568. Excluded for poor quality.10706568
Cornberg M, Petersen J, Schober A, . Real-world use, effectiveness and safety of anti-viral treatment in chronic hepatitis C genotype 3 infection. Aliment Pharmacol Ther. 2017;45(5):688–700. doi: 10.1111/apt.13925. PMID: 28078723. Excluded for ineligible study design for Key Question.28078723
Coughlan B, Sheehan J, Carr A, . Evaluation of a brief group based psychological/educational treatment programme for women with an iatrogenic chronic hepatitis C virus infection. J Clin Psychol Med Settings. 2004;11(4):303–14. Excluded for poor quality.
Coverdale SA, Khan MH, Byth K, . Effects of interferon treatment response on liver complications of chronic hepatitis C: 9-year follow-up study. Am J Gastroenterol. 2004;99(4):ajg2004123. doi: 10.1111/j.1572-0241.2004.04085.x. PMID: 15089895. Excluded for ineligible population.15089895
Coyle C, Moorman AC, Bartholomew T, . The HCV care continuum: linkage to HCV care and treatment among patients at an urban health network, Philadelphia, PA. Hepatology. 2019 doi: 10.1002/hep.30501. PMID: 30633811. Excluded for ineligible outcome.30633811
Cucchetti A, D’Amico G, Trevisani F, . Effect of direct-acting antivirals on future occurrence of hepatocellular carcinoma in compensated cirrhotic patients. Dig Liver Dis. 2018;50(2):156–62. doi: 10.1016/j.dld.2017.10.004. PMID: 29102521. Excluded for ineligible outcome.29102521
Curry MP, O’Leary JG, Bzowej N, . Sofosbuvir and velpatasvir for HCV in patients with decompensated cirrhosis. N Engl J Med. 2015;373(27):2618–28. doi: 10.1056/NEJMoa1512614. PMID: 26569658. Excluded for ineligible population.26569658
Dal Molin G, D’Agaro P, Ansaldi F, . Mother-to-infant transmission of hepatitis C virus: rate of infection and assessment of viral load and IgM anti-HCV as risk factors. J Med Virol. 2002;67(2):137–42. doi: 10.1002/jmv.2202. PMID: 11992574. Excluded for insufficient statistical analysis.11992574
Dalgard O, Bjoro K, Ring-Larsen H, . Pegylated interferon alfa and ribavirin for 14 versus 24 weeks in patients with hepatitis C virus genotype 2 or 3 and rapid virological response. Hepatology. 2008;47(1):35–42. doi: 10.1002/hep.21975. PMID: 17975791. Excluded for outdated medication.17975791
Dalgard O, Weiland O, Noraberg G, . Sofosbuvir based treatment of chronic hepatitis C genotype 3 infections-A Scandinavian real-life study. PLoS One. 2017;12(7):e0179764. doi: 10.1371/journal.pone.0179764. PMID: 28704381. Excluded for ineligible population.28704381
Damiani G, Franchi C, Pigatto P, . Outcomes assessment of hepatitis C virus-positive psoriatic patients treated using pegylated interferon in combination with ribavirin compared to new direct-acting antiviral agents. World J Hepatol. 2018;10(2):329–36. doi: 10.4254/wjh.v10.i2.329. PMID: 29527268. Excluded for ineligible study design for Key Question.29527268
Davitkov P, Chandar AK, Hirsch A, . Treatment selection choices should not be based on benefits or costs alone: a head-to-head randomized controlled trial of antiviral drugs for hepatitis C. PLoS One. 2016;11(10):e0163945. doi: 10.1371/journal.pone.0163945. PMID: 27741230. Excluded for ineligible intervention.27741230
Del Rio-Valencia JC, Asensi-Diez R, Madera-Pajin R, . Interferon-free treatments in patients with hepatitis C genotype 3 infection in a tertiary hospital. Rev Esp Quimioter. 2018;31(1):35–42. PMID: 29376623. Excluded for ineligible study design for Key Question.29376623
Delamare C, Carbonne B, Heim N, . Detection of hepatitis C virus RNA (HCV RNA) in amniotic fluid: a prospective study. J Hepatol. 1999;31(3):416–20. PMID: 10488698. Excluded for not a study: letter, editorial, non-systematic review article, no original data.10488698
Delotte J, Barjoan EM, Berrebi A, . Obstetric management does not influence vertical transmission of HCV infection: results of the ALHICE group study. J Matern Fetal Neonatal Med. 2014;27(7):664–70. doi: 10.3109/14767058.2013.829813. PMID: 23971940. Excluded for insufficient statistical analysis.23971940
Desnoyer A, Pospai D, Le MP, . Pharmacokinetics, safety and efficacy of a full dose sofosbuvir-based regimen given daily in hemodialysis patients with chronic hepatitis C. J Hepatol. 2016;65(1):40–7. PMID: 26952005. Excluded for ineligible population.26952005
Deterding K, Spinner CD, Schott E, . Ledipasvir plus sofosbuvir fixed-dose combination for 6 weeks in patients with acute hepatitis C virus genotype 1 monoinfection (HepNet Acute HCV IV): an open-label, single-arm, phase 2 study. Lancet Infect Dis. 2017;17(2):215–22. PMID: 28029529. Excluded for ineligible intervention.28029529
Dhiman RK, Grover GS, Premkumar M, . Direct-acting antiviral therapy is safe and effective in pediatric chronic hepatitis C: the public health perspective. J Pediatr Gastroenterol Nutr. 2019;68(1):74–80. doi: 10.1097/MPG.0000000000002139. PMID: 30211847. Excluded for ineligible study design for Key Question.30211847
Di Martino V, Crouzet J, Hillon P, . Long-term outcome of chronic hepatitis C in a population-based cohort and impact of antiviral therapy: a propensity-adjusted analysis. J Viral Hepat. 2011;18(7):493–505. doi: 10.1111/j.1365-2893.2011.01476.x. PMID: 21692956. Excluded for insufficient statistical analysis.21692956
Dieterich D, Nelson M, Soriano V, . Faldaprevir and pegylated interferon alpha-2a/ribavirin in individuals co-infected with hepatitis C virus genotype-1 and HIV. AIDS. 2015;29(5):571–81. doi: 10.1097/QAD.0000000000000579. PMID: 25710287. Excluded for ineligible intervention.25710287
D’Offizi G, Camma C, Taibi C, . Clinical and virological predictors of sustained response with an interferon-based simeprevir regimen for patients with chronic genotype 1 hepatitis C virus infection. New Microbiol. 2017;40(1):19–26. PMID: 28072888. Excluded for ineligible intervention.28072888
Dore GJ, Altice F, Litwin AH, . Elbasvir-grazoprevir to treat hepatitis C virus infection in persons receiving opioid agonist therapy: a randomized trial. Ann Intern Med. 2016;165(9):625–34. doi: 10.7326/M16-0816. PMID: 27537841. Excluded for ineligible population.27537841
Dore GJ, Lawitz E, Hezode C, . Daclatasvir plus peginterferon and ribavirin is noninferior to peginterferon and ribavirin alone, and reduces the duration of treatment for HCV genotype 2 or 3 infection. Gastroenterology. 2015;148(2):355–66.e1. doi: 10.1053/j.gastro.2014.10.007. PMID: 25311593. Excluded for ineligible intervention.25311593
Doss W, Shiha G, Hassany M, . Sofosbuvir plus ribavirin for treating Egyptian patients with hepatitis C genotype 4. J Hepatol. 2015;63(3):581–5. doi: 10.1016/j.jhep.2015.04.023. PMID: 25937436. Excluded for ineligible intervention.25937436
Dultz G, Muller T, Petersen J, . Effectiveness and safety of direct-acting antiviral combination therapies for treatment of hepatitis C virus in elderly patients: results from the German hepatitis C registry. Drugs Aging. 2018;35(9):843–57. doi: 10.1007/s40266-018-0572-0. PMID: 30084012. Excluded for ineligible study design for Key Question.30084012
Dusheiko G. The impact of antiviral therapy for hepatitis C on the quality of life: a perspective. Liver Int. 2017;37: Suppl 1:7–12. doi: 10.1111/liv.13292. PMID: 28052638. Excluded for not a study: letter, editorial, non-systematic review article, no original data.28052638
Dusheiko GM, Manns MP, Vierling JM, . Safety and tolerability of grazoprevir/elbasvir in patients with chronic hepatitis C (HCV) infection: Integrated analysis of phase 2-3 trials. Hepatology. 2015;62:562A. Excluded for ineligible population.
El Kassas M, Elbaz T, Hafez E, . Safety of direct antiviral agents in the management of hepatitis C. Expert Opin Drug Saf. 2016;15(12):1643–52. doi: 10.1080/14740338.2017.1240781. PMID: 27661100. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27661100
El Raziky M, Gamil M, Ashour MK, . Simeprevir plus sofosbuvir for eight or 12 weeks in treatment-naive and treatment-experienced hepatitis C virus genotype 4 patients with or without cirrhosis. J Viral Hepat. 2017;24(2):102–10. PMID: 27790789. Excluded for ineligible intervention.27790789
El-Karaksy HM, Mogahed EA, El-Raziky MS, . Safety and efficacy of combined treatment with pegylated interferon alpha-2b and ribavirin for HCV genotype 4 in children. J Interferon Cytokine Res. 2016;36(1):1–8. doi: 10.1089/jir.2015.0066. PMID: 26406390. Excluded for ineligible intervention.26406390
el-Khattib AA, Abdelhakam SM, Ghoraba DM, . Outcome of antiviral therapy in Egyptian hepatitis C virus (HCV) genotype 4 patients with advanced liver fibrosis. Eur J Intern Med. 2012;23(1):e34–5. doi: 10.1016/j.ejim.2011.10.003. PMID: 22153547. Excluded for not a study: letter, editorial, non-systematic review article, no original data.22153547
El-Khayat H, Kamal EM, Yakoot M, . Effectiveness of 8-week sofosbuvir/ledipasvir in the adolescent chronic hepatitis C-infected patients. Eur J Gastroenterol Hepatol. 2019;22:22. doi: 10.1097/MEG.0000000000001360. PMID: 30676473. Excluded for ineligible study design for Key Question.30676473
El-Khayat HR, Kamal EM, El-Sayed MH, . The effectiveness and safety of ledipasvir plus sofosbuvir in adolescents with chronic hepatitis C virus genotype 4 infection: a real-world experience. Aliment Pharmacol Ther. 2018;47(6):838–44. doi: 10.1111/apt.14502. PMID: 29349793. Excluded for ineligible study design for Key Question.29349793
El-Serag HB, Alsarraj A, Richardson P, . Hepatocellular carcinoma screening practices in the Department of Veterans Affairs: findings from a national facility survey. Dig Dis Sci. 2013;58(11):3117–26. doi: 10.1007/s10620-013-2794-7. PMID: 23868438. Excluded for ineligible intervention.23868438
Ennaifer R, Sabbah M, Hefaiedh R, . Antiviral therapy for hepatitis C virus infection, cryoglobulinemic glomerulonephritis and low-grade malignant lymphoma: a challenge? Tunis Med. 2015;93(3):203–4. PMID: 26367421. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26367421
Escudero A, Rodriguez F, Serra MA, . Pegylated alpha-interferon-2a plus ribavirin compared with pegylated alpha-interferon-2b plus ribavirin for initial treatment of chronic hepatitis C virus: prospective, non-randomized study. J Gastroenterol Hepatol. 2008;23(6):861–6. doi: 10.1111/j.1440-1746.2008.05397.x. PMID: 18422960. Excluded for outdated medication.18422960
Esteban R, Pineda JA, Calleja JL, . Efficacy of sofosbuvir and velpatasvir, with and without ribavirin, in patients with hepatitis C virus genotype 3 infection and cirrhosis. Gastroenterology. 2018;155(4):1120–7.e4. doi: 10.1053/j.gastro.2018.06.042. PMID: 29958855. Excluded for ineligible population.29958855
Everson G, Cooper C, Hezode C, . DAUPHINE: a randomized phase II study of danoprevir/ritonavir plus peginterferon alpha-2a/ribavirin in HCV genotypes 1 or 4. Liver Int. 2015;35(1):108–19. doi: 10.1111/liv.12471. PMID: 24517252. Excluded for ineligible intervention.24517252
Fabris P, Tositti G, Giordani MT, . Assessing patients’ understanding of hepatitis C virus infection and its impact on their lifestyle. Aliment Pharmacol Ther. 2006;23(8):1161–70. doi: 10.1111/j.1365-2036.2006.02882.x. PMID: 16611277. Excluded for poor quality.16611277
Falade-Nwulia O, Suarez-Cuervo C, Nelson DR, . Oral direct-acting agent therapy for hepatitis C virus infection: a systematic review. Ann Intern Med. 2017;166(9):637–48. doi: 10.7326/m16-2575. PMID: 28319996. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.28319996
Fartoux L, Degos F, Trepo C, . Effect of prolonged interferon therapy on the outcome of hepatitis C virus-related cirrhosis: a randomized trial. Clin Gastroenterol Hepatol. 2007;5(4):502–7. doi: 10.1016/j.cgh.2006.10.016. PMID: 17261383. Excluded for ineligible population.17261383
Fazel Y, Lam B, Golabi P, . Safety analysis of sofosbuvir and ledipasvir for treating hepatitis C. Expert Opin Drug Saf. 2015;14(8):1317–26. doi: 10.1517/14740338.2015.1053868. PMID: 26043900. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26043900
Feld JJ, Grebely J, Matthews GV, . Plasma interferon-gamma-inducible protein-10 levels are associated with early, but not sustained virological response during treatment of acute or early chronic HCV infection. PLoS One. 2013;8(11):e80003. doi: 10.1371/journal.pone.0080003. PMID: 24278230. Excluded for ineligible intervention.24278230
Ferenci P, Brunner H, Laferl H, . A randomized, prospective trial of ribavirin 400 mg/day versus 800 mg/day in combination with peginterferon alfa-2a in hepatitis C virus genotypes 2 and 3. Hepatology. 2008;47(6):1816–23. doi: 10.1002/hep.22262. PMID: 18454510. Excluded for outdated medication.18454510
Ferenci P, Caruntu FA, Lengyel G, . Boceprevir plus peginterferon alfa-2a/ribavirin in treatment-naive hepatitis C virus genotype 1 patients: International Phase IIIb/IV TriCo Trial. Infect Dis Ther. 2016;5(2):113–24. doi: 10.1007/s40121-016-0110-5. PMID: 27228998. Excluded for ineligible outcome.27228998
Fernández-Rodríguez CM, Alonso S, Martinez SM, . Peginterferon plus ribavirin and sustained virological response in HCV-related cirrhosis: outcomes and factors predicting response. Am J Gastroenterol. 2010;105(10):2164. doi: 10.1038/ajg.2010.294. PMID: 20700116. Excluded for ineligible population.20700116
Flamm SL, Muir AJ, Fried MW, . Sustained virologic response rates with telaprevir-based therapy in treatment-naive patients evaluated by race or ethnicity. J Clin Gastroenterol. 2015;49(4):336–44. doi: 10.1097/MCG.0000000000000150. PMID: 24828357. Excluded for ineligible outcome.24828357
Flisiak R, Janczewska E, Wawrzynowicz-Syczewska M, . Real-world effectiveness and safety of ombitasvir/paritaprevir/ritonavir +/- dasabuvir +/- ribavirin in hepatitis C: AMBER study. Aliment Pharmacol Ther. 2016;44(9):946–56. doi: 10.1111/apt.13790. PMID: 27611776. Excluded for ineligible study design for Key Question.27611776
Fontana RJ, Litman HJ, Dienstag JL, . YKL-40 genetic polymorphisms and the risk of liver disease progression in patients with advanced fibrosis due to chronic hepatitis C. Liver Int. 2012;32(4):665–74. doi: 10.1111/j.1478-3231.2011.02686.x. PMID: 22103814. Excluded for ineligible population.22103814
Fouad HM, Ahmed Mohamed A, Sabry M, . The effectiveness of ledipasvir/sofosbuvir in youth with genotype 4 hepatitis C virus: a single Egyptian center study. Pediatr Infect Dis J. 2019;38(1):22–5. doi: 10.1097/INF.0000000000002189. PMID: 30234791. Excluded for ineligible study design for Key Question.30234791
Fujii Y, Uchida Y, Mochida S. Drug-induced immunoallergic hepatitis during combination therapy with daclatasvir and asunaprevir. Hepatology. 2015;61(1):400–1. doi: 10.1002/hep.27559. PMID: 25308083. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25308083
Gamal N, Andreone P. Safety and efficacy of once daily ledipasvir/sofosbuvir fixed-dose combination in patients with chronic hepatitis C. Expert Opin Drug Saf. 2016;15(4):549–57. doi: 10.1517/14740338.2016.1157163. PMID: 26899025. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26899025
Gane EJ, Hyland RH, Yang Y, . Efficacy of ledipasvir plus sofosbuvir for 8 or 12 weeks in patients with hepatitis C virus genotype 2 infection. Gastroenterology. 2017;152(6):1366–71. doi: 10.1053/j.gastro.2017.01.017. PMID: 28137593. Excluded for ineligible intervention.28137593
Gane EJ, Kowdley KV, Pound D, . Efficacy of sofosbuvir, velpatasvir, and GS-9857 in patients with hepatitis C virus genotype 2, 3, 4, or 6 infections in an open-label, phase 2 trial. Gastroenterology. 2016;151(5):902–9. doi: 10.1053/j.gastro.2016.07.038. PMID: 27486033. Excluded for ineligible intervention.27486033
Gane EJ, Stedman CA, Hyland RH, . Efficacy of nucleotide polymerase inhibitor sofosbuvir plus the NS5A inhibitor ledipasvir or the NS5B non-nucleoside inhibitor GS-9669 against HCV genotype 1 infection. Gastroenterology. 2014;146(3):736–43.e1. doi: 10.1053/j.gastro.2013.11.007. PMID: 24262278. Excluded for ineligible intervention.24262278
Garland SM, Tabrizi S, Robinson P, . Hepatitis C-role of perinatal transmission. Aust N Z J Obstet Gynaecol. 1998;38(4):424–7. PMID: 9890224. Excluded for poor quality.9890224
Gentile I, Borgia G. Randomised controlled trial: ledipasvir/sofosbuvir administration achieves very high rate of viral clearance in patients with HCV genotype 1 infection without cirrhosis, regardless of ribavirin co-administration or length of treatment. BMJ Evid Based Med. 2014;19(6):223–4. Excluded for ineligible study design for Key Question.
George J, Burnevich E, Sheen IS, . Elbasvir/grazoprevir in Asia-Pacific/Russian participants with chronic hepatitis C virus genotype 1, 4, or 6 infection. Hepatol Commun. 2018;2(5):595–606. doi: 10.1002/hep4.1177. PMID: 29761174. Excluded for ineligible study design for Key Question.29761174
Gerber L, Estep M, Stepanova M, . Effects of viral eradication with ledipasvir and sofosbuvir, with or without ribavirin, on measures of fatigue in patients with chronic hepatitis C virus infection. Clin Gastroenterol Hepatol. 2016;14(1):156–64.e3. doi: 10.1016/j.cgh.2015.07.035. PMID: 26241510. Excluded for ineligible study design for Key Question.26241510
Giordanino C, Sacco M, Ceretto S, . Durability of the response to peginterferon-alpha2b and ribavirin in patients with chronic hepatitis C: a cohort study in the routine clinical setting. Eur J Gastroenterol Hepatol. 2014;26(1):52–8. doi: 10.1097/MEG.0b013e328362dc99. PMID: 23719564. Excluded for ineligible outcome.23719564
Gopalakrishnan S, Khatri A, Mensing S, . Exposure-response relationship for ombitasvir and paritaprevir/ritonavir in hepatitis C virus subgenotype 1b-infected Japanese patients in the phase 3 randomized GIFT-I study. Adv Ther. 2016;33(4):670–83. doi: 10.1007/s12325-016-0320-y. PMID: 27084721. Excluded for ineligible study design for Key Question.27084721
Granovsky MO, Minkoff HL, Tess BH, . Hepatitis C virus infection in the mothers and infants cohort study. Pediatrics. 1998;102(2 Pt 1):355–9. PMID: 9685438. Excluded for insufficient statistical analysis.9685438
Grebely J, Feld JJ, Wyles D, . Sofosbuvir-based direct-acting antiviral therapies for HCV in people receiving opioid substitution therapy: an analysis of phase 3 studies. Open Forum Infect Dis. 2018;5(2):ofy001. doi: 10.1093/ofid/ofy001. PMID: 29450210. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.29450210
Grebely J, Mauss S, Brown A, . Efficacy and safety of ledipasvir/sofosbuvir with and without ribavirin in patients with chronic HCV genotype 1 infection receiving opioid substitution therapy: analysis of phase 3 ION trials. Clin Infect Dis. 2016;63(11):1405–11. PMID: 27553375. Excluded for ineligible study design for Key Question.27553375
Grebely J, Puoti M, Wedemeyer H, . Efficacy and safety of ombitasvir/paritaprevir/ritonavir and dasabuvir with or without ribavirin in patients with chronic hepatitis C virus genotype 1 infection receiving opioid substitution therapy: a post hoc analysis of 12 clinical trials. Open Forum Infect Dis. 2018;5(11):ofy248. doi: 10.1093/ofid/ofy248. PMID: 30430131. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.30430131
Greig SL. Sofosbuvir/velpatasvir: a review in chronic hepatitis C. Drugs. 2016;76(16):1567–78. doi: 10.1007/s40265-016-0648-2. PMID: 27730529. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27730529
Gunn RA, Murray PJ, Brennan CH, . Evaluation of screening criteria to identify persons with hepatitis C virus infection among sexually transmitted disease clinic clients: results from the San Diego Viral Hepatitis Integration Project. Sex Transm Dis. 2003;30(4):340–4. PMID: 12671556. Excluded for poor quality.12671556
Gupta N, Mbituyumuremyi A, Kabahizi J, . Treatment of chronic hepatitis C virus infection in Rwanda with ledipasvir-sofosbuvir (SHARED): a single-arm trial. Lancet Gastroenterol Hepatol. 2019;4(2):119–26. doi: 10.1016/S2468-1253(18)30382-0. PMID: 30552056. Excluded for ineligible population.30552056
Hadziyannis SJ, Sette H, Jr., Morgan TR, . Peginterferon-alpha2a and ribavirin combination therapy in chronic hepatitis C: a randomized study of treatment duration and ribavirin dose. Ann Intern Med. 2004;140(5):346–55. PMID: 14996676. Excluded for outdated medication.14996676
Hagiwara S, Nishida N, Watanabe T, . Outcome of asunaprevir/daclatasvir combination therapy for chronic liver disease type C. Dig Dis. 2016;34(6):620–6. doi: 10.1159/000448822. PMID: 27750228. Excluded for ineligible intervention.27750228
Hagiwara S, Nishida N, Watanabe T, . Outcome of combination therapy with sofosbuvir and ledipasvir for chronic type C liver disease. Oncology. 2017;92: Suppl 1:3–9. doi: 10.1159/000451010. PMID: 27974712. Excluded for ineligible population.27974712
Hajarizadeh B, Cunningham EB, Reid H, . Direct-acting antiviral treatment for hepatitis C among people who use or inject drugs: a systematic review and meta-analysis. Lancet Gastroenterol Hepatol. 2018;3(11):754–67. PMID: 30245064. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.30245064
Harada N, Hiramatsu N, Oze T, . Risk factors for hepatocellular carcinoma in hepatitis C patients with normal alanine aminotransferase treated with pegylated interferon and ribavirin. J Viral Hepat. 2014;21(5):357–65. doi: 10.1111/jvh.12151. PMID: 24716638. Excluded for ineligible population.24716638
Harada N, Hiramatsu N, Oze T, . Incidence of hepatocellular carcinoma in HCV-infected patients with normal alanine aminotransferase levels categorized by Japanese treatment guidelines. J Gastroenterol. 2013;48(4):535–43. doi: 10.1007/s00535-012-0657-1. PMID: 22976932. Excluded for ineligible population.22976932
Hasegawa E, Kobayashi M, Kawamura Y, . Efficacy and anticarcinogenic activity of interferon for hepatitis C virus-related compensated cirrhosis in patients with genotype 1b low viral load or genotype 2. Hepatol Res. 2007;37(10):793–800. doi: 10.1111/j.1872-034X.2007.00140.x. PMID: 17593231. Excluded for ineligible population.17593231
Hassanein T, Cooksley G, Sulkowski M, . The impact of peginterferon alfa-2a plus ribavirin combination therapy on health-related quality of life in chronic hepatitis C. J Hepatol. 2004;40(4):675–81. doi: 10.1016/j.jhep.2003.12.014. PMID: 15030985. Excluded for ineligible intervention.15030985
Hayashi N, Seto C, Kato M, . Once-daily simeprevir (TMC435) with peginterferon/ribavirin for treatment-naive hepatitis C genotype 1-infected patients in Japan: the DRAGON study. J Gastroenterol. 2014;49(1):138–47. doi: 10.1007/s00535-013-0875-1. PMID: 24005956. Excluded for ineligible intervention.24005956
Heidrich B, Wiegand SB, Buggisch P, . Treatment of naive patients with chronic hepatitis C genotypes 2 and 3 with pegylated interferon alpha and ribavirin in a real world setting: relevance for the new era of DAA. PLoS One. 2014;9(10):e108751. doi: 10.1371/journal.pone.0108751. PMID: 25302676. Excluded for ineligible intervention.25302676
Helbling B, Jochum W, Stamenic I, . HCV-related advanced fibrosis/cirrhosis: randomized controlled trial of pegylated interferon alpha-2a and ribavirin. J Viral Hepat. 2006;13(11):762–9. doi: 10.1111/j.1365-2893.2006.00753.x. PMID: 17052276. Excluded for outdated medication.17052276
Hetta HF, Mekky MA, Khalil NK, . Extra-hepatic infection of hepatitis C virus in the colon tissue and its relationship with hepatitis C virus pathogenesis. J Med Microbiol. 2016;65(8):703–12. doi: 10.1099/jmm.0.000272. PMID: 27166142. Excluded for ineligible outcome.27166142
Hezode C, Colombo M, Bourliere M, . Elbasvir/grazoprevir for patients with hepatitis C virus infection and inherited blood disorders: A phase III study. Hepatology. 2017;66(3):736–45. doi: 10.1002/hep.29139. PMID: 28256747. Excluded for ineligible population.28256747
Hezode C, Forestier N, Dusheiko G, . Telaprevir and peginterferon with or without ribavirin for chronic HCV infection. N Engl J Med. 2009;360(18):1839–50. doi: 10.1056/NEJMoa0807650. PMID: 19403903. Excluded for outdated medication.19403903
Hezode C, Lebray P, De Ledinghen V, . Daclatasvir plus sofosbuvir, with or without ribavirin, for hepatitis C virus genotype 3 in a French early access programme. Liver Int. 2017 (pagination)doi: 10.1111/liv.13383. PMID: 28177199. Excluded for ineligible study design for Key Question.28177199
Hill A, Khwairakpam G, Wang J, . High sustained virological response rates using imported generic direct acting antiviral treatment for hepatitis C. J Virus Erad. 2017;3(4):200–3. PMID: 29057082. Excluded for ineligible study design for Key Question.29057082
Hirakawa M, Ikeda K, Arase Y, . Hepatocarcinogenesis following HCV RNA eradication by interferon in chronic hepatitis patients. Intern Med. 2008;47(19):1637–43. PMID: 18827409. Excluded for ineligible comparator.18827409
Hosry J, Mahale P, Turturro F, . Antiviral therapy improves overall survival in hepatitis C virus-infected patients who develop diffuse large B-cell lymphoma. Int J Cancer. 2016;139(11):2519–28. doi: 10.1002/ijc.30372. PMID: 27501007. Excluded for ineligible intervention.27501007
Hsu CS, Huang CJ, Kao JH, . Interferon-based therapy decreases risks of hepatocellular carcinoma and complications of cirrhosis in chronic hepatitis C patients. PLoS One. 2013;8(7):e70458. doi: 10.1371/journal.pone.0070458. PMID: 23894660. Excluded for ineligible population.23894660
Hsu YC, Ho HJ, Huang YT, . Association between antiviral treatment and extrahepatic outcomes in patients with hepatitis C virus infection. Gut. 2015;64(3):495–503. doi: 10.1136/gutjnl-2014-308163. PMID: 25398770. Excluded for ineligible comparator.25398770
Hsu YC, Ho HJ, Wu MS, . Postoperative peg-interferon plus ribavirin is associated with reduced recurrence of hepatitis C virus-related hepatocellular carcinoma. Hepatology. 2013;58(1):150–7. doi: 10.1002/hep.26300. PMID: 23389758. Excluded for ineligible population.23389758
Hsu YC, Lin JT, Ho HJ, . Antiviral treatment for hepatitis C virus infection is associated with improved renal and cardiovascular outcomes in diabetic patients. Hepatology. 2014;59(4):1293–302. doi: 10.1002/hep.26892. PMID: 24122848. Excluded for ineligible intervention.24122848
Hsu YH, Hung PH, Muo CH, . Interferon-based treatment of hepatitis C virus infection reduces all-cause mortality in patients with end-stage renal disease: an 8-year nationwide cohort study in Taiwan. Medicine. 2015;94(47):e2113. doi: 10.1097/MD.0000000000002113. PMID: 26632730. Excluded for ineligible population.26632730
Hu C, Yuan G, Liu J, . Sofosbuvir-based therapies for patients with hepatitis C virus infection: real-world experience in China. Can J Gastroenterol Hepatol. 2018;2018:3908767. doi: 10.1155/2018/3908767. PMID: 30538973. Excluded for ineligible study design for Key Question.30538973
Hu CC, Lin CL, Kuo YL, . Efficacy and safety of ribavirin plus pegylated interferon alfa in geriatric patients with chronic hepatitis C. Aliment Pharmacol Ther. 2013;37(1):81–90. doi: 10.1111/apt.12112. PMID: 23121150. Excluded for ineligible intervention.23121150
Huang JF, Yeh ML, Yu ML, . The tertiary prevention of hepatocellular carcinoma in chronic hepatitis C patients. J Gastroenterol Hepatol. 2015;30(12):1768–74. doi: 10.1111/jgh.13012. PMID: 26094738. Excluded for ineligible population.26094738
Huang QT, Hang LL, Zhong M, . Maternal HCV infection is associated with intrauterine fetal growth disturbance: a meta-analysis of observational studies. Medicine. 2016;95(35):e4777. doi: 10.1097/MD.0000000000004777. PMID: 27583932. Excluded for ineligible intervention.27583932
Huang QT, Huang Q, Zhong M, . Chronic hepatitis C virus infection is associated with increased risk of preterm birth: a meta-analysis of observational studies. J Viral Hepat. 2015;22(12):1033–42. doi: 10.1111/jvh.12430. PMID: 26081198. Excluded for ineligible intervention.26081198
Hum J, Jou JH, Green PK, . Improvement in glycemic control of type 2 diabetes after successful treatment of hepatitis C virus. Diabetes Care. 2017;40(9):1173–80. doi: 10.2337/dc17-0485. PMID: 28659309. Excluded for ineligible study design for Key Question.28659309
Hung CH, Lee CM, Lu SN, . Long-term effect of interferon alpha-2b plus ribavirin therapy on incidence of hepatocellular carcinoma in patients with hepatitis C virus-related cirrhosis. J Viral Hepat. 2006;13(6):409–14. doi: 10.1111/j.1365-2893.2005.00707.x. PMID: 16842444. Excluded for ineligible population.16842444
Hung CH, Lee CM, Wang JH, . Impact of diabetes mellitus on incidence of hepatocellular carcinoma in chronic hepatitis C patients treated with interferon-based antiviral therapy. Int J Cancer. 2011;128(10):2344–52. doi: 10.1002/ijc.25585. PMID: 20669224. Excluded for ineligible population.20669224
Hussar DA, Kavelak HL. Ledipasvir/sofosbuvir; ombitasvir/paritaprevir/ritonavir/dasabuvir sodium monohydrate; and peramivir. J Am Pharm Assoc. 2015;55(2):216, 9–20, 22. doi: 10.1331/JAPhA.2015.15512. PMID: 25749267. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25749267
Hussar DA, Snell CW. Boceprevir, telaprevir, and rilpivirine hydrochloride. J Am Pharm Assoc. 2012;52(1):120–6. doi: 10.1331/JAPhA.2012.12506. PMID: 22257626. Excluded for not a study: letter, editorial, non-systematic review article, no original data.22257626
Ide K, Sato I, Imai T, . Comparison of the safety profiles of pegylated interferon alpha-2a and alpha-2b administered in combination with ribavirin for chronic hepatitis C infection: a real-world retrospective cohort study. Biol Pharm Bull. 2016;39(12):2060–5. doi: 10.1248/bpb.b16-00617. PMID: 27645378. Excluded for ineligible intervention.27645378
Indolfi G, Serranti D, Resti M. Direct-acting antivirals for children and adolescents with chronic hepatitis C. Lancet Child Adolesc Health. 2018;2(4):298–304. doi: 10.1016/s2352-4642(18)30037-3. PMID: 30169301. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.30169301
Ioannou GN, Beste LA, Chang MF, . Effectiveness of sofosbuvir, ledipasvir/sofosbuvir, or paritaprevir/ritonavir/ombitasvir and dasabuvir regimens for treatment of patients with hepatitis C in the veterans affairs national health care system. Gastroenterology. 2016;151(3):457–71.e5. doi: 10.1053/j.gastro.2016.05.049. PMID: 27267053. Excluded for ineligible outcome.27267053
Ioannou GN, Beste LA, Green PK. Similar effectiveness of boceprevir and telaprevir treatment regimens for hepatitis C virus infection on the basis of a nationwide study of veterans. Clin Gastroenterol Hepatol. 2014;12(8):1371–80. doi: 10.1016/j.cgh.2013.12.011. PMID: 24361415. Excluded for ineligible intervention.24361415
Ishikawa T, Higuchi K, Kubota T, . Combination PEG-IFN a-2b/ribavirin therapy following treatment of hepatitis C virus-associated hepatocellular carcinoma is capable of improving hepatic functional reserve and survival. Hepatogastroenterology. 2012;59(114):529–32. doi: 10.5754/hge10867. PMID: 22024226. Excluded for ineligible population.22024226
Islam N, Krajden M, Shoveller J, . Incidence, risk factors, and prevention of hepatitis C reinfection: a population-based cohort study. Lancet Gastroenterol Hepatol. 2017;2(3):200–10. doi: 10.1016/s2468-1253(16)30182-0. PMID: 28404135. Excluded for ineligible intervention.28404135
Ismail WA, Wadea FM. The outcome of combined treatment with ombitasvir-paritaprevir-ritonavir, sofosbuvir with or without ribavirin as salvage therapy for Egyptian HCV experienced patients: a single center study. Drug Discov Ther. 2018;12(6):368–73. doi: 10.5582/ddt.2018.01080. PMID: 30674772. Excluded for ineligible population.30674772
Iwasaki Y, Araki Y, Taniguchi H, . Randomized trial of peginterferon alpha-2b plus low and escalating dose of ribavirin in patients with chronic hepatitis C with high viral load genotype 1. J Med Virol. 2015;87(4):625–33. doi: 10.1002/jmv.24097. PMID: 25611729. Excluded for ineligible intervention.25611729
Iwasaki Y, Okamoto R, Ishii Y, . Randomized trial of low-dose peginterferon alpha-2b plus low and escalating doses of ribavirin in older patients with chronic hepatitis C with high viral load genotype 1. J Med Virol. 2015;87(12):2082–9. doi: 10.1002/jmv.24276. PMID: 26010427. Excluded for ineligible intervention.26010427
Izumi N, Asahina Y, Kurosaki M, . Inhibition of hepatocellular carcinoma by PegIFNalpha-2a in patients with chronic hepatitis C: a nationwide multicenter cooperative study. J Gastroenterol. 2013;48(3):382–90. doi: 10.1007/s00535-012-0641-9. PMID: 22875473. Excluded for ineligible comparator.22875473
Jacobson IM, Brown RS, Jr., Freilich B, . Peginterferon alfa-2b and weight-based or flat-dose ribavirin in chronic hepatitis C patients: a randomized trial. Hepatology. 2007;46(4):971–81. doi: 10.1002/hep.21932. PMID: 17894303. Excluded for outdated medication.17894303
Jacobson IM, Gordon SC, Kowdley KV, . Sofosbuvir for hepatitis C genotype 2 or 3 in patients without treatment options. N Engl J Med. 2013;368(20):1867–77. doi: 10.1056/NEJMoa1214854. PMID: 23607593. Excluded for ineligible intervention.23607593
Jacobson IM, Lawitz E, Gane EJ, . Efficacy of 8 weeks of sofosbuvir, velpatasvir, and voxilaprevir in patients with chronic HCV infection: 2 phase 3 randomized trials. Gastroenterology. 2017;153(1):113–22. doi: 10.1053/j.gastro.2017.03.047. PMID: 28390869. Excluded for ineligible intervention.28390869
Jacobson IM, McHutchison JG, Dusheiko G, . Telaprevir for previously untreated chronic hepatitis C virus infection. N Engl J Med. 2011;364(25):2405–16. doi: 10.1056/NEJMoa1012912. PMID: 21696307. Excluded for inadequate duration.21696307
Jakobsen JC, Nielsen EE, Feinberg J, . Direct-acting antivirals for chronic hepatitis C. Cochrane Database Syst Rev. 2017;6:CD012143. doi: 10.1002/14651858.CD012143.pub3. PMID: 28585310. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.28585310
Jensen CM, Holle LM. Ledipasvir-sofosbuvir: a once-daily oral treatment option for chronic hepatitis C virus genotype 1 infection. Pharmacotherapy. 2016;36(5):562–74. doi: 10.1002/phar.1748. PMID: 27027412. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27027412
Jensen DM, Asselah T, Dieterich D, . Faldaprevir, pegylated interferon, and ribavirin for treatment-naive HCV genotype-1: pooled analysis of two phase 3 trials. Ann Hepatol. 2016;15(3):333–49. doi: 10.5604/16652681.1198803. PMID: 27049487. Excluded for ineligible intervention.27049487
Jhaveri M, Procaccini N, Kowdley KV. Update on hepatitis C treatment: systematic review of clinical trials. Minerva Gastroenterol Dietol. 2017;63(1):62–73. doi: 10.23736/S1121-421X.16.02345-X. PMID: 27768010. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27768010
Jhaveri R, Hashem M, El-Kamary SS, . Hepatitis C virus (HCV) vertical transmission in 12-month-old infants born to HCV-infected women and assessment of maternal risk factors. Open Forum Infect Dis. 2015;2(2):ofv089. doi: 10.1093/ofid/ofv089. PMID: 26180831. Excluded for insufficient statistical analysis.26180831
Kaishima T, Akita T, Ohisa M, . Cost-effectiveness analyses of anti-hepatitis C virus treatments using quality of life scoring among patients with chronic liver disease in Hiroshima prefecture, Japan. Hepatol Res. 2018;48(7):509–20. doi: 10.1111/hepr.13053. PMID: 29316059. Excluded for ineligible intervention.29316059
Kalafateli M, Buzzetti E, Thorburn D, . Pharmacological interventions for acute hepatitis C infection. Cochrane Database Syst Rev. 2017 (4)doi: 10.1002/14651858.CD011644.pub2. PMID: 28285495. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.28285495
Kallman J, O’Neil MM, Larive B, . Fatigue and health-related quality of life (HRQL) in chronic hepatitis C virus infection. Dig Dis Sci. 2007;52(10):2531–9. doi: 10.1007/s10620-006-9708-x. PMID: 17406828. Excluded for ineligible study design for Key Question.17406828
Kamal SM, Ahmed A, Mahmoud S, . Enhanced efficacy of pegylated interferon alpha-2a over pegylated interferon and ribavirin in chronic hepatitis C genotype 4A randomized trial and quality of life analysis. Liver Int. 2011;31(3):401–11. doi: 10.1111/j.1478-3231.2010.02435.x. PMID: 21281434. Excluded for ineligible intervention.21281434
Kaneko R, Nakazaki N, Omori R, . Efficacy of direct-acting antiviral treatment for chronic hepatitis C: a single hospital experience. World J Hepatol. 2018;10(1):88–94. doi: 10.4254/wjh.v10.i1.88. PMID: 29399282. Excluded for ineligible study design for Key Question.29399282
Kanogawa N, Ogasawara S, Chiba T, . Sustained virologic response achieved after curative treatment of hepatitis C virus-related hepatocellular carcinoma as an independent prognostic factor. J Gastroenterol Hepatol. 2015;30(7):1197–204. doi: 10.1111/jgh.12925. PMID: 25682720. Excluded for ineligible intervention.25682720
Kashiwagi K, Kubo N, Nakashima H, . A prospective comparison of the effect of interferon-alpha and interferon-beta treatment in patients with chronic hepatitis C on the incidence of hepatocellular carcinoma development. J Infect Chemother. 2003;9(4):333–40. doi: 10.1007/s10156-003-0271-5. PMID: 14691655. Excluded for insufficient statistical analysis.14691655
Kattakuzhy S, Gross C, Emmanuel B, . Expansion of treatment for hepatitis C virus infection by task shifting to community-based nonspecialist providers: a nonrandomized clinical trial. Ann Intern Med. 2017;167(5):311–8. doi: 10.7326/M17-0118. PMID: 28785771. Excluded for ineligible population.28785771
Kattakuzhy S, Wilson E, Sidharthan S, . Moderate sustained virologic response rates with 6-week combination directly acting anti-hepatitis C virus therapy in patients with advanced liver disease. Clin Infect Dis. 2016;62(4):440–7. doi: 10.1093/cid/civ897. PMID: 26503379. Excluded for ineligible intervention.26503379
Kawakubo M, Eguchi Y, Okada M, . Chronic hepatitis C treatment with daclatasvir plus asunaprevir does not lead to a decreased quality of life. Intern Med. 2018;57(14):1959–66. doi: 10.2169/internalmedicine.0091-17. PMID: 29526929. Excluded for ineligible intervention.29526929
Kawamura Y, Arase Y, Ikeda K, . Diabetes enhances hepatocarcinogenesis in noncirrhotic, interferon-treated hepatitis C patients. Am J Med. 2010;123(10):951–6.e1. doi: 10.1016/j.amjmed.2010.05.013. PMID: 20920698. Excluded for ineligible comparator.20920698
Kawaoka T, Kawakami Y, Tsuji K, . Dose comparison study of pegylated interferon-alpha-2b plus ribavirin in naive Japanese patients with hepatitis C virus genotype 2: a randomized clinical trial. J Gastroenterol Hepatol. 2009;24(3):366–71. doi: 10.1111/j.1440-1746.2008.05650.x. PMID: 19032459. Excluded for outdated medication.19032459
Keating GM. Ombitasvir/paritaprevir/ritonavir: a review in chronic HCV genotype 4 infection. Drugs. 2016;76(12):1203–11. doi: 10.1007/s40265-016-0612-1. PMID: 27401997. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27401997
Khan AQ, Awan A, Shahbuddin S, . Peginterferon alfa 2a/ribavirin versus peginterferon alfa 2b/ribavirin combination therapy in chronic hepatitis C genotype 3. Gastroenterology. 2007;132(4):A200–A. Excluded for outdated medication.
Khatri A, Menon RM, Marbury TC, . Pharmacokinetics and safety of co-administered paritaprevir plus ritonavir, ombitasvir, and dasabuvir in hepatic impairment. J Hepatol. 2015;63(4):805–12. doi: 10.1016/j.jhep.2015.05.029. PMID: 26070406. Excluded for ineligible outcome.26070406
Khatri A, Mensing S, Podsadecki T, . Exposure-efficacy analyses of ombitasvir, paritaprevir/ritonavir with dasabuvir +/- ribavirin in HCV genotype 1-infected patients. Clin Drug Investig. 2016;36(8):625–35. doi: 10.1007/s40261-016-0407-x. PMID: 27153823. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.27153823
Khokhar N, Niazi TK, Qureshi MO. Hepatocellular carcinoma after sustained viral response to interferon and ribavirin therapy in cirrhosis secondary to chronic hepatitis C. J Coll Physicians Surg Pak. 2013;23(10):699–702. doi: 10.2013/JCPSP.699702. PMID: 24112253. Excluded for ineligible comparator.24112253
Kimer N, Dahl EK, Gluud LL, . Antiviral therapy for prevention of hepatocellular carcinoma in chronic hepatitis C: systematic review and meta-analysis of randomised controlled trials. BMJ Open. 2012;2(5):e001313. doi: 10.1136/bmjopen-2012-001313. PMID: 23089208. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.23089208
Klibanov OM, Gale SE, Santevecchi B. Ombitasvir/paritaprevir/ritonavir and dasabuvir tablets for hepatitis C virus genotype 1 infection. Ann Pharmacother. 2015;49(5):566–81. doi: 10.1177/1060028015570729. PMID: 25680759. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.25680759
Kobayashi M, Suzuki F, Fujiyama S, . Sustained virologic response by direct antiviral agents reduces the incidence of hepatocellular carcinoma in patients with HCV infection. J Med Virol. 2017;89(3):476–83. doi: 10.1002/jmv.24663. PMID: 27531586. Excluded for ineligible population.27531586
Koff RS. Review article: the efficacy and safety of sofosbuvir, a novel, oral nucleotide NS5B polymerase inhibitor, in the treatment of chronic hepatitis C virus infection. Aliment Pharmacol Ther. 2014;39(5):478–87. doi: 10.1111/apt.12601. PMID: 24387618. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.24387618
Koh C, Heller T, Haynes-Williams V, . Long-term outcome of chronic hepatitis C after sustained virological response to interferon-based therapy. Aliment Pharmacol Ther. 2013;37(9):887–94. doi: 10.1111/apt.12273. PMID: 23461575. Excluded for ineligible outcome.23461575
Kohli A, Kapoor R, Sims Z, . Ledipasvir and sofosbuvir for hepatitis C genotype 4: a proof-of-concept, single-centre, open-label phase 2a cohort study. Lancet Infect Dis. 2015;15(9):1049–54. doi: 10.1016/S1473-3099(15)00157-7. PMID: 26187031. Excluded for ineligible population.26187031
Kohli A, Kattakuzhy S, Sidharthan S, . Four-week direct-acting antiviral regimens in noncirrhotic patients with hepatitis C virus genotype 1 infection: An open-label, nonrandomized trial. Ann Intern Med. 2015;163(12):899–907. doi: 10.7326/M15-0642. PMID: 26595450. Excluded for ineligible intervention.26595450
Kohli A, Osinusi A, Sims Z, . Virological response after 6 week triple-drug regimens for hepatitis C: a proof-of-concept phase 2A cohort study. Lancet. 2015;385(9973):1107–13. doi: 10.1016/S0140-6736(14)61228-9. PMID: 25591505. Excluded for ineligible study design for Key Question.25591505
Komatsu TE, Boyd S, Sherwat A, . Regulatory analysis of effects of hepatitis C virus NS5A polymorphisms on efficacy of elbasvir and grazoprevir. Gastroenterology. 2017;152(3):586–97. doi: 10.1053/j.gastro.2016.10.017. PMID: 27773808. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27773808
Kowdley KV, Nelson DR, Lalezari JP, . On-treatment HCV RNA as a predictor of sustained virological response in HCV genotype 3-infected patients treated with daclatasvir and sofosbuvir. Liver Int. 2016;36(11):1611–8. doi: 10.1111/liv.13165. PMID: 27188960. Excluded for ineligible population.27188960
Krans EE, Zickmund SL, Rustgi VK, . Screening and evaluation of hepatitis C virus infection in pregnant women on opioid maintenance therapy: a retrospective cohort study. Subst Abus. 2016;37(1):88–95. doi: 10.1080/08897077.2015.1118720. PMID: 26569631. Excluded for ineligible outcome.26569631
Krawitt EL, Gordon SR, Grace ND, . A study of low dose peginterferon alpha-2b with ribavirin for the initial treatment of chronic hepatitis C. Am J Gastroenterol. 2006;101(6):1268–73. doi: 10.1111/j.1572-0241.2006.00614.x. PMID: 16771948. Excluded for outdated medication.16771948
Krishnan P, Tripathi R, Schnell G, . Resistance analysis of baseline and treatment-emergent variants in hepatitis C virus genotype 1 in the AVIATOR study with paritaprevir-ritonavir, ombitasvir, and dasabuvir. Antimicrob Agents Chemother. 2015;59(9):5445–54. PMID: 26100711. Excluded for ineligible outcome.26100711
Kronfli N, Bhatnagar SR, Hull MW, . Trends in cause-specific mortality in HIV-hepatitis C co-infection following hepatitis C treatment scale-up. AIDS. 2019 doi: 10.1097/qad.0000000000002156. PMID: 30649045. Excluded for ineligible population.
Kumada H, Toyota J, Okanoue T, . Telaprevir with peginterferon and ribavirin for treatment-naive patients chronically infected with HCV of genotype 1 in Japan. J Hepatol. 2012;56(1):78–84. doi: 10.1016/j.jhep.2011.07.016. PMID: 21827730. Excluded for outdated medication.21827730
Kunimoto H, Ikeda K, Sorin Y, . Long-term outcomes of hepatitis-C-infected patients achieving a sustained virological response and undergoing raadical treatment for hepatocellular carcinoma. Oncology. 2016;90(3):167–75. doi: 10.1159/000443891. PMID: 26901157. Excluded for ineligible population.26901157
Kwo P, Gane EJ, Peng CY, . Effectiveness of elbasvir and grazoprevir combination, with or without ribavirin, for treatment-experienced patients with chronic hepatitis C Infection. Gastroenterology. 2017;152(1):164–75.e4. doi: 10.1053/j.gastro.2016.09.045. PMID: 27720838. Excluded for ineligible population.27720838
Kwo PY, Lawitz EJ, McCone J, . Efficacy of boceprevir, an NS3 protease inhibitor, in combination with peginterferon alfa-2b and ribavirin in treatment-naive patients with genotype 1 hepatitis C infection (SPRINT-1): an open-label, randomised, multicentre phase 2 trial. Lancet. 2010;376(9742):705–16. doi: 10.1016/s0140-6736(10)60934-8. PMID: 20692693. Excluded for outdated medication.20692693
Kwo PY, Poordad F, Asatryan A, . Glecaprevir and pibrentasvir yield high response rates in patients with HCV genotype 1-6 without cirrhosis. J Hepatol. 2017;67(2):263–71. PMID: 28412293. Excluded for ineligible study design for Key Question.28412293
La Torre A, Biadaioli R, Capobianco T, . Vertical transmission of HCV. Acta Obstet Gynecol Scand. 1998;77(9):889–92. PMID: 9808375. Excluded for poor quality.9808375
Lagasca AM, Kan VL. Hepatitis C treatment at a veterans affairs medical center after the availability of direct-acting agents: things are looking up. Clin Infect Dis. 2015;61(8):1347–9. doi: 10.1093/cid/civ573. PMID: 26187023. Excluded for ineligible outcome.26187023
Lagging M, Langeland N, Pedersen C, . Randomized comparison of 12 or 24 weeks of peginterferon alpha-2a and ribavirin in chronic hepatitis C virus genotype 2/3 infection. Hepatology. 2008;47(6):1837–45. doi: 10.1002/hep.22253. PMID: 18454508. Excluded for outdated medication.18454508
Lam JT, Jacob S. Boceprevir: a recently approved protease inhibitor for hepatitis C virus infection. Am J Health Syst Pharm. 2012;69(24):2135–9. doi: 10.2146/ajhp110500. PMID: 23230035. Excluded for not a study: letter, editorial, non-systematic review article, no original data.23230035
Lanini S, Mammone A, Puro V, . Triple therapy for hepatitis C improves viral response but also increases the risk of severe infections and anaemia: a frequentist meta-analysis approach. New Microbiol. 2014;37(3):263–76. PMID: 25180842. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.25180842
Lavitas P, Tesell M, Hydery T, . Overview of comprehensive hepatitis C virus medication management in a state medicaid program. J Manag Care Spec Pharm. 2016;22(10):1161–6. doi: 10.18553/jmcp.2016.22.10.1161. PMID: 27668564. Excluded for ineligible outcome.27668564
Lawitz E, Gane E, Pearlman B, . Efficacy and safety of 12 weeks versus 18 weeks of treatment with grazoprevir (MK-5172) and elbasvir (MK-8742) with or without ribavirin for hepatitis C virus genotype 1 infection in previously untreated patients with cirrhosis and patients with previous null response with or without cirrhosis (C-WORTHY): a randomised, open-label phase 2 trial. Lancet. 2015;385(9973):1075–86. doi: 10.1016/S0140-6736(14)61795-5. PMID: 25467591. Excluded for ineligible population.25467591
Lawitz E, Mangia A, Wyles D, . Sofosbuvir for previously untreated chronic hepatitis C infection. N Engl J Med. 2013;368(20):1878–87. doi: 10.1056/NEJMoa1214853. PMID: 23607594. Excluded for ineligible intervention.23607594
Lawitz E, Poordad F, Gutierrez JA, . Short-duration treatment with elbasvir/grazoprevir and sofosbuvir for hepatitis C: a randomized trial. Hepatology. 2017;65(2):439–50. doi: 10.1002/hep.28877. PMID: 27770561. Excluded for ineligible intervention.27770561
Lawitz E, Poordad F, Kowdley KV, . A phase 2a trial of 12-week interferon-free therapy with two direct-acting antivirals (ABT-450/r, ABT-072) and ribavirin in IL28B C/C patients with chronic hepatitis C genotype 1. J Hepatol. 2013;59(1):18–23. doi: 10.1016/j.jhep.2013.02.009. PMID: 23439262. Excluded for ineligible intervention.23439262
Lawitz E, Poordad F, Wells J, . Sofosbuvir-velpatasvir-voxilaprevir with or without ribavirin in direct-acting antiviral-experienced patients with genotype 1 hepatitis C virus. Hepatology. 2017;65(6):1803–9. doi: 10.1002/hep.29130. PMID: 28220512. Excluded for ineligible intervention.28220512
Lawitz E, Reau N, Hinestrosa F, . Efficacy of sofosbuvir, velpatasvir, and GS-9857 in patients with genotype 1 hepatitis C virus infection in an open-label, phase 2 trial. Gastroenterology. 2016;151(5):893–901.e1. doi: 10.1053/j.gastro.2016.07.039. PMID: 27486034. Excluded for ineligible intervention.27486034
Lawitz E, Sullivan G, Rodriguez-Torres M, . Exploratory trial of ombitasvir and ABT-450/r with or without ribavirin for HCV genotype 1, 2, and 3 infection. J Infect. 2015;70(2):197–205. doi: 10.1016/j.jinf.2014.09.008. PMID: 25246359. Excluded for ineligible intervention.25246359
Lee SS, Jeong SH, Jang ES, . Prospective cohort study on the outcomes of hepatitis C virus-related cirrhosis in South Korea. J Gastroenterol Hepatol. 2015;30(8):1281–7. doi: 10.1111/jgh.12950. PMID: 25778783. Excluded for ineligible population.25778783
Lee SS, Roberts SK, Berak H, . Safety of peginterferon alfa-2a plus ribavirin in a large multinational cohort of chronic hepatitis C patients. Liver Int. 2012;32(8):1270–7. doi: 10.1111/j.1478-3231.2012.02819.x. PMID: 22621707. Excluded for ineligible intervention.22621707
Lens S, Calleja JL, Campillo A, . Aplastic anemia and severe pancytopenia during treatment with peg-interferon, ribavirin and telaprevir for chronic hepatitis C. World J Gastroenterol. 2015;21(17):5421–6. doi: 10.3748/wjg.v21.i17.5421. PMID: 25954117. Excluded for ineligible population.25954117
Lens S, Torres F, Puigvehi M, . Predicting the development of liver cirrhosis by simple modelling in patients with chronic hepatitis C. Aliment Pharmacol Ther. 2016;43(3):364–74. doi: 10.1111/apt.13472. PMID: 26582599. Excluded for ineligible study design for Key Question.26582599
Leventer-Roberts M, Hammerman A, Brufman I, . Effectiveness of dasabuvir/ombitasvir/paritaprevir/ritonavir for hepatitis C virus in clinical practice: a population-based observational study. PLoS One. 2017;12(7):e0176858. doi: 10.1371/journal.pone.0176858. PMID: 28686590. Excluded for ineligible intervention.28686590
Li J, Gordon SC, Rupp LB, . Sustained virological response to hepatitis C treatment decreases the incidence of complications associated with type 2 diabetes. Aliment Pharmacol Ther. 2019;49(5):599–608. doi: 10.1111/apt.15102. PMID: 30650468. Excluded for ineligible population.30650468
Lin CW, Menon R, Liu W, . Exposure-safety response relationship for ombitasvir, paritaprevir/ritonavir, dasabuvir, and ribavirin in patients with chronic hepatitis C virus genotype 1 infection: analysis of data from five phase II and six phase III studies. Clin Drug Investig. 2017 doi: 10.1007/s40261-017-0520-5. PMID: 28378135. Excluded for not a study: letter, editorial, non-systematic review article, no original data.28378135
Lin HH, Kao JH, Hsu HY, . Absence of infection in breast-fed infants born to hepatitis C virus-infected mothers. J Pediatr. 1995;126(4):589–91. PMID: 7535353. Excluded for poor quality.7535353
Linas BP, Hu H, Barter DM, . Hepatitis C screening trends in a large integrated health system. Am J Med. 2014;127(5):398–405. doi: 10.1016/j.amjmed.2014.01.012. PMID: 24486288. Excluded for ineligible outcome.24486288
Litwin AH, Smith BD, Drainoni ML, . Primary care-based interventions are associated with increases in hepatitis C virus testing for patients at risk. Dig Liver Dis. 2012;44(6):497–503. doi: 10.1016/j.dld.2011.12.014. PMID: 22342471. Excluded for ineligible outcome.22342471
Liu CH, Huang YJ, Yang SS, . Generic sofosbuvir-based interferon-free direct acting antiviral agents for patients with chronic hepatitis C virus infection: a real-world multicenter observational study. Scientific Reports. 2018;8(1):13699. doi: 10.1038/s41598-018-32060-7. PMID: 30209349. Excluded for ineligible study design for Key Question.30209349
Liu CH, Liu CJ, Su TH, . Real-world effectiveness and safety of sofosbuvir and ledipasvir with or without ribavirin for patients with hepatitis C virus genotype 1 infection in Taiwan. PLoS One. 2018;13(12):e0209299. doi: 10.1371/journal.pone.0209299. PMID: 30576344. Excluded for ineligible study design for Key Question.30576344
Liu CH, Su TH, Liu CJ, . Sofosbuvir-based direct acting antiviral therapies for patients with hepatitis C virus genotype 2 infection. J Gastroenterol Hepatol. 2019;29:29. doi: 10.1111/jgh.14615. PMID: 30693965. Excluded for ineligible study design for Key Question.30693965
Liu CJ, Chuang WL, Sheen IS, . Efficacy of ledipasvir and sofosbuvir treatment of HCV infection in patients coinfected with HBV. Gastroenterology. 2018;154(4):989–97. doi: 10.1053/j.gastro.2017.11.011. PMID: 29174546. Excluded for ineligible outcome.29174546
Liu Y, Wang Z, Tobe RG, . Cost effectiveness of daclatasvir plus asunaprevir therapy for Chinese patients with chronic hepatitis C virus genotype 1b. Clin Drug Investig. 2018;38(5):427–37. doi: 10.1007/s40261-018-0621-9. PMID: 29417464. Excluded for ineligible intervention.29417464
Lok AS, Everhart JE, Wright EC, . Maintenance peginterferon therapy and other factors associated with hepatocellular carcinoma in patients with advanced hepatitis C. Gastroenterology. 2011;140(3):840–9; quiz e12. doi: 10.1053/j.gastro.2010.11.050. PMID: 21129375. Excluded for ineligible intervention.21129375
Louie V, Latt NL, Gharibian D, . Real-world experiences with a direct-acting antiviral agent for patients with hepatitis C virus infection. Perm J. 2017;21doi: 10.7812/TPP/16-096. PMID: 28368787. Excluded for not a study: letter, editorial, non-systematic review article, no original data.28368787
Loustaud-Ratti V, Maynard M, Thevenon S, . Efficiency and safety of an early dose adjustment of ribavirin in patients infected with hepatitis c underexposed to the drug and treated with peginterferon ribavirin. Ther Drug Monit. 2016;38(6):684–92. doi: 10.1097/FTD.0000000000000332. PMID: 27559840. Excluded for ineligible intervention.27559840
Lu M, Li J, Zhang T, . Serum biomarkers indicate long-term reduction in liver fibrosis in patients with sustained virological response to treatment for HCV infection. Clin Gastroenterol Hepatol. 2016;14(7):1044–55.e3. doi: 10.1016/j.cgh.2016.01.009. PMID: 26804385. Excluded for ineligible outcome.26804385
Lucejko M, Parfieniuk-Kowerda A, Flisiak R. Ombitasvir/paritaprevir/ritonavir plus dasabuvir combination in the treatment of chronic HCV infection. Expert Opin Pharmacother. 2016;17(8):1153–64. doi: 10.1080/14656566.2016.1176143. PMID: 27064432. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27064432
Lyons MS, Kunnathur VA, Rouster SD, . Prevalence of diagnosed and undiagnosed hepatitis C in a Midwestern urban emergency department. Clin Infect Dis. 2016;62(9):1066–71. doi: 10.1093/cid/ciw073. PMID: 26908799. Excluded for ineligible outcome.26908799
Maan R, Al Marzooqi SH, Klair JS, . The frequency of acute kidney injury in patients with chronic hepatitis C virus infection treated with sofosbuvir-based regimens. Aliment Pharmacol Ther. 2017 (pagination)doi: 10.1111/apt.14117. PMID: 28470850. Excluded for ineligible intervention.28470850
Maan R, van der Meer AJ, Hansen BE, . Risk of infections during interferon-based treatment in patients with chronic hepatitis C virus infection and advanced hepatic fibrosis. J Gastroenterol Hepatol. 2015;30(6):1057–64. doi: 10.1111/jgh.12929. PMID: 25682797. Excluded for ineligible intervention.25682797
Mach TH, Ciesla A, Warunek W, . Efficacy of pegylated interferon alfa-2a or alfa-2b in combination with ribavirin in the treatment of chronic hepatitis caused by hepatitis C virus genotype 1b. Pol Arch Med Wewn. 2011;121(12):434–9. PMID: 22157768. Excluded for outdated medication.22157768
Macias J, Rivero A, Cifuentes C, . Sustained virological response to pegylated interferon plus ribavirin leads to normalization of liver stiffness in hepatitis C virus-infected patients. Enferm Infecc Microbiol Clin. 2013;31(7):424–9. doi: 10.1016/j.eimc.2012.12.004. PMID: 23453582. Excluded for ineligible population.23453582
Magni C, Niero F, Argenteri B, . Antiviral activity and tolerability between pegylated interferon Alpha-2a and Alpha-2b in naÏve patients with chronic hepatitis C: results of a prospective monocentric randomized trial: 883. Hepatology. 2009;50:720A. Excluded for outdated medication.
Mangia A, Santoro R, Minerva N, . Peginterferon alfa-2b and ribavirin for 12 vs. 24 weeks in HCV genotype 2 or 3. N Engl J Med. 2005;352(25):2609–17. doi: 10.1056/NEJMoa042608. PMID: 15972867. Excluded for outdated medication.15972867
Manns M, Zeuzem S, Sood A, . Reduced dose and duration of peginterferon alfa-2b and weight-based ribavirin in patients with genotype 2 and 3 chronic hepatitis C. J Hepatol. 2011;55(3):554–63. doi: 10.1016/j.jhep.2010.12.024. PMID: 21237227. Excluded for outdated medication.21237227
Manns MP, Fried MW, Zeuzem S, . Simeprevir with peginterferon/ribavirin for treatment of chronic hepatitis C virus genotype 1 infection: pooled safety analysis from phase IIb and III studies. J Viral Hepat. 2015;22(4):366–75. doi: 10.1111/jvh.12346. PMID: 25363449. Excluded for ineligible outcome.25363449
Manns MP, McCone J, Jr., Davis MN, . Overall safety profile of boceprevir plus peginterferon alfa-2b and ribavirin in patients with chronic hepatitis C genotype 1: a combined analysis of 3 phase 2/3 clinical trials. Liver Int. 2014;34(5):707–19. doi: 10.1111/liv.12300. PMID: 24118703. Excluded for ineligible intervention.24118703
Manns MP, McHutchison JG, Gordon SC, . Peginterferon alfa-2b plus ribavirin compared with interferon alfa-2b plus ribavirin for initial treatment of chronic hepatitis C: a randomised trial. Lancet. 2001;358(9286):958–65. PMID: 11583749. Excluded for outdated medication.11583749
Marcellin P, Forns X, Goeser T, . Telaprevir is effective given every 8 or 12 hours with ribavirin and peginterferon alfa-2a or -2b to patients with chronic hepatitis C. Gastroenterology. 2011;140(2):459–68.e1; quiz e14. doi: 10.1053/j.gastro.2010.10.046. PMID: 21034744. Excluded for outdated medication.21034744
Marcus JL, Hurley LB, Chamberland S, . No difference in effectiveness of 8 vs 12 weeks of ledipasvir and sofosbuvir for treatment of hepatitis C in black patients. Clin Gastroenterol Hepatol. 2018;16(6):927–35. doi: 10.1016/j.cgh.2018.03.003. PMID: 29535057. Excluded for ineligible study design for Key Question.29535057
Martinello M, Bhagani S, Gane E, . Shortened therapy of eight weeks with paritaprevir/ritonavir/ombitasvir and dasabuvir is highly effective in people with recent HCV genotype 1 infection. J Viral Hepat. 2018;25(10):1180–8. doi: 10.1111/jvh.12917. PMID: 29660224. Excluded for ineligible intervention.29660224
Martinez SM, Foucher J, Combis JM, . Longitudinal liver stiffness assessment in patients with chronic hepatitis C undergoing antiviral therapy. PLoS One. 2012;7(10):e47715. doi: 10.1371/journal.pone.0047715. PMID: 23082200. Excluded for ineligible outcome.23082200
Martinez-Macias RF, Cordero-Perez P, Juarez-Rodriguez OA, . Interferon-based therapy delays but metabolic comorbidity accelerates progression of chronic hepatitis C. Ann Hepatol. 2015;14(1):36–45. PMID: 25536640. Excluded for poor quality.25536640
Masip M, Tuneu L, Pages N, . Prevalence and detection of neuropsychiatric adverse effects during hepatitis C treatment. Int J Clin Pharm. 2015;37(6):1143–51. doi: 10.1007/s11096-015-0177-1. PMID: 26267215. Excluded for ineligible intervention.26267215
Matsumoto N, Ikeda H, Shigefuku R, . Hemoglobin decrease with iron deficiency induced by daclatasvir plus asunaprevir combination therapy for chronic hepatitis C virus genotype 1b. PLoS One. 2016;11(3):e0151238. doi: 10.1371/journal.pone.0151238. PMID: 26990758. Excluded for ineligible intervention.26990758
Mauss S, Klinker H. Drug-drug interactions in the treatment of HCV among people who inject drugs. Clin Infect Dis. 2013;57: Suppl 2:S125–8. doi: 10.1093/cid/cit299. PMID: 23884060. Excluded for ineligible intervention.23884060
Mazzarelli C, Considine A, Childs K, . Efficacy and tolerability of direct-acting antivirals for hepatitis C in older adults. J Am Geriatr Soc. 2018;66(7):1339–45. doi: 10.1111/jgs.15392. PMID: 29799112. Excluded for ineligible study design for Key Question.29799112
McCombs J, Matsuda T, Tonnu-Mihara I, . The risk of long-term morbidity and mortality in patients with chronic hepatitis C: results from an analysis of data from a Department of Veterans Affairs clinical registry. JAMA Intern Med. 2014;174(2):204–12. doi: 10.1001/jamainternmed.2013.12505. PMID: 24193887. Excluded for ineligible population.24193887
McConachie SM, Wilhelm SM, Kale-Pradhan PB. New direct-acting antivirals in hepatitis C therapy: a review of sofosbuvir, ledipasvir, daclatasvir, simeprevir, paritaprevir, ombitasvir and dasabuvir. Expert Rev Clin Pharmacol. 2016;9(2):287–302. doi: 10.1586/17512433.2016.1129272. PMID: 26651915. Excluded for ineligible study design for Key Question.26651915
McCormack PL. Daclatasvir: a review of its use in adult patients with chronic hepatitis C virus infection. Drugs. 2015;75(5):515–24. doi: 10.1007/s40265-015-0362-5. PMID: 25721433. Excluded for ineligible study design for Key Question.25721433
McDonald SA, Innes HA, Hayes PC, . What is the impact of a country-wide scale-up in antiviral therapy on the characteristics and sustained viral response rates of patients treated for hepatitis C? J Hepatol. 2015;62(2):262–8. doi: 10.1016/j.jhep.2014.08.046. PMID: 25195556. Excluded for ineligible intervention.25195556
McEwan P, Ward T, Yuan Y, . The impact of timing and prioritization on the cost-effectiveness of birth cohort testing and treatment for hepatitis C virus in the United States. Hepatology. 2013;58(1):54–64. doi: 10.1002/hep.26304. PMID: 23389841. Excluded for ineligible study design for Key Question.23389841
McGinn T, O’Connor-Moore N, Alfandre D, . Validation of a hepatitis C screening tool in primary care. Arch Intern Med. 2008;168(18):2009–13. doi: 10.1001/archinte.168.18.2009. PMID: 18852403. Excluded for poor quality.18852403
McHutchison J, Manns M, Harvey J, . Adherence to therapy enhances sustained response in chronic hepatitis C patients receiving PEG-interferon alfa-2b plus ribavirin. J Hepatol. 2001;34:2–3. Excluded for ineligible intervention.
McHutchison J, Sulkowski M. Scientific rationale and study design of the individualized dosing efficacy vs flat dosing to assess optimal pegylated interferon therapy (IDEAL) trial: determining optimal dosing in patients with genotype 1 chronic hepatitis C. J Viral Hepat. 2008;15(7):475–81. doi: 10.1111/j.1365-2893.2008.00973.x. PMID: 18363672. Excluded for outdated medication.18363672
McHutchison JG, Everson GT, Gordon SC, . Telaprevir with peginterferon and ribavirin for chronic HCV genotype 1 infection. N Engl J Med. 2009;360(18):1827–38. doi: 10.1056/NEJMoa0806104. PMID: 19403902. Excluded for outdated medication.19403902
McHutchison JG, Lawitz EJ, Shiffman ML, . Peginterferon alfa-2b or alfa-2a with ribavirin for treatment of hepatitis C infection. N Engl J Med. 2009;361(6):580–93. doi: 10.1056/NEJMoa0808010. PMID: 19625712. Excluded for inadequate duration.19625712
McIntyre PG, Tosh K, McGuire W. Caesarean section versus vaginal delivery for preventing mother to infant hepatitis C virus transmission. Cochrane Database Syst Rev. 2010 (6) PMID: 17054264. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.17054264
McMenamin MB, Jackson AD, Lambert J, . Obstetric management of hepatitis C-positive mothers: analysis of vertical transmission in 559 mother-infant pairs. Am J Obstet Gynecol. 2008;199(3):315.e1–5. doi: 10.1016/j.ajog.2008.05.021. PMID: 18771997. Excluded for insufficient statistical analysis.18771997
McPhee F, Suzuki Y, Toyota J, . High sustained virologic response to daclatasvir plus asunaprevir in elderly and cirrhotic patients with hepatitis C virus genotype 1b without baseline NS5A polymorphisms. Adv Ther. 2015;32(7):637–49. doi: 10.1007/s12325-015-0221-5. PMID: 26155891. Excluded for ineligible intervention.26155891
Mecenate F, Pellicelli AM, Barbaro G, . Short versus standard treatment with pegylated interferon alfa-2A plus ribavirin in patients with hepatitis C virus genotype 2 or 3: the cleo trial. BMC Gastroenterol. 2010;10:21. doi: 10.1186/1471-230x-10-21. PMID: 20170514. Excluded for outdated medication.20170514
Merchant RC, Baird JR, Liu T, . Brief intervention to increase emergency department uptake of combined rapid human immunodeficiency virus and hepatitis C screening among a drug misusing population. Acad Emerg Med. 2014;21(7):752–67. doi: 10.1111/acem.12419. PMID: 25125271. Excluded for ineligible outcome.25125271
Messori A, Badiani B, Trippoli S. Achieving sustained virological response in hepatitis C reduces the long-term risk of hepatocellular carcinoma: an updated meta-analysis employing relative and absolute outcome measures. Clin Drug Investig. 2015;35(12):843–50. doi: 10.1007/s40261-015-0338-y. PMID: 26446006. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26446006
Messori A, Fadda V, Maratea D, . Pegylated interferon-alpha2a versus pegylated interferon-alpha2b in hepatitis C: reappraisal of effectiveness on the basis of trial sequential analysis. Eur J Gastroenterol Hepatol. 2014;26(2):246–8. doi: 10.1097/MEG.0b013e3283657e20. PMID: 24366456. Excluded for ineligible intervention.24366456
Mettikanont P, Bunchorntavakul C, Reddy KR. Systematic review: epidemiology and response to direct-acting antiviral therapy in genotype 6 chronic hepatic C virus (HCV). Aliment Pharmacol Ther. 2019;27:27. doi: 10.1111/apt.15100. PMID: 30687952. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.30687952
Meyer-Wyss B, Rich P, Egger H, . Comparison of two PEG-interferon alpha-2b doses (1.0 or 1.5 microg/kg) combined with ribavirin in interferon-naive patients with chronic hepatitis C and up to moderate fibrosis. J Viral Hepat. 2006;13(7):457–65. doi: 10.1111/j.1365-2893.2005.00709.x. PMID: 16792539. Excluded for outdated medication.16792539
Michielsen P, Ho E, Francque S. Does antiviral therapy reduce the risk of hepatocellular carcinoma in patients with chronic hepatitis C? Minerva Gastroenterol Dietol. 2012;58(1):65–79. PMID: 22419005. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.22419005
Midgard H, Bjoro B, Maeland A, . Hepatitis C reinfection after sustained virological response. J Hepatol. 2016;64(5):1020–6. doi: 10.1016/j.jhep.2016.01.001. PMID: 26780289. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26780289
Mihaila RG. Hepatitis C virus - associated B cell non-Hodgkin’s lymphoma. World J Gastroenterol. 2016;22(27):6214–23. doi: 10.3748/wjg.v22.i27.6214. PMID: 27468211. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27468211
Miller ER, McNally S, Wallace J, . The ongoing impacts of hepatitis C-a systematic narrative review of the literature. BMC Public Health. 2012;12:672. doi: 10.1186/1471-2458-12-672. PMID: 22900973. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.22900973
Miller MH, Dillon JF. Early diagnosis improves outcomes in hepatitis C. Practitioner. 2015;259(1787):25–7, 3. PMID: 26753270. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26753270
Mimidis K, Papadopoulos VP, Elefsiniotis I, . Hepatitis C virus survival curve analysis in naive patients treated with peginterferon alpha-2b plus ribavirin. A randomized controlled trial for induction with high doses of peginterferon and predictability of sustained viral response from early virologic data. J Gastrointestin Liver Dis. 2006;15(3):213–9. PMID: 17013444. Excluded for outdated medication.17013444
Minaei AA, Kowdley KV. ABT-450/ ritonavir and ABT-267 in combination with ABT-333 for the treatment of hepatitis C virus. Expert Opin Pharmacother. 2015;16(6):929–37. doi: 10.1517/14656566.2015.1024653. PMID: 25800085. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.25800085
Minola E, Maccabruni A, Pacati I, . Amniocentesis as a possible risk factor for mother-to-infant transmission of hepatitis C virus. Hepatology. 2001;33(5):1341–2. doi: 10.1053/jhep.2001.0103305le02. PMID: 11343269. Excluded for ineligible study design for Key Question.11343269
Mir F, Kahveci AS, Ibdah JA, . Sofosbuvir/velpatasvir regimen promises an effective pan-genotypic hepatitis C virus cure. Drug Des Devel Ther. 2017;11:497–502. doi: 10.2147/DDDT.S130945. PMID: 28260862. Excluded for not a study: letter, editorial, non-systematic review article, no original data.28260862
Miyase S, Haraoka K, Ouchida Y, . Randomized trial of peginterferon alpha-2a plus ribavirin versus peginterferon alpha-2b plus ribavirin for chronic hepatitis C in Japanese patients. J Gastroenterol. 2012;47(9):1014–21. doi: 10.1007/s00535-012-0560-9. PMID: 22382633. Excluded for outdated medication.22382633
Miyazaki R, Miyagi K. Effect and safety of daclatasvir-asunaprevir combination therapy for chronic hepatitis C virus genotype 1b -infected patients on hemodialysis. Therap Apher Dial. 2016;20(5):462–7. doi: 10.1111/1744-9987.12407. PMID: 27098678. Excluded for ineligible intervention.27098678
Mizokami M, Yokosuka O, Takehara T, . Ledipasvir and sofosbuvir fixed-dose combination with and without ribavirin for 12 weeks in treatment-naive and previously treated Japanese patients with genotype 1 hepatitis C: an open-label, randomised, phase 3 trial. Lancet Infect Dis. 2015;15(6):645–53. doi: 10.1016/S1473-3099(15)70099-X. PMID: 25863559. Excluded for ineligible population.25863559
Money D, Boucoiran I, Wagner E, . Obstetrical and neonatal outcomes among women infected with hepatitis C and their infants. J Obstet Gynaecol Can. 2014;36(9):785–94. PMID: 25222357. Excluded for ineligible outcome.25222357
Monteith C, Ni Ainle F, Cooley S, . Hepatitis C virus-associated thrombocytopenia in pregnancy: impact upon multidisciplinary care provision. J Perinat Med. 2014;42(1):135–8. doi: 10.1515/jpm-2013-0080. PMID: 24006316. Excluded for ineligible outcome.24006316
Moreno-Planas JM, Larrubia-Marfil JR, Sanchez-Ruano JJ, . Influence of baseline MELD score in the efficacy of treatment of hepatitis C with simeprevir and sofosbuvir. Enferm Infecc Microbiol Clin. 2018;36(5):277–83. doi: 10.1016/j.eimc.2017.05.001. PMID: 28641865. Excluded for ineligible population.28641865
Morgan RL, Baack B, Smith BD, . Eradication of hepatitis C virus infection and the development of hepatocellular carcinoma: a meta-analysis of observational studies. Ann Intern Med. 2013;158(5_Part_1):329–37. doi: 10.7326/0003-4819-158-5-201303050-00005. PMID: 23460056. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.23460056
Morgan TR, Ghany MG, Kim H-Y, . Outcome of sustained virological responders with histologically advanced chronic hepatitis C. Hepatology. 2010;52(3):833–44. PMID: 20564351. Excluded for ineligible population.20564351
Morio K, Imamura M, Kawakami Y, . Real-world efficacy and safety of daclatasvir and asunaprevir therapy for hepatitis C virus-infected cirrhosis patients. J Gastroenterol Hepatol. 2017;32(3):645–50. doi: 10.1111/jgh.13511. PMID: 27513614. Excluded for ineligible intervention.27513614
Morio R, Imamura M, Kawakami Y, . Safety and efficacy of dual therapy with daclatasvir and asunaprevir for older patients with chronic hepatitis C. J Gastroenterol. 2017;52(4):504–11. doi: 10.1007/s00535-016-1255-4. PMID: 27631593. Excluded for ineligible intervention.27631593
Moriya T, Sasaki F, Mizui M, . Transmission of hepatitis C virus from mothers to infants: its frequency and risk factors revisited. Biomed Pharmacother. 1995;49(2):59–64. PMID: 7605903. Excluded for poor quality.7605903
Mourad A, Deuffic-Burban S, Ganne-Carrie N, . Hepatocellular carcinoma screening in patients with compensated hepatitis C virus (HCV)-related cirrhosis aware of their HCV status improves survival: a modeling approach. Hepatology. 2014;59(4):1471–81. doi: 10.1002/hep.26944. PMID: 24677195. Excluded for ineligible intervention.24677195
Muir AJ, Poordad F, Lalezari J, . Daclatasvir in combination with asunaprevir and beclabuvir for hepatitis C virus genotype 1 infection with compensated cirrhosis. JAMA. 2015;313(17):1736–44. doi: 10.1001/jama.2015.3868. PMID: 25942724. Excluded for ineligible intervention.25942724
Mulligan K, Sullivan J, Yoon L, . Evaluating HCV screening, linkage to care, and treatment across insurers. Am J Manag Care. 2018;24(8):e257–e64. PMID: 30130026. Excluded for ineligible outcome.30130026
Mullins C, Gibson W, Klibanov OM. Harvoni (ledipasvir and sofosbuvir) for hepatitis C. Nurse Pract. 2015;40(11):22–6. doi: 10.1097/01.NPR.0000472253.59198.1c. PMID: 26474199. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26474199
Murfin M. New medications for treatment of chronic hepatitis C. JAAPA. 2015;28(7):57–9. doi: 10.1097/01.JAA.0000466592.48713.85. PMID: 26107799. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26107799
Myers RP, Regimbeau C, Thevenot T, . Interferon for acute hepatitis C. Cochrane Database Syst Rev. 2009 (1). Excluded for ineligible intervention.
Nafisi S, Roy S, Gish R, . Defining the possibilities: is short duration treatment of chronic hepatitis C genotype 1 with sofosbuvir-containing regimens likely to be as effective as current regimens? Expert Rev Anti Infect Ther. 2016;14(1):41–56. doi: 10.1586/14787210.2016.1114883. PMID: 26654939. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26654939
Nagaoki Y, Imamura M, Aikata H, . The risks of hepatocellular carcinoma development after HCV eradication are similar between patients treated with peg-interferon plus ribavirin and direct-acting antiviral therapy. PLoS One. 2017;12(8):e0182710. doi: 10.1371/journal.pone.0182710. PMID: 28797106. Excluded for ineligible comparator.28797106
Nagaty A, Abd El-Wahab EW. Real-life results of sofosbuvir based therapy in chronic hepatitis C -naive and -experienced patients in Egypt. PLoS One. 2017;12(10):e0184654. doi: 10.1371/journal.pone.0184654. PMID: 28981513. Excluded for ineligible study design for Key Question.28981513
Nahon P, Bourcier V, Layese R, . Eradication of hepatitis C virus infection in patients with cirrhosis reduces risk of liver and non-liver complications. Gastroenterology. 2017;152(1):142–56.e2. doi: 10.1053/j.gastro.2016.09.009. PMID: 27641509. Excluded for ineligible population.27641509
Nakamura Y, Imamura M, Kawakami Y, . Efficacy and safety of daclatasvir plus asunaprevir therapy for chronic hepatitis C patients with renal dysfunction. J Med Virol. 2017;89(4):665–71. doi: 10.1002/jmv.24679. PMID: 27602542. Excluded for ineligible intervention.27602542
Nam HC, Lee HL, Yang H, . Efficacy and safety of daclatasvir and asunaprevir for hepatitis C virus genotype 1b infection. Clin Mol Hepatol. 2016;22(2):259–66. doi: 10.3350/cmh.2016.0020. PMID: 27377910. Excluded for ineligible intervention.27377910
Neary MP, Cort S, Bayliss MS, . Sustained virologic response is associated with improved health-related quality of life in relapsed chronic hepatitis C patients. Semin Liver Dis. 1999;19: Suppl 1:77–85. PMID: 10349695. Excluded for ineligible intervention.10349695
Negro F, Forton D, Craxi A, . Extrahepatic morbidity and mortality of chronic hepatitis C. Gastroenterology. 2015;149(6):1345–60. doi: 10.1053/j.gastro.2015.08.035. PMID: 26319013. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26319013
Nettles RE, Gao M, Bifano M, . Multiple ascending dose study of BMS-790052, a nonstructural protein 5A replication complex inhibitor, in patients infected with hepatitis C virus genotype 1. Hepatology. 2011;54(6):1956–65. doi: 10.1002/hep.24609. PMID: 21837752. Excluded for ineligible intervention.21837752
Ng V, Saab S. Effects of a sustained virologic response on outcomes of patients with chronic hepatitis C. Clin Gastroenterol Hepatol. 2011;9(11):923–30. doi: 10.1016/j.cgh.2011.05.028. PMID: 21699815. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.21699815
Nguyen J, Barritt ASt, Jhaveri R. Cost effectiveness of early treatment with direct-acting antiviral therapy in adolescent patients with hepatitis C virus infection. J Pediatr. 2019;207:90–6. doi: 10.1016/j.jpeds.2018.12.012. PMID: 30738661. Excluded for ineligible outcome.30738661
Nguyen K, Van Nguyen T, Shen D, . Prevalence and presentation of hepatitis B and C virus (HBV and HCV) infection in Vietnamese Americans via serial community serologic testing. J Immigr Minor Health. 2015;17(1):13–20. doi: 10.1007/s10903-013-9975-5. PMID: 24474437. Excluded for ineligible study design for Key Question.24474437
Nguyen LH, Nguyen MH. Systematic review: Asian patients with chronic hepatitis C infection. Aliment Pharmacol Ther. 2013;37(10):921–36. doi: 10.1111/apt.12300. PMID: 23557103. Excluded for not a study: letter, editorial, non-systematic review article, no original data.23557103
Nguyen MT, Herrine SK, Laine CA, . Description of a new hepatitis C risk assessment tool. Arch Intern Med. 2005;165(17):2013–8. doi: 10.1001/archinte.165.17.2013. PMID: 16186472. Excluded for poor quality.16186472
Nishida N, Kono M, Minami T, . Safety, tolerability, and efficacy of sofosbuvir plus ribavirin in elderly patients infected with hepatitis C virus genotype 2. Dig Dis. 2016;34(6):632–9. doi: 10.1159/000448824. PMID: 27750230. Excluded for ineligible study design for Key Question.27750230
Nishiguchi S, Shiomi S, Nakatani S, . Prevention of hepatocellular carcinoma in patients with chronic active hepatitis C and cirrhosis. Lancet. 2001;357(9251):196–7. doi: 10.1016/s0140-6736(00)03595-9. PMID: 11213099. Excluded for ineligible population.11213099
Norton BL, Southern WN, Steinman M, . No differences in achieving hepatitis C virus care milestones between patients identified by birth cohort or risk-based screening. Clin Gastroenterol Hepatol. 2016;14(9):1356–60. doi: 10.1016/j.cgh.2016.04.017. PMID: 27108792. Excluded for ineligible outcome.27108792
Oeda S, Iwane S, Takasaki M, . Optimal follow-up of patients with viral hepatitis improves the detection of early-stage hepatocellular carcinoma and the prognosis of survival. Intern Med. 2016;55(19):2749–58. doi: 10.2169/internalmedicine.55.6730. PMID: 27725532. Excluded for ineligible intervention.27725532
Ogawa E, Furusyo N, Kajiwara E, . Comparative safety study on severe anemia by simeprevir versus telaprevir-based triple therapy for chronic hepatitis C. J Gastroenterol Hepatol. 2015;30(8):1309–16. doi: 10.1111/jgh.12945. PMID: 25777545. Excluded for ineligible outcome.25777545
Ohashi K, Ishikawa T, Suzuki M, . Health-related quality of life on the clinical course of patients with chronic hepatitis C receiving daclatasvir/asunaprevir therapy: a prospective observational study comparing younger (<70) and elderly (>=70) patients. Exp Ther Med. 2018;15(1):970–6. doi: 10.3892/etm.2017.5488. PMID: 29399105. Excluded for ineligible population.29399105
Ohmer S, Honegger J. New prospects for the treatment and prevention of hepatitis C in children. Curr Opin Pediatr. 2016;28(1):93–100. doi: 10.1097/MOP.0000000000000313. PMID: 26709684. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26709684
Ojha RP, MacDonald BR, Chu TC, . Comparative effectiveness of 8- and 12-week ledipasvir/sofosbuvir regimens for HCV infection. Antivir Ther. 2018;23(7):585–92. doi: 10.3851/IMP3249. PMID: 29969099. Excluded for ineligible study design for Key Question.29969099
Okamoto M, Nagata I, Murakami J, . Prospective reevaluation of risk factors in mother-to-child transmission of hepatitis C virus: high virus load, vaginal delivery, and negative anti-NS4 antibody. J Infect Dis. 2000;182(5):1511–4. doi: 10.1086/315883. PMID: 11023474. Excluded for poor quality.11023474
Okanoue T, Itoh Y, Minami M, . Interferon therapy lowers the rate of progression to hepatocellular carcinoma in chronic hepatitis C but not significantly in an advanced stage: a retrospective study in 1148 patients. Viral Hepatitis Therapy Study Group. J Hepatol. 1999;30(4):653–9. PMID: 10207807. Excluded for poor quality.10207807
O’Leary JG, Fontana RJ, Brown K, . Efficacy and safety of simeprevir and sofosbuvir with and without ribavirin in subjects with recurrent genotype 1 hepatitis C postorthotopic liver transplant: the randomized GALAXY study. Transpl Int. 2017;30(2):196–208. PMID: 27896858. Excluded for ineligible intervention.27896858
Omata M, Yoshida H, Shiratori Y. Prevention of hepatocellular carcinoma and its recurrence in chronic hepatitis C patients by interferon therapy. Clin Gastroenterol Hepatol. 2005;3(10 Suppl 2):S141–3. PMID: 16234063. Excluded for ineligible study design for Key Question.16234063
Onofrey S, Aneja J, Haney GA, . Underascertainment of acute hepatitis C virus infections in the U.S. surveillance system: a case series and chart review. Ann Intern Med. 2015;163(4):254–61. doi: 10.7326/M14-2939. PMID: 26121304. Excluded for ineligible intervention.26121304
Osinusi A, Townsend K, Kohli A, . Virologic response following combined ledipasvir and sofosbuvir administration in patients with HCV genotype 1 and HIV co-infection. JAMA. 2015;313(12):1232–9. doi: 10.1001/jama.2015.1373. PMID: 25706232. Excluded for ineligible population.25706232
Ozono Y, Nagata K, Hasuike S, . Efficacy and safety of sofosbuvir and ledipasvir in Japanese patients aged 75 years or over with hepatitis C genotype 1. World J Hepatol. 2017;9(36):1340–5. doi: 10.4254/wjh.v9.i36.1340. PMID: 29359017. Excluded for ineligible study design for Key Question.29359017
Paccagnini S, Principi N, Massironi E, . Perinatal transmission and manifestation of hepatitis C virus infection in a high risk population. Pediatr Infect Dis J. 1995;14(3):195–9. PMID: 7761184. Excluded for ineligible population.7761184
Parisi MR, Soldini L, Vidoni G, . Point-of-care testing for HCV infection: recent advances and implications for alternative screening. New Microbiol. 2014;37(4):449–57. PMID: 25387283. Excluded for ineligible study design for Key Question.25387283
Paydas S. Hepatitis C virus and lymphoma. Crit Rev Oncol Hematol. 2015;93(3):246–56. doi: 10.1016/j.critrevonc.2014.10.008. PMID: 25457774. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25457774
Pearlman BL, Ehleben C, Perrys M. The combination of simeprevir and sofosbuvir is more effective than that of peginterferon, ribavirin, and sofosbuvir for patients with hepatitis C-related child’s class A cirrhosis. Gastroenterology. 2015;148(4):762–70.e2; quiz e11-2. doi: 10.1053/j.gastro.2014.12.027. PMID: 25557952. Excluded for ineligible population.25557952
Pembrey L, European Paediatric Hepatitis C Virus Network. Effects of mode of delivery and infant feeding on the risk of mother-to-child transmission of hepatitis C virus. European Paediatric Hepatitis C Virus Network. BJOG. 2001;108(4):371–7. PMID: 11305543. Excluded for not a study: letter, editorial, non-systematic review article, no original data.11305543
Perello C, Carrion JA, Ruiz-Antoran B, . Effectiveness and safety of ombitasvir, paritaprevir, ritonavir +/- dasabuvir +/- ribavirin: an early access programme for Spanish patients with genotype 1/4 chronic hepatitis C virus infection. J Viral Hepat. 2017;24(3):226–37. PMID: 27976491. Excluded for ineligible study design for Key Question.27976491
Petersen T, Townsend K, Gordon LA, . High adherence to all-oral directly acting antiviral HCV therapy among an inner-city patient population in a phase 2a study. Hepatol Int. 2016;10(2):310–9. doi: 10.1007/s12072-015-9680-7. PMID: 26612014. Excluded for ineligible intervention.26612014
Pillai AA, Maheshwari R, Vora R, . Treatment of HCV infection in liver transplant recipients with ledipasvir and sofosbuvir without ribavirin. Aliment Pharmacol Ther. 2017;45(11):1427–32. doi: 10.1111/apt.14059. PMID: 28382751. Excluded for ineligible population.28382751
Pillai AA, Wedd J, Norvell JP, . Simeprevir and sofosbuvir (SMV-SOF) for 12 weeks for the treatment of chronic hepatitis C genotype 1 infection: a real world (Transplant) hepatology practice experience. Am J Gastroenterol. 2016;111(2):250–60. doi: 10.1038/ajg.2015.422. PMID: 26832650. Excluded for ineligible intervention.26832650
Pinzani M. Liver fibrosis in the post-HCV era. Semin Liver Dis. 2015;35(2):157–65. doi: 10.1055/s-0035-1550056. PMID: 25974901. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25974901
Pipan C, Amici S, Astori G, . Vertical transmission of hepatitis C virus in low-risk pregnant women. Eur J Clin Microbiol Infect Dis. 1996;15(2):116–20. PMID: 8801082. Excluded for poor quality.8801082
Pockros PJ, Jensen D, Tsai N, . JUMP-C: a randomized trial of mericitabine plus pegylated interferon alpha-2a/ribavirin for 24 weeks in treatment-naive HCV genotype 1/4 patients. Hepatology. 2013;58(2):514–23. doi: 10.1002/hep.26275. PMID: 23359491. Excluded for ineligible intervention.23359491
Pol S, Bourliere M, Lucier S, . Safety and efficacy of daclatasvir-sofosbuvir in HCV genotype 1-mono-infected patients. J Hepatol. 2017;66(1):39–47. PMID: 27622858. Excluded for ineligible study design for Key Question.27622858
Pol S, Ghalib RH, Rustgi VK, . Daclatasvir for previously untreated chronic hepatitis C genotype-1 infection: a randomised, parallel-group, double-blind, placebo-controlled, dose-finding, phase 2a trial. Lancet Infect Dis. 2012;12(9):671–7. doi: 10.1016/S1473-3099(12)70138-X. PMID: 22714001. Excluded for ineligible intervention.22714001
Polepally AR, Badri PS, Eckert D, . Effects of mild and moderate renal impairment on ombitasvir, paritaprevir, ritonavir, dasabuvir, and ribavirin pharmacokinetics in patients with chronic HCV infection. Eur J Drug Metab Pharmacokinet. 2017;42(2):333–9. doi: 10.1007/s13318-016-0341-6. PMID: 27165046. Excluded for ineligible intervention.27165046
Pontali E, Fiore V, Ialungo AM, . Treatment with direct-acting antivirals in a multicenter cohort of HCV-infected inmates in Italy. Int J Drug Policy. 2018;59:50–3. doi: 10.1016/j.drugpo.2018.06.017. PMID: 29986272. Excluded for ineligible population.29986272
Poordad F, Agarwal K, Younes Z, . Low relapse rate leads to high concordance of sustained virologic response (SVR) at 12 weeks with SVR at 24 weeks after treatment with ABT-450/ritonavir, ombitasvir, and dasabuvir plus ribavirin in subjects with chronic hepatitis C virus genotype 1 infection in the AVIATOR study. Clin Infect Dis. 2015;60(4):608–10. doi: 10.1093/cid/ciu865. PMID: 25365973. Excluded for ineligible population.25365973
Poordad F, McCone J, Jr., Bacon BR, . Boceprevir for untreated chronic HCV genotype 1 infection. N Engl J Med. 2011;364(13):1195–206. doi: 10.1056/NEJMoa1010494. PMID: 21449783. Excluded for inadequate duration.21449783
Poordad F, Sievert W, Mollison L, . Fixed-dose combination therapy with daclatasvir, asunaprevir, and beclabuvir for noncirrhotic patients with HCV genotype 1 infection. JAMA. 2015;313(17):1728–35. doi: 10.1001/jama.2015.3860. PMID: 25942723. Excluded for ineligible intervention.25942723
Porter JC, Lusk HM, Katz AR. Prevalence of HCV infection among clients in community-based health settings in Hawaii, 2002-2010: assessing risk factors. Am J Public Health. 2014;104(8):1534–9. doi: 10.2105/AJPH.2013.301282. PMID: 24028267. Excluded for ineligible study design for Key Question.24028267
Porto AF, Tormey L, Lim JK. Management of chronic hepatitis C infection in children. Curr Opin Pediatr. 2012;24(1):113–20. doi: 10.1097/MOP.0b013e32834eb73f. PMID: 22157364. Excluded for ineligible population.22157364
Pothineni NV, Delongchamp R, Vallurupalli S, . Impact of hepatitis C seropositivity on the risk of coronary heart disease events. Am J Cardiol. 2014;114(12):1841–5. doi: 10.1016/j.amjcard.2014.09.020. PMID: 25438910. Excluded for ineligible intervention.25438910
Poullot E, Bouscary D, Guyader D, . Large granular lymphocyte leukemia associated with hepatitis C virus infection and B cell lymphoma: improvement after antiviral therapy. Leuk Lymphoma. 2013;54(8):1797–9. doi: 10.3109/10428194.2012.752486. PMID: 23176408. Excluded for not a study: letter, editorial, non-systematic review article, no original data.23176408
Poynard T, Moussalli J, Munteanu M, . Slow regression of liver fibrosis presumed by repeated biomarkers after virological cure in patients with chronic hepatitis C. J Hepatol. 2013;59(4):675–83. doi: 10.1016/j.jhep.2013.05.015. PMID: 23712051. Excluded for ineligible population.23712051
Pradat P, Tillmann HL, Sauleda S, . Long-term follow-up of the hepatitis C HENCORE cohort: response to therapy and occurrence of liver-related complications. J Viral Hepat. 2007;14(8):556–63. doi: 10.1111/j.1365-2893.2006.00829.x. PMID: 17650289. Excluded for ineligible outcome.17650289
Prasad MR, Honegger JR. Hepatitis C virus in pregnancy. Am J Perinatol. 2013;30(2):149–59. doi: 10.1055/s-0033-1334459. PMID: 23389935. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.23389935
Prasad N, Patel MR, Pandey A, . Direct-acting antiviral agents in hepatitis C virus-infected renal allograft recipients: treatment and outcome experience from single center. Indian J Nephrol. 2018;28(3):220–5. doi: 10.4103/ijn.IJN_190_17. PMID: 29962673. Excluded for ineligible population.29962673
Puigvehi M, De Cuenca B, Viu A, . Eight weeks of paritaprevir/r/ombitasvir + dasabuvir in HCV genotype 1b with mild-moderate fibrosis: results from a real-world cohort. Liver Int. 2019;39(1):90–7. doi: 10.1111/liv.13950. PMID: 30160363. Excluded for ineligible intervention.30160363
Punzalan CS, Barry C, Zacharias I, . Sofosbuvir plus simeprevir treatment of recurrent genotype 1 hepatitis C after liver transplant. Clin Transplant. 2015;29(12):1105–11. doi: 10.1111/ctr.12634. PMID: 26358816. Excluded for ineligible population.26358816
Qu Y, Guo Y, Li T, . Efficacy and safety of sofosbuvir-based interferon-free therapies for hepatitis C in liver transplant recipients. J Gastroenterol Hepatol. 2017;32(4):740–8. doi: 10.1111/jgh.13614. PMID: 27749979. Excluded for ineligible population.27749979
Rabie R, Mumtaz K, Renner EL. Efficacy of antiviral therapy for hepatitis C after liver transplantation with cyclosporine and tacrolimus: a systematic review and meta-analysis. Liver Transpl. 2013;19(1):36–48. doi: 10.1002/lt.23516. PMID: 22821730. Excluded for ineligible population.22821730
Rasenack J, Zeuzem S, Feinman SV, . Peginterferon alpha-2a (40kD) [Pegasys] improves HR-QOL outcomes compared with unmodified interferon alpha-2a [Roferon-A]: in patients with chronic hepatitis C. Pharmacoeconomics. 2003;21(5):341–9. PMID: 12627987. Excluded for ineligible intervention.12627987
Reddy KR, Bourliere M, Sulkowski M, . Ledipasvir and sofosbuvir in patients with genotype 1 hepatitis C virus infection and compensated cirrhosis: an integrated safety and efficacy analysis. Hepatology. 2015;62(1):79–86. doi: 10.1002/hep.27826. PMID: 25846144. Excluded for ineligible population.25846144
Reddy KR, Lim JK, Kuo A, . All-oral direct-acting antiviral therapy in HCV-advanced liver disease is effective in real-world practice: observations through HCV-TARGET database. Aliment Pharmacol Ther. 2017;45(1):115–26. doi: 10.1111/apt.13823. PMID: 27790729. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27790729
Reddy KR, Zeuzem S, Zoulim F, . Simeprevir versus telaprevir with peginterferon and ribavirin in previous null or partial responders with chronic hepatitis C virus genotype 1 infection (ATTAIN): a randomised, double-blind, non-inferiority phase 3 trial. Lancet Infect Dis. 2015;15(1):27–35. doi: 10.1016/S1473-3099(14)71002-3. PMID: 25482330. Excluded for ineligible intervention.25482330
Reid CT, De Gascun C, Hall W, . Is universal screening for hepatitis C infection prior to commencing antitumour necrosis factor-alpha therapy necessary? Br J Dermatol. 2013;169(6):1319–21. doi: 10.1111/bjd.12598. PMID: 24032395. Excluded for ineligible study design for Key Question.24032395
Rein DB, Smith BD, Wittenborn JS, . The cost-effectiveness of birth-cohort screening for hepatitis C antibody in U.S. primary care settings. Ann Intern Med. 2012;156(4):263–70. doi: 10.7326/0003-4819-156-4-201202210-00378. PMID: 22056542. Excluded for ineligible intervention.22056542
Rein DB, Wittenborn JS, Smith BD, . The cost-effectiveness, health benefits, and financial costs of new antiviral treatments for hepatitis C virus. Clin Infect Dis. 2015;61(2):157–68. doi: 10.1093/cid/civ220. PMID: 25778747. Excluded for ineligible study design for Key Question.25778747
Renard S, Borentain P, Salaun E, . Severe pulmonary arterial hypertension in patients treated for hepatitis C with sofosbuvir. Chest. 2016;149(3):e69–73. doi: 10.1016/j.chest.2015.09.018. PMID: 26965976. Excluded for ineligible study design for Key Question.26965976
Resti M, Azzari C, Mannelli F, . Mother to child transmission of hepatitis C virus: prospective study of risk factors and timing of infection in children born to women seronegative for HIV-1. Tuscany Study Group on hepatitis C virus infection. BMJ. 1998;317(7156):437–41. PMID: 9703524. Excluded for poor quality.9703524
Roberts EA, Yeung L. Maternal-infant transmission of hepatitis C virus infection. Hepatology. 2002;36(5 Suppl 1):S106–13. doi: 10.1053/jhep.2002.36792. PMID: 12407583. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.12407583
Rodger AJ, Jolley D, Thompson SC, . The impact of diagnosis of hepatitis C virus on quality of life. Hepatology. 1999;30(5):1299–301. PMID: 10534353. Excluded for poor quality.10534353
Rodriguez-Torres M, Lawitz E, Yangco B, . Daclatasvir and peginterferon/ribavirin for black/African-American and Latino patients with HCV infection. Ann Hepatol. 2016;15(6):834–45. doi: 10.5604/16652681.1222098. PMID: 27740516. Excluded for ineligible intervention.27740516
Rosen I, Kori M, Eshach Adiv O, . Pegylated interferon alfa and ribavirin for children with chronic hepatitis C. World J Gastroenterol. 2013;19(7):1098–103. doi: 10.3748/wjg.v19.i7.1098. PMID: 23467199. Excluded for ineligible intervention.23467199
Rosenberg WM, Tanwar S, Trembling P. Complexities of HCV management in the new era of direct-acting antiviral agents. QJM. 2014;107(1):17–9. doi: 10.1093/qjmed/hct181. PMID: 24065837. Excluded for not a study: letter, editorial, non-systematic review article, no original data.24065837
Rossi C, Butt ZA, Wong S, . Hepatitis C virus reinfection after successful treatment with direct-acting antiviral therapy in a large population-based cohort. J Hepatol. 2018;69(5):1007–14. doi: 10.1016/j.jhep.2018.07.025. PMID: 30142429. Excluded for ineligible outcome.30142429
Rostaing L, Alric L, Kamar N. Use of direct-acting agents for hepatitis C virus-positive kidney transplant candidates and kidney transplant recipients. Transpl Int. 2016;29(12):1257–65. doi: 10.1111/tri.12870. PMID: 27717014. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27717014
Ruggeri M, Rolli FR, Kondili LA, . Cost-effectiveness analysis of daclatasvir/sofosbuvir for the treatment of the HCV patients failed after the first line with second generation of DAAs in Italy. Expert Rev Pharmacoecon Outcomes Res. 2018:1–12. doi: 10.1080/14737167.2019.1537784. PMID: 30351994. Excluded for not a study: letter, editorial, non-systematic review article, no original data.30351994
Rumi MG, Aghemo A, Prati GM, . Randomized study of peginterferon-alpha2a plus ribavirin vs peginterferon-alpha2b plus ribavirin in chronic hepatitis C. Gastroenterology. 2010;138(1):108–15. doi: 10.1053/j.gastro.2009.08.071. PMID: 19766645. Excluded for outdated medication.19766645
Saab S, Greenberg A, Li E, . Sofosbuvir and simeprevir is effective for recurrent hepatitis C in liver transplant recipients. Liver Int. 2015;35(11):2442–7. doi: 10.1111/liv.12856. PMID: 25913321. Excluded for ineligible population.25913321
Saab S, Mehta D, Hudgens S, . Effect of ombitasvir/paritaprevir/ritonavir + dasabuvir regimen on health-related quality of life for patients with hepatitis C. Liver Int. 2018;38(8):1377–94. doi: 10.1111/liv.13690. PMID: 29314597. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.29314597
Saab S, Park SH, Mizokami M, . Safety and efficacy of ledipasvir/sofosbuvir for the treatment of genotype 1 hepatitis C in subjects aged 65 years or older. Hepatology. 2016;63(4):1112–9. doi: 10.1002/hep.28425. PMID: 26704693. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26704693
Sadler MD, Lee SS. Revolution in hepatitis C antiviral therapy. Br Med Bull. 2015;113(1):31–44. doi: 10.1093/bmb/ldv004. PMID: 25680808. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25680808
Salemi JL, Whiteman VE, August EM, . Maternal hepatitis B and hepatitis C infection and neonatal neurological outcomes. J Viral Hepat. 2014;21(11):e144–53. doi: 10.1111/jvh.12250. PMID: 24666386. Excluded for ineligible intervention.24666386
Sanchez Antolin G, Testillano M, Pascasio JM, . Efficacy and safety of therapy with simeprevir and sofosbuvir in liver transplant recipients infected by hepatitis C virus genotype 4: cohort Spanish society of liver transplantation cohort. Transplant Proc. 2016;48(9):3013–6. doi: 10.1016/j.transproceed.2016.08.034. PMID: 27932134. Excluded for ineligible population.27932134
Sarpel D, Baichoo E, Dieterich DT. Chronic hepatitis B and C infection in the United States: a review of current guidelines, disease burden and cost effectiveness of screening. Expert Rev Anti Infect Ther. 2016;14(5):511–21. doi: 10.1586/14787210.2016.1174066. PMID: 27043049. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27043049
Sarrazin C, Dvory-Sobol H, Svarovskaia ES, . Prevalence of resistance-associated substitutions in HCV NS5A, NS5B, or NS3 and outcomes of treatment with ledipasvir and sofosbuvir. Gastroenterology. 2016;151(3):501–12.e1. doi: 10.1053/j.gastro.2016.06.002. PMID: 27296509. Excluded for ineligible study design for Key Question.27296509
Sarrazin C, Isakov V, Svarovskaia ES, . Late relapse versus hepatitis C virus reinfection in patients with sustained virologic response after sofosbuvir-based therapies. Clin Infect Dis. 2017;64(1):44–52. doi: 10.1093/cid/ciw676. PMID: 27737953. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27737953
Saxena V, Khungar V, Verna EC, . Safety and efficacy of current direct-acting antiviral regimens in kidney and liver transplant recipients with hepatitis C: results from the HCV-TARGET study. Hepatology. 2017;66(4):1090–101. doi: 10.1002/hep.29258. PMID: 28504842. Excluded for ineligible population.28504842
Saxena V, Nyberg L, Pauly M, . Safety and efficacy of simeprevir/sofosbuvir in hepatitis C-infected patients with compensated and decompensated cirrhosis. Hepatology. 2015;62(3):715–25. doi: 10.1002/hep.27922. PMID: 26033798. Excluded for ineligible population.26033798
Scalioni LP, Cruz HM, de Paula VS, . Performance of rapid hepatitis C virus antibody assays among high- and low-risk populations. J Clin Virol. 2014;60(3):200–5. doi: 10.1016/j.jcv.2014.04.001. PMID: 24794796. Excluded for ineligible country.24794796
Scavone C, Sportiello L, Rafaniello C, . New era in treatment options of chronic hepatitis C: focus on safety of new direct-acting antivirals (DAAs). Expert Opin Drug Saf. 2016;15(sup2):85–100. doi: 10.1080/14740338.2016.1221396. PMID: 27875916. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27875916
Schechter-Perkins EM, Miller NS, Hall J, . Implementation and preliminary results of an emergency department nontargeted, opt-out hepatitis C virus screening program. Acad Emerg Med. 2018;31:31. doi: 10.1111/acem.13484. PMID: 29851238. Excluded for ineligible study design for Key Question.29851238
Schreiber J, McNally J, Chodavarapu K, . Treatment of a patient with genotype 7 hepatitis C virus infection with sofosbuvir and velpatasvir. Hepatology. 2016;64(3):983–5. PMID: 27177605. Excluded for ineligible study design for Key Question.27177605
Schutz A, Moser S, Schwanke C, . Directly observed therapy of chronic hepatitis C with ledipasvir/sofosbuvir in people who inject drugs at risk of nonadherence to direct-acting antivirals. J Viral Hepat. 2018;25(7):870–3. doi: 10.1111/jvh.12857. PMID: 29316001. Excluded for ineligible study design for Key Question.29316001
Scott GD, Rieger KE. New-onset cutaneous lichen planus following therapy for hepatitis C with ledipasvir-sofosbuvir. J Cutan Pathol. 2016;43(4):408–9. doi: 10.1111/cup.12656. PMID: 26816004. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26816004
Scott N, McBryde E, Vickerman P, . The role of a hepatitis C virus vaccine: modelling the benefits alongside direct-acting antiviral treatments. BMC Med. 2015;13:198. doi: 10.1186/s12916-015-0440-2. PMID: 26289050. Excluded for ineligible study design for Key Question.26289050
Seaberg EC, Witt MD, Jacobson LP, . Differences in hepatitis C virus prevalence and clearance by mode of acquisition among men who have sex with men. J Viral Hepat. 2014;21(10):696–705. doi: 10.1111/jvh.12198. PMID: 25280229. Excluded for ineligible intervention.25280229
Sears DM, Cohen DC, Ackerman K, . Birth cohort screening for chronic hepatitis during colonoscopy appointments. Am J Gastroenterol. 2013;108(6):981–9. doi: 10.1038/ajg.2013.50. PMID: 23511461. Excluded for ineligible study design for Key Question.23511461
Serfaty L. Follow-up of patients with chronic hepatitis C and a sustained viral response. Liver Int. 2016;36: Suppl 1:67–71. doi: 10.1111/liv.13016. PMID: 26725900. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26725900
Shebl FM, El-Kamary SS, Shardell M, . Estimating incidence rates with misclassified disease status: a likelihood-based approach, with application to hepatitis C virus. Int J Infect Dis. 2012;16(7):e527–31. doi: 10.1016/j.ijid.2012.02.017. PMID: 22543295. Excluded for ineligible study design for Key Question.22543295
Sherman KE, Flamm SL, Afdhal NH, . Response-guided telaprevir combination treatment for hepatitis C virus infection. N Engl J Med. 2011;365(11):1014–24. doi: 10.1056/NEJMoa1014463. PMID: 21916639. Excluded for outdated medication.21916639
Shiffman ML. Universal screening for chronic hepatitis C virus. Liver Int. 2016;36: Suppl 1:62–6. doi: 10.1111/liv.13012. PMID: 26725899. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26725899
Shiffman ML, Rustgi V, Bennett M, . Safety and efficacy of ombitasvir/paritaprevir/ritonavir plus dasabuvir with or without ribavirin in HCV-infected patients taking concomitant acid-reducing agents. Am J Gastroenterol. 2016;111(6):845–51. doi: 10.1038/ajg.2016.108. PMID: 27045929. Excluded for ineligible intervention.27045929
Shiffman ML, Sterling RK, Contos M, . Long term changes in liver histology following treatment of chronic hepatitis C virus. Ann Hepatol. 2014;13(4):340–9. PMID: 24927604. Excluded for ineligible outcome.24927604
Shiffman ML, Suter F, Bacon BR, . Peginterferon alfa-2a and ribavirin for 16 or 24 weeks in HCV genotype 2 or 3. N Engl J Med. 2007;357(2):124–34. doi: 10.1056/NEJMoa066403. PMID: 17625124. Excluded for outdated medication.17625124
Shiha G, Esmat G, Hassany M, . Ledipasvir/sofosbuvir with or without ribavirin for 8 or 12 weeks for the treatment of HCV genotype 4 infection: results from a randomised phase III study in Egypt. Gut. 2018;17:17. doi: 10.1136/gutjnl-2017-315906. PMID: 29666174. Excluded for ineligible population.29666174
Shiha G, Soliman R, ElBasiony M, . Sofosbuvir plus daclatasvir with or without ribavirin for treatment of chronic HCV genotype 4 patients: real-life experience. Hepatol Int. 2018;12(4):339–47. doi: 10.1007/s12072-018-9861-2. PMID: 29663115. Excluded for ineligible study design for Key Question.29663115
Shindo M, Hamada K, Oda Y, . Long‐term follow‐up study of sustained biochemical responders with interferon therapy. Hepatology. 2001;33(5):1299–302. doi: 10.1053/jhep.2001.24100. PMID: 11343259. Excluded for poor quality.11343259
Shindoh J, Hasegawa K, Matsuyama Y, . Low hepatitis C viral load predicts better long-term outcomes in patients undergoing resection of hepatocellular carcinoma irrespective of serologic eradication of hepatitis C virus. J Clin Oncol. 2013;31(6):766–73. doi: 10.1200/JCO.2012.44.3234. PMID: 23129744. Excluded for ineligible population.23129744
Shiratori Y, Ito Y, Yokosuka O, . Antiviral therapy for cirrhotic hepatitis C: association with reduced hepatocellular carcinoma development and improved survival. Ann Intern Med. 2005;142(2):105–14. PMID: 15657158. Excluded for ineligible population.15657158
Shousha HI, Akl K, Ragheb S, . Generic sofosbuvir/ledipasvir for treatment of naive, non-cirrhotic, easy to treat patients with chronic hepatitis c genotype 4: 8 vs. 12 weeks of treatment. Hepat Mon. 2018;18(9). Excluded for ineligible intervention.
Simmons B, Saleem J, Heath K, . Long-term treatment outcomes of patients infected with hepatitis C virus: a systematic review and meta-analysis of the survival benefit of achieving a sustained virological response. Clin Infect Dis. 2015;61(5):730–40. doi: 10.1093/cid/civ396. PMID: 25987643. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.25987643
Singal AG, Volk ML, Jensen D, . A sustained viral response is associated with reduced liver-related morbidity and mortality in patients with hepatitis C virus. Clin Gastroenterol Hepatol. 2010;8(3):280–8.e1. doi: 10.1016/j.cgh.2009.11.018. PMID: 19948249. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.19948249
Siqueira FM, Ferreira VL, Borba HHL, . Quality of life of Brazilian chronic hepatitis C patients treated with interferon-free therapies. Rev Inst Med Trop Sao Paulo. 2018;60:e72. doi: 10.1590/S1678-9946201860072. PMID: 30462795. Excluded for ineligible population.30462795
Slim J, Afridi MS. Managing adverse effects of interferon-alfa and ribavirin in combination therapy for HCV. Infect Dis Clin North Am. 2012;26(4):917–29. doi: 10.1016/j.idc.2012.08.006. PMID: 23083824. Excluded for not a study: letter, editorial, non-systematic review article, no original data.23083824
Smith BD, Yartel AK. Comparison of hepatitis C virus testing strategies: birth cohort versus elevated alanine aminotransferase levels. Am J Prev Med. 2014;47(3):233–41. doi: 10.1016/j.amepre.2014.05.011. PMID: 25145616. Excluded for ineligible comparator.25145616
Smith BD, Yartel AK, Krauskopf K, . Hepatitis C virus antibody positivity and predictors among previously undiagnosed adult primary care outpatients: cross-sectional analysis of a multisite retrospective cohort study. Clin Infect Dis. 2015;60(8):1145–52. doi: 10.1093/cid/civ002. PMID: 25595745. Excluded for ineligible outcome.25595745
Smith MA, Lim A. Profile of paritaprevir/ritonavir/ombitasvir plus dasabuvir in the treatment of chronic hepatitis C virus genotype 1 infection. Drug Des Devel Ther. 2015;9:6083–94. doi: 10.2147/DDDT.S80226. PMID: 26622169. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26622169
Smith MA, Love BL, Mohammad RA. The changing landscape of adverse drug events associated with chronic hepatitis C virus therapy. Expert Opin Drug Saf. 2015;14(11):1649–52. doi: 10.1517/14740338.2015.1088002. PMID: 26365685. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26365685
Snow KJ, Richards AH, Kinner SA. Use of multiple data sources to estimate hepatitis C seroprevalence among prisoners: a retrospective cohort study. PLoS One. 2017;12(7):e0180646. doi: 10.1371/journal.pone.0180646. PMID: 28686715. Excluded for ineligible country.28686715
Snow KJ, Young JT, Preen DB, . Incidence and correlates of hepatitis C virus infection in a large cohort of prisoners who have injected drugs. BMC Public Health. 2014;14:830. doi: 10.1186/1471-2458-14-830. PMID: 25113132. Excluded for ineligible country.25113132
Soga K, Shibasaki K, Aoyagi Y. Effect of interferon on incidence of hepatocellular carcinoma in patients with chronic hepatitis C. Hepatogastroenterology. 2005;52(64):1154–8. PMID: 16001651. Excluded for poor quality.16001651
Solis-Munoz P, Mingote-Adan C, Solis-Herruzo JA. Neurocognitive function and dysfunction after hepatitis C therapy. Hepatology. 2014;60(1):431. doi: 10.1002/hep.26919. PMID: 24178628. Excluded for not a study: letter, editorial, non-systematic review article, no original data.24178628
Solund C, Andersen ES, Mossner B, . Outcome and adverse events in patients with chronic hepatitis C treated with direct-acting antivirals: a clinical randomized study. Eur J Gastroenterol Hepatol. 2018;30(10):1177–86. doi: 10.1097/MEG.0000000000001192. PMID: 29994874. Excluded for ineligible population.29994874
Sommese L, Sabia C, Paolillo R, . Screening tests for hepatitis B virus, hepatitis C virus, and human immunodeficiency virus in blood donors: evaluation of two chemiluminescent immunoassay systems. Scand J Infect Dis. 2014;46(9):660–4. doi: 10.3109/00365548.2014.926564. PMID: 25073538. Excluded for ineligible outcome.25073538
Sood A, Midha V, Hissar S, . Comparison of low-dose pegylated interferon versus standard high-dose pegylated interferon in combination with ribavirin in patients with chronic hepatitis C with genotype 3: an Indian experience. J Gastroenterol Hepatol. 2008;23(2):203–7. doi: 10.1111/j.1440-1746.2007.05057.x. PMID: 17645472. Excluded for outdated medication.17645472
Soriano V, Young B, Terrault N. Report from the International Conference on Viral Hepatitis (ICVH), San Francisco, March 2016. AIDS Rev. 2016;18(2):81–8. PMID: 27196355. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27196355
Sou FM, Wu CK, Chang KC, . Clinical characteristics and prognosis of HCC occurrence after antiviral therapy for HCV patients between sustained and non-sustained responders. J Formos Med Assoc. 2019;118(1 Pt 3):504–13. doi: 10.1016/j.jfma.2018.10.017. PMID: 30527565. Excluded for insufficient statistical analysis.30527565
Southern WN, Drainoni ML, Smith BD, . Physician nonadherence with a hepatitis C screening program. Qual Manag Health Care. 2014;23(1):1–9. doi: 10.1097/QMH.0000000000000007. PMID: 24368717. Excluded for ineligible outcome.24368717
Southern WN, Norton B, Steinman M, . A birth-cohort testing intervention identified hepatitis C virus infection among patients with few identified risks: a cross-sectional study. BMC Infect Dis. 2015;15:553. doi: 10.1186/s12879-015-1283-3. PMID: 26626449. Excluded for ineligible outcome.26626449
Spelman T, Morris MD, Zang G, . A longitudinal study of hepatitis C virus testing and infection status notification on behaviour change in people who inject drugs. J Epidemiol Community Health. 2015;69(8):745–52. doi: 10.1136/jech-2014-205224. PMID: 25814695. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25814695
Spencer JD, Latt N, Beeby PJ, . Transmission of hepatitis C virus to infants of human immunodeficiency virus-negative intravenous drug-using mothers: rate of infection and assessment of risk factors for transmission. J Viral Hepat. 1997;4(6):395–409. PMID: 9430360. Excluded for poor quality.9430360
Stasi C, Arena U, Zignego AL, . Longitudinal assessment of liver stiffness in patients undergoing antiviral treatment for hepatitis C. Dig Liver Dis. 2013;45(10):840–3. doi: 10.1016/j.dld.2013.03.023. PMID: 23660078. Excluded for ineligible outcome.23660078
Stasi C, Piluso A, Arena U, . Evaluation of the prognostic value of liver stiffness in patients with hepatitis C virus treated with triple or dual antiviral therapy: a prospective pilot study. World J Gastroenterol. 2015;21(10):3013–9. doi: 10.3748/wjg.v21.i10.3013. PMID: 25780300. Excluded for ineligible outcome.25780300
Stein MR, Soloway IJ, Jefferson KS, . Concurrent group treatment for hepatitis C: implementation and outcomes in a methadone maintenance treatment program. J Subst Abuse Treat. 2012;43(4):424–32. doi: 10.1016/j.jsat.2012.08.007. PMID: 23036920. Excluded for ineligible intervention.23036920
Steininger C, Kundi M, Jatzko G, . Increased risk of mother-to-infant transmission of hepatitis C virus by intrapartum infantile exposure to maternal blood. J Infect Dis. 2003;187(3):345–51. doi: 10.1086/367704. PMID: 12552417. Excluded for insufficient statistical analysis.12552417
Stepanova M, Nader F, Cure S, . Patients’ preferences and health utility assessment with SF-6D and EQ-5D in patients with chronic hepatitis C treated with sofosbuvir regimens. Aliment Pharmacol Ther. 2014;40(6):676–85. doi: 10.1111/apt.12880. PMID: 25040192. Excluded for ineligible intervention.25040192
Stewart RA, MacDonald BR, Chu TC, . Ledipasvir/sofosbuvir effectively treats hepatitis C virus infections in an underserved population. Dig Dis Sci. 2018;63(12):3233–40. doi: 10.1007/s10620-018-5205-2. PMID: 30014226. Excluded for ineligible study design for Key Question.30014226
Stockman LJ, Greer J, Holzmacher R, . Performance of risk-based and birth-cohort strategies for identifying hepatitis C virus infection among people entering prison, Wisconsin, 2014. Public Health Rep. 2016;131(4):544–51. doi: 10.1177/0033354916662212. PMID: 27453598. Excluded for ineligible population.27453598
Stockman LJ, Guilfoye SM, Benoit AL, . Rapid hepatitis C testing among persons at increased risk for infection-Wisconsin, 2012-2013. MMWR. 2014;63(14):309–11. PMID: 24717818. Excluded for ineligible outcome.24717818
Su F, Green PK, Berry K, . The association between race/ethnicity and the effectiveness of direct antiviral agents for hepatitis C virus infection. Hepatology. 2017;65(2):426–38. doi: 10.1002/hep.28901. PMID: 27775854. Excluded for ineligible comparator.27775854
Suda G, Kudo M, Nagasaka A, . Efficacy and safety of daclatasvir and asunaprevir combination therapy in chronic hemodialysis patients with chronic hepatitis C. J Gastroenterol. 2016;51(7):733–40. doi: 10.1007/s00535-016-1162-8. PMID: 26768604. Excluded for ineligible intervention.26768604
Suraweera D, Weeratunga AN, Saab S. Spotlight on grazoprevir-elbasvir once-daily combination and its potential in the treatment of hepatitis C. Drug Des Devel Ther. 2016;10:2119–27. doi: 10.2147/DDDT.S90537. PMID: 27418810. Excluded for not a study: letter, editorial, non-systematic review article, no original data.27418810
Suryaprasad AG, White JZ, Xu F, . Emerging epidemic of hepatitis C virus infections among young nonurban persons who inject drugs in the United States, 2006-2012. Clin Infect Dis. 2014;59(10):1411–9. doi: 10.1093/cid/ciu643. PMID: 25114031. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25114031
Suwanthawornkul T, Anothaisintawee T, Sobhonslidsuk A, . Efficacy of second generation direct-acting antiviral agents for treatment naive hepatitis C genotype 1: a systematic review and network meta-analysis. PLoS One. 2015;10(12):e0145953. doi: 10.1371/journal.pone.0145953. PMID: 26720298. Excluded for ineligible intervention.26720298
Syriopoulou V, Nikolopoulou G, Daikos GL, . Mother to child transmission of hepatitis C virus: rate of infection and risk factors. Scand J Infect Dis. 2005;37(5):350–3. doi: 10.1080/00365540510032105. PMID: 16051571. Excluded for poor quality.16051571
Tada T, Kumada T, Toyoda H, . Viral eradication reduces all-cause mortality, including non-liver-related disease, in patients with progressive hepatitis C virus-related fibrosis. J Gastroenterol Hepatol. 2017;32(3):687–94. doi: 10.1111/jgh.13589. PMID: 27577675. Excluded for ineligible study design for Key Question.27577675
Tajiri H, Miyoshi Y, Funada S, . Prospective study of mother-to-infant transmission of hepatitis C virus. Pediatr Infect Dis J. 2001;20(1):10–4. PMID: 11176560. Excluded for poor quality.11176560
Takahashi H, Mizuta T, Eguchi Y, . Post-challenge hyperglycemia is a significant risk factor for the development of hepatocellular carcinoma in patients with chronic hepatitis C. J Gastroenterol. 2011;46(6):790–8. doi: 10.1007/s00535-011-0381-2. PMID: 21331763. Excluded for ineligible comparator.21331763
Takeda K, Noguchi R, Namisaki T, . Efficacy and tolerability of interferon-free regimen for patients with genotype-1 HCV infection. Exp Ther Med. 2018;16(3):2743–50. doi: 10.3892/etm.2018.6481. PMID: 30210615. Excluded for ineligible study design for Key Question.30210615
Takeuchi LC, Pham TK, Katz AR. Hepatitis C virus antibody prevalence, demographics and associated factors among persons screened at Hawai’i community-based health settings, 2010-2013. Hawaii J Med Public Health. 2015;74(1):9–15. PMID: 25628977. Excluded for ineligible study design for Key Question.25628977
Taki S, Tamai H, Ida Y, . The real-world safety and efficacy of daclatasvir and asunaprevir for elderly patients. Gut Liver. 2018;12(1):86–93. doi: 10.5009/gnl17048. PMID: 28798288. Excluded for ineligible intervention.28798288
Tam E, Luetkemeyer AF, Mantry PS, . Ledipasvir/sofosbuvir for treatment of hepatitis C virus in sofosbuvir-experienced, NS5A treatment-naive patients: findings from two randomized trials. Liver Int. 2018;38(6):1010–21. doi: 10.1111/liv.13616. PMID: 29091342. Excluded for ineligible population.29091342
Tamai H, Shingaki N, Ida Y, . Real-world safety and efficacy of sofosbuvir and ledipasvir for elderly patients. Jgh Open. 2018;2(6):300–6. doi: 10.1002/jgh3.12088. PMID: 30619941. Excluded for ineligible population.30619941
Tame M, Buonfiglioli F, Del Gaudio M, . Long-term leukocyte natural alpha-interferon and ribavirin treatment in hepatitis C virus recurrence after liver transplantation. World J Gastroenterol. 2013;19(32):5278–85. doi: 10.3748/wjg.v19.i32.5278. PMID: 23983430. Excluded for ineligible population.23983430
Tanaka T, Selzner N, Therapondos G, . Virological response for recurrent hepatitis C improves long-term survival in liver transplant recipients. Transpl Int. 2013;26(1):42–9. doi: 10.1111/j.1432-2277.2012.01571.x. PMID: 23137287. Excluded for ineligible population.23137287
Tanase AM, Dumitrascu T, Dima S, . Influence of hepatitis viruses on clinicopathological profiles and long-term outcome in patients undergoing surgery for hepatocellular carcinoma. Hepatobiliary Pancreat Dis Int. 2014;13(2):162–72. PMID: 24686543. Excluded for ineligible population.24686543
Tang L, Kamat M, Shukla A, . Comparative antiviral efficacy of generic sofosbuvir versus brand name sofosbuvir with ribavirin for the treatment of hepatitis C. Interdiscip Perspect Infect Dis. 2018;2018:9124604. doi: 10.1155/2018/9124604. PMID: 30364048. Excluded for ineligible intervention.30364048
Tanzi M, Bellelli E, Benaglia G, . The prevalence of HCV infection in a cohort of pregnant women, the related risk factors and the possibility of vertical transmission. Eur J Epidemiol. 1997;13(5):517–21. PMID: 9258562. Excluded for poor quality.9258562
Taylor BS, Hanson JT, Veerapaneni P, . Hospital-based hepatitis C screening of baby boomers in a majority Hispanic south Texas cohort: successes and barriers to implementation. Public Health Rep. 2016;131: Suppl 2:74–83. doi: 10.1177/00333549161310S212. PMID: 27168665. Excluded for ineligible outcome.27168665
Teriaky A, Reau N. Evaluation of hepatitis C patients in the direct-acting antiviral era. Clin Liver Dis. 2015;19(4):591–604, v. doi: 10.1016/j.cld.2015.06.001. PMID: 26466649. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26466649
Terrault NA, Zeuzem S, Di Bisceglie AM, . Effectiveness of ledipasvir-sofosbuvir combination in patients with hepatitis C virus infection and factors associated with sustained virologic response. Gastroenterology. 2016;151(6):1131–40.e5. doi: 10.1053/j.gastro.2016.08.004. PMID: 27565882. Excluded for ineligible study design for Key Question.27565882
Thomas SL, Newell ML, Peckham CS, . A review of hepatitis C virus (HCV) vertical transmission: risks of transmission to infants born to mothers with and without HCV viraemia or human immunodeficiency virus infection. Int J Epidemiol. 1998;27(1):108–17. PMID: 9563703. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.9563703
Thu Thuy PT, Bunchorntavakul C, Tan Dat H, . Sofosbuvir-ledipasvir with or without ribavirin for chronic hepatitis C genotype-1 and 6: real-world experience in Vietnam. Antivir Ther. 2018;23(5):415–23. doi: 10.3851/IMP3217. PMID: 29303482. Excluded for ineligible population.29303482
Tong MJ, Chang PW, Huynh TT, . Adverse events associated with ribavirin in sofosbuvir-based therapies for patients with chronic hepatitis C: a community practice experience. J Dig Dis. 2016;17(2):113–21. doi: 10.1111/1751-2980.12313. PMID: 26749171. Excluded for ineligible intervention.26749171
Tong MJ, el-Farra NS, Reikes AR, . Clinical outcomes after transfusion-associated hepatitis C. N Engl J Med. 1995;332(22):1463–6. doi: 10.1056/nejm199506013322202. PMID: 7739682. Excluded for ineligible intervention.7739682
Torres DM, Harrison SA. Killing two birds with one stone: screening for chronic hepatitis C at the time of colonoscopy in the baby boomer cohort. Am J Gastroenterol. 2013;108(6):990–2. doi: 10.1038/ajg.2013.54. PMID: 23735918. Excluded for not a study: letter, editorial, non-systematic review article, no original data.23735918
Torres HA, Mahale P, Blechacz B, . Effect of hepatitis C virus infection in patients with cancer: addressing a neglected population. J Natl Compr Canc Netw. 2015;13(1):41–50. PMID: 25583768. Excluded for ineligible population.25583768
Tovo PA, Palomba E, Ferraris G, . Increased risk of maternal-infant hepatitis C virus transmission for women coinfected with human immunodeficiency virus type 1. Italian Study Group for HCV infection in children. Clin Infect Dis. 1997;25(5):1121–4. PMID: 9402369. Excluded for insufficient statistical analysis.9402369
Toyoda H, Atsukawa M, Takaguchi K, . Real-world virological efficacy and safety of elbasvir and grazoprevir in patients with chronic hepatitis C virus genotype 1 infection in Japan. J Gastroenterol. 2018;08:08. doi: 10.1007/s00535-018-1473-z. PMID: 29740665. Excluded for ineligible study design for Key Question.29740665
Toyoda H, Kumada T, Tada T, . Risk factors of hepatocellular carcinoma development in non-cirrhotic patients with sustained virologic response for chronic hepatitis C virus infection. J Gastroenterol Hepatol. 2015;30(7):1183–9. doi: 10.1111/jgh.12915. PMID: 25678094. Excluded for ineligible comparator.25678094
Toyoda H, Kumada T, Tada T, . Safety and efficacy of dual direct-acting antiviral therapy (daclatasvir and asunaprevir) for chronic hepatitis C virus genotype 1 infection in patients on hemodialysis. J Gastroenterol. 2016;51(7):741–7. doi: 10.1007/s00535-016-1174-4. PMID: 26872889. Excluded for ineligible intervention.26872889
Traynor K. Sofosbuvir approved for chronic hepatitis C infection. Am J Health Syst Pharm. 2014;71(2):90. doi: 10.2146/news140006. PMID: 24375596. Excluded for not a study: letter, editorial, non-systematic review article, no original data.24375596
Trepka MJ, Zhang G, Leguen F, . Benefits and adverse effects of hepatitis C screening: early results of a screening program. J Public Health Manag Pract. 2007;13(3):263–9. doi: 10.1097/01.PHH.0000267684.23529.2c. PMID: 17435493. Excluded for poor quality.17435493
Truchi R, Gelsi E, Cherikh F, . Hepatitis C virus cure as motivation for alcohol withdrawal? Hepatology. 2013;57(4):1678. doi: 10.1002/hep.25659. PMID: 22334280. Excluded for not a study: letter, editorial, non-systematic review article, no original data.22334280
Tsuji K, Kurosaki M, Itakura J, . Real-world efficacy and safety of ledipasvir and sofosbuvir in patients with hepatitis C virus genotype 1 infection: a nationwide multicenter study by the Japanese Red Cross Liver Study Group. J Gastroenterol. 2018;53(10):1142–50. doi: 10.1007/s00535-018-1455-1. PMID: 29626296. Excluded for ineligible study design for Key Question.29626296
Tsujita E, Yamashita Y, Takeishi K, . Second hepatectomy for recurrent hepatocellular carcinoma achieved sustained virological response to interferon therapy for hepatitis C. Hepatogastroenterology. 2013;60(128):2048–54. doi: 10.5754/hge13382. PMID: 24088310. Excluded for ineligible population.24088310
Turer E, Rockey DC, Singal AG. A potential novel use for direct antiviral therapy. Hepatology. 2013;57(1):414–5. doi: 10.1002/hep.26145. PMID: 23172611. Excluded for not a study: letter, editorial, non-systematic review article, no original data.23172611
Turner BJ, Taylor BS, Hanson J, . High priority for hepatitis C screening in safety net hospitals: results from a prospective cohort of 4582 hospitalized baby boomers. Hepatology. 2015;62(5):1388–95. doi: 10.1002/hep.28018. PMID: 26250753. Excluded for ineligible population.26250753
Uojima H, Kobayashi S, Hidaka H, . Efficacy and tolerability of ombitasvir/paritaprevir/ritonavir in HCV genotype 1-infected elderly Japanese patients. Ann Hepatol. 2018;18(1):109–15. doi: 10.5604/01.3001.0012.7868. PMID: 30596630. Excluded for ineligible population.
Vafiadis I, Trilianos P, Vlachogiannakos J, . Efficacy and safety of interferon-based therapy in the treatment of adult thalassemic patients with chronic hepatitis C: a 12 years audit. Ann Hepatol. 2013;12(4):364–70. PMID: 23813130. Excluded for ineligible outcome.23619252
Valla DC, Chevallier M, Marcellin P, . Treatment of hepatitis C virus-related cirrhosis: a randomized, controlled trial of interferon alfa-2b versus no treatment. Hepatology. 1999;29(6):1870–5. doi: 10.1002/hep.510290616. PMID: 10347132. Excluded for ineligible population.10347132
van der Meer AJ. Achieving sustained virological response: what’s the impact on further hepatitis C virus-related disease? Expert Rev Gastroenterol Hepatol. 2015;9(5):559–66. doi: 10.1586/17474124.2015.1001366. PMID: 25579804. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25579804
van der Meer AJ, Veldt BJ, Feld JJ, . Association between sustained virological response and all-cause mortality among patients with chronic hepatitis C and advanced hepatic fibrosis. JAMA. 2012;308(24):2584–93. doi: 10.1001/jama.2012.144878. PMID: 23268517. Excluded for ineligible population.23268517
Vashakidze E, Imnadze T. Combined antiviral treatment of hepatitis C virus infection with pegylated interferon (Peg-Ifn) a-2a (Pegferon) and ribavirin (Copegus) in inmates. Georgian Med. 2017 (264):86–90. PMID: 28480857. Excluded for ineligible intervention.28480857
Veldt BJ, Heathcote EJ, Wedemeyer H, . Sustained virologic response and clinical outcomes in patients with chronic hepatitis C and advanced fibrosis. Ann Intern Med. 2007;147(10):677–84. PMID: 18025443. Excluded for ineligible population.18025443
Vermehren J, Peiffer KH, Welsch C, . The efficacy and safety of direct acting antiviral treatment and clinical significance of drug-drug interactions in elderly patients with chronic hepatitis C virus infection. Aliment Pharmacol Ther. 2016;44(8):856–65. doi: 10.1111/apt.13769. PMID: 27549000. Excluded for ineligible study design for Key Question.27549000
Vermehren J, Schlosser B, Domke D, . High prevalence of anti-HCV antibodies in two metropolitan emergency departments in Germany: a prospective screening analysis of 28,809 patients. PLoS One. 2012;7(7):e41206. doi: 10.1371/journal.pone.0041206. PMID: 22848445. Excluded for ineligible study design for Key Question.22848445
Vierling JM, Zeuzem S, Poordad F, . Safety and efficacy of boceprevir/peginterferon/ribavirin for HCV G1 compensated cirrhotics: meta-analysis of 5 trials. J Hepatol. 2014;61(2):200–9. doi: 10.1016/j.jhep.2014.03.022. PMID: 24747798. Excluded for ineligible population.24747798
Virabhak S, Yasui K, Yamazaki K, . Cost-effectiveness of direct-acting antiviral regimen ombitasvir/paritaprevir/ritonavir in treatment-naive and treatment-experienced patients infected with chronic hepatitis C virus genotype 1b in Japan. J Med Econ. 2016;19(12):1144–56. doi: 10.1080/13696998.2016.1206908. PMID: 27348464. Excluded for ineligible study design for Key Question.27348464
Virlogeux V, Choupeaux L, Pradat P, . Sofosbuvir plus daclatasvir with or without ribavirin for chronic hepatitis C infection: impact of drug concentration on viral load decay. Dig Liver Dis. 2016;48(11):1351–6. doi: 10.1016/j.dld.2016.07.014. PMID: 27498075. Excluded for ineligible study design for Key Question.27498075
Voelker R. Birth cohort screening may help find hepatitis C cases. JAMA. 2012;307(12):1242. doi: 10.1001/jama.2012.337. PMID: 22453559. Excluded for not a study: letter, editorial, non-systematic review article, no original data.22453559
von Felden J, Vermehren J, Ingiliz P, . High efficacy of sofosbuvir/velpatasvir and impact of baseline resistance-associated substitutions in hepatitis C genotype 3 infection. Aliment Pharmacol Ther. 2018;47(9):1288–95. doi: 10.1111/apt.14592. PMID: 29536554. Excluded for ineligible population.29536554
von Wagner M, Huber M, Berg T, . Peginterferon-alpha-2a (40KD) and ribavirin for 16 or 24 weeks in patients with genotype 2 or 3 chronic hepatitis C. Gastroenterology. 2005;129(2):522–7. doi: 10.1016/j.gastro.2005.05.008. PMID: 16083709. Excluded for outdated medication.16083709
Vukovic VR, Baskic D, Mijailovic Z, . Association between risk factors, basal viral load, virus genotype and the degree of liver fibrosis with the response to the therapy in patients with chronic hepatitis C virus infection. Vojnosanit Pregl. 2015;72(6):505–9. PMID: 26226722. Excluded for ineligible outcome.26226722
Vuppalanchi R, Kwo PY. The cost-effectiveness of birth cohort screening for hepatitis C antibody in US primary care settings. Gastroenterology. 2013;144(2):457–9. doi: 10.1053/j.gastro.2012.12.013. PMID: 23260498. Excluded for not a study: letter, editorial, non-systematic review article, no original data.23260498
Walker DR, Pedrosa MC, Manthena SR, . Early view of the effectiveness of new direct-acting antiviral (DAA) regimens in patients with hepatitis C virus (HCV). Adv Ther. 2015;32(11):1117–27. doi: 10.1007/s12325-015-0258-5. PMID: 26538232. Excluded for ineligible population.26538232
Walsh CE, Workowski K, Terrault NA, . Ledipasvir-sofosbuvir and sofosbuvir plus ribavirin in patients with chronic hepatitis C and bleeding disorders. Haemophilia. 2017;23(2):198–206. doi: 10.1111/hae.13178. PMID: 28124511. Excluded for ineligible population.28124511
Wang C, Sun JH, O’Boyle DR, 2nd, . Persistence of resistant variants in hepatitis C virus-infected patients treated with the NS5A replication complex inhibitor daclatasvir. Antimicrob Agents Chemother. 2013;57(5):2054–65. doi: 10.1128/AAC.02494-12. PMID: 23403428. Excluded for ineligible intervention.23403428
Wang X, Liu F, Wei F, . Efficacy and safety of pegylated interferon plus ribavirin therapy for chronic hepatitis C genotype 6: a meta-analysis. PLoS One. 2014;9(6):e100128. doi: 10.1371/journal.pone.0100128. PMID: 24963667. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.24963667
Ware JE, Jr., Bayliss MS, Mannocchia M, . Health-related quality of life in chronic hepatitis C: impact of disease and treatment response. The Interventional Therapy Group. Hepatology. 1999;30(2):550–5. doi: 10.1002/hep.510300203. PMID: 10421667. Excluded for ineligible outcome.10421667
Waruingi W, Mhanna MJ, Kumar D, . Hepatitis C virus universal screening versus risk based selective screening during pregnancy. J Neonatal Perinatal Med. 2015;8(4):371–8. doi: 10.3233/NPM-15915024. PMID: 26836823. Excluded for poor quality.26836823
Wedemeyer H, Dore GJ, Ward JW. Estimates on HCV disease burden worldwide - filling the gaps. J Viral Hepat. 2015;22: Suppl 1:1–5. doi: 10.1111/jvh.12371. PMID: 25560838. Excluded for ineligible outcome.25560838
Wedemeyer H, Jensen D, Herring R, Jr., . PROPEL: a randomized trial of mericitabine plus peginterferon alpha-2a/ribavirin therapy in treatment-naive HCV genotype 1/4 patients. Hepatology. 2013;58(2):524–37. doi: 10.1002/hep.26274. PMID: 23348636. Excluded for ineligible intervention.23348636
Wehmeyer MH, Ingiliz P, Christensen S, . Real-world effectiveness of sofosbuvir-based treatment regimens for chronic hepatitis C genotype 3 infection: results from the multicenter German hepatitis C cohort (GECCO-03). J Med Virol. 2018;90(2):304–12. doi: 10.1002/jmv.24903. PMID: 28710853. Excluded for ineligible population.28710853
Wehmeyer MH, Jordan S, Luth S, . Efficacy and safety of sofosbuvir-based triple therapy in hepatitis C genotype 4 infection. Dig Liver Dis. 2015;47(9):811–4. doi: 10.1016/j.dld.2015.05.018. PMID: 26091766. Excluded for ineligible outcome.26091766
Wei L, Wang FS, Zhang MX, . Daclatasvir plus asunaprevir in treatment-naive patients with hepatitis C virus genotype 1b infection. World J Gastroenterol. 2018;24(12):1361–72. doi: 10.3748/wjg.v24.i12.1361. PMID: 29599611. Excluded for ineligible intervention.29599611
Weiler N, Zeuzem S, Welker MW. Concise review: Interferon-free treatment of hepatitis C virus-associated cirrhosis and liver graft infection. World J Gastroenterol. 2016;22(41):9044–56. doi: 10.3748/wjg.v22.i41.9044. PMID: 27895394. Excluded for ineligible population.27895394
Welker MW, Luhne S, Lange CM, . Lactic acidosis in patients with hepatitis C virus cirrhosis and combined ribavirin/sofosbuvir treatment. J Hepatol. 2016;64(4):790–9. doi: 10.1016/j.jhep.2015.11.034. PMID: 26658684. Excluded for ineligible population.26658684
Welzel TM, Petersen J, Herzer K, . Daclatasvir plus sofosbuvir, with or without ribavirin, achieved high sustained virological response rates in patients with HCV infection and advanced liver disease in a real-world cohort. Gut. 2016;65(11):1861–70. doi: 10.1136/gutjnl-2016-312444. PMID: 27605539. Excluded for ineligible study design for Key Question.27605539
Werner CR, Schwarz JM, Egetemeyr DP, . Second-generation direct-acting-antiviral hepatitis C virus treatment: efficacy, safety, and predictors of SVR12. World J Gastroenterol. 2016;22(35):8050–9. doi: 10.3748/wjg.v22.i35.8050. PMID: 27672299. Excluded for ineligible population.27672299
White DA, Anderson ES, Pfeil SK, . Hepatitis C virus screening and emergency department length of stay. PLoS One. 2016;11(10):e0164831. doi: 10.1371/journal.pone.0164831. PMID: 27760176. Excluded for ineligible study design for Key Question.27760176
White DA, Anderson ES, Pfeil SK, . Results of a rapid hepatitis C virus screening and diagnostic testing program in an urban emergency department. Ann Emerg Med. 2016;67(1):119–28. doi: 10.1016/j.annemergmed.2015.06.023. PMID: 26253712. Excluded for ineligible outcome.26253712
Wilder JM, Jeffers LJ, Ravendhran N, . Safety and efficacy of ledipasvir-sofosbuvir in black patients with hepatitis C virus infection: a retrospective analysis of phase 3 data. Hepatology. 2016;63(2):437–44. doi: 10.1002/hep.28334. PMID: 26547499. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26547499
Winckler FC, Braz AMM, Silva VND, . Influence of the inflammatory response on treatment of hepatitis C with triple therapy. Rev Soc Bras Med Trop. 2018;51(6):731–6. doi: 10.1590/0037-8682-0137-2018. PMID: 30517525. Excluded for ineligible population.430517525
Wisloff T, White R, Dalgard O, . Feasibility of reaching world health organization targets for hepatitis C and the cost-effectiveness of alternative strategies. J Viral Hepat. 2018;25(9):1066–77. doi: 10.1111/jvh.12904. PMID: 29624813. Excluded for ineligible intervention.29624813
Wong VW, Wong GL, Chim AM, . Targeted hepatitis C screening among ex-injection drug users in the community. J Gastroenterol Hepatol. 2014;29(1):116–20. doi: 10.1111/jgh.12355. PMID: 24033786. Excluded for ineligible country.24033786
Woodrell C, Weiss J, Branch A, . Primary care-based hepatitis C treatment outcomes with first-generation direct-acting agents. J Addict Med. 2015;9(5):405–10. doi: 10.1097/ADM.0000000000000147. PMID: 26291545. Excluded for ineligible intervention.26291545
Wu CJ, Roytman MM, Hong LK, . Real-world experience with sofosbuvir-based regimens for chronic hepatitis C, including patients with factors previously associated with inferior treatment response. Hawaii J Med Public Health. 2015;74(9 Suppl 2):3–7. PMID: 26793407. Excluded for ineligible intervention.26793407
Wu CK, Chang KC, Hung CH, . Dynamic alpha-fetoprotein, platelets and AST-to-platelet ratio index predict hepatocellular carcinoma in chronic hepatitis C patients with sustained virological response after antiviral therapy. J Antimicrob Chemother. 2016;71(7):1943–7. doi: 10.1093/jac/dkw097. PMID: 27073265. Excluded for ineligible intervention.27073265
Wu CK, Chang KC, Tseng PL, . Comparison of therapeutic response and clinical outcome between HCV patients with normal and abnormal alanine transaminase levels. PLoS One. 2016;11(3):e0142378. doi: 10.1371/journal.pone.0142378. PMID: 26968010. Excluded for ineligible study design for Key Question.26968010
Wyles D, Brau N, Kottilil S, . Sofosbuvir and velpatasvir for the treatment of hepatitis C virus in patients coinfected with human immunodeficiency virus type 1: an open-label, phase 3 study. Clin Infect Dis. 2017;65(1):6–12. doi: 10.1093/cid/cix260. PMID: 28369210. Excluded for ineligible population.28369210
Wyles DL, Rodriguez-Torres M, Lawitz E, . All-oral combination of ledipasvir, vedroprevir, tegobuvir, and ribavirin in treatment-naive patients with genotype 1 HCV infection. Hepatology. 2014;60(1):56–64. doi: 10.1002/hep.27053. PMID: 24501005. Excluded for ineligible intervention.24501005
Xu F, Leidner AJ, Tong X, . Estimating the number of patients infected with chronic HCV in the United States who meet highest or high-priority treatment criteria. Am J Public Health. 2015;105(7):1285–9. doi: 10.2105/AJPH.2015.302652. PMID: 25973816. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25973816
Yakoot M, Abdo AM, Yousry A, . Very rapid virologic response and early HCV response kinetics, as quick measures to compare efficacy and guide a personalized response-guided therapy. Drug Des Devel Ther. 2016;10:2659–67. doi: 10.2147/DDDT.S111496. PMID: 27601883. Excluded for ineligible intervention.27601883
Yamashita N, Ohho A, Yamasaki A, . Hepatocarcinogenesis in chronic hepatitis C patients achieving a sustained virological response to interferon: significance of lifelong periodic cancer screening for improving outcomes. J Gastroenterol. 2014;49(11):1504–13. doi: 10.1007/s00535-013-0921-z. PMID: 24317936. Excluded for poor quality.24317936
Yang CHT, Goel A, Ahmed A. Clinical utility of ledipasvir/sofosbuvir in the treatment of adolescents and children with hepatitis C. Adolesc Helath Med Ther. 2018;9:103–10. doi: 10.2147/AHMT.S147896. PMID: 30104913. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.30104913
Yang D, Liang HJ, Li D, . The efficacy and safety of telaprevir-based regimens for treating chronic hepatitis C virus genotype 1 infection: a meta-analysis of randomized trials. Intern Med. 2013;52(6):653–60. PMID: 23503406. Excluded for ineligible intervention.23503406
Yang S, Britt RB, Hashem MG, . Outcomes of pharmacy-led hepatitis C direct-acting antiviral utilization management at a veterans affairs medical center. J Manag Care Spec Pharm. 2017;23(3):364–9. doi: 10.18553/jmcp.2017.23.3.364. PMID: 28230455. Excluded for ineligible intervention.28230455
Yang YH, Chen WC, Tsan YT, . Statin use and the risk of cirrhosis development in patients with hepatitis C virus infection. J Hepatol. 2015;63(5):1111–7. doi: 10.1016/j.jhep.2015.07.006. PMID: 26196278. Excluded for ineligible intervention.26196278
Yang YM, Choi EJ. Efficacy and safety outcomes of sofosbuvir-based treatment regimens for hepatitis C virus-infected patients with or without cirrhosis from phase III clinical trials. Ther Clin Risk Manag. 2017;13:477–97. doi: 10.2147/tcrm.S134818. PMID: 28442915. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.28442915
Yano M, Kumada H, Kage M, . The long-term pathological evolution of chronic hepatitis C. Hepatology. 1996;23(6):1334–40. doi: 10.1002/hep.510230607. PMID: 8675148. Excluded for ineligible outcome.8675148
Yao Y, Yue M, Wang J, . Grazoprevir and elbasvir in patients with genotype 1 hepatitis C virus infection: a comprehensive efficacy and safety analysis. Can J Gastroenterol Hepatol. 2017;2017:8186275. doi: 10.1155/2017/8186275. PMID: 28164081. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.28164081
Yenice N, Mehtap O, Gumrah M, . The efficacy of pegylated interferon alpha 2a or 2b plus ribavirin in chronic hepatitis C patients. Turk J Gastroenterol. 2006;17(2):94–8. PMID: 16830289. Excluded for outdated medication.16830289
Yoshida EM, Sulkowski MS, Gane EJ, . Concordance of sustained virological response 4, 12, and 24 weeks post-treatment with sofosbuvir-containing regimens for hepatitis C virus. Hepatology. 2015;61(1):41–5. doi: 10.1002/hep.27366. PMID: 25314116. Excluded for ineligible intervention.25314116
Young J, Weis N, Hofer H, . The effectiveness of daclatasvir based therapy in European patients with chronic hepatitis C and advanced liver disease. BMC Infect Dis. 2017;17(1):45. doi: 10.1186/s12879-016-2106-x. PMID: 28061762. Excluded for ineligible population.28061762
Younossi Z, Blissett D, Blissett R, . In an era of highly effective treatment, hepatitis C screening of the United States general population should be considered. Liver Int. 2018;38(2):258–65. doi: 10.1111/liv.13519. PMID: 28719013. Excluded for not a study: letter, editorial, non-systematic review article, no original data.28719013
Younossi Z, Henry L. Systematic review: patient-reported outcomes in chronic hepatitis C-the impact of liver disease and new treatment regimens. Aliment Pharmacol Ther. 2015;41(6):497–520. doi: 10.1111/apt.13090. PMID: 25616122. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.25616122
Younossi ZM. The efficacy of new antiviral regimens for hepatitis C infection: Evidence from a systematic review. Hepatology. 2018;67(3):1160–2. doi: 10.1002/hep.29580. PMID: 29023922. Excluded for not a study: letter, editorial, non-systematic review article, no original data.29023922
Younossi ZM, LaLuna LL, Santoro JJ, . Implementation of baby boomer hepatitis C screening and linking to care in gastroenterology practices: a multi-center pilot study. BMC Gastroenterol. 2016;16:45. doi: 10.1186/s12876-016-0438-z. PMID: 27044402. Excluded for ineligible study design for Key Question.27044402
Younossi ZM, Stepanova M, Chan HL, . Patient-reported outcomes in Asian patients with chronic hepatitis C treated with ledipasvir and sofosbuvir. Medicine. 2016;95(9):e2702. doi: 10.1097/MD.0000000000002702. PMID: 26945356. Excluded for ineligible population.26945356
Younossi ZM, Stepanova M, Esteban R, . Superiority of interferon-free regimens for chronic hepatitis C: the effect on health-related quality of life and qork productivity. Medicine. 2017;96(7):e5914. doi: 10.1097/MD.0000000000005914. PMID: 28207507. Excluded for ineligible intervention.28207507
Younossi ZM, Stepanova M, Feld J, . Sofosbuvir/velpatasvir improves patient-reported outcomes in HCV patients: results from ASTRAL-1 placebo-controlled trial. J Hepatol. 2016;65(1):33–9. doi: 10.1016/j.jhep.2016.02.042. PMID: 26956698. Excluded for not a study: letter, editorial, non-systematic review article, no original data.26956698
Younossi ZM, Stepanova M, Henry L, . Sofosbuvir and ledipasvir are associated with high sustained virologic response and improvement of health-related quality of life in East Asian patients with hepatitis C virus infection. J Viral Hepat. 2018;25(12):1429–37. doi: 10.1111/jvh.12965. PMID: 29974665. Excluded for ineligible population.29974665
Younossi ZM, Stepanova M, Marcellin P, . Treatment with ledipasvir and sofosbuvir improves patient-reported outcomes: results from the ION-1, -2, and -3 clinical trials. Hepatology. 2015;61(6):1798–808. doi: 10.1002/hep.27724. PMID: 25627448. Excluded for not a study: letter, editorial, non-systematic review article, no original data.25627448
Younossi ZM, Stepanova M, Nader F, . Patient-reported outcomes of elderly adults with chronic hepatitis C treated with interferon- and ribavirin-free regimens. J Am Geriatr Soc. 2016;64(2):386–93. doi: 10.1111/jgs.13928. PMID: 26825683. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26825683
Younossi ZM, Stepanova M, Nader F, . Patient-reported outcomes in chronic hepatitis C patients with cirrhosis treated with sofosbuvir-containing regimens. Hepatology. 2014;59(6):2161–9. doi: 10.1002/hep.27161. PMID: 24710669. Excluded for ineligible population.24710669
Younossi ZM, Stepanova M, Nader F, . The patient’s journey with chronic hepatitis C from interferon plus ribavirin to interferon- and ribavirin-free regimens: a study of health-related quality of life. Aliment Pharmacol Ther. 2015;42(3):286–95. doi: 10.1111/apt.13269. PMID: 26059536. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.26059536
Younossi ZM, Stepanova M, Omata M, . Quality of life of Japanese patients with chronic hepatitis C treated with ledipasvir and sofosbuvir. Medicine. 2016;95(33):e4243. doi: 10.1097/MD.0000000000004243. PMID: 27537553. Excluded for ineligible population.27537553
Younossi ZM, Stepanova M, Pol S, . The impact of ledipasvir/sofosbuvir on patient-reported outcomes in cirrhotic patients with chronic hepatitis C: the SIRIUS study. Liver Int. 2016;36(1):42–8. doi: 10.1111/liv.12886. PMID: 26059860. Excluded for ineligible population.26059860
Younossi ZM, Tanaka A, Eguchi Y, . Treatment of hepatitis C virus leads to economic gains related to reduction in cases of hepatocellular carcinoma and decompensated cirrhosis in Japan. J Viral Hepat. 2018;25(8):945–51. doi: 10.1111/jvh.12886. PMID: 29478258. Excluded for ineligible intervention.29478258
Youssef NF, El Kassas M, Farag A, . Health-related quality of life in patients with chronic hepatitis C receiving sofosbuvir-based treatment, with and without interferon: a prospective observational study in Egypt. BMC Gastroenterol. 2017;17(1):18. doi: 10.1186/s12876-017-0581-1. PMID: 28109264. Excluded for ineligible intervention.28109264
Yu ML, Dai CY, Huang JF, . A randomised study of peginterferon and ribavirin for 16 versus 24 weeks in patients with genotype 2 chronic hepatitis C. Gut. 2007;56(4):553–9. doi: 10.1136/gut.2006.102558. PMID: 16956917. Excluded for outdated medication.16956917
Zamor PJ, Vierling J, Ghalib R, . Elbasvir/grazoprevir in black adults with hepatitis C virus infection: a pooled analysis of phase 2/3 clinical trials. Am J Gastroenterol. 2018;113(6):863–71. doi: 10.1038/s41395-018-0053-4. PMID: 29695828. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.29695828
Zanetti AR, Tanzi E, Newell ML. Mother-to-infant transmission of hepatitis C virus. J Hepatol. 1999;31: Suppl 1:96–100. PMID: 10622569. Excluded for poor quality.10622569
Zanetti AR, Tanzi E, Romano L, . A prospective study on mother-to-infant transmission of hepatitis C virus. Intervirology. 1998;41(4–5):208–12. doi: 10.1159/000024938. PMID: 10213898. Excluded for poor quality.10213898
Zanini B, Benini F, Pigozzi MG, . Addicts with chronic hepatitis C: difficult to reach, manage or treat? World J Gastroenterol. 2013;19(44):8011–9. doi: 10.3748/wjg.v19.i44.8011. PMID: 24307794. Excluded for ineligible intervention.24307794
Zeuzem S, Berg T, Gane E, . Simeprevir increases rate of sustained virologic response among treatment-experienced patients with HCV genotype-1 infection: a phase IIb trial. Gastroenterology. 2014;146(2):430–41.e6. doi: 10.1053/j.gastro.2013.10.058. PMID: 24184810. Excluded for ineligible population.24184810
Zeuzem S, Diago M, Gane E, . Peginterferon alfa-2a (40 kilodaltons) and ribavirin in patients with chronic hepatitis C and normal aminotransferase levels. Gastroenterology. 2004;127(6):1724–32. PMID: 15578510. Excluded for outdated medication.15578510
Zeuzem S, Hezode C, Bronowicki JP, . Daclatasvir plus simeprevir with or without ribavirin for the treatment of chronic hepatitis C virus genotype 1 infection. J Hepatol. 2016;64(2):292–300. doi: 10.1016/j.jhep.2015.09.024. PMID: 26453968. Excluded for ineligible intervention.26453968
Zeuzem S, Serfaty L, Vierling J, . The safety and efficacy of elbasvir and grazoprevir in participants with hepatitis C virus genotype 1b infection. J Gastroenterol. 2018;53(5):679–88. doi: 10.1007/s00535-018-1429-3. PMID: 29344726. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.29344726
Zuniga IA, Chen JJ, Lane DS, . Analysis of a hepatitis C screening programme for US veterans. Epidemiol Infect. 2006;134(2):249–57. doi: 10.1017/s095026880500498x. PMID: 16490127. Excluded for poor quality.16490127
Zuure F, Davidovich U, Kok G, . Evaluation of a risk assessment questionnaire to assist hepatitis C screening in the general population. Euro Surveill. 2010;15(15):19539. PMID: 20429995. Excluded for poor quality.20429995
Zuure FR, Urbanus AT, Langendam MW, . Outcomes of hepatitis C screening programs targeted at risk groups hidden in the general population: a systematic review. BMC Public Health. 2014;14:66. doi: 10.1186/1471-2458-14-66. PMID: 24450797. Excluded for systematic review or meta-analysis used as a source document only to identify individual studies.24450797

## Appendix A6 Criteria for Assessing Internal Validity of Individual Studies

### Randomized Controlled Trials (RCTs) and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  - For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  - For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.
Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.
Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.
Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor: Has a fatal flaw, such as: uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes