# References

1 Patnode CD, Perdue LA, Rushkin M, . Screening for Illicit Drug Use, Including Nonmedical Use of Prescription Drugs: An Updated Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 186. Prepared by Kaiser Permanente Research Affiliates Evidence-based Practice Center. Rockville, MD: Agency for Healthcare Research and Quality. Available at: https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryDraft/drug-use-in-adolescents-and-adults-including-pregnant-women-screening?ds=1&s=drug. 2019.
2 Polen MR, Whitlock EP, Wisdom JP, . Screening in Primary Care Settings for Illicit Drug Use: Staged Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 58, Part 1. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024.) AHRQ Publication No. 08-05108-EF-s. Rockville, MD, Agency for Healthcare Research and Quality. January 2008.
3 U.S. Preventive Services Task Force. Illicit and Nonmedical Drug Use in Children, Adolescents, and Young Adults: Preventive Interventions. 2018. https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryDraft/illicit-and-nonmedical-prescription-drug-use-in-children-and-adolescents-interventions?ds=1&s=drug%20use. Accessed September 9, 2018.
4 Bernstein J, Bernstein E, Tassiopoulos K, . Brief motivational intervention at a clinic visit reduces cocaine and heroin use. Drug Alcohol Depend. 2005;77(1):49–59. doi: 10.1016/j.drugalcdep.2004.07.006. PMID: 15607841.15607841
5 Guo S, Jiang Z, Wu Y. Efficacy of naltrexone hydrochloride for preventing relapse among opiate-dependent patients after detoxification. Hong Kong J Paediatr. 2001;11(4):2–8+28.
6 Schwartz RP, Highfield DA, Jaffe JH, . A randomized controlled trial of interim methadone maintenance. Arch Gen Psychiatry. 2006;63(1):102–9. PMID: 16389204.16389204
7 U.S. Preventive Services Task Force. Final Recommendation Statement. Drug Use, Illicit: Screening. 2008. https://www.uspreventiveservicestaskforce.org/Page/Document/RecommendationStatementFinal/drug-use-illicit-screening. Accessed September 11, 2018.
8 United States Department of Veterans Affairs. VA/DoD Clinical Practice Guideline for the Management of Substance Use Disorders. 2015. https://www.healthquality.va.gov/guidelines/MH/sud/VADODSUDCPGRevised22216.pdf Accessed April 26, 2019.
9 American Society Of Addiction Medicine. The National Practice Guideline for the Use of Medications in the Treatment of Addiction Involving Opioid Use. Sep-Oct 2015. https://www.asam.org/docs/default-source/practice-support/guidelines-and-consensus-docs/asam-national-practice-guideline-supplement.pdf Accessed April 26, 2019.
10 Substance Abuse and Mental Health Services Administration. Tip 63 Medications for Opioid Use Disorder. 2018. https://store.samhsa.gov/product/TIP-63-Medications-for-Opioid-Use-Disorder-Executive-Summary/sma18-5063exsumm Accessed April 26, 2019.
11 Korthuis PT, McCarty D, Weimer M, . Primary care-based models for the treatment of opioid use disorder: a scoping review. Ann Intern Med. 2017;166(4):268–78. doi: 10.7326/m16-2149. PMID: 27919103.27919103
12 Friedmann PD, Schwartz RP. Just call it “treatment”. Addict Sci Clin Pract. 2012;7:10. doi: 10.1186/1940-0640-7-10. PMID: 23186149.23186149
13 Saitz R. Things that work, things that don’t work, and things that matter-including words. J Addict Med. 2015;9(6):429–30. doi: 10.1097/adm.0000000000000160. PMID: 26517322.26517322
14 Fiellin DA, Pantalon MV, Chawarski MC, . Counseling plus buprenorphine-naloxone maintenance therapy for opioid dependence. N Engl J Med. 2006;355(4):365–74. PMID: 16870915.16870915
15 Carroll KM, Weiss RD. The role of behavioral interventions in buprenorphine maintenance treatment: a review. Am J Psychiatry. 2017;174(8):738–47. doi: 10.1176/appi.ajp.2016.16070792. PMID: 27978771.27978771
16 Institute of Medicine. Psychosocial interventions for mental and substance use disorders: A framework for establishing evidence-based standards. Washington, DC: The National Academies Press; 2015. https://www.integration.samhsa.gov/news/Psychosocial_Interventions_for_Mental_and_Substance_Use.pdf Accessed April 26, 2019.
17 National Institutes of Health. Principles of Adolescent Substance Use Disorder Treatment: A Research-Based Guide. 2014. https://www.drugabuse.gov/publications/principles-adolescent-substance-use-disorder-treatment-research-based-guide/evidence-based-approaches-to-treating-adolescent-substance-use-disorders. Accessed September 12, 2018.
18 SAMHSA-HRSA Center for Integrated Health Solutions. SBIRT: Brief Intervention. https://www.integration.samhsa.gov/clinical-practice/sbirt/brief-interventions. Accessed September 12, 2018.
19 Chou R, Korthuis P, McCarty D, . Management of Suspected Opioid Overdose With Naloxone by Emergency Medical Services Personnel. Comparative Effectiveness Review No. 193. (Prepared by the Pacific Northwest Evidence-based Practice Center under Contract No. 290-2015-00009-I.) AHRQ Publication No. 17(18)-EHC025-EF. Rockville, MD: Agency for Healthcare Research and Quality; November 2017. https://effectivehealthcare.ahrq.gov/sites/default/files/pdf/cer-193-naloxone-final_1.pdf Accessed April 26, 2019.
20 Chou R, Korthuis PT, McCarty D, . Management of Suspected Opioid Overdose With Naloxone in Out-of-Hospital Settings: A Systematic Review. Ann Intern Med. 2017;167(12):867–75. doi: 10.7326/m17-2224. PMID: 29181532.29181532
21 Clark AK, Wilder CM, Winstanley EL. A systematic review of community opioid overdose prevention and naloxone distribution programs. J Addict Med. 2014;8(3):153–63. doi: 10.1097/ADM.0000000000000034. PMID: 24874759.24874759
22 Giglio RE, Li G, DiMaggio CJ. Effectiveness of bystander naloxone administration and overdose education programs: a meta-analysis. Inj Epidemiol. 2015;2(1):10. doi: 10.1186/s40621-015-0041-8. PMID: 27747742.27747742
23 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. http://www.uspreventiveservicestaskforce.org/Home/GetFile/6/7/procedure-manual_2016/pdf. Accessed August 29, 2018.
24 Knight JR, Sherritt L, Gibson EB, . Effect of computer-based substance use screening and behavioral counseling vs. usual care for youths in pediatric primary care: a pilot randomized trial. JAMA Netw Open. 2019;2(6):e196258. doi: doi: 10.1001/jamanetworkopen.2019.6258.31225897
25 Krupitsky E, Zvartau E, Blokhina E, . Randomized trial of long-acting sustained-release naltrexone implant vs oral naltrexone or placebo for preventing relapse to opioid dependence. Arch Gen Psychiatry. 2012;69(9):973–81. doi: 10.1001/archgenpsychiatry.2012.1a. PMID: 22945623.22945623
26 Krupitsky E, Nunes EV, Ling W, . Injectable extended-release naltrexone for opioid dependence: a double-blind, placebo-controlled, multicentre randomised trial. Lancet. 2011;377(9776):1506–13. doi: 10.1016/S0140-6736(11)60358-9. PMID: 21529928.21529928
27 Mitchell SG, Gryczynski J, Schwartz RP, . Changes in quality of life following buprenorphine treatment: Relationship with treatment retention and illicit opioid use. J Psychoactive Drugs. 2015;47(2):149–57. doi: 10.1080/02791072.2015.1014948. PMID: 25950595.25950595
28 Perreault M, Julien D, White ND, . Psychological predictors of retention in a low-threshold methadone maintenance treatment for opioid addicts: a 1-year follow-up study. Subst Use Misuse. 2015;50(1):24–31. doi: 10.3109/10826084.2014.957769. PMID: 25245107.25245107
29 Simpson DD, Joe GW, Rowan-Szal GA. Drug abuse treatment retention and process effects on follow-up outcomes. Drug Alcohol Depend. 1997;47(3):227–35. PMID: 9306048.9306048
30 Babor TF, Christiansen K, Donaldson J, . Brief treatments for cannabis dependence: Findings from a randomized multisite trial. J Consult Clin Psychol. 2004;72(3):455–66. doi: 10.1037/0022-006x.72.3.455. PMID: 15279529.15279529
31 Copeland J, Swift W, Roffman R, . A randomized controlled trial of brief cognitive-behavioral interventions for cannabis use disorder. J Subst Abuse Treat. 2001a;21(2):55–64; discussion 5-6. PMID: 11551733.11551733
32 McCambridge J, Strang J. Deterioration over time in effect of motivational interviewing in reducing drug consumption and related risk among young people. Addiction. 2005;100(4):470–8. PMID: 15784061.15784061
33 Stephens RS, Roffman RA, Curtin L. Comparison of extended versus brief treatments for marijuana use. J Consult Clin Psychol. 2000;68(5):898–908. PMID: 11068976.11068976
34 Arndt IO, Dorozynsky L, Woody GE, . Desipramine treatment of cocaine dependence in methadone-maintained patients. Arch Gen Psychiatry. 1992;49(11):888–93. PMID: 1444727.1444727
35 Assadi SM, Radgoodarzi R, Ahmadi-Abhari SA. Baclofen for maintenance treatment of opioid dependence: a randomized double-blind placebo-controlled clinical trial [ISRCTN32121581]. BMC Psychiatry. 2003;3:16. doi: 10.1186/1471-244x-3-16. PMID: 14624703.14624703
36 Batki SL, Washburn AM, Delucchi K, . A controlled trial of fluoxetine in crack cocaine dependence. Drug Alcohol Depend. 1996;41(2):137–42. PMID: 8809502.8809502
37 Feingold A, Oliveto A, Schottenfeld R, . Utility of crossover designs in clinical trials: efficacy of desipramine vs. placebo in opioid-dependent cocaine abusers. Am J Addict. 2002;11(2):111–23. PMID: 12028741.12028741
38 Passos SR, Camacho LA, Lopes CS, . Nefazodone in out-patient treatment of inhaled cocaine dependence: a randomized double-blind placebo-controlled trial. Addiction. 2005;100(4):489–94. doi: 10.1111/j.1360-0443.2005.01041.x. PMID: 15784063.15784063
39 Petrakis IL, Carroll KM, Nich C, . Disulfiram treatment for cocaine dependence in methadone-maintained opioid addicts. Addiction. 2000;95(2):219–28. PMID: 10723850.10723850
40 Avants SK, Margolin A, Holford TR, . A randomized controlled trial of auricular acupuncture for cocaine dependence. Arch Intern Med. 2000;160(15):2305–12. PMID: 10927727.10927727
41 Gruber K, Chutuape MA, Stitzer ML. Reinforcement-based intensive outpatient treatment for inner city opiate abusers: a short-term evaluation. Drug Alcohol Depend. 2000;57(3):211–23. doi: 10.1016/S0376-8716%2899%2900054-X. PMID: 10661672.10661672
42 Fudala PJ, Bridge TP, Herbert S, . Office-based treatment of opiate addiction with a sublingual-tablet formulation of buprenorphine and naloxone. N Engl J Med. 2003;349(10):949–58. PMID: 12954743.12954743
43 Johnson RE, Eissenberg T, Stitzer ML, . A placebo controlled clinical trial of buprenorphine as a treatment for opioid dependence. Drug Alcohol Depend. 1995;40(1):17–25. PMID: 8746920.8746920
44 D’Amico EJ, Parast L, Shadel WG, . Brief motivational interviewing intervention to reduce alcohol and marijuana use for at-risk adolescents in primary care. J Consult Clin Psychol. 2018;86(9):775–86. doi: 10.1037/ccp0000332. PMID: 30138016.30138016
45 Bernstein E, Edwards E, Dorfman D, . Screening and brief intervention to reduce marijuana use among youth and young adults in a pediatric emergency department. Acad Emerg Med. 2009;16(11):1174–85. doi: 10.1111/j.1553-2712.2009.00490.x. PMID: 20053238.20053238
46 Blow FC, Walton MA, Bohnert ASB, . A randomized controlled trial of brief interventions to reduce drug use among adults in a low-income urban emergency department: the HealthiER You study. Addiction. 2017;112(8):1395–405. doi: 10.1111/add.13773. PMID: 28127808.28127808
47 Bogenschutz MP, Donovan DM, Mandler RN, . Brief intervention for patients with problematic drug use presenting in emergency departments: a randomized clinical trial. JAMA Intern Med. 2014;174(11):1736–45. doi: 10.1001/jamainternmed.2014.4052. PMID: 25179753.25179753
48 Gelberg L, Andersen RM, Afifi AA, . Project QUIT (Quit Using Drugs Intervention Trial): a randomized controlled trial of a primary care-based multi-component brief intervention to reduce risky drug use. Addiction. 2015;110(11):1777–90. doi: 10.1111/add.12993. PMID: 26471159.26471159
49 Gelberg L, Andersen RM, Rico MW, . A pilot replication of QUIT, a randomized controlled trial of a brief intervention for reducing risky drug use, among Latino primary care patients. Drug Alcohol Depend. 2017;179:433–40. doi: 10.1016/j.drugalcdep.2017.04.022. PMID: 28844733.28844733
50 Gryczynski J, O’Grady KE, Mitchell SG, . Immediate versus delayed computerized brief intervention for illicit drug misuse. J Addict Med. 2016;10(5):344–51. doi: 10.1097/ADM.0000000000000248. PMID: 27504925.27504925
51 Humeniuk R, Ali R, Babor T, . A randomized controlled trial of a brief intervention for illicit drugs linked to the alcohol, smoking and substance involvement screening test (ASSIST) in clients recruited from primary health-care settings in four countries. Addiction. 2012;107(5):957–66. doi: 10.1111/j.1360-0443.2011.03740.x. PMID: 22126102.22126102
52 Lee CM, Kilmer JR, Neighbors C, . Indicated prevention for college student marijuana use: a randomized controlled trial. J Consult Clin Psychol. 2013;81(4):702–9. doi: 10.1037/a0033285. PMID: 23750464.23750464
53 Lee CM, Neighbors C, Kilmer JR, . A brief, web-based personalized feedback selective intervention for college student marijuana use: a randomized clinical trial. Psychol Addict Behav. 2010;24(2):265–73. doi: 10.1037/a0018859. PMID: 20565152.20565152
54 Martino S, Ondersma SJ, Forray A, . A randomized controlled trial of screening and brief interventions for substance misuse in reproductive health. Am J Obstet Gynecol. 2018;218(3):322.e1–.e12. doi: 10.1016/j.ajog.2017.12.005. PMID: 29247636.29247636
55 Mason M, Light J, Campbell L, . Peer network counseling with urban adolescents: a randomized controlled trial with moderate substance users. J Subst Abuse Treat. 2015;58:16–24. doi: 10.1016/j.jsat.2015.06.013. PMID: 26234955.26234955
56 Ondersma SJ, Svikis DS, Schuster CR. Computer-based brief intervention a randomized trial with postpartum women.[Erratum appears in Am J Prev Med. 2007 Jun;32(6):549]. Am J Prev Med. 2007;32(3):231–8. PMID: 17236741.17236741
57 Ondersma SJ, Svikis DS, Thacker C, . Computer-delivered indirect screening and brief intervention for drug use in the perinatal period: a randomized trial. Drug Alcohol Depend. 2018;185:271–7. doi: 10.1016/j.drugalcdep.2017.12.022. PMID: 29482051.29482051
58 Ondersma SJ, Svikis DS, Thacker LR, . Computer-delivered screening and brief intervention (e-SBI) for postpartum drug use: a randomized trial. J Subst Abuse Treat. 2014;46(1):52–9. doi: 10.1016/j.jsat.2013.07.013. PMID: 24051077.24051077
59 Palfai TP, Saitz R, Winter M, . Web-based screening and brief intervention for student marijuana use in a university health center: Pilot study to examine the implementation of eCHECKUP TO GO in different contexts. Addict Behav. 2014;39(9):1346–52. doi: 10.1016/j.addbeh.2014.04.025. PMID: 24845164.24845164
60 Poblete F, Barticevic NA, Zuzulich MS, . A randomized controlled trial of a brief intervention for alcohol and drugs linked to the alcohol, smoking and substance involvement screening test (ASSIST) in primary health care in Chile. Addiction. 2017;112(8):1462–9. doi: 10.1111/add.13808. PMID: 28239995.28239995
61 Roy-Byrne P, Bumgardner K, Krupski A, . Brief intervention for problem drug use in safety-net primary care settings: a randomized clinical trial. JAMA. 2014;312(5):492–501. doi: 10.1001/jama.2014.7860. PMID: 25096689.25096689
62 Saitz R, Palfai TP, Cheng DM, . Screening and brief intervention for drug use in primary care: the ASPIRE randomized clinical trial. JAMA. 2014;312(5):502–13. doi: 10.1001/jama.2014.7862. PMID: 25096690.25096690
63 Stein MD, Hagerty CE, Herman DS, . A brief marijuana intervention for non-treatment-seeking young adult women. J Subst Abuse Treat. 2011;40(2):189–98. doi: 10.1016/j.jsat.2010.11.001. PMID: 21185685.21185685
64 Tzilos Wernette G, Plegue M, Kahler CW, . A pilot randomized controlled trial of a computer-delivered brief intervention for substance use and risky sex during pregnancy. J Womens Health (Larchmt). 2018;27(1):83–92. doi: 10.1089/jwh.2017.6408. PMID: 28981379.28981379
65 Walton MA, Bohnert K, Resko S, . Computer and therapist based brief interventions among cannabis-using adolescents presenting to primary care: one year outcomes. Drug Alcohol Depend. 2013;132(3):646–53. doi: 10.1016/j.drugalcdep.2013.04.020. PMID: 23711998.23711998
66 Watkins KE, Ober AJ, Lamp K, . Collaborative care for opioid and alcohol use disorders in primary care: the SUMMIT randomized clinical trial. JAMA Intern Med. 2017;177(10):1480–8. doi: 10.1001/jamainternmed.2017.3947. PMID: 28846769.28846769
67 Woolard R, Baird J, Longabaugh R, . Project reduce: reducing alcohol and marijuana misuse: effects of a brief intervention in the emergency department. Addict Behav. 2013;38(3):1732–9. doi: 10.1016/j.addbeh.2012.09.006. PMID: 23261491.23261491
68 Yonkers KA, Forray A, Howell HB, . Motivational enhancement therapy coupled with cognitive behavioral therapy versus brief advice: a randomized trial for treatment of hazardous substance use in pregnancy and after delivery. Gen Hosp Psychiatry. 2012;34(5):439–49. doi: 10.1016/j.genhosppsych.2012.06.002. PMID: 22795046.22795046
69 Zahradnik A, Otto C, Crackau B, . Randomized controlled trial of a brief intervention for problematic prescription drug use in non-treatment-seeking patients. Addiction. 2009;104(1):109–17. doi: 10.1111/j.1360-0443.2008.02421.x. PMID: 19133895.19133895
70 Schottenfeld RS, Chawarski MC, Mazlan M. Maintenance treatment with buprenorphine and naltrexone for heroin dependence in Malaysia: a randomised, double-blind, placebo-controlled trial. Lancet. 2008;371(9631):2192–200. doi: 10.1016/S0140-6736(08)60954-X. PMID: 18586174.18586174
71 Cornish JW, Metzger D, Woody GE, . Naltrexone pharmacotherapy for opioid dependent federal probationers. J Subst Abuse Treat. 1997;14(6):529–34. PMID: 9437624.9437624
72 Hollister LE. Clinical evaluation of naltrexone treatment of opiate-dependent individuals. Report of the National Research Council Committee on Clinical Evaluation of Narcotic Antagonists. Arch Gen Psychiatry. 1978;35(3):335–40. PMID: 365122.365122
73 Krupitsky EM, Zvartau EE, Masalov DV, . Naltrexone for heroin dependence treatment in St. Petersburg, Russia. J Subst Abuse Treat. 2004;26(4):285–94. PMID: 15182893.15182893
74 Krupitsky EM, Zvartau EE, Masalov DV, . Naltrexone with or without fluoxetine for preventing relapse to heroin addiction in St. Petersburg, Russia. J Subst Abuse Treat. 2006;31(4):319–28. PMID: 17084785.17084785
75 Krupitsky E, Zvartau E, Blokhina E, . Naltrexone with or without guanfacine for preventing relapse to opiate addiction in St. Petersburg, Russia. Drug Alcohol Depend. 2013;132(3):674–80. doi: 10.1016/j.drugalcdep.2013.04.021. PMID: 23683793.23683793
76 Krupitsky E, Zvartau E, Blokhina E, . Anhedonia, depression, anxiety, and craving in opiate dependent patients stabilized on oral naltrexone or an extended release naltrexone implant. Am J Drug Alcohol Abuse. 2016;42(5):614–20. PMID: 27436632.27436632
77 Lerner A, Sigal M, Bacalu A, . A naltrexone double blind placebo controlled study in Israel. Isr J Psychiatry Relat Sci. 1992;29(1):36–43. PMID: 1568861.1568861
78 San L, Pomarol G, Peri JM, . Follow-up after a six-month maintenance period on naltrexone versus placebo in heroin addicts. Br J Addict. 1991;86(8):983–90. PMID: 1912753.1912753
79 Shufman EN, Porat S, Witztum E, . The efficacy of naltrexone in preventing reabuse of heroin after detoxification. Biol Psychiatry. 1994;35(12):935–45. PMID: 8080893.8080893
80 Stella L, D’Ambra C, Mazzeo F, . Naltrexone plus benzodiazepine aids abstinence in opioid-dependent patients. Life Sci. 2005;77(21):2717–22. PMID: 15979652.15979652
81 Gruber VA, Delucchi KL, Kielstein A, . A randomized trial of 6-month methadone maintenance with standard or minimal counseling versus 21-day methadone detoxification. Drug Alcohol Depend. 2008;94(1-3):199–206. doi: 10.1016/j.drugalcdep.2007.11.021. PMID: 18243585.18243585
82 Kakko J, Svanborg KD, Kreek MJ, . 1-year retention and social function after buprenorphine-assisted relapse prevention treatment for heroin dependence in Sweden: a randomised, placebo-controlled trial. Lancet. 2003;361(9358):662–8. PMID: 12606177.12606177
83 Krook AL, Brors O, Dahlberg J, . A placebo-controlled study of high dose buprenorphine in opiate dependents waiting for medication-assisted rehabilitation in Oslo, Norway. Addiction. 2002;97(5):533–42. PMID: 12033654.12033654
84 Ling W, Casadonte P, Bigelow G, . Buprenorphine implants for treatment of opioid dependence: a randomized controlled trial. JAMA. 2010;304(14):1576–83. doi: 10.1001/jama.2010.1427. PMID: 20940383.20940383
85 Rosenthal RN, Ling W, Casadonte P, . Buprenorphine implants for treatment of opioid dependence: randomized comparison to placebo and sublingual buprenorphine/naloxone. Addiction. 2013;108(12):2141–9. doi: 10.1111/add.12315. PMID: 23919595.23919595
86 Schwartz RP, Jaffe JH, Highfield DA, . A randomized controlled trial of interim methadone maintenance: 10-month follow-up. Drug Alcohol Depend. 2007;86(1):30–6. PMID: 16793221.16793221
87 Schwartz RP, Jaffe JH, O’Grady KE, . Interim methadone treatment: impact on arrests. Drug Alcohol Depend. 2009;103(3):148–54. doi: 10.1016/j.drugalcdep.2009.03.007. PMID: 19443133.19443133
88 Baker A, Boggs TG, Lewin TJ. Randomized controlled trial of brief cognitive-behavioural interventions among regular users of amphetamine. Addiction. 2001a;96(9):1279–87. doi: 10.1080/09652140120070337. PMID: 11672492.11672492
89 Baker A, Boggs TG, Lewin TJ. Characteristics of regular amphetamine users and implications for treatment. Drug Alcohol Rev. 2001b;20(1):49–56.
90 Baker A, Lee NK, Claire M, . Brief cognitive behavioural interventions for regular amphetamine users: a step in the right direction. Addiction. 2005;100(3):367–78. doi: 10.1111/j.1360-0443.2005.01002.x. PMID: 15733250.15733250
91 Bonar EE, Walton MA, Barry KL, . Sexual HIV risk behavior outcomes of brief interventions for drug use in an inner-city emergency department: Secondary outcomes from a randomized controlled trial. Drug Alcohol Depend. 2018;183:217–24. doi: 10.1016/j.drugalcdep.2017.10.036. PMID: 29291549.29291549
92 Copeland J, Swift W, Rees V. Clinical profile of participants in a brief intervention program for cannabis use disorder. J Subst Abuse Treat. 2001b;20(1):45–52. PMID: 11239727.11239727
93 de Dios MA, Herman DS, Britton WB, . Motivational and mindfulness intervention for young adult female marijuana users. J Subst Abuse Treat. 2012;42(1):56–64. doi: 10.1016/j.jsat.2011.08.001. PMID: 21940136.21940136
94 de Gee EA, Verdurmen JE, Bransen E, . A randomized controlled trial of a brief motivational enhancement for non-treatment-seeking adolescent cannabis users. J Subst Abuse Treat. 2014;47(3):181–8. PMID: 24969735.24969735
95 Dembo R, Briones-Robinson R, Schmeidler J, . Brief intervention impact on truant youths’ marijuana use: eighteen-month follow-up. J Child Adolesc Subst Abuse. 2016;25(1):18–32. doi: 10.1080/1067828X.2013.872068.
96 Dupont HB, Candel MJ, Kaplan CD, . Assessing the efficacy of MOTI-4 for reducing the use of cannabis among youth in the Netherlands: A randomized controlled trial. J Subst Abuse Treat. 2016;65:6–12. doi: 10.1016/j.jsat.2015.11.012. PMID: 26780988.26780988
97 Fischer B, Dawe M, McGuire F, . Feasibility and impact of brief interventions for frequent cannabis users in Canada. J Subst Abuse Treat. 2013;44(1):132–8. doi: 10.1016/j.jsat.2012.03.006. PMID: 22520278.22520278
98 Fischer B, Jones W, Shuper P, . 12-month follow-up of an exploratory ‘brief intervention’ for high-frequency cannabis users among Canadian university students. Subst Abuse Treat Prev Policy. 2012;7:15. doi: 10.1186/1747-597x-7-15. PMID: 22538183.22538183
99 Gates PJ, Norberg MM, Copeland J, . Randomized controlled trial of a novel cannabis use intervention delivered by telephone. Addiction. 2012;107(12):2149–58. doi: 10.1111/j.1360-0443.2012.03953.x. PMID: 22632139.22632139
100 Jones HE, Wong CJ, Tuten M, . Reinforcement-based therapy: 12-month evaluation of an outpatient drug-free treatment for heroin abusers. Drug Alcohol Depend. 2005;79(2):119–28. doi: 10.1016/j.drugalcdep.2005.01.006. PMID: 16002021.16002021
101 Litt MD, Kadden RM, Kabela-Cormier E, . Coping skills training and contingency management treatments for marijuana dependence: exploring mechanisms of behavior change. Addiction. 2008;103(4):638–48. doi: 10.1111/j.1360-0443.2008.02137.x. PMID: 18339108.18339108
102 Litt MD, Kadden RM, Petry NM. Behavioral treatment for marijuana dependence: randomized trial of contingency management and self-efficacy enhancement. Addict Behav. 2013;38(3):1764–75. doi: 10.1016/j.addbeh.2012.08.011. PMID: 23254227.23254227
103 Litt MD, Kadden RM, Stephens RS. Coping and self-efficacy in marijuana treatment: results from the marijuana treatment project. J Consult Clin Psychol. 2005;73(6):1015–25. doi: 10.1037/0022-006x.73.6.1015. PMID: 16392975.16392975
104 Lozano BE, Stephens RS, Roffman RA. Abstinence and moderate use goals in the treatment of marijuana dependence. Addiction. 2006;101(11):1589–97. PMID: 17034438.17034438
105 Marsden J, Stillwell G, Barlow H, . An evaluation of a brief motivational intervention among young ecstasy and cocaine users: no effect on substance and alcohol use outcomes. Addiction. 2006;101(7):1014–26. PMID: 16771893.16771893
106 Martin G, Copeland J. The adolescent cannabis check-up: randomized trial of a brief intervention for young cannabis users. J Subst Abuse Treat. 2008;34(4):407–14. PMID: 17869051.17869051
107 McCambridge J, Slym RL, Strang J. Randomized controlled trial of motivational interviewing compared with drug information and advice for early intervention among young cannabis users. Addiction. 2008;103(11):1809–18. PMID: 18778385.18778385
108 McCambridge J, Strang J. The efficacy of single-session motivational interviewing in reducing drug consumption and perceptions of drug-related risk and harm among young people: results from a multi-site cluster randomized trial. Addiction. 2004;99(1):39–52. PMID: 14678061.14678061
109 Rooke S, Copeland J, Norberg M, . Effectiveness of a self-guided web-based cannabis treatment program: randomized controlled trial. J Med Internet Res. 2013;15(2):e26. doi: 10.2196/jmir.2256. PMID: 23470329.23470329
110 Schaub MP, Wenger A, Berg O, . A web-based self-help intervention with and without chat counseling to reduce cannabis use in problematic cannabis users: three-arm randomized controlled trial. J Med Internet Res. 2015;17(10):e232. doi: 10.2196/jmir.4860. PMID: 26462848.26462848
111 Stein MD, Herman DS, Anderson BJ. A motivational intervention trial to reduce cocaine use. J Subst Abuse Treat. 2009;36(1):118–25.18657938
112 Stephens RS, Roffman RA, Fearer SA, . The marijuana check-up: promoting change in ambivalent marijuana users. Addiction. 2007;102(6):947–57. doi: 10.1111/j.1360-0443.2007.01821.x. PMID: 17523990.17523990
113 Tait RJ, McKetin R, Kay-Lambkin F, . Six-month outcomes of a Web-based intervention for users of amphetamine-type stimulants: randomized controlled trial. J Med Internet Res. 2015;17(4):e105. doi: 10.2196/jmir.3778. PMID: 25925801.25925801
114 Baumeister SE, Gelberg L, Leake BD, . Effect of a primary care based brief intervention trial among risky drug users on health-related quality of life. Drug Alcohol Depend. 2014;142:254–61. doi: 10.1016/j.drugalcdep.2014.06.034. PMID: 25042213.25042213
115 Bogenschutz MP, Donovan DM, Adinoff B, . Design of NIDA CTN Protocol 0047: screening, motivational assessment, referral, and treatment in emergency departments (SMART-ED). Am J Drug Alcohol Abuse. 2011;37(5):417–25. doi: 10.3109/00952990.2011.596971. PMID: 21854285.21854285
116 Fuster D, Cheng DM, Wang N, . Brief intervention for daily marijuana users identified by screening in primary care: a subgroup analysis of the ASPIRE randomized clinical trial. Subst Abus. 2016;37(2):336–42. doi: 10.1080/08897077.2015.1075932. PMID: 26453188.26453188
117 Kim TW, Bernstein J, Cheng DM, . Receipt of addiction treatment as a consequence of a brief intervention for drug use in primary care: a randomized trial. Addiction. 2016;112(5):818–27. doi: 10.1111/add.13701. PMID: 27886657.27886657
118 Krupski A, Joesch JM, Dunn C, . Testing the effects of brief intervention in primary care for problem drug use in a randomized controlled trial: rationale, design, and methods. Addict Sci Clin Pract. 2012;7:27. doi: 10.1186/1940-0640-7-27. PMID: 23237456.23237456
119 Mason MJ, Sabo R, Zaharakis NM. Peer network counseling as brief treatment for urban adolescent heavy cannabis users. J Stud Alcohol Drugs. 2017;78(1):152–7. PMID: 27936376.27936376
120 Otto C, Crackau B, Lohrmann I, . Brief intervention in general hospital for problematic prescription drug use: 12-month outcome. Drug Alcohol Depend. 2009;105(3):221–6. doi: 10.1016/j.drugalcdep.2009.07.010. PMID: 19726140.19726140
121 Kadden RM, Litt MD, Kabela-Cormier E, . Abstinence rates following behavioral treatments for marijuana dependence. Addict Behav. 2007;32(6):1220–36. doi: 10.1016/j.addbeh.2006.08.009. PMID: 16996224.16996224
122 Sobell LC, Sobell MB. Timeline Follow-Back. In: Litten RZ, Allen JP, eds. Measuring Alcohol Consumption: Psychosocial and Biochemical Methods. Totowa, NJ: Humana Press; 1992:41–72.
123 Coffin PO, Behar E, Rowe C, . Nonrandomized intervention study of naloxone coprescription for primary care patients receiving long-term opioid therapy for pain. Ann Intern Med. 2016;165(4):245–52. doi: 10.7326/m15-2771. PMID: 27366987.27366987
124 Parmar MK, Strang J, Choo L, . Randomized controlled pilot trial of naloxone-on-release to prevent post-prison opioid overdose deaths. Addiction. 2017;112(3):502–15. doi: 10.1111/add.13668. PMID: 27776382.27776382
125 Substance Abuse and Mental Health Services Administration. An Introduction to Extended-Release Injectable Naltrexone for the Treatment of People With Opiod Dependence. 2012. https://www.integration.samhsa.gov/Intro_To_Injectable_Naltrexone.pdf Accessed April 26, 2019.
126 Tanum L, Solli KK, Latif ZE, . Effectiveness of injectable extended-release naltrexone vs daily buprenorphine-naloxone for opioid dependence: a randomized clinical noninferiority trial. JAMA Psychiatry. 2017;74(12):1197–205. doi: 10.1001/jamapsychiatry.2017.3206. PMID: 29049469.29049469
127 Lee JD, Nunes EV, Jr., Novo P, . Comparative effectiveness of extended-release naltrexone versus buprenorphine-naloxone for opioid relapse prevention (X: bOT): a multicentre, open-label, randomised controlled trial. Lancet. 2018;27(391(10118)):309–19. doi: 10.1016/S0140-6736(17)32812-X. PMID: 29150198.29150198
128 Lewin ME, Altman S, eds. America’s health care safety net: intact but endangered. Washington, DC: National Academy Press; 2000.
129 World Health Organization Department of Mental Health and Substance Dependence. The Alcohol, Smoking and Substance Involvement Screening Test (ASSIST): Guidelines for Use in Primary Care (Draft Version 1.1 for Field Testing. Geneva: 2003. http://www.who.int/substance_abuse/activities/en/Draft_The_ASSIST_Guidelines.pdf Accessed April 26, 2019.
130 MacArthur GJ, Minozzi S, Martin N, . Opiate substitution treatment and HIV transmission in people who inject drugs: systematic review and meta-analysis. BMJ. 2012;345:e5945. doi: 10.1136/bmj.e5945. PMID: 23038795.23038795
131 Sordo L, Barrio G, Bravo MJ, . Mortality risk during and after opioid substitution treatment: systematic review and meta-analysis of cohort studies. BMJ. 2017;357:j1550. doi: 10.1136/bmj.j1550. PMID: 28446428.28446428
132 Haber PS, Elsayed M, Espinoza D, . Constipation and other common symptoms reported by women and men in methadone and buprenorphine maintenance treatment. Drug Alcohol Depend. 2017;181:132–9. doi: 10.1016/j.drugalcdep.2017.09.024. PMID: 29054032.29054032
133 Lugoboni F, Mirijello A, Zamboni L, . High prevalence of constipation and reduced quality of life in opioid-dependent patients treated with opioid substitution treatments. Expert Opin Pharmacother. 2016;17(16):2135–41. doi: 10.1080/14656566.2016.1232391. PMID: 27603712.27603712
134 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014;160(4):267–70. doi: 10.7326/m13-2886. PMID: 24727843.24727843
135 Voelker R. Monthly buprenorphine injection approved for opioid use disorder. JAMA. 2018;319(3):220. doi: 10.1001/jama.2017.20647. PMID: 29340663.29340663
136 Sharma D, Kar S. Recent advances in pharmacological management of substance use disorders. Int J Nutr Pharmacol Neurol Dis. 2015;5(4):118–27. doi: 10.4103/2231-0738.167505.
137 Forray A, Sofuoglu M. Future pharmacological treatments for substance use disorders. Br J Clin Pharmacol. 2014;77(2):382–400. doi: 10.1111/j.1365-2125.2012.04474.x. PMID: 23039267.23039267
138 The American College of Obstetrians and Gynecologists. Committee Opinion No. 711: Opioid Use and Opioid Use Disorder in Pregnancy. 2017. https://www.acog.org/Clinical-Guidance-and-Publications/Committee-Opinions/Committee-on-Obstetric-Practice/Opioid-Use-and-Opioid-Use-Disorder-in-Pregnancy. Accessed September 12, 2018.
139 McCormick C. Suboxone and Subtex Approval Letter, vol 732. Rockville, MD: Center for Drug Evaluation and Research; Food and Drug Administration. 2002.
140 Hammond CJ. The role of pharmacotherapy in the treatment of adolescent substance use disorders. Child Adolesc Psychiatr Clin N Am. 2016;25(4):685–711. doi: 10.1016/j.chc.2016.05.004. PMID: 27613346.27613346