# Acknowledgments

The authors acknowledge Carrie Patnode, PhD, MPH, Megan Rushkin, MPH, and Rochelle Fu, PhD. The authors also thank the AHRQ Medical Officers David Meyers, MD, MPH, and Kathleen Irwin, MD, MPH; as well as the U.S. Preventive Services Task Force.