# Chapter 4 Discussion

## Summary of Review Findings

This report updates a 2008 USPSTF review on screening for drug use in adolescents and adults.^2^ It also supplements a USPSTF screening review by including trials of interventions for drug use conducted in treatment-seeking populations.^1^

Table 8 summarizes the evidence reviewed for this update. Compared to the 2008 USPSTF review, substantially more evidence is available to support the effectiveness of FDA-approved pharmacotherapies for treatment of opioid use disorder on drug use outcomes (two trials included in the 2008 USPSTF review, compared with 19 trials in this report) and to support the effectiveness of psychological interventions for cannabis, stimulant, or mixed drug use outcomes (five trials included in the 2008 USPSTF review, compared with 52 trials in this report). Our findings supplement the USPSTF screening review,^1^ which found no consistent evidence that psychosocial interventions are effective at improving drug use or health outcomes, based on 27 trials of persons with unhealthy drug use identified through screening. With the inclusion of 25 additional trials conducted in treatment-seeking populations, we found psychosocial interventions effective for improving drug use outcomes. Effects of psychosocial interventions were generally stronger in treatment-seeking populations than in screen-detected populations, for cannabis use than other drug use outcomes, for shorter-term (3 to 4 month) than longer-term (6 to 12 month) outcomes, and for more intensive interventions versus brief interventions. Few trials evaluated psychosocial interventions for stimulant or opioid use and estimates were imprecise; therefore, effects on these types of drug use are uncertain.

Table 8 Summary of Evidence

Key Question^*^ | Intervention | Studies (k) Observations (n) Study Designs | Summary of Findings^†^ | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
Efficacy of interventions (Key Questions 4a, b) | Naltrexone for opioid use disorder | 13 trials (N=1,718) | - Drug use relapse: 11 trials, RR 0.73 (95% CI 0.62 to 0.85) I^2^=78%; ARD −18% (95% CI −26% to −10%); - Retention in treatment: 9 trials, RR 1.71 (95% CI 1.13 to 2.49), I^2^=67%; ARD 15% (95% CI 5% to 22%); - Mortality: Reported in 5 trials, with very few events; Other health, legal, and social outcomes: Few trials, with inconsistent effects | For drug use relapse and retention in treatment, inconsistency in magnitude but not direction of effect. Estimates reasonably precise. Results consistent in stratified and sensitivity analyses. | Overall risk of bias moderate. Attrition was high. Methods for defining drug use relapse and retention in treatment varied.; Reporting bias not detected. | Moderate | All trials enrolled treatment-seeking persons with opioid use disorder due to heroin use. Naltrexone administered in conjunction with drug use counseling.; Most trials evaluated oral naltrexone, some trials recruited patients from the criminal justice system, and around half of naltrexone trials were conducted in countries in which opioid agonist therapy is not available
Efficacy of interventions (Key Questions 4a, b) | Opioid agonist therapy (buprenorphine or methadone) for opioid use disorder | 7 trials (N=1,109); - Buprenorphine: 5 trials (N=679); - Methadone: 2 trials (N=430); All trials conducted in treatment-seeking individuals | - Drug use relapse: 4 trials, RR 0.75 (95% CI 0.59 to 0.82), I^2^=75%; ARD −35%, 95% CI −67% to −3%); - Retention in treatment: 7 trials, RR 2.58 (95% CI 1.78 to 4.59), I^2^=71%; ARD 39% (95% CI 23% to 54%); - Results very similar when stratified by buprenorphine or methadone; - Mortality: Reported in 2 trials, with very few events; Other health, legal, and social outcomes: Few trials, with inconsistent effects | For drug use relapse and retention in treatment, inconsistency in magnitude but not direction of effect. Estimates reasonably precise. Results consistent in stratified and sensitivity analyses. | Overall risk of bias moderate. Attrition was high. Two trials used an open-label design. Methods for defining drug use relapse utilized urine drug test findings.; Reporting bias not detected. | Moderate | All trials enrolled treatment-seeking persons with opioid use disorder, primarily due to heroin use. Opioid agonist therapy usually administered in conjunction with drug use counseling.; Opioid agonist therapy usually administered in addiction treatment setting. No trial evaluated newly U.S. Food and Drug Administration-approved, injectable buprenorphine.
Efficacy of interventions (Key Questions 4a, b), continued | Psychosocial interventions | 52 trials (N=15,659); - Screen-detected populations: 27 trials (N=10,227); - Treatment-seeking populations: 25 trials (N=5,432) | Drug use abstinence; - 3 to 4 months: 15 trials, RR 1.60 (95% CI 1.24 to 2.13), I^2^=61%; ARD 9% (95% CI 5% to 15%); - 6 to 12 months: 14 trials, RR 1.25 (95% CI 1.11 to 1.52), I^2^=38%; ARD 10% (95% CI 3% to 16%); Drug use days (in last 7 days); - 3 to 4 months: 19 trials, mean difference −0.49 day (95% CI −0.85 to −0.13), I^2^=89%; - 6 to 12 months: 15 trials, mean difference −0.08 day (95% CI −0.30 to 0.11), I^2^=45%; Drug use severity; - 3 to 4 months: 17 trials, SMD −0.18 (95% CI −0.32 to −0.05), I^2^=73%; - 6 to 12 months: 13 trials, SMD −0.10 (95% CI −0.24 to 0.02), I^2^=65%; Mortality: Reported in 4 trials with few events; Other health, social, and legal outcomes: Few trials, with inconsistent effects | Substantial clinical heterogeneity and inconsistency. Effects present in trials of treatment-seeking but not screen-detected populations. Effects also generally stronger in trials that evaluated cannabis use than other type of drug use, trial of adult than trial of adolescents or young adults, and trial of more intensive than brief interventions. No stratified analysis explained inconsistency. | Overall risk of bias moderate. Attrition was high. Trials of psychosocial interventions could not be effectively blinded. Methods for measuring drug use outcomes varied.; Reporting bias not detected. | Moderate | Studies varied in terms of whether patients were screen-detected or treatment-seeking, recruitment setting, and severity and type of drug use. Most trials evaluated psychosocial interventions that utilized cognitive behavioral therapy or motivational interventions, but treatment intensity varied. Brief interventions are usually designed to be feasible for delivery in primary care settings.
Harms of interventions (Key Question 5) | Naltrexone for opioid use disorder | 11 trials (N=1,645) | - Withdrawal due to adverse events: 3 trials, RR 1.54 (95% CI 0.35 to 8.31), I^2^=0%; - Serious adverse events: 3 trials, RR 1.24 (95% CI 0.11 to 10.21, I^2^=59%; - Constipation: 2 trials, RR 0.97 (95% CI 0.37 to 2.39, I^2^=0%; - Diarrhea: 2 trials, RR 1.94 (95% CI 0.70 to 6.53, I^2^=0% | Findings consistent but imprecise | Overall risk of bias moderate. Harms reporting was inconsistent and harms were NR by all trials | Low-moderate | See entry for efficacy of naltrexone
Harms of interventions (Key Question 5) | Opioid agonist therapy (buprenorphine or methadone) for opioid use disorder | 4 trials (N=639) on buprenorphine; No studies on methadone | - Serious adverse events: 2 trials, RR 0.32 (95% CI 0.09 to 1.12), I^2^=0%; - Withdrawal due to adverse events: 1 trial (RR 0.89, 95% CI 0.06 to 13.7); - No hospitalizations due to serious medication-related adverse events: 1 trial; - Constipation: 2 trials, RR 2.36 (95% CI 1.16 to 4.92), I^2^=0%; ARD 12% (95% CI - 5% to 41%); - Diaphoresis: 3 trials, RR 1.15 (95% CI 0.55 to 2.73), I^2^=44%; - Nausea: 2 trials, RR 1.13 (95% CI 0.41 to 6.07), I^2^=30% | Some inconsistency and imprecision | Overall risk of bias moderate. Harms reporting was inconsistent and harms were NR by all trials | Low-moderate | See entry for efficacy of opioid agonist therapy
Harms of interventions (Key Question 5) | Psychosocial interventions | 4 trials (N=1,198) | - No harms were reported in either intervention of control groups; No serious adverse events were noted | Findings consistent but imprecise | Overall risk of bias moderate. Harms were only reported in a few trials. However, serious harms are not expected with this type of intervention | Low-moderate | See entry for efficacy of psychosocial interventions
Efficacy of naloxone (Key Question 6) | - | No studies | -- | -- | -- | -- | --
Harms of naloxone (Key Question 7) | - | No studies | -- | -- | -- | -- | --

* The Key Question numbers are from the analytic framework in the screening report;^1^ Key Questions 1-3 are addressed in that report.

† Comparisons are against placebo or no medication for pharmacological interventions, and against waitlist, a minimal intervention, or usual care for psychosocial interventions.

Abbreviations: ARD = absolute risk difference; CI = confidence interval; NR = not reported; RR = risk ratio; SMD = standardized mean difference; U.S. = United States.

With regard to pharmacotherapies, evidence indicates that naltrexone (an opioid antagonist) and opioid agonists (methadone and the partial agonist buprenorphine) are effective at reducing the likelihood of drug use relapse and increasing the likelihood of retention in treatment. Although the 2008 USPSTF review^2^ also found that pharmacotherapies are effective at improving drug use outcomes, five of the seven trials of pharmacotherapies in the 2008 USPSTF report evaluated medications that are not FDA-approved for treatment of drug use, and are not first-line or recommended treatments. For this report, which was restricted to pharmacological medications approved by FDA as of September 2018, trials were primarily conducted in persons using heroin and/or meeting DSM-IV criteria for opioid use disorder, and medications were typically administered in conjunction with drug use counseling, in accordance with recommended practice.^8,9^ Based on pooled estimates, the number needed to treat to avoid one additional case of relapse was 5.3 for naltrexone and 2.9 for opioid agonists and the number needed to treat for one additional case of treatment retention was 6.7 for naltrexone and 2.6 for opioid agonists. Results were similar when analyses of opioid agonists were stratified according to whether the medication was methadone or buprenorphine. Definitions for relapse varied across trials, though most trials incorporated urine drug test findings. Although statistical heterogeneity was high in the naltrexone analyses, relative risk estimates for drug use abstinence favored naltrexone in 10 of 12 trials and results were consistent in stratified and sensitivity analyses based on the mode of administration, timing of outcome assessment, dose, and study quality. Most naltrexone trials evaluated oral naltrexone, some naltrexone trials recruited patients from the criminal justice system, oral medications were administered daily under direct observation, and almost half of the naltrexone trials were conducted in Russia, where opioid agonist therapy with methadone or buprenorphine is not permitted. These factors could potentially reduce the applicability of findings to current U.S. primary care practice, where pharmacological alternatives to naltrexone are available and extended-release, injectable naltrexone was approved by the FDA in 2010.^125^ Head-to-head trials, which were not included in this report, suggest that extended-release injectable naltrexone is similarly effective as sublingual buprenorphine/naloxone for improving drug use outcomes, though naltrexone can be more difficult to initiate.^126,127^

Like the 2008 USPSTF review, we found psychosocial interventions to be effective at improving some drug use outcomes when all trials of screen-detected or treatment-seeking populations were included in analyses. Effects were present at 3 to 4 months for increased likelihood of drug use abstinence, decreased number of drug use days, and decreased drug use severity, but at 6 to 12 months were only observed for drug use abstinence. Most trials of psychosocial interventions utilized CBT or motivational interventions, with contingency management evaluated in some trials, and ranged in intensity from one or two session brief interventions to ongoing treatment for months. The majority of trials of psychosocial interventions recruited patients with cannabis use or mixed drug use. Based on overall pooled estimates, psychosocial interventions were associated with a number needed to treat for one additional case of drug use abstinence compared with controls of 11 at 3 to 4 months and 17 through 6 to 12 months. A factor that complicates interpretation of abstinence findings is that trials varied with regard to how abstinence was assessed, with some trials relying on self-report and others incorporating laboratory measures (drug testing of urine or hair). Psychosocial interventions were also associated with an average reduction of 0.5 drug use days per week and a small but statistically significant decrease in drug use severity at 3 to 4 months (SMD −0.18). Effects on continuous outcomes such as drug use severity and drug use days could be harder to detect than effects on a dichotomous outcome such as drug use abstinence because of variability in baseline drug use severity, including trials that enrolled patients with infrequent drug use or mild drug use severity. Trials of psychosocial interventions were characterized by marked variability in patient populations, interventions, outcomes, recruitment and treatment settings, and other factors, likely contributing for the substantial statistical heterogeneity observed in pooled analyses. Effects of psychosocial interventions tended to be greater in trials of treatment-seeking than screen-detected individuals, trials evaluating cannabis use than those evaluating stimulant or mixed drug use, trials evaluating face-to-face than other modes of delivery, and trials evaluating more intensive rather than brief interventions. However, these findings should be interpreted with caution, as none of these factors fully accounted for statistical heterogeneity, the relatively small number of trials limited the usefulness of subgroup analyses, and most tests for interaction effects were not statistically significant.

Some considerations that might explain why psychosocial interventions appear to be more effective in trials of treatment-seeking than screen-detected populations are that the drug use thresholds for enrolling patients in screening trials (based on measures of drug use severity; frequency or duration or use; or type of drug use) were generally lower than trials of treatment-seeking individuals, and most trials of psychosocial interventions in screen-detected populations evaluated brief interventions, often consisting of a single session. One recent intervention trial conducted in a primary care safety net setting (practices that organize and deliver a significant level of health care and other services to uninsured, Medicaid, and other vulnerable patients)^128^ found that 8 percent of persons identified through screening who met the screening threshold for trial participation reported use of intravenous drugs in the past 30 days and 30 percent had a DAST-10 score of ≥6, indicating substantial or severe drug use.^61^ Another intervention trial conducted in a primary care setting found that 18 percent of persons meeting the drug use screening threshold for trial participation had an ASSIST score ≥27,^62^ indicating a high risk of dependence.^129^ Neither trial excluded patients with a past history of drug use or current or past treatment for drug use, which could have increased the proportion of patients with more severe drug use. Nonetheless, these studies suggest that some persons with drug use identified on screening in primary care settings may have more severe drug use. The effectiveness of psychosocial interventions implemented in primary care settings might be enhanced by targeting interventions to those patients identified on screening as having more severe drug use and/or by offering more intensive (e.g., multisession) interventions.

As in the 2008 USPSTF report and the USPSTF screening review, we found limited and inconsistent evidence on the effects of pharmacotherapy and psychological interventions on other health outcomes. Trials were not designed or powered to assess outcomes such as mortality or overdose events, which were infrequently reported, though they appeared to be rare. No trial assessed effects of interventions for drug use on risk of HIV or other infectious diseases associated with injection drug use, though limited evidence from pharmacotherapy trials found no clear effects on HIV risk behaviors. A meta-analysis of observational studies that did not meet inclusion criteria found opioid agonist therapy associated with decreased risk of HIV infection in persons who inject drugs (rate ratio 0.60, 95% CI 0.42 to 0.85, I^2^=23%, based on 6 studies reporting adjusted risk estimates).^130^ We found limited evidence showing no clear effects of drug use interventions on legal outcomes such as incarceration, criminal activity, quality of life, or social outcomes. However, most trials did not assess these outcomes. The 2008 USPSTF review previously found fair evidence that stopping or reducing drug misuse is associated with reduced mortality and morbidity.^2^ A subsequent meta-analysis of cohort studies found treatment with methadone and buprenorphine associated with decreased mortality risk; retention in treatment was also associated with decreased risk of overdose mortality.^131^

Assessment and reporting of harms in trials of pharmacotherapies was suboptimal, but indicated no increase in risk of serious adverse events or study withdrawal due to adverse events versus placebo or no pharmacotherapy. Buprenorphine was associated with an increased risk of constipation versus placebo (number needed to harm 8), though this finding was based on only two trials. Although reporting on harms in trials of methadone included in this review was very limited and inconsistent, observational studies indicate that methadone may be associated with higher risk of constipation relative to buprenorphine.^132,133^ Trials of psychosocial interventions did not assess for harms, though serious harms are not anticipated with this type of intervention.

Evidence on the benefits and harms of preemptive naloxone prescribed in primary care settings for reducing overdose risk in persons with opioid use disorder or misuse is not available. Although one study found coprescription of naloxone to patients prescribed opioids for pain was associated with reduced risk of opioid-related emergency department visits, it was nonrandomized and enrolled patients who did not necessarily have opioid misuse or use disorder.^123^ To date, the effectiveness of naloxone has mainly been demonstrated in the context of evaluations of community opioid overdose prevention and naloxone distribution programs.^21,22^

## Limitations

Our review methods has some limitations. We restricted inclusion to English language articles and did not search for studies published only as abstracts. There was substantial variability in populations, interventions, comparisons, and measurement of outcomes, with unexplained statistical heterogeneity that was only partially explained in stratified and sensitivity analyses based on these and other factors. Therefore, we performed random effects analyses, which result in wider confidence intervals than fixed effects models when statistical heterogeneity is present, reflecting the greater uncertainty in estimates. In addition, we performed analyses using the profile likelihood method, which may be more reliable when statistical heterogeneity is present,^134^ though results using the profile likelihood and Dersimonian and Laird methods were very similar. The relatively small number of trials limited the usefulness of subgroup and sensitivity analyses; therefore, results of such analyses should be interpreted with caution. We restricted inclusion to trials with at least three months followup, which might have excluded relevant evidence from shorter-term trials. We also excluded head-to-head trials, which are useful for directly assessing the relative effects of different therapies. We did not evaluate the evidence on several therapies that are not considered first-line options for treatment of drug use, such as mindfulness interventions, acupuncture, and music therapy.

There were also limitations in the evidence. Most trials had methodological limitations, though we excluded poor-quality trials with serious flaws and findings were generally similar when we restricted analyses to good quality trials. Trials primarily focused on evaluation of effects of interventions on intermediate outcomes such as drug use or retention in treatment. There was little direct evidence on the effects of interventions on mortality or other clinical, social, and legal outcomes. However, as noted above, the 2008 USPSTF review and other analyses have found limited evidence from observational studies for an association between reduction in opioid (usually heroin) misuse and improved health outcomes.^2,131^ Evidence was also limited on the effectiveness of treatments for opioid use disorder related to prescription drug use and stimulant use. Trials varied in how abstinence was assessed, with some trials relying on self-report and others incorporating results from drug testing of urine or hair. Similarly, drug use severity was assessed using a variety of scales that varied in terms of the extent to which they focused on frequency of use versus consequences of use. For trials of pharmacotherapies, the outcome of retention in treatment often incorporated drug use relapse; therefore, these two drug use outcomes are not independent. Evidence was not available for naloxone for mitigation of risks associated with opioid use disorder or misuse.

## Emerging Issues/Next Steps

The FDA approved an injectable, once-monthly buprenorphine formulation for treatment of moderate to severe opioid use disorder in 2017.^135^ The approval was based on two trials showing effectiveness at improving drug use outcomes versus placebo. However, these trials have not yet been published.

A number of pharmacotherapies have been evaluated for treatment of drug use disorder that are not approved by the FDA for this indication, and are not currently recommended treatments. For cannabis use, off-label pharmacotherapies that have been studied include dronabinol, N-acetylcysteine, gabapentin, buspirone, divalproex, and cannabis replacement therapy. For stimulant use disorder, off-label pharmacotherapies that have been studied include modafinil, disulfiram, propanolol, methylphenidate, vigabatrin, topiramate, rivastigmine, naltrexone, and serotoninergic agents.^136,137^

## Relevance for Priority Populations

Drug use is associated with adverse maternal and neonatal outcomes. The only trials of interventions to reduce drug use in pregnant or postpartum women were conducted in screen-detected populations and are discussed in more detail in the USPSTF screening review,^1^ which found no clear evidence of benefits in these populations. In this review, no trial evaluated pharmacotherapy for opioid use disorder in pregnant women. The American College of Obstetricians and Gynecologists recommends screening for opioid use in pregnant women and opioid agonist therapy with methadone or buprenorphine in those with opioid use disorder.^138^ Evidence to determine whether effects of interventions vary by sex was very limited. Trials did not report effects of pharmacotherapies or psychosocial interventions on drug use abstinence/relapse, retention in treatment, drug use severity, or drug use days stratified by patient sex; few trials evaluated the interaction between drug use interventions and sex on other outcomes, with most reporting no statistically significant interactions.^4,46,48,55,95,96,111^

Substance use in adolescents is associated with increased risk of adult substance use disorders, and can be associated with serious consequences. We found some evidence suggesting that psychosocial interventions may be less effective at reducing drug use days in adolescents or young adults (less than 25 years of age) compared with older adults. Although family-based approaches are a recommended psychosocial technique for treatment of adolescent drug use, no trial of a family-based approach met inclusion criteria.^17^ We also did not include trials of school-based therapies or community-level therapies, which may be relevant for this population. Although no trial of pharmacotherapy for opioid use disorder in adolescents met inclusion criteria, the FDA approved the use of buprenorphine for patients 16 years and older in 2002.^139^ Methadone can also be used in adolescents, but requires two documented failed treatments of opioid detoxification or drug-free treatment and parental or legal guardian consent.^140^

No trial was designed to assess effectiveness of interventions for drug use specifically in older adults or to determine how effectiveness of interventions varies according to race or ethnicity.

## Future Research

Research is needed to determine effective interventions for drug use primarily related to prescription opioids or stimulant use, and for drug use related to illicit opioids that does not meet criteria for an opioid use disorder. In screen-detected populations with unhealthy drug use, trials that target therapies to persons with more severe drug use or evaluate more intensive psychosocial interventions would be helpful for clarifying whether psychosocial interventions that have been shown to improve drug use outcomes in treatment-seeking populations can be effectively applied to screen-detected populations. In trials that identify patients through screening, stratification of results according to drug use severity and whether patients are newly diagnosed or have a history of past drug use would be helpful for understanding the effectiveness of interventions in these different populations. Ideally, future trials of interventions to reduce drug use should evaluate drug use outcomes using standardized measures as well as health outcomes, including measures of morbidity, quality of life, psychological outcomes, and function. Direct evidence is limited on the effects of drug use interventions on risk of acquisition of HIV and other infectious diseases related to injection drug use. Research is also needed to understand the extent to which the newly FDA-approved extended release injectable buprenorphine formulation impacts treatment uptake of or adherence to this therapy and retention in substance use treatment in the future. Studies are needed to understand optimal interventions in important populations with unique needs such as adolescents, pregnant or postpartum women, and older adults. Finally, research is needed to estimate the effects of naloxone for mitigating overdose risk associated with opioid use disorder or misuse.

## Conclusions

Pharmacological and psychosocial interventions are effective at improving some drug use outcomes, but evidence of effectiveness remains primarily derived from trials conducted in treatment-seeking individuals. Although the applicability of data from such trials to persons whose drug use is identified through primary care-based screening is uncertain, intervention trials that enrolled patients based on screening identified a spectrum of drug use, ranging from mild drug use to more severe, untreated disease. The applicability of current evidence on drug use interventions to screening might be greater for the subset of patients screened in primary care settings with severe, untreated drug use who could utilize pharmacotherapies or more intensive psychosocial interventions.