# Chapter 3 Results

The literature flow diagram (Appendix A3) summarizes the results of the literature search, including the number of studies identified at the abstract and title stage, studies reviewed at the full-text stage, the number of studies included by Key Question and intervention, and the number of studies excluded. For this supplemental report, we reviewed 10,091 abstracts, of which 1,125 were reviewed as full text articles. We included a total of 71 trials (reported in 87 publications) of interventions for drug use. From the 2008 USPSTF review,^2^ we carried forward seven trials, which are included in the results below.^4–6,30–33^ One trial from the 2008 USPSTF review evaluated naltrexone,^5^ one trial evaluated methadone,^6^ and five trials evaluated psychosocial interventions. Only one trial from the 2008 USPSTF review evaluated a treatment (brief psychosocial intervention) for drug use in a screen-detected population.^4^ We excluded 10 other trials of treatments included in the 2008 USPSTF report. Six trials evaluated a medication not approved by the FDA for treatment of substance use disorders (desipramine, baclofen, fluoxetine, nefazodone, or disulfiram),^34–39^ two trials evaluated non-included interventions (acupuncture^40^ or an intervention that involved provision of housing),^41^ and two trials had duration of followup less than 3 months.^42,43^

The USPSTF screening review included 27 trials on the effectiveness of psychosocial interventions for treatment of drug use in screen-detected populations, all of which are included in this supplemental report.^4,44–69^ It identified no trials of pharmacotherapy for drug use in screen-detected populations.

We identified 17 additional trials of FDA-approved pharmacotherapies for treatment of opioid use disorder (12 evaluated naltrexone, one evaluated methadone, and five evaluated buprenorphine; one trial evaluated both naltrexone and buprenorphine)^70^ and 22 additional trials of psychosocial therapies for treatment of drug use in treatment-seeking (non-screen-detected) settings that were not included in the 2008 USPSTF report^2^ or screening review.^1^ The total numbers of studies included in this supplement are 19 trials of pharmacotherapies and 52 trials of psychosocial interventions (27 in screen-detected populations, 25 in treatment-seeking populations).

## Key Questions 4a And 4b Do Interventions to Reduce Drug Use Reduce Drug Use or Improve Other Risky Behaviors? Do Interventions to Reduce Drug Use Reduce Morbidity or Mortality or Improve Other Health, Social, or Legal Outcomes?

### Summary

- In treatment-seeking populations with opioid use disorder due to heroin use, naltrexone was associated with decreased risk of drug use relapse (12 trials; relative risk [RR] 0.73, 95% confidence interval [CI] 0.62 to 0.85, I^2^=78%; absolute risk difference [ARD] −18%, 95% CI −26% to −10%) and increased likelihood of retention in treatment (9 trials, RR 1.71, 95% CI 1.13 to 2.49, I^2^=67%; ARD 15%, 95% CI 5% to 22%) versus placebo or no naltrexone (Figures 2 and 3); the duration of treatment was 6 months in 10 of 13 trials.
- In treatment-seeking populations with opioid use disorder primarily due to heroin use, opioid agonist therapy with methadone or buprenorphine was associated with decreased risk of relapse while on treatment (4 trials; RR 0.75, 95% CI 0.59 to 0.82; I^2^=75%; ARD −35%, 95% CI −67% to −3%) and increased likelihood of retention in treatment (7 trials; RR 2.58, 95% CI 1.78 to 4.59, I^2^=71%; ARD 39%, 95% CI 23% to 54%) versus placebo or no opioid agonist treatment (Figures 4 and 5); the duration of treatment ranged from 3 to 12 months (6 months in 4 of 7 trials).
  ○ In stratified analyses, effects on risk of relapse and retention in treatment were similar for methadone and buprenorphine.
- Psychosocial interventions were associated with increased likelihood of abstinence from drug use versus control conditions (waitlist, minimal intervention, or usual care) at 3 to 4 months (15 trials; RR 1.60, 95% CI 1.24 to 2.13, I^2^=61%; ARD 9%, 95% CI 5% to 15%) and at 6 to 12 months (14 trials; RR 1.25, 95% CI 1.11 to 1.52, I^2^=38%; ARD 6%, 95% CI 2% to 10%) (Figures 6 and 7).
  ○ In a stratified analysis, effects were statistically significant for abstinence at 3 to 4 months from cannabis use (7 trials; RR 2.08, 95% CI 1.51 to 3.07, I^2^=28%) (Figure 6), but were weaker and not statistically significant for abstinence from mixed drug use (7 trials; RR 1.24, 95% CI 0.92 to 1.80, I^2^=60%).
  ○ Effects on abstinence were greater at 3 to 4 months in trials of treatment-seeking populations (7 trials; RR 2.08, 95% CI 1.51 to 3.07, I^2^=28%) than in trials of screen-detected populations (8 trials; RR 1.28, 95% CI 0.97 to 1.84, I^2^=57%; p for interaction=0.05) (Figure 8).
  ○ Effects on abstinence were greater at in trials of face-to-face interventions than in trials with other (web, computer, telephone) interventions and effects were smaller in trials of brief than intensive interventions, but the differences were not statistically significant.
- Psychosocial interventions were associated with decreased number of drug use days (standardized to use in the last 7 days) versus controls at 3 to 4 months (19 trials, mean difference −0.49 day, 95% CI −0.85 to −0.13, I^2^=89%) but not at 6 to 12 months (15 trials, mean difference −0.08, 95% CI −0.30 to 0.11, I^2^=45%) (Figures 9 and 10).
  ○ Beneficial effects of psychosocial interventions on drug use days at 3 to 4 months were present in trials of treatment-seeking populations (10 trials, mean difference −0.91 day, 95% CI −1.52 to −0.31, I^2^=86%) but not in trials of screen-detected populations (9 trials, mean difference −0.10 day, 95% CI −0.31 to 0.12, I^2^=46%) (Figure 11).
- Psychosocial interventions were associated with a small but statistically significant decrease in drug use severity versus controls at 3 to 4 months (17 trials, standardized mean difference [SMD] −0.18, 95% CI −0.32 to −0.05, I^2^=73%) but not at 6 to 12 months (13 trials, SMD −0.10, 95% CI −0.24 to 0.02, I^2^=65%) (Figures 12 and 13).
- Evidence on the effects of pharmacotherapies and psychosocial interventions on other health, social, and legal outcomes was limited and inconsistent.

Figure 2 Naltrexone vs. Placebo/No Medication—Relapse

Abbreviations: CI = confidence interval; RR = relative risk.

Figure 2 is a forest plot examining relapse comparing naltrexone versus placebo or no medication with two subgroups. The relative risk for 11 studies in the oral administration subgroup is 0.76 (95% confidence interval 0.65 to 0.88) with an I-squared value of 70%. The relative risk for the 2 studies in the injection/implant administration subgroup is 0.41 (95% confidence interval 0.06 to 2.40) with an I-squared value of 98%. The overall relative risk is 0.73 (95% confidence interval 0.62 to 0.85) with an I-squared value of 78%.

Figure 3 Naltrexone vs. Placebo/No Medication—Retention in Treatment

Abbreviations: CI = confidence interval; RR = relative risk.

Figure 3 is a forest plot examining retention in treatment comparing naltrexone versus placebo or no medication with two subgroups. The relative risk for 8 studies in the oral administration subgroup is 1.59 (95% confidence interval 1.00 to 2.38) with an I-squared value of 61%. The relative risk for the 2 studies in the injection/implant administration subgroup is 2.48 (95% confidence interval 0.58 to 11.75) with an I-squared value of 94%. The overall relative risk is 1.71 (95% confidence interval 1.13 to 2.49) with an I-squared value of 67%.

Figure 4 Opioid Agonist Therapy vs. Placebo/No Medication—Relapse

Abbreviations: CI = confidence interval; RR = relative risk.

Figure 4 is a forest plot examining relapse comparing opioid agonist therapy versus placebo or no medication with two subgroups. The relative risk for 3 studies in the buprenorphine subgroup is 0.59 (95% confidence interval 0.21 to 1.31) with an I-squared value of 84%. The relative risk for the 1 study in the methadone subgroup is 0.71 (95% confidence interval 0.61 to 0.84). The overall relative risk of all studies is 0.75 (95% confidence interval 0.59 to 0.82) with an I-squared value of 75%.

Figure 5 Opioid Agonist Therapy vs. Placebo/No Medication—Retention in Treatment

Abbreviations: CI = confidence interval; RR = relative risk.

Figure 5 is a forest plot examining retention in treatment comparing opioid agonist therapy versus placebo or no medication with two subgroups. The relative risk for 5 studies in the buprenorphine subgroup is 2.52 (95% confidence interval 1.89 to 4.74) with an I-squared value of 51%. The relative risk for the 2 studies in the methadone subgroup is 2.22 (95% confidence interval 0.63 to 7.56), with an I-squared value of 92%. The overall relative risk is 2.58 (95% confidence interval 1.78 to 4.59) with an I-squared value of 71%.

Figure 6 Psychosocial Interventions vs. Control Conditions—Abstinence at 3- to 4-Month Followup, Stratified by Drug

Abbreviations: Adol = adolescent; Adul = adult; CI = confidence interval; Comp = computer; FTF = face-to-face; MI = minimal intervention; Pg = pregnant; Pp = postpartum; RR = relative risk; Tel = telephone; WL = waitlist; Yadult = young adult.

Figure 6 is a forest plot examining abstinence at 3- to 4-month followup comparing psychosocial interventions versus control conditions with three subgroups. The relative risk for 7 studies in the cannabis subgroup is 2.08 (95% confidence interval 1.51 to 3.07) with an I-squared value of 28%. The relative risk for the 7 studies in the mixed subgroup is 1.24 (95% confidence interval 0.92 to 1.80), with an I-squared value of 60%. The risk ratio for the 1 study in the prescription subgroup is 2.08 (95% confidence interval (0.81 to 5.38). The overall relative risk is 1.60 (95% confidence interval 1.24 to 2.13) with an I-squared value of 61%.

Figure 7 Psychosocial Interventions vs. Control Conditions—Abstinence at 6- to 12-Month Followup, Stratified by Drug

Abbreviations: Adol = adolescent; Adul = adult; CI = confidence interval; Comp = computer; FTF = face-to-face; MI = minimal intervention; Pg = pregnant; Pp = postpartum; RR = relative risk; Tel = telephone; UC = usual care; WL = waitlist; YAdult = young adult.

Figure 7 is a forest plot examining abstinence at 6- to 12-month followup comparing psychosocial interventions versus control conditions with four subgroups. The relative risk for 4 studies in the cannabis subgroup is 1.58 (95% confidence interval 1.17 to 3.06) with an I-squared value of 36.1%. The relative risk for the 5 studies in the mixed subgroup is 1.12 (95% confidence interval 0.92 to 1.36), with an I-squared value of 0.0%. The risk ratio for the 1 study in the prescription subgroup is 1.25 (95% confidence interval 0.65 to 2.40). The relative risk for 4 studies in the stimulants subgroup is 1.45 (95% confidence interval 0.86 to 2.56), with an I-squared value of 65.4%. The overall relative risk is 1.25 (95% confidence interval 1.11 to 1.52) with an I-squared value of 38.3%.

Figure 8 Psychosocial Interventions vs. Control Conditions—Abstinence at 3- to 4-Month Followup, Stratified by Population

Abbreviations: Adol = adolescent; Adul = adult; CI = confidence interval; Comp = computer; FTF = face-to-face; MI = minimal intervention; Pg = pregnant; Pp = postpartum; RR = relative risk; Tel = telephone; WL = waitlist; Yadult = young adult.

Figure 8 is a forest plot examining abstinence at 3- to 4-month followup comparing psychosocial interventions versus control conditions with two subgroups. The relative risk for 7 studies in the treatment seeking subgroup is 2.08 (95% confidence interval 1.51 to 3.07) with an I-squared value of 27.9%. The relative risk for the 8 studies in the screen detected subgroup is 1.28 (95% confidence interval 0.97 to 1.84), with an I-squared value of 57.2%. The overall relative risk is 1.60 (95% confidence interval 1.24 to 2.13) with an I-squared value of 61.4%.

Figure 9 Psychosocial Interventions vs. Control Conditions—Drug Use Days, Standardized to Drug Use in the Past 7 Days at 3- to 4-Month Followup, Stratified by Drug

Abbreviations: AC = active control; Adol = adolescent; CG = control group; CI = confidence interval; Comp = computer; FTF = face-to-face; IG = intervention group; min = minimal intervention; SD = standard deviation; UC = usual care; WL = wait list; YAdult= young adult.

Figure 9 is a forest plot examining drug use days at 3- to 4-month followup comparing psychosocial interventions versus control conditions with two subgroups. The difference in change for 14 studies in the cannabis subgroup is −0.68 (95% confidence interval −1.14 to −0.23) with an I-squared value of 88.6%. The difference in change for the 5 studies in the mixed subgroup is −0.05 (95% confidence interval −0.39 to 0.31), with an I-squared value of 57.8%. The overall difference in change is −0.49 (95% confidence interval −0.85 to −0.13) with an I-squared value of 88.8%.

Figure 10 Psychosocial Interventions vs. Control Conditions—Drug Use Days, Standardized to Drug Use in the Past 7 Days, at 6- to 12-Month Followup, Stratified by Drug

Abbreviations: AC = active control; CG = control group; CI = confidence interval; Comp = computer; FTF = face-to face; IG = intervention group; Min = minimal intervention; SD = standard deviation; UC = usual care; YAdult = young adult.

Figure 10 is a forest plot examining drug use days, standardized to drug use in past 7 days, at 6- to 12-month followup comparing psychosocial interventions versus control conditions with three subgroups. The difference in change for 7 studies in the cannabis subgroup is −0.21 (95% confidence interval −0.65 to 0.16) with an I-squared value of 40.8%. The difference in change for the 7 studies in the mixed subgroup is 0.04 (95% confidence interval −0.22 to 0.28), with an I-squared value of 42.9%. The difference in change for the 1 study in the stimulant subgroup is −0.47 (95% confidence interval −1.17 to 0.24). The overall difference in change is −0.08 (95% confidence interval −0.30 to 0.11) with an I-squared value of 45.3%.

Figure 11 Psychosocial Interventions vs. Control Conditions—Drug Use Days, Standardized to Drug Use in the Past 7 Days at 3- to 4-Month Followup, Stratified by Population

Abbreviations: AC = active control; Adol = adolescent; CG = control group; CI = confidence interval; Comp = computer; FTF = face-to-face; IG = intervention group; Min = minimal intervention; SD = standard deviation; UC = usual care; WL = wait list; YAdult= young adult.

Figure 11 is a forest plot examining drug use days, standardized to drug use in past 7 days, at 3- to 4-month followup comparing psychosocial interventions versus control conditions with two subgroups. The difference in change for 10 studies in the not screen-detected subgroup is −0.91 (95% confidence interval −1.52 to −0.31) with an I-squared value of 86.2%. The difference in change for the 9 studies in the screen detected subgroup is −0.10 (95% confidence interval −0.31 to 0.12), with an I-squared value of 45.8%. The overall difference in change is −0.49 (95% confidence interval −0.85 to −0.13) with an I-squared value of 88.8%.

Figure 12 Psychosocial Interventions vs. Control Conditions—Drug Use Severity at 3- to 4-Month Followup, Stratified by Drug

Abbreviations: Adul = adult; Adol = adolescent; ASSIST = Alcohol, Smoking, and Substance Involvement Screening Test; CI = confidence interval; Comp = computer; DSM-IV CPS = Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Compendium of Pharmaceuticals and Specialties; FTF = face-to-face; MA = marijuana subscale; MI = minimal intervention; MDS = Marijuana Dependence Scale; MNC = marijuana negative consequences; MPS = Marijuana Problem Scale; NIP = Noteworthy Index of Problems; NR = not reported; PAdul = postpartum adult; RAPI = Rutgers Alcohol Problems Index; RMPI = Rutgers Marijuana Problem Index; SD = standard deviation; SDS = Severity of Dependence Scale; SMD = standardized mean difference; Tel = telephone; TO = total (scale); UC = usual care; WL = waitlist; YAdul = young adult.

Figure 12 is a forest plot examining drug use severity at 3- to 4-month followup comparing psychosocial interventions versus control conditions with two subgroups. The standardized mean difference for the 13 studies in the cannabis subgroup is −0.21 (95% confidence interval −0.39 to −0.04), with an I-squared value of 78%. The standardized mean difference for the 4 studies in the polysubstance subgroup is −0.05 (95% confidence interval −0.20 to 0.05), with an I-squared value of 1.3%. The overall standardized mean difference is −0.18 (95% confidence interval −0.32 to −0.05) with an I-squared value of 73%.

Figure 13 Psychosocial Interventions vs. Control Conditions—Drug Use Severity at 6- to 12- Month Followup, Stratified by Drug

Abbreviations: Adul = adult; Adol = adolescent; ASID = Addiction Severity Index (drugs); ASSIST = Alcohol, Smoking, and Substance Involvement Screening Test; ATTS = amphetamine-type stimulant use; CA = cannabis; CI = confidence interval; Comp = computer; FTF = face-to-face; MA = marijuana subscale; MI = minimal intervention; MPS = Marijuana Problem Scale; NIP = Noteworthy Index of Problems; PAdul = postpartum adult; RAPI = Rutgers Alcohol Problems Index; RMPI = Rutgers Marijuana Problem Index; SD = standard deviation; SDS = Severity of Dependence Scale; SMD = standardized mean difference; UC = usual care; WL = waitlist; YAdul = young adult.

Figure 13 is a forest plot examining drug use severity at 6- to 12-month followup comparing psychosocial interventions versus control conditions with three subgroups. The standardized mean difference for 1 study in the amphetamines subgroup is 0.10 (95% confidence interval −0.35 to 0.54). The standardized mean difference for the 8 studies in the cannabis subgroup is −0.16 (95% confidence interval −0.37 to 0.03), with an I-squared value of 72%. The standardized mean difference for the 4 studies in the polysubstance subgroup is −0.001 (95% confidence interval (−0.18 to 0.12), with an I-squared value of 42%. The overall standardized mean difference is −0.10 (95% confidence interval −0.24 to 0.02) with an I-squared value of 65%.

### Evidence

#### Naltrexone for Opioid Use Disorder

The 2008 USPSTF review included one trial of naltrexone for treatment of opioid use disorder.^5^ Including this trial, we identified thirteen trials (in 14 publications) on the effects of naltrexone versus placebo or no naltrexone for opioid use disorder in persons receiving drug use counseling (Table 1, Appendixes B1, B2, and B3).^5,25,26,70–80^ Sample sizes ranged from 31 to 306 (total N=1,718). In these trials, the diagnosis of opioid use disorder was generally based on meeting DSM-II-R, DSM-III, or DSM-IV criteria. Drug use counseling was usually described as individual (most common) or group counseling with a frequency ranging from 3 times/week to biweekly; however, details regarding counseling methods were limited. Twelve trials assessed oral naltrexone, one trial^26^ injectable naltrexone (300 mg every 4 weeks), and one trial^25^ implantable (not FDA-approved) naltrexone (1000 mg twice a month). Among trials of oral naltrexone, the dose was 50 mg daily in seven trials;^5,25,73–75,79,80^ up to 150 mg daily in two trials,^70,72^ and 100 or 150 mg two or three times weekly in three trials.^71,77,78^ Two trials evaluated naltrexone and placebo with or without a second medication (fluoxetine or guanfacine); the second medication did not appear to affect findings so we combined the naltrexone and non-naltrexone arms in analyses. The duration of treatment was 6 months in 10 trials. In the other three trials, the duration of treatment was 2,^77^ 3,^79^ or 9 months.^72^ Outcomes were assessed at the end of treatment in all trials except for two, which evaluated outcomes at 6 or 10 months following the completion of treatment.^77,78^ Five trials were conducted in Russia,^25,26,73–75^ two in Israel,^77,79^ two in the United States^71,72^, two in Europe,^78,80^ one in Malaysia,^70^ and one in China.^5^ Patients were recruited from inpatient settings, drug treatment settings, or from the criminal justice system (e.g., parolees); no study reported recruitment of patients from primary care settings, or identification of drug use through screening in primary care settings. Naltrexone treatment was administered in outpatient settings.

Table 1 Trials of Medications for Opioid Use Disorder vs. Placebo/No Medication

Drug | Author, year; Country; N; Quality | Population; Intervention vs. control | Intervention; route of administration | Dose | Duration of treatment | Relapse Intervention vs. control | Retention in treatment Intervention vs. control
Naltrexone | Cornish, 1997^71^; U.S.; N=51; Fair | NR by intervention group; Mean age 39 years; 10% female; Primary opioid of use: heroin; Duration of use: NR | Naltrexone; oral | 25 mg, titrated to 100 mg on Tuesday and 150 mg on Friday | 6 months | Proportion of opioid-positive urine tests; 8% vs. 30% (n/N NR) p<0.05 | 52% (18/34) vs. 33% (6/17)^*^; RR 1.50; 95% CI 0.73 to 3.07
Naltrexone | Guo, 2001^5^; China; N=49; Fair | Mean age 25 vs. 27 years; 11% vs. 7% female; Primary opioid of use: heroin; Duration of use: 3.6 vs. 3.6 years | Naltrexone; oral | 50 mg | 6 months | Not defined; 71% (25/35) vs. 93% (13/14); RR 0.77; 95% CI 0.60 to 0.99 | NR
Naltrexone | Hollister, 1978^72^; U.S.; N=192; Fair | Mean age NR; 0% vs. 0% female; Primary opioid of use: NR; Duration of use: NR | Naltrexone; oral | 50 mg to 100-150 mg | 9 months | ≥1 positive samples, among patients with ≥5 urine samples; 35% (21/60) vs. 41% (26/64); RR 0.86; 95% CI 0.55 to 1.36 | NR
Naltrexone | Krupitsky, 2004^73^; Russia; N=52; Fair | Mean age 23 vs. 21 years; 11% vs. 28% female; Primary opioid of use: heroin; Duration of use: 2.3 vs. 2.9 years | Naltrexone; oral | 50 mg | 6 months | ≥3 opioid-positive urine tests or signs/ symptoms of withdrawal; 30% (8/27) vs. 72% (18/25); RR 0.41; 95% CI 0.22 to 0.77 | 44% (12/27) vs. 16% (4/25); RR 2.78; 95% CI 1.03 to 7.49
Naltrexone | Krupitsky, 2006^74^; Russia; N=280; Fair | Mean age 24 vs. 23 years; 25% vs. 31% female; Primary opioid of use: heroin; Duration of use: 3.8 vs. 3.4 years | Naltrexone; oral | 50 mg | 6 months | Reported everyday heroin use, ≥3 consecutive opioid-positive urine tests, or signs/symptoms of withdrawal; 31% (43/140) vs. 60% (84/140); RR 0.51 95% CI 0.39 to 0.68 | 39% (55/140) vs. 16% (22/140); RR 2.50; 95% CI 1.62 to 3.86
Naltrexone | Krupitsky, 2011^26^; Russia; N=250; Good | Mean age 29 vs. 30 years; 10% vs. 14% female; Primary opioid of use: heroin; Duration of use: 9.1 vs. 10.0 years | Naltrexone; injectable | 300 mg every 4 weeks | 6 months | Positive urine drug test or self-reported opioid use; 64% (81/126) vs. 77% (96/124); RR 0.83; 95% CI 0.71 to 0.98 | 53% (67/126) vs. 38% (47/124); RR 1.40; 95% CI 1.06 to 1.85
Naltrexone | Krupitsky, 2012^25^ and Krupitsky, 2016^76^; Russia; N=306; Good | Mean age 28 vs. 28 vs. 29 years; 28% vs. 28% vs. 28% female; Primary opioid of use: heroin; Duration of use: 7.8 vs. 7.9 vs. 8.3 years | A: Naltrexone; implant; B: Naltrexone; oral | A: 1,000 mg bimonthly; B: 50 mg | 6 months | Daily heroin use, signs and symptoms of withdrawal, or positive naloxone challenge; A: 13% (13/102) vs. B: 57% (58/102) vs. placebo: 69% (70/102); A vs. placebo: RR 0.19; 95% CI 0.11 to 0.33; B vs. placebo: RR 0.84; 95% CI 0.66 to 1.09 | A: 53% (54/102) vs. B: 16% (16/102) vs. placebo: 11% (11/102); A vs. placebo: RR 5.40; 95% CI 2.30 to 12.66; B vs. placebo: RR 1.33; 95% CI 0.56 to 3.20
Naltrexone | Krupitsky, 2013^75^; Russia; N=301; Good | Mean age 28 vs. 28 years; 16% vs. 19% female; Primary opioid of use: heroin; Duration of use: 8.1 vs. 8.5 years | Naltrexone; oral | 50 mg | 6 months | Daily heroin use, 3 consecutive opioid-positive urine tests, or signs/ symptoms of withdrawal; 36.4% (55/151) vs. 52.0% (78/150); RR 0.70; 95% CI 0.54 to 0.91 | 23% (35/151) vs. 8.7% (13/150); RR 2.67; 95% CI 1.47 to 4.85
Naltrexone | Lerner, 1992^77^; Israel; N=31; Fair | NR by intervention group; Mean age 27 years; % female: NR; Primary opioid of use: heroin; Duration of use: 2.8 years | Naltrexone; oral | 12.5 mg, titrated to 50 mg, then 100 mg Monday and Wednesday, 150 mg Friday | 2 months (12 month follow-up) | Positive urine drug test, 12 months; 47% (7/15) vs. 62% (10/16); RR 0.75; 95% CI 0.39 to 1.45 | NR (only reported through 2 months)
Naltrexone | San, 1991^78^; Spain; N=50; Fair | Mean age 26 vs. 27 years; 21% vs. 27% female; Primary opioid of use: heroin; Duration of use: 6.5 vs. 8.0 years | Naltrexone; oral | 100 mg Monday and Wednesday, 150 mg Friday | 6 months (12 month follow-up) | Positive urine drug test, 12 months; 57% (16/28) vs. 55% (12/22); RR 1.05; 95% CI 0.64 to 1.72 | 14% (4/28) vs. 36% (8/22); RR 0.39; 95% CI 0.14 to 1.14
Naltrexone | Schottenfeld, 2008^70^,^†^; Malaysia; N=82 (naltrexone and control arms); Fair | Mean age 38 vs. 36 years; % female: NR; Primary opioid of use: heroin; Duration of use: 16.4 vs. 14.8 years | Naltrexone; oral | 50 mg, titrated to 100-150 mg | 6 months | 3 consecutive positive urine tests or opiate positive test followed by two consecutive positive or missing tests:; 91% (39/43) vs. 92% (36/39); RR 0.98; 95% CI 0.86 to 1.12 | 21% (9/43) vs. 13% (5/39); RR 1.63; 95% CI 0.60 to 4.45
Naltrexone | Shufman, 1994^79^; Israel; N=32; Fair | Mean age 34 vs. 32 years; 0% vs. 0% female; Primary opioid of use: heroin; Duration of use: 6.7 vs. 5.9 years | Naltrexone; oral | 25 mg, titrated to 50 mg | 3 months | ≥1 positive urine drug test:; 62% (10/16) vs. 81% (13/16); RR 0.77; 95% CI 0.49 to 1.20 | 50% (8/16) vs. 56% (9/16); RR 0.89; 95% CI 0.46 to 1.71
Naltrexone | Stella, 2005^80^; Italy; N=42; Fair | Mean age: NR; % female: NR; Primary opioid of use: NR; Duration of use: NR | Naltrexone; oral | 50 mg | 6 months | Not defined; 57% (16/28) vs. 79% (11/14); RR 0.75; 95% CI 0.63 to 0.90 | NR
Buprenorphine | Kakko, 2003^82^; Sweden; N=40; Fair | Mean age 29 vs. 32 years; 25% vs. 30% female; Primary opioid of use: heroin; Duration of use: 5.8 vs. 4.8 years | Buprenorphine; sublingual | 16 mg/day | 12 months | ≥2 positive urine samples within last 3 months; 20% (4/20) vs. 100% (20/20); RR 0.20 (95% CI 0.08 to 0.48) | Voluntary or involuntary withdrawal: 75% (15/20) vs. 0% (0/20); RR 33.00 (95% CI 2.11 to 515.05)
Buprenorphine | Krook, 2002^83^; Norway; N=106; Fair | Mean age 38 vs. 38 years; 35% vs. 33% female; Primary opioid of use: heroin; Duration of use: 20 vs. 20 years | Buprenorphine; sublingual | 16 mg/day | 3 months | Self-reported heroin use, mean change from baseline (0-10 visual analog scale); −3.21 vs. 0.52; p<0.001 | 29% (16/55) vs. 2% (1/51); RR 14.84 (95% CI 2.04 to 107.89)
Buprenorphine | Ling, 2010^84^; U.S.; N=163; Fair | Mean age 36 vs. 39 years; 33% vs. 27% female; Primary opioid of use: heroin (63%); prescription pain medication (37%); Duration of use: NR; duration >5 years: 16% vs. 14% | Buprenorphine; implant | 320 mg | 6 months | Mean proportion of negative urine tests (72 samples per patient):; 36.6% (95% CI 30.5% to 42.6%) vs. 22.4% (15.3% to 29.5%); p=0.01 | 66% (71/108) vs. 31% (17/55); RR 2.13 (95% CI 1.40 to 3.23)
Buprenorphine | Rosenthal, 2013^85^; U.S.; N=287; Good | Mean age 36 vs. 35 vs. 35 years; 37% vs. 40% vs. 43% female; Primary opioid of use: heroin (62%); prescription pain medication (37%); unspecified other (1%); Duration of use: NR; proportion with duration >5 years: 25% vs. 31% vs. 22% | A: Buprenorphine; implant; B: Buprenorphine- naloxone; sublingual | A: 320 mg; B: 12-16 mg/day | 6 months | >50% of urine samples negative for opioids: A: 72.8% (83/114) vs. B: NR vs. placebo: 94.4% (51/54); A vs. placebo: RR 0.77 (95% CI 0.68 to 0.88 | Completed trial; A: 64% (73/114) vs. B: 64% (76/119) vs. placebo: 26% (14/54); (A or B) vs. placebo: RR 2.5 (95% CI 1.6 to 3.9)
Buprenorphine | Schottenfeld, 2008^70^,^†^; Malaysia; N=83; (buprenorphine and control arms); Fair | Mean age 38 vs. 36 years; % female: NR; Primary opioid of use: heroin; Duration of use: 16.4 vs. 14.8 years | Buprenorphine; sublingual | 8 mg/day, titrated to 16 to 24 mg/day | 6 months | 3 consecutive positive urine tests or opiate positive test followed by two consecutive positive or missing tests: 75% (33/44) vs. 92% (36/39); RR 0.81 (95% CI 0.67 to 0.99) | 41% (18/44) vs. 13% (5/39); RR 3.19 (95% CI 1.31 to 7.79)
Methadone | Gruber, 2008^81^; U.S.; N=111; Fair | Mean age 43 vs. 40 vs. 43 years; 46% vs. 46% vs. 26% female; Primary opioid of use: heroin; Duration of use: 16.6 vs. 16.9 vs. 20.4 years | A: Methadone; oral (+ minimal counseling); B: Methadone; oral (+ standard counseling) | Up to 90 mg/day | 6 months | Self-reported heroin use (days); A: 5.9 (SD 7.7) vs. B: 4.2 (SD 6.7) vs. placebo: 18.4 (SD 12.8); A vs. placebo: p=0.0003 | Retention at 8.5 months; A: 48.6% (17/35) vs. B: 51.4% (19/37) vs. placebo: 38.5% (15/39): (A or B) vs. placebo: RR 1.30 (95% CI 0.82 to 2.06)
Methadone | Schwartz, 2007^86^; Schwartz, 2006^6^; Schwartz, 2009^87^; U.S.; N=319; Good | Mean age 41 vs. 42 years; 42% vs. 38% female; Primary opioid of use: heroin; Duration of use: 18 vs. 19 years | Methadone; oral | Mean 78.4 mg/day | 4 months | Opioid-positive drug test: 57% (99/175) vs. 79% (80/101); RR 0.71 (95% CI 0.61 to 0.84) | Entered into methadone treatment: 76% (151/199) vs. 21% (25/120); RR 3.64 (95% CI 2.55 to 5.21)

* n/N estimated from reported denominators and proportions.

† Study included naltrexone, buprenorphine and control arms; total N=126.

Abbreviations: CI = confidence interval; NR = not reported; RR = risk ratio; SD = standard deviation; U.S. = United States.

In all trials that reported the opioid of use, heroin was the primary opioid of use in all or nearly all patients. Study participants were predominantly men (proportion female ranged from 0 to 31 percent); no trial reported outcomes stratified by patient sex. The mean age ranged from 21 to 29 years, with no studies conducted in adolescents. In studies that reported the duration of drug use, the mean ranged from 2 to over 16 years.^5,25,26,70,73–79^ Information to characterize the severity of drug use was otherwise limited. All trials required patients to be withdrawn from opioids prior to initiation of naltrexone. Four trials^25,26,70,78^ described inpatient or residential withdrawal from opioids; details about withdrawal methods and setting were otherwise not reported well.

Three studies were rated good quality^25,26,75^ and the remainder were rated fair quality (Appendix B4). Methodological shortcomings in the fair-quality trials included unclear randomization or allocation concealment methods and unclear or high attrition. All trials were blinded.

##### Detailed Results: Drug Use and Other Risky Behaviors

Thirteen trials reported effects of naltrexone versus placebo or no naltrexone on risk of drug use relapse.^5,25,26,70–80^ Definitions for relapse varied and were based on findings on urine drug tests, self-report, and/or presence of signs or symptoms of withdrawal; in two trials^5,80^ relapse was not defined (Table 1). Among the non-naltrexone arms, the proportion of patients with relapse ranged from 41 to 93 percent. Naltrexone was associated with decreased risk of relapse versus placebo or no naltrexone (12 trials; RR 0.73, 95% CI 0.62 to 0.85; Figure 2; ARD −18%, 95% CI −26% to −10%).^5,25,26,70,72–80^ Treatment with naltrexone was for 2 to 9 months (6 months in 9 trials) and outcomes were assessed at 3 to 12 months after the start of treatment. Although statistical heterogeneity was high (I^2^=78%), the RR estimate favored naltrexone in all but two trials,^70,78^ which both reported point estimates close to one. Estimates were similar for naltrexone administered orally (11 trials; RR 0.76, 95% CI 0.65 to 0.88; I^2^=70%)^5,25,70,72–80^ or by injection/implant (2 trials; RR 0.41, 95% CI 0.06 to 2.40; I^2^=98%) (Table 2).^25,26^ Excluding two trials^77,78^ that evaluated risk of relapse 6 or 10 months after discontinuation of naltrexone had little impact on the pooled estimate (10 trials; RR 0.71, 95% CI 0.59 to 0.84; I^2^=82%). Restricting the analysis to trials of oral naltrexone at a dose of 50 mg/day (7 trials; RR 0.69, 95% CI 0.58 to 0.81; I^2^=47%)^5,25,73–75,79,80^ or to good-quality trials (3 trials; RR 0.67, 95% CI 0.48 to 0.94; I^2^=84%)^25,26,75^ also resulted in similar pooled estimates. One trial that did not provide poolable relapse data reported results consistent with the pooled findings.^71^

Table 2 Naltrexone Trials—Relapse and Retention in Treatment

Outcome; Study Characteristics | Group analyzed | Number of trials | Relative risk (95% confidence interval) | I^2^
Relapse, all trials | All participants | 12 | 0.73 (0.62 to 0.85) | 78%
Route of administration; p for interaction=0.13 | Oral | 11 | 0.76 (0.65 to 0.88) | 70%
Route of administration; p for interaction=0.13 | Injection or implant | 2 | 0.41 (0.06 to 2.40) | 98%
Timing of outcome assessment; p for interaction=0.36 | On treatment | 10 | 0.71 (0.59 to 0.84) | 82%
Timing of outcome assessment; p for interaction=0.36 | Post intervention | 2 | 0.93 (0.54 to 1.50) | 0%
Study quality; p for interaction=0.52 | Good quality | 3 | 0.67 (0.48 to 0.94) | 84%
Study quality; p for interaction=0.52 | Fair quality | 9 | 0.76 (0.61 to 0.91) | 78%
Naltrexone dose (oral administration); p for interaction=0.70 | ≤50 mg/day | 7 | 0.69 (0.58 to 0.81) | 47%
Naltrexone dose (oral administration); p for interaction=0.70 | >50 mg/day | 4 | 0.97 (0.81 to 1.11) | 0%
Retention in treatment, all trials | All participants | 9 | 1.71 (1.13 to 2.49) | 67%
Route of administration; p for interaction=0.37 | Oral | 8 | 1.59 (1.00 to 2.38) | 61%
Route of administration; p for interaction=0.37 | Injection or implant | 2 | 2.48 (0.58 to 11.75) | 94%
Timing of outcome assessment; p for interaction=0.05 | On treatment | 8 | 1.89 (1.36 to 2.65) | 59%
Timing of outcome assessment; p for interaction=0.05 | Post intervention | 1 | 0.39 (0.14 to 1.14) | --
Study quality; p for interaction=0.33 | Good quality | 3 | 2.10 (1.21 to 4.13) | 78%
Study quality; p for interaction=0.33 | Fair quality | 6 | 1.43 (0.78 to 2.47) | 67%
Naltrexone dose (oral administration); p for interaction=0.18 | ≤50 mg/day | 6 | 1.84 (1.22 to 2.71) | 49%
Naltrexone dose (oral administration); p for interaction=0.18 | >50 mg/day | 2 | 0.82 (0.14 to 4.48) | 73%

Nine trials reported effects of naltrexone versus placebo or no naltrexone on the likelihood of retention in treatment.^25,26,70,71,73–75,78,79^ In some trials, relapse was included in the definition of non-retention. Among the arms not receiving naltrexone, rates of retention ranged from 9 to 56 percent. Naltrexone was associated with increased likelihood of treatment retention (9 trials; RR 1.71, 95% CI 1.13 to 2.49; I^2^=67%; Figure 3; ARD 15%, 95% CI 5% to 22%). There was no interaction between route of naltrexone administration and likelihood of treatment retention (oral: 8 trials; RR 1.59, 95% CI 1.00 to 2.38; I^2^=61%; injection/implant: 2 trials; RR 2.48, 95% CI 0.58 to 11.75; I^2^=94%; p for interaction=0.37) (Table 2). Results were similar when analyses were restricted to trials of oral naltrexone at a dose of 50 mg/day (6 trials; RR 1.84, 95% CI 1.22 to 2.71; I^2^=49%)^25,73–75,79^ or to good quality trials (3 trials; RR 2.10, 95% CI 1.21 to 4.13; I^2^=78%).^25,26,75^

Effects on other outcomes related to other drug use and/or risk behaviors were reported less consistently (Appendix B3). Five trials reported no difference between naltrexone versus placebo or no naltrexone in risk of alcohol, marijuana, or other (non-opiate) drug use.^72–74,78,79^ There were no clear differences between naltrexone versus placebo or versus no naltrexone in measures of addiction severity (2 trials)^73,74^ or severity of drug use or risky sexual behaviors (4 trials).^26,70,73,74^

##### Detailed Results: Health, Social and Legal Outcomes

Mortality was rare in the naltrexone trials, with a total of three deaths (2 naltrexone and 1 placebo) in five trials.^26,70,73,74,78^

Evidence on the effects of naltrexone versus placebo or no naltrexone on health outcomes such as global function, quality of life, depression, and anxiety was limited. One trial found no difference between naltrexone versus placebo in the Global Assessment of Function (GAF).^75^ Another trial found naltrexone associated with improved quality of life, as measured by the mean change in Euro-Qol-5 score (14.1 versus 2.7; p=0.0005), the proportion of patients with improvement in Clinical Global Impressions scale (86% versus 58%; p=0.0002), and mean difference in Short Form Health Survey (SF)-36 mental component score (5.09, 95% CI 2.09 to 8.09; p=0.004)^26^ Five trials reported effects of naltrexone on psychiatric measures. Four trials found no differences between naltrexone versus placebo in risk of anxiety^80^ or depression,^75,79^ or in scores on the Brief Psychiatric Rating Scale (BPRS).^73^ One other trial found naltrexone associated with more severe depression, based on the Minnesota Multifactorial Personality Inventory (MMPI) depression scores (mean 73.7 versus 65.5; p<0.02).^78^ Two other trials reported results that appeared to favor naltrexone based on scales measuring depression (Beck Depression Inventory [BDI]) and anxiety (Spielberger State-Anxiety Inventory [SSAI], State-Trait Anxiety Inventory [STAI]) severity, but the statistical significance of between group comparisons was not reported.^73,76^

Three trials reported legal outcomes.^71,72,77^ One trial of persons on parole or probation found those taking naltrexone had lower rates of reincarceration than those taking no medication (26% versus 56%; RR 0.45, 95% CI 0.23 to 0.89).^71^ Two other trials reported no difference between naltrexone versus placebo in the likelihood of contact with law enforcement.^72,77^ One trial reported no difference between naltrexone versus placebo in likelihood of employment.^78^

#### Opioid Agonist Therapy (Buprenorphine or Methadone) for Opioid Use Disorder

The 2008 USPSTF report included one trial of methadone for treatment of opioid use disorder.^6^ Including this trial, we identified seven trials (reported in 9 publications) on the effects of opioid agonist therapy with buprenorphine or methadone versus placebo or no medication (waitlist or usual care) for opioid use disorder (Table 1, Appendixes B5, B6, and B7).^6,70,81–87^ Sample sizes ranged from 40 to 319 (total N=1,109). Two trials^6,81,86,87^ evaluated oral methadone. The dose of methadone was up to 90 mg/day in one trial^81^ and averaged 78 mg/day in the other trial.^6,86,87^ Five trials^70,82–85^ evaluated buprenorphine. Buprenorphine was taken sublingually in four trials^70,82,83,85^ (dose ranged from 8 to 24 mg/day) and administered by implant in two trials^84,85^ (4 implants, with a total dose of 320 mg). One trial^85^ evaluated both oral and implanted buprenorphine. The duration of treatment ranged from three to twelve months (6 months in 4 trials^70,81,84,85^ and 3,^83^ 4,^86^ or 12^82^ months in 1 trial each). The buprenorphine implant trials required that patients successfully undergo induction with sublingual buprenorphine prior to randomization. Oral methadone and sublingual buprenorphine were administered daily under direct observation, though some trials allowed take-home doses for weekends and holidays. In five trials, all patients received some individual and/or group drug use counseling.^70,81,82,84,85^ The intensity of counseling ranged from “minimal” (not described) to “standard” counseling for 45 to 60 minutes on a weekly or twice weekly basis. Two trials did not include a counseling intervention;^6,83,86,87^ both were designed to evaluate bridging therapy with methadone or buprenorphine while awaiting entry into more comprehensive care.

The main type of opioid used was heroin in all of the trials. In two trials, prescription opioids were the main opioid of use in about one-third of patients.^84,85^ Prescription opioid use was not described in the other trials. In five trials, the diagnosis of opioid use disorder was based on DSM-IV criteria.^6,70,81,84–87^ Criteria for the diagnosis of opioid use disorder were not specified in the other two trials.^81,83^ Four trials were conducted in the United States,^6,81,84–87^ two trials in Europe,^82,83^ and one trial in Malaysia.^70^ Patients were recruited from inpatient settings in one trial,^82^ from the community in one trial,^70^ and from outpatient addiction treatment settings in the other five trials. In one trial, treatment was initiated on an inpatient basis.^82^ Otherwise, treatment was administered in outpatient addiction treatment settings.

Study participants were predominantly male (proportion female ranged from 25% to 43%) and mean age ranged from 29 to 43 years; no study was conducted in adolescents. No trial stratified outcomes by patient sex. In studies that reported the duration of drug use, the mean ranged from 5 to 20 years.^70,81–83^ Three studies reported that the mean number of days of heroin use in the last 30 days ranged from 19 to 30.^6,70,81,86,87^

Two studies were rated good-quality^6,85–87^ and the remainder were rated fair quality (Appendix B8). Methodological shortcomings in the fair-quality trials included unclear randomization or allocation concealment methods and unclear or high attrition. Both methadone trials utilized an unblinded design; one trial^81^ compared methadone versus usual care and the other trial^6,86,87^ compared methadone versus waitlist control.

##### Detailed Results: Drug Use and Other Risky Behaviors

Four trials reported effects of opioid agonist therapy with buprenorphine or methadone versus placebo or no medication on risk of drug use (Table 1).^6,70,82,85–87^ Drug use outcomes were informed by urine drug test findings, though specific criteria varied (Table 1). Among the control arms, the proportion of patients with relapse ranged from 79 to 100 percent. Opioid agonist therapy was associated with decreased risk of relapse versus controls after 4 to 12 months of treatment (4 trials; RR 0.75, 95% CI 0.59 to 0.82; I^2^=75%; Figure 4; ARD −35%, 95% CI −67% to −13%).^6,70,82,85–87^ Although statistical heterogeneity was high, all four trials found opioid agonist therapy to be effective, with relative risk estimates ranging from 0.22 to 0.81. Estimates were similar in one trial of methadone (RR 0.71, 95% CI 0.61 to 0.84)^6,86,87^ and three trials of buprenorphine (RR 0.59, 95% CI 0.21 to 1.31; I^2^=84%);^70,82,85^ stratification by drug did not reduce statistical heterogeneity and there was no statistically significant interaction (p=0.78). The methadone trial did not include counseling. Stratification of the buprenorphine trials according to whether administration was sublingual (2 trials, RR 0.46, 95% CI 0.08 to 2.19, I^2^=93%)^70,82^ or by implant (1 trial, RR 0.77, 95% CI 0.68 to 0.88)^85^ also did not reduce statistical heterogeneity, with no statistically significant interaction (p=0.70). Restricting the analysis to two good quality trials resulted in a pooled estimate (RR 0.75, 95% CI 0.65 to 0.85, I^2^=0%) very similar to the overall estimate (Table 3).^6,85–87^

Table 3 Opioid Agonist Trials—Relapse and Retention in Treatment

Outcome; Study Characteristics | Group analyzed | Number of trials | Relative risk (95% confidence interval) | I^2^
Relapse, all trials | All participants | 4 | 0.75 (0.59 to 0.82) | 75%
Drug; p for interaction=0.78 | Buprenorphine | 3 | 0.59 (0.21 to 1.31) | 84%
Drug; p for interaction=0.78 | Methadone | 1 | 0.71 (0.61 to 0.84) | -
Type of counseling; p for interaction=0.78 | Standard counseling | 3 | 0.59 (0.21 to 1.31) | 84%
Type of counseling; p for interaction=0.78 | No counseling | 1 | 0.71 (0.61 to 0.84) | -
Study quality; p for interaction=0.54 | Good quality | 2 | 0.75 (0.65 to 0.85) | 0%
Study quality; p for interaction=0.54 | Fair quality | 2 | 0.46 (0.08 to 2.19) | 93%
Buprenorphine route of administration; p for interaction=0.70 | Sublingual | 2 | 0.46 (0.08 to 2.19) | 93%
Buprenorphine route of administration; p for interaction=0.70 | Implant | 1 | 0.77 (0.68 to 0.88) | --
Retention in treatment, all trials | All participants | 7 | 2.58 (1.78 to 4.59) | 71%
Drug; p for interaction=0.54 | Buprenorphine | 5 | 2.52 (1.89 to 4.74) | 51%
Drug; p for interaction=0.54 | Methadone | 2 | 2.22 (0.63 to 7.56) | 92%
Type of counseling; p for interaction=0.79 | Standard counseling | 5 | 2.09 (1.54 to 3.33) | 56%
Type of counseling; p for interaction=0.79 | Minimal or no counseling | 3 | 2.78 (0.93 to 13.74) | 86%
Study quality; p for interaction=0.72 | Good quality | 2 | 3.15 (1.90 to 4.81) | 42%
Study quality; p for interaction=0.72 | Fair quality | 5 | 2.34 (1.41 to 9.20) | 73%
Buprenorphine route of administration; p for interaction=0.46 | Sublingual | 4 | 2.95 (1.97 to 12.06) | 57%
Buprenorphine route of administration; p for interaction=0.46 | Implant | 2 | 2.27 (1.58 to 3.31) | 0%

Three trials reported effects of opioid agonist therapy with buprenorphine or methadone on drug use outcomes that could not be pooled.^81,83,84^ Results also indicated positive effects of opioid agonist therapy on drug use (Table 1). One trial found methadone with minimal or standard counseling associated with fewer self-reported days of heroin use versus usual care (4.2 to 5.9 vs. 18.4); counseling intensity had no clear effect.^81^ One trial found sublingual buprenorphine without counseling associated with greater decrease in self-reported heroin use versus placebo (−3.2 vs. 0.52 on a 0 to 10 Visual Analog Scale [VAS], p<0.001).^83^ A third trial found sublingual buprenorphine associated with a higher proportion of negative urine drug tests versus placebo (37% vs. 22%, p=0.01).^84^

Seven trials reported effects of opioid agonist therapy versus placebo or versus no medication on likelihood of retention in treatment.^6,70,81–87^ In some trials, relapse was included in the definition of non-retention (Appendixes B5, B6, and B7). Among patients who did not receive opioid agonists, rates of retention ranged from 0 to 38 percent. Opioid agonist therapy was associated with increased likelihood of treatment retention (7 trials; RR 2.58, 95% CI 1.78 to 4.59; I^2^=71%; Figure 5; ARD 39%, 95% CI 23% to 54%). Statistical heterogeneity was present, but all trials reported estimates in favor of buprenorphine or methadone; relative risk estimates ranged from 1.30 to 31.00. Pooled estimates were similar for five trials^70,82–85^ of buprenorphine (RR 2.52, 95% CI 1.89 to 4.74, I^2^=51%) and two trials^6,81,86,87^ of methadone (RR 2.22, 95% CI 0.63 to 7.56, I^2^=92%), with no statistically significant interaction (p=0.54) (Table 3). Among trials of buprenorphine, there was no statistically significant interaction between sublingual administration (4 trials; RR 2.95, 95% CI 1.97 to 12.06, I^2^=57%)^70,82,83,85^ or administration as an implant (2 trials; RR 2.27, 95% CI 1.58 to 3.31, I^2^=0%)^84,85^ and retention in treatment (p for interaction=0.46). Restricting the analysis to two good quality trials (RR 3.15, 95% CI 1.90 to 4.81; I^2^=42%) resulted in a pooled estimate similar to the overall estimate (Table 3).^6,85^ Pooled estimates were also similar for trials with minimal or no counseling (3 trials; RR 2.78, 95% CI 0.93 to 13.74; I^2^=86%)^6,81,83,86,87^ and trials with standard counseling (5 trials; RR 2.09, 95% CI 1.54 to 3.33; I^2^=56%; p for interaction=0.79).^70,81,82,84,85^

Effects on other outcomes related to other drug use and/or risk behaviors were reported less consistently (Appendix B7). Two trials reported inconsistent effects of methadone versus placebo on cocaine use,^6,81,86,87^ one trial found methadone associated with decreased alcohol use,^81^ and one trial found no effects of methadone on the Addiction Severity Index (ASI).^81^ One trial found sublingual buprenorphine associated with decreased non-opioid drug use versus placebo.^83^ Another trial found sublingual buprenorphine associated with more days in treatment without heroin relapse versus placebo (79 vs. 39, p=0.007) and no difference in HIV risk behaviors based on the AIDS Risk Inventory score.^70^

##### Detailed Results: Health, Social, and Legal Outcomes

Evidence on health outcomes associated with opioid agonist therapy versus placebo or versus no opioid agonist therapy was very limited. Mortality was reported in two trials of buprenorphine. There were a total of four deaths, all in patients randomized to placebo.^70,82^ Two trials found implanted buprenorphine associated with greater likelihood of reporting a “very much” or “much” improved Clinical Global Impressions (CGI) (RR 1.36, 95% CI 1.06 to 1.74; I^2^=43%).^84,85^ One trial found no difference between sublingual buprenorphine versus placebo in anxiety and depression (based on the Symptom Checklist [SCL]-5 scale), but buprenorphine was associated with greater wellbeing (mean change from baseline −2.00 vs. −0.43 on a 0 to 10 VAS, p<0.001) and life satisfaction (mean change −0.65 vs. −0.24 on the 0 to 10 Temporal Satisfaction with Life Scale [TSLS], p<0.05).^83^ No trial reported the effects of opioid agonist therapy on social or legal outcomes.

#### Psychosocial Interventions

Fifty-two trials (reported in 65 publications) evaluated psychosocial interventions for unhealthy drug use or drug use disorders (Table 4, Appendixes B9, B10, and B11).^4,30–33,44–69,88–121^

Table 4 Psychosocial Intervention Trials—Study Characteristics Interventions

Author, year; Country; N; Quality | Population; Type of drug use | Screen-detected? | Type of intervention | Method of delivery | Number of sessions | Duration of sessions (hours, unless otherwise stated) | Control | Timing of outcome assessment (months)
Babor, 2004^30^; U.S.; N=450; Good | Adult; Cannabis | No | A. Multicomponent (MET + CBT + case management); B. Brief MET | A. Face-to-face; B. Face-to-face | A. 9; B. 2 | A. NR; B. 1 | Waitlist | 4
Baker, 2001a^88^ and Baker, 2001b^89^; Australia; N=64; Fair | Adult; Amphetamines | No | A. CBT + MI; B. Brief CBT | A. Face-to-face; B. Face-to-face | A. 4; B. 2 | A. 0.5-1; B. 0.5-1 | Minimal intervention | 6
Baker, 2005^90^; Australia; N=214; Fair | Adult; Amphetamines | No | A. CBT + MI; B. Brief CBT | A. Face-to-face; some assessments conducted over the telephone; B. Face-to-face; some assessments conducted over the telephone | A. 4; B. 2 | A. 0.75-1; B. 0.75-1 | Minimal intervention | 6
Bernstein, 2005^4^; U.S.; N=1,175; Fair | Adults; Cocaine; heroin | Yes^*^ | Brief MI + telephone booster | Face-to-face; telephone | 1 | 10-45 minutes | Minimal intervention | 6
Bernstein, 2009^45^; U.S.; N=139; Fair | Adolescent/ Young Adult; Cannabis | Yes | Brief MI | Face-to-face; telephone | 1 | 20-30 minutes + 5-10 minute telephone booster call | Usual care | 12
Blow, 2017 ^46^ Bonar, 2018^91^; U.S.; N=780; Good | Adult; Cannabis | Yes | A. Brief MI, computer-delivered; B. Brief MI, therapist-delivered | A. Computer; B. Face-to-face | A. 1; B. 1 | A. 30 minutes; B. 30 minutes | Usual care | 12
Bogenschulz, 2014^47^ and Bogenschulz, 2011^115^; U.S.; N=854; Fair | Adult; Multiple drugs (18% street opioids; 5% prescription opioids) | Yes | Brief MI + telephone booster | Face-to-face; telephone | 1 + 2 telephone booster calls | NR | Minimal intervention | 12
Copeland, 2001a^31^ and Copeland, 2001b^92^; Australia; N=229; Fair | Adult; Cannabis | No | A. CBT; B. CBT | A. Face-to-face; B. Face-to-face | A. 6; B. 1 | A. 1; B. 1.5 | Waitlist | 6
D’Amico, 2018^44^; U.S.; N=294; Fair | Adolescent; Cannabis | Yes | Brief MI | Face-to-face | 1 | 0.25-0.33 | Minimal intervention | 12
de Dios, 2012^93^; U.S.; N=34; Fair | Young Adult; Cannabis | No | Brief MET + mindfulness meditation | Face-to-face | 2 | NR | Minimal intervention | 3
de Gee, 2014^94^; The Netherlands; N=119; Good | Young Adult; Cannabis | No | MI | Face to face | 2 | 1.5 | Minimal intervention | 3
Dembo, 2016^95^; U.S.; N=300; Fair | Adolescent; Cannabis | No | A. Brief MET + CBT (youth only); B. Brief MET (youth and parent) | Face-to-face | A. 2; B. 2 | A. 1.5; B. 1.5 | Usual care | 18
Dupont, 2016^96^; The Netherlands; N=131; Fair | Adolescent / Young Adult; Cannabis | No | MET | Face-to-face | 4 | NR | Usual care | 6
Fischer, 2012^98^ and Fischer, 2013^97^; Canada; N=134; Fair | Young Adult; Cannabis | No | Brief oral or written intervention consisting of short, fact-based and nonjudgmental information on cannabis-related health risks | Face-to-face | 1 | 30 minutes | Minimal intervention | 12
Gates, 2012^99^; Australia; N=149; Fair | Adult; Cannabis | No | CBT + MI | Telephone | 4 | 1 | Waitlist | 3
Gelberg, 2015^48^ and Baumeister, 2014^114^; U.S.; N=334; Fair | Adult; Multiple drugs (7% opioids) | Yes^*^ | Brief MI + telephone booster | Face-to-face; telephone | 1 + 2 telephone booster calls | 3-4 minutes + 20-30 minute telephone booster | Minimal intervention | 3
Gelberg, 2017^49^; U.S.; N=65; Fair | Adult; Multiple drugs (11% opioids) | Yes^*^ | Brief MI + telephone booster | Face-to-face; telephone | 1 + 2 telephone booster calls | 3-4 minutes + 20-30 minute telephone booster | Minimal intervention | 3
Gryczynski, 2016^50^; United States; N=80; Fair | Adult; Multiple drugs (24% opioids [proportion of patients at moderate risk]) | Yes^*^ | Brief computer intervention | Computer | 1 | 10 minutes | Waitlist | 3
Humeniuk, 2012^51^; Australia, Brazil, India, U.S.; N=389; Fair | Adolescent/ Adult; Multiple drugs (13% opioids [proportion of patients at moderate risk]) | Yes^*^ | Brief MI | Face-to-face | 1 | 15 minutes | Waitlist | 3
Jones, 2005^100^; U.S.; N=130; Fair | Adult; Opioids | No | Contingency management | Face-to-face | 57 | NR | Usual care | 6
Lee, 2010^53^; U.S.; N=341; Fair | Adolescent/ Young Adult; Cannabis | Yes | Brief MI | Computer | 1 | NR | Minimal intervention | 6
Lee, 2013^52^; U.S.; N=212; Fair | Young Adult; Cannabis | Yes | Brief MI | Face-to-face | 1 | 1 | Minimal intervention | 6
Litt, 2005^103^; U.S.; N=450; Fair | Adult; Cannabis | No | A. CBT + MET; B. Brief MET | Face-to-face | A. 9; B. 2 | NR | Waitlist | 4
Litt, 2008^101^ and Kadden, 2007^121^; U.S.; N=240; Fair | Adult; Cannabis | No | A. CBT + MET + contingency management; B. CBT + MET; C. Contingency management | Face-to-face | A. 9; B. 9; C. 9 | A. 1; B. 1; C. 15 minutes | Usual care | 14
Litt, 2013^102^; U.S.; N=215; Fair | Adult; Cannabis | No | A. CBT + MET + contingency management (for completing homework assignments); B. CBT + MET + contingency management (for cannabis-free urine samples) | Face-to-face | A. 9; B. 9 | A. 1; B. 1 | Usual care | 9
Lozano, 2006^104^; U.S.; N=290; Fair | Adult; Cannabis | No | A. CBT; B. MET | Face-to-face | A. 14; B. 2 | A. 2; B. 1.5 | Waitlist | 4
Marsden, 2006^105^; U.K.; N=342; Good | Adolescent/ Young Adult; Stimulants | No | Brief MET | Face-to-face | 1 | 45 minutes | Minimal intervention | 6
Martin, 2008^106^; Australia; N=40; Fair | Adolescent; Cannabis | No | Brief CBT | Face-to-face | 2 | NR | Waitlist | 3
Martino, 2018^54^; U.S.; N=439; Good | Adults; Multiple drugs (% opioids NR) | Yes^*^ | A. Brief MI (in person); B. Brief MI (computer) | A. Face-to-face; B. Computer | A. 1; B. 1 | A. 20 minutes; B. 20 minutes | Usual care | 6
Mason, 2015^55^ and Mason, 2017^119^; U.S.; N=119; Fair | Adolescent; Cannabis and alcohol | Yes^*^ | Brief MI | Face-to-face | 1 | 20 minutes | Minimal intervention | 6
McCambridge, 2004^108^ and McCambridge, 2005^32^; U.K.; N=200; Fair | Adolescent/ Young Adult; Cannabis; Stimulants | No | Brief MET | Face-to-face | 1 | 1 | Minimal intervention | 12
McCambridge, 2008^107^; U.K.; N=326; Fair | Adolescent/ Young Adult; Cannabis | No | Brief MET | Face-to-face | 1 | ≤1 | Minimal intervention | 6
Ondersma, 2007^56^; U.S.; N=107; Fair | Adult (Postpartum women); Multiple drugs (% opioids NR) | Yes | Brief MET + CBT | Computer | 1 | 20 minutes | Minimal intervention | 4
Ondersma, 2014 ^58^; U.S.; N=143; Fair | Adult (Postpartum women); Multiple drugs (% opioids NR) | Yes | Brief MET + CBT | Computer | 1 | 20 minutes | Minimal intervention | 6
Ondersma, 2018^57^; U.S.; N=500; Fair | Adult (Postpartum women); Multiple drugs (% opioids NR) | Yes | Brief MET + CBT | Computer | 1 | 20 minutes | Minimal intervention | 6
Palfai, 2014^59^; U.S.; N=123; Fair | Young Adult; Cannabis | Yes | Brief MI | Computer | 1 | NR | Minimal intervention | 6
Poblete, 2017^60^; Chile; N=806; Fair | Young Adult; Multiple drugs (% opioids NR) | Yes^*^ | Brief MI | Face-to-face | 1 | NR | Minimal intervention | 3
Rooke, 2013^109^; Australia; N=230; Fair | Adult; Cannabis | No | CBT + MI | Computer | 6 | NR | Minimal intervention | 3
Roy-Byrne, 2014^61^ and Krupski, 2012^118^; U.S.; N=868; Good | Adult; Multiple drugs (26% opioids use in last 30 days) | Yes^*^ | Brief MI | Face-to-face | 1 + 1 telephone booster | 0.5 | Minimal intervention | 12
Saitz, 2014^62^, Fuster, 2016^116^ and Kim, 2016^117^; U.S.; N=528; Good | Adult; Multiple drugs (18% opioids; includes prescription opioids) | Yes^*^ | A. Brief MI; B. Brief MI + telephone booster | Face-to-face | A. 1; B. 1 | A. 15 minutes; B. 30-45 minutes + 20-30 minute telephone booster | Minimal intervention | 6
Schaub, 2015 ^110^; Germany; N=308; Fair | Young Adult/ Adult; Cannabis | No | A. CBT + MI + online chat; B. CBT + MI | Computer | A. 8; B. 8 | A. NR; online chat 20-30 minutes; B. NR | Waitlist | 3
Stein, 2009^111^; U.S.; N=198; Fair | Adult; Stimulants | No | MI | Face-to-face | 4 | 20-40 minutes | Minimal intervention | 6
Stein, 2011^63^; U.S.; N=332; Fair | Young Adult; Cannabis | Yes | Brief MI | Face-to-face | 2 | 45 minutes | Minimal intervention | 6
Stephens, 2000^33^; U.S.; N=291; Fair | Adult; Cannabis | No | A. CBT + social support; B. MI | Face-to-face | A. 14; B. 2 | A. 2; B. 1.5 | Waitlist | 4
Stephens, 2007^112^; U.S.; N=188; Good | Adult; Cannabis | No | Brief MI (review of personal feedback report) | Face-to-face | 1 | 1.5 | Minimal intervention | 12
Tait, 2015^113^; Australia; N=160; Fair | Young Adult; Stimulants | No | MET + CBT | Computer | 3 | NR | Waitlist | 6
Tzilos Wernette, 2018^64^; U.S.; N=50; Fair | Adult (Pregnant women); Cannabis/ alcohol | Yes | Brief MI | Computer | 1 + 1 booster | 1 | Minimal intervention | 4
Walton, 2013^65^; U.S.; N=328; Fair | Adolescent; Cannabis | Yes | A. Brief MI (computer); B. Brief MI (in person) | A. Computer; B. Face-to-face | A. 1; B. 1 | A. NR; B. NR | Usual care | 12
Watkins, 2017^66^; U.S.; N=397; Fair | Adult; Multiple drugs (20% heroin; 10% prescription opioids) | Yes | Multicomponent (collaborative care) | Face-to-face | NA | NA | Usual care | 6
Woolard, 2013 ^67^; U.S.; N=515; Fair | Adult; Opioids/alcohol; Cannabis | Yes | Brief MI | Face-to-face | NR | NR | Usual care | 12
Yonkers, 2012^68^; U.S.; N=183; Fair | Adult (Pregnant women); Multiple drugs (% primary opioid use NR; 11% opioid use in past month) | Yes | MET + CBT | Computer | 6 | 0.5 | Minimal intervention | 3
Zahradnik, 2009^69^ and Otto, 2009^120^; Germany; N=126; Fair | Adult; Multiple drugs (% opioids NR) | Yes | Brief MI | Face-to-face | 2 | 0.5 | Minimal intervention | 12

* Study conducted in primary care setting.

Abbreviations: CBT = cognitive behavioral therapy; MET = motivational enhancement therapy; MI = motivational interviewing; NR = not reported; U.K. = United Kingdom; U.S. = United States.

Twenty-seven trials enrolled patients who were not seeking treatment for substance use, but were identified through screening for unhealthy drug use (additional details available in the USPSTF screening review^1^; also see Appendixes B9, B10, and B11).^4,44–69^ One of these trials^4^ was included in the 2008 USPSTF review.^2^ None of the trials of screen-detected populations required patients to meet DSM criteria for substance dependence, abuse, or use disorder at baseline, but used thresholds to define unhealthy drug use (e.g. use of drugs within a specific time frame, ASSIST score ≥4, or Drug Abuse Screening Test [DAST]-10 score ≥3; Appendixes B9 and B10).

Twenty-five trials (in 30 publications) were conducted in persons engaging in drug use who were not identified through screening in primary care settings (Table 4, Appendixes B9, B10, and B11).^30–33,88–90,92–113,121^ Three of these trials^31–33^ were included in the 2008 USPSTF review.^2^ In these trials, patients were seeking substance use treatment or recruited based on known substance use (“treatment-seeking”). In 17 trials, patients were primarily recruited through advertisements for study participation. In the other nine trials, patients were directly recruited in target settings; referred by peers, clinician, family members, or social workers/counselors; or recruited from callers to a cannabis help line. Of the 25 trials, five required patients to meet DSM-IV criteria for substance abuse or dependence.^30,100–103^ The severity of substance use at baseline varied. For example, among trials of persons using cannabis, mean scores on the SDS (range 0 to 15; higher scores indicate higher level of dependence) ranged from 4.1^107^ to 9.8^31^ and mean scores on the MPS (range 0 to 38; higher scores indicate higher level of dependence) ranged from 3.7^59^ to 9.5.^30^

Across all trials, sample sizes ranged from 34 to 1,175 (total N=15,659.) The duration of followup was 3 to 4 months after the start of interventions in 18 trials,^30,33,441,48–51,56,60,64,68,93,94,99,103,104,106,109,110^ 6 to 9 months in 21 trials,^4,31,52,54,55,57–59,62,63,66,88,90,96,100,102,105,107,111,113^ and ≥12 months in 13 trials.^32,44–46,61,65,67,69,95,98,101,112,115^ Thirty-five trials^4,30,33,44,46,48–50,52–59,61–68,95,100–104,111,112,115^ were conducted in the United States, seven trials in Europe,^69,94,96,105,107,108,110^ and 10 trials in other countries.^31,51,60,88,90,97,99,106,109,113^

The primary substance used was cannabis in 29 trials,^30,31,33,44–46,53,55,59,63–65,93–96,98,99,101–104,106–110,112^ stimulants in six trials,^4,88,90,105,111,113^ opioids in two trials,^67,100^ and mixed or multiple drugs in 15 trials.^48–51,54,56–58,60–62,66,68,69,115^ Among the trials reporting mixed or multiple drug use at baseline, the proportion of patients that reported opioid use ranged from 5 to 26 percent. Five trials evaluated adolescents,^44,55,65,95,96,106^ eight trials evaluated young adults (18 to 25 years of age),^52,59,60,63,93,94,98,113^ and six trials evaluated mixed populations of adolescents or young adults.^32,45,53,105,107,108^ Thirty-two trials evaluated adults or mixed populations of adults and adolescents,^4,30,31,33,46–50,54,56–58,61,62,64,66–69,88,90,99–104,109–112^ including three trials of postpartum females^56–58^ and two trials^64,68^ of pregnant females. All trials of postpartum and pregnant females were conducted in screen-detected populations; they are discussed in more detail in the USPSTF screening report and not presented separately in this report.^1^ Among the psychosocial intervention trials that did not focus on pregnant or postpartum females, three only enrolled females;^54,63,93^ in the other trials the proportion of females ranged from 13 to 71 percent (median 34%).

Thirty-seven trials evaluated brief psychosocial interventions, defined here as one or two sessions, each ≤60 minutes in duration.^4,30,44–65,67,69,88,90,93,95,97,103,105–108,112^ The most commonly used techniques in the brief intervention trials utilized motivational interventions (e.g., MET or MI) or CBT. Nineteen trials evaluated more intensive (non-brief) psychosocial interventions; in these, the number of sessions ranged from two to 14, aside from one trial^100^ that utilized 57 sessions.^30,31,33,66,68,88,90,94,96,99–104,109–111,113^ The most commonly used techniques in the intensive psychosocial interventions trials were motivational interventions and CBT; some trials used contingency management.

The mode of delivery for psychosocial interventions was face-to-face in 37 trials^4,30,31,33,44,45,48,49,51,53,55,60–63,66,67,69,88,90,93–96,98,100–108,111,112,115^ and by computer, Internet, or telephone in 12 trials;^50,53,56–59,64,68,99,109,110,113^ three trials used multiple modes of delivery.^46,54,65^ The intervention was delivered by someone with graduate level education in 65 percent of the studies; 15 percent of studies utilized research staff without graduate level education or mixed educational levels, one study was delivered by substance treatment outreach workers who were in recovery,^4^ and 17 percent of studies were solely computer-based. The control intervention consisted of a minimal intervention in 30 trials,^4,44,48,49,52,53,55–64,68,69,88,90,93,94,98,105,107–109,111,112,115^ waitlist in 11 trials,^30,31,33,50,51,99,103,104,106,110,113^ and usual care in 11 trials.^45,46,54,65–67,95,96,100–102^ Minimal intervention controls typically consisted of brief education without a defined psychological intervention. In some trials, usual care could have included referral to drug treatment, though trials in which patients assigned to usual care were routinely referred for drug treatment were excluded (see Methods).

Eight trials^30,46,54,61,62,94,105,112^ were rated good quality and the remainder were rated fair quality (Appendix B12). Methodological limitations in the fair quality trials included high attrition, failure to blind or unclear blinding of outcome assessors, and unclear randomization methods. Attrition was generally high; at three to four months attrition ranged from two to 67 percent and at six to 12 months attrition ranged from two to 46 percent. Blinding of patients and care providers to receipt of psychosocial interventions was not feasible given the nature of the interventions. Commonly reported drug use outcomes were changes in days of drug use (in the last 90 days, 30 days, or week), various measures of drug use severity (e.g., the ASSIST score, the SDS, the MPS, the Rutgers Alcohol Problems Index [RAPI; adapted for cannabis use], and others), and rates of drug use abstinence (based on self-report, urine testing, and/or hair sample testing). All studies assessed drug use frequency based on patient self-report using standardized questionnaires. Nineteen studies reported use of timeline followback methods (a method which uses a calendar and memory aids to prompt recall)^122^ and one study^33^ reported use of collaterals (family members, friends) to verify self-report. Thirteen studies reported use of urine testing to detect drug use in all or a sample of patients, three studies reported use of hair samples,^57,58,62^ and one study reported use of saliva testing.^105^

##### Detailed Results: Drug Use and Other Risky Behaviors

Abstinence. Psychosocial interventions were associated with increased likelihood of abstinence from drug use at 3 to 4 months (15 trials; RR 1.60, 95% CI 1.24 to 2.13, I^2^=61%; ARD 9%, 95% CI 5% to 15%; Figure 6)^30,33,47,49,56,58,64,68,69,99,107–110^ and at 6 to 12 months (14 trials; RR 1.25, 95% CI 1.11 to 1.52, I^2^=38%; ARD 6%, 95% CI 2% to 10%; Figure 7)^4,31,45,47,57,58,62,69,88–90,92,105,107,108,113^ versus controls (waitlist, minimal intervention, or usual care). Stratified according to the primary type of drug of use, estimates favored psychosocial interventions for abstinence from cannabis use (7 trials; RR 2.08, 95% CI 1.51 to 3.07 at 3 to 4 months; I^2^=28%^30,33,99,107–110^ and 4 trials, RR 1.58, 95% CI 1.17 to 3.06 at 6 to 12 months, I^2^=36%).^31,45,107,108^ Effects on stimulant use (4 trials, RR 1.45, 95% CI 0.86 to 2.56 at 6 to 12 months, I^2^=65%),^88–90,105,113^ and mixed drug use (7 trials, RR 1.24, 95% CI 0.92 to 1.80 at 3 to 4 months, I^2^=60%^47,49,56–58,64,68^ and 5 trials, RR 1.12, 95% CI 0.92 to 1.36 at 6 to 12 months, I^2^=0%) were not statistically significant. There was a statistically significant interaction between type of drug use and effects of psychosocial interventions on abstinence at 3 to 4 months (p for interaction=0.10) but not at 6 to 12 months (p for interaction=0.43) (Table 5). Only one trial evaluated effects of a psychosocial intervention on prescription drug use (type of prescription drug use not specified); estimates were imprecise (RR 2.08, 95% CI 0.81 to 5.38 at 3 to 4 months, and RR 1.25, 95% CI 0.65 to 2.40 at 12 months).^69^ One trial of patients with opioid (heroin) use (n=126) found contingency management associated with increased likelihood of opioid abstinence versus usual care (OR 2.15, 95% CI 1.16 to 4.00), but could not be pooled because the number of patients evaluated in each group for this outcome was not reported.^100^ In all of the trials of cannabis and stimulant use, abstinence was based on self-report. All trials of mixed drug use utilized hair or urine testing to assess abstinence, except for one trial that evaluated 6 sessions of MET plus CBT in pregnant women (RR 0.95, 95% CI 0.59 to 1.55).^68^

Table 5 Psychosocial Intervention Trials—Abstinence at 3 to 4 Months or 6 to 12 Months

Timing; Study Characteristics | Group analyzed | Number of trials | Relative risk (95% Confidence interval) | I^2^
3-4 months, all trials | All participants | 15 | 1.60 (1.24 to 2.13) | 61%
Type of drug use; p for interaction=0.10 | Cannabis | 7 | 2.08 (1.51 to 3.07) | 28%
Type of drug use; p for interaction=0.10 | Mixed drugs | 7 | 1.24 (0.92 to 1.80) | 60%
Type of drug use; p for interaction=0.10 | Prescription drugs | 1 | 2.08 (0.81 to 5.38) | --
Population; p for interaction=0.05 | Screen-detected population | 8 | 1.28 (0.97 to 1.84) | 57%
Population; p for interaction=0.05 | Treatment-seeking population | 7 | 2.08 (1.51 to 3.07) | 28%
Type of intervention p for interaction=0.34 | Brief interventions | 10 | 1.46 (1.11 to 2.09) | 56%
Type of intervention p for interaction=0.34 | Other (non-brief) interventions | 6 | 2.01 (1.17 to 3.58) | 70%
Age group; p for interaction=0.77 | Adolescent/young adult | 2 | 1.54 (0.78 to 5.22) | 61%
Age group; p for interaction=0.77 | Adult | 13 | 1.58 (1.20 to 2.16) | 64%
Pregnancy (adult only) | Pregnant or postpartum | 5 | 1.24 (0.99 to 1.89) | 41%
Pregnancy (adult only) | Not pregnant or postpartum | 8 | 1.77 (1.17 to 2.80) | 71%
Mode of delivery; p for interaction=0.61 | Face-to-face | 7 | 1.77 (1.13 to 3.02) | 76%
Mode of delivery; p for interaction=0.61 | Other (web, computer, telephone) | 8 | 1.43 (1.10 to 2.04) | 35%
Study quality; p for interaction=0.10 | Good quality | 1 | 4.34 (1.75 to 10.72) | --
Study quality; p for interaction=0.10 | Fair quality | 14 | 1.50 (1.18 to 1.98) | 56%
6-12 months, all trials | All participants | 14 | 1.25 (1.11 to 1.52) | 38%
Type of drug use; p for interaction=0.43 | Cannabis | 4 | 1.58 (1.17 to 3.06) | 36%
Type of drug use; p for interaction=0.43 | Stimulants | 4 | 1.45 (0.86 to 2.56) | 65%
Type of drug use; p for interaction=0.43 | Mixed drugs | 5 | 1.12 (0.92 to 1.36) | 0%
Type of drug use; p for interaction=0.43 | Prescription drugs | 1 | 1.25 (0.65 to 2.40) | --
Population; p for interaction=0.26 | Screen-detected population | 7 | 1.17 (0.99 to 1.41) | 2%
Population; p for interaction=0.26 | Treatment-seeking population | 7 | 1.51 (1.14 to 2.37) | 57%
Type of intervention p for interaction=0.22 | Brief interventions | 11 | 1.22 (1.08 to 1.42) | 14%
Type of intervention p for interaction=0.22 | Other (non-brief) interventions | 3 | 1.99 (0.55 to 7.80) | 71%
Age group; p for interaction=0.52 | Adolescent/young adult | 5 | 1.25 (1.04 to 1.64) | 14%
Age group; p for interaction=0.52 | Adult | 9 | 1.30 (1.05 to 1.80) | 51%
Postpartum status (adult only) | Postpartum | 2 | 1.07 (0.76 to 1.71) | 0%
Postpartum status (adult only) | Not postpartum | 7 | 1.41 (1.04 to 2.16) | 57%
Mode of delivery; p for interaction=0.23 | Face-to-face | 11 | 1.31 (1.13 to 1.69) | 43%
Mode of delivery; p for interaction=0.23 | Other (web, computer, telephone) | 3 | 1.04 (0.73 to 1.45) | 0%
Study quality; p for interaction=0.21 | Good quality | 2 | 1.11 (0.58 to 1.51) | 58%
Study quality; p for interaction=0.21 | Fair quality | 12 | 1.35 (1.15 to 1.73) | 35%

Effects of psychosocial interventions on likelihood of drug use abstinence at 3 to 4 months were stronger in trials of treatment-seeking populations (7 trials, RR 2.08, 95% CI 1.51 to 3.07, I^2^=28%)^30,33,99,107–110^ than trials of screen-detected populations (8 trials, RR 1.28, 95% CI 0.97 to 1.84, I^2^=57%; p for interaction=0.05) (Figure 8).^47,49,56–58,64,68,69^ Of the screen-detected trials, all except for one^69^ enrolled persons with mixed drug use and five trials^56–58,64,68^ enrolled pregnant or postpartum women. At 6 to 12 months, effects on likelihood of abstinence were weaker in trials of screen-detected (7 trials, RR 1.17, 95% CI 0.99 to 1.41, I^2^=2%)^4,45,47,57,58,62,69^ compared with treatment-seeking (7 trials, RR 1.51, 95% CI 1.14 to 2.37, I^2^=57%)^31,88–90,92,105,107,108,113^ populations (Figure 14), but the interaction was not statistically significant (p for interaction=0.26). None of the trials of screen-detected populations at 6 to 12 months evaluated pregnant women and two enrolled postpartum women;^57,58^ five of the seven trials enrolled persons with mixed drug use.

Figure 14 Psychosocial Interventions vs. Control Conditions—Abstinence at 6- to 12-Month Followup, Stratified by Population

Abbreviations: Adol = adolescent; Adul = adult; CI = confidence interval; Comp = computer; FTF = face-to-face; MI = minimal intervention; Pp = postpartum; RR = relative risk; UC = usual care; WL = waitlist; YAdult = young adult.

Figure 14 is a forest plot examining abstinence at 6- to 12-month followup comparing psychosocial interventions versus control conditions with two subgroups. The relative risk for 7 studies in the treatment seeking subgroup is 1.51 (95% confidence interval 1.14 to 2.37) with an I-squared value of 57.0%. The relative risk for the 7 studies in the screen detected subgroup is 1.17 (95% confidence interval 0.99 to 1.41), with an I-squared value of 2.2%. The overall relative risk is 1.25 (95% confidence interval 1.11 to 1.52) with an I-squared value of 38.3%.

Effects of psychosocial interventions on abstinence were somewhat stronger in trials of intensive compared with brief interventions and in trials that used face-to-face versus other (web, computer, or telephone) delivery methods, but the differences were not statistically significant (Table 5). No trial reporting abstinence enrolled only adolescents and there were no statistically significant differences between trials that enrolled adults >25 years of age and those that enrolled adolescents and young adults (up to 25 years of age) (Table 5).

At 3 to 4 months, five trials reporting effects of psychosocial interventions on drug use abstinence enrolled pregnant or postpartum females (RR 1.24, 95% CI 0.99 to 1.89, I^2^=41%)^56–58,64,68^ and at 6 to 12 months two trials enrolled postpartum females (RR 1.07, 95% CI 0.76 to 1.71, I^2^=0%).^57,58^ Restricting the analysis to trials of adults who were not pregnant or postpartum resulted in pooled estimates for drug use abstinence that were similar to the overall estimates at 3 to 4 months (8 trials, RR 1.77, 95% CI 1.17 to 2.80, I^2^=71%) and at 6 to 12 months (7 trials, RR 1.41, 95% CI 1.04 to 2.16, I^2^=57%). No trial that enrolled men and women reported effects on abstinence stratified by sex. There was no statistically significant interaction between study quality and effects of psychosocial interventions on drug use abstinence, but only three trials were rated good quality, limiting the usefulness of this stratified analysis (Table 5).^30,62,105^

Drug Use Days. Twenty trials reported effects of psychosocial interventions on frequency of drug use based on the number of drug use days. Standardized to drug use in the past 7 days, effects of psychosocial interventions versus controls at 3 to 4 months after the start of the intervention ranged from a decrease of −2.30 days to an increase of 0.26 day. When the data were pooled, psychosocial interventions were associated with decreased number of drug use days versus controls at 3 to 4 months (19 trials, mean difference −0.49 day, 95% CI −0.85 to −0.13), but statistical heterogeneity was high (I^2^=89%) (Figure 9).^30,33,45–47,52–54,59,61,67,93,94,97–99,106,107,109,110^

In stratified analyses (Table 6), effects of psychosocial interventions on drug use days at 3 to 4 months were present in trials of treatment-seeking populations (10 trials, mean difference −0.91 day, 95% CI −1.52 to −0.31, I^2^=86%)^30,33,93,94,97–99,106,107,109,110^ but not in trials of screen-detected populations (9 trials, mean difference −0.10 day, 95% CI −0.31 to 0.12, I^2^=46%;^45–47,52–54,59,61,67^ p for interaction=0.02) (Figure 11). Effects on drug use days were also present in trials of intensive interventions (10 trials, mean difference −0.88 day, 95% CI −1.50 to −0.28, I^2^=91%)^30,33,45,47,61,67,93,94,99,106,109,110^ but not in trials of brief interventions (9 trials, mean difference −0.13 day, 95% CI −0.36 to 0.12, I^2^=42%;^46,52–54,59,97,98,107^ p for interaction=0.03). Effects were also present in trials that evaluated cannabis use (14 trials, mean difference −0.68 day, 95% CI −1.14 to −0.23, I^2^=89%)^30,33,45,52,53,59,67,93,94,97–99,106,107,109^ but not in trials that evaluated “any drug use” (5 trials, mean difference −0.05 day, 95% CI −0.39 to 0.31, I^2^=58%),^46,47,54,61,110^ though the interaction between drug use type and effects on drug use days was not statistically significant (p=0.11) (Figure 9). All trials that reported any drug use except for one^110^ were conducted in screen-detected populations. No trial evaluated effects of psychosocial interventions on opioid use days.

Table 6 Psychosocial Intervention Trials—Drug Use Days at 3 to 4 Months or 6 to 12 Months

Timing; Study Characteristics | Group analyzed | Number of trials | Mean difference (95% confidence interval) | I^2^
3-4 months all trials | All participants | 19 | −0.49 (−0.85 to −0.13) | 89%
Type of drug use; p for interaction=0.11 | Cannabis | 14 | −0.68 (−1.14 to −0.23) | 89%
Type of drug use; p for interaction=0.11 | Any drug use | 5 | −0.05 (−0.39 to 0.31) | 58%
Population; p for interaction=0.02 | Screen-detected population | 9 | −0.10 (−0.31 to 0.12) | 46%
Population; p for interaction=0.02 | Treatment-seeking population | 10 | −0.91 (−1.52 to −0.31) | 86%
Type of intervention; p for interaction=0.03 | Brief interventions | 9 | −0.13 (−0.36 to 0.12) | 42%
Type of intervention; p for interaction=0.03 | Other (more intensive) interventions | 10 | −0.88 (−1.50 to −0.28) | 91%
Age group; p for interaction=0.38 | Adolescent | 1 | −1.47 (−2.99 to 0.06) | -
Age group; p for interaction=0.38 | Young adult or adolescent/young adult | 8 | −0.15 (−0.37 to 0.03) | 0%
Age group; p for interaction=0.38 | Adult | 10 | −0.63 (−1.22 to −0.03) | 93%
Mode of delivery; p for interaction=0.66 | Face-to-face | 14 | −0.54 (−1.01 to −0.08) | 90%
Mode of delivery; p for interaction=0.66 | Other (web, computer, telephone) | 5 | −0.27 (−0.82 to 0.13) | 49%
Study quality; p for interaction=0.82 | Good quality | 5 | −0.42 (−1.30 to 0.48) | 93%
Study quality; p for interaction=0.82 | Fair quality | 14 | −0.51 (−0.93 to −0.11) | 86%
6-12 months, all trials | All participants | 15 | −0.08 (−0.30 to 0.11) | 45%
Type of drug use; p for interaction=0.42 | Cannabis | 7 | −0.21 (−0.65 to 0.16) | 41%
Type of drug use; p for interaction=0.42 | Stimulants | 1 | −0.47 (−1.17 to 0.24) | --
Type of drug use; p for interaction=0.42 | Any drug use | 7 | 0.04 (−0.22 to 0.28) | 43%
Population; p for interaction=0.22 | Screen-detected population | 10 | 0.00 (−0.24 to 0.22) | 42%
Population; p for interaction=0.22 | Treatment-seeking population | 5 | −0.29 (−0.69 to 0.09) | 12%
Type of intervention; p for interaction=0.90 | Brief interventions | 11 | −0.06 (−0.24 to 0.11) | 0%
Type of intervention; p for interaction=0.90 | Other (more intensive) interventions | 4 | −0.16 (−0.88 to 0.46) | 79%
Age group; p for interaction=0.80 | Young adult or adolescent/young adult | 7 | −0.09 (−0.34 to 0.12) | 0%
Age group; p for interaction=0.80 | Adult | 8 | −0.07 (−0.40 to 0.22) | 66%
Mode of delivery; p for interaction=0.80 | Face-to-face | 13 | −0.10 (−0.36 to 0.12) | 53%
Mode of delivery; p for interaction=0.80 | Other (web, computer, telephone) | 2 | −0.05 (−0.42 to 0.38) | 0%
Study quality; p for interaction=0.70 | Good quality | 6 | −0.12 (−0.46 to 0.16) | 36%
Study quality; p for interaction=0.70 | Fair quality | 9 | −0.04 (−0.38 to 0.23) | 45%

Note: Drug use days standardized to drug use in the past 7 days.

When trials were stratified according to age, effects of psychosocial interventions on drug use days were greater in trials of adults (10 trials, mean difference −0.63, 95% CI −1.22 to −0.03, I^2^=93%)^30,33,46,47,54,61,67,99,109,110^ than trials of young adults (8 trials, mean difference −0.15, 95% CI −0.37 to 0.03; I^2^=0%).^45,52,53,59,93,94,97,98^ One trial evaluated adolescents^106^ and one of the young adult trials also enrolled adolescents,^107^ each showing no statistically significant effect. There was no statistically significant interaction between age group and effects on drug use days (p=0.38). None of the trials that reported effects on drug use days enrolled pregnant or postpartum persons.

Effects of psychosocial interventions on drug use days at 6 to 12 months versus controls were smaller than at 3 to 4 months and not statistically significant (15 trials, mean difference −0.08, 95% CI −0.30 to 0.11, I^2^=45%) (Figure 10).^45–47,52–54,59,61,62,67,97,98,105,107,111,112^ Differences ranged from a decrease of −1.37 days to an increase of 0.51 days. There were also no statistically significant effects on drug use days at 6 months in subgroup analyses based on whether the population was screen-detected (Figure 15), type of drug use (cannabis, stimulants, or any drug), age group, whether the intervention was brief, or whether the intervention included a face-to-face component. Estimates were similar for good and fair quality trials at 3 to 4 months and at 6 to 12 months (Table 6).

Figure 15 Psychosocial Interventions vs. Control Conditions—Drug Use Days, Standardized to Drug Use in the Past 7 Days, at 6- to 12-Month Followup, Stratified by Population

Abbreviations: AC = active control; CG = control group; CI = confidence interval; Comp = computer; FTF = face-to-face; IG = intervention group; Min = minimal intervention; SD = standard deviation; UC=usual care; YAdult = young adult.

Figure 15 is a forest plot examining drug use days, standardized to drug use in past 7 days, at 6- to 12-month followup comparing psychosocial interventions versus control conditions with two subgroups. The difference in change for 5 studies in the not screen-detected subgroup is −0.29 (95% confidence interval −0.69 to 0.09) with an I-squared value of 12.5%. The difference in change for the 10 studies in the screen-detected subgroup is 0.00 (95% confidence interval −0.24 to 0.22), with an I-squared value of 42.0%. The overall difference in change is −0.08 (95% confidence interval −0.30 to 0.11) with an I-squared value of 45.3%.

Thirteen trials reported drug use outcomes that could not be pooled.^48,50,55,63,66,95,96,100–104,119^ As in the pooled analyses on drug use outcomes, findings from these trials were inconsistent. Four trials that could not be pooled reported less drug use in the intervention group;^48,95,100,103^ the remaining trials found no differences between groups. None of the trials reported effects of psychosocial interventions on drug use days enrolled pregnant or postpartum women and no trial stratified effects on drug use days by sex.

##### Detailed Results: Health, Social, and Legal Outcomes

Twenty-two trials reported effects of psychosocial interventions on severity or consequences of drug use, measured using a variety of drug use severity scales (e.g., MPS, DSM-IV Cannabis Problem Scale, the SDS, or the ASSIST scale).^30,31,33,44,51–53,58–62,65,67,92,94,99,106,107,109,110,112,113^ At 3 to 4 months, the effects of psychosocial interventions versus controls (minimal intervention, waitlist, or usual care) on measures of drug use severity ranged from an improvement in the standardized mean difference of −1.00 to a worsening of 0.14. When data were pooled, psychosocial interventions were associated with a small but statistically significant effect on drug use severity (17 trials, SMD −0.18, 95% CI −0.32 to −0.05),^30,33,44,52,53,59,65,94,99,106,107,109,110^ but statistical heterogeneity was high (I^2^=73%) (Figure 12). In stratified analyses, psychosocial interventions were associated with a statistically significant effect on drug use severity in persons primarily using cannabis (13 trials, SMD −0.21, 95% CI −0.39 to −0.04, I^2^=78%)^44,94,99,107,109,110^ but not in persons with mixed substance use (4 trials, SMD −0.05, 95% CI −0.20 to 0.05, I^2^=1.3%);^51,58,60,67^ however, there was no statistically significant interaction (p for interaction=0.45). Similarly, effects were somewhat stronger in trials of treatment-seeking populations (8 trials, SMD −0.30, 95% CI −0.57 to −0.03, I^2^=82%)^30,33,94,99,106,107,109,110^ than in trials of screen-detected populations (9 trials, SMD −0.05, 95% CI −0.15 to 0.05, I^2^=17%),^44,51–53,58–60,65,67^ but there was no statistically significant interaction (p for interaction=0.12) (Figure 16). Effects were also somewhat stronger in trials of intensive interventions (6 trials; SMD −0.32, 95% CI −0.70 to 0.06, I^2^=89%)^30,33,94,99,109,110^ than in trials of brief interventions (12 trials; SMD −0.09, 95% CI −0.20 to −0.002, I^2^=36%; p for interaction=0.18)^30,44,51–53,58–60,65,67,106,107^ and in trials that included adults (8 trials, SMD −0.31, 95% CI −0.57 to −0.07, I^2^=82%)^30,33,51,58,67,99,109,110^ than in trials of young adults with or without adolescents (6 trials, SMD −0.01, 95% CI −0.15 to 0.08, I^2^=22%)^52,53,59,60,94,107^ or trials of only adolescents (3 trials, SMD −0.08, 95% CI −0.26 to 0.10, I^2^=0%; p for interaction=0.20).^44,65,106^ Among the trials that included adults (including young adults), estimates were similar when one trial of postpartum women (SMD −0.29, 95% CI −0.67 to 0.10)^58^ was excluded (13 trials, SMD −0.19, 95% CI −0.37 to −0.03, I^2^=79%). There were no subgroup differences based on mode of delivery (face-to-face or non-face-to-face), or study quality (good or fair) (Table 7). In five trials that reported cannabis use severity using the SDS (scale 0 to 15; higher scores indicate higher level of dependence), the mean difference between psychosocial interventions versus control conditions was less than 1 point (−0.66, 95% CI −1.39 to 0.07, I^2^=62%).

Figure 16 Psychosocial Interventions vs. Control Conditions—Drug Use Severity at 3- to 4-Month Followup, Stratified by Population

Abbreviations: Adul = adult; Adol = adolescent; ASSIST = Alcohol, Smoking, and Substance Involvement Screening Test; CI = confidence interval; Comp = computer; DSM-IV CPS = Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Compendium of Pharmaceuticals and Specialties; FTF = face-to-face; MA = marijuana subscale; MDS = Marijuana Dependence Scale; MNC = marijuana negative consequences; MPS = Marijuana Problem Scale; NIP = Noteworthy Index of Problems; NR = not reported; PAdul = postpartum adult; RAPI = Rutgers Alcohol Problems Index; RMPI = Rutgers Marijuana Problem Index; SD = standard deviation; SDS = Severity of Dependence Scale; SMD = standardized mean difference; Tel = telephone; TO = total (scale); YAdul = young adult.

Figure 16 is a forest plot examining drug use severity at 3- to 4-month followup comparing psychosocial interventions versus control conditions with two subgroups. The difference in change for the 8 studies in the non-screen-detected subgroup is −0.30 (95% confidence interval −0.57 to −0.03), with an I-squared value of 82.3%. The difference in change for the 9 studies in the screen-detected subgroup is −0.05 (95% confidence interval −0.15 to 0.05), with an I-squared value of 16.6%. The overall difference in change is −0.18 (95% confidence interval −0.32 to −0.05) with an I-squared value of 73.2%.

Table 7 Psychosocial Intervention Trials—Drug Use Severity at 3 to 4 Months or 6 to 12 Months

Timing; Study Characteristics | Group analyzed | Number of trials | Standardized mean difference (95% confidence interval) | I^2^
3-4 month followup, all trials | All participants | 17 | −0.18 (−0.32 to −0.05) | 73%
Type of drug use; p for interaction=0.45 | Cannabis use | 13 | −0.21 (−0.39 to −0.04) | 78%
Type of drug use; p for interaction=0.45 | Mixed substance use | 4 | −0.05 (−0.20 to 0.05) | 1.3%
Population; p for interaction=0.12 | Screen-detected population | 9 | −0.05 (−0.15 to 0.05) | 17%
Population; p for interaction=0.12 | Treatment-seeking population | 8 | −0.30 (−0.57 to −0.03) | 82%
Type of intervention; p for interaction=0.18 | Brief interventions | 12 | −0.09 (−0.20 to −0.002) | 36%
Type of intervention; p for interaction=0.18 | Other (non-brief) interventions | 6 | −0.32 (−0.70 to 0.06) | 89%
Age group; p for interaction=0.20 | Adolescent | 3 | −0.08 (−0.26 to 0.10) | 0%
Age group; p for interaction=0.20 | Young adult | 6 | −0.01 (−0.15 to 0.08) | 22%
Age group; p for interaction=0.20 | Adult | 8 | −0.31 (−0.57 to −0.07) | 82%
Mode of delivery; p for interaction=0.66 | Face-to-face | 11 | −0.15 (−0.33 to 0.02) | 77%
Mode of delivery; p for interaction=0.66 | Other (web, computer, telephone) | 7 | −0.20 (−0.42 to −0.01) | 64%
Study quality; p for interaction=0.64 | Good quality | 2 | −0.11 (−0.32 to 0.13) | 0%
Study quality; p for interaction=0.64 | Fair quality | 15 | −0.19 (−0.35 to −0.04) | 76%
6-12 month followup, all trials | All participants | 13 | −0.10 (−0.24 to 0.02) | 65%
Type of drug use; p for interaction=0.57 | Amphetamine use | 1 | 0.10 (−0.35 to 0.54) | --
Type of drug use; p for interaction=0.57 | Cannabis use | 8 | −0.16 (−0.37 to 0.03) | 72%
Type of drug use; p for interaction=0.57 | Mixed substance use | 4 | −0.001 (−0.18 to 0.12) | 42%
Population; p for interaction=0.27 | Screen-detected population | 9 | −0.03 (−0.15 to 0.06) | 40%
Population; p for interaction=0.27 | Treatment-seeking population | 4 | −0.23 (−0.62 to 0.17) | 82%
Type of intervention p for interaction=0.03 | Brief interventions | 10 | −0.02 (−0.13 to 0.06) | 35%
Type of intervention p for interaction=0.03 | Other (non-brief) interventions | 3 | −0.36 (−0.80 to 0.14) | 71%
Age group; p for interaction=0.56 | Adolescent | 2 | −0.10 (−0.37 to 0.18) | 44%
Age group; p for interaction=0.56 | Young adult | 5 | 0.02 (−0.16 to 0.15) | 26%
Age group; p for interaction=0.56 | Adult | 6 | −0.18 (−0.44 to 0.04) | 80%
Mode of delivery; p for interaction=0.63 | Face-to-face | 9 | −0.11 (−0.28 to 0.03) | 70%
Mode of delivery; p for interaction=0.63 | Other (web, computer, telephone) | 5 | −0.03 (−0.28 to 0.16) | 44%
Study quality; p for interaction=0.69 | Good-quality | 3 | −0.02 (−0.41 to 0.22) | 72%
Study quality; p for interaction=0.69 | Fair quality | 10 | −0.12 (−0.27 to 0.03) | 62%

At 6 to 12 months, the effects of psychosocial interventions on measures of drug use severity versus control conditions ranged from an improvement in the SMD of −0.61 to a worsening of 0.11. When data were pooled, there was no difference between psychosocial interventions versus control conditions in drug use severity (13 trials, SMD −0.10, 95% CI −0.24 to 0.02, I^2^=65%)^31,44,52,53,58,59,61,62,65,67,92,107,112,113^ (Figure 13). There were also no statistically significant differences when trials were stratified according to whether the main drug of use was amphetamines (1 trial, SMD 0.10, 95% CI −0.35 to 0.54),^113^ cannabis (8 trials, SMD −0.16, 95% CI −0.37 to 0.03, I^2^=72%),^31,44,52,53,59,65,92,107,112^ or mixed drugs (4 trials, SMD −0.001, 95% CI −0.18 to 0.12, I^2^=42%).^58,61,62,67^ No study evaluated effects of psychosocial interventions on opioid drug use severity.

Psychological interventions also were not associated with statistically significant effects on drug use severity in subgroups defined by age group, intensity of interventions, or mode of delivery (Table 7). However, effects on drug use severity were absent in trials of brief interventions (10 trials, SMD −0.02, 95% CI −0.13 to 0.06, I^2^=35%)^44,52,53,58,59,61,62,65,67,107^ and favored psychosocial interventions in trials of intensive interventions (3 trials, SMD −0.36, 95% CI −0.80 to 0.14, I^2^=70%; p for interaction=0.03).^31,92,112,113^ Similarly, effects were absent in trials of screen-detected populations (9 trials, SMD −0.03, 95% CI −0.15 to 0.06, I^2^=40%)^44,52,53,58,59,61,62,65,67^ but favored psychosocial interventions in trials of treatment-seeking populations (4 trials, SMD −0.23, 95% CI −0.62 to 0.17, I^2^=82%; p for interaction=0.27) (Figure 17).^31,92,107,112,113^ No trial evaluated effects of psychosocial interventions on drug use severity stratified by patient sex.

Figure 17 Psychosocial Interventions vs. Control Conditions—Drug Use Severity at 6- to 12-Month Followup, Stratified by Population

Abbreviations: Adul = adult; Adol = adolescent; ASID = Addiction Severity Index (drugs); ASSIST = Alcohol, Smoking, and Substance Involvement Screening Test; ATTS = amphetamine-type stimulant use; CA = cannabis; CI = confidence interval; Comp = computer; FTF = face-to-face; MA = marijuana subscale; MPS = Marijuana Problem Scale; NIP = Noteworthy Index of Problems; PAdul = postpartum adult; RAPI = Rutgers Alcohol Problems Index; RMPI = Rutgers Marijuana Problem Index; SD = standard deviation; SDS = Severity of Dependence Scale; SMD = standardized mean difference; YAdul = young adult.

Figure 17 is a forest plot examining drug use severity at 6- to 12-month followup comparing psychosocial interventions versus control conditions with two subgroups. The standardized mean difference for the 4 studies in the non-screen-detected subgroup is −0.23 (95% confidence interval −0.62 to 0.17), with an I-squared value of 81.9%. The standardized mean difference for the 9 studies in the screen-detected subgroup is −0.03 (95% confidence interval −0.15 to 0.06), with an I-squared value of 40.2%. The overall standardized mean difference is −0.10 (95% confidence interval −0.24 to 0.02) with an I-squared value of 64.8%.

Data on effects of psychosocial interventions on other health, social, and legal outcomes was limited. Mortality was reported in four trials. In these trials, there were few mortality events, resulting in imprecise estimates.^47,61,66,69^ Two trials found no differences between psychosocial interventions versus control conditions in risk of emergency department visits or hospital admissions.^62,66^ Six trials found no statistically significant effects of psychosocial interventions on measures related to mental health.^30,48,62,90,110,111^ Two trials found no effect of psychosocial interventions on likelihood of driving after cannabis use^45,97,98^ and four of five trials found no effect on risk of incarceration or involvement in criminal activity.^47,61,88–90^ One trial^32,108^ found a brief intervention associated with decreased likelihood of selling drugs to friends (15% vs. 40%, OR 0.42, p=0.008). Three trials reported inconsistent effects of psychosocial interventions on measures of employment,^30,100,111^ with two trials showing no effects.^30,111^ Six trials found no effects of psychosocial interventions versus control conditions on quality of life or function (measured by the SF-12 Physical Component Scale, EUROHIS, General Health Questionnaire [GHQ]-28, or a 0 to 100 Health-related Quality of Life [HRQOL] scale).^48,62,66,88,111,113^

Seven trials found no statistically significant differences between psychosocial interventions versus control conditions in injection drug or sexual risk behaviors.^57,61,62,64,88–91^ One other trial found a brief therapist-initiated, computer guided behavioral intervention with a 3 month booster session associated with a reduction in scores on the sexual risk subscale of the HIV Risk Taking Behaviour Scale over 12 months compared with a minimal intervention, but brief interventions that were computer-delivered or did not include a booster session had no significant effects.^91^

## Key Question 5 What Are the Harms of Interventions to Reduce Drug Use?

### Summary

- There was no difference between naltrexone versus placebo or versus no naltrexone in risk of withdrawal due to adverse events (3 trials; RR 1.54; 95% CI 0.35 to 8.31; I^2^=0%), but the estimate was imprecise; three other trials reported no study withdrawals in either naltrexone or control groups.
  ○ Naltrexone was not associated with increased risk of serious adverse events, but reporting of serious adverse events was suboptimal and few events were reported.
- There was no difference between buprenorphine versus placebo in risk of serious adverse events (2 trials; RR 0.32, 95% CI 0.09 to 1.12; I^2^=0%); buprenorphine was associated with increased risk of constipation (2 trials; RR 2.36, 95% CI 1.16 to 4.92, I^2^=0%; ARD 12%, 95% CI −5% to 41%).
- Harms were not reported in two trials of methadone.
- Most psychosocial trials did not report harms, though no serious adverse events were noted; four trials reported no harms.

### Evidence

#### Naltrexone for Opioid Use Disorder

Eleven trials of naltrexone versus placebo or no medication reported harms of treatment (Appendixes B1, B2, and B3). Two studies described no or few adverse events during the study in either naltrexone or control groups,^71,75^ but did not provide additional details or data about specific adverse events, and one study reported the number of adverse events but the denominator was not provided.^72^ Among the other studies, three provided data on study withdrawals due to adverse events.^25,26,74^ All reported few events in either group, with no difference between naltrexone and control when pooled, based on an imprecise estimate (RR 1.54; 95% CI 0.35 to 8.31; I^2^=0%). Three other studies reported no study withdrawals due to adverse events in either group.^5,70,78^ There were also no differences in risk of serious adverse events (3 studies^25,26,70^; RR 1.24, 95% CI 0.11 to 10.21; I^2^=59%). One other study^5^ reported no serious adverse events in either group. One study^73^ reported on increase in risk of suicide attempts (4% [1/27] vs. 0% [0/25]; RR 2.39, 95% CI 0.12 to 65), and another study^26^ reported no suicide events in either group. There was no difference between naltrexone versus placebo or no medication in risk of diarrhea (2 studies; RR 1.94, 95% CI 0.70 to 6.53; I^2^=0%),^5,79^ nausea or vomiting (1 study; RR 1.40, 95% CI 0.33 to 5.93),^5^ or constipation (2 studies; RR 0.97, 95% CI 0.37 to 2.39; I^2^=0%).^5,70^

#### Opioid Agonist Therapy (Buprenorphine or Methadone) for Opioid Use Disorder

Four trials of opioid agonist therapy versus placebo, each of which evaluated buprenorphine, reported harms (Appendixes B5, B6, and B7).^70,83–85^ There was no difference between buprenorphine versus placebo in risk of serious adverse events, which were uncommon (2 trials; RR 0.32, 95% CI 0.09 to 1.12; I^2^=0%)^84,85^; one trial reported no hospitalizations due to serious medication-related adverse events.^70^ One trial found no difference between buprenorphine versus placebo in risk of withdrawal due to adverse events (RR 0.89, 95% CI 0.06 to 13.7)^70^ and one trial found no difference in risk of any adverse event (RR 1.14, 95% CI 0.90 to 1.43).^85^ There were no differences between buprenorphine versus placebo in risk of diaphoresis (3 trials; RR 1.15, 95% CI 0.55 to 2.73; I^2^=44%)^70,83,85^ or nausea (2 trials; RR 1.13, 95% CI 0.41 to 6.07; I^2^=30%).^83,85^ Buprenorphine was associated with increased risk of constipation versus placebo, based on two trials (RR 2.36, 95% CI 1.16 to 4.92, I^2^=0%; ARD 12%, 95% CI −5% to 41%).^70,84^

#### Psychosocial Interventions

Four trials of psychosocial interventions reported no adverse events in either intervention or control groups.^52,53,57,58^ Harms were otherwise not reported in trials of psychosocial interventions, with no serious adverse events noted.^57^

## Key Questions 6 and 7 Does Naloxone Reduce Morbidity or Mortality, or Improve Other Health Outcomes in Persons With Opioid Use Disorder or Misuse? What Are the Harms of Naloxone in Persons With Opioid Use Disorder or Misuse?

No study evaluated the benefits or harms of preemptive prescribing of naloxone versus placebo or versus no naloxone for mitigating overdose risk in persons with opioid use disorder or misuse in primary care settings. Although one nonrandomized intervention study found provision of naloxone in primary care settings associated with decreased likelihood of opioid-related emergency department visits after 6 months (incidence rate ratio 0.53, 95% CI 0.34 to 0.83) and 1 year (incidence rate ratio 0.37, 95% CI 0.22 to 0.64), the intervention consisted of training and support in naloxone prescribing to providers and clinic staff, and patients were prescribed long-term opioid therapy for pain and were not selected on the basis of drug misuse or abuse.^123^ A trial from the United Kingdom of provision of naloxone upon release to incarcerated adults with heroin injection use was stopped early because two-thirds of naloxone administrations were to persons other than the ex-prisoner. At the time that the study ended, five drug-related deaths had occurred within 12 weeks post-release, among over 1,500 persons randomized.^124^