# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^23^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for the full screening review, including an analytic framework (Figure 1) with the Key Questions and the patient populations, interventions, and outcomes reviewed.^1^ This supplemental report addresses the following Key Questions included within the full analytic framework on screening, focusing on the benefits and harms of drug use treatments in screen-detected as well as treatment-seeking populations, and naloxone prescribed in clinical settings as a rescue medication for acute opioid overdose for purposes of risk mitigation:

- Do interventions to reduce drug use^*^ reduce drug use or improve other risky behaviors? (Key Question 4a in the original screening analytic framework^1^)
- Do interventions to reduce drug use^*^ reduce morbidity or mortality or improve other health, social, or legal outcomes? (Key Question 4b in the original screening analytic framework^1^)
- What are the harms of interventions to reduce drug use^*^? (Key Question 5 in the original screening analytic framework^1^)
- Does naloxone reduce morbidity or mortality, or improve other health outcomes in persons with opioid use disorder or misuse? (New Key Question 6 in the analytic framework for supplemental review)
- What are the harms of naloxone in persons with opioid use disorder or misuse? (New Key Question 7 in the analytic framework for supplemental review)

Figure 1 Analytic Framework and Key Questions

*Drug use refers to substance use disorders or misuse related to opioids, stimulants, or cannabis, or polysubstance use related to one or more of these drugs for Key Questions 4 and 5.

Note: Numbers on the figure refer to the numbers of the Key Questions.

Key Questions Addressed in a Separate Report^1^

1 a. Does primary care screening for drug use^*^ in adolescents and adults, including pregnant women, reduce drug use or improve other risky behaviors?
  b. Does primary care screening for drug use^*^ in adolescents and adults, including pregnant women, reduce morbidity or mortality or improve other health, social, or legal outcomes?
2 What is the accuracy of drug use screening instruments?
3 What are the harms of primary care screening for drug use in adolescents and adults, including pregnant women?

Key Questions Addressed in this Report

4 a. Do interventions to reduce drug use^†^ reduce drug use or improve other risky behaviors?
  b. Do interventions to reduce drug use^†^ reduce morbidity or mortality or improve other health, social, or legal outcomes?
5 What are the harms of interventions to reduce drug use^†^?
6 Does naloxone reduce morbidity or mortality, or improve other health outcomes in persons with opioid use disorder or misuse?
7 What are the harms of naloxone in persons with opioid use disorder or misuse?

Note: “Screening” refers to screening methods that pose questions about drug use or drug-related risks, not laboratory testing of biologic samples for the presence of drugs.

* Includes illicit drug use and nonmedical pharmaceutical drug use.

† Drug use refers to substance use disorders or misuse related to opioids, stimulants, or cannabis, or polysubstance use related to one or more of these drugs for Key Questions 4 and 5.

The analytic framework depicts the relationship between the populations, interventions, outcomes, and harms of interventions for drug use. The far left of the framework describes the target population as adolescents and adults, including pregnant women. To the right of the population is an arrow which represents screening for drug use, and specifically the accuracy of drug use screening instruments (key question 2). A subsequent arrow leads to potential harms of screening for drug use (key question 3). An arrow from screening also leads to interventions for drug use, and the examination on the effect of behavioral outcomes, including drug abstinence, frequency and/or quantity of drug use, and other risky behaviors (key question 4a). In addition, a separate arrow leads to the examination of the effect on health and related outcomes, including morbidity, mortality, and social/legal outcomes (key question 4b). Key question 6 addresses a separate question of whether naloxone reduces morbidity or mortality, or improves other health outcomes in persons with opioid use disorder or misuse. A subsequent arrow from interventions leads to the assessment of harms of interventions to reduce drug use (key questions 5), and also the assessment of harms of naloxone in persons with opioid use disorder or misuse. (key question 7). A dotted line represents the association between the behavioral outcomes and health and related outcomes. An overarching arrow leads directly from screening to the behavioral outcomes (key question 1a), and the health and related outcomes (key question 1b).

Key Questions 1-3 in the analytic framework are addressed in a separate screening review.^1^

* Drug use refers to substance use disorders or misuse related to opioids, stimulants, or cannabis, or polysubstance use related to one or more of these drugs.

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, Ovid MEDLINE, Embase, and PsycINFO for relevant studies and systematic reviews. Databases were searched from inception to September 2018. After September 2018, we conducted surveillance through article alerts and targeted searches of high-impact journals to identify major studies that may affect conclusions. The last surveillance was conducted on November 22, 2019. One new pilot trial^24^ of a psychosocial intervention among adolescents identified through screening was identified in the surveillance scan; however, this study does not substantively change the findings or conclusions of this review and was not added to the final report. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for the Key Questions addressed in this supplemental report (Appendix A2). We included randomized trials of pharmacotherapy and psychosocial interventions conducted in populations engaging in drug use regardless of whether their drug use was identified through primary care-based screening, including persons seeking substance use treatment or with signs and symptoms of drug use, and whether or not they met criteria for a substance use disorder. We incorporated all trials of drug use treatment from the USPSTF screening review^1^ that enrolled screen-detected populations, along with additional trials of treatment-seeking populations. In addition, we included trials on the benefits and harms of naloxone in persons with opioid use disorder or misuse; this topic was not addressed in the 2008 review or the screening update.

We included trials of adolescents (defined as persons 12 to <18 years of age) and adults engaging in use of opioids, stimulants (e.g., cocaine, methamphetamines, and ecstasy), and cannabis. We also included trials of patients engaged in mixed drug use (defined as studies that evaluated more than one type of drug use, but individuals did not necessarily use more than one drug) or polysubstance use (defined as studies in which an individual used more than one drug), as long as one of the three drug classes was the predominant drug of use. We did not restrict inclusion to persons meeting formal criteria (e.g., DSM-IV criteria for abuse or dependence or DSM-5 criteria) for substance use disorder. Rather, we included trials in which patients reported any nonmedical drug use, including those meeting formal DSM-IV or DSM-5 criteria. We included studies of pregnant and postpartum women. We included trials of pharmacotherapies in which treatment was initiated in inpatient settings, as long as subsequent therapy was administered in outpatient settings. Trials in which all therapy was administered in inpatient settings were excluded. We excluded trials of incarcerated patients and trials in which patients were selected on the basis of having a concurrent medical (e.g., HIV or hepatitis C virus [HCV] infection) or psychiatric (e.g., depression or schizophrenia) condition; trials of individuals using prescribed opioids without signs or symptoms of misuse or addiction; and trials in which patients were selected based on use of alcohol, nicotine, or another substance other than opioids, stimulants, and cannabis.

For pharmacotherapies, we focused on medications that are FDA-approved for substance use disorder as of September 2018. These are buprenorphine (sublingual or extended-release injection or implant), buprenorphine/naloxone, methadone, and naltrexone (oral or extended-release injection) for treatment of opioid use disorder. We included two trials of extended-release naltrexone formulations, including implantable naltrexone^25^ (formulation not FDA-approved as of 2019) and injectable naltrexone^26^ (formulation FDA-approved in 2010). Analyses of naltrexone were stratified according to route of administration (oral versus implant/injectable). No pharmacotherapies are currently FDA-approved for treatment of cannabis or stimulant use disorder. We excluded trials of methadone or buprenorphine for detoxification (withdrawal management), as maintenance therapy with these medications is generally recommended due to a high risk of relapse.^10^ We also included studies of preemptive naloxone prescribed in clinical settings as a rescue medication for acute overdose events, for mitigation of opioid-related harms. For psychosocial interventions, we included interventions that utilized one or more of the following techniques: CBT, motivational interventions, contingency management, twelve-step facilitation therapy, family interventions, and adaptations or combinations of these methods.^8^ We did not restrict inclusion of trials of psychosocial interventions based on the number or length of intervention sessions. However, we categorized interventions as brief (defined for this report as 1 or 2 sessions, each less than 1 hour in duration) or intensive (not meeting definition for brief). Psychosocial interventions could be delivered face-to-face or using other modalities (e.g., telephone, Internet, or computer). Interventions could be delivered in office-based settings or in opioid treatment programs. We excluded trials of school-based or community level interventions.

We included trials in which included interventions were compared against placebo, a minimal intervention (including attention control), or waitlist control. Minimal interventions and attention controls were similar in intensity (e.g., duration) to the intervention, but were designed to have minimal or no specific effect. Minimal interventions and attention controls commonly consisting of brief educational interventions without a psychosocial component. We only included trials that compared an included intervention against usual care if the usual care intervention did not represent active treatment for drug use disorders. In some trials, usual care could include referral to pharmacotherapy or psychosocial intervention, though we excluded trials in which patients were routinely referred for drug treatment. For trials of pharmacotherapy, we included trials in which all patients received psychosocial interventions, consistent with how pharmacotherapy for opioid use disorder is delivered in clinical practice and the standard of care.^10^ Otherwise, we excluded head-to-head trials comparing one active intervention versus another, trials of combination versus single modality pharmacotherapy, and trials comparing different intensities or duration of pharmacologic therapy or psychosocial interventions.

We included trials that evaluated outcomes at 3 months or longer following the initiation of the interventions. Outcomes were drug use (i.e., abstinence, frequency and/or quantity of drug use, severity of drug use disorder, polysubstance use other risky behaviors), clinical outcomes (i.e., all-cause mortality, drug-related mortality, drug-related morbidity, obstetrical/perinatal/neonatal outcomes, quality of life), other drug-related problems (i.e., legal problems, social and family relations, employment, school/educational outcomes), and harms, including serious adverse events such as death and adverse events resulting in hospitalizations or study withdrawal. For trials of pharmacotherapy for opioid use disorder, we also included retention in substance use treatment as an outcome, because of the ongoing nature of treatment, the chronic relapsing nature of opioid use disorder, and the association between retention in treatment (implying ongoing engagement in care) with reductions in substance use and criminal behavior, and improvements in functioning and quality of life.^27–29^ Because most measures of drug use severity (e.g., Severity of Dependence Scale [SDS], ASSIST, Marijuana Problem Scale [MPS], number of DSM-IV dependence symptoms met) include social, legal, and other consequences of drug use, we considered them measures of drug-related problems.

Additional details on study eligibility for inclusion are available in Appendix A2. The literature flow diagram (Appendix A3) summarizes the results of the literature search. Appendix A4 lists the included studies, and Appendix A5 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We abstracted details about the study design, inclusion criteria, patient population (including measures of drug use severity), recruitment and treatment setting, interventions, analysis, followup, and results (Appendix B). For trials of screen-detected populations, we utilized the quality ratings as reported in the USPSTF screening review.^1^ For all other trials, investigators independently applied criteria developed by the USPSTF^23^ (Appendix A6) to rate the quality of each study as good, fair, or poor. Discrepancies were resolved through a consensus process. In accordance with the USPSTF Procedure Manual, we excluded studies rated poor quality due to important methodological shortcomings that severely undermine their reliability.^23^ Appendix C1 shows all outcomes measures mentioned in the report.

## Data Synthesis

We supplemented a random effects meta-analysis reported in the USPSTF screening review on effects of psychosocial interventions on differences in change from baseline in the number of drug use days in screen-detected populations with additional trials conducted in treatment-seeking populations. Drug use days were standardized to the number of days of drug use in the past 7 days and the analysis was stratified according to whether patients were screen-detected. Results were analyzed separately for outcomes assessed at 3 or 4 months and outcomes assessed at 6 to 12 months. The meta-analysis used the random effects profile likelihood model; additional details regarding statistical methods are available in the USPSTF screening review.^1^

We performed a new (not in the USPSTF screening review) random effects meta-analysis using the profile likelihood model on the dichotomous outcomes abstinence, retention in treatment (for trials of medications for opioid use disorder), and harms (serious adverse events, study withdrawal due to adverse events, nausea, diaphoresis, and constipation). We pooled data separately for the opioid antagonist naltrexone, the opioid agonists methadone and buprenorphine, and psychosocial interventions. The analysis for methadone and buprenorphine was stratified by drug. To explore heterogeneity, we also performed additional stratified analyses. For all interventions, we stratified analyses according to whether the population was screen-detected or treatment seeking, the main type of drug use measured by the study (cannabis, stimulant, opioid, or mixed drugs), age group (adolescent [12 to 17 years of age], young adult [18 to 25 years of age], or adult [>25 years of age]), study quality, and pregnancy or postpartum status. For pharmacotherapies, we also stratified by route of administration, naltrexone dose, timing of outcome assessment, and intensity of the interventions; and for psychosocial interventions, we stratified according to intervention intensity (brief versus intensive as defined above) and mode of delivery (face-to-face, or other).

For trials of psychosocial interventions, we also performed a new random effects meta-analysis using the profile likelihood method on the continuous outcome of drug use severity. Outcomes related to drug use severity were reported in too few trials of pharmacotherapies (which focused on abstinence/relapse and retention in treatment) to permit pooling. Because trials used different scales to measure drug use severity, we calculated the standardized mean difference as the effect measure. The followup scores were used in the primary analysis and sensitivity analyses were conducted based on change score from baseline (results were similar and results based on change scores are not reported separately). Data were separately analyzed for 3 to 4 month and 6 to 12 month outcomes. The primary analysis was stratified according to the predominant type of drug use; we performed additional stratified analyses based on the intensity of psychosocial interventions, study population (age, whether or not screen detected), mode of delivery, and study quality. Heterogeneity between studies was evaluated by the χ^2^ test and I^2^ statistics. All analyses were conducted using Stata/IC 13.1 (StataCorp LP, College Station, TX). Analyses were repeated using the Dersimonian and Laird model; results were similar to results using the profile likelihood method and are not reported separately.

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (“good”, “fair”, “poor”) using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and directness of evidence in the Summary of Evidence table.^23^

## Expert Review and Public Comment

A draft version of this supplemental report was reviewed by content experts (Appendix A7), representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. Clarifications were made to the report in response to comments, including abstraction of additional details regarding the persons delivering interventions evaluated in the trials.

In addition, a draft of the full report was posted on the USPSTF Web site from August 13, 2019 through September 9, 2019. In response, a footnote was added to the Analytic Framework (Figure 1) to clarify that “screening” refers to screening methods that pose questions about drug use or drug-related risks, not laboratory testing of biologic samples for the presence of drugs, and the conclusion was clarified to state that although the applicability of data from such trials to persons whose drug use is identified through primary care-based screening is uncertain, intervention trials that enrolled patients based on screening identified a spectrum of drug use, ranging from mild drug use to more severe, untreated disease.