# Chapter 1 Introduction

This report supplements a review for the U.S. Preventive Services Task Force (USPSTF) on screening for drug use in primary care in adolescents and adults, including pregnant women,^1^ focusing on evidence examining the benefits and harms of psychosocial interventions and pharmacotherapy for persons engaging in drug use. The USPSTF screening review updates a 2008 USPSTF review on screening for illicit drug use.^2^ Like the 2008 USPSTF review, the screening review addresses the benefits and harms of screening through use of instruments with questions about drug use or drug-related risks, the accuracy of drug use screening instruments, and the benefits and harms of counseling interventions to reduce drug use detected through screening in primary care settings (referred to in this report as “screen-detected”).^1^ Such patients may have less severe drug use than persons seeking treatment for or referred for treatment of drug use or persons with clinical signs or symptoms of drug use (referred to in this report as “treatment-seeking”); however, symptom severity may overlap between screen-detected and treatment-seeking populations. Unlike the 2008 USPSTF review, the screening review does not address evidence on interventions among treatment-seeking persons,^2^ because evidence from screen-detected populations is more directly applicable for guiding decisions about screening for drug use in primary care settings. A potential limitation of this approach is that it excludes some evidence on more intensive psychosocial interventions and evidence on the effectiveness of pharmacotherapies, which have been primarily studied in treatment-seeking populations.

This supplemental review focuses on the benefits and harms of counseling and other psychosocial interventions and pharmacotherapies for adolescents, adults, and pregnant women engaging in opioid, cannabis, stimulant, mixed drug, or polysubstance use, expanding the scope from screen-detected individuals to also address effectiveness of interventions in persons who were identified when seeking substance use treatment, when presenting with signs or symptoms of drug use, or through other means. Such evidence might further inform assessments regarding potential benefits and harms of drug use screening in primary care settings, given the variability in drug use severity among patients identified through screening. This supplemental review also differs from the 2008 USPSTF review in that it addresses the benefits and harms of preemptive naloxone prescribed in primary care settings as a rescue medication for treating acute overdose episodes in individuals with opioid use. A separate USPSTF update on drug use prevention in children, adolescents, and young adults through age 25 years is in progress.^3^

## 2008 USPSTF Review

The 2008 USPSTF review found fair- to good-evidence that pharmacologic therapy is effective at reducing short-term illicit drug use.^2^ However, 16 of the 17 treatment trials included in the 2008 USPSTF review were conducted among treatment-seeking populations who had already developed health, social, and/or legal problems due to drug use. The exception was one trial which found a brief counseling intervention effective at decreasing opiate and cocaine use among 1,175 screen-detected primary care patients.^4^ In addition, only two of the eight trials of pharmacotherapies included in the 2008 USPSTF review evaluated medications approved by the Food and Drug Administration (FDA) for treatment of substance use disorders.^5,6^ The 2008 USPSTF review found limited and less consistent evidence of positive effects of pharmacotherapies or psychosocial interventions on social, legal, and health outcomes related to drug use. The 2008 USPSTF review also found limited evidence from observational studies conducted outside the United States for an association between stopping or reducing opioid (usually heroin) misuse and long-term improvement in mortality rates; none of the studies examining this association were conducted in screen-detected populations whose drug use was detected in primary care settings. Based on the 2008 review, the USPSTF concluded that the evidence was insufficient to determine the benefits and harms of screening for illicit drug use in primary care settings.^7^

## USPSTF Screening Review

The USPSTF screening review included 27 trials on the effectiveness of psychosocial interventions for drug use in screen-detected populations.^1^ Substance use eligibility criteria varied, frequently consisting of self-reported drug use within a specified time-frame (e.g., 30 days to 1 year), or requiring patients to meet a certain threshold score on a screening instruments (e.g., Alcohol, Smoking, and Substance Involvement Screening Test [ASSIST] score ≥4). No trial required patients to meet the Diagnostic and Statistical Manual of Mental Disorder (DSM)-IV criteria for abuse or dependence or DSM-5 criteria for substance use disorder. All but two trials evaluated brief counseling interventions (typically 1 or 2 sessions, less than an hour in duration), often incorporating motivational techniques. No trial evaluated pharmacotherapy.

The USPSTF screening review found no consistent evidence that psychosocial interventions were effective at reducing drug use at 3- to 12-month followup in screen-detected populations, or at improving health, social, or legal outcomes associated with drug use.^1^ Evidence on harms was sparse, but indicated no serious harms associated with counseling interventions. Evidence on the effects of psychosocial interventions about drug use for adolescents, pregnant women, and postpartum women was very limited and also showed no clear benefits. Additional details on the benefits and harms of treatment for drug use in screen-detected populations are available in the full screening review.^1^

## Interventions to Reduce Drug Use

This supplemental report to the USPSTF screening review addresses pharmacotherapy and psychosocial interventions to reduce drug use in persons engaging in opioid, cannabis, stimulant, or polysubstance use involving one or more of these drugs.

Currently, the only pharmacotherapies approved by the FDA for treatment of drug use disorders addressed in this report (opioids, cannabis, or stimulants) are opioid agonists, partial agonists, and antagonists for treatment of opioid use disorder. Lofexidine was recently approved by the FDA to mitigate symptoms of abrupt opioid withdrawal. As it is not a treatment for opioid use disorder, it is not addressed in this report. A recent guideline from the Department of Veterans Affairs/Department of Defense (VA/DoD) found insufficient evidence to recommend for or against pharmacotherapy for cannabis use or stimulant use disorder.^8^ Several FDA-approved medications are considered first-line therapy for treatment of opioid use disorder;^8–10^ they are methadone (an opioid agonist), buprenorphine (a partial opioid agonist) with or without naloxone (available in combination with naloxone or as a mono-product, and in sublingual or buccal administration or extended-release implantable or injectable formulations), and naltrexone (an opioid antagonist, available as an oral or extended-release injectable formulation). In the United States, methadone for treatment of opioid use disorder must be dispensed through a licensed opioid treatment program.^11^ Buprenorphine and naltrexone can be prescribed in office-based settings as well as dispensed in an opioid treatment program, though additional training and a waiver from the Drug Enforcement Agency (DEA) is required for office-based prescribing of buprenorphine. The purpose of medications for opioid use disorder is to block the euphoric and sedating effects of opioids, reduce cravings for opioids, and/or to mitigate symptoms of opioid withdrawal. Medications are used in combination with psychosocial interventions to prevent relapse to opioid use.^10^ Use of medications for treatment of opioid use disorder is traditionally referred to as “medication assisted treatment” (MAT). However, experts have suggested that the term “medication assisted” is misleading because it implies that medications play an adjunctive role in treatment for opioid use disorder.^12,13^ Rather, evidence indicates that medications are the main driver of therapeutic effectiveness, with several studies finding no clear differences in the effectiveness between more versus less intensive psychosocial interventions in persons receiving medications for opioid use disorder.^14,15^ A potential alternative to the term “medication assisted treatment” that retains the MAT acronym and does not suggest that medications are a secondary component is “medications for addiction treatment.” We used the term “pharmacotherapy” in this report to refer to methadone, buprenorphine, or naltrexone and “opioid agonist therapy” to refer to methadone and buprenorphine.

Psychosocial interventions are used for treatment of various drug use disorders. A recent guideline from the VA/DoD recommends psychosocial interventions for treatment of cannabis use and stimulant disorder.^8,16^ In addition, medications for opioid use disorder are administered in conjunction with psychosocial interventions. Commonly used psychosocial techniques include cognitive-behavioral therapy (CBT), motivational interventions, 12-step facilitation therapy, contingency management, and family interventions. Psychosocial techniques can be combined in a variety of ways. CBT helps individuals to positively address unhealthy drug use behaviors by identifying and correcting maladaptive thought patterns, goal setting, and learning and applying coping strategies. Motivational intervention techniques, such as motivational interviewing (MI) and Motivational Enhancement Therapy (MET), seek to positively impact unhealthy behaviors by eliciting and enhancing motivations to change. Contingency management is based on operant conditioning principles, utilizing an incentive-based approach that rewards behaviors that meet desired outcomes.^16^ Twelve-step facilitation therapy focuses on actively engaging individuals in a mutual support group guided based on twelve-step principles. Family interventions actively engage the family and address contributing factors to drug use, such as family communication and conflict, school and work issues, and peer networks. Family interventions are often used for treatment of adolescent substance misuse.^17^

Psychosocial interventions range in intensity, from brief interventions (e.g., 1 or 2 to sessions, each lasting less than 1 hour) to more intensive, ongoing treatments (e.g., once or twice weekly sessions for 1 to 2 hours). Brief interventions are usually designed for persons with unhealthy drug use but who do not have more serious substance use (e.g., do not meet DSM-5 criteria for substance use disorder), though these interventions can be a bridge to more intensive therapy in persons who require it.^18^ Brief interventions are often designed so that they can be delivered opportunistically in most settings, including primary care, with minimal training. More intensive psychosocial interventions often require additional training or expertise to deliver.

## Naloxone for Risk Mitigation in Persons With Opioid Use Disorder or Misuse

Naloxone is an opioid antagonist that rapidly counteracts the central nervous system and respiratory depressant effects of opioids potentially preventing fatal overdose and mitigating overdose-related harms.^19^ Unlike the pharmacotherapies described above, naloxone is preemptively prescribed as a rescue medication for acute overdose events administered by persons witnessing the overdose, not as a treatment for opioid use disorder or misuse. Therefore, it may help mitigate the risks of ongoing opioid use. The American Society of Addiction Medicine recommends, based on consensus opinion, that patients being treated for opioid use disorder and their family members/significant others be given prescriptions for naloxone.^9^ Naloxone can be administered in a number of ways by witnesses to overdose events, including the intravenous, intramuscular, subcutaneous, and intranasal routes. The FDA recently approved new naloxone devices: a handheld intramuscular or subcutaneous auto-injector and a new intranasal formulation and delivery device. Both devices administer a consistent preset dose and are designed for use by individuals regardless of level of health care training. Improvised use of injectable naloxone administered intranasally using an atomizer is also used for cost or other reasons, but the naloxone is less concentrated compared to the FDA approved intranasal formulation. Data on the effectiveness of naloxone used in this way is uncertain, particularly for overdose related to high potency synthetic opioids (fentanyl and fentanyl analogues).^20^ Naloxone has been shown to be effective for reversal of opioid overdose, but has mainly been evaluated in the context of non-randomized evaluations of community opioid overdose prevention and naloxone distribution programs.^21,22^ The effectiveness of naloxone that is preemptively prescribed in clinical settings for mitigating overdose risk in individuals with opioid use is less certain.