# Appendix C Supplemental Materials

## Appendix C1 Outcome Measures and Scoring

Abbreviation | Full name of outcome measure | Scale | Direction
ADI | Adolescent Diagnostic Interview | Varies according to subscale/domain | Higher score=worse outcomes
ARI | AIDS Risk Inventory | Varies according to subscale/domain | Lower score=lower risk of acquiring AIDS
ASI | Addiction Severity Index | 0 to 9 | Lower score=better outcomes
ASSIST | Alcohol, Smoking, and Substance Involvement Screening Test | 0-39 for individual drug categories and alcohol; total score range 0-414 | Higher score=higher risk of problematic drug use
BDI | Beck Depression Inventory | 0 to 63 | Higher score=more severe depressive symptoms
BPRS | Brief Psychiatric Rating Scale | 0 to 126 | Higher score=more severe psychiatric condition
CGI | Clinical Global Impressions | 1 to 7 | Higher score=more severe illness
COWS | Clinical Opiate Withdrawal Scale | Varies according to subscale/domain | Higher score=more severe symptoms
CPQ | Cannabis Problems Questionnaire | 0 to 22 | Higher score=more problems
CUDIT | Cannabis Use Disorders Identification Test | 0 to 40 | Higher score=more severe cannabis use disorder
CUPIT | Cannabis Use Problems Identification Test | 0 to 58 and 0 to 24 | Higher score=more problems and/or less control over cannabis use
DSM-IV CPS | Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Compendium of Pharmaceuticals and Specialties | 0 to 11 | Higher score=worse mental disorder
EUROHIS | EUROHIS-QOL 8-item index | 0 to 40 | Higher score=better quality of life
GAIN | Global Appraisal of Individual Needs | Varies according to subscale/domain | Higher score=greater need for referral
GHQ-28 | 28-Item General Health Questionnaire | 0 to 84 | Lower score=better health
HRQOL | Health-Related Quality of Life | 0 to 100 | Higher score=better outcome
MAP | Maudsley Addiction Profile | 0 to 240 | Higher score=greater addiction severity
MDS | Marijuana Dependence Scale | 0 to 9 | Higher score=greater dependence on marijuana
MHI-5 | Mental Health Inventory-5 | 0 to 100 | Lower score=greater emotional functioning
MMPI | Minnesota Multifactoral Personality Inventory | Varies according to subscale/domain | Higher score=worse depression
MPS | Marijuana Problem Scale | 0 to 38 | Higher score=more cannabis use consequences
NIP | Noteworthy Index of Problems | 0 to 19 | Higher score=greater frequency of drug or alcohol use events
OASIS | Overall Anxiety Severity and Impairment Scale | 0 to 20 | Higher score=more severe anxiety severity and impairment
OTI | Opioid Treatment Index | Varies according to subscale/domain | Higher score=greater dysfunction
RAPI | Rutgers Alcohol Problems Index | 0 to 69 | Higher score=more instances of negative problems related to alcohol drinking in the past year
RMPI | Rutgers Marijuana Problem Index | Varies according to subscale/domain | Higher score=more instances of negative consequences related to drug use experienced in the last 3 months
SCL-5 | Symptom Checklist-5 | 0 to 4 | Higher score=worse anxiety and depression
SDS | Severity of Dependence Scale | 0 to 15 | Higher score=higher level of dependence
SF-12 | 12-Item Short Form Health Survey | 0 to 100 | Higher score=better health
SIP-R | Short Inventory of Problems | 0 to 45 | Higher score=worse outcome
SOWS | Subjective Opiate Withdrawal Scale | 0 to 4 | Higher score=more severe symptoms
SSAI | Spielberger State-Anxiety Inventory | 20 to 80 | Higher score=greater anxiety
STAI | State-Trait Anxiety Inventory | 0 to 160 | Higher score=greater anxiety
TSLS | Temporal Satisfaction with Life Scale | 0 to 7 | Higher score =worse overall life satisfaction
VAS | Visual Analog Scale | 0 to 10 | Lower score=greater subjective wellbeing
YSR | Youth Self-Report | 0 to 62 and 0 to 64 | Higher score=more problems and/or fewer social competencies