# Appendix B Evidence Tables and Quality Tables

Appendix B1 Naltrexone Trials—Study Characteristics

Appendix B2 Naltrexone Trials—Intervention Characteristics

Appendix B3 Naltrexone Trials—Results

Appendix B4 Naltrexone Trials—Quality Assessment

Appendix B5 Methadone and Buprenorphine Trials—Study Characteristics

Appendix B6 Methadone and Buprenorphine Trials—Intervention Characteristics

Appendix B7 Methadone and Buprenorphine Trials—Results

Appendix B8 Methadone and Buprenorphine Trials—Quality Assessment

Appendix B9 Psychosocial Trials—Study Characteristics

Appendix B10 Psychosocial Trials—Intervention Characteristics

Appendix B11 Psychosocial Trials—Results

Appendix B12 Psychosocial Trials—Quality Assessment