# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Key Questions 4-5

#### Database: Ovid MEDLINE(R)

##### Pharmacologic interventions

1. substance-related disorders/ or amphetamine-related disorders/ or cocaine-related disorders/ or drug overdose/ or heroin dependence/ or inhalant abuse/ or marijuana abuse/ or opioid-related disorders/ or substance abuse, intravenous/ or substance abuse, oral/
2. exp Cannabinoids/
3. Cannabis/
4. exp “Marijuana Use”/
5. exp Analgesics, Opioid/
6. exp Cocaine/
7. exp Amphetamines/
8. exp Street Drugs/
9. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
10. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
11. exp Buprenorphine/
12. exp Methadone/
13. Naltrexone/
14. (buprenorphine or probuphine or sublocade or subutex or suboxone or methadone or naltrexone or vivitrol).ti,ab,kw.
15. treatment outcome/
16. (treatment* or intervention*).ti,ab.
17. (dt or th or pc or rh).fs.
18. 1 and (or/11-14)
19. (or/2-9) and 10 and (or/11-14)
20. 18 or 19
21. 20 and (or/15-17)
22. Randomized Controlled Trials as Topic/
23. double-blind method/ or random allocation/
24. (random* or control* or trial or placebo or blind*).ti,ab,kw.
25. 21 and (or/22-24)
26. limit 21 to randomized controlled trial
27. 25 or 26
28. meta-analysis.pt.
29. meta-analysis/ or systematic review/ or meta-analysis as topic/ or “meta analysis (topic)”/ or “systematic review (topic)”/ or exp technology assessment, biomedical/
30. (medline or cochrane or “systematic review” or “meta analysis” or metaanalysis).ti,ab,kw.
31. 21 and (or/28-30)
32. limit 21 to (meta analysis or systematic reviews)
33. 31 or 32
34. 27 or 33
35. limit 34 to (english language and humans)

#### Database: Ovid MEDLINE(R)

##### Nonpharmacologic interventions – systematic reviews

1. substance-related disorders/ or amphetamine-related disorders/ or cocaine-related disorders/ or drug overdose/ or heroin dependence/ or inhalant abuse/ or marijuana abuse/ or opioid-related disorders/ or substance abuse, intravenous/ or substance abuse, oral/
2. exp Cannabinoids/
3. Cannabis/
4. exp “Marijuana Use”/
5. exp Analgesics, Opioid/
6. exp Cocaine/
7. exp Amphetamines/
8. exp Street Drugs/
9. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
10. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
11. exp Behavior Therapy/
12. psychotherapy/
13. exp Psychotherapy, Group/
14. exp Counseling/
15. Self-Help Groups/
16. psychoanalytic therapy/
17. (brief adj3 intervention*).ti,ab.
18. (“cognitive behavior* therapy” or “cbt”).ti,ab.
19. (“contingency management” or voucher* or prize*).ti,ab.
20. (motivation* adj3 enhanc*).ti,ab.
21. (“12 step” or “twelve step” or anonymous).ti,ab.
22. 21 not alcohol*.ti.
23. (family adj3 (counsel* or intervention* or therap*)).ti,ab.
24. psychotherapy, brief/
25. or/2-9
26. 10 and 25
27. 1 or 26
28. or/11-20
29. or/22-24
30. 28 or 29
31. 27 and 30
32. limit 31 to (meta analysis or systematic reviews)
33. meta-analysis.pt.
34. meta-analysis/ or systematic review/ or meta-analysis as topic/ or “meta analysis (topic)”/ or “systematic review (topic)”/ or exp technology assessment, biomedical/
35. ((systematic* adj3 (review* or overview*)) or (methodologic* adj3 (review* or overview*))).ti,ab.
36. ((quantitative adj3 (review* or overview* or synthes*)) or (research adj3 (integrati* or overview*))).ti,ab.
37. ((integrative adj3 (review* or overview*)) or (collaborative adj3 (review* or overview*)) or (pool* adj3 analy*)).ti,ab.
38. (data synthes* or data extraction* or data abstraction*).ti,ab.
39. (handsearch* or hand search*).ti,ab.
40. (mantel haenszel or peto or der simonian or dersimonian or fixed effect* or latin square*).ti,ab.
41. (met analy* or metanaly* or technology assessment* or HTA or HTAs or technology overview* or technology appraisal*).ti,ab.
42. (meta regression* or metaregression*).ti,ab.
43. (meta-analy* or metaanaly* or systematic review* or biomedical technology assessment* or bio-medical technology assessment*).mp,hw.
44. (medline or cochrane or pubmed or medlars or embase or cinahl).ti,ab,hw.
45. (cochrane or (health adj2 technology assessment) or evidence report).jw.
46. (meta-analysis or systematic review).ti,ab.
47. (comparative adj3 (efficacy or effectiveness)).ti,ab.
48. (outcomes research or relative effectiveness).ti,ab.
49. ((indirect or indirect treatment or mixed-treatment) adj comparison*).ti,ab.
50. or/33-49
51. 31 and 50
52. 32 or 51

#### Database: Ovid MEDLINE(R)

##### Nonpharmacologic interventions - RCTs

1. substance-related disorders/ or amphetamine-related disorders/ or cocaine-related disorders/ or drug overdose/ or heroin dependence/ or inhalant abuse/ or marijuana abuse/ or opioid-related disorders/ or substance abuse, intravenous/ or substance abuse, oral/
2. exp Cannabinoids/
3. Cannabis/
4. exp “Marijuana Use”/
5. exp Analgesics, Opioid/
6. exp Cocaine/
7. exp Amphetamines/
8. exp Street Drugs/
9. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
10. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
11. exp Behavior Therapy/
12. psychotherapy/
13. exp Psychotherapy, Group/
14. exp Counseling/
15. Self-Help Groups/
16. psychoanalytic therapy
17. (brief adj3 intervention*).ti,ab.
18. (“cognitive behavior* therapy” or “cbt”).ti,ab.
19. (“contingency management” or voucher* or prize*).ti,ab.
20. (motivation* adj3 enhanc*).ti,ab.
21. (“12 step” or “twelve step” or anonymous).ti,ab.
22. 21 not alcohol*.ti.
23. (family adj3 (counsel* or intervention* or therap*)).ti,ab.
24. psychotherapy, brief/
25. or/2-9
26. 10 and 25
27. 1 or 26
28. or/11-20
29. or/22-24
30. 28 or 29
31. 27 and 30
32. limit 31 to randomized controlled trial
33. 31 and (random* or control* or trial or sham).ti,ab,kf.
34. 32 or 33

#### Database: PsycINFO

##### Pharmacologic interventions

1. drug abuse/ or drug usage/ or drug dependency/ or drug addiction/ or “substance use disorder”/
2. exp opiates/
3. exp cocaine/
4. marijuana usage/ or marijuana/
5. exp cannabis/ or cannabinoids/
6. exp cns stimulating drugs/
7. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
8. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
9. (or/2-7) and 8
10. 1 or 9
11. buprenorphine/
12. methadone/
13. naltrexone/
14. (buprenorphine or probuphine or sublocade or subutex or suboxone or methadone or naltrexone or vivitrol).ti,ab.
15. 10 and (11 or 12 or 13 or 14)
16. exp Treatment Outcomes/
17. (treatment* or therap* or intervention*).ti,ab.
18. 15 and (16 or 17)
19. Clinical Trials/
20. (random* or control* or trial or placebo or sham or blind*).ti,ab.
21. exp Treatment Effectiveness Evaluation/ or exp “Literature Review”/
22. (systematic or “meta analysis” or metaanalysis or medline).ti,ab.
23. 18 and (or/19-22)
24. limit 23 to (human and english language)

#### Database: PsycINFO

##### Nonpharmacologic interventions – systematic reviews

1. drug abuse/ or drug usage/ or drug dependency/ or drug addiction/ or “substance use disorder”/
2. exp opiates/
3. exp cocaine/
4. marijuana usage/ or marijuana/
5. exp cannabis/ or cannabinoids/
6. exp cns stimulating drugs/
7. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
8. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
9. (or/2-7) and 8
10. 1 or 9
11. exp psychotherapy/
12. cognitive therapy/
13. exp COUNSELING/
14. exp family therapy/
15. exp behavior modification/
16. exp psychotherapeutic techniques/
17. exp psychotherapeutic processes/
18. (brief adj3 intervention*).ti,ab.
19. (“cognitive behavior* therapy” or “cbt”).ti,ab.
20. (“contingency management” or voucher* or prize*).ti,ab.
21. (motivation* adj3 enhanc*).ti,ab.
22. (family adj3 (counsel* or intervention* or therap*)).ti,ab.
23. exp support groups/
24. (“12 step” or “twelve step” or anonymous).ti,ab.
25. 24 not alcohol*.ti.
26. 10 and (or/11-23)
27. 10 and 25
28. 26 or 27
29. (cinahl or cochrane or embase or medline or pubmed or scopus or “sociological abstracts” or “web of science”).ab.
30. (“systematic review” or “meta analysis” or “metaanalysis”).ti,ab.
31. (“systematic review” or “meta analysis”).md.
32. exp “Literature Review”/
33. 28 and (or/29-32)

#### Database: PsycINFO

##### Nonpharmacologic interventions - RCTs

1. drug abuse/ or drug usage/ or drug dependency/ or drug addiction/ or “substance use disorder”/
2. exp opiates/
3. exp cocaine/
4. marijuana usage/ or marijuana/
5. exp cannabis/ or cannabinoids/
6. exp cns stimulating drugs/
7. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
8. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
9. (or/2-7) and 8
10. 1 or 9
11. exp psychotherapy/
12. cognitive therapy/
13. exp COUNSELING/
14. exp family therapy/
15. exp behavior modification/
16. exp psychotherapeutic techniques/
17. exp psychotherapeutic processes/
18. (brief adj3 intervention*).ti,ab.
19. (“cognitive behavior* therapy” or “cbt”).ti,ab.
20. (“contingency management” or voucher* or prize*).ti,ab.
21. (motivation* adj3 enhanc*).ti,ab.
22. (family adj3 (counsel* or intervention* or therap*)).ti,ab.
23. (art or music* or acupuncture).ti,ab.
24. (“12 step” or “twelve step” or anonymous).ti,ab.
25. 24 not alcohol*.ti.
26. 10 and (or/11-23)
27. 10 and 25
28. 26 or 27
29. limit 28 to “0300 clinical trial”
30. exp Clinical Trials/
31. 28 and 30
32. 28 and (random* or control* or trial or sham).ti,ab,hw,id.
33. 29 or 31 or 32

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

##### Pharmacologic interventions

1. substance-related disorders/ or amphetamine-related disorders/ or cocaine-related disorders/ or drug overdose/ or heroin dependence/ or inhalant abuse/ or marijuana abuse/ or opioid-related disorders/ or substance abuse, intravenous/ or substance abuse, oral/
2. exp Cannabinoids/
3. Cannabis/
4. exp Analgesics, Opioid/
5. exp Cocaine/
6. exp Amphetamines/
7. exp Street Drugs/
8. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
9. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
10. exp Buprenorphine/
11. exp Methadone/
12. Naltrexone/
13. (buprenorphine or probuphine or sublocade or subutex or suboxone or methadone or naltrexone or vivitrol).ti,ab,kw.
14. treatment outcome/
15. (treatment* or intervention*).ti,ab.
16. (dt or th or pc or rh).fs.
17. 1 and (or/10-13)
18. (or/2-8) and 9 and (or/10-13)
19. 17 or 18
20. 19 and (or/14-16)
21. limit 20 to english language
22. limit 21 to medline records
23. 21 not 22

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

##### Nonpharmacologic interventions

1. substance-related disorders/ or amphetamine-related disorders/ or cocaine-related disorders/ or drug overdose/ or heroin dependence/ or inhalant abuse/ or marijuana abuse/ or opioid-related disorders/ or substance abuse, intravenous/ or substance abuse, oral/
2. exp Cannabinoids/
3. Cannabis/
4. exp Analgesics, Opioid/
5. exp Cocaine/
6. exp Amphetamines/
7. exp Street Drugs/
8. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
9. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
10. exp Behavior Therapy/
11. psychotherapy/
12. exp Psychotherapy, Group/
13. exp Counseling/
14. Self-Help Groups/
15. psychotherapy, brief/
16. (brief adj3 intervention*).ti,ab.
17. (“cognitive behavior* therapy” or “cbt”).ti,ab.
18. (“contingency management” or voucher* or prize*).ti,ab.
19. (motivation* adj3 enhanc*).ti,ab.
20. (“12 step” or “twelve step” or anonymous).ti,ab.
21. 20 not alcohol*.ti.
22. (family adj3 (counsel* or intervention* or therap*)).ti,ab.
23. psychoanalytic therapy/
24. or/2-8
25. 9 and 24
26. 1 or 25
27. or/10-19
28. or/21-23
29. 27 or 28
30. 26 and 29
31. limit 30 to medline records
32. 30 not 31

### Key Questions 4-7

#### Database: Elsevier Embase

(‘drug dependence treatment’/exp OR ‘drug dependence treatment’) AND (‘buprenorphine’/exp OR buprenorphine OR ‘naltrexone’/exp OR naltrexone OR ‘methadone’/exp OR methadone OR ‘naloxone’/exp OR naloxone) AND (random*:ab,ti OR placebo*:de,ab,ti OR ((double NEXT/1 blind*):ab,ti)) AND [embase]/lim NOT ([embase]/lim AND [medline]/lim) AND [english]/lim

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. (opioid* or opiate* or amphetamine* or methamphetamine* or cocaine or stimulant* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin or cannabinoid or cannabis or marijuana or hash*).ti,ab.
2. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
3. (treatment* or intervention*).ti,ab.
4. 1 and 2 and 3
5. limit 4 to full systematic reviews

### Key Questions 6-7

#### Database: Ovid MEDLINE(R)

1. opioid-related disorders/
2. exp Analgesics, Opioid/ or Drug Overdose/
3. (opioid* or opiate* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin).ti,ab.
4. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
5. Naloxone/
6. (naloxone or evzio or narcan).ti,ab,kw.
7. treatment outcome/
8. (treatment* or intervention*).ti,ab.
9. (dt or th or pc or rh).fs.
10. Randomized Controlled Trials as Topic/
11. double-blind method/ or random allocation/
12. (random* or control* or trial or placebo or blind*).ti,ab,kw.
13. meta-analysis.pt.
14. meta-analysis/ or systematic review/ or meta-analysis as topic/ or “meta analysis (topic)”/ or “systematic review (topic)”/ or exp technology assessment, biomedical/
15. (medline or cochrane or “systematic review” or “meta analysis” or metaanalysis).ti,ab,kw.
16. 1 and (5 or 6)
17. (2 or 3) and 4 and (5 or 6)
18. 16 or 17
19. 18 and (7 or 8 or 9)
20. 19 and (or/10-15)
21. limit 19 to (meta analysis or randomized controlled trial or systematic reviews)
22. 20 or 21
23. limit 22 to (english language and humans)

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. opioid-related disorders/
2. exp Analgesics, Opioid/ or Drug Overdose/
3. (opioid* or opiate* or oxycodone or fentanyl or codeine or hydrocodone or hydromorphone or meperidine or methadone or morphine or heroin).ti,ab.
4. (addict* or abus* or misuse* or mis-use* or misusing or mis-using or “non medical” or extramedical or “extra medical” or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder* or consumption or diversion*).ti,ab.
5. Naloxone/
6. (naloxone or evzio or narcan).ti,ab,kw.
7. treatment outcome/
8. (treatment* or intervention*).ti,ab.
9. (dt or th or pc or rh).fs.
10. 1 and (5 or 6)
11. (2 or 3) and 4 and (5 or 6)
12. 10 or 11
13. 12 and (or/7-9)
14. limit 13 to english language

## Appendix A2 Inclusion and Exclusion Criteria

PICOTS | Inclusion criteria | Exclusion criteria
Conditions | Unhealthy drug use related to:; KQs 4 and 5:; Prescription or illicit opioids; Cannabinoids; Stimulants; Polysubstance use involving prescription or illicit opioids, cannabinoids, or stimulants; KQs 6 and 7:; Prescription or illicit opioids | Other drugs
Populations | Adolescents and adults age 12 years and older; Studies in which participants are identified as engaging in drug use (as defined above); A priori subpopulations at greater risk for drug use or its consequences will be examined based on the following factors: age (particularly young adults ages 18 to 25 years and adolescents ages 12 to 17 years), sex, race/ethnicity, socioeconomic status, pregnancy status, concurrent substance use (tobacco or alcohol), and severity of the disorder | Studies limited to:; Persons with psychotic disorders (e.g., schizophrenia); Psychiatric inpatients, persons who are court-mandated to receive treatment (with the exception of adolescents), persons who are incarcerated); Persons who have failed standard treatments; Persons prescribed opioids, stimulants, or using marijuana under medical supervision without a use disorder or misuse; <70% SUD or unclear if majority is alcohol use
Interventions | KQs 4 and 5:; Psychosocial interventions to reduce drug use, within the following broad categories, or combinations or adaptations of these categories:; Brief interventions; Cognitive behavioral therapy (including relapse prevention); Contingency management; Motivational enhancement therapy; 12-step facilitation therapy; Family interventions (e.g., Adolescent Community Reinforcement Approach or Assertive Continuing Care); Within each approach, there may be variability in specific strategies (e.g., action plans, diaries), delivery method (e.g., face-to-face, electronic, individual, group-based), length of contact (e.g., brief, extended), and the number of contacts (e.g., single, multiple); FDA-approved medications to treat drug use disorder. FDA-approved medications are currently only available for treatment of opioid use disorder: buprenorphine (Probuphine®, Sublocade®, Subutex®, and generic forms), combined buprenorphine and naloxone (Suboxone®, Zubsolv®, Bunavail®), methadone, and extended release naltrexone (Vivitrol®) and oral naltrexone; KQs 6 and 7:; Naloxone (including Evzio®, Narcan®) | Psychosocial interventions not within the specified categories; Psychosocial intervention is not described sufficiently to allow replication; Interventions to prevent drug use initiation; Management of persons prescribed opioids, stimulants, or using marijuana under medical supervision without a use disorder or misuse; Vocational rehabilitation; Housing interventions; Neurostimulation/non-invasive brain stimulation techniques; Medications for treatment of drug use not approved by the FDA for this indication; Community-based, media, or policy interventions; School-based interventions (university-based intervention included); Syringe exchange, supervision injection; HIV-focused interventions; Acupuncture, music therapy, art therapy, mindfulness-based interventions
Comparisons | KQs 4-7:; Included interventions vs:; No intervention; Placebo; Usual care (unless the description of usual care is actually a head-to-head comparison); Waitlist; Attention control (e.g., intervention is similar in format and intensity but is not thought to have a specific effect); Minimal intervention (e.g., no more than one single brief contact per year, brief written materials such as pamphlets); Medication + psychosocial intervention versus psychosocial intervention alone | Comparisons involving non-specified interventions; Included intervention vs. included intervention; Combinations of interventions vs. one intervention, other than specified; Comparisons involving differing intensities of treatments
Settings | KQs 4-7: Any, aside from inpatient/residential or correctional facility | Inpatient/residential facility; Correctional facility
Outcomes | KQs 4a:; Drug use (self-report and/or biologic measures):; Abstinence (use/no use); Frequency and/or quantity of drug use; Severity of drug use disorder (reported as an index measured by a standardized questionnaire, such as the Short Inventory of Problems, Addiction Severity Index, Severity of Dependence Scale, or DSM-V severity); Polysubstance use; Other risky behaviors (e.g., alcohol, tobacco, or other drug use; risky sexual behaviors); KQs4b:; All-cause mortality; Drug-related mortality (intentional and unintentional); Drug-related morbidity (e.g., mental health symptoms/disorders, STI/HIV transmission, hepatitis B or C virus transmission, respiratory infection, cardiovascular complications, stroke, seizure, nonfatal overdose, injuries and accidents, cognitive impairment, visit to emergency department, hospital inpatient stay); Obstetrical/perinatal/neonatal outcomes (e.g., perinatal mortality, preterm labor/delivery, low birth weight, placental abruption, intrauterine growth restriction, preeclampsia, antepartum or postpartum hemorrhage, gestational hypertension, decreased neonate length/head circumference, neonate neurobehavioral effects, congenital anomalies, neonatal abstinence syndrome, neonatal intensive care unit admission, length of neonate hospitalization); Quality of life; Drug-related problems, such as legal problems, social and family relations, employment, and school/educational outcomes; KQ5:; Serious harms at any time point after the intervention began (e.g., death, seizure, cardiovascular event, other medical issue requiring urgent medical treatment, serious obstetrical/perinatal/neonatal complication attributable to included medications); Demoralization due to failed quit attempt; Stigma, labeling, and/or discrimination; Privacy issues (e.g., insurability status); Job loss; Interference with the doctor-patient relationship | Attitudes, knowledge, and beliefs related to drug use; Intention to change behavior
Outcomes, continued | KQ 6:; All-cause mortality; Drug-related mortality (intentional and unintentional); Drug-related morbidity (e.g., nonfatal overdose and associated complications [e.g., seizure, cardiovascular, respiratory events], visit to emergency department, hospital inpatient stay); KQ 7:; Serious harms, including withdrawal, agitation and associated injuries | Not applicable
Outcome assessment timing | At least 3 months after baseline measurement (except for studies in pregnant women, for which shorter lengths of followup will be included) | Not applicable
Study designs | KQs 4-7: Randomized, controlled trials and nonrandomized controlled trials; if evidence from controlled trials is lacking; large cohort and case-control studies for harms of medications | Time series studies, before-after studies with no comparison group, cross-sectional studies, case studies, case series, editorials/commentaries
Countries | Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries that are not categorized as “Very High” on the 2014 Human Development Index
Language | English | Non-English

Abbreviations: DSM-V=Diagnostic and Statistical Manual of Mental Disorders Fifth Edition; FDA=food and drug administration; KQ=key question; PICOT=population, intervention, comparator, outcome, timing, study design/setting; STI=sexually transmitted infection; SUD=substance use disorder.

## Appendix A3 Literature Flow Diagram

*Other sources include reference lists of relevant articles and systematic reviews, reviewer suggestions, etc.; includes background articles.

^†^The numbers in the bottom row do not sum to the total listed because some trials are included in multiple Key Questions or subcategories.

^‡^Two pharmacologic trials have been carried forward from the prior report.^2^

^§^Five psychosocial trials have been carried forward from the prior report.^2^

Note: Key Questions 1-3 are addressed in a separate report.^1^

Abbreviations: FDA = U.S. Food and Drug Administration; KQ = key question.

Appendix A4 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 7763 citations were identified through literature database searches for psychosocial interventions, 7008 citations were identified through literature database searches for pharmacologic interventions, 17 citations were identified from the previous review, and 118 citations were identified through other sources (including lists of relevant articles and systematic reviews, reviewer suggestions; and includes background articles). 10,091 citations were screened after duplicates were removed, and 1,125 articles were reviewed at the full-text level after excluding 8,966 citations based on review of title and abstract. 1,038 full-text articles that were reviewed were excluded for the following reasons: inpatient population (11); incarcerated population (15); <70% drug misuse or likely majority alcohol (13); other wrong population (e.g., schizophrenia focus) (99); non-FDA approved pharmacologic intervention (59); wrong psychosocial intervention (e.g., prevention, housing, etc.) (124); wrong outcome (43); school setting (10); wrong country (10); <3 month followup duration (43); wrong comparator (321); wrong study design for key question (71); systematic review or meta-analysis used as a source document only to identify individual studies (109); not a peer-reviewed study, wrong publication type, nonsystematic review, etc. (87); results reported elsewhere, duplicate results (16); or poor quality (7). 71 intervention trials in 87 publications were included that provide evidence for the key questions, as follows: KQ 4a, b (efficacy of interventions): Pharmacologic interventions: 13 trials in 14 publications for naltrexone, 7 trials in 9 publications for opioid agonist therapy (buprenorphine or methadone). Psychosocial interventions: 27 trials in 6 publications for screen-detected populations, 25 trials in 30 publications for non-screen-detected populations. KQ 5 (harms of interventions): 11 trials for naltrexone, 4 trials for buprenorphine, 4 trials for psychosocial. KQ 6 (efficacy of naloxone): no studies. KQ 7 (harms of naloxone): no studies. The number of included studies does not sum to the total listed because some trials are included in multiple key questions or subcategories. Key Questions 1-3 are addressed in a separate report.

## Appendix A4 List of Included Studies

Babor TF, Christiansen K, Donaldson J, . Brief treatments for cannabis dependence: Findings from a randomized multisite trial. J Consult Clin Psychol. 2004;72(3):455–66. doi: 10.1037/0022-006x.72.3.455. PMID: 15279529.15279529
Baker A, Boggs TG, Lewin TJ. Randomized controlled trial of brief cognitive-behavioural interventions among regular users of amphetamine. Addiction. 2001;96(9):1279–87. doi: 10.1080/09652140120070337. PMID: 11672492.11672492
Baker A, Boggs TG, Lewin TJ. Characteristics of regular amphetamine users and implications for treatment. Drug Alcohol Rev. 2001;20(1):49–56.
Baker A, Lee NK, Claire M, . Brief cognitive behavioural interventions for regular amphetamine users: a step in the right direction. Addiction. 2005;100(3):367–78. doi: 10.1111/j.1360-0443.2005.01002.x. PMID: 15733250.15733250
Bernstein E, Edwards E, Dorfman D, . Screening and brief intervention to reduce marijuana use among youth and young adults in a pediatric emergency department. Acad Emerg Med. 2009;16(11):1174–85. doi: 10.1111/j.1553-2712.2009.00490.x. PMID: 20053238.20053238
Bernstein J, Bernstein E, Tassiopoulos K, . Brief motivational intervention at a clinic visit reduces cocaine and heroin use. Drug Alcohol Depend. 2005;77(1):49–59. doi: 10.1016/j.drugalcdep.2004.07.006. PMID: 15607841.15607841
Blow FC, Walton MA, Bohnert ASB, . A randomized controlled trial of brief interventions to reduce drug use among adults in a low-income urban emergency department: the HealthiER You study. Addiction. 2017;112(8):1395–405. doi: 10.1111/add.13773. PMID: 28127808.28127808
Bonar EE, Walton MA, Barry KL, . Sexual HIV risk behavior outcomes of brief interventions for drug use in an inner-city emergency department: Secondary outcomes from a randomized controlled trial. Drug Alcohol Depend. 2018;183:217–24. doi: 10.1016/j.drugalcdep.2017.10.036. PMID: 29291549.29291549
Bogenschutz MP, Donovan DM, Mandler RN, . Brief intervention for patients with problematic drug use presenting in emergency departments: a randomized clinical trial. JAMA Intern Med. 2014;174(11):1736–45. doi: 10.1001/jamainternmed.2014.4052. PMID: 25179753.25179753
Bogenschutz MP, Donovan DM, Adinoff B, . Design of NIDA CTN Protocol 0047: screening, motivational assessment, referral, and treatment in emergency departments (SMART-ED). Am J Drug Alcohol Abuse. 2011;37(5):417–25. doi: 10.3109/00952990.2011.596971. PMID: 21854285.21854285
Copeland J, Swift W, Roffman R, . A randomized controlled trial of brief cognitive-behavioral interventions for cannabis use disorder. J Subst Abuse Treat. 2001a;21(2):55–64; discussion 5-6. PMID: 11551733.11551733
Copeland J, Swift W, Rees V. Clinical profile of participants in a brief intervention program for cannabis use disorder. J Subst Abuse Treat. 2001b;20(1):45–52. PMID: 11239727.11239727
Cornish JW, Metzger D, Woody GE, . Naltrexone pharmacotherapy for opioid dependent federal probationers. J Subst Abuse Treat. 1997;14(6):529–34. PMID: 9437624.9437624
D’Amico EJ, Parast L, Shadel WG, . Brief motivational interviewing intervention to reduce alcohol and marijuana use for at-risk adolescents in primary care. J Consult Clin Psychol. 2018;86(9):775–86. doi: 10.1037/ccp0000332. PMID: 30138016.30138016
de Dios MA, Herman DS, Britton WB, . Motivational and mindfulness intervention for young adult female marijuana users. J Subst Abuse Treat. 2012;42(1):56–64. doi: 10.1016/j.jsat.2011.08.001. PMID: 21940136.21940136
de Gee EA, Verdurmen JE, Bransen E, . A randomized controlled trial of a brief motivational enhancement for non-treatment-seeking adolescent cannabis users. J Subst Abuse Treat. 2014;47(3):181–8. PMID: 24969735.24969735
Dembo R, Briones-Robinson R, Schmeidler J, . Brief intervention impact on truant youths’ marijuana use: eighteen-month follow-up. J Child Adolesc Subst Abuse. 2016;25(1):18–32. doi: 10.1080/1067828X.2013.872068.
Dupont HB, Candel MJ, Kaplan CD, . Assessing the efficacy of MOTI-4 for reducing the use of cannabis among youth in the Netherlands: A randomized controlled trial. J Subst Abuse Treat. 2016;65:6–12. doi: 10.1016/j.jsat.2015.11.012. PMID: 26780988.26780988
Fischer B, Jones W, Shuper P, . 12-month follow-up of an exploratory ‘brief intervention’ for high-frequency cannabis users among Canadian university students. Subst Abuse Treat Prev Policy. 2012;7:15. doi: 10.1186/1747-597x-7-15. PMID: 22538183.22538183
Fischer B, Dawe M, McGuire F, . Feasibility and impact of brief interventions for frequent cannabis users in Canada. J Subst Abuse Treat. 2013;44(1):132–8. doi: 10.1016/j.jsat.2012.03.006. PMID: 22520278.22520278
Gates PJ, Norberg MM, Copeland J, . Randomized controlled trial of a novel cannabis use intervention delivered by telephone. Addiction. 2012;107(12):2149–58. doi: 10.1111/j.1360-0443.2012.03953.x. PMID: 22632139.22632139
Gelberg L, Andersen RM, Afifi AA, . Project QUIT (Quit Using Drugs Intervention Trial): a randomized controlled trial of a primary care-based multi-component brief intervention to reduce risky drug use. Addiction. 2015;110(11):1777–90. doi: 10.1111/add.12993. PMID: 26471159.26471159
Baumeister SE, Gelberg L, Leake BD, . Effect of a primary care based brief intervention trial among risky drug users on health-related quality of life. Drug Alcohol Depend. 2014;142:254–61. doi: 10.1016/j.drugalcdep.2014.06.034. PMID: 25042213.25042213
Gelberg L, Andersen RM, Rico MW, . A pilot replication of QUIT, a randomized controlled trial of a brief intervention for reducing risky drug use, among Latino primary care patients. Drug Alcohol Depend. 2017;179:433–40. doi: 10.1016/j.drugalcdep.2017.04.022. PMID: 28844733.28844733
Gruber VA, Delucchi KL, Kielstein A, . A randomized trial of 6-month methadone maintenance with standard or minimal counseling versus 21-day methadone detoxification. Drug Alcohol Depend. 2008;94(1-3):199–206. doi: 10.1016/j.drugalcdep.2007.11.021. PMID: 18243585.18243585
Gryczynski J, O’Grady KE, Mitchell SG, . Immediate versus delayed computerized brief intervention for illicit drug misuse. J Addict Med. 2016;10(5):344–51. doi: 10.1097/ADM.0000000000000248. PMID: 27504925.27504925
Guo S, Jiang Z, Wu Y. Efficacy of naltrexone hydrochloride for preventing relapse among opiate-dependent patients after detoxification. Hong Kong J Paediatr. 2001;11(4):2–8+28.
Hollister LE. Clinical evaluation of naltrexone treatment of opiate-dependent individuals. Report of the National Research Council Committee on Clinical Evaluation of Narcotic Antagonists. Arch Gen Psychiatry. 1978;35(3):335–40. PMID: 365122.365122
Humeniuk R, Ali R, Babor T, . A randomized controlled trial of a brief intervention for illicit drugs linked to the alcohol, smoking and substance involvement screening test (ASSIST) in clients recruited from primary health-care settings in four countries. Addiction. 2012;107(5):957–66. doi: 10.1111/j.1360-0443.2011.03740.x. PMID: 22126102.22126102
Jones HE, Wong CJ, Tuten M, . Reinforcement-based therapy: 12-month evaluation of an outpatient drug-free treatment for heroin abusers. Drug Alcohol Depend. 2005;79(2):119–28. doi: 10.1016/j.drugalcdep.2005.01.006. PMID: 16002021.16002021
Kakko J, Svanborg KD, Kreek MJ, . 1-year retention and social function after buprenorphine-assisted relapse prevention treatment for heroin dependence in Sweden: a randomised, placebo-controlled trial. Lancet. 2003;361(9358):662–8. PMID: 12606177.12606177
Krook AL, Brors O, Dahlberg J, . A placebo-controlled study of high dose buprenorphine in opiate dependents waiting for medication-assisted rehabilitation in Oslo, Norway. Addiction. 2002;97(5):533–42. PMID: 12033654.12033654
Krupitsky E, Nunes EV, Ling W, . Injectable extended-release naltrexone for opioid dependence: a double-blind, placebo-controlled, multicentre randomised trial. Lancet. 2011;377(9776):1506–13. doi: 10.1016/S0140-6736(11)60358-9. PMID: 21529928.21529928
Krupitsky E, Zvartau E, Blokhina E, . Naltrexone with or without guanfacine for preventing relapse to opiate addiction in St. Petersburg, Russia. Drug Alcohol Depend. 2013;132(3):674–80. doi: 10.1016/j.drugalcdep.2013.04.021. PMID: 23683793.23683793
Krupitsky EM, Zvartau EE, Masalov DV, . Naltrexone for heroin dependence treatment in St. Petersburg, Russia. J Subst Abuse Treat. 2004;26(4):285–94. PMID: 15182893.15182893
Krupitsky EM, Zvartau EE, Masalov DV, . Naltrexone with or without fluoxetine for preventing relapse to heroin addiction in St. Petersburg, Russia. J Subst Abuse Treat. 2006;31(4):319–28. PMID: 17084785.17084785
Krupski A, Joesch JM, Dunn C, . Testing the effects of brief intervention in primary care for problem drug use in a randomized controlled trial: rationale, design, and methods. Addict Sci Clin Pract. 2012;7:27. doi: 10.1186/1940-0640-7-27. PMID: 23237456.23237456
Krupitsky E, Zvartau E, Blokhina E, . Anhedonia, depression, anxiety, and craving in opiate dependent patients stabilized on oral naltrexone or an extended release naltrexone implant. Am J Drug Alcohol Abuse. 2016;42(5):614–20. PMID: 27436632.27436632
Lee CM, Kilmer JR, Neighbors C, . Indicated prevention for college student marijuana use: a randomized controlled trial. J Consult Clin Psychol. 2013;81(4):702–9. doi: 10.1037/a0033285. PMID: 23750464.23750464
Lee CM, Neighbors C, Kilmer JR, . A brief, web-based personalized feedback selective intervention for college student marijuana use: a randomized clinical trial. Psychol Addict Behav. 2010;24(2):265–73. doi: 10.1037/a0018859. PMID: 20565152.20565152
Lerner A, Sigal M, Bacalu A, . A naltrexone double blind placebo controlled study in Israel. Isr J Psychiatry Relat Sci. 1992;29(1):36–43. PMID: 1568861.1568861
Ling W, Casadonte P, Bigelow G, . Buprenorphine implants for treatment of opioid dependence: a randomized controlled trial. JAMA. 2010;304(14):1576–83. doi: 10.1001/jama.2010.1427. PMID: 20940383.20940383
Litt MD, Kadden RM, Kabela-Cormier E, . Coping skills training and contingency management treatments for marijuana dependence: exploring mechanisms of behavior change. Addiction. 2008;103(4):638–48. doi: 10.1111/j.1360-0443.2008.02137.x. PMID: 18339108.18339108
Kadden RM, Litt MD, Kabela-Cormier E, . Abstinence rates following behavioral treatments for marijuana dependence. Addict Behav. 2007;32(6):1220–36. doi: 10.1016/j.addbeh.2006.08.009. PMID: 16996224.16996224
Litt MD, Kadden RM, Petry NM. Behavioral treatment for marijuana dependence: randomized trial of contingency management and self-efficacy enhancement. Addict Behav. 2013;38(3):1764–75. doi: 10.1016/j.addbeh.2012.08.011. PMID: 23254227.23254227
Litt MD, Kadden RM, Stephens RS. Coping and self-efficacy in marijuana treatment: results from the marijuana treatment project. J Consult Clin Psychol. 2005;73(6):1015–25. doi: 10.1037/0022-006x.73.6.1015. PMID: 16392975.16392975
Lozano BE, Stephens RS, Roffman RA. Abstinence and moderate use goals in the treatment of marijuana dependence. Addiction. 2006;101(11):1589–97. PMID: 17034438.17034438
Marsden J, Stillwell G, Barlow H, . An evaluation of a brief motivational intervention among young ecstasy and cocaine users: no effect on substance and alcohol use outcomes. Addiction. 2006;101(7):1014–26. PMID: 16771893.16771893
Martin G, Copeland J. The adolescent cannabis check-up: randomized trial of a brief intervention for young cannabis users. J Subst Abuse Treat. 2008;34(4):407–14. PMID: 17869051.17869051
Martino S, Ondersma SJ, Forray A, . A randomized controlled trial of screening and brief interventions for substance misuse in reproductive health. Am J Obstet Gynecol. 2018;218(3):322.e1-.e12. doi: 10.1016/j.ajog.2017.12.005. PMID: 29247636.29247636
Mason M, Light J, Campbell L, . Peer network counseling with urban adolescents: a randomized controlled trial with moderate substance users. J Subst Abuse Treat. 2015;58:16–24. doi: 10.1016/j.jsat.2015.06.013. PMID: 26234955.26234955
Mason MJ, Sabo R, Zaharakis NM. Peer network counseling as brief treatment for urban adolescent heavy cannabis users. J Stud Alcohol Drugs. 2017;78(1):152–7. PMID: 27936376.27936376
McCambridge J, Slym RL, Strang J. Randomized controlled trial of motivational interviewing compared with drug information and advice for early intervention among young cannabis users. Addiction. 2008;103(11):1809–18. PMID: 18778385.18778385
McCambridge J, Strang J. The efficacy of single-session motivational interviewing in reducing drug consumption and perceptions of drug-related risk and harm among young people: results from a multi-site cluster randomized trial. Addiction. 2004;99(1):39–52. PMID: 14678061.14678061
McCambridge J, Strang J. Deterioration over time in effect of motivational interviewing in reducing drug consumption and related risk among young people. Addiction. 2005;100(4):470–8. PMID: 15784061.15784061
Ondersma SJ, Svikis DS, Schuster CR. Computer-based brief intervention a randomized trial with postpartum women. Am J Prev Med. 2007;32(3):231–8. PMID: 17236741.17236741
Ondersma SJ, Svikis DS, Thacker C, . Computer-delivered indirect screening and brief intervention for drug use in the perinatal period: a randomized trial. Drug Alcohol Depend. 2018;185:271–7. doi: 10.1016/j.drugalcdep.2017.12.022. PMID: 29482051.29482051
Ondersma SJ, Svikis DS, Thacker LR, . Computer-delivered screening and brief intervention (e-SBI) for postpartum drug use: a randomized trial. J Subst Abuse Treat. 2014;46(1):52–9. doi: 10.1016/j.jsat.2013.07.013. PMID: 24051077.24051077
Palfai TP, Saitz R, Winter M, . Web-based screening and brief intervention for student marijuana use in a university health center: Pilot study to examine the implementation of eCHECKUP TO GO in different contexts. Addict Behav. 2014;39(9):1346–52. doi: 10.1016/j.addbeh.2014.04.025. PMID: 24845164.24845164
Poblete F, Barticevic NA, Zuzulich MS, . A randomized controlled trial of a brief intervention for alcohol and drugs linked to the alcohol, smoking and substance involvement screening test (ASSIST) in primary health care in Chile. Addiction. 2017;112(8):1462–9. doi: 10.1111/add.13808. PMID: 28239995.28239995
Rooke S, Copeland J, Norberg M, . Effectiveness of a self-guided web-based cannabis treatment program: randomized controlled trial. J Med Internet Res. 2013;15(2):e26. doi: 10.2196/jmir.2256. PMID: 23470329.23470329
Rosenthal RN, Ling W, Casadonte P, . Buprenorphine implants for treatment of opioid dependence: randomized comparison to placebo and sublingual buprenorphine/naloxone. Addiction. 2013;108(12):2141–9. doi: 10.1111/add.12315. PMID: 23919595.23919595
Roy-Byrne P, Bumgardner K, Krupski A, . Brief intervention for problem drug use in safety-net primary care settings: a randomized clinical trial. JAMA. 2014;312(5):492–501. doi: 10.1001/jama.2014.7860. PMID: 25096689.25096689
Krupitsky E, Zvartau E, Blokhina E, . Randomized trial of long-acting sustained-release naltrexone implant vs oral naltrexone or placebo for preventing relapse to opioid dependence. Arch Gen Psychiatry. 2012;69(9):973–81. doi: 10.1001/archgenpsychiatry.2012.1a. PMID: 22945623.22945623
Saitz R, Palfai TP, Cheng DM, . Screening and brief intervention for drug use in primary care: the ASPIRE randomized clinical trial. JAMA. 2014;312(5):502–13. doi: 10.1001/jama.2014.7862. PMID: 25096690.25096690
Fuster D, Cheng DM, Wang N, . Brief intervention for daily marijuana users identified by screening in primary care: a subgroup analysis of the ASPIRE randomized clinical trial. Subst Abus. 2016;37(2):336–42. doi: 10.1080/08897077.2015.1075932. PMID: 26453188.26453188
Kim TW, Bernstein J, Cheng DM, . Receipt of addiction treatment as a consequence of a brief intervention for drug use in primary care: a randomized trial. Addiction. 2016;112(5):818–27. doi: 10.1111/add.13701. PMID: 27886657.27886657
San L, Pomarol G, Peri JM, . Follow-up after a six-month maintenance period on naltrexone versus placebo in heroin addicts. Br J Addict. 1991;86(8):983–90. PMID: 1912753.1912753
Schaub MP, Wenger A, Berg O, . A web-based self-help intervention with and without chat counseling to reduce cannabis use in problematic cannabis users: three-arm randomized controlled trial. J Med Internet Res. 2015;17(10):e232. doi: 10.2196/jmir.4860. PMID: 26462848.26462848
Schottenfeld RS, Chawarski MC, Mazlan M. Maintenance treatment with buprenorphine and naltrexone for heroin dependence in Malaysia: a randomised, double-blind, placebo-controlled trial. Lancet. 2008;371(9631):2192–200. doi: 10.1016/S0140-6736(08)60954-X. PMID: 18586174.18586174
Schwartz RP, Jaffe JH, Highfield DA, . A randomized controlled trial of interim methadone maintenance: 10-month follow-up. Drug Alcohol Depend. 2007;86(1):30–6. PMID: 16793221.16793221
Schwartz RP, Highfield DA, Jaffe JH, . A randomized controlled trial of interim methadone maintenance. Arch Gen Psychiatry. 2006;63(1):102–9. PMID: 16389204.16389204
Schwartz RP, Jaffe JH, O’Grady KE, . Interim methadone treatment: impact on arrests. Drug Alcohol Depend. 2009;103(3):148–54. doi: 10.1016/j.drugalcdep.2009.03.007. PMID: 19443133.19443133
Shufman EN, Porat S, Witztum E, . The efficacy of naltrexone in preventing reabuse of heroin after detoxification. Biol Psychiatry. 1994;35(12):935–45. PMID: 8080893.8080893
Stein MD, Hagerty CE, Herman DS, . A brief marijuana intervention for non-treatment-seeking young adult women. J Subst Abuse Treat. 2011;40(2):189–98. doi: 10.1016/j.jsat.2010.11.001. PMID: 21185685.21185685
Stein MD, Herman DS, Anderson BJ. A motivational intervention trial to reduce cocaine use. J Subst Abuse Treat. 2009;36(1):118–25.18657938
Stella L, D’Ambra C, Mazzeo F, . Naltrexone plus benzodiazepine aids abstinence in opioid-dependent patients. Life Sci. 2005;77(21):2717–22. PMID: 15979652.15979652
Stephens RS, Roffman RA, Curtin L. Comparison of extended versus brief treatments for marijuana use. J Consult Clin Psychol. 2000;68(5):898–908. PMID: 11068976.11068976
Stephens RS, Roffman RA, Fearer SA, . The marijuana check-up: promoting change in ambivalent marijuana users. Addiction. 2007;102(6):947–57. doi: 10.1111/j.1360-0443.2007.01821.x. PMID: 17523990.17523990
Tait RJ, McKetin R, Kay-Lambkin F, . Six-month outcomes of a Web-based intervention for users of amphetamine-type stimulants: randomized controlled trial. J Med Internet Res. 2015;17(4):e105. doi: 10.2196/jmir.3778. PMID: 25925801.25925801
Tzilos Wernette G, Plegue M, Kahler CW, . A pilot randomized controlled trial of a computer-delivered brief intervention for substance use and risky sex during pregnancy. J Womens Health (Larchmt). 2018;27(1):83–92. doi: 10.1089/jwh.2017.6408. PMID: 28981379.28981379
Walton MA, Bohnert K, Resko S, . Computer and therapist based brief interventions among cannabis-using adolescents presenting to primary care: one year outcomes. Drug Alcohol Depend. 2013;132(3):646–53. doi: 10.1016/j.drugalcdep.2013.04.020. PMID: 23711998.23711998
Watkins KE, Ober AJ, Lamp K, . Collaborative care for opioid and alcohol use disorders in primary care: the SUMMIT randomized clinical trial. JAMA Intern Med. 2017;177(10):1480–8. doi: 10.1001/jamainternmed.2017.3947. PMID: 28846769.28846769
Woolard R, Baird J, Longabaugh R, . Project reduce: reducing alcohol and marijuana misuse: effects of a brief intervention in the emergency department. Addict Behav. 2013;38(3):1732–9. doi: 10.1016/j.addbeh.2012.09.006. PMID: 23261491.23261491
Yonkers KA, Forray A, Howell HB, . Motivational enhancement therapy coupled with cognitive behavioral therapy versus brief advice: a randomized trial for treatment of hazardous substance use in pregnancy and after delivery. Gen Hosp Psychiatry. 2012;34(5):439–49. doi: 10.1016/j.genhosppsych.2012.06.002. PMID: 22795046.22795046
Zahradnik A, Otto C, Crackau B, . Randomized controlled trial of a brief intervention for problematic prescription drug use in non-treatment-seeking patients. Addiction. 2009;104(1):109–17. doi: 10.1111/j.1360-0443.2008.02421.x. PMID: 19133895.19133895
Otto C, Crackau B, Lohrmann I, . Brief intervention in general hospital for problematic prescription drug use: 12-month outcome. Drug Alcohol Depend. 2009;105(3):221–6. doi: 10.1016/j.drugalcdep.2009.07.010. PMID: 19726140.19726140

## Appendix A5 List of Excluded Studies With Reasons For Exclusion

Abbott PJ, Weller SB, Delaney HD, . Community reinforcement approach in the treatment of opiate addicts. Am J Drug Alcohol Abuse. 1998;24(1):17–30. PMID: 9513627. Excluded: Wrong comparator9513627
Aboujaoude E, Salame WO. Naltrexone: A pan-addiction treatment? CNS Drugs. 2016;30(8):719–33. doi: 10.1007/s40263-016-0373-0. PMID: 27401883. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27401883
Abrahms JL. A Cognitive-behavioural versus nondirective group treatment program for opioid addicted persons: an adjunct to methadone maintenance. Int J Addict. 1979;14(4):503–11. Excluded: Wrong comparator478698
Abramowitz SI, Pantleo PM. The effectiveness of brief methadone withdrawal among urban opiate addicts. Int J Addict. 1972;7(4):629–35. doi: 10.3109/10826087209028116. PMID: 4659588. Excluded: Wrong study design for key question4659588
Achmad YM, Istiqomah AN, Iskandar S, . Integration of methadone maintenance treatment and HIV care for injecting drug users: a cohort study in Bandung, Indonesia. Acta Med Indones. 2009;41: Suppl 1:23–7. PMID: 19920294. Excluded: Wrong study design for key question19920294
Adi Y, Juarez-Garcia A, Wang D, . Oral naltrexone as a treatment for relapse prevention in formerly opioid-dependent drug users: a systematic review and economic evaluation. Health Technol Assess. 2007;11(6):iii–iv, 1–85. PMID: 17280624. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies17280624
Aghataher A, Mahani KN. The effect of rational emotive behavior group therapy on self-concept and depression of self-introduced drug abusers referred to ofogh addiction treatment center in Zarand (Kerman, Iran). Biomed Pharmacol J. 2014;7(1):317–23. doi: 10.13005/bpj/493. Excluded: Wrong country
Ahmad-Abadi FK, Maarefvand M, Aghaei H, . Effectiveness of Satir-informed family-therapy on the codependency of drug dependents’ family members in Iran: A randomized controlled trial. J Evid Inf Soc Work. 2017;14(4):301–10. doi: 10.1080/23761407.2017.1331147. PMID: 28644761. Excluded: Wrong country28644761
Ahmadi J. A controlled trial of buprenorphine treatment for opium dependence: the first experience from Iran. Drug Alcohol Depend. 2002;66(2):111–4. PMID: 11906798. Excluded: <3 month followup duration11906798
Ahmadi J, Ahmadi K, Ohaeri J. Controlled, randomized trial in maintenance treatment of intravenous buprenorphine dependence with naltrexone, methadone or buprenorphine: a novel study. Eur J Clin Invest. 2003;33(9):824–9. PMID: 12925043. Excluded: Wrong comparator12925043
Ahmadi J, Babaee-Beigi M, Alishahi M, . Twelve-month maintenance treatment of opium-dependent patients. J Subst Abuse Treat. 2004;26(1):363–6. PMID: 14698800. Excluded: Wrong study design for key question14698800
Ainscough TS, McNeill A, Strang J, . Contingency management interventions for non-prescribed drug use during treatment for opiate addiction: A systematic review and meta-analysis. Drug Alcohol Depend. 2017;178:318–39. doi: 10.1016/j.drugalcdep.2017.05.028. PMID: 28688295. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28688295
Alessi SM, Hanson T, Wieners M, . Low-cost contingency management in community clinics: delivering incentives partially in group therapy. Exp Clin Psychopharmacol. 2007;15(3):293–300. PMID: 17563216. Excluded: Incarcerated population17563216
Alessi SM, Rash C, Petry NM. Contingency management is efficacious and improves outcomes in cocaine patients with pretreatment marijuana use. Drug Alcohol Depend. 2011;118(1):62–7. doi: 10.1016/j.drugalcdep.2011.03.001. PMID: 21440999. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies21440999
Alexander JF, Parsons BV. Short-term behavioral intervention with delinquent families: Impact on family process and recidivism. J Abnorm Psychol. 1973;81(3):219–25. PMID: 4710043. Excluded: Wrong outcome4710043
Ali S, Tahir B, Jabeen S, . Methadone treatment of opiate addiction: A systematic review of comparative studies. Innov Clin Neurosci. 2017;14(7-8):8–19. PMID: 29616150. Excluded: Wrong comparator29616150
Amass L, Bickel WK, Higgins ST, . Alternate-day dosing during buprenorphine treatment of opioid dependence. Life Sci. 1994;54(17):1215–28. PMID: 8164503. Excluded: Wrong comparator8164503
Amass L, Kamien JB, Mikulich SK. Efficacy of daily and alternate-day dosing regimens with the combination buprenorphine-naloxone tablet. Drug Alcohol Depend. 2000;58(1-2):143–52. PMID: 10669065. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)10669065
Amato L, Davoli M, Perucci CA, . An overview of systematic reviews of the effectiveness of opiate maintenance therapies: available evidence to inform clinical practice and research. J Subst Abuse Treat. 2005;28(4):321–9. PMID: 15925266. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies15925266
Amato L, Minozzi S, Davoli M, . Psychosocial combined with agonist maintenance treatments versus agonist maintenance treatments alone for treatment of opioid dependence. Cochrane Database Syst Rev. 2011 (10):CD004147. doi: 10.1002/14651858.CD004147.pub4. PMID: 21975742. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies21975742
Amato L, Minozzi S, Davoli M, . Psychosocial combined with agonist maintenance treatments versus agonist maintenance treatments alone for treatment of opioid dependence. Cochrane Database Syst Rev. 2004 (4):CD004147. PMID: 15495081. Excluded: Wrong comparator15495081
Andrade LF, Alessi SM, Petry NM. The impact of contingency management on quality of life among cocaine abusers with and without alcohol dependence. Am J Addict. 2012;21(1):47–54. doi: 10.1111/j.1521-0391.2011.00185.x. PMID: 22211346. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies22211346
Anglin M. The efficacy of civil commitment in treating narcotics addiction. J Drug Issues. 1988;18(4):527–45. doi: 10.1177/002204268801800403. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Annis HM, Peachey JE. The use of calcium carbimide in relapse prevention counselling: results of a randomized controlled trial. Br J Addict. 1992;87(1):63–72. PMID: 1543940. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)1543940
Anton RF, Moak DH, Latham P, . Naltrexone combined with either cognitive behavioral or motivational enhancement therapy for alcohol dependence. J Clin Psychopharmacol. 2005;25(4):349–57. PMID: 16012278. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)16012278
Anton RF, O’Malley SS, Ciraulo DA, . Combined pharmacotherapies and behavioral interventions for alcohol dependence: the COMBINE study: a randomized controlled trial. JAMA. 2006;295(17):2003–17. doi: 10.1001/jama.295.17.2003. PMID: 16670409. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)16670409
Arlt VK. Clinician mindfulness, motivational interviewing and treatment outcomes for substance-using adolescents. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2017;78(2-B(E)):No Pagination Specified. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Arndt IO, Dorozynsky L, Woody GE, . Desipramine treatment of cocaine dependence in methadone-maintained patients. Arch Gen Psychiatry. 1992;49(11):888–93. PMID: 1444727. Excluded: Non-FDA approved pharmacologic intervention1444727
Ashraf I, Ashraf S, Asif JA, . Metabolic effects of opiate use during pregnancy: A reappraisal. IMJ. 2016;23(5):481–4. Excluded: Wrong study design for key question
Assadi SM, Radgoodarzi R, Ahmadi-Abhari SA. Baclofen for maintenance treatment of opioid dependence: a randomized double-blind placebo-controlled clinical trial [ISRCTN32121581]. BMC Psychiatry. 2003;3:16. doi: 10.1186/1471-244x-3-16. PMID: 14624703. Excluded: Non-FDA approved pharmacologic intervention14624703
Aubrey LL. Motivational interviewing with adolescents presenting for outpatient substance abuse treatment: ProQuest Information & Learning; 1998. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Avants SK, Margolin A, Holford TR, . A randomized controlled trial of auricular acupuncture for cocaine dependence. Arch Intern Med. 2000;160(15):2305–12. PMID: 10927727. Excluded: Non-FDA approved pharmacologic intervention10927727
Avants SK, Margolin A, Usubiaga MH, . Targeting HIV-related outcomes with intravenous drug users maintained on methadone: a randomized clinical trial of a harm reduction group therapy. J Subst Abuse Treat. 2004;26(2):67–78. PMID: 15050083. Excluded: Wrong comparator15050083
Ayres R, Ingram J, Rees A, . Enhancing motivation within a rapid opioid substitution treatment feasibility RCT: A nested qualitative study. Subst Abuse Treat Prev Policy. 2014;9:44. doi: 10.1186/1747-597X-9-44. PMID: 25407020. Excluded: Wrong outcome25407020
Azrin N, Donohue B, Besalel V, . Youth drug abuse treatment: A controlled outcome study. J Child Adolesc Subst Abuse. 1994;3(3):1–16. Excluded: Wrong comparator
Azrin NH, Acierno R, Kogan ES, . Follow-up results of supportive versus behavioral therapy for illicit drug use. Behav Res Ther. 1996;34(1):41–6. PMID: 8561763. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies8561763
Azrin NH, Donohue B, Teichner GA, . A controlled evaluation and description of individual-cognitive problem solving and family-behavior therapies in dually-diagnosed conduct-disordered and substance-dependent youth. J Child Adolesc Subst Abuse. 2001;11(1):1–43. Excluded: Wrong comparator
Azrin NH, McMahon PT, Donohue B, . Behavior therapy for drug abuse: a controlled treatment outcome study. Behav Res Ther. 1994;32(8):857–66. PMID: 7993330. Excluded: Wrong comparator7993330
Babowitch JD, Antshel KM. Adolescent treatment outcomes for comorbid depression and substance misuse: A systematic review and synthesis of the literature. J Affect Disord. 2016;201:25–33. doi: 10.1016/j.jad.2016.04.018. PMID: 27156096. Excluded: Other wrong population (e.g., schizophrenia focus)27156096
Back SE, Gentilin S, Brady KT. Cognitive-behavioral stress management for individuals with substance use disorders: a pilot study. J Nerv Ment Dis. 2007;195(8):662–8. PMID: 17700298. Excluded: Wrong outcome17700298
Baer JS, Garrett SB, Beadnell B, . Brief motivational intervention with homeless adolescents: evaluating effects on substance use and service utilization. Psychol Addict Behav. 2007;21(4):582–6. PMID: 18072842. Excluded: Other wrong population (e.g., schizophrenia focus)18072842
Baewert A, Gombas W, Schindler SD, . Influence of peak and trough levels of opioid maintenance therapy on driving aptitude. Eur Addict Res. 2007;13(3):127–35. PMID: 17570908. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17570908
Bahrami S, Asghari F. A controlled trial of acceptance and commitment therapy for addiction severity in methamphetamine users: Preliminary study. Arch Psychiatry Psychother. 2017;19(2):49–55. doi: 10.12740/APP/68159. Excluded: Wrong country
Baker TE, Chang G. The use of auricular acupuncture in opioid use disorder: A systematic literature review. Am J Addict. 2016;25(8):592–602. doi: 10.1111/ajad.12453. PMID: 28051842. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28051842
Bale RN, Van Stone WW, Kuldau JM, . Therapeutic communities vs methadone maintenance. A prospective controlled study of narcotic addiction treatment: design and one-year follow-up. Arch Gen Psychiatry. 1980;37(2):179–93. PMID: 7352849. Excluded: Wrong comparator7352849
Ball SA, Martino S, Nich C, . Site matters: multisite randomized trial of motivational enhancement therapy in community drug abuse clinics. J Consult Clin Psychol. 2007;75(4):556–67. PMID: 17663610. Excluded: <70% drug misuse or likely majority alcohol17663610
Bandstra ES. Maternal opioid treatment: Human experimental research (MOTHER) Study: maternal, fetal and neonatal outcomes from secondary analyses. Addiction. 2012;107: Suppl 1:1–4. doi: 10.1111/j.1360-0443.2012.04059.x. PMID: 23106922. Excluded: Wrong comparator23106922
Bandstra ES, Morrow CE, Mansoor E, . Prenatal drug exposure: infant and toddler outcomes. J Addict Dis. 2010;29(2):245–58. doi: 10.1080/10550881003684871. PMID: 20407980. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.20407980
Bao YP, Liu ZM, Epstein DH, . A meta-analysis of retention in methadone maintenance by dose and dosing strategy. Am J Drug Alcohol Abuse. 2009;35(1):28–33. doi: 10.1080/00952990802342899. PMID: 19152203. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies19152203
Baranok N. Treatment of family codependency as a factor promoting remission in opiate addicts. The international psychiatry and behavioral neurosciences yearbook - 2012, Vol 2. Hauppauge, NY: Nova Biomedical Books; US; 2013:275–80. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Barlow J, Sembi S, Gardner F, . An evaluation of the parents under pressure programme: a study protocol for an RCT into its clinical and cost effectiveness. Trials. 2013;14:210. doi: 10.1186/1745-6215-14-210. PMID: 23841920. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.23841920
Barnett PG, Masson CL, Sorensen JL, . Linking opioid-dependent hospital patients to drug treatment: Health care use and costs 6 months after randomization. Addiction. 2006;101(12):1797–804. PMID: 17156179. Excluded: Wrong comparator17156179
Barrett K, Chang YP. Behavioral interventions targeting chronic pain, depression, and substance use disorder in primary care. J Nurs Scholarsh. 2016;48(4):345–53. doi: 10.1111/jnu.12213. PMID: 27149578. Excluded: Other wrong population (e.g., schizophrenia focus)27149578
Batki SL, Washburn AM, Delucchi K, . A controlled trial of fluoxetine in crack cocaine dependence. Drug Alcohol Depend. 1996;41(2):137–42. PMID: 8809502. Excluded: Non-FDA approved pharmacologic intervention8809502
Bawor M, Dennis BB, Bhalerao A, . Sex differences in outcomes of methadone maintenance treatment for opioid use disorder: A systematic review and meta-analysis. CMAJ Open. 2015;3(3):E344–51. doi: 10.9778/cmajo.20140089. PMID: 26457294. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26457294
Beck AK, Forbes E, Baker AL, . Systematic review of SMART recovery: Outcomes, process variables, and implications for research. Psychol Addict Behav. 2017;31(1):1–20. doi: 10.1037/adb0000237. PMID: 28165272. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28165272
Becker SJ, Curry JF. Outpatient interventions for adolescent substance abuse: a quality of evidence review. J Consult Clin Psychol. 2008;76(4):531–43. doi: 10.1037/0022-006X.76.4.531. PMID: 18665683. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies18665683
Beebe KL, Chavoustie S, Ling W, . Buprenorphine implants for the treatment of opioid dependence: Six and 12 month outcomes. Neuropsychopharmacology. 2012;38(2). Excluded: Results reported elsewhere, duplicate results
Beitel M, Genova M, Schuman-Olivier Z, . Reflections by inner-city drug users on a Buddhist-based spirituality-focused therapy: a qualitative study. Am J Orthopsychiatry. 2007;77(1):1–9. PMID: 17352579. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17352579
Bell J. Buprenorphine in the treatment of heroin addiction. Dusunen Adam. 2012;25(2):93–100. doi: 10.5350/DAJPN20122502001. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Bell J, Hall W, Byth K. Changes in criminal activity after entering methadone maintenance. Br J Addict. 1992;87(2):251–8. PMID: 1313321. Excluded: Wrong study design for key question1313321
Bell MD, Laws HB, Petrakis IB. A randomized controlled trial of cognitive remediation and work therapy in the early phase of substance use disorder recovery for older veterans: Neurocognitive and substance use outcomes. Psychiatr Rehabil J. 2017;40(1):94–102. doi: 10.1037/prj0000211. PMID: 27732034. Excluded: Wrong comparator27732034
Bellack AS, Bennett ME, Gearon JS, . A randomized clinical trial of a new behavioral treatment for drug abuse in people with severe and persistent mental illness. Arch Gen Psychiatry. 2006;63(4):426–32. doi: 10.1001/archpsyc.63.4.426. PMID: 16585472. Excluded: Other wrong population (e.g., schizophrenia focus)16585472
Benishek LA, Dugosh KL, Kirby KC, . Prize-based contingency management for the treatment of substance abusers: a meta-analysis. Addiction. 2014;109(9):1426–36. doi: 10.1111/add.12589. PMID: 24750232. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24750232
Bennett GA, Withers J, Thomas PW, . A randomised trial of early warning signs relapse prevention training in the treatment of alcohol dependence. Addict Behav. 2005;30(6):1111–24. doi: 10.1016/j.addbeh.2004.10.008. PMID: 15925121. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)15925121
Berman AH, Wennberg P, Sinadinovic K. Changes in mental and physical well-being among problematic alcohol and drug users in 12-month Internet-based intervention trials. Psychol Addict Behav. 2015;29(1):97–105. doi: 10.1037/a0038420. PMID: 25664387. Excluded: <70% drug misuse or likely majority alcohol25664387
Bernard JP, Havnes I, Slordal L, . Methadone-related deaths in Norway. Forensic Sci Int. 2013;224(1-3):111–6. doi: 10.1016/j.forsciint.2012.11.010. PMID: 23246070. Excluded: Wrong study design for key question23246070
Bernstein SL, D’Onofrio G. Screening, treatment initiation, and referral for substance use disorders. Addict Sci Clin Pract. 2017;12(1):18. doi: 10.1186/s13722-017-0083-z. PMID: 28780906. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28780906
Bertrand K, Roy E, Vaillancourt E, . Randomized controlled trial of motivational interviewing for reducing injection risk behaviours among people who inject drugs. Addiction. 2015;110(5):832–41. doi: 10.1111/add.12867. PMID: 25641704. Excluded: Wrong comparator25641704
Bickel WK, Amass L, Higgins ST, . Effects of adding behavioral treatment to opioid detoxification with buprenorphine. J Consult Clin Psychol. 1997;65(5):803–10. PMID: 9337499. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)9337499
Bickel WK, Marsch LA, Buchhalter AR, . Computerized behavior therapy for opioid-dependent outpatients: a randomized controlled trial. Exp Clin Psychopharmacol. 2008;16(2):132–43. doi: 10.1037/1064-1297.16.2.132. PMID: 18489017. Excluded: Wrong comparator18489017
Binder T, Vavrinkova B. Prospective randomised comparative study of the effect of buprenorphine, methadone and heroin on the course of pregnancy, birthweight of newborns, early postpartum adaptation and course of the neonatal abstinence syndrome (NAS) in women followed up in the outpatient department. Neuro Endocrinol Lett. 2008;29(1):80–6. PMID: 18283247. Excluded: Wrong comparator18283247
Blokhina E, Krupitsky E, Bushara N, . Implantable and oral naltrexone for preventing relapse in opiate addicts: A psychometric evaluation. Drug Alcohol Depend. 2015;146(14). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Blow F, Bohnert AS, Ignacio R, . Efficacy of computer and therapist brief interventions for drug users. Drug Alcohol Depend. 2015;156(13). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Blumberg D, Carrizales F, Kazanis W, . Changes in quality of life in cocaine-dependent participants provided treatment with buprenorphine + naloxone & extended release naltrexone. Drug Alcohol Depend. 2017;171. Excluded: Non-FDA approved pharmacologic intervention
Bogenschutz MP, Rice SL, Tonigan J, . 12-step facilitation for the dually diagnosed: A randomized clinical trial. J Subst Abuse Treat. 2014;46(4):403–11. doi: 10.1016/j.jsat.2013.12.009. PMID: 24462479. Excluded: Other wrong population (e.g., schizophrenia focus)24462479
Bohnert AS, Blow F, Cunningham R, . A randomized clinical trial of a behavioral intervention to reduce opioid overdose risk behavior. Drug Alcohol Depend. 2015;156(13). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Bohnert ASB, Bonar EE, Cunningham R, . A pilot randomized clinical trial of an intervention to reduce overdose risk behaviors among emergency department patients at risk for prescription opioid overdose. Drug Alcohol Depend. 2016;163:40–7. doi: 10.1016/j.drugalcdep.2016.03.018. PMID: 27062245. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)27062245
Bonsack C, Gibellini Manetti S, Favrod J, . Motivational intervention to reduce cannabis use in young people with psychosis: a randomized controlled trial. Psychother Psychosom. 2011;80(5):287–97. doi: 10.1159/000323466. PMID: 21646823. Excluded: Other wrong population (e.g., schizophrenia focus)21646823
Bowen S, Chawla N, Collins SE, . Mindfulness-based relapse prevention for substance use disorders: a pilot efficacy trial. Substance Abuse. 2009;30(4):295–305. doi: 10.1080/08897070903250084. PMID: 19904665. Excluded: Wrong comparator19904665
Bowen S, Witkiewitz K, Clifasefi SL, . Relative efficacy of mindfulness-based relapse prevention, standard relapse prevention, and treatment as usual for substance use disorders: a randomized clinical trial. JAMA Psychiatry. 2014;71(5):547–56. PMID: 24647726. Excluded: Wrong comparator24647726
Bradford A, Hurley F, Golondzowski O, . Interim report on clinic intake and safety data collected from 17 NIDA-funded naltrexone studies. NIDA Res Monogr. 1976 (9):163–71. PMID: 794717. Excluded: Wrong study design for key question794717
Brewer S, Godley MD, Hulvershorn LA. Treating mental health and substance use disorders in adolescents: What is on the menu? Curr Psychiatry Rep. 2017;19(1)doi: 10.1007/s11920-017-0755-0. PMID: 28120255. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.28120255
Brigham GS, Slesnick N, Winhusen TM, . A randomized pilot clinical trial to evaluate the efficacy of community reinforcement and family training for treatment retention (CRAFT-T) for improving outcomes for patients completing opioid detoxification. Drug Alcohol Depend. 2014;138:240–3. doi: 10.1016/j.drugalcdep.2014.02.013. PMID: 24656054. Excluded: Other wrong population (e.g., schizophrenia focus)24656054
Britton PC, Conner KR. Suicide attempts within 12 months of treatment for substance use disorders. Suicide Life Threat Behav. 2010;40(1):14–21. doi: 10.1521/suli.2010.40.1.14. PMID: 20170258. Excluded: Wrong study design for key question20170258
Brogly SB, Saia KA, Walley AY, . Prenatal buprenorphine versus methadone exposure and neonatal outcomes: systematic review and meta-analysis. Am J Epidemiol. 2014;180(7):673–86. doi: 10.1093/aje/kwu190. PMID: 25150272. Excluded: Wrong comparator25150272
Brooner RK, Kidorf MS, King VL, . Behavioral contingencies improve counseling attendance in an adaptive treatment model. J Subst Abuse Treat. 2004;27(3):223–32. PMID: 15501375. Excluded: Wrong comparator15501375
Brown HL, Britton KA, Mahaffey D, . Methadone maintenance in pregnancy: a reappraisal. Am J Obstet Gynecol. 1998;179(2):459–63. PMID: 9731853. Excluded: Wrong study design for key question9731853
Brown SM. A mindfulness-based intervention to improve family functioning among child welfare-involved families with substance use. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2016;77(11-A(E)):No Pagination Specified. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Brown TG, Seraganian P, Tremblay J, . Matching substance abuse aftercare treatments to client characteristics. Addict Behav. 2002;27(4):585–604. PMID: 12188594. Excluded: Wrong comparator12188594
Brown TL, Henggeler SW, Schoenwald SK, . Multisystemic treatment of substance abusing and dependent juvenile delinquents: Effects on school attendance at posttreatment and 6-month follow-up. Child Serv Soc Pol Res Pract. 1999;2(2):81–93. Excluded: Other wrong population (e.g., schizophrenia focus)
Budney AJ, Higgins ST, Radonovich KJ, . Adding voucher-based incentives to coping skills and motivational enhancement improves outcomes during treatment for marijuana dependence. J Consult Clin Psychol. 2000;68(6):1051–61. PMID: 11142539. Excluded: Wrong comparator11142539
Budney AJ, Higgins ST, Radotrovich KJ, . Abstinence-based vouchers increase marijuana abstinence during outpatient treatment for marijuana dependence. NIDA Res Monogr. 2000. Excluded: Wrong comparator
Budney AJ, Moore BA, Rocha HL, . Clinical trial of abstinence-based vouchers and cognitive-behavioral therapy for cannabis dependence. J Consult Clin Psychol. 2006;74(2):307–16. doi: 10.1037/0022-006x.4.2.307. PMID: 16649875. Excluded: Wrong comparator16649875
Budney AJ, Vandrey RG, Stanger C. [Pharmacological and psychosocial interventions for cannabis use disorders]. Rev Bras Psiquiatr. 2010;32: Suppl 1:S46–55. PMID: 20512270. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies20512270
Burch AE, Rash CJ, Petry NM. Cocaine-using substance abuse treatment patients with and without HIV respond well to contingency management treatment. J Subst Abuse Treat. 2017;77:21–5. doi: 10.1016/j.jsat.2017.03.001. PMID: 28476266. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28476266
Busch S, Hawk K, Fiellin D, . Health service use in a randomized clinical trial comparing three methods of emergency department interventions for opioid dependence. Drug Alcohol Depend. 2015;156(13). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Calsyn DA, Crits-Christoph P, Hatch-Maillette MA, . Reducing sex under the influence of drugs or alcohol for patients in substance abuse treatment. Addiction. 2010;105(1):100–8. doi: 10.1111/j.1360-0443.2009.02812.x. PMID: 20078464. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)20078464
Calsyn DA, Hatch-Maillette M, Tross S, . Motivational and skills training HIV/sexually transmitted infection sexual risk reduction groups for men. J Subst Abuse Treat. 2009;37(2):138–50. doi: 10.1016/j.jsat.2008.11.008. PMID: 19150206. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19150206
Campbell AN, Nunes EV, Matthews AG, . "Internet-delivered treatment for substance abuse: A multisite randomized controlled trial": Correction. Am J Psychiatry. 2014;171(12):1339–40. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Campbell AN, Nunes EV, Matthews AG, . Internet-delivered treatment for substance abuse: a multisite randomized controlled trial. Am J Psychiatry. 2014;171(6):683–90. doi: 10.1176/appi.ajp.2014.13081055. PMID: 24700332. Excluded: Wrong comparator24700332
Campbell AN, Nunes EV, Pavlicova M, . Gender-based outcomes and acceptability of a computer-assisted psychosocial intervention for substance use disorders. J Subst Abuse Treat. 2015;53:9–15. doi: 10.1016/j.jsat.2014.12.006. PMID: 25613105. Excluded: Wrong outcome25613105
Carney T, Myers BJ, Louw J, . Brief school-based interventions and behavioural outcomes for substance-using adolescents. Cochrane Database Syst Rev. 2016 (1)doi: 10.1002/14651858.CD008969.pub3. PMID: 26787125. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26787125
Carroll KM, Ball SA, Martino S, . Computer-assisted delivery of cognitive-behavioral therapy for addiction: a randomized trial of CBT4CBT. Am J Psychiatry. 2008;165(7):881–8. doi: 10.1176/appi.ajp.2008.07111835. PMID: 18450927. Excluded: Wrong comparator18450927
Carroll KM, Ball SA, Martino S, . Enduring effects of a computer-assisted training program for cognitive behavioral therapy: A 6-month follow-up of CBT4CBT. Drug Alcohol Depend. 2009;100(1-2):178–81. doi: 10.1016/j.drugalcdep.2008.09.015. PMID: 19041197. Excluded: Wrong comparator19041197
Carroll KM, Ball SA, Nich C, . Motivational interviewing to improve treatment engagement and outcome in individuals seeking treatment for substance abuse: a multisite effectiveness study. Drug Alcohol Depend. 2006;81(3):301–12. doi: 10.1016/j.drugalcdep.2005.08.002. PMID: 16169159. Excluded: <70% drug misuse or likely majority alcohol16169159
Carroll KM, Ball SA, Nich C, . Targeting behavioral therapies to enhance naltrexone treatment of opioid dependence: efficacy of contingency management and significant other involvement. Arch Gen Psychiatry. 2001;58(8):755–61. PMID: 11483141. Excluded: Wrong comparator11483141
Carroll KM, Easton CJ, Nich C, . The use of contingency management and motivational/skills-building therapy to treat young adults with marijuana dependence. J Consult Clin Psychol. 2006;74(5):955–66. doi: 10.1037/0022-006x.74.5.955. PMID: 17032099. Excluded: Wrong comparator17032099
Carroll KM, Martino S, Ball SA, . A multisite randomized effectiveness trial of motivational enhancement therapy for Spanish-speaking substance users. J Consult Clin Psychol. 2009;77(5):993–9. doi: 10.1037/a0016489. PMID: 19803579. Excluded: <70% drug misuse or likely majority alcohol19803579
Carroll KM, Nich C, Ball SA, . Treatment of cocaine and alcohol dependence with psychotherapy and disulfiram. Addiction. 1998;93(5):713–27. PMID: 9692270. Excluded: Wrong comparator9692270
Carroll KM, Onken LS. Behavioral therapies for drug abuse. Am J Psychiatry. 2005;162(8):1452–60. doi: 10.1176/appi.ajp.162.8.1452. PMID: 16055766. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.16055766
Carroll KM, Rounsaville BJ, Nich C, . One-year follow-up of psychotherapy and pharmacotherapy for cocaine dependence. Delayed emergence of psychotherapy effects. Arch Gen Psychiatry. 1994;51(12):989–97. PMID: 7979888. Excluded: Wrong comparator7979888
Carroll KM, Sinha R, Nich C, . Contingency management to enhance naltrexone treatment of opioid dependence: a randomized clinical trial of reinforcement magnitude. Exp Clin Psychopharmacol. 2002;10(1):54–63. PMID: 11866252. Excluded: Wrong comparator11866252
Castells X, Cunill R, PerezMana C, . Psychostimulant drugs for cocaine dependence. Cochrane Database Syst Rev. 2016 (9)doi: 10.1002/14651858.CD007380.pub4. PMID: 27670244. Excluded: Non-FDA approved pharmacologic intervention27670244
Centers for Disease C, Prevention. Integrated prevention services for HIV infection, viral hepatitis, sexually transmitted diseases, and tuberculosis for persons who use drugs illicitly: summary guidance from CDC and the U.S. Department of Health and Human Services. MMWR Recomm Rep. 2012;61(RR-5):1–40. PMID: 23135062. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.23135062
Chaparro LE, Furlan AD, Deshpande A, . Opioids compared to placebo or other treatments for chronic low-back pain. Cochrane Database Syst Rev. 2013 (8):CD004959. doi: 10.1002/14651858.CD004959.pub4. PMID: 23983011. Excluded: Other wrong population (e.g., schizophrenia focus)23983011
Chaparro LE, Furlan AD, Deshpande A, . Opioids compared with placebo or other treatments for chronic low back pain: an update of the Cochrane review.[Reprint of Cochrane Database Syst Rev. 2013;8:CD004959; PMID: 23983011]. Spine. 2014;39(7):556–63. doi: 10.1097/BRS.0000000000000249. PMID: 24480962. Excluded: Other wrong population (e.g., schizophrenia focus)24480962
Chatters R, Cooper K, Day E, . Psychological and psychosocial interventions for cannabis cessation in adults: A systematic review. Addict Res Theory. 2016;24(2):93–110. doi: 10.3109/16066359.2015.1073719. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Chawarski MC, Mazlan M, Schottenfeld RS. Behavioral drug and HIV risk reduction counseling (BDRC) with abstinence-contingent take-home buprenorphine: a pilot randomized clinical trial. Drug Alcohol Depend. 2008;94(1-3):281–4. doi: 10.1016/j.drugalcdep.2007.11.008. PMID: 18164145. Excluded: Wrong comparator18164145
Chawarski MC, Zhou W, Schottenfeld RS. Behavioral drug and HIV risk reduction counseling (BDRC) in MMT programs in Wuhan, China: a pilot randomized clinical trial. Drug Alcohol Depend. 2011;115(3):237–9. doi: 10.1016/j.drugalcdep.2010.09.024. PMID: 21159452. Excluded: Wrong comparator21159452
Chen W, Hong Y, Zou X, . Effectiveness of prize-based contingency management in a methadone maintenance program in China. Drug Alcohol Depend. 2013;133(1):270–4. doi: 10.1016/j.drugalcdep.2013.05.028. PMID: 23831409. Excluded: Wrong comparator23831409
Cheng AL, Lin H, Kasprow W, . Impact of supported housing on clinical outcomes: analysis of a randomized trial using multiple imputation technique. J Nerv Ment Dis. 2007;195(1):83–8. PMID: 17220745. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17220745
Chiesa A, Serretti A. Are mindfulness-based interventions effective for substance use disorders? A systematic review of the evidence. Subst Use Misuse. 2014;49(5):492–512. doi: 10.3109/10826084.2013.770027. PMID: 23461667. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies23461667
Chindalore VL, Craven RA, Yu KP, . Adding ultralow-dose naltrexone to oxycodone enhances and prolongs analgesia: a randomized, controlled trial of Oxytrex. J Pain. 2005;6(6):392–9. PMID: 15943961. Excluded: Other wrong population (e.g., schizophrenia focus)15943961
Chopra MP, Landes RD, Gatchalian KM, . Buprenorphine medication versus voucher contingencies in promoting abstinence from opioids and cocaine. Exp Clin Psychopharmacol. 2009;17(4):226–36. doi: 10.1037/a0016597. PMID: 19653788. Excluded: Wrong comparator19653788
Christoff AO, Boerngen-Lacerda R. Reducing substance involvement in college students: a three-arm parallel-group randomized controlled trial of a computer-based intervention. Addict Behav. 2015;45:164–71. doi: 10.1016/j.addbeh.2015.01.019. PMID: 25679364. Excluded: Wrong country25679364
Church SH, Rothenberg JL, Sullivan MA, . Concurrent substance use and outcome in combined behavioral and naltrexone therapy for opiate dependence. Am J Drug Alcohol Abuse. 2001;27(3):441–52. PMID: 11506261. Excluded: Wrong study design for key question11506261
Chutuape MA, Silverman K, Stitzer ML. Effects of urine testing frequency on outcome in a methadone take-home contingency program. Drug Alcohol Depend. 2001;62(1):69–76. PMID: 11173169. Excluded: Wrong comparator11173169
Cochran G, Field C, Karp J, . A community pharmacy intervention for opioid medication misuse: a pilot randomized clinical trial. J Am Pharm Assoc. 2018 PMID: 29691197. Excluded: Wrong comparator29691197
Cochran G, Stitzer M, Campbell AN, . Web-based treatment for substance use disorders: differential effects by primary substance. Addict Behav. 2015;45:191–4. doi: 10.1016/j.addbeh.2015.02.002. PMID: 25697725. Excluded: <70% drug misuse or likely majority alcohol25697725
Coffin PO, Santos GM, Hern J, . Extended-release naltrexone for methamphetamine dependence among men who have sex with men: a randomized placebo-controlled trial. Addiction. 2018;113(2):268–78. doi: 10.1111/add.13950. PMID: 28734107. Excluded: Non-FDA approved pharmacologic intervention28734107
Comer SD, Sullivan MA, Yu E, . Injectable, sustained-release naltrexone for the treatment of opioid dependence: a randomized, placebo-controlled trial. Arch Gen Psychiatry. 2006;63(2):210–8. PMID: 16461865. Excluded: <3 month followup duration16461865
Comulada WS, Weiss RE, Cumberland W, . Reductions in drug use among young people living with HIV. Am J Drug Alcohol Abuse. 2007;33(3):493–501. PMID: 17613977. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17613977
Conrod PJ, Stewart SH, Pihl RO, . Efficacy of brief coping skills interventions that match different personality profiles of female substance abusers. Psychol Addict Behav. 2000;14(3):231–42. PMID: 10998949. Excluded: Other wrong population (e.g., schizophrenia focus)10998949
Cooper K, Chatters R, Kaltenthaler E, . Psychological and psychosocial interventions for cannabis cessation in adults: A systematic review short report. Health Technol Assess. 2015;19(56):1–130. doi: 10.3310/hta19560. PMID: 26202542. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26202542
Cornelius JR, Bukstein OG, Wood DS, . Double-blind placebo-controlled trial of fluoxetine in adolescents with comorbid major depression and an alcohol use disorder. Addict Behav. 2009;34(10):905–9. doi: 10.1016/j.addbeh.2009.03.008. PMID: 19321268. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19321268
Courbasson C, Nishikawa Y, Dixon L. Outcome of dialectical behaviour therapy for concurrent eating and substance use disorders. Clin Psychol Psychother. 2012;19(5):434–49. doi: 10.1002/cpp.748. PMID: 21416557. Excluded: Other wrong population (e.g., schizophrenia focus)21416557
Crits-Christoph P, Ring-Kurtz S, McClure B, . A randomized controlled study of a web-based performance improvement system for substance abuse treatment providers. J Subst Abuse Treat. 2010;38(3):251–62. doi: 10.1016/j.jsat.2010.01.001. PMID: 20116964. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)20116964
Cropsey KL, Lane PS, Hale GJ, . Results of a pilot randomized controlled trial of buprenorphine for opioid dependent women in the criminal justice system. Drug Alcohol Depend. 2011;119(3):172–8. doi: 10.1016/j.drugalcdep.2011.06.021. PMID: 21782352. Excluded: Incarcerated population21782352
Curran S, Savage C. Patient response to naltrexone: issues of acceptance, treatment effects, and frequency of administration. NIDA Res Monogr. 1976 (9):67–9. PMID: 794722. Excluded: Wrong study design for key question794722
Czuchry M, Newbern-McFarland D, Dansereau DF. Visual representation tools for improving addiction treatment outcomes. J Psychoactive Drugs. 2009;41(2):181–7. PMID: 19705680. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19705680
Dakof GA, Henderson CE, Rowe CL, . A randomized clinical trial of family therapy in juvenile drug court. J Fam Psychol. 2015;29(2):232–41. doi: 10.1037/fam0000053. PMID: 25621927. Excluded: Wrong comparator25621927
D’Amico EJ, Hunter SB, Miles JN, . A randomized controlled trial of a group motivational interviewing intervention for adolescents with a first time alcohol or drug offense. J Subst Abuse Treat. 2013;45(5):400–8. doi: 10.1016/j.jsat.2013.06.005. PMID: 23891459. Excluded: Other wrong population (e.g., schizophrenia focus)23891459
D’Amico EJ, Miles JN, Stern SA, . Brief motivational interviewing for teens at risk of substance use consequences: a randomized pilot study in a primary care clinic. J Subst Abuse Treat. 2008;35(1):53–61. PMID: 18037603. Excluded: Poor quality18037603
Danaee-far M, Maarefvand M, Rafiey H. Effectiveness of a brief home-based social work motivational intervention for male methamphetamine users in Tehran: A randomized clinical trial. Subst Use Misuse. 2016;51(14):1863–9. doi: 10.1080/10826084.2016.1200620. PMID: 27608368. Excluded: Wrong country27608368
Danielson CK. Reducing risk for substance use problems among adolescents with a child maltreatment history. J Am Acad Child Adolesc Psychiatry. 2016;Conference: 63rd annual meeting of the american academy of child and adolescent psychiatry. United states. Conference start:. 20161024. Conference end: 20161029 55(10 Supplement 1):S293. Excluded: Other wrong population (e.g., schizophrenia focus)
Danielson CK, McCart MR, Walsh K, . Reducing substance use risk and mental health problems among sexually assaulted adolescents: a pilot randomized controlled trial. J Fam Psychol. 2012;26(4):628–35. doi: 10.1037/a0028862. PMID: 22686269. Excluded: Other wrong population (e.g., schizophrenia focus)22686269
Darker CD, Sweeney BP, Barry JM, . Psychosocial interventions for benzodiazepine harmful use, abuse or dependence. Cochrane Database Syst Rev. 2015 (5)doi: 10.1002/14651858.CD009652.pub2. PMID: 26106751. Excluded: Other wrong population (e.g., schizophrenia focus)26106751
Das JK, Salam RA, Arshad A, . Interventions for adolescent substance abuse: An overview of systematic reviews. J Adolesc Health. 2016;59(4s):S61–s75. doi: 10.1016/j.jadohealth.2016.06.021. PMID: 27664597. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27664597
Davis ML, Powers MB, Handelsman P, . Behavioral therapies for treatment-seeking cannabis users: a meta-analysis of randomized controlled trials. Eval Health Prof. 2015;38(1):94–114. doi: 10.1177/0163278714529970. PMID: 24695072. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24695072
Deady M, Teesson M, Kay-Lambkin FJ. Treatments for co-occurring depression and substance use in young people: a systematic review. Curr Drug Abuse Rev. 2014;7(1):3–17. PMID: 25323123. Excluded: Other wrong population (e.g., schizophrenia focus)25323123
Dees SM, Dansereau DF, Simpson DD. Mapping-enhanced drug abuse counseling: urinalysis results in the first year of methadone treatment. J Subst Abuse Treat. 1997;14(1):45–54. PMID: 9218236. Excluded: Wrong comparator9218236
DeMarce JM, Stephens RS, Roffman RA. Psychological distress and marijuana use before and after treatment: testing cognitive-behavioral matching hypotheses. Addict Behav. 2005;30(5):1055–9. PMID: 15893104. Excluded: Wrong outcome15893104
Dennis BB, Bawor M, Paul J, . Pain and opioid addiction: A systematic review and evaluation of pain measurement in patients with opioid dependence on methadone maintenance treatment. Curr Drug Abuse Rev. 2016;9(1):49–60. PMID: 27021147. Excluded: Wrong outcome27021147
Dennis M, Godley SH, Diamond G, . The cannabis youth treatment (CYT) study: main findings from two randomized trials. J Subst Abuse Treat. 2004;27(3):197–213. doi: 10.1016/j.jsat.2003.09.005. PMID: 15501373. Excluded: Wrong comparator15501373
Diakogiannis IA, Steinberg M, Kosten TR. Mazindol treatment of cocaine abuse. A double-blind investigation. NIDA Res Monogr. 1990;105:514. PMID: 1876105. Excluded: Non-FDA approved pharmacologic intervention1876105
Dole VP, Robinson JW, Orraca J, . Methadone treatment of randomly selected criminal addicts. N Engl J Med. 1969;280(25):1372–5. PMID: 4890477. Excluded: Incarcerated population4890477
D’Onofrio G, Chawarski MC, O’Connor PG, . Emergency department-initiated buprenorphine for opioid dependence with continuation in primary care: Outcomes during and after treatment. Acad Emerg Med. 2017;24. Excluded: Results reported elsewhere, duplicate results
D’Onofrio G, Chawarski MC, O’Connor PG, . Emergency department-initiated buprenorphine for opioid dependence with continuation in primary care: Outcomes during and after intervention. J Gen Intern Med. 2017;32(6):660–6. doi: 10.1007/s11606-017-3993-2. PMID: 28194688. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28194688
D’Onofrio G, O’Connor P, Pantalon M, . A randomized clinical trial of emergency department initiated treatment for opioid dependence: Two and six month outcomes. Drug Alcohol Depend. 2015;156(13). Excluded: Results reported elsewhere, duplicate results
D’Onofrio G, O’Connor PG, Pantalon MV, . Emergency department-initiated buprenorphine/naloxone treatment for opioid dependence: A randomized clinical trial. JAMA. 2015;313(16):1636–44. doi: 10.1001/jama.2015.3474. PMID: 25919527. Excluded: <3 month followup duration25919527
Donovan DM, Daley DC, Brigham GS, . Stimulant abuser groups to engage in 12-step: A multisite trial in the National Institute on Drug Abuse clinical trials network. J Subst Abuse Treat. 2013;44(1):103–14. doi: 10.1016/j.jsat.2012.04.004. PMID: 22657748. Excluded: Wrong comparator22657748
Dowling NA, Merkouris SS, Lorains FK. Interventions for comorbid problem gambling and psychiatric disorders: Advancing a developing field of research. Addict Behav. 2016;58:21–30. doi: 10.1016/j.addbeh.2016.02.012. PMID: 26900888. Excluded: Other wrong population (e.g., schizophrenia focus)26900888
Downey KK, Helmus TC, Schuster CR. Treatment of heroin-dependent poly-drug abusers with contingency management and buprenorphine maintenance. Exp Clin Psychopharmacol. 2000;8(2):176–84. PMID: 10843300. Excluded: Wrong comparator10843300
Drummond C, Perryman K. Psychosocial interventions in pharmacotherapy of opioid dependence: a literature review. World Health Organization. London, UK: 2007. http://www.who.int/substance_abuse/activities/psychosocial_interventions.pdf?ua=1 Accessed September 10, 2018. Excluded: Wrong comparator
Dugosh K, Abraham A, Seymour B, . A systematic review on the use of psychosocial interventions in conjunction with medications for the treatment of opioid addiction. J Addict Med. 2016;10(2):93–103. doi: 10.1097/ADM.0000000000000193. PMID: 26808307. Excluded: Wrong comparator26808307
Dunn C, Deroo L, Rivara FP. The use of brief interventions adapted from motivational interviewing across behavioral domains: a systematic review. Addiction. 2001;96(12):1725–42. PMID: 11784466. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies11784466
Dunn K, DeFulio A, Everly JJ, . Employment-based reinforcement of adherence to oral naltrexone in unemployed injection drug users: 12-month outcomes. Psychol Addict Behav. 2015;29(2):270–6. doi: 10.1037/adb0000010. PMID: 25134047. Excluded: Wrong comparator25134047
Dunn KE, Defulio A, Everly JJ, . Employment-based reinforcement of adherence to oral naltrexone treatment in unemployed injection drug users. Exp Clin Psychopharmacol. 2013;21(1):74–83. doi: 10.1037/a0030743. PMID: 23205722. Excluded: Wrong comparator23205722
Dupont HB, Candel M, Lemmens P, . Stages of Change Model has Limited Value in Explaining the Change in Use of Cannabis among Adolescent Participants in an Efficacious Motivational Interviewing Intervention. J Psychoactive Drugs. 2017;49(5):363–72. doi: 10.1080/02791072.2017.1325030. PMID: 28548619. Excluded: Wrong outcome28548619
Dutra L, Stathopoulou G, Basden SL, . A meta-analytic review of psychosocial interventions for substance use disorders. Am J Psychiatry. 2008;165(2):179–87. doi: 10.1176/appi.ajp.2007.06111851. PMID: 18198270. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies18198270
Easton C, Swan S, Sinha R. Motivation to change substance use among offenders of domestic violence. J Subst Abuse Treat. 2000;19(1):1–5. PMID: 10867294. Excluded: Other wrong population (e.g., schizophrenia focus)10867294
Eccleston C, Fisher E, Thomas KH, . Interventions for the reduction of prescribed opioid use in chronic non-cancer pain. Cochrane Database Syst Rev. 2017 (11)doi: 10.1002/14651858.CD010323.pub3. PMID: 29130474. Excluded: Other wrong population (e.g., schizophrenia focus)29130474
ED-based counseling sessions reduce risky opioid use among certain patients. ED Management. 2016;28(7):81–3. PMID: 27439227. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.27439227
Edwards J, Elkins K, Hinton M, . Randomized controlled trial of a cannabis-focused intervention for young people with first-episode psychosis. Acta Psychiatr Scand. 2006;114(2):109–17. doi: 10.1111/j.1600-0447.2006.00783.x. PMID: 16836598. Excluded: Other wrong population (e.g., schizophrenia focus)16836598
Eisenberg K, Woodruff SI. Randomized controlled trial to evaluate screening and brief intervention for drug-using multiethnic emergency and trauma department patients. Addict Sci Clin Pract. 2013;8(1):8. doi: 10.1186/1940-0640-8-8. PMID: 23566363. Excluded: Results reported elsewhere, duplicate results23566363
Elk R, Mangus L, Rhoades H, . Cessation of cocaine use during pregnancy: effects of contingency management interventions on maintaining abstinence and complying with prenatal care. Addict Behav. 1998;23(1):57–64. PMID: 9468743. Excluded: Wrong comparator9468743
Elliott JC, Carey KB, Vanable PA. A preliminary evaluation of a web-based intervention for college marijuana use. Psychol Addict Behav. 2014;28(1):288–93. doi: 10.1037/a0034995. PMID: 24731118. Excluded: <3 month followup duration24731118
Epstein DH, Hawkins WE, Covi L, . Cognitive-behavioral therapy plus contingency management for cocaine use: findings during treatment and across 12-month follow-up. Psychol Addict Behav. 2003;17(1):73–82. PMID: 12665084. Excluded: Wrong comparator12665084
Epstein DH, Schmittner J, Umbricht A, . Promoting abstinence from cocaine and heroin with a methadone dose increase and a novel contingency. Drug Alcohol Depend. 2009;101(1-2):92–100. doi: 10.1016/j.drugalcdep.2008.11.006. PMID: 19101098. Excluded: Wrong comparator19101098
Erickson SJ, Tonigan J, Winhusen T. Therapist effects in a NIDA CTN intervention trial with pregnant substance abusing women: Findings from a RCT with MET and TAU conditions. Alcohol Treat Q. 2012;30(2):224–37. doi: 10.1080/07347324.2012.663295. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Esposito-Smythers C, Spirito A, Kahler CW, . Treatment of co-occurring substance abuse and suicidality among adolescents: A randomized trial. J Consult Clin Psychol. 2011;79(6):728–39. doi: 10.1037/a0026074. PMID: 22004303. Excluded: Other wrong population (e.g., schizophrenia focus)22004303
Everly JJ, DeFulio A, Koffarnus MN, . Employment-based reinforcement of adherence to depot naltrexone in unemployed opioid-dependent adults: A randomized controlled trial. Addiction. 2011;106(7):1309–18. doi: 10.1111/j.1360-0443.2011.03400.x. PMID: 21320227. Excluded: Wrong comparator21320227
Fals-Stewart W, Lam WK. Computer-assisted cognitive rehabilitation for the treatment of patients with substance use disorders: a randomized clinical trial. Exp Clin Psychopharmacol. 2010;18(1):87–98. doi: 10.1037/a0018058. PMID: 20158298. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)20158298
Fals-Stewart W, O’Farrell TJ. Behavioral family counseling and naltrexone for male opioid-dependent patients. J Consult Clin Psychol. 2003;71(3):432–42. PMID: 12795568. Excluded: Wrong comparator12795568
Fals-Stewart W, Schafer J. The treatment of substance abusers diagnosed with obsessive-compulsive disorder: An outcome study. J Subst Abuse Treat. 1992;9(4):365–70. doi: 10.1016/0740-5472%2892%2990032-J. PMID: 1479631. Excluded: Other wrong population (e.g., schizophrenia focus)1479631
Feaster DJ, Mitrani VB, Burns MJ, . A randomized controlled trial of structural ecosystems therapy for HIV medication adherence and substance abuse relapse prevention. Drug Alcohol Depend. 2010;111(3):227–34. doi: 10.1016/j.drugalcdep.2010.04.017. PMID: 20538417. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)20538417
Feingold A, Oliveto A, Schottenfeld R, . Utility of crossover designs in clinical trials: efficacy of desipramine vs. placebo in opioid-dependent cocaine abusers. Am J Addict. 2002;11(2):111–23. PMID: 12028741. Excluded: Non-FDA approved pharmacologic intervention12028741
Fernandes S, Ferigolo M, Benchaya MC, . Brief Motivational Intervention and telemedicine: a new perspective of treatment to marijuana users. Addict Behav. 2010;35(8):750–5. doi: 10.1016/j.addbeh.2010.03.001. PMID: 20385444. Excluded: Wrong country20385444
Festinger DS, Dugosh KL, Kirby KC, . Contingency management for cocaine treatment: cash vs. vouchers. J Subst Abuse Treat. 2014;47(2):168–74. doi: 10.1016/j.jsat.2014.03.001. PMID: 24746956. Excluded: Wrong comparator24746956
Fiellin DA, O’Connor PG, Chawarski M, . Methadone maintenance in primary care: a randomized controlled trial. JAMA. 2001;286(14):1724–31. PMID: 11594897. Excluded: Wrong comparator11594897
Fiellin DA, Pantalon MV, Chawarski MC, . Counseling plus buprenorphine-naloxone maintenance therapy for opioid dependence. N Engl J Med. 2006;355(4):365–74. PMID: 16870915. Excluded: Wrong comparator16870915
Filges T, Andersen D, Jorgensen A-MK. Effects of multidimensional family therapy (MDFT) on nonopioid drug abuse: a systematic review and meta-analysis. Res Soc Work Pract. 2018;28(1):68–83. doi: 10.1177/1049731515608241. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Filges T, Jorgensen AMK. Cognitive–behavioral therapies for young people in outpatient treatment for nonopioid drug use. Res Soc Work Pract. 2018;28(3):363–85. doi: 10.1177/1049731516629803. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Findling RL, Pagano ME, McNamara NK, . The short-term safety and efficacy of fluoxetine in depressed adolescents with alcohol and cannabis use disorders: a pilot randomized placebo-controlled trial. Child Adolesc Psychiatry Ment Health. 2009;3(1):11. doi: 10.1186/1753-2000-3-11. PMID: 19298659. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19298659
Fletcher JB, Shoptaw S, Peck JA, . Contingency management reduces symptoms of psychological and emotional distress among homeless, substance-dependent men who have sex with men. Ment Health Serv Res. 2014;7(4):420–30. doi: 10.1080/17523281.2014.892897. PMID: 25364379. Excluded: <70% drug misuse or likely majority alcohol25364379
Foxcroft DR, Callen H, Davies EL, . Effectiveness of the strengthening families programme 10-14 in Poland: cluster randomized controlled trial. Eur J Public Health. 2017;27(3):494–500. doi: 10.1093/eurpub/ckw195. PMID: 28339547. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28339547
French MT, Sacks S, de Leon G, . Modified therapeutic community for mentally ill chemical abusers: Outcomes and costs. Eval Health Prof. 1999;22(1):60–85. doi: 10.1177/016327879902200104. PMID: 10350964. Excluded: Other wrong population (e.g., schizophrenia focus)10350964
Frisman L, Ford J, Lin H-J, . Outcomes of trauma treatment using the TARGET model. J Groups Addict Recover. 2008;3(3-4):285–303. doi: 10.1080/15560350802424910. Excluded: Other wrong population (e.g., schizophrenia focus)
Fudala PJ, Bridge TP, Herbert S, . Office-based treatment of opiate addiction with a sublingual-tablet formulation of buprenorphine and naloxone. N Engl J Med. 2003;349(10):949–58. PMID: 12954743. Excluded: <3 month followup duration12954743
Galanter M, Dermatis H, Glickman L, . Network therapy: decreased secondary opioid use during buprenorphine maintenance. J Subst Abuse Treat. 2004;26(4):313–8. PMID: 15182896. Excluded: Wrong comparator15182896
Garland EL, Roberts-Lewis A, Tronnier CD, . Mindfulness-oriented recovery enhancement versus CBT for co-occurring substance dependence, traumatic stress, and psychiatric disorders: Proximal outcomes from a pragmatic randomized trial. Behav Res Ther. 2016;77:7–16. doi: 10.1016/j.brat.2015.11.012. PMID: 26701171. Excluded: Other wrong population (e.g., schizophrenia focus)26701171
Garland EL, Roberts-Lewis A, Tronnier CD, . "Mindfulness-oriented recovery enhancement versus CBT for co-occurring substance dependence, traumatic stress, and psychiatric disorders: Proximal outcomes from a pragmatic randomized trial": Corrigendum. Behav Res Ther. 2018;100:78. doi: 10.1016/j.brat.2017.09.007. PMID: 28964403. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.28964403
Garrett SB, Doyle SR, Peavy K, . Age differences in outcomes among patients in the “Stimulant Abuser Groups to Engage in 12-Step” (STAGE-12) intervention. J Subst Abuse Treat. 2018;84:21–9. doi: 10.1016/j.jsat.2017.10.012. PMID: 29195590. Excluded: Wrong outcome29195590
Gastfriend D, Silverman B, Memisoglu A, . Continuity of clinical efficacy with injectable extended-release naltrexone (XR-NTX). J Addict Med. 2013;7(4):E4. Excluded: Results reported elsewhere, duplicate results
Gates PJ, Sabioni P, Copeland J, . Psychosocial interventions for cannabis use disorder. Cochrane Database Syst Rev. 2016 (5):Cd005336. doi: 10.1002/14651858.CD005336.pub4. PMID: 27149547. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27149547
George TP, Chawarski MC, Pakes J, . Disulfiram versus placebo for cocaine dependence in buprenorphine-maintained subjects: a preliminary trial. Biol Psychiatry. 2000;47(12):1080–6. PMID: 10862808. Excluded: Non-FDA approved pharmacologic intervention10862808
Gerra G, Marcato A, Caccavari R, . Clonidine and opiate receptor antagonists in the treatment of heroin addiction. J Subst Abuse Treat. 1995;12(1):35–41. PMID: 7752296. Excluded: Non-FDA approved pharmacologic intervention7752296
Ghitza UE, Epstein DH, Preston KL. Contingency management reduces injection-related HIV risk behaviors in heroin and cocaine using outpatients. Addict Behav. 2008;33(4):593–604. PMID: 18068905. Excluded: Wrong comparator18068905
Ghitza UE, Epstein DH, Schmittner J, . Randomized trial of prize-based reinforcement density for simultaneous abstinence from cocaine and heroin. J Consult Clin Psychol. 2007;75(5):765–74. PMID: 17907858. Excluded: Wrong comparator17907858
Gibbons CJ, Nich C, Steinberg K, . Treatment process, alliance and outcome in brief versus extended treatments for marijuana dependence. Addiction. 2010;105(10):1799–808. doi: 10.1111/j.1360-0443.2010.03047.x. PMID: 20840200. Excluded: Wrong outcome20840200
Gilbert L, El-Bassel N, Manuel J, . An integrated relapse prevention and relationship safety intervention for women on methadone: testing short-term effects on intimate partner violence and substance use. Violence Vict. 2006;21(5):657–72. PMID: 17022356. Excluded: Wrong comparator17022356
Gilchrist LD, Schinke SP, Trimble JE, . Skills enhancement to prevent substance abuse among American Indian adolescents. Int J Addict. 1987;22(9):869–79. PMID: 3679639. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)3679639
Glasner S, Mooney LJ, Ang A, . Mindfulness-based relapse prevention for stimulant dependent adults: A pilot randomized clinical trial. Mindfulness (N Y). 2017;8(1):126–35. doi: 10.1007/s12671-016-0586-9. PMID: 28191264. Excluded: Wrong comparator28191264
Glasner-Edwards S, Mooney L, Ang A, . Mindfulness based relapse prevention improves stimulant use among adults with major depression and generalized anxiety disorder. Drug Alcohol Depend. 2015;156. Excluded: Other wrong population (e.g., schizophrenia focus)
Gmel G, Gaume J, Bertholet N, . Effectiveness of a brief integrative multiple substance use intervention among young men with and without booster sessions. J Subst Abuse Treat. 2013;44(2):231–40. doi: 10.1016/j.jsat.2012.07.005. PMID: 22885010. Excluded: Other wrong population (e.g., schizophrenia focus)22885010
Godley MD, Godley SH, Dennis ML, . The effect of assertive continuing care on continuing care linkage, adherence and abstinence following residential treatment for adolescents with substance use disorders. Addiction. 2007;102(1):81–93. doi: 10.1111/j.1360-0443.2006.01648.x. PMID: 17207126. Excluded: Wrong comparator17207126
Godley MD, Godley SH, Dennis ML, . A randomized trial of assertive continuing care and contingency management for adolescents with substance use disorders. J Consult Clin Psychol. 2014;82(1):40–51. doi: 10.1037/a0035264. PMID: 24294838. Excluded: Wrong comparator24294838
Godley SH, Garner BR, Passetti LL, . Adolescent outpatient treatment and continuing care: main findings from a randomized clinical trial. Drug Alcohol Depend. 2010;110(1-2):44–54. doi: 10.1016/j.drugalcdep.2010.02.003. PMID: 20219293. Excluded: Wrong comparator20219293
Goldstein MF, Deren S, Kang SY, . Evaluation of an alternative program for MMTP drop-outs: impact on treatment re-entry. Drug Alcohol Depend. 2002;66(2):181–7. PMID: 11906805. Excluded: Other wrong population (e.g., schizophrenia focus)11906805
Goti J, Diaz R, Serrano L, . Brief intervention in substance-use among adolescent psychiatric patients: a randomized controlled trial. Eur Child Adolesc Psychiatry. 2010;19(6):503–11. doi: 10.1007/s00787-009-0060-5. PMID: 19779855. Excluded: Other wrong population (e.g., schizophrenia focus)19779855
Gottheil E, Rieger JA, Farwell B, . An outpatient drug program for adolescent students: preliminary evaluation. Am J Drug Alcohol Abuse. 1977;4(1):31–41. PMID: 612189. Excluded: School setting612189
Gottheil E, Thornton C, Weinstein S. Effectiveness of high versus low structure individual counseling for substance abuse. Am J Addict. 2002;11(4):279–90. PMID: 12584871. Excluded: Wrong comparator12584871
Gowing L, Farrell MF, Bornemann R, . Oral substitution treatment of injecting opioid users for prevention of HIV infection. Cochrane Database Syst Rev. 2011 (8):CD004145. doi: 10.1002/14651858.CD004145.pub4. PMID: 21833948. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)21833948
Gowing LR, Hickman M, Degenhardt L. Mitigating the risk of HIV infection with opioid substitution treatment. Bull World Health Organ. 2013;91(2):148–9. doi: 10.2471/BLT.12.109553. PMID: 23554530. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)23554530
Grabowski J, Rhoades H, Stotts A, . Agonist-like or antagonist-like treatment for cocaine dependence with methadone for heroin dependence: two double-blind randomized clinical trials. Neuropsychopharmacology. 2004;29(5):969–81. PMID: 15039761. Excluded: Non-FDA approved pharmacologic intervention15039761
Grant JE, Odlaug BL, Kim SW. A double-blind, placebo-controlled study of N-acetyl cysteine plus naltrexone for methamphetamine dependence. Eur Neuropsychopharmacol. 2010;20(11):823–8. doi: 10.1016/j.euroneuro.2010.06.018. PMID: 20655182. Excluded: Non-FDA approved pharmacologic intervention20655182
Grant S, Colaiaco B, Motala A, . Mindfulness-based relapse prevention for substance use disorders: A systematic review and meta-analysis. J Addict Med. 2017;11(5):386–96. doi: 10.1097/adm.0000000000000338. PMID: 28727663. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28727663
Grenard JL, Ames SL, Wiers RW, . Brief intervention for substance use among at-risk adolescents: a pilot study. J Adolesc Health. 2007;40(2):188–91. doi: 10.1016/j.jadohealth.2006.08.008. PMID: 17259065. Excluded: School setting17259065
Gross A, Marsch LA, Badger GJ, . A comparison between low-magnitude voucher and buprenorphine medication contingencies in promoting abstinence from opioids and cocaine. Exp Clin Psychopharmacol. 2006;14(2):148–56. PMID: 16756418. Excluded: Wrong comparator16756418
Gruber K, Chutuape MA, Stitzer ML. Reinforcement-based intensive outpatient treatment for inner city opiate abusers: a short-term evaluation. Drug Alcohol Depend. 2000;57(3):211–23. doi: 10.1016/S0376-8716%2899%2900054-X. PMID: 10661672. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)10661672
Gunne LM, Gronbladh L. The Swedish methadone maintenance program: a controlled study. Drug Alcohol Depend. 1981;7(3):249–56. PMID: 7261900. Excluded: Poor quality7261900
Haber PS, Elsayed M, Espinoza D, . Constipation and other common symptoms reported by women and men in methadone and buprenorphine maintenance treatment. Drug Alcohol Depend. 2017;181:132–9. doi: 10.1016/j.drugalcdep.2017.09.024. PMID: 29054032. Excluded: Wrong study design for key question29054032
Hagedorn HJ, Noorbaloochi S, Simon AB, . Rewarding early abstinence in Veterans Health Administration addiction clinics. J Subst Abuse Treat. 2013;45(1):109–17. doi: 10.1016/j.jsat.2013.01.006. PMID: 23453480. Excluded: Wrong comparator23453480
Hall SM, Bass A, Hargreaves WA, . Contingency management and information feedback in outpatient heroin detoxification. Behav Ther. 1979;10(4):443–51. doi: 10.1016/S0005-7894%2879%2980049-0. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Haller DM, Meynard A, Lefebvre D, . Effectiveness of training family physicians to deliver a brief intervention to address excessive substance use among young patients: a cluster randomized controlled trial. CMAJ. 2014;186(8):E263–72. doi: 10.1503/cmaj.131301. PMID: 24616136. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)24616136
Hand DJ, Ellis JD, Carr MM, . Contingency management interventions for tobacco and other substance use disorders in pregnancy. Psychol Addict Behav. 2017;31(8):907–21. doi: 10.1037/adb0000291. PMID: 28639813. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28639813
Handelsman L, Rosenblum A, Palij M, . Bromocriptine for cocaine dependence. A controlled clinical trial. Am J Addict. 1997;6(1):54–64. PMID: 9097872. Excluded: Non-FDA approved pharmacologic intervention9097872
Haney M, Ramesh D, Glass A, . Naltrexone maintenance decreases cannabis self-administration and subjective effects in daily cannabis smokers. Neuropsychopharmacology. 2015;40(11):2489–98. doi: 10.1038/npp.2015.108. PMID: 25881117. Excluded: Non-FDA approved pharmacologic intervention25881117
Hanson T, Alessi SM, Petry NM. Contingency management reduces drug-related human immunodeficiency virus risk behaviors in cocaine-abusing methadone patients. Addiction. 2008;103(7):1187–97. doi: 10.1111/j.1360-0443.2008.02216.x. PMID: 18494842. Excluded: Wrong comparator18494842
Harris J. Mindfulness training: Impact of coping and self-efficacy in adolescent substance use: Seattle Pacific University; 2012. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Hartnett D, Carr A, Hamilton E, . The effectiveness of functional family therapy for adolescent behavioral and substance misuse problems: A meta-analysis. Fam Process. 2017;56(3):607–19. doi: 10.1111/famp.12256. PMID: 27731494. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27731494
Hartnett D, Carr A, Sexton T. The effectiveness of functional family therapy in reducing adolescent mental health risk and family adjustment difficulties in an irish context. Fam Process. 2016;55(2):287–304. doi: 10.1111/famp.12195. PMID: 26542420. Excluded: Wrong outcome26542420
Havassy B, Hargreaves WA. Allowing methadone clients control over dosage: A 48-week controlled trial. Addict Behav. 1981;6(4):283–8. doi: 10.1016/0306-4603%2881%2990041-1. Excluded: Wrong comparator
Hawkins JD, Catalano RF, Jr., Gillmore MR, . Skills training for drug abusers: generalization, maintenance, and effects on drug use. J Consult Clin Psychol. 1989;57(4):559–63. PMID: 2671072. Excluded: Wrong comparator2671072
Hawkins JD, Catalano RF, Jr., Wells EA. Measuring effects of a skills training intervention for drug abusers. J Consult Clin Psychol. 1986;54(5):661–4. PMID: 3771883. Excluded: Wrong comparator3771883
Hayes SC, Wilson KG, Gifford EV, . A preliminary trial of twelve-step facilitation and acceptance and commitment therapy with polysubstance-abusing methadone-maintained opiate addicts. Behav Ther. 2004;35(4):667–88. doi: 10.1016/S0005-7894%2804%2980014-5. Excluded: Wrong comparator
He F, Jiang Y, Li L. The effect of naloxone treatment on opioid-induced side effects: A meta-analysis of randomized and controlled trails. Medicine (Baltimore). 2016;95(37):e4729. doi: 10.1097/MD.0000000000004729. PMID: 27631221. Excluded: Other wrong population (e.g., schizophrenia focus)27631221
Heinzerling KG, Gadzhyan J, van Oudheusden H, . Pilot randomized trial of bupropion for adolescent methamphetamine abuse/dependence. J Adolesc Health. 2013;52(4):502–5. doi: 10.1016/j.jadohealth.2012.10.275. PMID: 23333007. Excluded: Non-FDA approved pharmacologic intervention23333007
Helmer SM, Muellmann S, Zeeb H, . Development and evaluation of the efficacy of a web-based ‘social norms’-intervention for the prevention and reduction of substance use in a cluster-controlled trial conducted at eight German universities. BMC Public Health. 2016;16:252. doi: 10.1186/s12889-016-2898-z. PMID: 26969585. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.26969585
Henggeler SW, Clingempeel WG, Brondino MJ, . Four-year follow-up of multisystemic therapy with substance-abusing and substance-dependent juvenile offenders. J Am Acad Child Adolesc Psychiatry. 2002;41(7):868–74. PMID: 12108813. Excluded: Other wrong population (e.g., schizophrenia focus)12108813
Henggeler SW, McCart MR, Cunningham PB, . Enhancing the effectiveness of juvenile drug courts by integrating evidence-based practices. J Consult Clin Psychol. 2012;80(2):264–75. doi: 10.1037/a0027147. PMID: 22309470. Excluded: Wrong comparator22309470
Henggeler SW, Melton GB, Smith LA. Family preservation using multisystemic therapy: an effective alternative to incarcerating serious juvenile offenders. J Consult Clin Psychol. 1992;60(6):953–61. PMID: 1460157. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)1460157
Henggeler SW, Pickrel SG, Brondino MJ. Multisystemic treatment of substance-abusing and dependent delinquents: outcomes, treatment fidelity, and transportability. Ment Health Serv Res. 1999;1(3):171–84. PMID: 11258740. Excluded: Other wrong population (e.g., schizophrenia focus)11258740
Hennessey EA, Fisher BW. A meta-analysis exploring the relationship between 12-step attendance and adolescent substance use relapse. J Groups Addict Recover. 2015;10(1):79–96. doi: 10.1080/1556035X.2015.999621. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Hersh D, Van Kirk JR, Kranzler HR. Naltrexone treatment of comorbid alcohol and cocaine use disorders. Psychopharmacology (Berl). 1998;139(1-2):44–52. PMID: 9768541. Excluded: Non-FDA approved pharmacologic intervention9768541
Hien DA, Cohen LR, Miele GM, . Promising treatments for women with comorbid PTSD and substance use disorders. Am J Psychiatry. 2004;161(8):1426–32. doi: 10.1176/appi.ajp.161.8.1426. PMID: 15285969. Excluded: Other wrong population (e.g., schizophrenia focus)15285969
Hien DA, Morgan-Lopez AA, Campbell AN, . Attendance and substance use outcomes for the seeking safety program: sometimes less is more. J Consult Clin Psychol. 2012;80(1):29–42. doi: 10.1037/a0026361. PMID: 22182262. Excluded: Other wrong population (e.g., schizophrenia focus)22182262
Hien DA, Wells EA, Jiang H, . Multisite randomized trial of behavioral interventions for women with co-occurring PTSD and substance use disorders. J Consult Clin Psychol. 2009;77(4):607–19. doi: 10.1037/a0016227. PMID: 19634955. Excluded: Other wrong population (e.g., schizophrenia focus)19634955
Higgins ST, Budney AJ, Bickel WK, . Outpatient behavioral treatment for cocaine dependence: One-year outcome. Exp Clin Psychopharmacol. 1995;3(2):205–12. Excluded: Wrong comparator
Higgins ST, Budney AJ, Bickel WK, . Outpatient behavioral treatment for cocaine dependence: One-year outcome. Addictive behaviors: Readings on etiology, prevention, and treatment. Washington, DC: American Psychological Association; US; 1997:629–45. Excluded: Wrong comparator
Higgins ST, Budney AJ, Bickel WK, . Achieving cocaine abstinence with a behavioral approach. Am J Psychiatry. 1993;150(5):763–9. doi: 10.1176/ajp.150.5.763. PMID: 8480823. Excluded: Wrong comparator8480823
Higgins ST, Stitzer ML, Bigelow GE, . Contingent methadone delivery: effects on illicit-opiate use. Drug Alcohol Depend. 1986;17(4):311–22. PMID: 3757767. Excluded: <3 month followup duration3757767
Hjorthoj CR, Fohlmann A, Larsen AM, . Specialized psychosocial treatment plus treatment as usual (TAU) versus TAU for patients with cannabis use disorder and psychosis: The CapOpus randomized trial. Psychol Med. 2013;43(7):1499–510. doi: 10.1017/S0033291712002255. PMID: 23040144. Excluded: Other wrong population (e.g., schizophrenia focus)23040144
Hoch E, Buhringer G, Pixa A, . CANDIS treatment program for cannabis use disorders: findings from a randomized multi-site translational trial. Drug Alcohol Depend. 2014;134:185–93. doi: 10.1016/j.drugalcdep.2013.09.028. PMID: 24176199. Excluded: Wrong study design for key question24176199
Hoch E, Noack R, Henker J, . Efficacy of a targeted cognitive-behavioral treatment program for cannabis use disorders (CANDIS). Eur Neuropsychopharmacol. 2012;22(4):267–80. doi: 10.1016/j.euroneuro.2011.07.014. PMID: 21865014. Excluded: Wrong study design for key question21865014
Hogue A, Henderson CE, Ozechowski TJ, . Evidence base on outpatient behavioral treatments for adolescent substance use: updates and recommendations 2007-2013. J Clin Child Adolesc Psychol. 2014;43(5):695–720. doi: 10.1080/15374416.2014.915550. PMID: 24926870. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24926870
Hogue A, Liddle HA. Family-based treatment for adolescent substance abuse: Controlled trials and new horizons in services research. J Fam Ther. 2009;31(2):126–54. doi: 10.1111/j.1467-6427.2009.00459.x. PMID: 21113237. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies21113237
Hohmann L, Bradt J, Stegemann T, . Effects of music therapy and music-based interventions in the treatment of substance use disorders: A systematic review. PLoS ONE. 2017;12(11):e0187363. doi: 10.1371/journal.pone.0187363. PMID: 29141012. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies29141012
Hops H, Ozechowski TJ, Waldron HB, . Adolescent health-risk sexual behaviors: effects of a drug abuse intervention. Aids Behav. 2011;15(8):1664–76. doi: 10.1007/s10461-011-0019-7. PMID: 21833690. Excluded: Wrong comparator21833690
Horigian VE, Anderson AR, Szapocznik J. Family-based treatments for adolescent substance use. Child Adolesc Psychiatr Clin N Am. 2016;25(4):603–28. doi: 10.1016/j.chc.2016.06.001. PMID: 27613341. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27613341
Horigian VE, Robbins MS, Dominguez R, . Principles for defining adverse events in behavioral intervention research: lessons from a family-focused adolescent drug abuse trial. Clin Trials. 2010;7(1):58–68. doi: 10.1177/1740774509356575. PMID: 20156957. Excluded: Wrong comparator20156957
Horigian VE, Weems CF, Robbins MS, . Reductions in anxiety and depression symptoms in youth receiving substance use treatment. Am J Addict. 2013;22(4):329–37. doi: 10.1111/j.1521-0391.2013.12031.x. PMID: 23795871. Excluded: Wrong study design for key question23795871
Hoseiny H, Jadidi M, Habiballah Nataj L, . The effect of methadone-maintenance therapy with and without interactive treatment on improving emotion-regulation strategies and resilience among opiate-dependent clients. Int J High Risk Behav Addict. 2015;4(1):e23526. doi: 10.5812/ijhrba.23526. PMID: 25821751. Excluded: Wrong study design for key question25821751
Hser YI, Li J, Jiang H, . Effects of a randomized contingency management intervention on opiate abstinence and retention in methadone maintenance treatment in China. Addiction. 2011;106(10):1801–9. doi: 10.1111/j.1360-0443.2011.03490.x. PMID: 21793958. Excluded: Wrong comparator21793958
Hsu SH, Collins SE, Marlatt GA. Examining psychometric properties of distress tolerance and its moderation of mindfulness-based relapse prevention effects on alcohol and other drug use outcomes. Addict Behav. 2013;38(3):1852–8. doi: 10.1016/j.addbeh.2012.11.002. PMID: 23266526. Excluded: Wrong outcome23266526
Huang YS, Tang TC, Lin CH, . Effects of motivational enhancement therapy on readiness to change MDMA and methamphetamine use behaviors in Taiwanese adolescents. Subst Use Misuse. 2011;46(4):411–6. doi: 10.3109/10826084.2010.501664. PMID: 20735217. Excluded: <3 month followup duration20735217
Hubbard RL, Leimberger JD, Haynes L, . Telephone enhancement of long-term engagement (TELE) in continuing care for substance abuse treatment: a NIDA clinical trials network (CTN) study. Am J Addict. 2007;16(6):495–502. PMID: 18058417. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)18058417
Humeniuk R, Dennington V, Ali R. The effectiveness of a brief intervention for illicit drugs linked to the alcohol, smoking and substance involvement screening test (ASSIST) in primary health care settings: a technical report of phase III findings of the WHO ASSIST randomized controlled trial. Geneva: World Health Organization. 2008. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Humeniuk R, Newcombe DAL, Dennington V, . A randomised controlled trial of a brief intervention for illicit drug use linked to ASSIST screening in a primary healthcare setting: results from the Australian component of the World Health Organization Phase III ASSIST studies. Aust J Prim Health. 2018;24(2):149–54. doi: 10.1071/PY17056. PMID: 29481765. Excluded: Results reported elsewhere, duplicate results29481765
Hunt GE, Siegfried N, Morley K, . Psychosocial interventions for people with both severe mental illness and substance misuse. Cochrane Database Syst Rev. 2013 (10):CD001088. doi: 10.1002/14651858.CD001088.pub3. PMID: 24092525. Excluded: Other wrong population (e.g., schizophrenia focus)24092525
Hunter SB, Ramchand R, Griffin BA, . The effectiveness of community-based delivery of an evidence-based treatment for adolescent substance use. J Subst Abuse Treat. 2012;43(2):211–20. doi: 10.1016/j.jsat.2011.11.003. PMID: 22209657. Excluded: Wrong comparator22209657
Hunter SB, Watkins KE, Hepner KA, . Treating depression and substance use: a randomized controlled trial. J Subst Abuse Treat. 2012;43(2):137–51. doi: 10.1016/j.jsat.2011.12.004. PMID: 22301087. Excluded: Wrong comparator22301087
Hwang VS. A brief motivational intervention for marijuana use in college students. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2018;78(9-B(E)):No Pagination Specified. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Iguchi MY, Belding MA, Morral AR, . Reinforcing operants other than abstinence in drug abuse treatment: An effective alternative for reducing drug use. J Consult Clin Psychol. 1997;65(3):421–8. PMID: 9170765. Excluded: Wrong comparator9170765
Indave B, Amato L, Minozzi S, . Antipsychotic medications for cocaine dependence. Cochrane Database Syst Rev. 2016 (6)doi: 10.1002/14651858.CD006306.pub3. PMID: 26992929. Excluded: Non-FDA approved pharmacologic intervention26992929
Ingersoll KS, Dillingham RA, Hettema JE, . Pilot RCT of bidirectional text messaging for ART adherence among nonurban substance users with HIV. Health Psychol. 2015;34S:1305–15. doi: 10.1037/hea0000295. PMID: 26651472. Excluded: Other wrong population (e.g., schizophrenia focus)26651472
Ingersoll KS, Farrell-Carnahan L, Cohen-Filipic J, . A pilot randomized clinical trial of two medication adherence and drug use interventions for HIV+ crack cocaine users. Drug Alcohol Depend. 2011;116(1-3):177–87. doi: 10.1016/j.drugalcdep.2010.12.016. PMID: 21306837. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)21306837
Irvin JE, Bowers CA, Dunn ME, . Efficacy of relapse prevention: a meta-analytic review. J Consult Clin Psychol. 1999;67(4):563–70. PMID: 10450627. Excluded: Wrong outcome10450627
Jacobus J, Taylor CT, Gray KM, . A multi-site proof-of-concept investigation of computerized approach-avoidance training in adolescent cannabis users. Drug Alcohol Depend. 2018;187:195–204. doi: 10.1016/j.drugalcdep.2018.03.007. PMID: 29679914. Excluded: <3 month followup duration29679914
Jaffe AJ, Rounsaville B, Chang G, . Naltrexone, relapse prevention, and supportive therapy with alcoholics: an analysis of patient treatment matching. J Consult Clin Psychol. 1996;64(5):1044–53. PMID: 8916634. Excluded: Other wrong population (e.g., schizophrenia focus)8916634
Jaffray M, Matheson C, Bond CM, . A cluster randomised controlled trial of enhanced pharmacy services (EPS) to improve outcomes for patients on methadone maintenance therapy (MMT). Int J Pharm Pract. 2011;19:4. doi: 10.1111/j.2042-7174.2011.00098.x. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Jalling C, Bodin M, Romelsjo A, . Parent programs for reducing adolescent’s antisocial behavior and substance use: A randomized controlled trial. J Child Fam Stud. 2016;25:811–26. doi: 10.1007/s10826-015-0263-y. PMID: 26900316. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)26900316
Jarvis BP, Holtyn AF, DeFulio A, . Effects of incentives for naltrexone adherence on opiate abstinence in heroin-dependent adults. Addiction. 2017;112(5):830–7. doi: 10.1111/add.13724. PMID: 27936293. Excluded: Wrong comparator27936293
Jarvis BP, Holtyn AF, Subramaniam S, . Extended-release injectable naltrexone for opioid use disorder: a systematic review. Addiction. 2018;113(7):1188–209. doi: 10.1111/add.14180. PMID: 29396985. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies29396985
Jayaram-Lindstrom N, Hammarberg A, Beck O, . Naltrexone for the treatment of amphetamine dependence: a randomized, placebo-controlled trial. Am J Psychiatry. 2008;165(11):1442–8. doi: 10.1176/appi.ajp.2008.08020304. PMID: 18765480. Excluded: Non-FDA approved pharmacologic intervention18765480
Jeal N, Macleod J, Turner K, . Systematic review of interventions to reduce illicit drug use in female drug-dependent street sex workers. BMJ Open. 2015;5(11):e009238. doi: 10.1136/bmjopen-2015-009238. PMID: 26582403. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26582403
Jenaabadi H, Jahangir AH. Comparing the effectiveness of mindfulness-based group therapy and methadone maintenance therapy on psychological symptoms (obsession, interpersonal sensitivity, depression, anxiety, and aggression) among opioid-dependent patients. Shiraz E Med J. 2017;18(6). Excluded: Wrong comparator
Jensen CD, Cushing CC, Aylward BS, . Effectiveness of motivational interviewing interventions for adolescent substance use behavior change: a meta-analytic review. J Consult Clin Psychol. 2011;79(4):433–40. doi: 10.1037/a0023992. PMID: 21728400. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies21728400
Jiang H, Du J, Wu F, . Efficacy of contingency management in improving retention and compliance to methadone maintenance treatment: a random controlled study. Shanghai Arch Psychiatry. 2012;24(1):11–9. doi: 10.3969/j.issn.1002-0829.2012.01.002. PMID: 25324596. Excluded: Wrong comparator25324596
Jiang S, Wu L, Gao X. Beyond face-to-face individual counseling: a systematic review on alternative modes of motivational interviewing in substance abuse treatment and prevention. Addict Behav. 2017;73:216–35. doi: 10.1016/j.addbeh.2017.05.023. PMID: 28554033. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28554033
Joanning H, Quinn W, Thomas F, . Treating adolescent drug abuse: A comparison of family systems therapy, group therapy, and family drug education. J Marital Fam Ther. 1992;18(4):345–56. Excluded: Wrong comparator
Johnson JD. The effects of a brief cognitive-behavioral group intervention on the depression and hopelessness of drug dependent, human immunodeficiency virus-positive, African-American women (immune deficiency). Dissertation Abstracts International: Section B: The Sciences and Engineering. 2001;62(1-B):551. Excluded: Wrong outcome
Johnson RE, Eissenberg T, Stitzer ML, . A placebo controlled clinical trial of buprenorphine as a treatment for opioid dependence. Drug Alcohol Depend. 1995;40(1):17–25. PMID: 8746920. Excluded: <3 month followup duration8746920
Johnson S, Sheridan Rains L, Marwaha S, . A randomised controlled trial of the clinical and cost-effectiveness of a contingency management intervention compared to treatment as usual for reduction of cannabis use and of relapse in early psychosis (CIRCLE): a study protocol for a randomised controlled trial. Trials. 2016;17(1)doi: 10.1186/s13063-016-1620-x. PMID: 27770820. Excluded: Other wrong population (e.g., schizophrenia focus)27770820
Jones HE, Haug N, Silverman K, . The effectiveness of incentives in enhancing treatment attendance and drug abstinence in methadone-maintained pregnant women. Drug Alcohol Depend. 2001;61(3):297–306. PMID: 11164694. Excluded: Wrong comparator11164694
Jones HE, Haug NA, Stitzer ML, . Improving treatment outcomes for pregnant drug-dependent women using low-magnitude voucher incentives. Addict Behav. 2000;25(2):263–7. PMID: 10795950. Excluded: Wrong comparator10795950
Jones HE, Johnson RE, Bigelow GE, . Safety and efficacy of L-tryptophan and behavioral incentives for treatment of cocaine dependence: a randomized clinical trial. Am J Addict. 2004;13(5):421–37. doi: 10.1080/10550490490512753. PMID: 15764421. Excluded: Wrong comparator15764421
Jones HE, O’Grady KE, Tuten M. Reinforcement-based treatment improves the maternal treatment and neonatal outcomes of pregnant patients enrolled in comprehensive care treatment. Am J Addict. 2011;20(3):196–204. doi: 10.1111/j.1521-0391.2011.00119.x. PMID: 21477047. Excluded: Wrong comparator21477047
Jones SL, Kanfer R, Lanyon RI. Skill training with alcoholics: A clinical extension. Addict Behav. 1982;7(3):285–90. PMID: 7180623. Excluded: Other wrong population (e.g., schizophrenia focus)7180623
Jordan JB. Acupuncture treatment for opiate addiction: a systematic review. J Subst Abuse Treat. 2006;30(4):309–14. PMID: 16716845. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.16716845
Judson BA, Goldstein A. Naltrexone treatment of heroin addiction: one-year follow-up. Drug Alcohol Depend. 1984;13(4):357–65. PMID: 6479015. Excluded: Wrong study design for key question6479015
Jungerman FS, Andreoni S, Laranjeira R. Short term impact of same intensity but different duration interventions for cannabis users. Drug Alcohol Depend. 2007;90(2-3):120–7. doi: 10.1016/j.drugalcdep.2007.02.019. PMID: 17412530. Excluded: Wrong country17412530
Kadden RM, Litt MD, Cooney NL, . Prospective matching of alcoholic clients to cognitive-behavioral or interactional group therapy. J Stud Alcohol. 2001;62(3):359–69. PMID: 11414346. Excluded: Other wrong population (e.g., schizophrenia focus)11414346
Kakko J, Gronbladh L, Svanborg KD, . A stepped care strategy using buprenorphine and methadone versus conventional methadone maintenance in heroin dependence: a randomized controlled trial. Am J Psychiatry. 2007;164(5):797–803. PMID: 17475739. Excluded: Wrong comparator17475739
Kaminer Y, Burleson JA. Psychotherapies for adolescent substance abusers: 15-month follow-up of a pilot study. Am J Addict. 1999;8(2):114–9. PMID: 10365191. Excluded: Wrong comparator10365191
Kaminer Y, Burleson JA, Blitz C, . Psychotherapies for adolescent substance abusers: a pilot study. J Nerv Ment Dis. 1998;186(11):684–90. PMID: 9824170. Excluded: Wrong comparator9824170
Kaminer Y, Burleson JA, Burke R, . The efficacy of contingency management for adolescent cannabis use disorder: a controlled study. Substance Abuse. 2014;35(4):391–8. doi: 10.1080/08897077.2014.933724. PMID: 25010430. Excluded: Wrong comparator25010430
Kaminer Y, Burleson JA, Goldberger R. Cognitive-behavioral coping skills and psychoeducation therapies for adolescent substance abuse. J Nerv Ment Dis. 2002;190(11):737–45. doi: 10.1097/00005053-200211000-00003. PMID: 12436013. Excluded: Wrong comparator12436013
Kamon J, Budney A, Stanger C. A contingency management intervention for adolescent marijuana abuse and conduct problems. J Am Acad Child Adolesc Psychiatry. 2005;44(6):513–21. PMID: 15908833. Excluded: Wrong study design for key question15908833
Kampman KM, Pettinati HM, Lynch KG, . Modafinil and naltrexone for the treatment of comorbid cocaine and alcohol dependence. Drug Alcohol Depend. 2014;146(14). Excluded: Non-FDA approved pharmacologic intervention
Kaner EF, Brown N, Jackson K. A systematic review of the impact of brief interventions on substance use and co-morbid physical and mental health conditions. Ment Health Serv Res. 2011;4(1):38–61. doi: 10.1080/17523281.2011.533449. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Kang SY, Kleinman PH, Woody GE, . Outcomes for cocaine abusers after once-a-week psychosocial therapy. Am J Psychiatry. 1991;148(5):630–5. PMID: 1850208. Excluded: Wrong study design for key question1850208
Karno M, Farabee D, Brecht ML, . Patient reactance moderates the effect of directive telephone counseling for methamphetamine users. J Stud Alcohol Drugs. 2012;73(5):844–50. PMID: 22846250. Excluded: Wrong outcome22846250
Katz D, Toner B. A systematic review of gender differences in the effectiveness of mindfulness-based treatments for substance use disorders. Mindfulness (N Y). 2013;4(4):318–31. doi: 10.1007/s12671-012-0132-3. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Katz EC, Chutuape MA, Jones HE, . Voucher reinforcement for heroin and cocaine abstinence in an outpatient drug-free program. Exp Clin Psychopharmacol. 2002;10(2):136–43. PMID: 12022799. Excluded: Wrong comparator12022799
Kay-Lambkin FJ, Baker AL, Kelly BJ, . It’s worth a try: The treatment experiences of rural and urban participants in a randomized controlled trial of computerized psychological treatment for comorbid depression and alcohol/other drug use. J Dual Diagn. 2012;8(4):262–76. doi: 10.1080/15504263.2012.723315. Excluded: Other wrong population (e.g., schizophrenia focus)
Keegan J, Lavenduski C, Schooff K. Comments and findings from a naltrexone double blind study. NIDA Res Monogr. 1976 (9):74–6. PMID: 794724. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.794724
Kelly AB, Halford WK, Young RM. Maritally distressed women with alcohol problems: the impact of a short-term alcohol-focused intervention on drinking behaviour and marital satisfaction. Addiction. 2000;95(10):1537–49. PMID: 11070529. Excluded: Other wrong population (e.g., schizophrenia focus)11070529
Kelly JF, Kaminer Y, Kahler CW, . A pilot randomized clinical trial testing integrated 12-Step facilitation (iTSF) treatment for adolescent substance use disorder. Addiction. 2017;112(12):2155–66. doi: 10.1111/add.13920. PMID: 28742932. Excluded: Wrong comparator28742932
Kelly SM, O’Grady K E, Jaffe JH, . Improvements in outcomes in methadone patients on probation/parole regardless of counseling early in treatment. J Addict Med. 2013;7(2):133–8. doi: 10.1097/ADM.0b013e318284a0c1. PMID: 23455877. Excluded: Wrong comparator23455877
Kelly SM, O’Grady KE, Gryczynski J, . Methadone patients in patient-centered treatment: one-year arrest data. Drug Alcohol Depend. 2016;171:e100–e1. Excluded: Wrong comparator
Kelly SM, Schwartz RP, O’Grady K E, . Impact of methadone with versus without drug abuse counseling on HIV risk: 4- and 12-month findings from a clinical trial. J Addict Med. 2012;6(2):145–52. doi: 10.1097/ADM.0b013e31823ae556. PMID: 22134175. Excluded: Wrong comparator22134175
Kelty E, Hulse G. A retrospective cohort study of birth outcomes in neonates exposed to naltrexone in utero: A comparison with methadone-, buprenorphine- and non-opioid-exposed neonates. Drugs. 2017;77(11):1211–9. doi: 10.1007/s40265-017-0763-8. PMID: 28536981. Excluded: Wrong study design for key question28536981
Kelty E, Hulse G. A retrospective cohort study of obstetric outcomes in opioid-dependent women treated with implant naltrexone, oral methadone or sublingual buprenorphine, and non-dependent controls. Drugs. 2017;77(11):1199–210. doi: 10.1007/s40265-017-0762-9. PMID: 28536980. Excluded: Wrong study design for key question28536980
Kemp R, Harris A, Vurel E, . Stop Using Stuff: trial of a drug and alcohol intervention for young people with comorbid mental illness and drug and alcohol problems. Australas Psychiatry. 2007;15(6):490–3. doi: 10.1080/10398560701439665. PMID: 17852064. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17852064
Kennedy AP, Phillips KA, Epstein DH, . A randomized investigation of methadone doses at or over 100 mg/day, combined with contingency management. Drug Alcohol Depend. 2013;130(1-3):77–84. doi: 10.1016/j.drugalcdep.2012.10.025. PMID: 23195924. Excluded: Wrong comparator23195924
Keoleian V, Stalcup SA, Polcin DL, . A cognitive behavioral therapy-based text messaging intervention for methamphetamine dependence. J Psychoactive Drugs. 2013;45(5):434–42. PMID: 24592670. Excluded: <3 month followup duration24592670
Khatami M, Woody G, O’Brien C, . Biofeedback treatment of narcotic addiction: a double-blind study. Drug Alcohol Depend. 1982;9(2):111–7. PMID: 7094834. Excluded: Wrong comparator7094834
Khusid MA, Vythilingam M. The emerging role of mindfulness meditation as effective self-management strategy, Part 2: Clinical implications for chronic pain, substance misuse, and insomnia. Mil Med. 2016;181(9):969–75. doi: 10.7205/MILMED-D-14-00678. PMID: 27612339. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27612339
Kidorf M, Brooner RK, Gandotra N, . Reinforcing integrated psychiatric service attendance in an opioid-agonist program: A randomized and controlled trial. Drug Alcohol Depend. 2013;133(1):30–6. doi: 10.1016/j.drugalcdep.2013.06.005. PMID: 23866988. Excluded: Other wrong population (e.g., schizophrenia focus)23866988
Kidorf M, King VL, Gandotra N, . Improving treatment enrollment and re-enrollment rates of syringe exchangers: 12-month outcomes. Drug Alcohol Depend. 2012;124(1-2):162–6. doi: 10.1016/j.drugalcdep.2011.12.008. PMID: 22209388. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)22209388
Kidorf M, King VL, Neufeld K, . Improving substance abuse treatment enrollment in community syringe exchangers. Addiction. 2009;104(5):786–95. doi: 10.1111/j.1360-0443.2009.02560.x. PMID: 19413790. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19413790
Kidorf M, King VL, Peirce J, . A treatment reengagement intervention for syringe exchangers. J Subst Abuse Treat. 2011;41(4):415–21. doi: 10.1016/j.jsat.2011.06.008. PMID: 21831559. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)21831559
Kidorf M, Stitzer ML. Contingent access to methadone maintenance treatment: effects on cocaine use of mixed opiate/cocaine abusers. NIDA Res Monogr. 1994;141(361). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Kidorf M, Stitzer ML. Contingent use of take-homes and split-dosing to reduce illicit drug use of methadone patients. Behav Ther. 1996;27(1):41–51. Excluded: Other wrong population (e.g., schizophrenia focus)
Kidorf M, Stitzer ML, Brooner RK, . Contingent methadone take-home doses reinforce adjunct therapy attendance of methadone maintenance patients. Drug Alcohol Depend. 1994;36(3):221–6. PMID: 7889813. Excluded: Wrong comparator7889813
Killeen TK, McRae-Clark AL, Waldrop AE, . Contingency management in community programs treating adolescent substance abuse: a feasibility study. J Child Adolesc Psychiatr Nurs. 2012;25(1):33–41. doi: 10.1111/j.1744-6171.2011.00313.x. PMID: 22299805. Excluded: Wrong comparator22299805
Killeen TK, Upadhyana H, McRae A, . Contingency management for community treatment-seeking adolescents with marijuana use disorders. Proceedings of the 70th Annual Scientific Meeting of the College on Problems of Drug Dependence. 2008. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Kim SJ, Marsch LA, Guarino H, . Predictors of outcome from computer-based treatment for substance use disorders: Results from a randomized clinical trial. Drug Alcohol Depend. 2015;157:174–8. doi: 10.1016/j.drugalcdep.2015.09.019. PMID: 26433562. Excluded: Wrong comparator26433562
Kim TW, Bernstein J, Cheng DM, . Does screening and brief intervention for drug use in primary care increase receipt of substance use disorder treatment? Drug Alcohol Depend. 2015;156(13). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Kimber J, Larney S, Hickman M, . Mortality risk of opioid substitution therapy with methadone versus buprenorphine: a retrospective cohort study. Lancet Psychiatry. 2015;2(10):901–8. doi: 10.1016/S2215-0366(15)00366-1. PMID: 26384619. Excluded: Wrong study design for key question26384619
King VL, Brooner RK, Peirce JM, . A randomized trial of web-based videoconferencing for substance abuse counseling. J Subst Abuse Treat. 2014;46(1):36–42. doi: 10.1016/j.jsat.2013.08.009. PMID: 24035556. Excluded: Wrong comparator24035556
King VL, Kidorf MS, Stoller KB, . A 12-month controlled trial of methadone medical maintenance integrated into an adaptive treatment model. J Subst Abuse Treat. 2006;31(4):385–93. PMID: 17084792. Excluded: Wrong comparator17084792
King VL, Stoller KB, Hayes M, . A multicenter randomized evaluation of methadone medical maintenance. Drug Alcohol Depend. 2002;65(2):137–48. PMID: 11772475. Excluded: Wrong comparator11772475
Kinlock TW, Battjes RJ, Schwartz RP, . A novel opioid maintenance program for prisoners: preliminary findings. J Subst Abuse Treat. 2002;22(3):141–7. PMID: 12039617. Excluded: Incarcerated population12039617
Kinlock TW, Battjes RJ, Schwartz RP, . A novel opioid maintenance program for prisoners: report of post-release outcomes. Am J Drug Alcohol Abuse. 2005;31(3):433–54. PMID: 16161728. Excluded: Incarcerated population16161728
Kinlock TW, Gordon MS, Schwartz RP, . A randomized clinical trial of methadone maintenance for prisoners: results at 12 months postrelease. J Subst Abuse Treat. 2009;37(3):277–85. doi: 10.1016/j.jsat.2009.03.002. PMID: 19339140. Excluded: Incarcerated population19339140
Kinlock TW, Gordon MS, Schwartz RP, . A randomized clinical trial of methadone maintenance for prisoners: results at 1-month post-release. Drug Alcohol Depend. 2007;91(2-3):220–7. PMID: 17628351. Excluded: Incarcerated population17628351
Kinlock TW, Gordon MS, Schwartz RP, . A study of methadone maintenance for male prisoners: 3-month postrelease outcomes. Crim Justice Behav. 2008;35(1):34–47. doi: 10.1177/0093854807309111. PMID: 18612373. Excluded: Incarcerated population18612373
Kirby KC, Carpenedo CM, Dugosh KL, . Randomized clinical trial examining duration of voucher-based reinforcement therapy for cocaine abstinence. Drug Alcohol Depend. 2013;132(3):639–45. doi: 10.1016/j.drugalcdep.2013.04.015. PMID: 23680075. Excluded: Wrong comparator23680075
Kirby KC, Kerwin ME, Carpenedo CM, . Interdependent group contingency management for cocaine-dependent methadone maintenance patients. J Appl Behav Anal. 2008;41(4):579–95. PMID: 19192861. Excluded: Wrong comparator19192861
Kirby KC, Marlowe DB, Festinger DS, . Schedule of voucher delivery influences initiation of cocaine abstinence. J Consult Clin Psychol. 1998;66(5):761–7. PMID: 9803694. Excluded: Wrong comparator9803694
Kirchmayer U, Davoli M, Verster A. Naltrexone maintenance treatment for opioid dependence. Cochrane Database Syst Rev. 2003 (2):CD001333. PMID: 12804405. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies12804405
Kirchmayer U, Davoli M, Verster AD, . A systematic review on the efficacy of naltrexone maintenance treatment in opioid dependence. Addiction. 2002;97(10):1241–9. PMID: 12359026. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies12359026
Kleber HK. The CASA multi-center trial of acupuncture for cocaine dependence. Acupunct Electrother Res. 1997;22(69). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Klein NC, Alexander JF, Parsons BV. Impact of family systems intervention on recidivism and sibling delinquency: a model of primary prevention and program evaluation. J Consult Clin Psychol. 1977;45(3):469–74. PMID: 864062. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)864062
Knapp PW, Soares GOB, Farrell MF, . Psychosocial interventions for cocaine and psychostimulant amphetamines related disorders. Cochrane Database Syst Rev. 2015 (4) PMID: 17636713. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies17636713
Knapp WP, Soares BG, Farrel M, . Psychosocial interventions for cocaine and psychostimulant amphetamines related disorders. Cochrane Database Syst Rev. 2007 (3):CD003023. PMID: 17636713. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies17636713
Knealing TW, Wong CJ, Diemer KN, . A randomized controlled trial of the therapeutic workplace for community methadone patients: a partial failure to engage. Exp Clin Psychopharmacol. 2006;14(3):350–60. PMID: 16893278. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)16893278
Korcha RA, Polcin DL, Evans K, . Intensive motivational interviewing for women with concurrent alcohol problems and methamphetamine dependence. J Subst Abuse Treat. 2014;46(2):113–9. doi: 10.1016/j.jsat.2013.08.013. PMID: 24074649. Excluded: Wrong comparator24074649
Korthuis PT, Lum PJ, Vergara-Rodriguez P, . Feasibility and safety of extended-release naltrexone treatment of opioid and alcohol use disorder in HIV clinics: a pilot/feasibility randomized trial. Addiction. 2017;112(6):1036–44. doi: 10.1111/add.13753. PMID: 28061017. Excluded: Other wrong population (e.g., schizophrenia focus)28061017
Kosten T, Oliveto A, Feingold A, . Desipramine and contingency management for cocaine and opiate dependence in buprenorphine maintained patients. Drug Alcohol Depend. 2003;70(3):315–25. PMID: 12757969. Excluded: Wrong comparator12757969
Kosten T, Poling J, Oliveto A. Effects of reducing contingency management values on heroin and cocaine use for buprenorphine- and desipramine-treated patients. Addiction. 2003;98(5):665–71. PMID: 12751984. Excluded: Wrong comparator12751984
Kosten TR, Kleber HD, Morgan C. Treatment of cocaine abuse with buprenorphine. Biol Psychiatry. 1989;26(6):637–9. Excluded: Non-FDA approved pharmacologic intervention2790101
Kosten TR, Morgan C, Kleber HD. Phase II clinical trials of buprenorphine: detoxification and induction onto naltrexone. NIDA Res Monogr. 1992;121:101–19. PMID: 1406906. Excluded: Wrong comparator1406906
Kosten TR, Morgan CH, Schottenfeld RS. Amantadine and desipramine in the treatment of cocaine abusing methadone maintained patients. NIDA Res Monogr. 1990;105:510–1. PMID: 1876103. Excluded: Non-FDA approved pharmacologic intervention1876103
Kosten TR, Morgan CM, Falcione J, . Pharmacotherapy for cocaine-abusing methadone-maintained patients using amantadine or desipramine. Arch Gen Psychiatry. 1992;49(11):894–8. PMID: 1444728. Excluded: Non-FDA approved pharmacologic intervention1444728
Kosten TR, Schottenfeld R, Ziedonis D, . Buprenorphine versus methadone maintenance for opioid dependence. J Nerv Ment Dis. 1993;181(6):358–64. PMID: 8501457. Excluded: Wrong comparator8501457
Kosten TR, Schumann B, Wright D, . A preliminary study of desipramine in the treatment of cocaine abuse in methadone maintenance patients. J Clin Psychiatry. 1987;48(11):442–4. PMID: 3680185. Excluded: Non-FDA approved pharmacologic intervention3680185
Kosten TR, Steinberg M, Diakogiannis IA. Crossover trial of mazindol for cocaine dependence. Am J Addict. 1993;2(2):161–4. doi: 10.3109/10550499309115955. Excluded: Non-FDA approved pharmacologic intervention
Kosten TR, Wu G, Huang W, . Pharmacogenetic randomized trial for cocaine abuse: disulfiram and dopamine beta-hydroxylase. Biol Psychiatry. 2013;73(3):219–24. doi: 10.1016/j.biopsych.2012.07.011. PMID: 22906516. Excluded: Non-FDA approved pharmacologic intervention22906516
Kouimtsidis C, Reynolds M, Coulton S, . How does cognitive behaviour therapy work with opioid-dependent clients? Results of the UKCBTMM Study. Drugs Educ Prev Polic. 2012;19(3):253–8. doi: 10.3109/09687637.2011.579194. Excluded: Wrong comparator
Kourounis G, Richards BD, Kyprianou E, . Opioid substitution therapy: Lowering the treatment thresholds. Drug Alcohol Depend. 2016;161:1–8. doi: 10.1016/j.drugalcdep.2015.12.021. PMID: 26832931. Excluded: Wrong outcome26832931
Kowalczyk WJ, Phillips KA, Jobes ML, . Clonidine maintenance prolongs opioid abstinence and decouples stress from craving in daily life: A randomized controlled trial with ecological momentary assessment. Am J Psychiatry. 2015;172(8):760–7. doi: 10.1176/appi.ajp.2014.14081014. PMID: 25783757. Excluded: Non-FDA approved pharmacologic intervention25783757
Kraft MK, Rothbard AB, Hadley TR, . Are supplementary services provided during methadone maintenance really cost-effective? Am J Psychiatry. 1997;154(9):1214–9. PMID: 9286179. Excluded: Wrong comparator9286179
Krupitsky E, Kibitov A, Zvartau E, . Pharmacogenetics of treatment of opioid dependence with oral naltrexone and long-acting sustained-release naltrexone implant. Drug Alcohol Depend. 2014;146(14). Excluded: Wrong outcome
Krupitsky E, Nunes EV, Ling W, . Injectable extended-release naltrexone (XR-NTX) for opioid dependence: long-term safety and effectiveness. Addiction. 2013;108(9):1628–37. doi: 10.1111/add.12208. PMID: 23701526. Excluded: Wrong study design for key question23701526
Krupitsky E, Zvartau E, Blokhina E, . Pharmacogenetics of treatment of opioid dependence with oral naltrexone and long acting sustained release naltrexone implant. Eur Neuropsychopharmacol. 2013;23(5). Excluded: Wrong outcome
Krupitsky E, Zvartau E, Blokhina E, . Anhedonia, depression, anxiety, and craving for opiates in opiate addicts stabilized on oral naltrexone and long acting naltrexone implant. Drug Alcohol Depend. 2015;156(13). Excluded: Results reported elsewhere, duplicate results
Krupitsky E, Zvartau E, Blokhina E, . Anhedonia, depression, anxiety, and craving for opiates in opiate addicts stabilized on oral naltrexone and long acting naltrexone implant. Eur Neuropsychopharmacol. 2015;25(29). Excluded: Results reported elsewhere, duplicate results
Krupitsky E, Zvartau E, Blokhina E, . Anhedonia, depression, anxiety, and craving for opiates in opiate dependent patients stabilized on oral naltrexone or an extended release naltrexone implant. Neuropsychopharmacology. Conference: 55th annual meeting of the American College of Neuropsychopharmacology, ACNP. 2016;41:S205–S6. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Krupitsky E, Zvartau E, Masalov D, . Doubleblind placebo-controlled randomized clinical trial of naltrexone for heroin addiction and HIV risk reduction in Russia. Drug Alcohol Depend. 2002;66. Excluded: Results reported elsewhere, duplicate results
Krupitsky E, Zvartau EE, Woody G. Long acting naltrexone implants for heroin dependence. Eur Neuropsychopharmacol. 2009;19(12). Excluded: Results reported elsewhere, duplicate results
Kumpfer KL, Alvarado R, Whiteside HO. Family-based interventions for substance use and misuse prevention. Subst Use Misuse. 2003;38(11-13):1759–87. PMID: 14582577. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.14582577
Kunoe N, Lobmaier P, Vederhus JK, . Naltrexone implants after in-patient treatment for opioid dependence: randomised controlled trial. Br J Addict. 2009;194(6):541–6. doi: 10.1192/bjp.bp.108.055319. PMID: 19478295. Excluded: Wrong comparator19478295
Kunoe N, Opheim A, Solli KK, . Design of a randomized controlled trial of extended-release naltrexone versus daily buprenorphine-naloxone for opioid dependence in Norway (NTX-SBX). BMC Pharmacol Toxicol. 2016;17(1):18. doi: 10.1186/s40360-016-0061-1. PMID: 27121539. Excluded: Wrong comparator27121539
Kurland AA, McCabe L, Hanlon TE. Contingent naloxone (N-allylnoroxymorphone) treatment of the paroled narcotic addict. Int Pharmacopsychiatry. 1975;10(3):157–68. PMID: 1099047. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)1099047
Kurti AN, Davis D, Redner R, . A review of the literature on remote monitoring technology in incentive-based interventions for health-related behavior change. Transl Issues Psychol Sci. 2016;2(2):128–52. doi: 10.1037/tps0000067. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27777964
Kurtz SP, Buttram ME, Pagano ME, . A randomized trial of brief assessment interventions for young adults who use drugs in the club scene. J Subst Abuse Treat. 2017;78:64–73. doi: 10.1016/j.jsat.2017.05.008. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28554606
Kurtz SP, Stall RD, Buttram ME, . A randomized trial of a behavioral intervention for high risk substance-using MSM. Aids Behav. 2013;17(9):2914–26. doi: 10.1007/s10461-013-0531-z. PMID: 23732957. Excluded: Other wrong population (e.g., schizophrenia focus)23732957
LaCour F, Elk R, Grabowski J, . Contingency management interventions in the treatment of cocaine-dependent patients infected with tubercolosis. NIDA Res Monogr. 1997;174(76). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Lagisetty P, Klasa K, Bush C, . Primary care models for treating opioid use disorders: What actually works? A systematic review. PLoS One. 2017;12(10):e0186315. doi: 10.1371/journal.pone.0186315. PMID: 29040331. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies29040331
Lakshmana G. Efficacy of combination of motivational interviewing and cognitive behavior intervention with substance abuse street adolescents in India: A randomized control study. J Soc Work Pract Addict. 2016;16(4):337–57. doi: 10.1080/1533256X.2016.1235414. Excluded: Wrong country
Landabaso MA, Iraurgi I, Jimenez-Lerma JM, . A randomized trial of adding fluoxetine to a naltrexone treatment programme for heroin addicts. Addiction. 1998;93(5):739–44. PMID: 9692272. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)9692272
Landovitz RJ, Fletcher JB, Shoptaw S, . Contingency management facilitates the use of postexposure prophylaxis among stimulant-using men who have sex with men. Open Forum Infect Dis. 2015;2(1) PMID: 25884003. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)25884003
Laporte C, Vaillant-Roussel H, Pereira B, . Cannabis and young users-a brief intervention to reduce their consumption (CANABIC): A cluster randomized controlled trial in primary care. Ann Fam Med. 2017;15(2):131–9. doi: 10.1370/afm.2003. PMID: 28289112. Excluded: Poor quality28289112
Laporte C, Vaillant-Roussel H, Pereira B, . CANABIC: CANnabis and adolescents: Effect of a brief intervention on their consumption - study protocol for a randomized controlled trial. Trials. 2014;15 PMID: 24479702. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.24479702
Larney S. Does opioid substitution treatment in prisons reduce injecting-related HIV risk behaviours? A systematic review. Addiction. 2010;105(2):216–23. doi: 10.1111/j.1360-0443.2009.02826.x. PMID: 20078480. Excluded: Incarcerated population20078480
Larochelle M, Bernson D, Land T, . Mortality after nonfatal opioid overdose: Medications for opioid use disorder are associated with lower risk. J Gen Intern Med. 2017;32(2):S250. Excluded: Wrong comparator
Lascaux M, Ionescu S, Phan O. Effectiveness of formalised therapy for adolescents with cannabis dependence: A randomised trial. Drugs Educ Prev Polic. 2016;23(5):404–9. doi: 10.3109/09687637.2016.1153603. Excluded: Wrong comparator
Lash SJ, Stephens RS, Burden JL, . Contracting, prompting, and reinforcing substance use disorder continuing care: a randomized clinical trial. Psychol Addict Behav. 2007;21(3):387–97. PMID: 17874889. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17874889
Latimer WW, Winters KC, D’Zurilla T, . Integrated family and cognitive-behavioral therapy for adolescent substance abusers: a stage I efficacy study. Drug Alcohol Depend. 2003;71(3):303–17. PMID: 12957348. Excluded: Wrong comparator12957348
Laurer M, van der Vennet R. Effect of art production on negative mood and anxiety for adults in treatment for substance abuse. Art Therapy. 2015;32(4):177–83. doi: 10.1080/07421656.2015.1092731. Excluded: Wrong study design for key question
Lavonas EJ, Severtson SG, Martinez EM, . Abuse and diversion of buprenorphine sublingual tablets and film. J Subst Abuse Treat. 2014;47(1):27–34. doi: 10.1016/j.jsat.2014.02.003. PMID: 24680219. Excluded: Wrong outcome24680219
Law FD, Diaper AM, Melichar JK, . Buprenorphine/naloxone versus methadone and lofexidine in community stabilisation and detoxification: A randomised controlled trial of low dose short-term opiate-dependent individuals. J Psychopharmacol. 2017;31(8):1046–55. doi: 10.1177/0269881117711710. PMID: 28631527. Excluded: Wrong comparator28631527
Law FD, Nutt DJ. Maintenance buprenorphine for opioid users. Lancet. 2003;361(9358):634–5. PMID: 12606172. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.12606172
Ledberg A. Mortality related to methadone maintenance treatment in Stockholm, Sweden, during 2006-2013. J Subst Abuse Treat. 2017;74:35–41. doi: 10.1016/j.jsat.2016.12.005. PMID: 28132698. Excluded: Wrong study design for key question28132698
Ledgerwood DM, Alessi SM, Hanson T, . Contingency management for attendance to group substance abuse treatment administered by clinicians in community clinics. J Appl Behav Anal. 2008;41(4):517–26. PMID: 19192856. Excluded: Wrong comparator19192856
Ledgerwood DM, Petry NM. Does contingency management affect motivation to change substance use? Drug Alcohol Depend. 2006;83(1):65–72. PMID: 16310974. Excluded: Wrong comparator16310974
Lee DC, Budney AJ, Brunette MF, . Outcomes from a computer-assisted intervention simultaneously targeting cannabis and tobacco use. Drug Alcohol Depend. 2015;155:134–40. doi: 10.1016/j.drugalcdep.2015.08.001. PMID: 26307942. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)26307942
Lee EB, An W, Levin ME, . An initial meta-analysis of acceptance and commitment therapy for treating substance use disorders. Drug Alcohol Depend. 2015;155:1–7. doi: 10.1016/j.drugalcdep.2015.08.004. PMID: 26298552. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26298552
Lee J, Gourevitch MN, Joseph H, . Effectiveness of buprenorphine vs. methadone maintenance in jail and post-release: A pilot study. Subst Abus. 2009;30(2):204–5. doi: 10.1080/08897070902802133. Excluded: Incarcerated population
Lee JD, Friedmann PD, Boney TY, . Extended-release naltrexone to prevent relapse among opioid dependent, criminal justice system involved adults: rationale and design of a randomized controlled effectiveness trial. Contemp Clin Trials. 2015;41:110–7. doi: 10.1016/j.cct.2015.01.005. PMID: 25602580. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.25602580
Lee JD, Friedmann PD, Kinlock TW, . Extended-release naltrexone to prevent opioid relapse in criminal justice offenders. N Engl J Med. 2016;374(13):1232–42. doi: 10.1056/NEJMoa1505409. PMID: 27028913. Excluded: Wrong comparator27028913
Lee JD, Friedmann PD, Kinlock TW, . Extended-release naltrexone for opioid relapse prevention among opioid-dependent, criminal justice-involved adults. Drug Alcohol Depend. 2015;156(13). Excluded: Wrong comparator
Lee JD, Grossman E, Truncali A, . Buprenorphine-naloxone maintenance following release from jail. Subst Abus. 2012;33(1):40–7. doi: 10.1080/08897077.2011.620475. PMID: 22263712. Excluded: Wrong study design for key question22263712
Lee JD, McDonald R, Grossman E, . Opioid treatment at release from jail using extended-release naltrexone: a pilot proof-of-concept randomized effectiveness trial. Addiction. 2015;110(6):1008–14. doi: 10.1111/add.12894. PMID: 25703440. Excluded: <3 month followup duration25703440
Lee JD, Nunes EV, Mpa PN, . NIDA clinical trials network CTN-0051, extended-release naltrexone vs. buprenorphine for opioid treatment (X:BOT): Study design and rationale. Contemp Clin Trials. 2016;50:253–64. doi: 10.1016/j.cct.2016.08.004. PMID: 27521809. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.27521809
Lee JD, Nunes EV, Jr., Novo P, . Comparative effectiveness of extended-release naltrexone versus buprenorphine-naloxone for opioid relapse prevention (X: bOT): a multicentre, open-label, randomised controlled trial. Lancet. 2018;27(391(10118)):309–19. doi: 10.1016/S0140-6736(17)32812-X. PMID: 29150198. Excluded: Wrong comparator29150198
Lee NK, Rawson RA. A systematic review of cognitive and behavioural therapies for methamphetamine dependence. Drug Alcohol Rev. 2008;27(3):309–17. doi: 10.1080/09595230801919494. PMID: 18368613. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies18368613
Lenz AS, Rosenbaum L, Sheperis D. Meta-analysis of randomized controlled trials of motivational enhancement therapy for reducing substance use. J Addict Offender Couns. 2016;37(2):66–86. doi: 10.1002/jaoc.12017. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Lerch J, Walters ST, Tang L, . Effectiveness of a computerized motivational intervention on treatment initiation and substance use: Results from a randomized trial. J Subst Abuse Treat. 2017;80:59–66. doi: 10.1016/j.jsat.2017.07.002. Excluded: <70% drug misuse or likely majority alcohol28755774
Lester KM, Milby JB, Schumacher JE, . Impact of behavioral contingency management intervention on coping behaviors and PTSD symptom reduction in cocaine-addicted homeless. J Trauma Stress. 2007;20(4):565–75. PMID: 17721968. Excluded: Wrong comparator17721968
Letourneau EJ, McCart MR, Sheidow AJ, . First evaluation of a contingency management intervention addressing adolescent substance use and sexual risk behaviors: Risk reduction therapy for adolescents. J Subst Abuse Treat. 2017;72:56–65. doi: 10.1016/j.jsat.2016.08.019. Excluded: Wrong comparator27629581
Levin FR. Randomized controlled pharmacotherapy trials for cannabis use disorder in adults. J Am Acad Child Adolesc Psychiatry. 2016;Conference: 63rd annual meeting of the American Academy of Child and Adolescent Psychiatry. United States. Conference start:. 20161024. Conference end: 20161029 55(10 Supplement 1):S66–S7. Excluded: Non-FDA approved pharmacologic intervention
Levin FR, Mariani JJ, Chicurel M, . Utility of a contingency management strategy to improve retention in a pharmacologic treatment trial targeting cannabis dependence. Proceedings of the 69th Annual Scientific Meeting of the College on Problems of Drug Dependence. 2007. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Lewis MW, Petry NM. Contingency management treatments that reinforce completion of goal-related activities: participation in family activities and its association with outcomes. Drug Alcohol Depend. 2005;79(2):267–71. PMID: 16002037. Excluded: Wrong study design for key question16002037
Lewis RA, Piercy FP, Sprenkle DH, . Family-based interventions for helping drug-abusing adolescents. J Adolesc Res. 1990;5(1):82–95. Excluded: Wrong comparator
Li L, Zhu S, Tse N, . Effectiveness of motivational interviewing to reduce illicit drug use in adolescents: a systematic review and meta-analysis. Addiction. 2016;111(5):795–805. doi: 10.1111/add.13285. PMID: 26687544. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26687544
Li W, Howard MO, Garland EL, . Mindfulness treatment for substance misuse: A systematic review and meta-analysis. J Subst Abuse Treat. 2017;75:62–96. doi: 10.1016/j.jsat.2017.01.008. PMID: 28153483. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28153483
Liang D, Han H, Du J, . A pilot study of a smartphone application supporting recovery from drug addiction. J Subst Abuse Treat. 2018;88:51–8. doi: 10.1016/j.jsat.2018.02.006. PMID: 29606226. Excluded: <3 month followup duration29606226
Liddle H, Dakof G. A randomized controlled trial of intensive outpatient, family-based therapy vs. residential drug treatment for co-morbid adolescent substance abusers. Drug Alcohol Depend. 2002;66(1):S103. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Liddle HA. Family-based therapies for adolescent alcohol and drug use: research contributions and future research needs. Addiction. 2004;99: Suppl 2:76–92. PMID: 15488107. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.15488107
Liddle HA. Multidimensional family therapy: A science-based treatment system for adolescent drug abuse. Sucht. 2010;56(1):43–50. doi: 10.1024/0939-5911/a000011. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Liddle HA. Multidimensional family therapy: Evidence base for transdiagnostic treatment outcomes, change mechanisms, and implementation in community settings. Fam Process. 2016;55(3):558–76. doi: 10.1111/famp.12243. PMID: 27565445. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.27565445
Liddle HA, Dakof GA, Henderson C, . Implementation outcomes of multidimensional family therapy-detention to community: A reintegration program for drug-using juvenile detainees. Int J Offender Ther Comp Criminol. 2011;55(4):587–604. doi: 10.1177/0306624x10366960. PMID: 20427547. Excluded: Incarcerated population20427547
Liddle HA, Dakof GA, Parker K, . Multidimensional family therapy for adolescent drug abuse: results of a randomized clinical trial. Am J Drug Alcohol Abuse. 2001;27(4):651–88. PMID: 11727882. Excluded: Wrong comparator11727882
Liddle HA, Dakof GA, Turner RM, . Treating adolescent drug abuse: a randomized trial comparing multidimensional family therapy and cognitive behavior therapy. Addiction. 2008;103(10):1660–70. doi: 10.1111/j.1360-0443.2008.02274.x. PMID: 18705691. Excluded: Wrong comparator18705691
Liddle HA, Rowe CL, Dakof GA, . Multidimensional family therapy for young adolescent substance abuse: twelve-month outcomes of a randomized controlled trial. J Consult Clin Psychol. 2009;77(1):12–25. doi: 10.1037/a0014160. PMID: 19170450. Excluded: Wrong comparator19170450
Liddle HA, Rowe CL, Dakof GA, . Early intervention for adolescent substance abuse: pretreatment to posttreatment outcomes of a randomized clinical trial comparing multidimensional family therapy and peer group treatment. J Psychoactive Drugs. 2004;36(1):49–63. PMID: 15152709. Excluded: Wrong comparator15152709
Liebschutz JM, Crooks D, Herman D, . Buprenorphine treatment for hospitalized, opioid-dependent patients: a randomized clinical trial. JAMA Intern Med. 2014;174(8):1369–76. doi: 10.1001/jamainternmed.2014.2556. PMID: 25090173. Excluded: Inpatient population25090173
Liebschutz JM, Crooks D, Herman DS, . Initiating buprenorphine maintenance for opiate-dependent hospitalized patients: A randomized controlled trial. J Gen Intern Med. 2013;28(24). Excluded: Inpatient population
Lincourt P, Kuettel TJ, Bombardier CH. Motivational interviewing in a group setting with mandated clients: a pilot study. Addict Behav. 2002;27(3):381–91. PMID: 12118626. Excluded: Wrong study design for key question12118626
Lindeman CA. Adolescent substance abuse: The seven challenges treatment modality versus cognitive behavioral therapy: Walden University; 2009. Excluded: Wrong comparator
Lindstrom M, Filges T, Jorgensen A-MK. Brief strategic family therapy for young people in treatment for drug use. Res Soc Work Pract. 2015;25(1):61–80. doi: 10.1177/1049731514530003. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Linehan MM, Dimeff LA, Reynolds SK, . Dialectical behavior therapy versus comprehensive validation therapy plus 12-step for the treatment of opioid dependent women meeting criteria for borderline personality disorder. Drug Alcohol Depend. 2002;67(1):13–26. PMID: 12062776. Excluded: Other wrong population (e.g., schizophrenia focus)12062776
Linehan MM, Schmidt H, 3rd, Dimeff LA, . Dialectical behavior therapy for patients with borderline personality disorder and drug-dependence. Am J Addict. 1999;8(4):279–92. PMID: 10598211. Excluded: Other wrong population (e.g., schizophrenia focus)10598211
Ling Murtaugh K, Krishnamurti T, Davis AL, . Spend today, clean tomorrow: predicting methamphetamine abstinence in a randomized controlled trial. Health Psychol. 2013;32(9):958–66. doi: 10.1037/a0032922. PMID: 24001246. Excluded: Wrong comparator24001246
Ling W, Amass L, Shoptaw S, . A multi-center randomized trial of buprenorphine-naloxone versus clonidine for opioid detoxification: findings from the National Institute on Drug Abuse Clinical Trials Network. Addiction. 2005;100(8):1090–100. PMID: 16042639. Excluded: Wrong comparator16042639
Ling W, Charuvastra C, Collins JF, . Buprenorphine maintenance treatment of opiate dependence: a multicenter, randomized clinical trial. Addiction. 1998;93(4):475–86. PMID: 9684386. Excluded: <3 month followup duration9684386
Ling W, Charuvastra C, Kaim SC, . Methadyl acetate and methadone as maintenance treatments for heroin addicts. A veterans administration cooperative study. Arch Gen Psychiatry. 1976;33(6):709–20. PMID: 779705. Excluded: Wrong comparator779705
Ling W, Dorus W, Hargreaves WA, . Alternative induction and crossover schedules for methadyl acetate. Arch Gen Psychiatry. 1984;41(2):193–9. PMID: 6365017. Excluded: Non-FDA approved pharmacologic intervention6365017
Ling W, Hillhouse M, Ang A, . Comparison of behavioral treatment conditions in buprenorphine maintenance. Addiction. 2013;108(10):1788–98. doi: 10.1111/add.12266. PMID: 23734858. Excluded: Wrong comparator23734858
Ling W, Klett CJ, Gillis RD. A cooperative clinical study of methadyl acetate. I. Three-times-a-week regimen. Arch Gen Psychiatry. 1978;35(3):345–53. PMID: 727887. Excluded: Non-FDA approved pharmacologic intervention727887
Ling W, Klett JC, Gillis RD. A cooperative clinical study of methadyl acetate. II. Friday-only regimen. Arch Gen Psychiatry. 1980;37(8):908–11. PMID: 7406654. Excluded: Non-FDA approved pharmacologic intervention7406654
Ling W, Shoptaw S, Hillhouse M, . Double-blind placebo-controlled evaluation of the PROMETATM protocol for methamphetamine dependence. Addiction. 2012;107(2):361–9. doi: 10.1111/j.1360-0443.2011.03619.x. PMID: 22082089. Excluded: Non-FDA approved pharmacologic intervention22082089
Ling W, Wesson DR, Charuvastra C, . A controlled trial comparing buprenorphine and methadone maintenance in opioid dependence. Arch Gen Psychiatry. 1996;53(5):401–7. PMID: 8624183. Excluded: Wrong comparator8624183
Lintzeris N, Bammer G, Rushworth L, . Buprenorphine dosing regime for inpatient heroin withdrawal: a symptom-triggered dose titration study. Drug Alcohol Depend. 2003;70(3):287–94. PMID: 12757966. Excluded: <3 month followup duration12757966
Lintzeris N, Bell J, Bammer G, . A randomized controlled trial of buprenorphine in the management of short-term ambulatory heroin withdrawal. Addiction. 2002;97(11):1395–404. PMID: 12410780. Excluded: Wrong comparator12410780
Lintzeris N, Leung SY, Dunlop AJ, . A randomised controlled trial of sublingual buprenorphine-naloxone film versus tablets in the management of opioid dependence. Drug Alcohol Depend. 2013;131(1-2):119–26. doi: 10.1016/j.drugalcdep.2012.12.009. PMID: 23317685. Excluded: Wrong comparator23317685
Lintzeris N, Strang J, Metrebian N, . Methodology for the randomised injecting opioid treatment trial (RIOTT): evaluating injectable methadone and injectable heroin treatment versus optimised oral methadone treatment in the UK. Harm Reduct J. 2006;3:28. PMID: 17002810. Excluded: Wrong comparator17002810
Liu S, Li L, Shen W, . Scopolamine detoxification technique for heroin dependence: A randomized trial. CNS Drugs. 2013;27(12):1093–102. doi: 10.1007/s40263-013-0111-9. PMID: 24092568. Excluded: Wrong comparator24092568
Lobmaier P, Kornor H, Kunoe N, . Sustained-release naltrexone for opioid dependence. Cochrane Database Syst Rev. 2008 (2):CD006140. doi: 10.1002/14651858.CD006140.pub2. PMID: 18425938. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies18425938
Lobmaier PP, Kunoe N, Gossop M, . Naltrexone implants compared to methadone: outcomes six months after prison release. Eur Addict Res. 2010;16(3):139–45. doi: 10.1159/000313336. PMID: 20424458. Excluded: Wrong comparator20424458
Lobmaier PP, Kunoe N, Gossop M, . Naltrexone depot formulations for opioid and alcohol dependence: a systematic review. CNS Neurosci Ther. 2011;17(6):629–36. doi: 10.1111/j.1755-5949.2010.00194.x. PMID: 21554565. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies21554565
Lofwall MR, Stitzer ML, Bigelow GE, . Comparative safety and side effect profiles of buprenorphine and methadone in the outpatient treatment of opioid dependence. Addict Disord Their Treat. 2005;4(2):49–64. Excluded: Wrong comparator
Lofwall MR, Strain EC, Stitzer ML, . Comparative safety and side-effect profiles of buprenorphine vs. methadone in the outpatient treatment of opioid dependence. Proceedings of the 66th Annual Scientific Meeting of College on Problems of Drug Dependence. 2004. Excluded: Results reported elsewhere, duplicate results
Lones CE, Bond GR, McGovern MP, . Individual placement and support (IPS) for methadone maintenance therapy patients: A pilot randomized controlled trial. Adm Policy Ment Health. 2017;44(3):359–64. doi: 10.1007/s10488-017-0793-2. PMID: 28213673. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28213673
Longshore D, Annon J, Anglin MD, . Levo-alpha-acetylmethadol (LAAM) versus methadone: treatment retention and opiate use. Addiction. 2005;100(8):1131–9. PMID: 16042643. Excluded: Non-FDA approved pharmacologic intervention16042643
Longshore D, Hsieh SC, Anglin MD. Reducing HIV risk behavior among injection drug users: effect of methadone maintenance treatment on number of sex partners. Int J Addict. 1994;29(6):741–57. PMID: 8034383. Excluded: Wrong study design for key question8034383
Lott DC, Strain EC, Brooner RK, . HIV risk behaviors during pharmacologic treatment for opioid dependence: a comparison of levomethadyl acetate [corrected] buprenorphine, and methadone. J Subst Abuse Treat. 2006;31(2):187–94. PMID: 16919747. Excluded: Wrong comparator16919747
Lott DC, Strain EC, Brooner RK, . HIV risk behaviors during pharmacologic treatment for opioid dependence: A comparison of levomethadyl acetate hydrochloride, buprenorphine, and methadone: “Erratum”. J Subst Abuse Treat. 2006;31(3):317. doi: 10.1016/j.jsat.2006.09.001. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Lotts VA. Predicting treatment-related change in adolescent substance use from change in recovery environment: Sam Houston State University; 2013. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Lowe J, Liang H, Riggs C, . Community partnership to affect substance abuse among Native American adolescents. Am J Drug Alcohol Abuse. 2012;38(5):450–5. doi: 10.3109/00952990.2012.694534. PMID: 22931079. Excluded: Wrong comparator22931079
Lua PL, Talib NS. Auricular acupuncture for drug dependence: an open-label randomized investigation on clinical outcomes, health-related quality of life, and patient acceptability. Altern Ther Health Med. 2013;19(4):28–42. PMID: 23981370. Excluded: Wrong comparator23981370
Lucas GM, Beauchamp G, Aramrattana A, . Short-term safety of buprenorphine/naloxone in HIV-seronegative opioid-dependent Chinese and Thai drug injectors enrolled in HIV Prevention Trials Network 058. Int J Drug Policy. 2012;23(2):162–5. doi: 10.1016/j.drugpo.2011.06.005. PMID: 21852093. Excluded: Wrong study design for key question21852093
Lucas GM, Chaudhry A, Hsu J, . Clinic-based treatment of opioid-dependent HIV-infected patients versus referral to an opioid treatment program: A randomized trial. Ann Intern Med. 2010;152(11):704–11. doi: 10.7326/0003-4819-152-11-201006010-00003. PMID: 20513828. Excluded: Wrong comparator20513828
Lucas GM, Young A, Donnell D, . Hepatotoxicity in a 52-week randomized trial of short-term versus long-term treatment with buprenorphine/naloxone in HIV-negative injection opioid users in China and Thailand. Drug Alcohol Depend. 2014;142:139–45. doi: 10.1016/j.drugalcdep.2014.06.013. PMID: 24999060. Excluded: Wrong comparator24999060
Ludwig AM, Levine J. A controlled comparison of five brief treatment techniques employing LSD, hypnosis, and psychotherapy. Am J Psychiatry. 1965;19:417–35. PMID: 14339608. Excluded: Wrong study design for key question14339608
Lugoboni F, Mirijello A, Zamboni L, . High prevalence of constipation and reduced quality of life in opioid-dependent patients treated with opioid substitution treatments. Expert Opin Pharmacother. 2016;17(16):2135–41. doi: 10.1080/14656566.2016.1232391. PMID: 27603712. Excluded: Wrong study design for key question27603712
Luoma JB, Kohlenberg BS, Hayes SC, . Slow and steady wins the race: a randomized clinical trial of acceptance and commitment therapy targeting shame in substance use disorders. J Consult Clin Psychol. 2012;80(1):43–53. doi: 10.1037/a0026070. PMID: 22040285. Excluded: Inpatient population22040285
Lussier JP, Heil SH, Mongeon JA, . A meta-analysis of voucher-based reinforcement therapy for substance use disorders. Addiction. 2006;101(2):192–203. PMID: 16445548. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies16445548
Luthar SS, Suchman NE, Altomare M. Relational psychotherapy mothers’ group: A randomized clinical trial for substance abusing mothers. Dev Psychopathol. 2007;19(1):243–61. PMID: 17241493. Excluded: Wrong comparator17241493
Ma J, Bao YP, Wang RJ, . Effects of medication-assisted treatment on mortality among opioids users: a systematic review and meta-analysis. Mol Psychiatry. 2018:1–16. doi: 10.1038/s41380-018-0094-5. PMID: 29934549. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)29934549
MacArthur GJ, Minozzi S, Martin N, . Opiate substitution treatment and HIV transmission in people who inject drugs: systematic review and meta-analysis. BMJ. 2012;345:e5945. doi: 10.1136/bmj.e5945. PMID: 23038795. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies23038795
Macgowan MJ, Engle B. Evidence for optimism: behavior therapies and motivational interviewing in adolescent substance abuse treatment. Child Adolesc Psychiatr Clin N Am. 2010;19(3):527–45. doi: 10.1016/j.chc.2010.03.006. PMID: 20682219. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.20682219
Maddux JF, Desmond DP, Vogtsberger KN. Patient-regulated methadone dose and optional counseling in methadone maintenance. Am J Addict. 1995;4(1):18–32. Excluded: Wrong comparator
Madigan K, Brennan D, Lawlor E, . A multi-center, randomized controlled trial of a group psychological intervention for psychosis with comorbid cannabis dependence over the early course of illness. Schizophr Res. 2013;143(1):138–42. doi: 10.1016/j.schres.2012.10.018. PMID: 23187069. Excluded: Other wrong population (e.g., schizophrenia focus)23187069
Madlung-Kratzer E, Spitzer B, Brosch R, . A double-blind, randomized, parallel group study to compare the efficacy, safety and tolerability of slow-release oral morphine versus methadone in opioid-dependent in-patients willing to undergo detoxification. 2009;104(9):1549–57. doi: 10.1111/j.1360-0443.2009.02653.x. PMID: 19686525. Excluded: Wrong comparator19686525
Madlung-Kratzer E, Spitzer B, Brosch R, . "A double-blind, randomized, parallel group study to compare the efficacy, safety and tolerability of slow-release oral morphine versus methadone in opioid dependent in-patients willing to undergo detoxification": Erratum. Addiction. 2009;104(11):1947. doi: 10.1111/j.1360-0443.2009.02818.x. Excluded: Inpatient population
Madras BK, Compton WM, Avula D, . Screening, brief interventions, referral to treatment (SBIRT) for illicit drug and alcohol use at multiple healthcare sites: Comparison at intake and 6 months later. Drug Alcohol Depend. 2009;99(1-3):280–95. doi: 10.1016/j.drugalcdep.2008.08.003. PMID: 18929451. Excluded: Wrong study design for key question18929451
Magidson JF, Gorka SM, MacPherson L, . Examining the effect of the life enhancement treatment for substance use (LETS ACT) on residential substance abuse treatment retention. Addict Behav. 2011;36(6):615–23. doi: 10.1016/j.addbeh.2011.01.016. PMID: 21310539. Excluded: Inpatient population21310539
Magill M. Cognitive-behavioral treatment with adult substance users: A meta-analysis. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2008;68(10-A):4479. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Magill M, Apodaca TR, Borsari B, . A meta-analysis of motivational interviewing process: Technical, relational, and conditional process models of change. J Consult Clin Psychol. 2018;86(2):140–57. doi: 10.1037/ccp0000250. Excluded: Wrong outcome29265832
Magill M, Ray LA. Cognitive-behavioral treatment with adult alcohol and illicit drug users: a meta-analysis of randomized controlled trials. J Stud Alcohol Drugs. 2009;70(4):516–27. PMID: 19515291. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies19515291
Magura S, Blankertz L, Madison EM, . An innovative job placement model for unemployed methadone patients: a randomized clinical trial. Subst Use Misuse. 2007;42(5):811–28. PMID: 17613946. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17613946
Magura S, Lee JD, Hershberger J, . Buprenorphine and methadone maintenance in jail and post-release: a randomized clinical trial. Drug Alcohol Depend. 2009;99(1-3):222–30. doi: 10.1016/j.drugalcdep.2008.08.006. PMID: 18930603. Excluded: Wrong comparator18930603
Malow RM, West JA, Corrigan SA, . Outcome of psychoeducation for HIV risk reduction. AIDS Educ Prev. 1994;6(2):113–25. PMID: 8018438. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)8018438
Mandell W, Vlahov D, Latkin CA, . Changes in HIV risk behaviors among counseled injecting drug users. J Drug Issues. 1994;24(3):555–67. doi: 10.1177/002204269402400314. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Manganiello AJ. A comparative study of hypnotherapy and psychotherapy in the treatment of methadone addicts. Am J Clin Hypn. 1984;26(4):273–9. doi: 10.1080/00029157.1984.10402575. PMID: 6486078. Excluded: Wrong comparator6486078
Mannaioni G, Lanzi C, Lotti M, . Methadone dose adjustments, plasma R-methadone levels and therapeutic outcome of heroin users: A randomized clinical trial. Eur Addict Res. 2018:9–18. doi: 10.1159/000485029. PMID: 29393208. Excluded: Wrong comparator29393208
Mannelli P, Patkar AA, Peindl K, . Very low dose naltrexone addition in opioid detoxification: A randomized, controlled trial. Addict Biol. 2009;14(2):204–13. doi: 10.1111/j.1369-1600.2008.00119.x. PMID: 18715283. Excluded: <3 month followup duration18715283
Mannelli P, Patkar AA, Peindl K, . Early outcomes following low dose naltrexone enhancement of opioid detoxification. Am J Addict. 2009;18(2):109–16. doi: 10.1080/10550490902772785. PMID: 19283561. Excluded: <3 month followup duration19283561
Mannelli P, Patkar AA, Peindl K, . Effectiveness of low-dose naltrexone in the post-detoxification treatment of opioid dependence. J Clin Psychopharmacol. 2007;27(5):468–74. PMID: 17873678. Excluded: Wrong comparator17873678
Mannelli P, Peindl K, Patkar AA, . Problem drinking and low-dose naltrexone-assisted opioid detoxification. J Stud Alcohol. 2011;72(3):507–13. PMID: 21513688. Excluded: <3 month followup duration21513688
Mannelli P, Peindl K, Wu LT, . The combination very low-dose naltrexone-clonidine in the management of opioid withdrawal. Am J Drug Alcohol Abuse. 2012;38(3):200–5. doi: 10.3109/00952990.2011.644003. PMID: 22233189. Excluded: Non-FDA approved pharmacologic intervention22233189
Mannelli P, Wu LT, Peindl KS, . Smoking and opioid detoxification: Behavioral changes and response to treatment. Nicotine Tob Res. 2013;15(10):1705–13. doi: 10.1093/ntr/ntt046. PMID: 23572466. Excluded: Wrong outcome23572466
Manning V, Best D, Faulkner N, . Does active referral by a doctor or 12-Step peer improve 12-Step meeting attendance? Results from a pilot randomised control trial. Drug Alcohol Depend. 2012;126(1-2):131–7. doi: 10.1016/j.drugalcdep.2012.05.004. PMID: 22677458. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)22677458
Mansergh G, Koblin BA, McKirnan DJ, . An intervention to reduce HIV risk behavior of substance-using men who have sex with men: a two-group randomized trial with a nonrandomized third group. PLoS Med. 2010;7(8):e1000329. doi: 10.1371/journal.pmed.1000329. PMID: 20811491. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)20811491
Manuel JK, Hagedorn HJ, Finney JW. Implementing evidence-based psychosocial treatment in specialty substance use disorder care. Psychol Addict Behav. 2011;25(2):225–37. doi: 10.1037/a0022398. PMID: 21668085. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)21668085
Marceau EM, Berry J, Lunn J, . Cognitive remediation improves executive functions, self-regulation and quality of life in residents of a substance use disorder therapeutic community. Drug Alcohol Depend. 2017;178:150–8. doi: 10.1016/j.drugalcdep.2017.04.023. PMID: 28651150. Excluded: Inpatient population28651150
March JC, Oviedo-Joekes E, Perea-Milla E, . Controlled trial of prescribed heroin in the treatment of opioid addiction. J Subst Abuse Treat. 2006;31(2):203–11. PMID: 16919749. Excluded: Non-FDA approved pharmacologic intervention16919749
Marchand KI, Oviedo-Joekes E, Guh D, . Client satisfaction among participants in a randomized trial comparing oral methadone and injectable diacetylmorphine for long-term opioid-dependency. BMC Health Serv Res. 2011;11:174. doi: 10.1186/1472-6963-11-174. PMID: 21791093. Excluded: Wrong comparator21791093
Margolin A. Acupuncture for the treatment of cocaine addiction: a randomized controlled trial. Survey of Anesthesiology. 2002;47(2):118. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Margolin A, Avants S, Change P, . Acupuncture for the treatment of cocaine dependence in methadone-maintained patients. Am J Addict. 1993;2(3):194–201. doi: 10.3109/10550499309113938. Excluded: Wrong study design for key question
Margolin A, Avants S, Malison RT, . High- and low-dose mazindol for cocaine dependence in methadone-maintained patients: A preliminary evaluation. Subst Abus. 1997;18(3):125–31. doi: 10.1080/08897079709511358. Excluded: Non-FDA approved pharmacologic intervention
Margolin A, Avants SK, Arnold R. Acupuncture and spirituality-focused group therapy for the treatment of HIV-positive drug users: a preliminary study. J Psychoactive Drugs. 2005;37(4):385–90. PMID: 16480165. Excluded: Wrong comparator16480165
Margolin A, Avants SK, Holford TR. Interpreting conflicting findings from clinical trials of auricular acupuncture for cocaine addiction: does treatment context influence outcome? J Altern Complement Med. 2002;8(2):111–21. PMID: 12006119. Excluded: <3 month followup duration12006119
Margolin A, Avants SK, Kleber HD. Rationale and design of the cocaine alternative treatments study (CATS): a randomized, controlled trial of acupuncture. J Altern Complement Med. 1998;4(4):405–18. PMID: 9884178. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)9884178
Margolin A, Avants SK, Kosten TR. Mazindol for relapse prevention to cocaine abuse in methadone-maintained patients. Am J Drug Alcohol Abuse. 1995;21(4):469–81. PMID: 8561098. Excluded: Non-FDA approved pharmacologic intervention8561098
Margolin A, Avants SK, Kosten TR, . A double-blind study of mazindol for treatment of cocaine abuse in newly abstinent cocaine abusing methadone-maintained patients: a prelliminary report. NIDA Res Monogr. 1994;141:446. Excluded: Non-FDA approved pharmacologic intervention
Margolin A, Avants SK, Warburton LA, . A randomized clinical trial of a manual-guided risk reduction intervention for HIV-positive injection drug users. Health Psychol. 2003;22(2):223–8. PMID: 12683743. Excluded: Wrong comparator12683743
Marijuana Treatment Project Research Group, Vendetti J, McRee B, . Correlates of pre-treatment drop-out among persons with marijuana dependence. Addiction. 2002;97: Suppl 1:125–34. PMID: 12460134. Excluded: Wrong study design for key question12460134
Marinković M, Djordjević-Jovanović L, Miljković S, . Quality of life of treated opiate addicts in the methadone maintenance program and those treated with buprenorphine. Vojnosanit Pregl. 2017;74(5):435–44. doi: 10.2298/VSP150710227M. Excluded: Wrong study design for key question
Marin-Navarrete R, Horigian VE, Medina-Mora ME, . Motivational enhancement treatment in outpatient addiction centers: A multisite randomized trial. Int J Clin Health Psychol. 2017;17(1):9–19. doi: 10.1016/j.ijchp.2016.05.001. Excluded: <70% drug misuse or likely majority alcohol30487876
Marques AC, Formigoni ML. Comparison of individual and group cognitive-behavioral therapy for alcohol and/or drug-dependent patients. Addiction. 2001;96(6):835–46. PMID: 11399215. Excluded: Other wrong population (e.g., schizophrenia focus)11399215
Marsch LA. The efficacy of methadone maintenance interventions in reducing illicit opiate use, HIV risk behavior and criminality: a meta-analysis. Addiction. 1998;93(4):515–32. PMID: 9684390. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies9684390
Marsch LA, Bickel WK, Badger GJ, . Buprenorphine treatment for opioid dependence: the relative efficacy of daily, twice and thrice weekly dosing. Drug Alcohol Depend. 2005;77(2):195–204. PMID: 15664721. Excluded: Wrong comparator15664721
Marsch LA, Bickel WK, Badger GJ, . Comparison of pharmacological treatments for opioid-dependent adolescents: a randomized controlled trial. Arch Gen Psychiatry. 2005;62(10):1157–64. PMID: 16203961. Excluded: Wrong comparator16203961
Marsch LA, Guarino H, Acosta M, . Web-based behavioral treatment for substance use disorders as a partial replacement of standard methadone maintenance treatment. J Subst Abuse Treat. 2014;46(1):43–51. doi: 10.1016/j.jsat.2013.08.012. PMID: 24060350. Excluded: Wrong comparator24060350
Marsch LA, Moore SK, Borodovsky JT, . A randomized controlled trial of buprenorphine taper duration among opioid-dependent adolescents and young adults. Addiction. 2016;111(8):1406–15. doi: 10.1111/add.13363. PMID: 26918564. Excluded: Wrong comparator26918564
Marsch LA, Stephens MA, Mudric T, . Predictors of outcome in LAAM, buprenorphine, and methadone treatment for opioid dependence. Exp Clin Psychopharmacol. 2005;13(4):293–302. PMID: 16366759. Excluded: Wrong comparator16366759
Marsden J, Goetz C, Meynen T, . Memory-focused cognitive therapy for cocaine use disorder: theory, procedures and preliminary evidence from an external pilot randomised controlled trial. EBioMedicine. 2018;29:177–89. doi: 10.1016/j.ebiom.2018.01.039. PMID: 29478874. Excluded: Wrong comparator29478874
Marshall K, Gowing L, Ali R, . Pharmacotherapies for cannabis dependence. Cochrane Database Syst Rev. 2014 (12) PMID: 25515775. Excluded: Non-FDA approved pharmacologic intervention25515775
Martell BA, Orson FM, Poling J, . Cocaine vaccine for the treatment of cocaine dependence in methadone-maintained patients: a randomized, double-blind, placebo-controlled efficacy trial. Arch Gen Psychiatry. 2009;66(10):1116–23. doi: 10.1001/archgenpsychiatry.2009.128. PMID: 19805702. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19805702
Martin G, Copeland J, Allsop S, . The adolescent cannabis check-up. Sixty Eight Annual Scientific Meeting of the College on Problems of Drug Dependence. 2005. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Martin WR, Jasinski DR, Mansky PA. Naltrexone, an antagonist for the treatment of heroin dependence. Effects in man. Arch Gen Psychiatry. 1973;28(6):784–91. PMID: 4707988. Excluded: Incarcerated population4707988
Mason WA, Kosterman R, Hawkins JD, . Reducing adolescents’ growth in substance use and delinquency: randomized trial effects of a parent-training prevention intervention. Prev Sci. 2003;4(3):203–12. PMID: 12940470. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)12940470
Matheson C, Jaffray M, Bond C, . Improving outcomes and quality of life for people on methadone maintenance therapy (MMT): The enhanced pharmacy services (EPS) randomised controlled trial. Int J Pharm Pract. 2010;18:75–6. doi: 10.1111/j.2042-7174.2010.tb00512.x. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Mattick RP, Ali R, White JM, . Buprenorphine versus methadone maintenance therapy: a randomized double-blind trial with 405 opioid-dependent patients. Addiction. 2003;98(4):441–52. PMID: 12653814. Excluded: Wrong comparator12653814
Mattick RP, Breen C, Kimber J, . Methadone maintenance therapy versus no opioid replacement therapy for opioid dependence. Cochrane Database Syst Rev. 2009 (3):CD002209. doi: 10.1002/14651858.CD002209.pub2. PMID: 19588333. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies19588333
Mattick RP, Breen C, Kimber J, . Buprenorphine maintenance versus placebo or methadone maintenance for opioid dependence. Cochrane Database Syst Rev. 2014 (2):CD002207. doi: 10.1002/14651858.CD002207.pub4. PMID: 24500948. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24500948
Mattick RP, Kimber J, Breen C, . Buprenorphine maintenance versus placebo or methadone maintenance for opioid dependence. Cochrane Database Syst Rev. 2008 (2):CD002207. doi: 10.1002/14651858.CD002207.pub3. PMID: 18425880. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies18425880
Matz J, Graff C, Vainio PJ, . Effect of nalmefene 20 and 80 mg on the corrected QT interval and T-wave morphology: a randomized, double-blind, parallel-group, placebo- and moxifloxacin-controlled, single-centre study. Clin Drug Invest. 2011;31(11):799–811. doi: 10.2165/11592950-000000000-00000. PMID: 21967071. Excluded: Non-FDA approved pharmacologic intervention21967071
Mauger S, Fraser R, Gill K. Utilizing buprenorphine-naloxone to treat illicit and prescription-opioid dependence. Neuropsychiatr Dis Treat. 2014;10:587–98. doi: 10.2147/NDT.S39692. PMID: 24741316. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.24741316
Mausbach BT, Semple SJ, Strathdee SA, . Efficacy of a behavioral intervention for increasing safer sex behaviors in HIV-negative, heterosexual methamphetamine users: results from the Fast-Lane Study. Ann Behav Med. 2007;34(3):263–74. PMID: 18020936. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)18020936
Mayer AR, Wilcox CE, Dodd AB, . The efficacy of attention bias modification therapy in cocaine use disorders. Am J Drug Alcohol Abuse. 2016;42(4):459–68. doi: 10.3109/00952990.2016.1151523. PMID: 27184297. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)27184297
Mayet S, Farrell M, Ferri M, . Psychosocial treatment for opiate abuse and dependence. Cochrane Database Syst Rev. 2005 (1):CD004330. PMID: 15744796. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies15744796
Mayet S, Farrell MF, Ferri M, . Psychosocial treatment for opiate abuse and dependence. Cochrane Database Syst Rev. 2014 (4) PMID: 15744796. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.15744796
Mays KL, Clark DL, Gordon AJ. Treating addiction with tunes: a systematic review of music therapy for the treatment of patients with addictions. Substance Abuse. 2008;29(4):51–9. doi: 10.1080/08897070802418485. PMID: 19042198. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies19042198
McAuley A, Aucott L, Matheson C. Exploring the life-saving potential of naloxone: A systematic review and descriptive meta-analysis of take home naloxone (THN) programmes for opioid users. Int J Drug Policy. 2015;26(12):1183–8. doi: 10.1016/j.drugpo.2015.09.011. PMID: 26508033. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26508033
McAuliffe WE. A randomized controlled trial of recovery training and self-help for opioid addicts in New England and Hong Kong. J Psychoactive Drugs. 1990;22(2):197–209. doi: 10.1080/02791072.1990.10472544. PMID: 2197394. Excluded: Other wrong population (e.g., schizophrenia focus)2197394
McCambridge J, Gossop M, Beswick T, . In-patient detoxification procedures, treatment retention, and post-treatment opiate use: comparison of lofexidine + naloxone, lofexidine + placebo, and methadone. Drug Alcohol Depend. 2007;88(1):91–5. PMID: 17064857. Excluded: Wrong outcome17064857
McCaul ME, Stitzer ML, Bigelow GE, . Contingency management interventions: effects on treatment outcome during methadone detoxification. J Appl Behav Anal. 1984;17(1):35–43. PMID: 6725168. Excluded: <3 month followup duration6725168
McDermott KA, Griffin ML, Connery HS, . Initial response as a predictor of 12-week buprenorphine-naloxone treatment response in a prescription opioid-dependent population. J Clin Psychiatry. 2015;76(2):189–94. doi: 10.4088/JCP.14m09096. PMID: 25562462. Excluded: Wrong comparator25562462
McDonald R, Strang J. Are take-home naloxone programmes effective? Systematic review utilizing application of the Bradford Hill criteria. Addiction. 2016;111(7):1177–87. doi: 10.1111/add.13326. PMID: 27028542. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27028542
McDonald RD, Tofighi B, Laska E, . Extended-release naltrexone opioid treatment at jail reentry (XOR). Contemp Clin Trials. 2016;49:57–64. doi: 10.1016/j.cct.2016.05.002. PMID: 27178765. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.27178765
McGillicuddy NB, Rychtarik RG, Duquette JA, . Development of a skill training program for parents of substance-abusing adolescents. J Subst Abuse Treat. 2001;20(1):59–68. PMID: 11239729. Excluded: <3 month followup duration11239729
McGillicuddy NB, Rychtarik RG, Papandonatos GD. Skill training versus 12-step facilitation for parents of substance-abusing teens. J Subst Abuse Treat. 2015;50:11–7. doi: 10.1016/j.jsat.2014.09.006. PMID: 25306932. Excluded: Wrong outcome25306932
McGlone L, Mactier H. Infants of opioid-dependent mothers: neurodevelopment at six months. Early Hum Dev. 2015;91(1):19–21. doi: 10.1016/j.earlhumdev.2014.10.006. PMID: 25460252. Excluded: Wrong study design for key question25460252
McGovern MP, Lambert-Harris C, Xie H, . A randomized controlled trial of treatments for co-occurring substance use disorders and post-traumatic stress disorder. Addiction. 2015;110(7):1194–204. doi: 10.1111/add.12943. PMID: 25846251. Excluded: Other wrong population (e.g., schizophrenia focus)25846251
McGregor C, Ali R, White JM, . A comparison of antagonist-precipitated withdrawal under anesthesia to standard inpatient withdrawal as a precursor to maintenance naltrexone treatment in heroin users: outcomes at 6 and 12 months. Drug Alcohol Depend. 2002;68(1):5–14. PMID: 12167548. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)12167548
McKay JR, Alterman AI, Cacciola JS, . Group counseling versus individualized relapse prevention aftercare following intensive outpatient treatment for cocaine dependence: initial results. J Consult Clin Psychol. 1997;65(5):778–88. PMID: 9337497. Excluded: Wrong comparator9337497
McKay JR, Lynch KG, Shepard DS, . The effectiveness of telephone-based continuing care for alcohol and cocaine dependence: 24-month outcomes. Arch Gen Psychiatry. 2005;62(2):199–207. Excluded: Wrong comparator15699297
McKay JR, van Horn D, Ivey M, . Enhanced continuing care provided in parallel to intensive outpatient treatment does not improve outcomes for patients with cocaine dependence. J Stud Alcohol Drugs. 2013;74(4):642–51. PMID: 23739030. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)23739030
McKay JR, Van Horn DH, Lynch KG, . An adaptive approach for identifying cocaine dependent patients who benefit from extended continuing care. J Consult Clin Psychol. 2013;81(6):1063–73. doi: 10.1037/a0034265. PMID: 24041231. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)24041231
McKeganey N, Russell C, Cockayne L. Medically assisted recovery from opiate dependence within the context of the UK drug strategy: methadone and Suboxone (buprenorphine-naloxone) patients compared. J Subst Abuse Treat. 2013;44(1):97–102. doi: 10.1016/j.jsat.2012.04.003. PMID: 22703715. Excluded: Wrong comparator22703715
McKellar J, Wagner T, Harris A, . One-year outcomes of telephone case monitoring for patients with substance use disorder. Addict Behav. 2012;37(10):1069–74. doi: 10.1016/j.addbeh.2012.03.009. PMID: 22651986. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)22651986
McKenzie M, Zaller N, Dickman SL, . A randomized trial of methadone initiation prior to release from incarceration. Subst Abus. 2012;33(1):19–29. doi: 10.1080/08897077.2011.609446. PMID: 22263710. Excluded: Incarcerated population22263710
McLachlan C, Crofts N, Wodak A, . The effects of methadone on immune function among injecting drug users: a review. Addiction. 1993;88(2):257–63. PMID: 8220063. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.8220063
McLellan AT, Arndt IO, Metzger DS, . The effects of psychosocial services in substance abuse treatment. JAMA. 1993;269(15):1953–9. PMID: 8385230. Excluded: Wrong comparator8385230
McLellan AT, Grossman DS, Blaine JD, . Acupuncture treatment for drug abuse: a technical review. J Subst Abuse Treat. 1993;10(6):569–76. PMID: 8308942. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)8308942
McLoughlin BC, PushpaRajah JA, Gillies D, . Cannabis and schizophrenia. Cochrane Database Syst Rev. 2014 (10)doi: 10.1002/14651858.CD004837.pub3. PMID: 25314586. Excluded: Other wrong population (e.g., schizophrenia focus)25314586
McMillan GP, Lapham S, Lackey M. The effect of a jail methadone maintenance therapy (MMT) program on inmate recidivism. Addiction. 2008;103(12):2017–23. doi: 10.1111/j.1360-0443.2008.02361.x. PMID: 19469745. Excluded: Incarcerated population19469745
McNicholas LF, Holbrook AM, O’Grady KE, . Effect of hepatitis C virus status on liver enzymes in opioid-dependent pregnant women maintained on opioid-agonist medication. Addiction. 2012;107: Suppl 1:91–7. doi: 10.1111/j.1360-0443.2012.04043.x. PMID: 23106931. Excluded: Wrong comparator23106931
McRae AL, Budney AJ, Brady KT. Treatment of marijuana dependence: a review of the literature. J Subst Abuse Treat. 2003;24(4):369–76. PMID: 12867212. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies12867212
Meade CS, Weiss RD, Fitzmaurice GM, . HIV risk behavior in treatment-seeking opioid-dependent youth: Results from a NIDA clinical trials network multisite study. J Acquir Immune Defic Syndr. 2010;55(1):65–72. doi: 10.1097/QAI.0b013e3181d916db. PMID: 20393347. Excluded: Wrong comparator20393347
Meader N. A comparison of methadone, buprenorphine and alpha(2) adrenergic agonists for opioid detoxification: a mixed treatment comparison meta-analysis. Drug Alcohol Depend. 2010;108(1-2):110–4. doi: 10.1016/j.drugalcdep.2009.12.008. PMID: 20074867. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies20074867
Meader N, Li R, Des Jarlais CD, . Psychosocial interventions for reducing injection and sexual risk behaviour for preventing HIV in drug users. Cochrane Database Syst Rev. 2010 (1)doi: 10.1002/14651858.CD007192.pub2. PMID: 20091623. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies20091623
Meandzija B, O’Connor PG, Fitzgerald B, . HIV infection and cocaine use in methadone maintained and untreated intravenous drug users. Drug Alcohol Depend. 1994;36(2):109–13. PMID: 7851277. Excluded: Wrong study design for key question7851277
Medvin RB, Brooks AC, Carpenedo CM, . Expanded brief intervention in primary care results in reduced self-reported substance use at six-month follow-up: Preliminary results. Drug Alcohol Depend. 2015;156(13). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Meier A, McGovern MP, Lambert-Harris C, . Adherence and competence in two manual-guided therapies for co-occurring substance use and posttraumatic stress disorders: clinician factors and patient outcomes. Am J Drug Alcohol Abuse. 2015;41(6):527–34. doi: 10.3109/00952990.2015.1062894. PMID: 26286351. Excluded: Other wrong population (e.g., schizophrenia focus)26286351
Melendez-Torres GJ, Bonell C. Systematic review of cognitive behavioural interventions for HIV risk reduction in substance-using men who have sex with men. Int J STD AIDS. 2014;25(9):627–35. doi: 10.1177/0956462413515638. PMID: 24352122. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24352122
Mello NK, Mendelson JH, Kuehnle JC, . Operant analysis of human heroin self-administration and the effects of naltrexone. J Pharmacol Exp Ther. 1981;216(1):45–54. PMID: 7452507. Excluded: <3 month followup duration7452507
Mendelson J, Jones RT, Welm S, . Buprenorphine and naloxone combinations: the effects of three dose ratios in morphine-stabilized, opiate-dependent volunteers. Psychopharmacology (Berl). 1999;141(1):37–46. PMID: 9952063. Excluded: <3 month followup duration9952063
Mendelson J, Jones RT, Welm S, . Buprenorphine and naloxone interactions in methadone maintenance patients. Biol Psychiatry. 1997;41(11):1095–101. PMID: 9146820. Excluded: <3 month followup duration9146820
Menza TW, Jameson DR, Hughes JP, . Contingency management to reduce methamphetamine use and sexual risk among men who have sex with men: a randomized controlled trial. BMC Public Health. 2010;10:774. doi: 10.1186/1471-2458-10-774. PMID: 21172026. Excluded: Wrong comparator21172026
Merchant RC, Baird JR, Liu T. Short-term efficacy of a brief intervention to reduce drug misuse and increase drug treatment utilization among adult emergency department patients. Acad Emerg Med. 2015;22(10):1172–80. doi: 10.1111/acem.12767. PMID: 26375468. Excluded: Poor quality26375468
Merchant RC, Baird JR, Liu T, . Brief intervention to increase emergency department uptake of combined rapid human immunodeficiency virus and hepatitis C screening among a drug misusing population. Acad Emerg Med. 2014;21(7):752–67. doi: 10.1111/acem.12419. PMID: 25125271. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)25125271
Merchant RC, Zhang Z, Liu T, . Does a brief intervention reduce drug use and increase drug treatment utilization among adult emergency department patients over a one-year period? Acad Emerg Med. 2016;23(10). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Messina N, Farabee D, Rawson R. Treatment responsivity of cocaine-dependent patients with antisocial personality disorder to cognitive-behavioral and contingency management interventions. J Consult Clin Psychol. 2003;71(2):320–9. PMID: 12699026. Excluded: Wrong comparator12699026
Metz V, Jagsch R, Ebner N, . Impact of treatment approach on maternal and neonatal outcome in pregnant opioid-maintained women. Hum Psychopharmacol. 2011;26(6):412–21. doi: 10.1002/hup.1224. PMID: 21823171. Excluded: Wrong comparator21823171
Metzger DS, Donnell D, Celentano DD, . Expanding substance use treatment options for HIV prevention with buprenorphine-naloxone: HIV prevention trials network 058. J Acquir Immune Defic Syndr. 2015;68(5):554–61. doi: 10.1097/QAI.0000000000000510. PMID: 25564105. Excluded: Wrong comparator25564105
Meyer MC, Johnston AM, Crocker AM, . Methadone and buprenorphine for opioid dependence during pregnancy: a retrospective cohort study. J Addict Med. 2015;9(2):81–6. doi: 10.1097/ADM.0000000000000092. PMID: 25622120. Excluded: Wrong comparator25622120
Michel L, Lions C, Maradan G, . Suicidal risk among patients enrolled in methadone maintenance treatment: HCV status and implications for suicide prevention (ANRS Methaville). Compr Psychiatry. 2015;62:123–31. doi: 10.1016/j.comppsych.2015.07.004. PMID: 26343476. Excluded: Wrong study design for key question26343476
Milburn NG, Iribarren FJ, Rice E, . A family intervention to reduce sexual risk behavior, substance use, and delinquency among newly homeless youth. J Adolesc Health. 2012;50(4):358–64. doi: 10.1016/j.jadohealth.2011.08.009. PMID: 22443839. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)22443839
Milby JB, Clarke C, Toro C, . Effectiveness of urine surveillance as an adjunct to outpatient psychotherapy for drug abusers. Int J Addict. 1980;15(7):993–1001. PMID: 7450954. Excluded: Wrong comparator7450954
Milby JB, Garrett C, English C, . Take-home methadone: contingency effects on drug-seeking and productivity of narcotic addicts. Addict Behav. 1978;3(3-4):215–20. PMID: 735908. Excluded: Wrong comparator735908
Milby JB, Schumacher JE, Raczynski JM, . Sufficient conditions for effective treatment of substance abusing homeless persons. Drug Alcohol Depend. 1996;43(1-2):39–47. doi: 10.1016/S0376-8716%2896%2901286-0. Excluded: Other wrong population (e.g., schizophrenia focus)8957141
Miller WR, Yahne CE, Tonigan JS. Motivational interviewing in drug abuse services: a randomized trial. J Consult Clin Psychol. 2003;71(4):754–63. PMID: 12924680. Excluded: Wrong comparator12924680
Mills EJ, Wu P, Gagnier J, . Efficacy of acupuncture for cocaine dependence: A systematic review & meta-analysis. Harm Reduct J. 2005;2. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Min Z, Xu L, Chen H, . A pilot assessment of relapse prevention for heroin addicts in a Chinese rehabilitation center. Am J Drug Alcohol Abuse. 2011;37(3):141–7. doi: 10.3109/00952990.2010.538943. PMID: 21438799. Excluded: Wrong study design for key question21438799
Minozzi S, Amato L, Bellisario C, . Maintenance treatments for opiate -dependent adolescents. Cochrane Database Syst Rev. 2014 (6):CD007210. doi: 10.1002/14651858.CD007210.pub3. PMID: 24957634. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.24957634
Minozzi S, Amato L, Bellisario C, . Detoxification treatments for opiate dependent adolescents. Cochrane Database Syst Rev. 2014 (4):CD006749. doi: 10.1002/14651858.CD006749.pub3. PMID: 24777492. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)24777492
Minozzi S, Amato L, Bellisario C, . Maintenance agonist treatments for opiate-dependent pregnant women. Cochrane Database Syst Rev. 2013 (12):CD006318. doi: 10.1002/14651858.CD006318.pub3. PMID: 24366859. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24366859
Minozzi S, Amato L, Davoli M. Maintenance treatments for opiate dependent adolescent. Cochrane Database Syst Rev. 2009 (2):CD007210. doi: 10.1002/14651858.CD007210.pub2. PMID: 19370679. Excluded: Wrong comparator19370679
Minozzi S, Amato L, Davoli M. Detoxification treatments for opiate dependent adolescents. Cochrane Database Syst Rev. 2009 (2):CD006749. doi: 10.1002/14651858.CD006749.pub2. PMID: 19370651. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19370651
Minozzi S, Amato L, Pani PP, . Dopamine agonists for the treatment of cocaine dependence. Cochrane Database Syst Rev. 2015 (5) PMID: 26014366. Excluded: Non-FDA approved pharmacologic intervention26014366
Minozzi S, Amato L, Vecchi S, . Oral naltrexone maintenance treatment for opioid dependence. Cochrane Database Syst Rev. 2011 (4):CD001333. doi: 10.1002/14651858.CD001333.pub4. PMID: 21491383. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.21491383
Minozzi S, Cinquini M, Amato L, . Anticonvulsants for cocaine dependence. Cochrane Database Syst Rev. 2015 (6) PMID: 25882271. Excluded: Non-FDA approved pharmacologic intervention25882271
Mintz J, O’Brien CP, O’Hare K, . Double-blind detoxification of methadone maintenance patients. Int J Addict. 1975;10(5):815–24. PMID: 1176233. Excluded: Wrong comparator1176233
Mintzer MZ, Correia CJ, Strain EC. A dose-effect study of repeated administration of buprenorphine/naloxone on performance in opioid-dependent volunteers. Drug Alcohol Depend. 2004;74(2):205–9. PMID: 15099664. Excluded: <3 month followup duration15099664
Miranda R, Ray L, Blanchard A, . Effects of naltrexone on adolescent alcohol cue reactivity and sensitivity: an initial randomized trial. Addict Biol. 2014;19(5):941–54. doi: 10.1111/adb.12050. PMID: 23489253. Excluded: Other wrong population (e.g., schizophrenia focus)23489253
Mitchell SG, Gryczynski J, Schwartz RP, . Changes in quality of life following buprenorphine treatment: Relationship with treatment retention and illicit opioid use. J Psychoactive Drugs. 2015;47(2):149–57. doi: 10.1080/02791072.2015.1014948. PMID: 25950595. Excluded: Wrong study design for key question25950595
Mitchell SG, Gryczynski J, Schwartz RP, . A randomized trial of intensive outpatient (IOP) vs. standard outpatient (OP) buprenorphine treatment for African Americans. Drug Alcohol Depend. 2013;128(3):222–9. doi: 10.1016/j.drugalcdep.2012.08.027. PMID: 22999817. Excluded: Wrong comparator22999817
Mitchell TB, White JM, Somogyi AA, . Comparative pharmacodynamics and pharmacokinetics of methadone and slow-release oral morphine for maintenance treatment of opioid dependence. Drug Alcohol Depend. 2003;72(1):85–94. PMID: 14563546. Excluded: <3 month followup duration14563546
Mitchell TB, White JM, Somogyi AA, . Slow-release oral morphine versus methadone: a crossover comparison of patient outcomes and acceptability as maintenance pharmacotherapies for opioid dependence. Addiction. 2004;99(8):940–5. PMID: 15265090. Excluded: Wrong comparator15265090
Mitcheson L, McCambridge J, Byrne S. Pilot cluster-randomised trial of adjunctive motivational interviewing to reduce crack cocaine use in clients on methadone maintenance. Eur Addict Res. 2007;13(1):6–10. PMID: 17172773. Excluded: <3 month followup duration17172773
Mogro-Wilson C, Letendre J, Toi H, . Utilizing mutual aid in reducing adolescent substance use and developing group engagement. Res Soc Work Pract. 2015;25(1):129–38. doi: 10.1177/1049731513518080. Excluded: <3 month followup duration
Mojtabai R, Zivin JG. Effectiveness and cost-effectiveness of four treatment modalities for substance disorders: a propensity score analysis. Health Serv Res. 2003;38(1 Pt 1):233–59. PMID: 12650390. Excluded: Wrong study design for key question12650390
Mok MS, Lippmann M, Steen SN. Multidose/observational, comparative clinical analgetic evaluation of buprenorphine. J Clin Pharmacol. 1981;21(7):323–9. PMID: 7263931. Excluded: Wrong comparator7263931
Monico LB, Gryczynski J, Schwartz RP, . Treatment outcomes among a cohort of African American buprenorphine patients: follow-up at 12 months. Am J Drug Alcohol Abuse. 2018;44(6):604–10. doi: 10.1080/00952990.2018.1461877. PMID: 29718715. Excluded: Wrong comparator29718715
Montgomery L, Burlew AK, Kosinski AS, . Motivational enhancement therapy for African American substance users: a randomized clinical trial. Cultur Divers Ethnic Minor Psychol. 2011;17(4):357–65. doi: 10.1037/a0025437. PMID: 21988576. Excluded: Wrong outcome21988576
Montgomery L, Carroll KM, Petry NM. Initial abstinence status and contingency management treatment outcomes: does race matter? J Consult Clin Psychol. 2015;83(3):473–81. doi: 10.1037/a0039021. PMID: 25798729. Excluded: Wrong outcome25798729
Montgomery L, Robinson C, Seaman EL, . A scoping review and meta-analysis of psychosocial and pharmacological treatments for cannabis and tobacco use among African Americans. Psychol Addict Behav. 2017;31(8):922–43. doi: 10.1037/adb0000326. PMID: 29199844. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies29199844
Monti PM, Abrams DB, Binkoff JA, . Communication skills training, communication skills training with family and cognitive behavioral mood management training for alcoholics. J Stud Alcohol. 1990;51(3):263–70. PMID: 2342366. Excluded: Other wrong population (e.g., schizophrenia focus)2342366
Monti PM, Rohsenow DJ, Michalec E, . Brief coping skills treatment for cocaine abuse: substance use outcomes at three months. Addiction. 1997;92(12):1717–28. PMID: 9581004. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)9581004
Monti PM, Rohsenow DJ, Rubonis AV, . Cue exposure with coping skills treatment for male alcoholics: a preliminary investigation. J Consult Clin Psychol. 1993;61(6):1011–9. PMID: 7906700. Excluded: Other wrong population (e.g., schizophrenia focus)7906700
Monti PM, Rohsenow DJ, Swift RM, . Naltrexone and cue exposure with coping and communication skills training for alcoholics: treatment process and 1-year outcomes. Alcohol Clin Exp Res. 2001;25(11):1634–47. PMID: 11707638. Excluded: Other wrong population (e.g., schizophrenia focus)11707638
Montoya ID, Gorelick DA, Preston KL, . Randomized trial of buprenorphine for treatment of concurrent opiate and cocaine dependence. Clin Pharmacol Ther. 2004;75(1):34–48. PMID: 14749690. Excluded: Wrong comparator14749690
Montoya ID, Schroeder JR, Preston KL, . Influence of psychotherapy attendance on buprenorphine treatment outcome. J Subst Abuse Treat. 2005;28(3):247–54. PMID: 15857725. Excluded: Wrong comparator15857725
Montoya ID, Svikis D, Marcus SC, . Psychiatric care of patients with depression and comorbid substance use disorders. J Clin Psychiatry. 2000;61(9):698–705; quiz 6. PMID: 11030495. Excluded: Wrong study design for key question11030495
Mooney L, Hillhouse MP, Thomas C, . Psychiatric symptoms and treatment outcomes in cocaine-dependent adults treated with buprenorphine and long-acting naltrexone. Drug Alcohol Depend. 2015;156(13). Excluded: <3 month followup duration
Mooney LJ, Nielsen S, Saxon A, . Cocaine use reduction with buprenorphine (CURB): rationale, design, and methodology. Contemp Clin Trials. 2013;34(2):196–204. doi: 10.1016/j.cct.2012.11.002. PMID: 23159524. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)23159524
Mooney ME, Poling J, Gonzalez G, . Preliminary study of buprenorphine and bupropion for opioid-dependent smokers. Am J Addict. 2008;17(4):287–92. doi: 10.1080/10550490802138814. PMID: 18612883. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)18612883
Moore BA, Barry DT, Sullivan LE, . Counseling and directly observed medication for primary care buprenorphine maintenance: a pilot study. J Addict Med. 2012;6(3):205–11. doi: 10.1097/ADM.0b013e3182596492. PMID: 22614936. Excluded: Wrong comparator22614936
Moore BA, Fiellin DA, Cutter CJ, . Cognitive behavioral therapy improves treatment outcomes for prescription opioid users in primary care buprenorphine treatment. J Subst Abuse Treat. 2016;71:54–7. doi: 10.1016/j.jsat.2016.08.016. PMID: 27776678. Excluded: Wrong comparator27776678
Moore SK, Marsch LA, Badger GJ, . Improvement in psychopathology among opioid-dependent adolescents during behavioral-pharmacological treatment. J Addict Med. 2011;5(4):264–71. doi: 10.1097/ADM.0b013e3182191099. PMID: 22107875. Excluded: Wrong comparator22107875
Morgan JR, Schackman BR, Leff JA, . Injectable naltrexone, oral naltrexone, and buprenorphine utilization and discontinuation among individuals treated for opioid use disorder in a United States commercially insured population. J Subst Abuse Treat. 2018;85:90–6. doi: 10.1016/j.jsat.2017.07.001. Excluded: Wrong study design for key question28733097
Morgenstern J, Blanchard KA, Kahler C, . Testing mechanisms of action for intensive case management. Addiction. 2008;103(3):469–77. doi: 10.1111/j.1360-0443.2007.02100.x. PMID: 18269366. Excluded: Wrong outcome18269366
Morgenstern J, Blanchard KA, McCrady BS, . Effectiveness of intensive case management for substance-dependent women receiving temporary assistance for needy families. Am J Public Health. 2006;96(11):2016–23. doi: 10.2105/ajph.2005.076380. PMID: 17018819. Excluded: Wrong comparator17018819
Morgenstern J, Blanchard KA, Morgan TJ, . Testing the effectiveness of cognitive-behavioral treatment for substance abuse in a community setting: within treatment and posttreatment findings. J Consult Clin Psychol. 2001;69(6):1007–17. PMID: 11777104. Excluded: <70% drug misuse or likely majority alcohol11777104
Morgenstern J, Bux DA, Parsons J, . Randomized trial to reduce club drug use and HIV risk behaviors among men who have sex with men. J Consult Clin Psychol. 2009;77(4):645–56. doi: 10.1037/a0015588. PMID: 19634958. Excluded: Other wrong population (e.g., schizophrenia focus)19634958
Morgenstern J, Hogue A, Dauber S, . A practical clinical trial of coordinated care management to treat substance use disorders among public assistance beneficiaries. J Consult Clin Psychol. 2009;77(2):257–69. doi: 10.1037/a0014489. PMID: 19309185. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19309185
Morie KP, Nich C, Hunkele K, . Alexithymia level and response to computer-based training in cognitive behavioral therapy among cocaine-dependent methadone maintained individuals. Drug Alcohol Depend. 2015;152:157–63. doi: 10.1016/j.drugalcdep.2015.04.004. PMID: 25982006. Excluded: <3 month followup duration25982006
Morley KC, Sitharthan G, Haber PS, . The efficacy of an opportunistic cognitive behavioral intervention package (OCB) on substance use and comorbid suicide risk: a multisite randomized controlled trial. J Consult Clin Psychol. 2014;82(1):130–40. doi: 10.1037/a0035310. PMID: 24364795. Excluded: Other wrong population (e.g., schizophrenia focus)24364795
Morley KC, Teesson M, Reid SC, . Naltrexone versus acamprosate in the treatment of alcohol dependence: A multi-centre, randomized, double-blind, placebo-controlled trial. Addiction. 2006;101(10):1451–62. doi: 10.1111/j.1360-0443.2006.01555.x. PMID: 16968347. Excluded: Other wrong population (e.g., schizophrenia focus)16968347
Morral AR, McCaffrey DF, Ridgeway G. Effectiveness of community-based treatment for substance-abusing adolescents: 12-month outcomes of youths entering phoenix academy or alternative probation dispositions. Psychol Addict Behav. 2004;18(3):257–68. doi: 10.1037/0893-164x.18.3.257. PMID: 15482081. Excluded: Wrong comparator15482081
Motamed M, Marsch LA, Solhkhah R, . Differences in treatment outcomes between prescription opioid-dependent and heroin-dependent adolescents. J Addict Med. 2008;2(3):158–64. doi: 10.1097/ADM.0b013e31816b2f84. PMID: 21768987. Excluded: <3 month followup duration21768987
Msekela S, Krupitsky E, Zvartau E, . Stabilization of remission from opioid dependence with long-acting naltrexone implant. Eur Neuropsychopharmacol. 2014;24(6). Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Mullins SM, Suarez M, Ondersma SJ, . The impact of motivational interviewing on substance abuse treatment retention: a randomized control trial of women involved with child welfare. J Subst Abuse Treat. 2004;27(1):51–8. doi: 10.1016/j.jsat.2004.03.010. PMID: 15223094. Excluded: Wrong comparator15223094
Murphy KM. Music therapy in addictions treatment: A systematic review of the literature and recommendations for future research. Music and Medicine. 2017;9(1):15–23. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Mysels DJ, Cheng WY, Nunes EV, . The association between naltrexone treatment and symptoms of depression in opioid-dependent patients. Am J Drug Alcohol Abuse. 2011;37(1):22–6. doi: 10.3109/00952990.2010.540281. PMID: 21192125. Excluded: <3 month followup duration21192125
Najavits LM, Gallop RJ, Weiss RD. Seeking safety therapy for adolescent girls with PTSD and substance use disorder: a randomized controlled trial. J Behav Health Serv Res. 2006;33(4):453–63. doi: 10.1007/s11414-006-9034-2. PMID: 16858633. Excluded: Other wrong population (e.g., schizophrenia focus)16858633
Najavits LM, Johnson KM. Pilot study of Creating Change, a new past-focused model for PTSD and substance abuse. Am J Addict. 2014;23(5):415–22. doi: 10.1111/j.1521-0391.2014.12127.x. PMID: 24628840. Excluded: Other wrong population (e.g., schizophrenia focus)24628840
Neufeld KJ, Kidorf MS, Kolodner K, . A behavioral treatment for opioid-dependent patients with antisocial personality. J Subst Abuse Treat. 2008;34(1):101–11. PMID: 17574801. Excluded: Wrong study design for key question17574801
Newman RG, Gevertz SG. Efficacy versus effectiveness of buprenorphine and methadone maintenance in pregnancy. J Addict Dis. 2011;30(4):318–22. doi: 10.1080/10550887.2011.609806. PMID: 22026523. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.22026523
Newman RG, Whitehill WB. Double-blind comparison of methadone and placebo maintenance treatments of narcotic addicts in Hong Kong. Lancet. 1979;2(8141):485–8. PMID: 90214. Excluded: Inpatient population90214
Newton AS, Dong K, Mabood N, . Brief emergency department interventions for youth who use alcohol and other drugs: a systematic review. Pediatr Emerg Care. 2013;29(5):673–84. doi: 10.1097/PEC.0b013e31828ed325. PMID: 23640153. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies23640153
Nich C, McCance-Katz EF, Petrakis IL, . Sex differences in cocaine-dependent individuals’ response to disulfiram treatment. Addict Behav. 2004;29(6):1123–8. PMID: 15236812. Excluded: Non-FDA approved pharmacologic intervention15236812
Nielsen S, Larance B, Degenhardt L, . Opioid agonist treatment for pharmaceutical opioid dependent people. Cochrane Database Syst Rev. 2016 (5):CD011117. doi: 10.1002/14651858.CD011117.pub2. PMID: 27157143. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.27157143
Nissen L. Strength-based approaches to juvenile justice: Assessment and programming.. Joint Meeting on Adolescent Treatment Effectiveness (JMATE); 2005 Washington, DC. Excluded: Results reported elsewhere, duplicate results
Nolan S, Dias Lima V, Fairbairn N, . The impact of methadone maintenance therapy on hepatitis C incidence among illicit drug users. Addiction. 2014;109(12):2053–9. doi: 10.1111/add.12682. PMID: 25041346. Excluded: Wrong study design for key question25041346
Noormohammadi A, Forinash A, Yancey A, . Buprenorphine versus methadone for opioid dependence in pregnancy. Ann Pharmacother. 2016;50(8):666–72. doi: 10.1177/1060028016648367. PMID: 27199497. Excluded: Wrong comparator27199497
Norberg MM, Hides L, Olivier J, . Brief interventions to reduce ecstasy use: a multi-site randomized controlled trial. Behav Ther. 2014;45(6):745–59. Excluded: Wrong comparator25311285
Nunes EV, Gordon M, Friedmann PD, . Relapse to opioid use disorder after inpatient treatment: Protective effect of injection naltrexone. J Subst Abuse Treat. 2018;85:49–55. doi: 10.1016/j.jsat.2017.04.016. PMID: 28473233. Excluded: Wrong comparator28473233
Nunes EV, Rothenberg JL, Sullivan MA, . Behavioral therapy to augment oral naltrexone for opioid dependence: a ceiling on effectiveness? Am J Drug Alcohol Abuse. 2006;32(4):503–17. PMID: 17127538. Excluded: Wrong comparator17127538
Nyamathi AM, Nandy K, Greengold B, . Effectiveness of intervention on improvement of drug use among methadone maintained adults. J Addict Dis. 2011;30(1):6–16. doi: 10.1080/10550887.2010.531669. PMID: 21218306. Excluded: Wrong comparator21218306
O’Brien CP, Childress AR, Arndt IO, . Pharmacological and behavioral treatments of cocaine dependence: controlled studies. J Clin Psychiatry. 1988;49 Suppl:17–22. PMID: 3276670. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.3276670
O’Brien CP, Friedmann PD, Nunes E, . Depot naltrexone as relapse prevention for opioid-dependent parolees. Drug Alcohol Depend. 2014;146(14). Excluded: Wrong comparator
Ochoa E, Madoz-Gurpide A, Salvador E. Gender differences in the treatment of the opiate dependence with naltrexone. Actas Esp Psiquiatr. 2008;36(4):197–204. PMID: 18461494. Excluded: Wrong study design for key question18461494
O’Connell MJ, Kasprow WJ, Rosenheck RA. Differential impact of supported housing on selected subgroups of homeless veterans with substance abuse histories. Psychiatric Services. 2012;63(12):1195–205. PMID: 23117205. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)23117205
O’Connor PG, Oliveto AH, Shi JM, . A randomized trial of buprenorphine maintenance for heroin dependence in a primary care clinic for substance users versus a methadone clinic. Am J Med. 1998;105(2):100–5. PMID: 9727815. Excluded: Wrong comparator9727815
O’Connor PG, Waugh ME, Carroll KM, . Primary care-based ambulatory opioid detoxification: the results of a clinical trial. J Gen Intern Med. 1995;10(5):255–60. PMID: 7616334. Excluded: <3 month followup duration7616334
O’Farrell TJ, Murphy M, Alter J, . Behavioral family counseling for substance abuse: a treatment development pilot study. Addict Behav. 2010;35(1):1–6. PMID: 19717243. Excluded: Wrong comparator19717243
O’Farrell TJ, Schumm JA, Murphy MM, . A randomized clinical trial of behavioral couples therapy versus individually-based treatment for drug-abusing women. J Consult Clin Psychol. 2017;85(4):309–22. doi: 10.1037/ccp0000185. PMID: 28333533. Excluded: Wrong comparator28333533
Ogel K, Coskun S. Cognitive behavioral therapy-based brief intervention for volatile substance misusers during adolescence: a follow-up study. Subst Use Misuse. 2011;46: Suppl 1:128–33. doi: 10.3109/10826084.2011.580233. PMID: 21609157. Excluded: Other wrong population (e.g., schizophrenia focus)21609157
Oldham NS, Wright NM, Adams CE, . The Leeds evaluation of efficacy of detoxification study (LEEDS) project: an open-label pragmatic randomised control trial comparing the efficacy of differing therapeutic agents for primary care detoxification from either street heroin or methadone [ISRCTN07752728]. BMC Fam Pract. 2004;5:9. PMID: 15117415. Excluded: Wrong comparator15117415
Oliveto A, Poling J, Mancino MJ, . Randomized, double blind, placebo-controlled trial of disulfiram for the treatment of cocaine dependence in methadone-stabilized patients. Drug Alcohol Depend. 2011;113(2-3):184–91. doi: 10.1016/j.drugalcdep.2010.07.022. PMID: 20828943. Excluded: Non-FDA approved pharmacologic intervention20828943
Oliveto A, Poling J, Sevarino KA, . Efficacy of dose and contingency management procedures in LAAM-maintained cocaine-dependent patients. Drug Alcohol Depend. 2005;79(2):157–65. PMID: 16002025. Excluded: Wrong comparator16002025
Olmstead TA, Cohen JP, Petry NM. Health-care service utilization in substance abusers receiving contingency management and standard care treatments. Addiction. 2012;107(8):1462–70. doi: 10.1111/j.1360-0443.2012.03831.x. PMID: 22296262. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies22296262
Ondersma SJ, Winhusen T, Lewis DF. Pre-treatment change in a randomized trial with pregnant substance-abusing women in community-based outpatient treatment. Contemp Clin Trials. 2012;33(5):1074–9. doi: 10.1016/j.cct.2012.06.002. PMID: 22710564. Excluded: Wrong study design for key question22710564
O’Neill K, Baker A, Cooke M, . Evaluation of a cognitive-behavioural intervention for pregnant injecting drug users at risk of HIV infection. Addiction. 1996;91(8):1115–25. PMID: 8828240. Excluded: Wrong comparator8828240
Ong T-h. The effectiveness of an indigenised group counselling programme in aftercare service for drug supervisees: A one-year follow-up study. Int J Adv Couns. 1991;14(4):285–300. doi: 10.1007/BF00116538. Excluded: Wrong study design for key question
Ordean A, Kahan M, Graves L, . Integrated care for pregnant women on methadone maintenance treatment: Canadian primary care cohort study. Can Fam Physician. 2013;59(10):e462–9. PMID: 24130301. Excluded: Wrong study design for key question24130301
Oreskovich MR, Saxon AJ, Ellis ML, . A double-blind, double-dummy, randomized, prospective pilot study of the partial mu opiate agonist, buprenorphine, for acute detoxification from heroin. Drug Alcohol Depend. 2005;77(1):71–9. PMID: 15607843. Excluded: Wrong comparator15607843
Oslin DW. Evidence-based treatment of geriatric substance abuse. Psychiatr Clin North Am. 2005;28(4):897–911, ix. PMID: 16325734. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.16325734
Oslin DW, Pettinati HM, Volpicelli JR, . The effects of naltrexone on alcohol and cocaine use in dually addicted patients. J Subst Abuse Treat. 1999;16(2):163–7. PMID: 10023615. Excluded: Non-FDA approved pharmacologic intervention10023615
Osterman R, Lewis D, Winhusen T. Efficacy of motivational enhancement therapy to decrease alcohol and illicit-drug use in pregnant substance users reporting baseline alcohol use. J Subst Abuse Treat. 2017;77:150–5. doi: 10.1016/j.jsat.2017.02.003. PMID: 28254158. Excluded: Wrong outcome28254158
Otiashvili D, Piralishvili G, Sikharulidze Z, . Methadone and buprenorphine-naloxone are effective in reducing illicit buprenorphine and other opioid use, and reducing HIV risk behavior-outcomes of a randomized trial. Drug Alcohol Depend. 2013;133(2):376–82. doi: 10.1016/j.drugalcdep.2013.06.024. PMID: 23916321. Excluded: Wrong comparator23916321
Otto KC, Quinn C, Sung YF. Auricular acupuncture as an adjunctive treatment for cocaine addiction. A pilot study. Am J Addict. 1998;7(2):164–70. PMID: 9598220. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)9598220
Otto MW, Hearon BA, McHugh RK, . A randomized, controlled trial of the efficacy of an interoceptive exposure-based CBT for treatment-refractory outpatients with opioid dependence. J Psychoactive Drugs. 2014;46(5):402–11. doi: 10.1080/02791072.2014.960110. PMID: 25364993. Excluded: Other wrong population (e.g., schizophrenia focus)25364993
Ouimette PC, Finney JW, Moos RH. Twelve-step and cognitive-behavioral treatment for substance abuse: a comparison of treatment effectiveness. J Consult Clin Psychol. 1997;65(2):230–40. PMID: 9086686. Excluded: Wrong comparator9086686
Oviedo-Joekes E, Brissette S, MacDonald S, . Safety profile of injectable hydromorphone and diacetylmorphine for long-term severe opioid use disorder. Drug Alcohol Depend. 2017;176:55–62. doi: 10.1016/j.drugalcdep.2017.02.021. PMID: 28521199. Excluded: Non-FDA approved pharmacologic intervention28521199
Ozechowski TJ, Liddle HA. Family-based therapy for adolescent drug abuse: knowns and unknowns. Clin Child Fam Psychol Rev. 2000;3(4):269–98. PMID: 11225740. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies11225740
Paddock SM, Hepner KA, Hudson T, . Association between process-based quality indicators and mortality for patients with substance use disorders. J Stud Alcohol Drugs. 2017;78(4):588–96. PMID: 28728641. Excluded: Wrong study design for key question28728641
Pani PP, Maremmani I, Pirastu R, . Buprenorphine: a controlled clinical trial in the treatment of opioid dependence. Drug Alcohol Depend. 2000;60(1):39–50. PMID: 10821988. Excluded: Wrong comparator10821988
Pani PP, Pirastu R, Ricci A, . Prohibition of take-home dosages: negative consequences on methadone maintenance treatment. Drug Alcohol Depend. 1996;41(1):81–4. PMID: 8793314. Excluded: Wrong comparator8793314
Pani PP, Trogu E, Contu P, . Psychiatric severity and treatment response in a comprehensive methadone maintenance treatment program. Drug Alcohol Depend. 1997;48(2):119–26. doi: 10.1016/S0376-8716%2897%2900115-4. Excluded: Wrong study design for key question9363411
Pani PP, Trogu E, Vacca R, . Disulfiram for the treatment of cocaine dependence. Cochrane Database Syst Rev. 2010 (1):CD007024. doi: 10.1002/14651858.CD007024.pub2. PMID: 20091613. Excluded: Non-FDA approved pharmacologic intervention20091613
Pani PP, Trogu E, Vecchi S, . Antidepressants for cocaine dependence and problematic cocaine use. Cochrane Database Syst Rev. 2011 (12) PMID: 22161371. Excluded: Non-FDA approved pharmacologic intervention22161371
Paris M, Silva M, Anez-Nava L, . Culturally adapted, web-based cognitive behavioral therapy for Spanish-speaking individuals with substance use disorders: a randomized clinical trial. Am J Public Health. 2018;108(11):1535–42. doi: 10.2105/ajph.2018.304571. PMID: 30252519. Excluded: Wrong comparator30252519
Parmar A, Sarkar S. Brief interventions for cannabis use disorders: A review. Addict Disord Their Treat. 2017;16(2):80–93. doi: 10.1097/ADT.0000000000000100. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Parsons BV, Jr., Alexander JF. Short-term family intervention: A therapy outcome study. J Consult Clin Psychol. 1973;41(2):195–201. PMID: 4747932. Excluded: Wrong outcome4747932
Parsons JT, Lelutiu-Weinberger C, Botsko M, . A randomized controlled trial utilizing motivational interviewing to reduce HIV risk and drug use in young gay and bisexual men. J Consult Clin Psychol. 2014;82(1):9–18. doi: 10.1037/a0035311. PMID: 24364800. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)24364800
Parwatikar SD, Knowles RR. Methadone-naloxone in combination for the treatment of heroin addicts. Clin Pharmacol Ther. 1973;14(6):941–8. PMID: 4584151. Excluded: Wrong comparator4584151
Passetti LL, Godley MD, Kaminer Y. Continuing care for adolescents in treatment for substance use disorders. Child Adolesc Psychiatr Clin N Am. 2016;25(4):669–84. doi: 10.1016/j.chc.2016.06.003. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27613345
Passos SR, Camacho LA, Lopes CS, . Nefazodone in out-patient treatment of inhaled cocaine dependence: a randomized double-blind placebo-controlled trial. Addiction. 2005;100(4):489–94. doi: 10.1111/j.1360-0443.2005.01041.x. PMID: 15784063. Excluded: Non-FDA approved pharmacologic intervention15784063
Patients more likely to engage in treatment at 30 days when given buprenorphine in the ED, referred for follow-up. ED Management. 2015;27(8):92–5. PMID: 26258203. Excluded: <3 month followup duration26258203
Paulozzi LJ, Logan JE, Hall AJ, . A comparison of drug overdose deaths involving methadone and other opioid analgesics in West Virginia. Addiction. 2009;104(9):1541–8. doi: 10.1111/j.1360-0443.2009.02650.x. PMID: 19686524. Excluded: Wrong study design for key question19686524
Peck JA, Reback CJ, Yang X, . Sustained reductions in drug use and depression symptoms from treatment for drug abuse in methamphetamine-dependent gay and bisexual men. J Urban Health. 2005;82(1 Suppl 1):i100–8. PMID: 15738315. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)15738315
Peirce JM, Petry NM, Stitzer ML, . Effects of lower-cost incentives on stimulant abstinence in methadone maintenance treatment: a National Drug Abuse Treatment Clinical Trials Network study. Arch Gen Psychiatry. 2006;63(2):201–8. PMID: 16461864. Excluded: Wrong comparator16461864
Peirce JM, Schacht RL, Brooner RK, . Incentivizing attendance to prolonged exposure in methadone maintenance. Drug Alcohol Depend. 2015;156(13). Excluded: Other wrong population (e.g., schizophrenia focus)
Peles E, Sason A, Schreiber S, . Newborn birth-weight of pregnant women on methadone or buprenorphine maintenance treatment: A national contingency management approach trial. Am J Addict. 2017;26(2):167–75. doi: 10.1111/ajad.12508. PMID: 28191917. Excluded: Wrong comparator28191917
Perez-Mana C, Castells X, Torrens M, . Efficacy of psychostimulant drugs for amphetamine abuse or dependence. Cochrane Database Syst Rev. 2013 (9)doi: 10.1002/14651858.CD009695.pub2. PMID: 23996457. Excluded: Non-FDA approved pharmacologic intervention23996457
Perry AE, Neilson M, Martyn-St James M, . Pharmacological interventions for drug-using offenders. Cochrane Database Syst Rev. 2015 (6):CD010862. doi: 10.1002/14651858.CD010862.pub2. PMID: 26035084. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26035084
Perry AE, Neilson M, Martyn-St James M, . Interventions for female drug-using offenders. Cochrane Database Syst Rev. 2015 (6):CD010910. doi: 10.1002/14651858.CD010910.pub2. PMID: 26035085. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26035085
Peters EN, Nich C, Carroll KM. Primary outcomes in two randomized controlled trials of treatments for cannabis use disorders. Drug Alcohol Depend. 2011;118(2-3):408–16. doi: 10.1016/j.drugalcdep.2011.04.021. PMID: 21620591. Excluded: Wrong outcome21620591
Peterson PL, Baer JS, Wells EA, . Short-term effects of a brief motivational intervention to reduce alcohol and drug risk among homeless adolescents. Psychol Addict Behav. 2006;20(3):254–64. Excluded: Other wrong population (e.g., schizophrenia focus)16938063
Petitjean S, Stohler R, Deglon JJ, . Double-blind randomized trial of buprenorphine and methadone in opiate dependence. Drug Alcohol Depend. 2001;62(1):97–104. PMID: 11173173. Excluded: Wrong comparator11173173
Petrakis IL, Carroll KM, Nich C, . Disulfiram treatment for cocaine dependence in methadone-maintained opioid addicts. Addiction. 2000;95(2):219–28. PMID: 10723850. Excluded: Non-FDA approved pharmacologic intervention10723850
Petry NM, Alessi SM. Prize-based contingency management is efficacious in cocaine-abusing patients with and without recent gambling participation. J Subst Abuse Treat. 2010;39(3):282–8. doi: 10.1016/j.jsat.2010.06.011. PMID: 20667679. Excluded: Wrong outcome20667679
Petry NM, Alessi SM, Carroll KM, . Contingency management treatments: Reinforcing abstinence versus adherence with goal-related activities. J Consult Clin Psychol. 2006;74(3):592–601. Excluded: Wrong comparator16822115
Petry NM, Alessi SM, Hanson T. Contingency management improves abstinence and quality of life in cocaine abusers. J Consult Clin Psychol. 2007;75(2):307–15. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.17469888
Petry NM, Alessi SM, Hanson T, . Randomized trial of contingent prizes versus vouchers in cocaine-using methadone patients. J Consult Clin Psychol. 2007;75(6):983–91. PMID: 18085914. Excluded: Wrong comparator18085914
Petry NM, Alessi SM, Marx J, . Vouchers versus prizes: contingency management treatment of substance abusers in community settings. J Consult Clin Psychol. 2005;73(6):1005–14. PMID: 16392974. Excluded: Wrong comparator16392974
Petry NM, Barry D, Alessi SM, . A randomized trial adapting contingency management targets based on initial abstinence status of cocaine-dependent patients. J Consult Clin Psychol. 2012;80(2):276–85. doi: 10.1037/a0026883. PMID: 22229758. Excluded: Wrong comparator22229758
Petry NM, Ford JD, Barry D. Contingency management is especially efficacious in engendering long durations of abstinence in patients with sexual abuse histories. Psychol Addict Behav. 2011;25(2):293–300. doi: 10.1037/a0022632. PMID: 21443305. Excluded: Other wrong population (e.g., schizophrenia focus)21443305
Petry NM, Kolodner KB, Li R, . Prize-based contingency management does not increase gambling. Drug Alcohol Depend. 2006;83(3):269–73. PMID: 16377101. Excluded: Wrong outcome16377101
Petry NM, Martin B. Low-cost contingency management for treating cocaine- and opioid-abusing methadone patients. J Consult Clin Psychol. 2002;70(2):398–405. PMID: 11952198. Excluded: Wrong comparator11952198
Petry NM, Martin B, Simcic F, Jr. Prize reinforcement contingency management for cocaine dependence: integration with group therapy in a methadone clinic. J Consult Clin Psychol. 2005;73(2):354–9. PMID: 15796645. Excluded: Wrong comparator15796645
Petry NM, Peirce JM, Stitzer ML, . Effect of prize-based incentives on outcomes in stimulant abusers in outpatient psychosocial treatment programs: a national drug abuse treatment clinical trials network study. Arch Gen Psychiatry. 2005;62(10):1148–56. doi: 10.1001/archpsyc.62.10.1148. PMID: 16203960. Excluded: Wrong comparator16203960
Petry NM, Roll JM, Rounsaville BJ, . Serious adverse events in randomized psychosocial treatment studies: safety or arbitrary edicts? J Consult Clin Psychol. 2008;76(6):1076–82. doi: 10.1037/a0013679. PMID: 19045975. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies19045975
Petry NM, Tedford J, Austin M, . Prize reinforcement contingency management for treating cocaine users: how low can we go, and with whom? Addiction. 2004;99(3):349–60. PMID: 14982548. Excluded: Wrong comparator14982548
Petry NM, Weinstock J, Alessi SM. A randomized trial of contingency management delivered in the context of group counseling. J Consult Clin Psychol. 2011;79(5):686–96. doi: 10.1037/a0024813. PMID: 21806297. Excluded: Wrong comparator21806297
Pettinati HM, Kampman KM, Lynch KG, . A pilot trial of injectable, extended-release naltrexone for the treatment of co-occurring cocaine and alcohol dependence. Am J Addict. 2014;23(6):591–7. doi: 10.1111/j.1521-0391.2014.12146.x. PMID: 25251201. Excluded: Non-FDA approved pharmacologic intervention25251201
Pettinati HM, Kampman KM, Lynch KG, . Gender differences with high-dose naltrexone in patients with co-occurring cocaine and alcohol dependence. J Subst Abuse Treat. 2008;34(4):378–90. PMID: 17664051. Excluded: Non-FDA approved pharmacologic intervention17664051
Pettinati HM, Kampman KM, Lynch KG, . A double blind, placebo-controlled trial that combines disulfiram and naltrexone for treating co-occurring cocaine and alcohol dependence. Addict Behav. 2008;33(5):651–67. PMID: 18079068. Excluded: Non-FDA approved pharmacologic intervention18079068
Phan O, Henderson CE, Angelidis T, . European youth care sites serve different populations of adolescents with cannabis use disorder. Baseline and referral data from the INCANT trial. BMC Psychiatry. 2011;11doi: 10.1186/1471-244X-11-110. PMID: 21749677. Excluded: Wrong outcome21749677
Piehler TF, Winters KC. Parental involvement in brief interventions for adolescent marijuana use. Psychol Addict Behav. 2015;29(3):512–21. doi: 10.1037/adb0000106. PMID: 26415058. Excluded: School setting26415058
Pilowsky DJ, Wu LT. Screening instruments for substance use and brief interventions targeting adolescents in primary care: a literature review. Addict Behav. 2013;38(5):2146–53. doi: 10.1016/j.addbeh.2013.01.015. PMID: 23454877. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies23454877
Pinto H, Maskrey V, Swift L, . The SUMMIT trial: a field comparison of buprenorphine versus methadone maintenance treatment. J Subst Abuse Treat. 2010;39(4):340–52. doi: 10.1016/j.jsat.2010.07.009. PMID: 20817384. Excluded: Wrong comparator20817384
Pinto H, Rumball D, Maskrey V, . A pilot study for a randomized controlled and patient preference trial of buprenorphine versus methadone maintenance treatment in the management of opiate dependent patients. J Subst Use. 2008;13(2):73–82. Excluded: Wrong comparator
Piotrowski NA, Hall S. Treatment of multiple drug abuse in the methadone clinic. Motivating behavior change among illicit drug abusers. 1999. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Piotrowski NA, Tusel DJ, Sees KL, . Contingency contracting with monetary reinforcers for abstinence from multiple drugs in a methadone program. Exp Clin Psychopharmacol. 1999;7(4):399–411. PMID: 10609975. Excluded: Wrong comparator10609975
Piralishvili G, Otiashvili D, Sikharulidze Z, . Opioid addicted buprenorphine injectors: drug use during and after 12-weeks of buprenorphine-naloxone or methadone in the Republic of Georgia. J Subst Abuse Treat. 2015;50:32–7. doi: 10.1016/j.jsat.2014.10.003. PMID: 25456093. Excluded: Wrong comparator25456093
Polcin DL, Bond J, Korcha R, . Randomized trial of intensive motivational interviewing for methamphetamine dependence. J Addict Dis. 2014;33(3):253–65. doi: 10.1080/10550887.2014.950029. PMID: 25115166. Excluded: Wrong comparator25115166
Pollack MH, Otto MW, Kaufman MJ, . Renshaw cognitive-behavioral therapy for illicit drug use during methadone maintenance: treatment outcomes and MR spectroscopy findings. Drug Alcohol Depend. 2001;63(1). Excluded: Other wrong population (e.g., schizophrenia focus)
Pollack MH, Penava SA, Bolton E, . A novel cognitive-behavioral approach for treatment-resistant drug dependence. J Subst Abuse Treat. 2002;23(4):335–42. PMID: 12495795. Excluded: Other wrong population (e.g., schizophrenia focus)12495795
Pompili M, Venturini P, Lamis DA, . Rehabilitation of the adolescent with a substance use disorder: Overview of treatment efficacy. Int J Emerg Ment Health. 2015;17(3):617–23. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Posadzki P, Choi J, Lee MS, . Yoga for addictions: A systematic review of randomised clinical trials. Focus Altern Complement Ther. 2014;19(1):1–8. doi: 10.1111/fct.12080. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Prendergast ML, Podus D, Chang E. Program factors and treatment outcomes in drug dependence treatment: an examination using meta-analysis. Subst Use Misuse. 2000;35(12-14):1931–65. PMID: 11138713. Excluded: Wrong outcome11138713
Preston KL, Umbricht A, Epstein DH. Methadone dose increase and abstinence reinforcement for treatment of continued heroin use during methadone maintenance. Arch Gen Psychiatry. 2000;57(4):395–404. PMID: 10768702. Excluded: Wrong comparator10768702
Preston KL, Umbricht A, Epstein DH. Abstinence reinforcement maintenance contingency and one-year follow-up. Drug Alcohol Depend. 2002;67(2):125–37. PMID: 12095662. Excluded: Wrong comparator12095662
Printz DMB, Buono FD, Lloyd DP, . Gender differences in timing of reminder messages for automated, CBT-based treatment for methadone. Drug Alcohol Depend. 2016;171. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Raby WN, Carpenter KM, Rothenberg J, . Intermittent marijuana use is associated with improved retention in naltrexone treatment for opiate-dependence. Am J Addict. 2009;18(4):301–8. doi: 10.1080/10550490902927785. PMID: 19444734. Excluded: Wrong outcome19444734
Rahimi-Movaghar A, Amin-Esmaeili M, Hefazi M, . Pharmacological therapies for maintenance treatments of opium dependence. Cochrane Database Syst Rev. 2013 (1):CD007775. doi: 10.1002/14651858.CD007775.pub2. PMID: 23440817. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies23440817
Rahimi-Movaghar A, Hefazi M, Davoli M, . Pharmacological therapies for management of opium withdrawal. Cochrane Database Syst Rev. 2009 (1)doi: 10.1002/14651858.CD007522. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Raisch DW, Fye CL, Boardman KD, . Opioid dependence treatment, including buprenorphine/naloxone. Ann Pharmacother. 2002;36(2):312–21. PMID: 11847954. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies11847954
Raistrick D, West D, Finnegan O, . A comparison of buprenorphine and lofexidine for community opiate detoxification: results from a randomized controlled trial. Addiction. 2005;100(12):1860–7. PMID: 16367987. Excluded: Wrong comparator16367987
Rash CJ, Alessi SM, Petry NM. Contingency management is efficacious for cocaine abusers with prior treatment attempts. Exp Clin Psychopharmacol. 2008;16(6):547–54. doi: 10.1037/a0014042. PMID: 19086775. Excluded: Wrong outcome19086775
Rash CJ, Stitzer M, Weinstock J. Contingency management: New directions and remaining challenges for an evidence-based intervention. J Subst Abuse Treat. 2017;72:10–8. doi: 10.1016/j.jsat.2016.09.008. PMID: 27746057. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27746057
Rawson RA, Glazer M, Callahan EJ, . Naltrexone and behavior therapy for heroin addiction. NIDA Res Monogr. 1979 (25):26–43. PMID: 117373. Excluded: Wrong comparator117373
Rawson RA, Huber A, McCann M, . A comparison of contingency management and cognitive-behavioral approaches during methadone maintenance treatment for cocaine dependence. Arch Gen Psychiatry. 2002;59(9):817–24. PMID: 12215081. Excluded: Wrong comparator12215081
Rawson RA, Marinelli-Casey P, Anglin MD, . A multi-site comparison of psychosocial approaches for the treatment of methamphetamine dependence. Addiction. 2004;99(6):708–17. doi: 10.1111/j.1360-0443.2004.00707.x. PMID: 15139869. Excluded: Wrong comparator15139869
Rawson RA, McCann MJ, Shoptaw SJ, . Naltrexone for opioid dependence: evaluation of a manualized psychosocial protocol to enhance treatment response. Drug Alcohol Rev. 2001;20(1):67–78. Excluded: Wrong comparator
Rawson RA, Tennant FS, Jr. Five-year follow-up of opiate addicts with naltrexone and behavior therapy. NIDA Res Monogr. 1984;49:289–95. PMID: 6434974. Excluded: Wrong study design for key question6434974
Rees V, Copeland J, Swift W, . Brief cognitive behavioral interventions for cannabis dependence. NIDA Res Monogr. 1999;179(79). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Reimer J, Verthein U, Karow A, . Physical and mental health in severe opioid-dependent patients within a randomized controlled maintenance treatment trial. Addiction. 2011;106(9):1647–55. doi: 10.1111/j.1360-0443.2011.03463.x. PMID: 21489005. Excluded: Wrong comparator21489005
Rezapour T, Hatami J, Farhoudian A, . Cognitive rehabilitation for individuals with opioid use disorder: a randomized controlled trial. Neuropsychol Rehabil. 2017. Excluded: Wrong comparator
Riggs PD, Hall SK, Mikulich-Gilbertson SK, . A randomized controlled trial of pemoline for attention-deficit/hyperactivity disorder in substance-abusing adolescents. J Am Acad Child Adolesc Psychiatry. 2004;43(4):420–9. doi: 10.1097/00004583-200404000-00008. PMID: 15187802. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)15187802
Rigter H. The European INCANT (international cannabis need of treatment) study. Neuropsychiatr Enfance Adolesc. 2012;60(5 SUPPL. 1):S26. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Rigter H, Henderson CE, Pelc I, . Multidimensional family therapy lowers the rate of cannabis dependence in adolescents: A randomised controlled trial in Western European outpatient settings. Drug Alcohol Depend. 2013;130(1-3):85–93. Excluded: Wrong comparator23140805
Rigter H, Pelc I, Tossmann P, . INCANT: a transnational randomized trial of multidimensional family therapy versus treatment as usual for adolescents with cannabis use disorder. BMC Psychiatry. 2010;10:28. doi: 10.1186/1471-244X-10-28. PMID: 20380718. Excluded: Wrong comparator20380718
Robbins MS, Feaster DJ, Horigian VE, . Therapist adherence in brief strategic family therapy for adolescent drug abusers. J Consult Clin Psychol. 2011;79(1):43–53. doi: 10.1037/a0022146. PMID: 21261433. Excluded: Wrong outcome21261433
Robbins MS, Feaster DJ, Horigian VE, . Brief strategic family therapy versus treatment as usual: results of a multisite randomized trial for substance using adolescents. J Consult Clin Psychol. 2011;79(6):713–27. doi: 10.1037/a0025477. PMID: 21967492. Excluded: Wrong comparator21967492
Robbins MS, Szapocznik J, Dillon FR, . The efficacy of structural ecosystems therapy with drug-abusing/dependent African American and Hispanic American adolescents. J Fam Psychol. 2008;22(1):51–61. doi: 10.1037/0893-3200.22.1.51. PMID: 18266532. Excluded: Other wrong population (e.g., schizophrenia focus)18266532
Robbins MS, Szapocznik J, Horigian VE, . Brief strategic family therapy for adolescent drug abusers: a multi-site effectiveness study. Contemp Clin Trials. 2009;30(3):269–78. doi: 10.1016/j.cct.2009.01.004. PMID: 19470315. Excluded: Wrong comparator19470315
Robles E, Stitzer ML, Strain EC, . Voucher-based reinforcement of opiate abstinence during methadone detoxification. Drug Alcohol Depend. 2002;65(2):179–89. PMID: 11772479. Excluded: Wrong comparator11772479
Roffman RA, Stephens RS, Simpson EE, . Treatment of marijuana dependence: preliminary results. J Psychoactive Drugs. 1988;20(1):129–37. doi: 10.1080/02791072.1988.10524382. PMID: 3392627. Excluded: <3 month followup duration3392627
Rogers RE, Higgins ST, Silverman K, . Abstinence-contingent reinforcement and engagement in non-drug-related activities among illicit drug abusers. Psychol Addict Behav. 2008;22(4):544–50. doi: 10.1037/0893-164X.22.4.544. PMID: 19071979. Excluded: Wrong comparator19071979
Rohsenow DJ, Monti PM, Martin RA, . Motivational enhancement and coping skills training for cocaine abusers: effects on substance use outcomes. Addiction. 2004;99(7):862–74. doi: 10.1111/j.1360-0443.2004.00743.x. PMID: 15200582. Excluded: Wrong comparator15200582
Rohsenow DJ, Monti PM, Martin RA, . Brief coping skills treatment for cocaine abuse: 12-month substance use outcomes. J Consult Clin Psychol. 2000;68(3):515–20. PMID: 10883569. Excluded: Wrong comparator10883569
Rohsenow DJ, Monti PM, Rubonis AV, . Cue exposure with coping skills training and communication skills training for alcohol dependence: 6- and 12-month outcomes. Addiction. 2001;96(8):1161–74. doi: 10.1080/09652140120060752. PMID: 11487422. Excluded: Other wrong population (e.g., schizophrenia focus)11487422
Roll JM, Chudzynski J, Cameron JM, . Duration effects in contingency management treatment of methamphetamine disorders. Addict Behav. 2013;38(9):2455–62. doi: 10.1016/j.addbeh.2013.03.018. PMID: 23708468. Excluded: Wrong comparator23708468
Roll JM, Petry NM, Stitzer ML, . Contingency management for the treatment of methamphetamine use disorders. Am J Psychiatry. 2006;163(11):1993–9. Excluded: Wrong comparator17074952
Romo L, Le Strat Y, Aubry C, . The role of brief motivational intervention on self-efficacy and abstinence in a cohort of patients with alcohol dependence. Int J Psychiatry Med. 2009;39(3):313–23. doi: 10.2190/PM.39.3.g. PMID: 19967902. Excluded: Other wrong population (e.g., schizophrenia focus)19967902
Roozen HG, Boulogne JJ, van Tulder MW, . A systematic review of the effectiveness of the community reinforcement approach in alcohol, cocaine and opioid addiction. Drug Alcohol Depend. 2004;74(1):1–13. PMID: 15072802. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)15072802
Roozen HG, de Waart R, van der Windt DA, . A systematic review of the effectiveness of naltrexone in the maintenance treatment of opioid and alcohol dependence. Eur Neuropsychopharmacol. 2006;16(5):311–23. PMID: 16361086. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies16361086
Rosen MI, Dieckhaus K, McMahon TJ, . Improved adherence with contingency management. AIDS Patient Care STDS. 2007;21(1):30–40. PMID: 17263651. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17263651
Rosenblum A, Magura S, Kayman DJ, . Motivationally enhanced group counseling for substance users in a soup kitchen: a randomized clinical trial. Drug Alcohol Depend. 2005;80(1):91–103. doi: 10.1016/j.drugalcdep.2005.03.012. PMID: 16157232. Excluded: Wrong comparator16157232
Rosenthal R, Kim S, Lofwall M, . A randomized trial of buprenorphine implants in adults stabilized on sublingual buprenorphine. Am J Addict. 2017;Conference: 27th annual meeting and symposium of the american academy of addiction psychiatry, AAAP. 2017. United states 26(3):265–6. Excluded: Results reported elsewhere, duplicate results
Rosenthal RN, Lofwall MR, Kim S, . Effect of buprenorphine implants on illicit opioid use among abstinent adults with opioid dependence treated with sublingual buprenorphine: A randomized clinical trial. JAMA. 2016;316(3):282–90. doi: 10.1001/jama.2016.9382. PMID: 27434441. Excluded: Wrong comparator27434441
Rostami R, Dehghani-Arani F. Neurofeedback training as a new method in treatment of crystal methamphetamine dependent patients: A preliminary study. Appl Psychophysiol Biofeed. 2015;40(3):151–61. doi: 10.1007/s10484-015-9281-1. PMID: 25894106. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)25894106
Rothenberg JL, Sullivan MA, Bornstein G, . Behavioral naltrexone therapy: Efficacy of a new behavioral treatment for heroin dependence and future directions. Drug Alcohol Depend. 2002;66(1). Excluded: Wrong study design for key question
Rothenberg JL, Sullivan MA, Church SH, . Behavioral naltrexone therapy: an integrated treatment for opiate dependence. J Subst Abuse Treat. 2002;23(4):351–60. PMID: 12495797. Excluded: Wrong study design for key question12495797
Rounsaville BJ, Glazer W, Wilber CH, . Short-term interpersonal psychotherapy in methadone-maintained opiate addicts. Arch Gen Psychiatry. 1983;40(6):629–36. PMID: 6342563. Excluded: Wrong comparator6342563
Rowan-Szal G, Joe GW, Chatham LR, . A simple reinforcement system for methadone clients in a community-based treatment program. J Subst Abuse Treat. 1994;11(3):217–23. PMID: 8072049. Excluded: Wrong comparator8072049
Rowan-Szal GA, Bartholomew NG, Chatham LR, . A combined cognitive and behavioral intervention for cocaine-using methadone clients. J Psychoactive Drugs. 2005;37(1):75–84. PMID: 15916253. Excluded: Wrong comparator15916253
Rowe CL. Family therapy for drug abuse: review and updates 2003-2010. J Marital Fam Ther. 2012;38(1):59–81. doi: 10.1111/j.1752-0606.2011.00280.x. PMID: 22283381. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.22283381
Runarsdottir V, Hansdottir I, Tyrfingsson T, . Extended-release injectable naltrexone (xr-ntx) with intensive psychosocial therapy for amphetamine-dependent persons seeking treatment: A placebo-controlled trial. J Addict Med. 2017;11(3):197–204. doi: 10.1097/ADM.0000000000000297. PMID: 28379861. Excluded: Non-FDA approved pharmacologic intervention28379861
Sabioni P, Le Foll B. Psychosocial and pharmacological interventions for the treatment of cannabis use disorder. F1000Res. 2018;7:173. doi: 10.12688/f1000research.11191.1. PMID: 29497498. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)29497498
Saitz R, Palfai TP, Cheng DM, . Screening and brief intervention for drug use in primary care: The aspire randomized trial. J Gen Intern Med. 2013;28(24). Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Salehi M, Emadossadat A, Kheirabadi GR, . The effect of buprenorphine on methamphetamine cravings. J Clin Psychopharmacol. 2015;35(6):724–7. doi: 10.1097/JCP.0000000000000408. PMID: 26468683. Excluded: Non-FDA approved pharmacologic intervention26468683
Salisbury AL, Coyle MG, O’Grady KE, . Fetal assessment before and after dosing with buprenorphine or methadone. Addiction. 2012;107: Suppl 1:36–44. doi: 10.1111/j.1360-0443.2012.04037.x. PMID: 23106925. Excluded: Wrong comparator23106925
Salisbury-Afshar E. Buprenorphine maintenance vs. methadone maintenance or placebo for opioid use disorder. Am Fam Physician. 2015;91(3):165–6. PMID: 25822268. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.25822268
Salloum IM, Jones YO. Efficacy of pharmacotherapy for comorbid major depression and substance use disorders: A review. Curr Psychiatry Rev. 2008;4(1):14–27. doi: 10.2174/157340008783743785. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Samet JH, Krupitsky EM, Cheng DM, . Mitigating risky sexual behaviors among Russian narcology hospital patients: the PREVENT (partnership to reduce the epidemic via engagement in narcology treatment) randomized controlled trial. Addiction. 2008;103(9):1474–83. doi: 10.1111/j.1360-0443.2008.02251.x. PMID: 18636998. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)18636998
Santa Ana EJ, Wulfert E, Nietert PJ. Efficacy of group motivational interviewing (GMI) for psychiatric inpatients with chemical dependence. J Consult Clin Psychol. 2007;75(5):816–22. PMID: 17907864. Excluded: Other wrong population (e.g., schizophrenia focus)17907864
Santisteban DA, Coatsworth JD, Perez-Vidal A, . Efficacy of brief strategic family therapy in modifying Hispanic adolescent behavior problems and substance use. J Fam Psychol. 2003;17(1):121–33. PMID: 12666468. Excluded: <70% drug misuse or likely majority alcohol12666468
Santisteban DA, Mena MP, Muir J, . The efficacy of two adolescent substance abuse treatments and the impact of comorbid depression: results of a small randomized controlled trial. Psychiatr Rehabil J. 2015;38(1):55–64. doi: 10.1037/prj0000106. PMID: 25799306. Excluded: Other wrong population (e.g., schizophrenia focus)25799306
Santisteban DA, Szapocznik J, Perez-Vidal A, . Efficacy of intervention for engaging youth and families into treatment and some variables that may contribute to differential effectiveness. J Fam Psychol. 1996;10(1):35. Excluded: Wrong comparator
Satre DD, Leibowitz A, Sterling SA, . A randomized clinical trial of motivational interviewing to reduce alcohol and drug use among patients with depression. J Consult Clin Psychol. 2016;84(7):571–9. doi: 10.1037/ccp0000096. PMID: 26985728. Excluded: Other wrong population (e.g., schizophrenia focus)26985728
Saulle R, Vecchi S, Gowing L. Supervised dosing with a long-acting opioid medication in the management of opioid dependence. Cochrane Database Syst Rev. 2017;4:CD011983. doi: 10.1002/14651858.CD011983.pub2. PMID: 28447766. Excluded: Wrong comparator28447766
Saunders B, Wilkinson C, Phillips M. The impact of a brief motivational intervention with opiate users attending a methadone programme. Addiction. 1995;90(3):415–24. PMID: 7735025. Excluded: Wrong comparator7735025
Saunders E, McGovern MP, Lambert-Harris C, . The impact of addiction medications on outcomes for persons with co-occurring PTSD and opioid use disorders. Drug Alcohol Depend. 2016;171. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Saunders EC, McGovern MP, Lambert-Harris C, . The impact of addiction medications on treatment outcomes for persons with co-occurring PTSD and opioid use disorders. Am J Addict. 2015;24(8):722–31. doi: 10.1111/ajad.12292. PMID: 26388539. Excluded: Other wrong population (e.g., schizophrenia focus)26388539
Saunders JB, Jones R, Dean A, . Comparison of rapid opiate detoxification and naltrexone with methadone maintenance in the treatment of opiate dependence: A randomized controlled trial. Drug Alcohol Depend. 2002;66(1). Excluded: Wrong comparator
Saxon AJ, Hser YI, Woody G, . Medication-assisted treatment for opioid addiction: Methadone and buprenorphine. J Food Drug Anal. 2013;21(4 SUPPL.):S69–S72. doi: 10.1016/j.jfda.2013.09.037. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.24436573
Saxon AJ, Ling W, Hillhouse M, . Buprenorphine/naloxone and methadone effects on laboratory indices of liver health: a randomized trial. Drug Alcohol Depend. 2013;128(1-2):71–6. doi: 10.1016/j.drugalcdep.2012.08.002. PMID: 22921476. Excluded: Wrong comparator22921476
Sayegh CS, Huey SJ, Zara EJ, . Follow-up treatment effects of contingency management and motivational interviewing on substance use: A meta-analysis. Psychol Addict Behav. 2017;31(4):403–14. doi: 10.1037/adb0000277. PMID: 28437121. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28437121
Schaeffer CM, Henggeler SW, Ford JD, . RCT of a promising vocational/employment program for high-risk juvenile offenders. J Subst Abuse Treat. 2014;46(2):134–43. doi: 10.1016/j.jsat.2013.06.012. PMID: 23958035. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)23958035
Schaub M, Sullivan R, Haug S, . Web-based cognitive behavioral self-help intervention to reduce cocaine consumption in problematic cocaine users: Randomized controlled trial. J Med Internet Res. 2012;14(6):e166. doi: 10.2196/jmir.2244. PMID: 23192752. Excluded: Poor quality23192752
Scherbaum N, Kluwig J, Specka M, . Group psychotherapy for opiate addicts in methadone maintenance treatment-a controlled trial. Eur Addict Res. 2005;11(4):163–71. PMID: 16110222. Excluded: Wrong comparator16110222
Schinke SP, Schilling RF, Gilchrist LD. Prevention of drug and alcohol abuse in American Indian youths. Soc Work Res Abstr. 1986;22(4):18–9. doi: 10.1093/swra/22.4.18. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Schmitt JM, Stotts AL, Rhoades HM, . Naltrexone combined with relapse prevention for the treatment of cocaine dependence. NIDA Res Monogr. 1999;180(112). Excluded: Results reported elsewhere, duplicate results
Schmitz JM, Averill P, Sayre S, . Cognitive–behavioral treatment of bipolar disorder and substance abuse: A preliminary randomized study. Addict Disord Their Treat. 2002;1(1):17–24. Excluded: Other wrong population (e.g., schizophrenia focus)
Schmitz JM, Lindsay JA, Green CE, . High-dose naltrexone therapy for cocaine-alcohol dependence. Am J Addict. 2009;18(5):356–62. doi: 10.3109/10550490903077929. PMID: 19874153. Excluded: Non-FDA approved pharmacologic intervention19874153
Schmitz JM, Stotts AL, Rhoades HM, . Naltrexone and relapse prevention treatment for cocaine-dependent patients. Addict Behav. 2001;26(2):167–80. PMID: 11316375. Excluded: <3 month followup duration11316375
Schmitz JM, Stotts AL, Sayre SL, . Treatment of cocaine-alcohol dependence with naltrexone and relapse prevention therapy. Am J Addict. 2004;13(4):333–41. PMID: 15370932. Excluded: Wrong comparator15370932
Schmitz JM, Stotts AL, Sayre SL, . Naltrexone and relapse prevention treatment for cocaine-alcohol-dependent patients. Drug Alcohol Depend. 2002;66(1). Excluded: <3 month followup duration
Schmitz JM, Stotts AL, Vujanovic AA, . A sequential multiple assignment randomized trial for cocaine cessation and relapse prevention: Tailoring treatment to the individual. Contemp Clin Trials. 2018;65:109–15. doi: 10.1016/j.cct.2017.12.015. PMID: 29287664. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.29287664
Schottenfeld RS, Chawarski MC, Pakes JR, . Methadone versus buprenorphine with contingency management or performance feedback for cocaine and opioid dependence. Am J Psychiatry. 2005;162(2):340–9. PMID: 15677600. Excluded: Wrong comparator15677600
Schottenfeld RS, Mokri A, Taheri Nakhost H, . Buprenorphine vs naltrexone maintenance treatment for opium- or heroin-dependent individuals in Iran: Preliminary findings of a pilot randomized clinical trial. Proceedings of the 69th Annual Scientific Meeting of the College on Problems of Drug Dependence. 2007. Excluded: Results reported elsewhere, duplicate results
Schottenfeld RS, Pakes JR, Kosten TR. Prognostic factors in buprenorphine- versus methadone-maintained patients. J Nerv Ment Dis. 1998;186(1):35–43. PMID: 9457145. Excluded: Wrong comparator9457145
Schottenfeld RS, Pakes JR, Oliveto A, . Buprenorphine vs methadone maintenance treatment for concurrent opioid dependence and cocaine abuse. Arch Gen Psychiatry. 1997;54(8):713–20. PMID: 9283506. Excluded: Wrong comparator9283506
Schroeder JR, Epstein DH, Umbricht A, . Changes in HIV risk behaviors among patients receiving combined pharmacological and behavioral interventions for heroin and cocaine dependence. Addict Behav. 2006;31(5):868–79. PMID: 16085366. Excluded: Wrong comparator16085366
Schroeder JR, Schmittner JP, Epstein DH, . Adverse events among patients in a behavioral treatment trial for heroin and cocaine dependence: effects of age, race, and gender. Drug Alcohol Depend. 2005;80(1):45–51. PMID: 16157230. Excluded: Wrong comparator16157230
Schuler ME, Nair P, Black MM. Ongoing maternal drug use, parenting attitudes, and a home intervention: effects on mother-child interaction at 18 months. J Dev Behav Pediatr. 2002;23(2):87–94. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)11943970
Schwartz RP, Kelly SM, Mitchell SG, . Interim methadone and patient navigation in jail: Rationale and design of a randomized clinical trial. Contemp Clin Trials. 2016;49:21–8. doi: 10.1016/j.cct.2016.06.002. PMID: 27282117. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.27282117
Schwartz RP, Kelly SM, Mitchell SG, . Patient-centered methadone treatment: a randomized clinical trial. Addiction. 2017;112(3):454–64. doi: 10.1111/add.13622. PMID: 27661788. Excluded: Wrong comparator27661788
Schwartz RP, Kelly SM, O’Grady KE, . Randomized trial of standard methadone treatment compared to initiating methadone without counseling: 12-month findings. Addiction. 2012;107(5):943–52. doi: 10.1111/j.1360-0443.2011.03700.x. PMID: 22029398. Excluded: Wrong comparator22029398
Scott WC, Kaiser D, Othmer S, . Effects of an EEG biofeedback protocol on a mixed substance abusing population. Am J Drug Alcohol Abuse. 2005;31(3):455–69. PMID: 16161729. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)16161729
Sealock MD, Gottfredson DC, Gallagher CA. Drug treatment for juvenile offenders: Some good and bad news. J Res Crime Delinq. 1997;34(2):210–36. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Secades-Villa R, Garcia-Rodriguez O, Garcia-Fernandez G, . Community reinforcement approach plus vouchers among cocaine-dependent outpatients: twelve-month outcomes. Psychol Addict Behav. 2011;25(1):174–9. doi: 10.1037/a0021451. PMID: 21261406. Excluded: Wrong comparator21261406
Secades-Villa R, Garcia-Rodriguez O, Higgins ST, . Community reinforcement approach plus vouchers for cocaine dependence in a community setting in Spain: six-month outcomes. J Subst Abuse Treat. 2008;34(2):202–7. PMID: 17512158. Excluded: Wrong comparator17512158
Secades-Villa R, Sanchez-Hervas E, Zacares-Romaguera F, . Community reinforcement approach (CRA) for cocaine dependence in the Spanish public health system: 1 year outcome. Drug Alcohol Rev. 2011;30(6):606–12. doi: 10.1111/j.1465-3362.2010.00250.x. PMID: 21355914. Excluded: Wrong comparator21355914
Sees KL, Delucchi KL, Masson C, . Methadone maintenance vs 180-day psychosocially enriched detoxification for treatment of opioid dependence: a randomized controlled trial. JAMA. 2000;283(10):1303–10. PMID: 10714729. Excluded: Wrong comparator10714729
Senay EC, Dorus W, Goldberg F, . Withdrawal from methadone maintenance. Rate of withdrawal and expectation. Arch Gen Psychiatry. 1977;34(3):361–7. PMID: 843188. Excluded: Wrong comparator843188
Sexton T, Turner CW. The effectiveness of functional family therapy for youth with behavioral problems in a community practice setting. J Fam Psychol. 2010;24(3):339–48. doi: 10.1037/a0019406. PMID: 20545407. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)20545407
Sharma A, O’Grady KE, Kelly SM, . Pharmacotherapy for opioid dependence in jails and prisons: research review update and future directions. Subst Abuse Rehabil. 2016;7:27–40. doi: 10.2147/SAR.S81602. PMID: 27217808. Excluded: Incarcerated population27217808
Shaul L, Koeter MW, Schippers GM. Brief motivation enhancing intervention to prevent criminal recidivism in substance-abusing offenders under supervision: A randomized trial. Psychology, Crime & Law. 2016;22(9):903–14. doi: 10.1080/1068316X.2016.1202248. Excluded: <70% drug misuse or likely majority alcohol
Shetty V, Murphy DA, Zigler C, . Randomized controlled trial of personalized motivational interventions in substance using patients with facial injuries. J Oral Maxillofac Surg. 2011;69(9):2396–411. doi: 10.1016/j.joms.2010.12.040. PMID: 21496991. Excluded: <70% drug misuse or likely majority alcohol21496991
Shoptaw S, Huber A, Peck J, . Randomized, placebo-controlled trial of sertraline and contingency management for the treatment of methamphetamine dependence. Drug Alcohol Depend. 2006;85(1):12–8. doi: 10.1016/j.drugalcdep.2006.03.005. PMID: 16621339. Excluded: Wrong comparator16621339
Sigmon SC. Interim treatment: Bridging delays to opioid treatment access. Prev Med. 2015;80:32–6. doi: 10.1016/j.ypmed.2015.04.017. PMID: 25937593. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies25937593
Sigmon SC, Correia CJ, Stitzer ML. Cocaine abstinence during methadone maintenance: effects of repeated brief exposure to voucher-based reinforcement. Exp Clin Psychopharmacol. 2004;12(4):269–75. PMID: 15571444. Excluded: Wrong comparator15571444
Sigmon SC, Ochalek TA, Meyer AC, . Interim buprenorphine vs. waiting list for opioid dependence. N Engl J Med. 2016;375(25):2504–5. doi: 10.1056/NEJMc1610047. PMID: 28002704. Excluded: <3 month followup duration28002704
Silverman K, Higgins ST, Brooner RK, . Sustained cocaine abstinence in methadone maintenance patients through voucher-based reinforcement therapy. Arch Gen Psychiatry. 1996;53(5):409–15. PMID: 8624184. Excluded: Wrong comparator8624184
Silverman K, Robles E, Mudric T, . A randomized trial of long-term reinforcement of cocaine abstinence in methadone-maintained patients who inject drugs. J Consult Clin Psychol. 2004;72(5):839–54. PMID: 15482042. Excluded: Wrong comparator15482042
Silverman K, Svikis D, Robles E, . A reinforcement-based therapeutic workplace for the treatment of drug abuse: Six-month abstinence outcomes. Exp Clin Psychopharmacol. 2001;9(1):14–23. PMID: 11519628. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)11519628
Silverman K, Wong CJ, Needham M, . A randomized trial of employment-based reinforcement of cocaine abstinence in injection drug users. J Appl Behav Anal. 2007;40(3):387–410. PMID: 17970256. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17970256
Simpson DD, Joe GW, Rowan-Szal GA, . Drug abuse treatment process components that improve retention. J Subst Abuse Treat. 1997;14(6):565–72. PMID: 9437628. Excluded: Wrong comparator9437628
Sinadinovic K, Wennberg P, Berman AH. Targeting problematic users of illicit drugs with internet-based screening and brief intervention: a randomized controlled trial. Drug Alcohol Depend. 2012;126(1-2):42–50. doi: 10.1016/j.drugalcdep.2012.04.016. PMID: 22613182. Excluded: Other wrong population (e.g., schizophrenia focus)22613182
Sinadinovic K, Wennberg P, Berman AH. Internet-based screening and brief intervention for illicit drug users: a randomized controlled trial with 12-month follow-up. J Stud Alcohol Drugs. 2014;75(2):313–8. PMID: 24650825. Excluded: Other wrong population (e.g., schizophrenia focus)24650825
Sinha R, Easton C, Renee-Aubin L, . Engaging young probation-referred marijuana-abusing individuals in treatment: a pilot trial. Am J Addict. 2003;12(4):314–23. PMID: 14504024. Excluded: Wrong comparator14504024
Slesnick N, Erdem G. Efficacy of ecologically-based treatment with substance-abusing homeless mothers: substance use and housing outcomes. J Subst Abuse Treat. 2013;45(5):416–25. doi: 10.1016/j.jsat.2013.05.008. PMID: 23890686. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)23890686
Slesnick N, Erdem G, Bartle-Haring S, . Intervention with substance-abusing runaway adolescents and their families: results of a randomized clinical trial. J Consult Clin Psychol. 2013;81(4):600–14. doi: 10.1037/a0033463. PMID: 23895088. Excluded: Wrong comparator23895088
Slesnick N, Prestopnik JL. Ecologically based family therapy outcome with substance abusing runaway adolescents. J Adolesc. 2005;28(2):277–98. doi: 10.1016/j.adolescence.2005.02.008. PMID: 15878048. Excluded: Wrong comparator15878048
Slesnick N, Prestopnik JL. Comparison of family therapy outcome with alcohol-abusing, runaway adolescents. J Marital Fam Ther. 2009;35(3):255–77. doi: 10.1111/j.1752-0606.2009.00121.x. PMID: 19522781. Excluded: Other wrong population (e.g., schizophrenia focus)19522781
Smelson D, Kalman D, Losonczy MF, . A brief treatment engagement intervention for individuals with co-occurring mental illness and substance use disorders: results of a randomized clinical trial. Community Ment Health J. 2012;48(2):127–32. doi: 10.1007/s10597-010-9346-9. PMID: 20859765. Excluded: Other wrong population (e.g., schizophrenia focus)20859765
Smith DC, Hall JA, Williams JK, . Comparative efficacy of family and group treatment for adolescent substance abuse. Am J Addict. 2006;15: Suppl 1:131–6. doi: 10.1080/10550490601006253. PMID: 17182429. Excluded: Wrong comparator17182429
Smith L, Mosley J, Johnson J, . Probuphine (Buprenorphine) subdermal implants for the treatment of opioid-dependent patients. P T. 2017;42(8):505–8. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.28781503
Smith TE. Reducing adolescents’ marihuana abuse. Soc Work Health Care. 1983;9(1):33–44. doi: 10.1300/J010v09n01_03. PMID: 6605586. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.6605586
Sokol R, LaVertu AE, Morrill D, . Group-based treatment of opioid use disorder with buprenorphine: A systematic review. J Subst Abuse Treat. 2018;84:78–87. doi: 10.1016/j.jsat.2017.11.003. PMID: 29195596. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies29195596
Somoza E, Carter J, Upadhyaya H, . A double-blind, placebo controlled clinical trial of naltrexone as a treatment for cocaine dependence. NIDA Res Monogr. 1998;179(138). Excluded: Non-FDA approved pharmacologic intervention
Sordo L, Barrio G, Bravo MJ, . Mortality risk during and after opioid substitution treatment: systematic review and meta-analysis of cohort studies. BMJ. 2017;357:j1550. doi: 10.1136/bmj.j1550. PMID: 28446428. Excluded: Wrong study design for key question28446428
Sorensen JL, Masson CL, Delucchi K, . Randomized trial of drug abuse treatment-linkage strategies. J Consult Clin Psychol. 2005;73(6):1026–35. PMID: 16392976. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)16392976
Sorsdahl K, Stein DJ, Corrigall J, . The efficacy of a blended motivational interviewing and problem solving therapy intervention to reduce substance use among patients presenting for emergency services in South Africa: A randomized controlled trial. Subst Abuse Treat Prev Policy. 2015;10:46. doi: 10.1186/s13011-015-0042-1. PMID: 26576946. Excluded: Wrong country26576946
Soyka M. Buprenorphine use in pregnant opioid users: a critical review. CNS Drugs. 2013;27(8):653–62. doi: 10.1007/s40263-013-0072-z. PMID: 23775478. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.23775478
Soyka M, Trader A, Klotsche J, . Six-year mortality rates of patients in methadone and buprenorphine maintenance therapy: Results from a nationally representative cohort study. J Clin Psychopharmacol. 2011;31(5):678–80. doi: 10.1097/JCP.0b013e31822cd446. PMID: 21881461. Excluded: Wrong study design for key question21881461
Spirito A, Hernandez L, Marceau K, . Effects of a brief, parent-focused intervention for substance using adolescents and their sibling. J Subst Abuse Treat. 2017;77:156–65. doi: 10.1016/j.jsat.2017.02.002. PMID: 28259500. Excluded: Wrong comparator28259500
Spoth R, Redmond C, Clair S, . Preventing substance misuse through community-university partnerships: randomized controlled trial outcomes 41/2 years past baseline. Am J Prev Med. 2011;40(4):440–7. doi: 10.1016/j.amepre.2010.12.012. PMID: 21406278. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)21406278
Spoth R, Redmond C, Shin C, . Brief family intervention effects on adolescent substance initiation: school-level growth curve analyses 6 years following baseline. J Consult Clin Psychol. 2004;72(3):535–42. PMID: 15279537. Excluded: School setting15279537
Spoth R, Redmond C, Shin C, . Substance-use outcomes at 18 months past baseline: the PROSPER community-university partnership trial. Am J Prev Med. 2007;32(5):395–402. PMID: 17478265. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17478265
Spoth R, Redmond C, Shin C, . PROSPER community-university partnership delivery system effects on substance misuse through 6 1/2 years past baseline from a cluster randomized controlled intervention trial. Prev Med. 2013;56(3-4):190–6. doi: 10.1016/j.ypmed.2012.12.013. PMID: 23276777. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)23276777
Spoth R, Redmond C, Shin C, . PROSPER delivery of universal preventive interventions with young adolescents: long-term effects on emerging adult substance misuse and associated risk behaviors. Psychol Med. 2017;47(13):2246–59. doi: 10.1017/S0033291717000691. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28399955
Spoth R, Trudeau L, Guyll M, . Universal intervention effects on substance use among young adults mediated by delayed adolescent substance initiation. J Consult Clin Psychol. 2009;77(4):620–32. doi: 10.1037/a0016029. PMID: 19634956. Excluded: Wrong study design for key question19634956
Spoth RL, Randall GK, Trudeau L, . Substance use outcomes 51/2 years past baseline for partnership-based, family-school preventive interventions. Drug Alcohol Depend. 2008;96(1-2):57–68. doi: 10.1016/j.drugalcdep.2008.01.023. PMID: 18434045. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)18434045
Spoth RL, Redmond C, Shin C. Randomized trial of brief family interventions for general populations: adolescent substance use outcomes 4 years following baseline. J Consult Clin Psychol. 2001;69(4):627–42. PMID: 11550729. Excluded: School setting11550729
Spoth RL, Trudeau LS, Guyll M, . Benefits of universal intervention effects on a youth protective shield 10 years after baseline. J Adolesc Health. 2012;50(4):414–7. doi: 10.1016/j.jadohealth.2011.06.010. PMID: 22443848. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)22443848
Spruit IP. The effectiveness of the medical prescription of heroin studied by randomized trials in The Netherlands, watched suspiciously by parliament and neighborhoods. Subst Use Misuse. 2002;37(4):555–63. PMID: 12064437. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.12064437
Srisurapanont M, Sombatmai S, Boripuntakul T. Brief intervention for students with methamphetamine use disorders: a randomized controlled trial. Am J Addict. 2007;16(2):111–6. PMID: 17453612. Excluded: <3 month followup duration17453612
Srivastava A, Kahan M, Nader M. Primary care management of opioid use disorders: Abstinence, methadone, or buprenorphine-naloxone? Can Fam Physician. 2017;63(3):200–5. PMID: 28292795. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.28292795
Staiger PK, Kyrios M, Williams JS, . Improving the retention rate for residential treatment of substance abuse by sequential intervention for social anxiety. BMC Psychiatry. 2014;14:43. doi: 10.1186/1471-244X-14-43. PMID: 24533512. Excluded: Inpatient population24533512
Stanger C, Budney AJ, Kamon JL, . A randomized trial of contingency management for adolescent marijuana abuse and dependence. Drug Alcohol Depend. 2009;105(3):240–7. doi: 10.1016/j.drugalcdep.2009.07.009. PMID: 19717250. Excluded: Wrong comparator19717250
Stein MD, Caviness CM, Morse EF, . A developmental-based motivational intervention to reduce alcohol and marijuana use among non-treatment-seeking young adults: a randomized controlled trial. Addiction. 2017;113(3):440–53. doi: 10.1111/add.14026. PMID: 28865169. Excluded: Other wrong population (e.g., schizophrenia focus)28865169
Steinka-Fry KT, Tanner-Smith EE, Dakof GA, . Culturally sensitive substance use treatment for racial/ethnic minority youth: A meta-analytic review. J Subst Abuse Treat. 2017;75:22–37. doi: 10.1016/j.jsat.2017.01.006. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies28237051
Stephens RS, Roffman RA, Simpson EE. Treating adult marijuana dependence: a test of the relapse prevention model. J Consult Clin Psychol. 1994;62(1):92–9. PMID: 8034835. Excluded: Wrong comparator8034835
Stewart DG, Siebert EC, Arlt VK, . READY or not: Findings from a school-based MI intervention for adolescent substance use. J Subst Abuse Treat. 2016;71:23–9. doi: 10.1016/j.jsat.2016.08.007. PMID: 27776673. Excluded: School setting27776673
Stitzer M, Calsyn D, Matheson T, . Development of a multi-target contingency management intervention for HIV positive substance users. J Subst Abuse Treat. 2017;72:66–71. doi: 10.1016/j.jsat.2016.08.018. PMID: 27624618. Excluded: Other wrong population (e.g., schizophrenia focus)27624618
Stitzer ML, Iguchi MY, Felch LJ. Contingent take-home incentive: effects on drug use of methadone maintenance patients. J Consult Clin Psychol. 1992;60(6):927–34. PMID: 1460154. Excluded: Wrong comparator1460154
Stoermer R, Drewe J, Dursteler-Mac Farland KM, . Safety of injectable opioid maintenance treatment for heroin dependence. Biol Psychiatry. 2003;54(8):854–61. PMID: 14550686. Excluded: <3 month followup duration14550686
Stoller KB, Bigelow GE, Walsh SL, . Effects of buprenorphine/naloxone in opioid-dependent humans. Psychopharmacology (Berl). 2001;154(3):230–42. PMID: 11351930. Excluded: Inpatient population11351930
Stotts AL, Green C, Masuda A, . A stage I pilot study of acceptance and commitment therapy for methadone detoxification. Drug Alcohol Depend. 2012;125(3):215–22. doi: 10.1016/j.drugalcdep.2012.02.015. PMID: 22425411. Excluded: Wrong outcome22425411
Stotts AL, Northrup TF. The promise of third-wave behavioral therapies in the treatment of substance use disorders. Curr Opin Psychol. 2015;2:75–81. PMID: 26693170. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26693170
Stotts AL, Schmitz JM, Rhoades HM, . Motivational interviewing with cocaine-dependent patients: A pilot study. J Consult Clin Psychol. 2001;69(5):858–62. doi: 10.1037/0022-006X.69.5.858. Excluded: Wrong comparator11680565
Strain EC, Stitzer ML, Liebson IA, . Dose-response effects of methadone in the treatment of opioid dependence. Ann Intern Med. 1993;119(1):23–7. PMID: 8498759. Excluded: Wrong comparator8498759
Strain EC, Stitzer ML, Liebson IA, . Comparison of buprenorphine and methadone in the treatment of opioid dependence. Am J Psychiatry. 1994;151(7):1025–30. PMID: 8010359. Excluded: Wrong comparator8010359
Strain EC, Stitzer ML, Liebson IA, . Buprenorphine versus methadone in the treatment of opioid-dependent cocaine users. Psychopharmacology (Berl). 1994;116(4):401–6. PMID: 7701040. Excluded: Wrong comparator7701040
Strang J, Best D, Ridge G, . Randomised clinical trial of the effects of time on a waiting list on clinical outcomes in opiate addicts awaiting outpatient treatment. Drugs Educ Prev Polic. 2005;12(Suppl1):115–8. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Streck JM, Ochalek TA, Hruska B, . Improvement in psychiatric symptoms during interim buprenorphine treatment. Drug Alcohol Depend. 2017;171. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Suchman NE, DeCoste CL, McMahon TJ, . Mothering from the inside out: Results of a second randomized clinical trial testing a mentalization-based intervention for mothers in addiction treatment. Dev Psychopathol. 2017;29(2):617–36. doi: 10.1017/S0954579417000220. PMID: 28401850. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28401850
Sullivan LE, Barry D, Moore BA, . A trial of integrated buprenorphine/naloxone and HIV clinical care. Clin Infect Dis. 2006;43: Suppl 4:S184–90. PMID: 17109305. Excluded: Wrong comparator17109305
Sullivan LE, Bruce RD, Haltiwanger D, . Initial strategies for integrating buprenorphine into HIV care settings in the United States. Clin Infect Dis. 2006;43: Suppl 4:S191–6. PMID: 17109306. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.17109306
Sullivan LE, Moore BA, Chawarski MC, . Buprenorphine/naloxone treatment in primary care is associated with decreased human immunodeficiency virus risk behaviors. J Subst Abuse Treat. 2008;35(1):87–92. PMID: 17933486. Excluded: Wrong study design for key question17933486
Sullivan MA, Bisaga A, Glass A, . Opioid use and dropout in patients receiving oral naltrexone with or without single administration of injection naltrexone. Drug Alcohol Depend. 2015;147:122–9. doi: 10.1016/j.drugalcdep.2014.11.028. PMID: 25555621. Excluded: Wrong comparator25555621
Sullivan MA, Bisaga A, Mariani JJ, . Naltrexone treatment for opioid dependence: does its effectiveness depend on testing the blockade? Drug Alcohol Depend. 2013;133(1):80–5. doi: 10.1016/j.drugalcdep.2013.05.030. PMID: 23827259. Excluded: <3 month followup duration23827259
Sun HM, Li XY, Chow EP, . Methadone maintenance treatment programme reduces criminal activity and improves social well-being of drug users in China: a systematic review and meta-analysis. BMJ Open. 2015;5(1):e005997. doi: 10.1136/bmjopen-2014-005997. PMID: 25573521. Excluded: Wrong comparator25573521
Surratt HL, Inciardi JA. An effective HIV risk-reduction protocol for drug-using female sex workers. J Prev Interv Community. 2010;38(2):118–31. doi: 10.1080/10852351003640732. PMID: 20391059. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)20391059
Sussman S, Sun P, Rohrbach LA, . One-year outcomes of a drug abuse prevention program for older teens and emerging adults: evaluating a motivational interviewing booster component. Health Psychol. 2012;31(4):476–85. doi: 10.1037/a0025756. PMID: 21988096. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)21988096
Svikis DS, Keyser-Marcus L, Stitzer M, . Randomized multi-site trial of the job seekers’ workshop in patients with substance use disorders. Drug Alcohol Depend. 2012;120(1-3):55–64. doi: 10.1016/j.drugalcdep.2011.06.024. PMID: 21802222. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)21802222
Sweeney LP, Samet JH, Larson MJ, . Establishment of a multidisciplinary health evaluation and linkage to primary care (HELP) clinic in a detoxification unit. J Addict Dis. 2004;23(2):33–45. PMID: 15132341. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)15132341
Swisher JD, Warner RW, Herr EL. Experimental comparison of four approaches to drug abuse prevention among ninth and eleventh graders. J Couns Psychol. 1972;19(4):328–32. doi: 10.1037/h0033084. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Szapocznik J, Kurtines WM, Foote F, . Conjoint versus one-person family therapy: further evidence for the effectiveness of conducting family therapy through one person with drug-abusing adolescents. J Consult Clin Psychol. 1986;54(3):395–7. PMID: 3722570. Excluded: Wrong comparator3722570
Szapocznik J, Kurtines WM, Foote FH, . Conjoint versus one-person family therapy: some evidence for the effectiveness of conducting family therapy through one person. J Consult Clin Psychol. 1983;51(6):889–99. PMID: 6655103. Excluded: Wrong comparator6655103
Szapocznik J, Muir JA, Duff JH, . Brief strategic family therapy: implementing evidence-based models in community settings. Psychotherapy Research. 2015;25(1):121–33. doi: 10.1080/10503307.2013.856044. PMID: 24274187. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.24274187
Szapocznik J, Williams RA. Brief strategic family therapy: twenty-five years of interplay among theory, research and practice in adolescent behavior problems and drug abuse. Clin Child Fam Psychol Rev. 2000;3(2):117–34. PMID: 11227062. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.11227062
Tait RJ, Hulse GK. A systematic review of the effectiveness of brief interventions with substance using adolescents by type of drug. Drug Alcohol Rev. 2003;22(3):337–46. PMID: 15385228. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies15385228
Tait RJ, Hulse GK. Adolescent substance use and hospital presentations: a record linkage assessment of 12-month outcomes. Drug Alcohol Depend. 2005;79(3):365–71. PMID: 15896928. Excluded: Wrong study design for key question15896928
Tait RJ, Hulse GK, Robertson SI. Effectiveness of a brief-intervention and continuity of care in enhancing attendance for treatment by adolescent substance users. Drug Alcohol Depend. 2004;74(3):289–96. PMID: 15194207. Excluded: Other wrong population (e.g., schizophrenia focus)15194207
Tait RJ, Hulse GK, Robertson SI, . Emergency department-based intervention with adolescent substance users: 12-month outcomes. Drug Alcohol Depend. 2005;79(3):359–63. PMID: 16102378. Excluded: Other wrong population (e.g., schizophrenia focus)16102378
Tait RJ, McKetin R, Kay-Lambkin F, . Breakingtheice: a protocol for a randomised controlled trial of an internet-based intervention addressing amphetamine-type stimulant use. BMC Psychiatry. 2012;12:67. doi: 10.1186/1471-244X-12-67. PMID: 22731926. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.22731926
Tang YY, Tang R, Posner MI. Mindfulness meditation improves emotion regulation and reduces drug abuse. Drug Alcohol Depend. 2016;163: Suppl 1:S13–8. doi: 10.1016/j.drugalcdep.2015.11.041. PMID: 27306725. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.27306725
Tanner-Smith EE, Steinka-Fry KT, Hennessy EA, . Can brief alcohol interventions for youth also address concurrent illicit drug use? results from a meta-analysis. J Youth Adolesc. 2015;44(5):1011–23. doi: 10.1007/s10964-015-0252-x. PMID: 25600491. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)25600491
Tanner-Smith EE, Steinka-Fry KT, Hensman Kettrey H, . Adolescent substance use treatment effectiveness: A systematic review and meta-analysis. Nashville, TN: Peabody Research Institute, Vanderbilt University; 2016. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Tanner-Smith EE, Wilson SJ, Lipsey MW. The comparative effectiveness of outpatient treatment for adolescent substance abuse: A meta-analysis. J Subst Abuse Treat. 2013;44(2):145–58. doi: 10.1016/j.jsat.2012.05.006. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies22763198
Tarantino N, Lamis DA, Ballard ED, . Parent-child conflict and drug use in college women: A moderated mediation model of self-control and mindfulness. J Couns Psychol. 2015;62(2):303–13. doi: 10.1037/cou0000013. PMID: 24660687. Excluded: Wrong study design for key question24660687
Taxman FS, Walters ST, Sloas LB, . Motivational tools to improve probationer treatment outcomes. Contemp Clin Trials. 2015;43:120–8. doi: 10.1016/j.cct.2015.05.016. PMID: 26009023. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.26009023
Ter Riet G, Kleijnen J, Knipschild P. A meta-analysis of studies into the effect of acupuncture on addiction. Br J Gen Pract. 1990;40(338):379–82. PMID: 2148263. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies2148263
Terplan M, Lui S. Psychosocial interventions for pregnant women in outpatient illicit drug treatment programs compared to other interventions. Cochrane Database Syst Rev. 2007 (4):CD006037. PMID: 17943878. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies17943878
Terplan M, Ramanadhan S, Locke A, . Psychosocial interventions for pregnant women in outpatient illicit drug treatment programs compared to other interventions. Cochrane Database Syst Rev. 2015 (4):CD006037. doi: 10.1002/14651858.CD006037.pub3. PMID: 25835053. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies25835053
Tetrault JM, Moore BA, Barry DT, . Brief versus extended counseling along with buprenorphine/naloxone for HIV-infected opioid dependent patients. J Subst Abuse Treat. 2012;43(4):433–9. doi: 10.1016/j.jsat.2012.07.011. PMID: 22938914. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)22938914
The Marijuana Treatment Project Research Group. Brief treatments for cannabis dependence: Findings from a randomized multisite trial. Addictive behaviors: New readings on etiology, prevention, and treatment. Washington, DC: American Psychological Association; US; 2009:429–57. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Thomas CP, Fullerton CA, Kim M, . Medication-assisted treatment with buprenorphine: assessing the evidence. Psychiatr Serv. 2014;65(2):158–70. doi: 10.1176/appi.ps.201300256. PMID: 24247147. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24247147
Thornton PI, Igleheart HC, Silverman LH. Subliminal stimulation of symbiotic fantasies as an aid in the treatment of drug abusers. Int J Addict. 1987;22(8):751–65. PMID: 3316063. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)3316063
Throckmorton DC, Temple R, Rappaport BA, . Injectable extended-release naltrexone for opioid dependence. Lancet. 2011;378(9792):665–6. doi: 10.1016/S0140-6736%2811%2961332-9. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.
Thylstrup B, Hesse M. Impulsive lifestyle counseling to prevent dropout from treatment for substance use disorders in people with antisocial personality disorder: A randomized study. Addict Behav. 2016;57:48–54. doi: 10.1016/j.addbeh.2016.02.001. PMID: 26882500. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)26882500
Thylstrup B, Schroder S, Hesse M. Psycho-education for substance use and antisocial personality disorder: a randomized trial. BMC Psychiatry. 2015;15:283. doi: 10.1186/s12888-015-0661-0. PMID: 26573140. Excluded: Other wrong population (e.g., schizophrenia focus)26573140
Tiihonen J, Krupitsky E, Verbitskaya E, . Naltrexone implant for the treatment of polydrug dependence: a randomized controlled trial. Am J Psychiatry. 2012;169(5):531–6. PMID: 22764364. Excluded: <3 month followup duration22764364
Timko C, DeBenedetti A. A randomized controlled trial of intensive referral to 12-step self-help groups: one-year outcomes. Drug Alcohol Depend. 2007;90(2-3):270–9. PMID: 17524574. Excluded: Wrong comparator17524574
Timko C, Debenedetti A, Billow R. Intensive referral to 12-Step self-help groups and 6-month substance use disorder outcomes. Addiction. 2006;101(5):678–88. Excluded: Wrong comparator16669901
Timko C, Kong C, Vittorio L, . Screening and brief intervention for unhealthy substance use in patients with chronic medical conditions: A systematic review. J Clin Nurs. 2016;25(21-22):3131–43. doi: 10.1111/jocn.13244. PMID: 27140392. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies27140392
Timko C, Schultz NR, Cucciare MA, . Retention in medication-assisted treatment for opiate dependence: A systematic review. J Addict Dis. 2016;35(1):22–35. doi: 10.1080/10550887.2016.1100960. PMID: 26467975. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies26467975
Timko C, Sempel JM. Intensity of acute services, self-help attendance and one-year outcomes among dual diagnosis patients. J Stud Alcohol Drugs. 2004;65(2):274–82. doi: 10.15288/jsa.2004.65.274. Excluded: Other wrong population (e.g., schizophrenia focus)
Tjagvad C, Skurtveit S, Linnet K, . Methadone-related overdose deaths in a liberal opioid maintenance treatment programme. Eur Addict Res. 2016;22(5):249–58. doi: 10.1159/000446429. PMID: 27246839. Excluded: Wrong study design for key question27246839
Tolou-Shams M, Dauria E, Conrad SM, . Outcomes of a family-based HIV prevention intervention for substance using juvenile offenders. J Subst Abuse Treat. 2017;77:115–25. doi: 10.1016/j.jsat.2017.03.013. PMID: 28476263. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)28476263
Tossmann HP, Jonas B, Tensil MD, . A controlled trial of an internet-based intervention program for cannabis users. Cyberpsychol Behav Soc Netw. 2011;14(11):673–9. doi: 10.1089/cyber.2010.0506. PMID: 21651419. Excluded: Poor quality21651419
Tsai LC, Doan TJ. Breastfeeding among mothers on opioid maintenance treatment: A literature review. J Hum Lact. 2016;32(3):521–9. doi: 10.1177/0890334416641909. PMID: 27053175. Excluded: Wrong study design for key question27053175
Tsui JI, Evans JL, Lum PJ, . Association of opioid agonist therapy with lower incidence of hepatitis C virus infection in young adult injection drug users. JAMA Intern Med. 2014;174(12):1974–81. doi: 10.1001/jamainternmed.2014.5416. PMID: 25347412. Excluded: Wrong study design for key question25347412
Tuchman E, Gregory C, Simson M, . Safety, efficacy, and feasibility of office-based prescribing and community pharmacy dispensing of methadone: Results of a pilot study in New Mexico. Addict Disord Their Treat. 2006;5(2):43–51. Excluded: Wrong comparator
Tucker T, Ritter A, Maher C, . A randomized control trial of group counseling in a naltrexone treatment program. J Subst Abuse Treat. 2004;27(4):277–88. PMID: 15610829. Excluded: Wrong comparator15610829
Turner KM, Hutchinson S, Vickerman P, . The impact of needle and syringe provision and opiate substitution therapy on the incidence of hepatitis C virus in injecting drug users: pooling of UK evidence. Addiction. 2011;106(11):1978–88. doi: 10.1111/j.1360-0443.2011.03515.x. PMID: 21615585. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies21615585
Tusel DJ, Piotrowski NA, Sees KL, . Contingency contracting for illicit drug use wit opioid addicts in methadone treatment. NIDA Res Monogr. 1994;153(155). Excluded: Wrong comparator
Tuten M, DeFulio A, Jones HE, . Abstinence-contingent recovery housing and reinforcement-based treatment following opioid detoxification. Addiction. 2012;107(5):973–82. doi: 10.1111/j.1360-0443.2011.03750.x. PMID: 22151478. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)22151478
Tuten M, Svikis DS, Keyser-Marcus L, . Lessons learned from a randomized trial of fixed and escalating contingency management schedules in opioid-dependent pregnant women. Am J Drug Alcohol Abuse. 2012;38(4):286–92. doi: 10.3109/00952990.2011.643977. PMID: 22352784. Excluded: Wrong comparator22352784
Unger A, Jagsch R, Bawert A, . Are male neonates more vulnerable to neonatal abstinence syndrome than female neonates? Gend Med. 2011;8(6):355–64. doi: 10.1016/j.genm.2011.10.001. PMID: 22088886. Excluded: Wrong comparator22088886
Unger AS, Martin PR, Kaltenbach K, . Clinical characteristics of Central European and North American samples of pregnant women screened for opioid agonist treatment. Eur Addict Res. 2010;16(2):99–107. doi: 10.1159/000284683. PMID: 20160444. Excluded: Wrong outcome20160444
Valls-Serrano C, Caracuel A, Verdejo-Garcia A. Goal management training and mindfulness meditation improve executive functions and transfer to ecological tasks of daily life in polysubstance users enrolled in therapeutic community treatment. Drug Alcohol Depend. 2016;165:9–14. doi: 10.1016/j.drugalcdep.2016.04.040. PMID: 27246405. Excluded: Wrong outcome27246405
van Dam D, Ehring T, Vedel E, . Trauma-focused treatment for posttraumatic stress disorder combined with CBT for severe substance use disorder: a randomized controlled trial. BMC Psychiatry. 2013;13:172. doi: 10.1186/1471-244X-13-172. PMID: 23782590. Excluded: Other wrong population (e.g., schizophrenia focus)23782590
van Dam D, Vedel E, Ehring T, . Psychological treatments for concurrent posttraumatic stress disorder and substance use disorder: a systematic review. Clin Psychol Rev. 2012;32(3):202–14. doi: 10.1016/j.cpr.2012.01.004. PMID: 22406920. Excluded: Other wrong population (e.g., schizophrenia focus)22406920
Van den Brink W, Haasen C. Evidenced-based treatment of opioid-dependent patients. Can J Psychiatry. 2006;51(10):635–46. PMID: 17052031. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.17052031
van Emmerik-van Oortmerssen K, Vedel E, Koeter MW, . Investigating the efficacy of integrated cognitive behavioral therapy for adult treatment seeking substance use disorder patients with comorbid ADHD: study protocol of a randomized controlled trial. BMC Psychiatry. 2013;13:132. doi: 10.1186/1471-244X-13-132. PMID: 23663651. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.23663651
Van Ryzin MJ, Roseth CJ, Fosco GM, . A component-centered meta-analysis of family-based prevention programs for adolescent substance use. Clin Psychol Rev. 2016;45:72–80. doi: 10.1016/j.cpr.2016.03.007. Excluded: Wrong study design for key question27064553
Vaughn MG, Howard MO. Adolescent substance abuse treatment: A synthesis of controlled evaluations. Res Soc Work Pract. 2004;14(5):325–35. doi: 10.1177/1049731504265834. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies
Vederhus JK, Timko C, Kristensen O, . Motivational intervention to enhance post-detoxification 12-Step group affiliation: a randomized controlled trial. Addiction. 2014;109(5):766–73. doi: 10.1111/add.12471. PMID: 24400937. Excluded: Wrong outcome24400937
Veilleux JC, Colvin PJ, Anderson J, . A review of opioid dependence treatment: pharmacological and psychosocial interventions to treat opioid addiction. Clin Psychol Rev. 2010;30(2):155–66. doi: 10.1016/j.cpr.2009.10.006. PMID: 19926374. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies19926374
Verthein U, Haasen C, Krausz M. Auricular acupuncture as a treatment of cocaine, heroin, and alcohol addiction: A pilot study. Addict Disord Their Treat. 2002;1(1):11–6. doi: 10.1097/00132576-200205000-00003. Excluded: Wrong study design for key question
Vigna-Taglianti F, Vadrucci S, Faggiano F, . Is universal prevention against youths’ substance misuse really universal? Gender-specific effects in the EU-Dap school-based prevention trial. J Epidemiol Community Health. 2009;63(9):722–8. doi: 10.1136/jech.2008.081513. PMID: 19395396. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)19395396
Vocci FJ. Cognitive remediation in the treatment of stimulant abuse disorders: a research agenda. Exp Clin Psychopharmacol. 2008;16(6):484–97. doi: 10.1037/a0014101. PMID: 19086769. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.19086769
Vorma H, Naukkarinen H, Sarna S, . Treatment of out-patients with complicated benzodiazepine dependence: comparison of two approaches. Addiction. 2002;97(7):851–9. PMID: 12133124. Excluded: Other wrong population (e.g., schizophrenia focus)12133124
Vorma H, Naukkarinen H, Sarna S, . Long-term outcome after benzodiazepine withdrawal treatment in subjects with complicated dependence. Drug Alcohol Depend. 2003;70(3):309–14. PMID: 12757968. Excluded: Other wrong population (e.g., schizophrenia focus)12757968
Wagoner JL, Piazza NJ. Group therapy for adult substance abusers on probation. J Offender Rehabil. 1993;19(3-4):41–56. doi: 10.1300/J076v19n03_02. Excluded: Wrong comparator
Wain R, Wilbourne PL, Harris KW, . Motivational interview improves treatment entry in homeless veterans. Drug Alcohol Depend. 2011;115(1-2):113–9. doi: 10.1016/j.drugalcdep.2010.11.006. Excluded: Wrong outcome21145181
Waldron HB, Kaminer Y. On the learning curve: the emerging evidence supporting cognitive-behavioral therapies for adolescent substance abuse. Addiction. 2004;99: Suppl 2:93–105. PMID: 15488108. Excluded: Not a peer-reviewed study, wrong publication type, nonsystematic review, etc.15488108
Waldron HB, Slesnick N, Brody JL, . Treatment outcomes for adolescent substance abuse at 4- and 7-month assessments. J Consult Clin Psychol. 2001;69(5):802–13. PMID: 11680557. Excluded: Wrong comparator11680557
Waldron HB, Turner CW. Evidence-based psychosocial treatments for adolescent substance abuse. J Clin Child Adolesc Psychol. 2008;37(1):238–61. doi: 10.1080/15374410701820133. PMID: 18444060. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies18444060
Walker DD, Roffman RA, Stephens RS, . Motivational enhancement therapy for adolescent marijuana users: a preliminary randomized controlled trial. J Consult Clin Psychol. 2006;74(3):628–32. doi: 10.1037/0022-006x.74.3.628. PMID: 16822119. Excluded: School setting16822119
Walker DD, Stephens R, Roffman R, . Randomized controlled trial of motivational enhancement therapy with nontreatment-seeking adolescent cannabis users: a further test of the teen marijuana check-up. Psychol Addict Behav. 2011;25(3):474–84. doi: 10.1037/a0024076. PMID: 21688877. Excluded: School setting21688877
Walter L, Hillhouse M, Saxon A, . The cocaine use reduction with buprenorphine study: Cocaine use findings. Drug Alcohol Depend. 2015;156(13). Excluded: Non-FDA approved pharmacologic intervention
Wang LJ, Lu SF, Chong MY, . A family-oriented therapy program for youths with substance abuse: Long-term outcomes related to relapse and academic or social status. Neuropsychiatr Dis Treat. 2016;12:699–706. doi: 10.2147/NDT.S105199. PMID: 27099500. Excluded: Wrong country27099500
Wang X, Tan L, Li Y, . HCV and HIV infection among heroin addicts in methadone maintenance treatment (MMT) and not in MMT in Changsha and Wuhan, China. PLoS One. 2012;7(9):e45632. doi: 10.1371/journal.pone.0045632. PMID: 23029149. Excluded: Wrong outcome23029149
Warden D, Subramaniam GA, Carmody T, . Predictors of attrition with buprenorphine/naloxone treatment in opioid dependent youth. Addict Behav. 2012;37(9):1046–53. doi: 10.1016/j.addbeh.2012.04.011. PMID: 22626890. Excluded: Wrong comparator22626890
Washburn AM, Fullilove RE, Fullilove MT, . Acupuncture heroin detoxification: a single-blind clinical trial. J Subst Abuse Treat. 1993;10(4):345–51. PMID: 8411294. Excluded: <3 month followup duration8411294
Watson J, Toner P, Day E, . Youth social behaviour and network therapy (Y-SBNT): adaptation of a family and social network intervention for young people who misuse alcohol and drugs - a randomised controlled feasibility trial. Health Technol Assess. 2017;21(15):1–260. doi: 10.3310/hta21150. PMID: 28399988. Excluded: Wrong comparator28399988
Wechsberg WM, Zule WA, Riehman KS, . African-American crack abusers and drug treatment initiation: barriers and effects of a pretreatment intervention. Subst Abuse Treat Prev Policy. 2007;2:10. PMID: 17394653. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)17394653
Weinstock J, Rash CJ, Petry NM. Contingency management for cocaine use in methadone maintenance patients: when does abstinence happen? Psychol Addict Behav. 2010;24(2):282–91. doi: 10.1037/a0017542. PMID: 20565154. Excluded: Wrong comparator20565154
Weiss L, Petry NM. Older methadone patients achieve greater durations of cocaine abstinence with contingency management than younger patients. Am J Addict. 2013;22(2):119–26. doi: 10.1111/j.1521-0391.2013.00306.x. PMID: 23414496. Excluded: Wrong comparator23414496
Weiss R, Potter JS, Griffin ML, . Long-term outcomes from the national drug abuse treatment clinical trials network prescription opioid addiction treatment study. Drug Alcohol Depend. 2015;156(13). Excluded: Results reported elsewhere, duplicate results
Weiss RD, Potter JS, Griffin ML, . Long-term outcomes from the national drug abuse treatment clinical trials network prescription opioid addiction treatment study. Drug Alcohol Depend. 2015;150:112–9. doi: 10.1016/j.drugalcdep.2015.02.030. PMID: 25818060. Excluded: Wrong study design for key question25818060
Weiss RD, Rao V. The prescription opioid addiction treatment study: What have we learned. Drug Alcohol Depend. 2017;173: Suppl 1:S48–S54. doi: 10.1016/j.drugalcdep.2016.12.001. PMID: 28363320. Excluded: Wrong study design for key question28363320
Welle-Strand GK, Skurtveit S, Jones HE, . Neonatal outcomes following in utero exposure to methadone or buprenorphine: A national cohort study of opioid-agonist treatment of pregnant women in Norway from 1996 to 2009. Drug Alcohol Depend. 2013;127(1-3):200–6. doi: 10.1016/j.drugalcdep.2012.07.001. Excluded: Wrong comparator22841456
Wetzel H, Szegedi A, Scheurich A, . Combination treatment with nefazodone and cognitive-behavioral therapy for relapse prevention in alcohol-dependent men: a randomized controlled study. J Clin Psychiatry. 2004;65(10):1406–13. PMID: 15491246. Excluded: Other wrong population (e.g., schizophrenia focus)15491246
White A. Trials of acupuncture for drug dependence: a recommendation for hypotheses based on the literature. Acupunct Med. 2013;31(3):297–304. doi: 10.1136/acupmed-2012-010277. PMID: 23665887. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies23665887
Wikner BN, Ohman I, Selden T, . Opioid-related mortality and filled prescriptions for buprenorphine and methadone. Drug Alcohol Rev. 2014;33(5):491–8. doi: 10.1111/dar.12143. PMID: 24735085. Excluded: Wrong study design for key question24735085
Winhusen T, Kropp F, Babcock D, . Motivational enhancement therapy to improve treatment utilization and outcome in pregnant substance users. J Subst Abuse Treat. 2008;35(2):161–73. PMID: 18083322. Excluded: Wrong comparator18083322
Winklbaur-Hausknost B, Jagsch R, Graf-Rohrmeister K, . Lessons learned from a comparison of evidence-based research in pregnant opioid-dependent women. Hum Psychopharmacol. 2013;28(1):15–24. doi: 10.1002/hup.2275. PMID: 23161599. Excluded: Wrong comparator23161599
Winters KC, Fahnhorst T, Botzet A, . Brief intervention for drug-abusing adolescents in a school setting: outcomes and mediating factors. J Subst Abuse Treat. 2012;42(3):279–88. doi: 10.1016/j.jsat.2011.08.005. PMID: 22000326. Excluded: School setting22000326
Winters KC, Leitten W. Brief intervention for drug-abusing adolescents in a school setting. Psychol Addict Behav. 2007;21(2):249–54. Excluded: School setting17563146
Winters KC, Stinchfield R, Latimer WW, . Long-term outcome of substance-dependent youth following 12-step treatment. J Subst Abuse Treat. 2007;33(1):61–9. PMID: 17588490. Excluded: Inpatient population17588490
Winters KC, Stinchfield RD, Opland E, . The effectiveness of the Minnesota model approach in the treatment of adolescent drug abusers. Addiction. 2000;95(4):601–12. PMID: 10829335. Excluded: Inpatient population10829335
Witkiewitz K, Bowen S. Depression, craving, and substance use following a randomized trial of mindfulness-based relapse prevention. J Consult Clin Psychol. 2010;78(3):362–74. doi: 10.1037/a0019172. PMID: 20515211. Excluded: <70% drug misuse or likely majority alcohol20515211
Witkiewitz K, Bowen S, Douglas H, . Mindfulness-based relapse prevention for substance craving. Addict Behav. 2013;38(2):1563–71. doi: 10.1016/j.addbeh.2012.04.001. PMID: 22534451. Excluded: Wrong outcome22534451
Witkiewitz K, Greenfield BL, Bowen S. Mindfulness-based relapse prevention with racial and ethnic minority women. Addict Behav. 2013;38(12):2821–4. doi: 10.1016/j.addbeh.2013.08.018. PMID: 24018224. Excluded: Wrong comparator24018224
Wood SK, Eckley L, Hughes K, . Computer-based programmes for the prevention and management of illicit recreational drug use: a systematic review. Addict Behav. 2014;39(1):30–8. doi: 10.1016/j.addbeh.2013.09.010. PMID: 24144590. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24144590
Woodruff SI, Clapp JD, Eisenberg K, . Randomized clinical trial of the effects of screening and brief intervention for illicit drug use: the life shift/shift gears study. Addict Sci Clin Pract. 2014;9:8. doi: 10.1186/1940-0640-9-8. PMID: 24886786. Excluded: Poor quality24886786
Woody GE, McLellan AT, Luborsky L, . Twelve-month follow-up of psychotherapy for opiate dependence. Am J Psychiatry. 1987;144(5):590–6. PMID: 3578568. Excluded: Wrong comparator3578568
Woody GE, Poole SA, Subramaniam G, . Extended vs short-term buprenorphine-naloxone for treatment of opioid-addicted youth: a randomized trial. JAMA. 2008;300(17):2003–11. doi: 10.1001/jama.2008.574. PMID: 18984887. Excluded: Wrong comparator18984887
Yancovitz SR, Des Jarlais DC, Peyser NP, . A randomized trial of an interim methadone maintenance clinic. Am J Public Health. 1991;81(9):1185–91. PMID: 1659236. Excluded: Wrong comparator1659236
Yazdanbakhsh K, Dehghan F, Mirzaei S, . The effectiveness of levinson-based cognitive-behavioral therapy on psychological well-being of methamphetamine-dependent patients. Acta medica Mediterranea. 2016;32(Specialue5):2001–4. Excluded: <3 month followup duration
Yen CF, Wu HY, Yen JY, . Effects of brief cognitive-behavioral interventions on confidence to resist the urges to use heroin and methamphetamine in relapse-related situations. J Nerv Ment Dis. 2004;192(11):788–91. PMID: 15505525. Excluded: Wrong outcome15505525
Yonkers KA, Howell HB, Allen AE, . A treatment for substance abusing pregnant women. Arch Women Ment Health. 2009;12(4):221–7. doi: 10.1007/s00737-009-0069-2. PMID: 19350369. Excluded: Wrong study design for key question19350369
Young MM, Stevens A, Galipeau J, . Effectiveness of brief interventions as part of the screening, brief intervention and referral to treatment (SBIRT) model for reducing the nonmedical use of psychoactive substances: a systematic review. Syst Rev. 2014;3:50. doi: 10.1186/2046-4053-3-50. PMID: 24887418. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies24887418
Zanis DA, Coviello D, Alterman AI, . A community-based trial of vocational problem-solving to increase employment among methadone patients. J Subst Abuse Treat. 2001;21(1):19–26. PMID: 11516923. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)11516923
Zgierska A, Rabago D, Chawla N, . Mindfulness meditation for substance use disorders: a systematic review. Substance Abuse. 2009;30(4):266–94. doi: 10.1080/08897070903250019. PMID: 19904664. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies19904664
Zhang SX. An evaluation of the Los Angeles County juvenile drug treatment boot camp: Final report. San Marcos, CA: California State University. 2000. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)
Ziaee SS, Fadardi JS, Cox WM, . Effects of attention control training on drug abusers’ attentional bias and treatment outcome. J Consult Clin Psychol. 2016;84(10):861–73. doi: 10.1037/a0040290. PMID: 27281374. Excluded: Wrong psychosocial intervention (e.g. prevention, housing, etc.)27281374
Zuroff DC, Schwarz JC. Effects of transcendental meditation and muscle relaxation on trait anxiety, maladjustment, locus of control, and drug use. J Consult Clin Psychol. 1978;46(2):264–71. PMID: 348732. Excluded: Other wrong population (e.g., schizophrenia focus)348732

## Appendix A6 U.S. Preventive Services Task Force Quality Rating Criteria

### Criteria for Assessing Internal Validity of Individual Studies

#### RCTs and Cohort Studies

Criteria:

Initial assembly of comparable groups:

For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups

For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts

Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)

Important differential loss to followup or overall high loss to followup

Measurements: equal, reliable, and valid (includes masking of outcome assessment)

Clear definition of interventions

All important outcomes considered

Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

#### Systematic Reviews

Criteria:

Comprehensiveness of sources considered/search strategy used

Standard appraisal of included studies

Validity of conclusions

Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

Source: U.S. Preventive Services Task Force Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

## Appendix A7 Reviewers of the Draft Report

- Will M Aklin, PhD, National Institute on Drug Abuse
- Rebecca DelCarmen Wiggins, PhD, NIH, Office of Research on Women’s Health
- Joan Fleishman, PsyD, Behavioral Health Clinical and Research Director, Family Medicine, Oregon Health and Science University
- Jean Ko, PhD, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion
- Sharon Levy, MD, MPH, Director, Adolescent Substance Use and Addiction Program; Assistant Professor in Pediatrics, Harvard Medical School; American Academy of Pediatrics Committee on Substance Abuse
- Christina Mikosz, MD, Centers for Disease Control and Prevention, National Center for Injury Prevention and Control
- Yngvild Olsen, MD, MPH, DFASAM, Medical Director, Institutes for Behavior Resources Inc./REACH Health Services in Baltimore City; Board of Directors, American Society of Addiction Medicine
- Kevin A. Sevarino, MD, PhD, Assistant Clinical Professor of Psychiatry, Yale University and the University of Connecticut Schools of Medicine; Medical Director, U.S. Department of Veteran’s Affairs, Connecticut Healthcare System Newington Mental Health Firm; Board of Directors, American Academy of Addiction Psychiatry

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.