# References

1 U.S. Preventive Services Task Force. Final Recommendation Statement: Drug Use, Illicit: Screening. http://www.uspreventiveservicestaskforce.org/Page/Document/RecommendationStatementFinal/drug-use-illicit-screening. Accessed September 19, 2016.
2 Polen MR, Whitlock EP, Wisdom JP, . Screening in Primary Care Settings for Illicit Drug Use: Staged Systematic Review for the United States Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality 2008. PMID: 2072215320722153
3 Lanier D, Ko S. Screening in Primary Care Settings for Illicit Drug Use: Assessment of Screening Instruments: A Supplemental Evidence Update for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality 2008. PMID: 2072215420722154.
4 Moyer VA. Primary care behavioral interventions to reduce illicit drug and nonmedical pharmaceutical use in children and adolescents: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;160(9):634–9. PMID: 24615535. 10.7326/M14-0334 24615535
5 Patnode CD, O’Connor E, Rowland M, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. In: Primary Care Behavioral Interventions to Prevent or Reduce Illicit Drug and Nonmedical Pharmaceutical Use in Children and Adolescents: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2014. PMID: 2471625024716250.
6 National Academies of Sciences, Engineering, and Medicine. The health effects of cannabis and cannabinoids: The current state of evidence and recommendations for research. Washington, DC: The National Academies Press: 2017. PMID: None. 10.17226/24625
7 Mokdad AH, Marks JS, Stroup DF, . Actual causes of death in the United States, 2000. JAMA. 2004;291(10):1238–45. PMID: 15010446. 10.1001/jama.291.10.1238 15010446
8 Murray CJ, Lopez AD. Measuring the global burden of disease. N Engl J Med. 2013;369(5):448–57. PMID: 23902484. 10.1056/NEJMra1201534 23902484
9 Johnson NB, Hayes LD, Brown K, . CDC National Health Report: leading causes of morbidity and mortality and associated behavioral risk and protective factors-United States, 2005–2013. MMWR supplements. 2014;63(4):3–27. PMID: 25356673.25356673
10 Centers for Disease Control and Prevention. Drug Overdose Deaths. https://www.cdc.gov/drugoverdose/data/statedeaths.html. Accessed May 2, 2019.
11 National Drug Intelligence Center. The Economic Impact of Illicit Drug Use on American Society. Washington D.C.: United States Department of Justice; 2011.
12 Center for Behavioral Health Statistics and Quality. Results from the 2017 National Survey on Drug Use and Health: Detailed Tables. https://www.samhsa.gov/data/sites/default/files/cbhsq-reports/NSDUHDetailedTabs2017/NSDUHDetailedTabs2017.pdf. Accessed October 2, 2018.
13 Muhuri P, Gfroerer J. Substance use among women: associations with pregnancy, parenting, and race/ethnicity. Matern Child Health J. 2009;13(3):376–85. PMID: 1856687818566878
14 Garg M, Garrison L, Leeman L, . Validity of Self-Reported Drug Use Information Among Pregnant Women. Matern Child Health J. 2016;20(1):41–7. PMID: 26175273. 10.1007/s10995-015-1799-6 26175273
15 Grekin ER, Svikis DS, Lam P, . Drug use during pregnancy: validating the Drug Abuse Screening Test against physiological measures. Psychol Addict Behav. 2010;24(4):719–23. PMID: 21198230. 10.1037/a0021741 21198230
16 Beatty JR, Chase SK, Ondersma SJ. A randomized study of the effect of anonymity, quasi-anonymity, and Certificates of Confidentiality on postpartum women’s disclosure of sensitive information. Drug Alcohol Depend. 2014;134:280–4. 10.1016/j.drugalcdep.2013.10.016 24246900
17 Bessa MA, Mitsuhiro SS, Chalem E, . Underreporting of use of cocaine and marijuana during the third trimester of gestation among pregnant adolescents. Addict Behav. 2010;35(3):266–9. 10.1016/j.addbeh.2009.10.007 19896774
18 Harrington M, Robinson J, Bolton S, . A longitudinal study of risk factors for incident drug use in adults: findings from a representative sample of the US population. Can J Psychiatry. 2011;56(11):686–95. PMID: 22114923. 10.1177/070674371105601107 22114923
19 Kuczkowski KM. The effects of drug abuse on pregnancy. Current opinion in obstetrics & gynecology. 2007;19(6):578–85. 10.1097/GCO.0b013e3282f1bf17 18007137
20 McCalla S, Minkoff HL, Feldman J, . Predictors of cocaine use in pregnancy. Obstet Gynecol. 1992;79(5 (Pt 1)):641–4.1565342
21 National Institute on Drug Abuse. Drugs, Brains, and Behavior: The Science of Addiction. Bethesda, MD: National Institute on Drug Abuse (NIDA); 2014.
22 Substance Abuse and Mental Health Services Administration. PREVENTING PRESCRIPTION DRUG MISUSE: Understanding Who Is at Risk. CAPT Decision-Support Tools. https://www.samhsa.gov/capt/sites/default/files/resources/preventing-prescription-drug-misuse-understanding.pdf. Accessed March 12, 2019.
23 Center for Substance Abuse Treatment. Substance Abuse Treatment: Addressing the Specific Needs of Women. Rockville, MD: Substance Abuse and Mental Health Services Administration; 2009. PMID: 2251485922514859.
24 Saitz R. Screening for unhealthy use of alcohol and other drugs in primary care. UpToDate. 2015.
25 The American College of Obstetricians and Gynecologists. Committee opinion no. 633: Alcohol abuse and other substance use disorders: ethical issues in obstetric and gynecologic practice. Obstet Gynecol. 2015;125(6):1529–37. PMID: 26000541. 10.1097/01.AOG.0000466371.86393.9b 26000541
26 Substance Abuse and Mental Health Services Administration. Screening, Brief Intervention, and Referral to Treatment (SBIRT). Accessed July 13, 2016.
27 Pilowsky D, Wu L. Screening for alcohol and drug use disorders among adults in primary care: A review. Subst Abuse Rehabil. 2012;3(1):25–34. PMID: 22553426. 10.2147/SAR.S30057 22553426
28 National Institute on Drug Abuse. Brief Intervention Helps Adolescents Curb Substance Use https://www.drugabuse.gov/news-events/nida-notes/2012/12/brief-intervention-helps-adolescents-curb-substance-use. Accessed May 12, 2016.
29 Smedslund G, Berg R, Hammerstrom K, . Motivational interviewing for substance abuse. Cochrane Database Syst Rev. 2011(5):CD008063. PMID: 21563163. 10.1002/14651858.CD008063.pub2 21563163
30 National Institute on Drug Abuse. Principles of Drug Addiction Treatment: A Research-Based Guide (Third Edition): Cognitive-Behavioral Therapy (Alcohol, Marijuana, Cocaine, Methamphetamine, Nicotine). https://www.drugabuse.gov/publications/principles-drug-addiction-treatment-research-based-guide-third-edition/evidence-based-approaches-to-drug-addiction-treatment/behavioral. Accessed May 12, 2016.
31 Sevarino K. Medically supervised opioid withdrawal during treatment for addiction. http://www.uptodate.com/contents/medically-supervised-opioid-withdrawal-during-treatment-for-addiction. Accessed February 17, 2016.
32 Strain E. Pharmacotherapy for opioid use disorder. http://www.uptodate.com/contents/medically-supervised-opioid-withdrawal-during-treatment-for-addiction. Accessed April 5, 2016.
33 The National Center on Addiction and Substance Abuse. Missed Opportunity: National Survey of Primary Care Physicians and Patients on Substance Abuse. http://www.centeronaddiction.org/addiction-research/reports/national-survey-primary-care-physicians-patients-substance-abuse. Accessed May 17, 2016.
34 Floyd R, Belodoff B, Sidhu J, . A survey of obstetrician-gynecologists on their patients’ use of tobacco and other drugs during pregnancy. Prenatal and Neonatal Medicine. 2001;6(4):201–7.
35 Chou R, Dana T, Blazina I, . Interventions for Drug Use – Supplemental Report: A Systematic Review for the U.S. Preventive Services Task Force. Contract No. HHSA290201500007i, Task Order No. HHSA29032004T. Pacific Northwest Evidence-Based Practice Center. Oregon Health & Science University. Rockville, MD: Agency for Healthcare Research and Quality; 2019.
36 United Nations Development Programme. Human Development Report 2014. Sustaining Human Progress: Reducing Vulnerabilities and Building Resilience. http://hdr.undp.org/sites/default/files/hdr14-report-en-1.pdf. Accessed January, 2016.
37 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
38 Newcombe RG. Two-sided confidence intervals for the single proportion: comparison of seven methods. Stat Med. 1998;17(8):857–72. PMID: 9595616.9595616
39 Wilson EB. Probable inference, the law of succession, and statistical inference. Journal of the American Statistical Association. 1927;22(158):209–12. PMID: None.
40 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
41 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
42 Kelly SM, Gryczynski J, Mitchell SG, . Validity of brief screening instrument for adolescent tobacco, alcohol, and drug use. Pediatrics. 2014;133(5):819–26. PMID: 24753528. 10.1542/peds.2013-2346 24753528
43 McNeely J, Strauss SM, Saitz R, . A Brief Patient Self-administered Substance Use Screening Tool for Primary Care: Two-site Validation Study of the Substance Use Brief Screen (SUBS). Am J Med. 2015;128(7):784.e9–19. PMID: 25770031. 10.1016/j.amjmed.2015.02.007 25770031
44 Tiet Q, Leyva Y, Moos R, . Screen of Drug Use: Diagnostic Accuracy of a New Brief Tool for Primary Care. JAMA Intern Med. 2015;175(8):1371–7. PMID: 26075352. 10.1001/jamainternmed.2015.2438 26075352
45 Smith P, Schmidt S, Allensworth-Davies D, . A single-question screening test for drug use in primary care. Arch Intern Med. 2010;170(13):1155–60. PMID: 20625025. 10.1001/archinternmed.2010.140 20625025
46 Knight J, Sherritt L, Shirier L, . Validity of the CRAFFT substance abuse screening test among adolescent clinic patients. Arch Pediatr Adolesc Med. 2002;156(6):607–14. PMID: 12038895. 10.1001/archpedi.156.6.607 12038895
47 Chasnoff I, Wells A, McGourty R, . Validation of the 4P’s Plus screen for substance use in pregnancy validation of the 4P’s Plus. J Perinatol. 2007;27(12):744–8. PMID: 17805340. 10.1038/sj.jp.7211823 17805340
48 Brown RL, Leonard T, Saunders LA, . A two-item conjoint screen for alcohol and other drug problems. J Am Board Fam Pract. 2001;14(2):95–106. PMID: 11314930.11314930
49 McCann BS, Simpson TL, Ries R, . Reliability and validity of screening instruments for drug and alcohol abuse in adults seeking evaluation for attention-deficit/hyperactivity disorder. Am J Addict. 2000;9(1):1–9. PMID: 10914288. 10.1080/10550490050172173 10914288
50 McNeely J, Wu LT, Subramaniam G, . Performance of the Tobacco, Alcohol, Prescription Medication, and Other Substance Use (TAPS) Tool for Substance Use Screening in Primary Care Patients. Ann Intern Med. 2016. PMID: 27595276. 10.7326/m16-0317 27595276
51 Kumar PC, Cleland CM, Gourevitch MN, . Accuracy of the Audio Computer Assisted Self Interview version of the Alcohol, Smoking and Substance Involvement Screening Test (ACASI ASSIST) for identifying unhealthy substance use and substance use disorders in primary care patients. Drug Alcohol Depend. 2016;165:38–44. PMID: 27344194. 10.1016/j.drugalcdep.2016.05.030 27344194
52 Harris SK, Knight JR, Jr., Van Hook S, . Adolescent substance use screening in primary care: Validity of computer self-administered versus clinician-administered screening. Subst Abus. 2016;37(1):197–203. PMID: 25774878. 10.1080/08897077.2015.1014615 25774878
53 Lam LP, Leung WC, Ip P, . Validation of the Drug Abuse Screening Test (DAST-10): A study on illicit drug use among Chinese pregnant women. Sci. 2015;5:11420. PMID: 26091290. 10.1038/srep11420 26091290
54 Gryczynski J, Kelly SM, Mitchell SG, . Validation and performance of the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) among adolescent primary care patients. Addiction. 2015;110(2):240–7. PMID: 25311148. 10.1111/add.12767 25311148
55 Legleye S, Guignard R, Richard JB, . Properties of the Cannabis Abuse Screening Test (CAST) in the general population. Int J Methods Psychiatr Res. 2015;24(2):170–83. PMID: 26077195. 10.1002/mpr.1465 26077195
56 Mitchell SG, Kelly SM, Gryczynski J, . The CRAFFT cut-points and DSM-5 criteria for alcohol and other drugs: a reevaluation and reexamination. Subst Abus. 2014;35(4):376–80. PMID: 25036144. 10.1080/08897077.2014.936992 25036144
57 Bastiani L, Siciliano V, Curzio O, . Optimal scaling of the CAST and of SDS Scale in a national sample of adolescents. Addict Behav. 2013;38(4):2060–7. PMID: 23396173. 10.1016/j.addbeh.2012.12.016 23396173
58 Ondersma SJ, Svikis DS, LeBreton JM, . Development and preliminary validation of an indirect screener for drug use in the perinatal period. Addiction. 2012;107(12):2099–106. PMID: 22882721. 10.1111/j.1360-0443.2012.03982.x 22882721
59 Fernandez-Artamendi S, Fernandez-Hermida JR, Muniz-Fernandez J, . Screening of cannabis-related problems among youth: the CPQ-A-S and CAST questionnaires. Subst Abuse Treat Prev Policy. 2012;7:13. PMID: 22471908. 10.1186/1747-597X-7-13 22471908
60 Legleye S, Piontek D, Kraus L. Psychometric properties of the Cannabis Abuse Screening Test (CAST) in a French sample of adolescents. Drug Alcohol Depend. 2011;113(2–3):229–35. PMID: 20869178. 10.1016/j.drugalcdep.2010.08.011 20869178
61 Dawson DA, Compton WM, Grant BF. Frequency of 5+/4+ drinks as a screener for drug use and drug-use disorders. J Stud Alcohol Drugs. 2010;71(5):751–60. PMID: 20731982. 10.15288/jsad.2010.71.751 20731982
62 Lane WG, Dubowitz H, Feigelman S, . Screening for parental substance abuse in pediatric primary care. Ambul Pediatr. 2007;7(6):458–62. PMID: 17996841. 10.1016/j.ambp.2007.07.007 17996841
63 Harrison PA, Godecker A, Sidebottom A. Validity of the Prenatal Risk Overview for detecting drug use disorders in pregnancy. Public Health Nurs. 2012;29(6):563–73. PMID: 23078427. 10.1111/j.1525-1446.2012.01030.x 23078427
64 D’Amico EJ, Parast L, Meredith LS, . Screening in Primary Care: What Is the Best Way to Identify At-Risk Youth for Substance Use? Pediatrics. 2016;138(6). PMID: 27940696. 10.1542/peds.2016-1717 27940696
65 Beaudoin FL, Merchant RC, Clark MA. Prevalence and Detection of Prescription Opioid Misuse and Prescription Opioid Use Disorder Among Emergency Department Patients 50 Years of Age and Older: Performance of the Prescription Drug Use Questionnaire, Patient Version. Am J Geriatr Psychiatry. 2016;24(8):627–36. PMID: 27426210. 10.1016/j.jagp.2016.03.010 27426210
66 Chung T, Colby SM, O’Leary TA, . Screening for cannabis use disorders in an adolescent emergency department sample. Drug Alcohol Depend. 2003;70(2):177–86. 10.1016/S0376-8716(02)00346-0 12732411
67 Rial A, Kim-Harris S, Knight JR, . Empirical validation of the CRAFFT Abuse Screening Test in a Spanish sample. Adicciones. 2018;0(0):1105. PMID: 29353300. 10.20882/adicciones.1105 29353300
68 Legleye S. The Cannabis Abuse Screening Test and the DSM-5 in the general population: Optimal thresholds and underlying common structure using multiple factor analysis. Int J Methods Psychiatr Res. 2018;27(2):e1597. PMID: 29124816. 10.1002/mpr.1597 29124816
69 Saitz R, Cheng DM, Allensworth-Davies D, . The ability of single screening questions for unhealthy alcohol and other drug use to identify substance dependence in primary care. J Stud Alcohol Drugs. 2014;75(1):153–7. PMID: 24411807. 10.15288/jsad.2014.75.153 24411807
70 McNeely J, Cleland CM, Strauss SM, . Validation of Self-Administered Single-Item Screening Questions (SISQs) for Unhealthy Alcohol and Drug Use in Primary Care Patients. J Gen Intern Med. 2015;30(12):1757–64. PMID: 25986138 10.1007/s11606-015-3391-6 25986138
71 Wu LT, McNeely J, Subramaniam GA, . Design of the NIDA clinical trials network validation study of tobacco, alcohol, prescription medications, and substance use/misuse (TAPS) tool. Contemp Clin Trials. 2016;50:90–7. PMID: 27444426. 10.1016/j.cct.2016.07.013 27444426
72 Tiet QQ, Leyva Y, Moos RH, . Diagnostic accuracy of a two-item screen for drug use developed from the alcohol, smoking and substance involvement screening test (ASSIST). Drug Alcohol Depend. 2016;164:22–7. PMID: 27234660. 10.1016/j.drugalcdep.2016.03.029 27234660
73 Smith PC, Cheng DM, Allensworth-Davies D, . Use of a single alcohol screening question to identify other drug use. Drug Alcohol Depend. 2014;139:178–80. PMID: 24768061. 10.1016/j.drugalcdep.2014.03.027 24768061
74 Gryczynski J, McNeely J, Wu LT, . Validation of the TAPS-1: A Four-Item Screening Tool to Identify Unhealthy Substance Use in Primary Care. J Gen Intern Med. 2017. PMID: 28550609. 10.1007/s11606-017-4079-x 28550609
75 Tiet QQ, Leyva YE, Moos RH, . Diagnostic accuracy of a two-item Drug Abuse Screening Test (DAST-2). Addict Behav. 2017;74:112–7. PMID: 28609724. 10.1016/j.addbeh.2017.06.008 28609724
76 Kelly SM, O’Grady KE, Gryczynski J, . The concurrent validity of the Problem Oriented Screening Instrument for Teenagers (POSIT) substance use/abuse subscale in adolescent patients in an urban federally qualified health center. Subst Abus. 2017:1–7. PMID: 28686545. 10.1080/08897077.2017.1351413 28080324
77 Araujo M, Golpe S, Brana T, . Psychometric validation of the POSIT for screening alcohol and other drugs risk consumption among adolescents. Adicciones. 2018;30(2):130–9. PMID: 28492958. 10.20882/adicciones.958 28492958
78 D’Amico EJ, Parast L, Shadel WG, . Brief motivational interviewing intervention to reduce alcohol and marijuana use for at-risk adolescents in primary care. J Consult Clin Psychol. 2018;86(9):775–86. PMID: 30138016. 10.1037/ccp0000332 30138016
79 Baumeister SE, Gelberg L, Leake BD, . Effect of a primary care based brief intervention trial among risky drug users on health-related quality of life. Drug Alcohol Depend. 2014;142:254–61. PMID: 25042213. 10.1016/j.drugalcdep.2014.06.034 25042213
80 Bernstein E, Edwards E, Dorfman D, . Screening and brief intervention to reduce marijuana use among youth and young adults in a pediatric emergency department. Acad Emerg Med. 2009;16(11):1174–85. PMID: 20053238. 10.1111/j.1553-2712.2009.00490.x 20053238
81 Bernstein J, Bernstein E, Tassiopoulos K, . Brief motivational intervention at a clinic visit reduces cocaine and heroin use. Drug Alcohol Depend. 2005;77(1):49–59. PMID: 15607841. 10.1016/j.drugalcdep.2004.07.006 15607841
82 Blow FC, Walton MA, Bohnert ASB, . A randomized controlled trial of brief interventions to reduce drug use among adults in a low-income urban emergency department: the HealthiER You study. Addiction. 2017;112(8):1395–405. PMID: 28127808. 10.1111/add.13773 28127808
83 Bogenschutz M, Donovan D, Mandler R, . Brief intervention for patients with problematic drug use presenting in emergency departments: a randomized clinical trial. JAMA Intern Med. 2014;174(11):1736–45. PMID: 25179753. 10.1001/jamainternmed.2014.4052 25179753
84 Bogenschutz MP, Donovan DM, Adinoff B, . Design of NIDA CTN Protocol 0047: screening, motivational assessment, referral, and treatment in emergency departments (SMART-ED). American Journal of Drug & Alcohol Abuse. 2011;37(5):417–25. PMID: 21854285. 10.3109/00952990.2011.596971 21854285
85 Bonar EE, Walton MA, Cunningham RM, . Computer-enhanced interventions for drug use and HIV risk in the emergency room: preliminary results on psychological precursors of behavior change. J Subst Abuse Treat. 2014;46(1):5–14. PMID: 24035142. 10.1016/j.jsat.2013.08.005 24035142
86 Fuster D, Cheng DM, Wang N, . Brief intervention for daily marijuana users identified by screening in primary care: A subgroup analysis of the ASPIRE randomized clinical trial. Subst Abus. 2016;37(2):336–42. PMID: 26453188. 10.1080/08897077.2015.1075932 26453188
87 Gelberg L, Andersen RM, Afifi AA, . Project QUIT (Quit Using Drugs Intervention Trial): a randomized controlled trial of a primary care-based multi-component brief intervention to reduce risky drug use. Addiction. 2015;110(11):1777–90. PMID: 26471159. 10.1111/add.12993 26471159
88 Gelberg L, Andersen RM, Rico MW, . A pilot replication of QUIT, a randomized controlled trial of a brief intervention for reducing risky drug use, among Latino primary care patients. Drug Alcohol Depend. 2017;179:433–40. PMID: 28844733. 10.1016/j.drugalcdep.2017.04.022 28844733
89 Humeniuk R, Ali R, Babor T, . A randomized controlled trial of a brief intervention for illicit drugs linked to the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) in clients recruited from primary health-care settings in four countries. Addiction. 2012;107(5):957–66. PMID: 22126102. 10.1111/j.1360-0443.2011.03740.x 22126102
90 Humeniuk R, Newcombe DAL, Dennington V, . A randomised controlled trial of a brief intervention for illicit drug use linked to ASSIST screening in a primary healthcare setting: results from the Australian component of the World Health Organization Phase III ASSIST studies. Aust J Prim Health. 2018. PMID: 29481765. 10.1071/py17056 29481765
91 Kim TW, Bernstein J, Cheng DM, . Receipt of addiction treatment as a consequence of a brief intervention for drug use in primary care: a randomized trial. Addiction. 2017;112(5):818–27. PMID: 27886657. 10.1111/add.13701 27886657
92 Krupski A, Joesch J, Dunn C, . Testing the effects of brief intervention in primary care for problem drug use in a randomized controlled trial: rationale, design, and methods. Addict Sci Clin Pract. 2012(7):27. PMID: 23237456. 10.1186/1940-0640-7-27 23237456
93 Lee C, Neighbors C, Kilmer J, . A brief, web-based personalized feedback selective intervention for college student marijuana use: a randomized clinical trial. Psychol Addict Behav. 2010;24(2):265–73. PMID: 20565152. 10.1037/a0018859 20565152
94 Lee CM, Kilmer JR, Neighbors C, . Indicated prevention for college student marijuana use: a randomized controlled trial. J Consult Clin Psychol. 2013;81(4):702–9. PMID: 23750464. 10.1037/a0033285 23750464
95 Martino S, Ondersma SJ, Forray A, . A randomized controlled trial of screening and brief interventions for substance misuse in reproductive health. Am J Obstet Gynecol. 2018;218(3):322.e1–.e12. PMID: 29247636. 10.1016/j.ajog.2017.12.005 29247636
96 Mason M, Light J, Campbell L, . Peer Network Counseling with Urban Adolescents: A Randomized Controlled Trial with Moderate Substance Users. J Subst Abuse Treat. 2015;58:16–24. PMID: 26234955. 10.1016/j.jsat.2015.06.013 26234955
97 Mason MJ, Sabo R, Zaharakis NM. Peer Network Counseling as Brief Treatment for Urban Adolescent Heavy Cannabis Users. Journal of Studies on Alcohol & Drugs. 2017;78(1):152–7. PMID: 27936376.27936376
98 Ondersma S, Svikis D, Thacker L, . Computer-delivered screening and brief intervention (e-SBI) for postpartum drug use: a randomized trial. J Subst Abuse Treat. 2014;46(1):52–9. PMID: 24051077. 10.1016/j.jsat.2013.07.013 24051077
99 Ondersma SJ, Svikis DS, Schuster CR. Computer-based brief intervention a randomized trial with postpartum women.[Erratum appears in Am J Prev Med. 2007 Jun;32(6):549]. Am J Prev Med. 2007;32(3):231–8. PMID: 17236741.17236741
100 Ondersma SJ, Svikis DS, Thacker C, . Computer-delivered indirect screening and brief intervention for drug use in the perinatal period: A randomized trial. Drug Alcohol Depend. 2018;185:271–7. PMID: 29482051. 10.1016/j.drugalcdep.2017.12.022 29482051
101 Palfai T, Saitz R, Winter M, . Web-based screening and brief intervention for student marijuana use in a university health center: pilot study to examine the implementation of eCHECKUP TO GO in different contexts. Addict Behav. 2014;39(9):1346–52. PMID: 24845164. 10.1016/j.addbeh.2014.04.025 24845164
102 Poblete F, Barticevic NA, Zuzulich MS, . A randomized controlled trial of a brief intervention for alcohol and drugs linked to the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) in primary health care in Chile. Addiction. 2017;112(8):1462–9. PMID: 28239995. 10.1111/add.13808 28239995
103 Roy-Byrne P, Bumgardner K, Krupski A, . Brief intervention for problem drug use in safety-net primary care settings: a randomized clinical trial. JAMA. 2014;312(5):492–501. PMID: 25096689. 10.1001/jama.2014.7860 25096689
104 Saitz R, Palfai T, Cheng D, . Screening and brief intervention for drug use in primary care: the ASPIRE randomized clinical trial. JAMA. 2014;312(5):502–13. PMID: 25096690. 10.1001/jama.2014.7862 25096690
105 Stein M, Hagerty C, Herman D, . A brief marijuana intervention for non-treatment-seeking young adult women. J Subst Abuse Treat. 2011;40(2):189–98. PMID: 21185685. 10.1016/j.jsat.2010.11.001 21185685
106 Tzilos Wernette G, Plegue M, Kahler CW, . A Pilot Randomized Controlled Trial of a Computer-Delivered Brief Intervention for Substance Use and Risky Sex During Pregnancy. J Womens Health (Larchmt). 2017. PMID: 28981379. 10.1089/jwh.2017.6408 28981379
107 Walton MA, Bohnert K, Resko S, . Computer and therapist based brief interventions among cannabis-using adolescents presenting to primary care: one year outcomes. Drug Alcohol Depend. 2013;132(3):646–53. PMID: 23711998. 10.1016/j.drugalcdep.2013.04.020 23711998
108 Watkins KE, Ober AJ, Lamp K, . Collaborative Care for Opioid and Alcohol Use Disorders in Primary Care: The SUMMIT Randomized Clinical Trial. JAMA Internal Medicine. 2017;177(10):1480–8. PMID: 28846769. 10.1001/jamainternmed.2017.3947 28846769
109 Woolard R, Baird J, Longabaugh R, . Project reduce: reducing alcohol and marijuana misuse: effects of a brief intervention in the emergency department. Addict Behav. 2013;38(3):1732–9. PMID: 23261491. 10.1016/j.addbeh.2012.09.006 23261491
110 Yonkers K, Forray A, Howell H, . Motivational enhancement therapy coupled with cognitive behavioral therapy versus brief advice: a randomized trial for treatment of hazardous substance use in pregnancy and after delivery. Gen Hosp Psychiatry. 2012;34(5):439–49. PMID: 22795046. 10.1016/j.genhosppsych.2012.06.002 22795046
111 Zahradnik A, Otto C, Crackau B, . Randomized controlled trial of a brief intervention for problematic prescription drug use in non-treatment-seeking patients. Addiction. 2009;401(1):109–17. PMID: 19133895. 10.1111/j.1360-0443.2008.02421.x 19133895
112 Gryczynski J, O’Grady KE, Mitchell SG, . Immediate Versus Delayed Computerized Brief Intervention for Illicit Drug Misuse. J Addict Med. 2016;10(5):344–51. PMID: 27504925. 10.1097/adm.0000000000000248 27504925
113 National Institutes of Health. Screening, Brief Intervention and Referral to Treatment (SBIRT) for Drug Abuse in General Medical Settings (R01). https://grants.nih.gov/grants/guide/rfa-files/RFA-DA-08-021.html. Accessed September 11, 2017.
114 Saitz R, Alford DP, Bernstein J, . Screening and brief intervention for unhealthy drug use in primary care settings: randomized clinical trials are needed. J Addict Med. 2010;4(3):123–30. PMID: 20936079. 10.1097/ADM.0b013e3181db6b67 20936079
115 Rubin R. Medical Marijuana Is Legal in Most States, but Physicians Have Little Evidence to Guide Them. JAMA. 2017(Published online April 05, 2017). PMID: None. 10.1001/jama.2017.0813
116 Pacula RL, Kilmer B, Wagenaar AC, . Developing public health regulations for marijuana: lessons from alcohol and tobacco. Am J Public Health. 2014;104(6):1021–8. PMID: 24825201. 10.2105/AJPH.2013.301766 24825201
117 Ghosh T, Van Dyke M, Maffey A, . The Public Health Framework of Legalized Marijuana in Colorado. Am J Public Health. 2016;106(1):21–7. PMID: 26562117. 10.2105/AJPH.2015.302875 26562117
118 Cochrane Drugs and Alcohol. Our Reviews. http://cda.cochrane.org/our-reviews. Accessed September 11, 2017.
119 Young M, Stevens A, Galipeau J, . Effectiveness of brief interventions as part of the Screening, Brief Intervention and Referral to Treatment (SBIRT) model for reducing the nonmedical use of psychoactive substances: a systematic review. Syst Rev. 2014;3:50. PMID: 24887418. 10.1186/2046-4053-3-50 24887418
120 Farr SL, Hutchings YL, Ondersma SJ, . Brief interventions for illicit drug use among peripartum women. Am J Obstet Gynecol. 2014;211(4):336–43. PMID: 24721261. 10.1016/j.ajog.2014.04.005 24721261
121 National Institute on Drug Abuse, National Institutes of Health, U.S. Department of Health and Human Services. Resource Guide: Screening for Drug Use in General Medical Settings. https://d14rmgtrwzf5a.cloudfront.net/sites/default/files/resource_guide.pdf. Accessed September 11, 2017.
122 Watson JM, Fayter D, Mdege N, . Interventions for alcohol and drug problems in outpatient settings: a systematic review. Drug Alcohol Rev. 2013;32(4):356–67. PMID: 23490212. 10.1111/dar.12037 23490212
123 Chiesa A, Serretti A. Are mindfulness-based interventions effective for substance use disorders? A systematic review of the evidence. Subst Use Misuse. 2014;49(5):492–512. PMID: 23461667. 10.3109/10826084.2013.770027 23461667
124 Moore B, Fazzino T, Garnet B, . Computer-based interventions for drug use disorders: a systematic review. J Subst Abuse Treat. 2011;40(3):215–23. PMID: 2185683.21185683
125 Li L, Zhu S, Tse N, . Effectiveness of motivational interviewing to reduce illicit drug use in adolescents: a systematic review and meta-analysis. Addiction. 2016;111(5):795–805. PMID: 26687544. 10.1111/add.13285 26687544
126 Tait R, Spijkerman R, Riper H. Internet and computer based interventions for cannabis use: a meta-analysis. Drug Alcohol Depend. 2013;133(2):295–304. PMID: 23747236.23747236
127 Hoch E, Preuss UW, Ferri M, . Digital Interventions for Problematic Cannabis Users in Non-Clinical Settings: Findings from a Systematic Review and Meta-Analysis. Eur Addict Res. 2016;22(5):233–42. PMID: 27160333. 10.1159/000445716 27160333
128 Cooper K, Chatters R, Kaltenthaler E, . Psychological and psychosocial interventions for cannabis cessation in adults: a systematic review short report. Health Technol Assess. 2015;19(56):1–130. PMID: 26202542. 10.3310/hta19560 26202542
129 Gulliver A, Farrer L, Chan JK, . Technology-based interventions for tobacco and other drug use in university and college students: a systematic review and meta-analysis. Addict Sci Clin Pract. 2015;10:5. PMID: 25928221. 10.1186/s13722-015-0027-4 25928221
130 Connery HS. Medication-assisted treatment of opioid use disorder: review of the evidence and future directions. Harv Rev Psychiatry. 2015;23(2):63–75. PMID: 25747920. 10.1097/HRP.0000000000000075 25747920
131 Newton AS, Dong K, Mabood N, . Brief emergency department interventions for youth who use alcohol and other drugs: a systematic review. Pediatr Emerg Care. 2013;29(5):673–84. PMID: 23640153. 10.1097/PEC.0b013e31828ed325 23640153
132 D’Amico EJ, Miles JN, Stern SA, . Brief motivational interviewing for teens at risk of substance use consequences: a randomized pilot study in a primary care clinic. J Subst Abuse Treat. 2008;35(1):53–61. PMID: 18037603. 10.1016/j.jsat.2007.08.008 18037603
133 Madras B, Compton W, Avula D, . Screening, brief interventions, referral to treatment (SBIRT) for illicit drug and alcohol use at multiple healthcare sites: comparison at intake and 6 months later. Drug Alcohol Depend. 2009;99(1–3):280–95. PMID: 18929451.18929451
134 Guy GJ, Zhang K, Bohm MK, . Vital Signs: Changes in Opioid Prescribing in the United States, 2006–2015. MMWR Morb Mortal Wkly Rep. 2017;66:697–704. PMID: None. 10.15585/mmwr.mm6626a4 28683056
135 Chou R, Deyo R, Devine B, . The effectiveness and risks of long-term opioid treatment of chronic pain. Evidence Report/Technology Assessment No. 218. AHRQ Publication No. 14-E005-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. http://www.effectivehealthcare.ahrq.gov/ehc/products/557/1971/chronic-pain-opioid-treatment-report-141007.pdf.
136 Hingson R, Compton WM. Screening and brief intervention and referral to treatment for drug use in primary care: Back to the drawing board. JAMA. 2014;312(5):488–9. PMID: 25096687. 10.1001/jama.2014.7863 25096687
137 Saitz R. Commentary on Gelberg et al. 2015: Alcohol and other drug screening and brief intervention-evidence in crisis. Addiction. 2015;110(11):1791–3. PMID: 26471160. 10.1111/add.13054 26471160
138 American Academy of Family Physicians. Illicit Drug Use. http://www.aafp.org/patient-care/clinical-recommendations/all/illicit-drug-use.html. Accessed September 19, 2016.
139 American Academy of Family Physicians. Illicit or Nonmedical Drug Use, in Children and Adolescents. http://www.aafp.org/patient-care/clinical-recommendations/all/illicit-drug-use.html. Accessed September 20, 2016.
140 Department of Veterans Affairs. VA/DoD Clinical Practice Guideline for the Management of Substance Use Disorders. Washington DC: Department of Defense; 2015.
141 Levy SJ, Williams JF, Committee On Substance USE, . Substance Use Screening, Brief Intervention, and Referral to Treatment. Pediatrics. 2016;138(1). 10.1542/peds.2016-1211
142 ACOG Committee on Health Care for Underserved Women, American Society of Addiction Medicine. ACOG Committee Opinion No. 524: Opioid abuse, dependence, and addiction in pregnancy. Obstet Gynecol. 2014;119(5):1070–6. PMID: 22525931.22525931
143 ACOG Committee on Health Care for Underserved Women, American College of Obstetricians and Gynecologists. ACOG Committee Opinion No. 538: Nonmedical use of prescription drugs. Obstet Gynecol. 2014;120(4):977–82. PMID: 22996128.22996128
144 Whiting P, Rutjes AW, Reitsma JB, . The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. PMID: 14606960. 10.1186/1471-2288-3-25 14606960
145 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046