# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Kathleen Irwin, MD, MPH, David Meyers, MD, MPH, Ernest Sullivent, MD, MPH, and Amanda Borsky, DrPH, MPP, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Richard Saitz, MD, MPH, at Boston University Schools of Medicine and Public Health for his content expertise and review of the draft report; Cheryl Arratoon, MSc, Sharon Levy, MD, MPH, Jennifer McNeely, MD, MS, Natalie Mercer, PhD, Steven Ondersma, PhD, MA, Brad Stein, MD, PhD, Adrienne Stevens, PhD, and Matthew Young, PhD, for providing expert review of the draft report; Christina Mikosz, MD, MPH, Jean Ko, PhD, and Rebecca DelCarmen-Wiggins, PhD, for providing federal review of the report; and Smyth Lai, MLS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.