# Chapter 4 Discussion

## Summary of Evidence

A summary of our findings, including our overall assessment of the strength of evidence for each Key Question, is presented in Table 17.

Table 17 Summary of Evidence, by Key Question

Key Question | No. of Studies (k), no. of Observations (n) | Summary of Findings | Consistency/Precision Reporting Bias | Overall Study Quality | Body of Evidence Limitations | EPC Assessment of Overall Strength of Evidence | Applicability
KQ 1. Benefits of screening | k=0 | NA | NA | NA | NA | Insufficient | NA
KQ 2. Screening accuracy | k=28 cross-sectional studies; n=65,720^*^ | Thirty different screening tools were evaluated including brief frequency-based tools, risk assessment tools, and indirect screeners. Among adolescents, sensitivity of frequency-based and risk assessment tools for detecting any cannabis use or unhealthy cannabis use ranged from 0.68 to 0.98 (95% CI range, 0.64 to 0.99) and specificity ranged from 0.82 to 1.00 (95% CI range, 0.80 to 1.00). Among adults, sensitivity of frequency-based and risk assessment tools for detecting unhealthy use of “any drug” ranged from 0.71 to 0.94 (95% CI range, 0.62 to 0.97) and specificity ranged from 0.87 to 0.97 (95% CI range, 0.83 to 0.98). Tools were less accurate in detecting unhealthy use of prescription opioids or sedatives then other specific drugs, especially cannabis. Sensitivity and specificity of frequency-based and risk assessment tools for detecting any prenatal drug use (not including alcohol) was lower than the estimates found for non-pregnant adults and ranged from 0.37 to 0.76 (95% CI range, 0.24 to 0.86) and 0.68 to 0.83 (95% CI range, 0.55 to 0.91). | Reasonably consistent/Imprecise; None suspected | Good: 11; Fair: 17 | Each instrument was not evaluated in more than 1 or 2 studies.; No studies restricted inclusion to young adults specifically (the age group with the highest prevalence of use).; Low prevalence of some drugs makes it difficult to determine if the screening tools are accurate for those substances.; Few studies included biologic confirmation of drug use.; Few studies among pregnant women using brief screeners. | Low | Most studies conducted in U.S.-based primary care population; although included studies represented samples with generally higher prevalence of drug use and drug use disorders than U.S. national estimates. Higher representation of nonwhite and low SES participants.
KQ 3. Harms of screening | k=0 | NA | NA | NA | NA | Insufficient | NA
KQ 4a. Benefits of interventions: Drug use and other risky behavior | k=26 RCTs; n=9542 | No consistent effect of the interventions on rates of self-reported or biologically confirmed drug use or other risky behaviors such as alcohol use or risky sexual behaviors at 3 to 12 months followup. Frequency and quantity of drug use generally decreased, and rates of abstinence increased in both intervention and control groups with no statistically significant between-group differences detected. | Reasonably consistent/Imprecise | Good: 4; Fair: 22 | Modest sample sizes in most trials with inadequate power for important subgroup analyses.; Most drug use measures based on self-report with heterogeneous measures.; Small effect sizes may reflect research structure. Control groups may have been influenced to alter behavior based on assessment schedules alone. | Low | Applicable to U.S.-based screen-detected drug-using persons.; Evidence for adolescents and young adults primarily focused on cannabis use only. Trials among adults represented black adults with lower SES and high rates of comorbid mental health illnesses. Drug use spanned casual cannabis use to severe opiate and stimulant use.
KQ 4b. Benefits of interventions: Health, social, and legal outcomes | k=13 RCTs; n=4739 | None of the trials found a statistically significant difference between intervention and control groups on health, social or legal outcomes (including global measures of drug-related consequences) at 6- to 12-month followup. | Reasonably consistent/Imprecise; None suspected | Good: 3; Fair: 10 | | Low
KQ 5. Harms of interventions | k=4; n=1491 | There were no harms or unintended effects of the interventions. | Reasonably consistent/Reasonably precise; None suspected | Good: 0; Fair: 4 | Few trials reported potential harms of interventions; findings limited to two trials among college students and one trial among postpartum women. | Low^†^ | Applicable to college-aged cannabis users in the US and postpartum women.

* N includes one U.S.-based community sample (n=42,923) that only evaluated a single-item alcohol question for predicting problematic drug use. Without this study, total n = 22,797.

† No a priori serious harms hypothesized related to primary care relevant counseling interventions.

Abbreviations: EPC = Evidence-based Practice Center

### Benefits and Harms of Screening

We identified no studies that addressed the benefits or harms of screening (vs. no screening) for drug use in primary care. Several screening instruments have been developed to identify drug use and risks associated with drug use for primary care settings; however, these instruments have not been evaluated in more than one or two studies. Given this lack of replication and the heterogeneity in the studies, we believe the strength of this body of evidence is low (Table 17). Some frequency-based screening instruments only include questions related to the use of and/or frequency of drugs (and may ask about alcohol and tobacco use) while others also include an assessment of the patient’s risk level (i.e., specific indicators of a disorder, including experiencing drug-related consequences) for individuals with positive screening results. In general, both types of instruments (frequency-based and fuller risk assessments instruments) have sensitivity greater than or equal to 0.80 and specificity greater than or equal to 0.85 for identifying unhealthy drug use and drug use disorders when validated against structured diagnostic interviews. While one frequency-based screening tool (TAPS-1) had adequate performance to detect unhealthy use and use disorder of prescription drugs, sensitivity and specificity estimates for other screening tools were generally lower and less precise for the detection of prescription medication problem use and disorders than other drugs, which may result from confusion about what constitutes nonmedical use. The low prevalence of prescription drug misuse and other drug types (cocaine, heroin) also leads to poor precision in some estimates.

Other studies evaluated instruments to identify unhealthy drug use through indirect questions, such as assessing the frequency of heavy drinking episodes or other indicators of an alcohol use disorder and not asking participants about their drug use specifically. These instruments generally did not perform as well in detecting unhealthy drug use or drug use disorders. Such instruments, however, may be important where under-reporting of drug use is of concern such as in studies among pregnant women.

Sensitivity and specificity estimates were also lower for identifying any drug use or unhealthy drug use when confirmed by a biologic reference standard versus a diagnostic interview in the two studies that included both reference standards. There was no clear pattern for better performance for interview-administered versus self-administered (either paper-pencil or electronic) instruments. Additionally, all screening instruments were validated under confidential conditions; it is not known how their performance would differ if patients knew that their health care providers would be informed of the results.

The prevalence of drug use greatly affects the positive predictive values (PPV) of screening tools and therefore can be used to inform clinical actions (Table 18). Looking across a range of sensitivities and specificities based on our review, the PPV is quite low (≤50% for adults) given the low prevalence of any drug use and extremely low prevalence for specific classes of drugs. Put another way, approximately one-half or greater of participants who screen positive for drug use or unhealthy drug use may not actually have use that indicates the need for brief psychosocial interventions or referral to treatment. In this case, further assessment to define patients’ risk level may help determine the appropriateness of brief interventions or treatment as well as the need for arranging referral for further support.

Table 18 Estimated Positive and Negative Predictive Values Based on US Prevalence of Current Drug Use and Study Reported Sensitivity and Specificity for Drug Use Screening Instruments^*^

Population | Substance | Prevalence of current drug use^12^ | PPV 70/80^†^ | PPV 80/90^†^ | PPV 90/90^†^ | NPV 70/80^†^ | NPV 80/90^†^ | NPV 90/90^†^
Adolescents | Any illicit drug | 7.9 | 23.1 | 40.7 | 43.6 | 96.9 | 98.1 | 99.1
Adolescents | Marijuana | 6.5 | 19.6 | 35.7 | 38.5 | 97.5 | 98.5 | 99.2
Adolescents | Prescription drug (misuse) | 1.6 | 5.4 | 11.5 | 12.8 | 99.4 | 99.6 | 99.8
Adolescents | Cocaine | 0.1 | 0.3 | 0.8 | 0.9 | 100.0 | 100.0 | 100.0
Adolescents | Hallucinogens | 0.5 | 1.7 | 3.9 | 4.3 | 99.8 | 99.9 | 99.9
Adolescents | Inhalants | 0.6 | 2.1 | 4.6 | 5.2 | 99.8 | 99.9 | 99.9
Adolescents | Heroin | 0 | NA | NA | NA | NA | NA | NA
Young adults | Any illicit drug | 23.2 | 51.4 | 70.7 | 73.1 | 89.8 | 93.7 | 96.8
Young adults | Marijuana | 20.8 | 47.9 | 67.8 | 70.3 | 91.0 | 94.5 | 97.2
Young adults | Prescription drug (misuse) | 4.6 | 14.4 | 27.8 | 30.3 | 98.2 | 98.9 | 99.5
Young adults | Cocaine | 1.6 | 5.4 | 11.5 | 12.8 | 99.4 | 99.6 | 99.8
Young adults | Hallucinogens | 1.9 | 6.3 | 13.4 | 14.8 | 99.3 | 99.6 | 99.8
Young adults | Inhalants | 0.4 | 1.4 | 3.1 | 3.5 | 99.8 | 99.9 | 100.0
Young adults | Heroin | 0.3 | 1.0 | 2.4 | 2.6 | 99.9 | 99.9 | 100.0
Adults (excluding young adults) | Any illicit drug | 8.9 | 25.5 | 43.9 | 46.8 | 96.5 | 97.9 | 98.9
Adults (excluding young adults) | Marijuana | 7.2 | 21.4 | 38.3 | 41.1 | 97.2 | 98.3 | 99.1
Adults (excluding young adults) | Prescription drug (misuse) | 2.0 | 6.7 | 14.0 | 15.5 | 99.2 | 99.5 | 99.8
Adults (excluding young adults) | Cocaine | 0.6 | 2.1 | 4.6 | 5.2 | 99.8 | 99.9 | 99.9
Adults (excluding young adults) | Hallucinogens | 0.3 | 1.0 | 2.4 | 2.6 | 99.9 | 99.9 | 100.0
Adults (excluding young adults) | Inhalants | 0.2 | 0.7 | 1.6 | 1.8 | 99.9 | 100.0 | 100.0
Adults (excluding young adults) | Heroin | 0.2 | 0.7 | 1.6 | 1.8 | 99.9 | 100.0 | 100.0
Pregnant women | Any illicit drug | 6.3 | 19.0 | 35.0 | 37.7 | 97.5 | 98.5 | 99.3

* All prevalence, PPV, NPV, sensitivity, and specificity values are percentages

† Sensitivity/specificity

Abbreviations: PPV = positive predictive value; NA = not applicable; NPV = negative predictive value

### Benefits and Harms of Interventions

The previous review to support the USPSTF recommendation included only one trial^81^ that addressed treatment for drug use among an “asymptomatic” screen-detected population. Given the USPSTF determination of insufficient evidence in 2008 and a call to action for more research among primary care screen-detected populations,^113,^ ^114^ results from several well-conducted trials that were subsequently published were included in this review. Despite the increase in the number of relevant trials, there are still few studies that have evaluated the effectiveness of interventions among systematically screened populations for reducing drug use. We identified 27 eligible trials, with heterogeneity in the target populations and drugs targeted. Across all 27 trials, in general, there was no effect of brief, personalized interventions on rates of self-reported or biologically confirmed drug use or drug-related consequences. Three fair-quality trials among adolescents (n=741)—all targeting cannabis use and/or alcohol and other drug use—found no effect on self-reported drug use at 3-, 6- or 12-month followup. Likewise, there was no consistent evidence of a benefit of brief interventions on self-reported drug use compared with controls at 3-, 6-, or 12-months followup within the trials among screen-detected adults (n analyzed=7090). In general, self-reported drug use days decreased in both the intervention and control groups over time, with no statistically significant differences between groups. Finally, five fair-quality trials among pregnant and postpartum women (n=943) found mixed and inconsistent effects of brief interventions on women’s self-reported drug use at 3–6 months followup. Fourteen of these 27 trials reported the effects of the interventions on health, legal, or social consequences related to drug use, and none found differences between groups.

There was some evidence, although not definitive, that interventions limited to participants with more severe drug problems^81^ or subgroup analyses among those at higher risk (e.g., greater use of stimulant and opiate abuse^103^) may result in reduced drug use (although not related consequences), whereas no clear benefits were seen in those with lower baseline drug severity, including predominantly marijuana users. Although none of the trials took place in settings or during time periods that allowed legal recreational marijuana use, the legalization climate nationally may have served to normalize marijuana use and reduce motivation to change. Because there are no identified guidelines for a point at which marijuana-related consequences can be minimized and potential positives maximized,^6^ it is clear that there will continue to be numerous challenges for clinical practice^115^ and public health assessment and policy^6,^ ^116,^ ^117^ related to marijuana use.

Regardless of the effectiveness of brief interventions in addressing drug use following screening, asking about drug use in primary care, particularly among patients with a higher propensity for drug use (e.g., history of abuse, family history of addiction, known alcohol use disorder, mood disorder), may still be clinically justified to ensure the quality and safety of health care. Knowing patients’ drug use status and the specific types of drugs being used can inform possible drug-medication interactions, potential issues with medication adherence, safe prescribing of certain other classes of medications (e.g., narcotics, amphetamines), and overall health-related quality of life.

## Comparison With 2008 USPSTF Review

This update review differs in scope from the 2008 USPSTF review on this subject,^2^ which resulted in a different body of evidence. First, the 2008 review used a staged approach that focused on evidence for critical KQs that addressed the overarching question on direct evidence of benefit from screening and the health benefits of drug treatment (the current KQ 1 and KQ 3). Given that the evidence was considered insufficient on these critical KQs, further systematic review to include the other key questions in the analytic framework (i.e., harms and tool accuracy) were deemed unwarranted. Subsequently, a separate supplemental review was conducted that specifically related to KQ 2 on the accuracy of screening tools.^3^ In this current review, we addressed all five KQs regardless of the sufficiency or results related to each question. We omitted the original KQ related to the relationship between decreased drug use or abstinence and morbidity and mortality. We planned to address this question contextually (rather than through systematic search and selection methods) to frame the results of the review; however, given the lack of effectiveness on drug use outcomes seen in the included trials, we do not provide a robust summary here. The previous review found fair evidence that stopping or reducing drug “misuse” is related to reduced mortality and morbidity, although none of that evidence was derived from individuals screened for drug misuse in primary care settings. Second, while the 2008 review intended to only include treatment trials among screen-detected samples, 16 of the 17 included treatment trials were conducted among treatment-seeking, instead of primary-care-screened, populations. As a result, most of the interventions were pharmacotherapy treatments among treatment-seeking patients. Our current review applied strict inclusion criteria to ensure that the evidence applied to a screen-detected population and thus, only carried forward one trial that was previously included.^81^ Likewise, because pharmacotherapy (medication-assisted therapy) is only approved for use among adults with opioid use disorders, these therapies were considered out-of-scope for this review. Other existing systematic reviews have found these treatments to be effective in ameliorating opioid withdrawal and assisting with detoxification.^118^ Lastly, the previous review only included evidence related to the use of illicit opiates, cocaine, and cannabis (or those targeting all drugs) whereas our update included any psychoactive drug used for nonmedical purposes. Despite the differences in our criteria, this did not result in material differences given that all our included intervention trials targeted any drug use, cannabis, or cocaine and heroin, specifically.

## Comparison With Other Reviews

We are unaware of any existing systematic reviews that have synthesized the performance of screening instruments for unhealthy drug use among primary care-relevant populations. The findings from our review with respect to intervention effectiveness are generally concordant with those of Young and colleagues’ 2014 systematic review^119^ (k=5) on the effectiveness of the SBIRT model for reducing nonmedical use of psychoactive substances. Young and colleagues’ review limited interventions to those following the SBIRT model, while our review allowed for variation in intervention approach and the length and number of contacts. Moreover, our review included studies with at least 3 months of followup, while Young and colleagues included studies with even shorter-term (1–2 months) followup. Despite these differences in scope, our review generated a similar body of evidence, with our review sharing four of the five trials included in the Young and colleagues review.^80,^ ^81,^ ^89,^ ^111^ Young and colleagues encountered similar limitations among their included studies, such as the lack of systematic screening for participants, heterogeneity in study characteristics, incomplete reporting, and small sample sizes. Due to these limitations, Young and colleagues concluded insufficient evidence to determine the efficacy of brief interventions to reduce drug use among nontreatment seeking, screen-detected populations. Our review is also similar with that of Farr and colleagues^120^ with both reviews finding mixed effects of brief interventions on drug use among pregnant and postpartum women in the short-term (<3 months).

## Applicability

Despite inclusion criteria designed to result in the selection of studies highly applicable to U.S. primary care, many of the screening studies were conducted in populations with high prevalence of drug use. As such, the tool accuracy reported in the included studies may not reflect the accuracy for all U.S. primary care settings. Additionally, some of the larger studies were conducted among non-clinic-based samples (e.g., national random samples) and results may not be generalizable to the primary care setting. Likewise, given the research context of these studies, in most cases participants’ screening responses were anonymous and were not shared with the patients’ personal clinicians. As a result, tool accuracy may be overestimated and may not accurately reflect responses that would be given if the patient knew their results would be shared with their clinician. In any case, given the potentially low PPV for detecting drug use that requires provision or referral for psychosocial interventions or other treatments, further assessment to define patients’ risk level, such as the procedure recommended by the National Institute on Drug Abuse (NIDA) may help.^121^ NIDA recommends referring patients for a full assessment if a problem is indicated by the screen or through discussion with the patient. Specifically, for adults age 18 or older they recommend first using the NIDA Quick Screen (adapted from the Smith et al.^45^ study included in this review), which assesses previous-year use of alcohol, tobacco, prescription drugs for nonmedical reasons, and illegal drugs. If the patient answers “never” for all drugs, abstinence should be reinforced. If the patient says “yes” (at any frequency) to use of illegal or prescription drugs for nonmedical reasons, they then recommend beginning the NIDA-Modified ASSIST (an 8-item tool based on the ASSIST as tested in this review). For each substance used, a score is calculated based on frequency of use in the previous 3 months and problems related to use that helps to identify a patient’s risk level and to determine further steps such as offering continuing support, considering whether to make a referral for further diagnostic assessment or treatment based on clinical judgment, or directly arranging such referrals.

By design, this review focused on primary care-relevant interventions to reduce drug use among screen-detected drug users. The findings presented here do not reflect the totality of evidence for treating drug use or drug use disorders. Like the screening evidence, while all of the included evidence reflected patients seen in primary care in the United States, they all generally targeted particular settings that resulted in samples with a higher prevalence of drug use and drug use disorders than national data. Most participants in the two studies among adolescents were black and had previous-year cannabis use. The five trials among young adults were mostly white college students with various frequency of cannabis use. The thirteen studies among adults, in contrast, represented higher-risk adults, including majority black adults with severe socioeconomic disadvantage and high rates of comorbid mental health conditions. As a result, across the body of evidence, there was a wide range in the severity and types of drug use addressed—from occasional cannabis use to those with diagnosed cocaine use disorders. All the interventions were quite similar, generally consisting of one personalized counseling session based on principles of motivational interviewing with or without a booster session or telephone call. These brief interventions were provided either by trained behavioral or mental health specialists or self-administered electronically. In only two trials did primary care providers administer the intervention.

## Limitations of the Review

This review was not intended to be a comprehensive review on the evidence for treating drug use or drug use disorders. It was designed, rather, to address outcomes related to screening (vs. no screening) for drug use, the accuracy with which drug screening instruments can identify unhealthy use or use disorders, and potential benefits and harms of providing counseling about reducing drug use among those who have been identified by screen detection. Therefore, we included only trials of interventions among screen-detected populations that were applicable to primary care. There are several other systematic reviews, however, related to nonpharmacologic interventions and pharmacologic treatments for drug dependence or drug use disorders among non-screen detected persons (i.e., treatment seeking or otherwise mandated/identified) or those conducted in settings not as applicable to primary care (e.g., school-based interventions) that show efficacy for reducing drug use.^118,^ ^120,^ ^122–131^

For KQ 4, we included studies reporting drug use outcomes at 3 months or longer followup. Many studies, including some of our included trials,^94,^ ^103–105,^ ^107^ have shown effectiveness of brief interventions in reducing drug use or drug-related consequences in the short term (i.e., 1 to 3 months),^87,^ ^89,^ ^132^ but not longer-term (i.e., 6 months or greater). It may be unreasonable to expect long-lasting effects (>3 months) of a single short feedback session in reducing drug use. Over time, effects of these interventions may wear off as motivations inspired by the interventions become less salient. This might suggest a need for more intensive multisession approaches, the addition of one or more booster sessions, or other brief interventions or referral to treatment. In addition, we only included randomized controlled trials and excluded observational designs which may have led to the exclusion of other relevant evidence. For example, in the observational study by Madras and colleagues,^133^ rates of illicit drug use were compared before screening and 6 months after screening, brief intervention, and referral to treatment services were provided across six states. Among those reporting baseline illicit drug use, rates of self-reported drug use at 6-month followup were statistically significantly lower following treatment.

Because this review focused on screening and subsequent psychosocial interventions for drug use, we did not include questions or evidence related to preventing misuse of prescription opioids or detecting misuse of prescription opioids among those on chronic opioid therapy. Most of our included screening instruments assessing drug use and several of the brief interventions, however, did address misuse of prescription drugs. Given the rise in opioid prescribing^134^ and the immense burden of opioid-related morbidity and mortality, particularly overdose deaths,^134^ it is clear that continued efforts to change prescribing practices (e.g., policies to reduce inappropriate opioid prescribing, requiring clinicians to review prescription drug monitoring program data) and monitor and treat prescription misuse are warranted. Clinical instruments have been designed for predicting opioid abuse or misuse prior to opioid therapy initiation, including the Screening and Opioid Assessment for Patients with Pain-Revised (SOAPP-R) tool, the Opioid Risk Tool (ORT), and the Brief Risk Interview, although results on the accuracy of these tools are very limited and inconsistent.^135^

## Limitations of the Studies and Future Research Needs

Several limitations related to the included studies should be noted and point to needs for future research. First, more research and replication are needed to test the performance and accuracy of brief screening instruments relevant for primary care implementation. Additional studies that focus on possible harms of screening are needed to elucidate factors that may deter acceptance of screening by providers and patients or discourage honest responses on screening tools. These harms may relate to concerns about documenting screening results and sharing them with referral providers, relatives, insurers, health authorities, and other entities needed for obtaining consent for treatment, authorizing payment for diagnostic or treatment services, or complying with mandatory reporting requirements. The current studies show promise for brief frequency-based screeners as well as risk assessment instruments, but they should be evaluated in more studies across more primary care populations. Future studies of screening instruments should examine their accuracy and impacts on clinical workflow and resources when they are implemented in primary care. Computer self-administered screening conducted prior to the medical visit is increasingly being used for other conditions and deserves further study as an approach to screening for drug use. Studies limited to young adults, who have the highest rates of drug use, are particularly warranted. Additionally, further understanding the social and legal context and consequences related to screening for drug use in pregnant and postpartum women is necessary.

Second, the body of evidence for the effectiveness of interventions among screen-detected populations is still relatively small and has important limitations. Few interventions were conducted in primary care settings or included involvement of the primary care provider. Thus, the feasibility and effectiveness of these interventions when delivered in primary care settings remains unclear given very limited encounter times, lack of trained interventionists, and uncertainty whether involving primary care providers in intervention delivery would influence patient drug use. In addition, some, but not all,^103,^ ^104^ of the studies had modest sample sizes, which may have limited their power to detect significant changes. Many of the included studies were framed as feasibility or pilot trials and included recommendations to conduct full-scale trials of the tested interventions. Few addressed potential harms of participating in interventions such as labeling or discrimination or loss of time from work, school or other important pursuits. Larger sample sizes would allow for meaningful subgroup analyses to evaluate how important characteristics of the population might modify effectiveness of the interventions. Additionally, in most cases, drug use outcomes were based on self-report and did not include biological confirmation. Most of the studies included steps to increase the validity of self-report including self-administration or blinding of assessors and assurances of confidentiality. However, introducing biological measures could provide important validation. In one of our included trials that included both self-report and biochemical measures, self-report of improvements in drug use was shown to be highly inflated.^81^ At baseline, there was good agreement between self-report and hair samples for current cocaine and/or heroin use; however, there was substantial under-reporting of cocaine and/or heroin use at followup (45% of participants reported no cocaine/heroin use, but only 18% tested negative for both substances), although there were no differences in this disagreement between intervention and control group participants. Research suggests self-report is both over- and underreported depending on several factors, including recency of use, reporting period, and amount used. While biologic measures may assist in determining any drug use, such measures are not sensitive in detecting unhealthy use – a construct that may be particularly important for drugs that are legal to use (e.g., marijuana, prescription opioids). Also, biological testing only assesses selected drugs and the length of detection time varies by drug.

Additionally, there was considerable variability in the measures used to detect change in drug use which precluded robust synthesis and comprehensive pooled analyses. Many of the measures, which generally focused on frequency of drug use, may not be as sensitive to change as other possible measures, including quantity of drugs used or number of times used on the days the drug is used. Continuing to include measures related to the consequences of drug use and other health, legal, and social outcomes is also important, especially tracking how many patients continue to substance use treatment or other referred services following brief intervention.

The control groups in most of the intervention trials included usual care or minimal interventions (i.e., at least a written referral list). The lack of differences seen between groups in these trials may be different if compared with controls under actual conditions of clinical practice rather than research structures. Assessment reactivity alone (introspective thinking about one’s drug use that is prompted by an assessment) may have minimized the effect sizes for the interventions with participants (both intervention and control participants) thinking introspectively about their drug use, thereby serving as a brief intervention or increasing social desirability bias in their self-reports of use. Alternative study designs such as stepped-wedge cluster randomized trials, sequential, multiple assignment, randomized trials (SMART), and micro-randomized trials should be considered in this field to determine real-world effectiveness and where interventions may need to be adaptive and equally provided to all participants throughout a study.

Given these limitations and an apparent lack of effectiveness of brief interventions for drug use, many in this field have proclaimed a need to consider evaluating alternatives to screening and brief interventions for reducing drug use in primary care such as those that apply different counseling strategies or multidisciplinary approaches or involve more or longer sessions.^136,^ ^137^ It is clear that primary care clinicians need to address the burden of drug use, but such a complex problem will likely require more complex solutions. Studies of new intervention models are needed including varied counseling approaches, multiple contact and longer sessions, team-based collaborative care approaches, and screening and interventions integrated into primary care and including the primary care provider. Additionally, more research on interventions that concurrently address common comorbidities such as unhealthy alcohol use, anxiety, and depression among primary care patients with unhealthy drug use are warranted.

Many ongoing studies (Appendix H) may address some of these research gaps. None of these ongoing studies, however, appear to address the overarching question related to the benefits and harms of screening for drug use.

## Conclusion

Several screening instruments with acceptable sensitivity and specificity have been developed to screen for drug use and drug use disorders in primary care, although in general, the accuracy of each tool has not been evaluated in more than one study and there is no evidence on the benefits or harms of screening versus no screening for drug use. Brief interventions for reducing the use of illicit drugs or the nonmedical use of prescription drugs in screen-detected primary care patients are unlikely to be effective for decreasing drug use or drug use consequences. Given the burden of drug use, more research is needed on approaches to identify and effectively intervene with patients exhibiting risky patterns of drug use in primary care.