# Chapter 3 Results

We reviewed a total of 17,921 abstracts and 273 articles for all KQs (Appendix D). The lists of included studies (55 trials in 74 publications) and excluded studies (with reasons for exclusion) are available in Appendix E and Appendix F, respectively. A list of abbreviations relating to the screening tools and reference standards is provided in Appendix G.

## Key Questions 1–3 Overall Summary of Results for Screening for Drug Use

No trials examined the benefits (KQ 1) or harms (KQ 3) of screening for drug use. We identified 28 studies^15,^ ^42–68^ (reported in 37 publications^15,^ ^42–77^) that addressed the accuracy of drug use screening instruments (KQ 2). Only one study among adolescents^46^ and one study among adults^49^ were included in the previous report^3^ to support the USPSTF recommendation. There was considerable heterogeneity in the populations (Table 3), screening tools (Table 4), substances addressed, reference standards, and target conditions included in each study. In general, each specific screening instrument has not been studied more than once or twice. Eleven studies recruited adolescents,^42,^ ^46,^ ^52,^ ^54,^ ^56,^ ^57,^ ^59,^ ^60,^ ^64,^ ^66,^ ^67^ 12 studies recruited adults,^43–45,^ ^48–51,^ ^55,^ ^61,^ ^62,^ ^65,^ ^68^ and five studies recruited pregnant or postpartum women^15,^ ^47,^ ^53,^ ^58,^ ^63^ (Table 3). None of the studies focused specifically on young adults (i.e., 18–25-year-olds) or older adults (i.e., ≥65 years); however, one study recruited participants from a Veterans Affairs hospital and the mean age was 62.6 years^44^ and another recruited adults 50 years or older and reported subgroup results for older adults.^65^ The majority of studies were conducted in the United States^15,^ ^42–52,^ ^54,^ ^56,^ ^58,^ ^61–66^ (21 of 28) and recruited patients from primary care (17 of 28).^42–48,^ ^50–54,^ ^56,^ ^62–64,^ ^67^ The number of screened participants ranged from 100 to 42,923; 20 studies screened fewer than 1000 participants.

Table 3 Study and Population Characteristics, by Subpopulation (KQ 2)

Target pop | Author, year | Quality rating | Country | Recruitment setting | Brief population description | N screened | Age, mean | Female, % | Race/ethnicity, % | Socioeconomic status | Screening tests
Adolescents | Bastiani, 2013^57^ | Fair | ITA | High School | Adolescents, aged 15–19 years, using cannabis in previous year | 5787 | 17.0 | 50.8 | NR | NR | SDS; CAST; CAST (binary)
Adolescents | Chung, 2003^66^ | Fair | US | ED | Adolescents age 13–19 years | 442 | 15.7 | 40.3 | White: 67.6; Black: 7.9; Hispanic: 16.7 | 50% with high school-educated parent | AUDIT; AUDIT-C; Single question, cannabis
Adolescents | D’Amico, 2016^64^ | Good | US | Primary care | Adolescents, aged 12–18 years | 1573 | 15.5 | 57.5 | White: 14.7; Black: 26.7; Hispanic: 51.4 | NR | CRAFFT; AUDIT; NIAAA Youth Screen; PESQ-PS
Adolescents | Fernandez-Artamendi, 2012^59,*^ | Fair | ESP | High School | Students, 16–20 years, using cannabis in the past month | 144 | 17.4 | 28.5 | NR | 2.1% living in residential care facility | CAST; CPQ-A-S
Adolescents | Gryczynski, 2015^54^ | Fair | US | Primary care | Adolescents, aged 12–17 years | 525 | NR | 54 | White: <1; Black: 93; Hispanic: 3 | 3% in college or not enrolled in high school | ASSIST; ASSIST-Lite
Adolescents | Harris, 2016^52^ | Good | US | Primary care | Adolescents, aged 12–17 years | 136 | 15.0 | 54.4 | White: 18.4; Black: 27.9; Hispanic: 24.3 | 58% with college graduate parent(s) | CRAFFT; Single question, cannabis
Adolescents | Kelly, 2014^42^ | Fair | US | Primary care | Adolescents, aged 12–17 years | 525 | NR | 54.5 | White: 0.8; Black: 92.8; Hispanic: NR | 2.5% not enrolled in school | BSTAD; POSIT; POSIT revised
Adolescents | Knight, 2002^46^ | Good | US | Primary care | Adolescents aged 14–18 years | 538 | NR | 68.4 | White: 24.2; Black: 50.6; Hispanic: 18.8 | NR | CRAFFT
Adolescents | Legleye, 2011^60^ | Good | FRA | Community-based | Adolescents, currently using cannabis | 2566 | 17.0 | 41.9 | NR | 5.1% not enrolled in school | CAST; CAST (binary)
Adolescents | Mitchell, 2014^56^ | Fair | US | Primary care | Adolescents, aged 12–17 years | 525 | NR | 54.5 | White: NR; Black: 92; Hispanic: NR | 13% not enrolled in school | CRAFFT
Adolescents | Rial, 2018^67^ | Fair | ESP | High School | Adolescents attending secondary education | 569 | 14.7 | 42.9 | NR | NR | CRAFFT; POSIT
Adults | Beaudoin, 2016^65^ | Good | US | ED | Adults 50 years or older using prescription opioids in the past 30 days | 112 | NR | 52.7 | White: 72.1; Black: 18.0; Hispanic: 9.8 | 79.5% HS grad or more | PDUQp
Adults | Brown, 2001^48^ | Good | US | Primary care | Adults, aged 18–59 years | 702 | NR | 67.9 | White: 83.3; Black: 12.1; Hispanic: 1.8 | 87% HS grad or more | TICS
Adults | Dawson, 2010^61^ | Fair | US | Community-based | Adults, aged ≥18 years | 42923 | NR | NR | NR | NR | Single-item alcohol HED
Adults | Kumar, 2016^51^ | Good | US | Primary care | Adults ≥18 years | 399 | 46.8 | 48.4 | White: 19.8; Black: 47.9; Hispanic: NR | 82% HS grad or more | ASSIST
Adults | Lane, 2007^62^ | Fair | US | Primary care | Caregivers of children aged under 6 years | 216 | 25.2 | 94.0 | NR | 65% HS grad or more | PSQ
Adults | Legleye, 2015^†^,^55^ | Fair | FRA | Community-based | Adolescents and adults, aged 15–64 years, using cannabis in the past year | 550 | 29.0 | 32.9 | NR | NR | CAST
Adults | Legleye, 2018^68ǁ^ | Good | FRA | Community-based | Adolescents and adults, aged 15–64 years, using cannabis in the past year | 1351 | NR | 44.0 | NR | NR | CAST
Adults | McCann, 2000^49^ | Fair | US | Other medical | Adults seeking evaluation for ADHD | 139 | 36.4 | 30.9 | White: 95.7; Black: NR; Hispanic: NR | NR | DAST-28
Adults | McNeely, 2016^50^ | Fair | US | Primary care | Adults, aged ≥18 years | 2057 | 46.0 | 56.2 | White: 33.4; Black: 55.6; Hispanic: NR | 81% HS grad or more | TAPS; TAPS-1
Adults | McNeely, 2015^43,^ ^70^ | Good | US | Primary care | Adults, aged 21–65 years | 586 | 46.0 | 49.8 | White: 18.7; Black: 50.2; Hispanic: 21.7 | 84% HS grad or more | SUBS; Single-item drug frequency question, drug^‡^
Adults | Smith, 2010^45,^ ^69^ | Good | US | Primary care | Adults, aged ≥18 years | 286 | 49.0 | 54.2 | White: 17.1; Black: 62.6; Hispanic: 16.1 | 72% HS grad or more | DAST-10; Single-item drug frequency question^§^; Single-item alcohol HED
Adults | Tiet, 2015^44,^ ^72^ | Fair | US | Primary care | VA adults | 640 | 62.6 | 4.7 | White: 57.5; Black: NR; Hispanic: NR | 76% HS grad or more | ASSIST-Drug; SoDU; DAST-2
Pregnant/Postpartum women | Chasnoff, 2007^47^ | Fair | US | Primary care | Pregnant women, aged ≥18 years | 228 | NR | 100 | NR, target population was 80% Black and 20% Hispanic | NR, 40% of residents were under 185% of the poverty level at the time of the 1990 census.; Medicaid or a Medicaid-managed care plan covered all the patients | 4P’s Plus
Pregnant/Postpartum women | Harrison, 2012^63^ | Fair | US | Primary care | Pregnant women | 745 | 23.0 | 100 | White: 10.2; Black: 58.7; Hispanic: 7.9 | | PRO
Pregnant/Postpartum women | Lam, 2015^53^ | Fair | HKG | Primary care | Pregnant women (<20 wks gestation) | 1082 | 31.0 | 100 | NR | 2.4% on public financial assistance | DAST-10
Pregnant/Postpartum women | Grekin, 2010^15^ | Fair | US | Hospital | Postpartum women in post-delivery recovery | 274 | NR | 100 | White: NR; Black: 90.3; Hispanic: NR | 68% HS grad or more; 84.5% receiving some form of public assistance | DAST-10
Pregnant/Postpartum women | Ondersma, 2012^58^ | Good | US | Hospital | Postpartum women in post-delivery recovery | 100 | NR | 100 | White: NR; Black: 94; Hispanic: NR | 72% HS grad or more; 86% receiving some form of public assistance | ASSIST-2 (modified); DAST-10; WIDUS

* Includes young adults, but the study sample mean age was 17 years

† Includes adolescents, but the study sample mean age was 29 years

‡ How many times in the past year have you used an illegal drug or used a prescription medication for nonmedical reasons (for example, because of the experience or feeling it caused)?

§ How many times in the past year have you used an illegal drug or used a prescription medication for nonmedical reasons?

ǁ Includes adolescents, but assume the majority of the sample was adults

Abbreviations: ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; AUDIT = Alcohol Use Disorders Identification Test; AUDIT-C = Alcohol Use Disorders Identification Test - Consumption; BSTAD = Brief Screener for Tobacco, Alcohol, and Other Drugs; CAST = Cannabis Abuse Screening Test; CPQ-A-S = Cannabis Problems Questionnaire for Adolescents Shortened; CRAFFT = Car Relax Alone Forget Family/Friends Trouble; DAST-2 = 2-Item Drug-Abuse Screening Test; DAST-10 = 10-Item Drug-Abuse Screening Test; DAST-28 = 28-Item Drug-Abuse Screening Test; ED = emergency department; ESP = Spain; FRA = France; HED = heavy episodic drinking; HKG = Hong Kong; HS = high school; ITA = Italy; KQ = key question; NR = not reported; PDUQp = Prescription Drug Use Questionnaire Patient Version; PESQ-PS = Personal Experience Screening Questionnaire; pop = population; PRO = Prenatal Risk Overview; PSQ = Parent Screening Questionnaire; SDS = Severity of Dependence Scale; SES = socioeconomic status; SoDU = Screen of Drug Use; SUBS = Substance Use Brief Screen; TAPS = Tobacco, Alcohol, Prescription Medication, and Other Substance Use; TICS = Two-Item Conjoint Screen; US = United States; WIDUS = Wayne Indirect Drug Use Screener; wks = weeks

Table 4 Properties of Screening Instruments (KQ 2)

Tool type | Tool name | Full name | No. of items | Substances addressed | Questions | Admin methods | Population addressed (Authors)
Frequency-based | ASSIST-2 (modified) | Alcohol, Smoking and Substance Involvement Screening Test (First 2 items of standard ASSIST, modified)^*^ | 2 | Tobacco, Alcohol, Cannabis, Cocaine, Amphetamines, Inhalants, Sedatives, Hallucinogens, Opioids, Other (nonspecified) | 1. In your life, which of the following substances have you ever used?^*^; 2. In the past 3 months, how often have you used the substances you mentioned? | Self, electronic | Pregnant women (Ondersma, 2012^58^)
Frequency-based | BSTAD | Brief Screener for Tobacco, Alcohol, and Other Drugs | 6 | Tobacco, Alcohol, drugs^†^ | 1. Do you have friends who smoked cigarettes or used other tobacco products in the past year?; 2. Do you have friends who drank beer, wine, or any drink containing alcohol in the past year?; 3. Do you have friends who in the past year sniffed or huffed anything; took illegal drugs like marijuana, cocaine, etc.; took prescription medications that were not prescribed for them; or took prescription or over-the-counter medications and took more than they were supposed to take?; 4. In the past year have you smoked cigarettes or used other tobacco products in the past year?; 5. In the past year have you drank beer, wine, or any drink containing alcohol in the past year?; 6. In the past year have you sniffed or huffed anything; taken illegal drugs like marijuana, cocaine, etc.; taken prescription medications that were not prescribed for them; or taken prescription or over-the-counter medications and took more than you were supposed to take?; a. In the past 30 days, on how many days have you used SPECIFIC SUBSTANCE?; b. In the past 90 days, on how many days have you used SPECIFIC SUBSTANCE?; c. In the past year, on how many days have you used SPECIFIC SUBSTANCE? | Self, electronic; Interviewer, face-to-face | Adolescents (Kelly, 2014^42^)
Frequency-based | Single-item cannabis frequency | | 2 | Marijuana | 1. During the past 12 months, did you ever use any marijuana?; 2. During the past 3 months, about how often did you use marijuana? | Self, electronic; Interviewer, face-to-face | Adolescents (Harris, 2016^52^, Chung, 2003^66^)
Frequency-based | Single-item drug frequency | NA | 1 | Illegal drugs, prescription medication | 1. How many times in the past year have you used an illegal drug or used a prescription medication for nonmedical reasons (for example, because of the experience or feeling it caused)? | Interviewer, face-to-face; Self, electronic | Adults (McNeely, 2015^43,^ ^70^,Smith, 2010^45,^ ^73^)
Frequency-based | SUBS | Substance Use Brief Screen | 4 | Tobacco, Alcohol, Illegal drug (including marijuana), recreational prescription medications^†^ | 1. In the past 12 months, on how many days did you use tobacco?; 2. In the past 12 months, on how many days did you have 4 or more alcohol drinks in a day, including wine or beer?; 3. In the past 12 months, on how many days did you use any illegal drug, including marijuana?; 4. In the past 12 months, on how many days did you use any prescription medication “recreationally” (just for the feeling, or using more than prescribed)? | Self, electronic | Adults (McNeely, 2015^43^)
Frequency-based | TAPS-1 | Tobacco, Alcohol, Prescription Medication, and Other Substance use – rapid screener | 4 | Tobacco, Alcohol, Illegal drug (including marijuana), prescription medications | In the past 12 months, how often have you:; 1. Used any tobacco product (for example, cigarettes, e-cigarettes, cigars, pipes, or smokeless tobacco)?; 2. Had 5/4 (M/F) or more drinks containing alcohol in one day?; 3. Used any drugs including marijuana, cocaine or crack, heroin, methamphetamine (crystal meth), hallucinogens, ecstasy (MDMA)?; 4. Used any prescription medications just for the feeling, more than prescribed, or that were not prescribed for you? (Prescription medications that may be used in this way include: opioid pain relievers (e.g., Oxycontin, Vicodin, Percocet, methadone), medications for anxiety or sleeping (e.g., Xanax, Ativan, Klonopin), medications for ADHD (e.g., Adderall or Ritalin) | Self, electronic; Interviewer, face-to-face | Adults (McNeely, 2016)^50,^ ^74^
Risk assessment | ASSIST | Alcohol, Smoking and Substance Involvement Screening Test | 8^‡^ | Tobacco, Alcohol, Cannabis, Cocaine, Amphetamines, Inhalants, Sedatives, Hallucinogens, Opioids, Other (nonspecified) | 1. In your life, which of the following substances have you ever used?; 2. In the past 3 months, how often have you used the substances you mentioned?; 3. During the past 3 months, how often have you had a strong desire or urge to use the substance?; 4. During the past 3 months, how often has your use of the substance led to health, social, legal, or financial problems?; 5. During the past 3 months, how often have you failed to do what was normally expected of you because of your use of the substance?; 6. Has a friend or relative or anyone else ever expressed concern about your use?; 7. Have you ever tried and failed to control, cut down, or stop using?; 8. Have you ever used any drug by injection?; (Includes opening question to assess use) | Interviewer, face-to-face; Self, electronic | Adolescents (Gryczynski, 2015^54^); Adults (Kumar, 2016^51^)
Risk assessment | ASSIST-Drug | Alcohol, Smoking and Substance Involvement Screening Test - Drug | 2 | Drugs | 1. How many days in the past 12 months have you used drugs?; 2. How many days in the past 12 months have you had a strong desire or urge to use drugs? | Interviewer, face-to-face | Adults (Tiet, 2015^44,^ ^72^)
Risk assessment | ASSIST-Lite (Cannabis) | Alcohol, Smoking and Substance Involvement Screening Test Lite (for Cannabis) | 3 | Cannabis | 1. Did you use cannabis in the past 3 months?; 2. Have you had a strong desire or urge to use cannabis at least once a week or more often?; 3. Has anyone expressed concern about your cannabis use? | Interviewer, face-to-face | Adolescents (Gryczynski, 2015^54^)
Risk assessment | CAST | Cannabis Abuse Screening Test | 6 | Cannabis | 1. Have you smoked cannabis before midday?; 2. Have you smoked cannabis when you were alone?; 3. Have you had memory problems when you smoked cannabis?; 4. Have friends or family members told you that you should reduce or stop your cannabis consumption?; 5. Have you tried to reduce or stop your cannabis use without succeeding?; 6. Have you had problems because of your cannabis use (argument, fight, accident, poor results at school, etc.)? | Interviewer, phone; Self, paper-pencil; Self, electronic | Adolescents (Bastiani, 2013^57^,Legleye, 2011^60^, Fernandez-Artamendi, 2012^59^); Adults (Legleye, 2015,^55^ Legleye, 2018^68^)
Risk assessment | CPQ-A-S | Cannabis Problems; Questionnaire for Adolescents Shortened | 12 | Cannabis | 1. Have you tended to smoke more on your own than you used to?; 2. Have you worried about meeting people you don’t know when you are stoned?; 3. Have you spent more time with smoking friends than other kinds of friends?; 4. Have your friends criticized you for smoking too much?; 5. Have you found yourself worried about the amount of money you have been spending on cannabis?; 6. Have you been in trouble with the police due to your smoking?; 7. Have you been physically sick after smoking?; 8. Have you passed out after a smoking session?; 9. Have you had pains in your chest or lungs after a smoking session?; 10. Have you had a persistent chest infection or cough?; 11. Have you felt paranoid or antisocial after a smoking session?; 12. Have you worried about getting out of touch with friends or family? | Self, electronic | Adolescents (Fernandez-Artamendi, 2012^59^)
Risk assessment | CRAFFT | Car Relax Alone Forget Friends Trouble | 6 | Alcohol, drugs | 1. Have you ever ridden in a CAR driven by someone (including yourself) who was “high” or had been using alcohol or drugs?; 2. Do you ever use alcohol or drugs to RELAX, feel better about yourself, or fit in?; 3. Do you ever use alcohol/drugs while you are by yourself, ALONE?; 4. Do you ever FORGET things you did while using alcohol or drugs?; 5. Do your family or FRIENDS ever tell you that you should cut down on your drinking or drug use?; 6. Have you gotten into TROUBLE while you were using alcohol or drugs?; (Includes opening question to assess use) | Interviewer, face-to-face; Self, electronic; Self, paper-pencil | Adolescents (Knight, 2002^46^, Harris, 2016^52^, Mitchell, 2014^56^, D’Amico, 2016,^64^ Rial, 2018^67,^ ^77^)
Risk assessment | DAST-2 | Drug Abuse Screening Test-2 items | 2 | Drugs | 1. How many days in the past 12 months have you felt bad or guilty about your drug use?; 2. How many days in the past 12 months have you used drugs other than those required for medical reasons? | Interviewer, face-to-face | Adults (Tiet, 2015^44,^ ^75^)
Risk assessment | DAST-10 | Drug Abuse Screening Test-10 items | 10 | Drugs | 1. Have you used drugs other than those required for medical reasons?; 2. Do you abuse more than one drug at a time?; 3. Are you always able to stop using drugs when you want to?; 4. Have you had “blackouts” or “flashbacks” as a result of drug use?; 5. Do you ever feel bad or guilty about your drug use?; 6. Does your spouse (or parents) ever complain about your involvement with drugs?; 7. Have you neglected your family because of your use of drugs?; 8. Have you engaged in illegal activities in order to obtain drugs?; 9. Have you ever experienced withdrawal symptoms (felt sick) when you stopped taking drugs?; 10. Have you had medical problems as a result of your drug use (e.g., memory loss, hepatitis, convulsions, bleeding, etc.)? | Interviewer, face-to-face; Self, paper-pencil; Self, electronic | Adults (Smith, 2010^45^); Pregnant women (Lam, 2015^53^, Ondersma, 2012^58^, Grekin, 2010^15^)
Risk assessment | DAST-28 | Drug Abuse Screening Test-28 items | 28 | Drugs | 1. Have you used drugs other than those required for medical reasons?; 2. Have you abused prescription drugs?; 3. Do you abuse more than one drug at a time?; 4. Can you get through the week without using drugs (other than those required for medical reasons)?; 5. Are you always able to stop using drugs when you want to?; 6. Do you abuse drugs on a continuous basis?; 7. Do you try to limit your drug use to certain situations?; 8. Have you had “blackouts” or “flashbacks” as a result of drug use?; 9. Do you ever feel bad about your drug abuse?; 10. Does your spouse (or parents) ever complain about your involvement with drugs?; 11. Do your friends or relatives know or suspect you abuse drugs?; 12. Has drug abuse ever created problems between you and your spouse?; 13. Has any family member ever sought help for problems related to your drug use?; 14. Have you ever lost friends because of your use of drugs?; 15. Have you ever neglected your family or missed work because of your use of drugs?; 16. Have you ever been in trouble at work because of drug abuse?; 17. Have you ever lost a job because of drug abuse?; 18. Have you gotten into fights when under the influence of drugs?; 19. Have you ever been arrested because of unusual behavior while under the influence of drugs?; 20. Have you ever been arrested for driving while under the influence of drugs?; 21. Have you engaged in illegal activities to obtain drugs?; 22. Have you ever been arrested for possession of illegal drugs?; 23. Have you ever experienced withdrawal symptoms as a result of heavy drug intake?; 24. Have you had medical problems as a result of your drug use (e.g., memory loss, hepatitis, convulsions, or bleeding)?; 25. Have you ever gone to anyone for help for a drug problem?; 26. Have you ever been in hospital for medical problems related to your drug use?; 27. Have you ever been involved in a treatment program specifically related to drug use?; 28. Have you been treated as an outpatient for problems related to drug abuse? | Interviewer, face-to-face | Adults (McCann, 2000^49^)
Risk assessment | PESQ-PS | Personal; Experience; Screening; Questionnaire Problem; Severity Scale | 18 | Alcohol, drugs | How often have you used alcohol or other drugs:; 1. At home; 2. At places on the street where adults hang around; 3. With older friends; 4. At the homes of friends or relatives; 5. At school activities, such as dances or football games; 6. At work; 7. When skipping school; 8. To enjoy music or colors, or feel more creative; How often have you:; 9. Made excuses to your parents about your alcohol or drug use; 10. Gotten drugs from a dealer; 11. Used alcohol or drugs secretly, so no one would know you were using; 12. Made excuses to teachers about your alcohol or drug use; 13. Been upset about other people talking about your using or drinking; When using alcohol or other drugs, how often have you:; 14. Spilled things, bumped into things, fallen down, or had trouble walking around; 15. Seen, felt, or heard things that were not there; 16. Spent money on things you wouldn’t normally buy; 17. Found out things you said or did while using or drinking that you did not remember; In order to get or pay for alcohol or other drugs, how often have you:; 18. Sold drugs | Self, paper-pencil | Adolescents (D’Amico, 2016^64^)
Risk assessment | POSIT Substance Use and Abuse Subscale | Problem Oriented Screening Instrument for Teenagers, Substance Use and Abuse Subscale | 17 | Alcohol, drugs | 1. Do you get into trouble because you use drugs or alcohol at school?; 2. Have you accidentally hurt yourself or someone else while high on alcohol or drugs?; 3. Do you miss out on activities because you spend too much money on drugs or alcohol?; 4. Do you ever feel you are addicted to alcohol or drugs?; 5. Have you started using more and more drugs or alcohol to get the effect you want?; 6. Do you ever leave a party because there is no alcohol or drugs?; 7. Do you have a constant desire for alcohol or drugs?; 8. During the past month have you driven a car while you were drunk or high?; 9. Have you had a car accident while high on drugs or alcohol?; 10. Do you forget things you did while drinking or using drugs?; 11. Does alcohol or drug use cause your moods to change quickly like from happy to sad or vice versa?; 12. Do your family or friends ever tell you that you should cut down on your drinking or drug use?; 13. Do you have serious arguments with friends or family members because of your drinking or drug use?; 14. Does your alcohol or drug use ever make you do something you would not normally do, like breaking rules, missing curfew, breaking the law or having sex with someone?; 15. Do you miss school or arrive late for school because of your alcohol or drug use?; 16. Do you have trouble getting along with any of your friends because of your alcohol or drug use?; 17. Do you ever feel you can’t control your drug use? | Interviewer, face-to-face | Adolescents (Rial, 2018,^67,^ ^77^ Kelly, 2014^42,^ ^76^)
Risk assessment | POSIT revised | Problem-Oriented Screening Instrument for Teenagers, revised | 11 | Alcohol, drugs | 1. Do you ever feel you are addicted to drugs?; 2. Have you started using more and more drugs or alcohol to get the effect you want?; 3. Does your alcohol or drug use ever make you want to do something you would not normally do – like breaking rules, missing curfew, breaking the law, or having sex with someone?; 4. Do you forget things you did while drinking or using drugs?; 5. Do your family and friends ever tell you that you should cut down on your drinking or drug use?; 6. Do you have a constant desire for alcohol or drugs?; 7. Do you ever feel you can’t control your alcohol or drug use?; 8. Do you have serious arguments with friends or family members because of your drinking or drug use?; 9. Do you miss out on activities because you spend too much money on drugs or alcohol?; 10. Does alcohol or drug use cause your moods to change quickly like form happy to sad or vice versa?; 11. Have you accidentally hurt yourself or someone else while high on alcohol or drugs? | Self, NR | Adolescents (Kelly, 2014^42,^ ^76^)
Risk assessment | PRO | Prenatal Risk Overview-Drug Use | 3 | Drugs | 1. During the 12 months before you knew you were pregnant, on how many days did you use marijuana or any other drug not prescribed for you by your doctor?; 2. During the past 12 months, have you neglected your responsibilities because of drug use?; 3. Since you have known you were pregnant, on how many days did you use marijuana or any other drug not prescribed for you by your doctor? | Interviewer, face-to-face | Pregnant women (Harrison, 2012^63^)
Risk assessment | PSQ | Parent Screening Questionnaire | 2 | Alcohol, drugs | 1. In the past year, have you or your partner had a problem with drugs or alcohol?; 2. In the past year, have you or your partner felt the need to cut back on drinking or drug use? | Self, electronic | Adults (Lane, 2007^62^)
Risk assessment | PDUQp | Prescription Drug Use Questionnaire, patient version | 31 | Prescription opioids | 1. Do you have more than one painful condition?; 2. Are you disabled by pain (unable to work or participate fully in activities)?; 3. Are you receiving any disability payments (such as SSI, or VA disability)?; 4. Do you have any current lawsuits or claims related to your pain problem?; 5. Have you tried any non-medication treatments for your pain problem (such as physical therapy, TENS, biofeedback); 6. Has your pain been adequately treated over the past 6 months?; 7. Do you feel at all angry or mistrustful toward your previous doctors?; 8. Have you been given pain medications from more than one clinic over the past 6 months?; 9. Have you ever been or do you think you might currently be addicted to pain medications?; 10. Has a doctor ever told you that you were addicted to pain medications?; 11. Have you had to increase the amount of pain medications you take over the past 6 months?; 12. Have you had to call in for more pain medications because your prescription ran out?; 13. Have you used the pain medications to help other symptoms such as problems sleeping, anxiety, or depression?; 14. Do you save up unused medications in case you might need them in the future?; 15. Do you ever use alcohol to help relieve some of the pain?; 16. Do you think certain pain medications (such as vicodin, codeine, or percocet) work better for you and you prefer to take them and not others?; 17. Have you ever lost your pain medications and needed them replaced?; 18. Have you had to visit the emergency room in the past 6 months because of your pain problem?; 19. Have you ever had to buy pain medications on the street?; 20. Have doctors ever refused to give you the pain medications you felt you needed because of fear that you might abuse them?; 21. Is anyone in your family or among your friends concerned that you might be addicted to pain medications?; 22. Do any of your family members disagree with your use of pain medications?; 23. Does anyone in your family help to take care of you due to your pain problem?; 24. Does your spouse or significant other have problems with drugs or alcohol?; 25. Have those in your family or among your friends ever obtained pain medications for you?; 26. Have you ever borrowed pain medications from a friend or family member?; 27. Has anyone in your immediate family (father, mother, siblings) ever had a problem with drugs or alcohol?; 28. Has anyone in your immediate family (father, mother, siblings) ever had a problem with chronic pain?; 29. Have you ever had an alcohol or drug addiction problem?; 30. Have you ever been treated for an alcohol or drug abuse problem?; 31. Have you ever been taken partially or completely off pain medications to decrease your tolerance? | Self, electronic | Adults (Beaudoin, 2016^65^)
Risk assessment | SDS | Severity Dependence Scale | 5 | Cannabis | During the past year:; 1. Did you think your use of cannabis was out of control?; 2. Did the prospect of missing a dose of cannabis makes you anxious or worried?; 3. Did you worry about your use of cannabis?; 4. Did you wish you could stop the use of cannabis?; 5. How difficult did you find it to stop, or go without cannabis? | Self, paper-pencil | Adolescents (Bastiani, 2013^57^)
Risk assessment | SoDU | Screen of Drug Use | 2 | Drugs | 1. How many days in the past 12 months have you used drugs other than alcohol?; 2. How many days in the past 12 months have you used drugs more than you meant to? | Interviewer, face-to-face | Adults (Tiet, 2015^44,^ ^72^)
Risk assessment | TAPS | Tobacco, Alcohol, Prescription Medication, and Other Substance Use | 5–26^§^ | Marijuana, cocaine or crack, heroin, methamphetamine, hallucinogens, ecstasy/MDMA, prescription medications^†^ | 1. In the past 12 months, how often have you used any drugs, including marijuana, cocaine or crack, heroin, methamphetamine (crystal meth), hallucinogens, or ecstasy/MDMA?; a. In the past 3 months, did you use SPECIFIC SUBSTANCE?; i. In the past 3 months, have you had a strong desire or urge to use SPECIFIC SUBSTANCE at least once a week or more often?; ii. In the past 3 months, has anyone expressed concern about your use of SPECIFIC SUBSTANCE?; 2. In the past 12 months, how often have you used any prescription medications (opiate pain reliever/medication for anxiety or sleep/medication for ADHD) just for the feeling, more than prescribed, or that were not prescribed for you?; a. In the past 3 months, did you use SPECIFIC SUBSTANCE not as prescribed or that was not prescribed for you?; i. In the past 3 months, have you tried and failed to control, cut down, or stop using SPECIFIC SUBSTANCE?; ii. In the past 3 months, has anyone expressed concern about your use of SPECIFIC SUBSTANCE?; 3. Any drugs or prescription medications; a. In the past 3 months, did you use any other illegal or recreational drug (for example, ecstasy, molly, GHB, poppers, LSD, mushrooms, special K, bath salts, synthetic marijuana (”spice”), whip-its, etc.)? (no = 0, yes = 1); b. In the past 3 months, what were the other drug(s) you used? (fill in response) | Self, electronic; Interviewer, face-to-face | Adults (McNeely, 2016^50^)
Risk assessment | TICS | Two-Item Conjoint Screen | 2 | Alcohol, drugs | 1. In the last year, have you ever drunk or used drugs more than you meant to?; 2. Have you felt you wanted or needed to cut down on your drinking or drug use in the last year? | Interviewer, face-to-face | Adults (Brown, 2001^48^)
Indirect^¶^ | AUDIT-C | Alcohol Use Disorders Identification Test - Consumption | 3 | Alcohol | 1. How often do you have a drink containing alcohol?; 2. How many drinks containing alcohol do you have on a typical day when you are drinking?; 3. How often do you have 6 or more drinks on one occasion? | | Adolescents (Chung, 2003^66^)
Indirect^¶^ | AUDIT | Alcohol Use Disorders Identification Test | 10 | Alcohol | 1. How often do you have a drink containing alcohol?; 2. How many drinks containing alcohol do you have on a typical day when you are drinking?; 3. How often do you have 6 or more drinks on one occasion?; 4. How often during the last year have you found that you were not able to stop drinking once you had started?; 5. How often during the last year have you failed to do what was expected of you because of drinking?; 6. How often during the last year have you needed a first drink in the morning to get yourself going after a heavy drinking session?; 7. How often during the last year have you had a feeling of guilt or remorse after drinking?; 8. How often during the last year have you been unable to remember what happened the night before because of your drinking?; 9. Have you or someone else been injured because of your drinking?; 10. Has a relative, friend, or doctor, or other health care worker been concerned about your drinking or suggested you cut down?; (Includes opening question to assess use) | Interviewer, face-to-face; Self, electronic | Adolescents (D’Amico, 2016^64^ Chung, 2003^66^)
Indirect^¶^ | NIAAA Youth Screen | National Institute on Alcohol Abuse and Alcoholism Screening Guide | 2 | Alcohol | 1. In the past year, on how many days have you had more than a few sips of beer, wine, or any drink containing alcohol?; Do any of your friends drink alcohol?^ǁ^ | Interviewer, face-to-face | Adolescents (D’Amico, 2016^64^)
Indirect^¶^ | Single-item HED frequency | NA | 1 | Alcohol | 1. How many times in the past year have you had 5/4 (male/female) or more drinks in a day?; (Often includes opening question to assess use) | Interviewer, face-to-face | Adults (Dawson, 2010^61^, Smith, 2010^45,^ ^69,^ ^73^)
Indirect^¶^ | WIDUS | Wayne Indirect Drug Use Screener | 6 | Cigarettes | 1. I am currently married; 2. In the past year I have been bothered by pain in my teeth or mouth; 3. I have smoked at least 100 cigarettes in my entire life; 4. Most of my friends smoke cigarettes; 5. There have been times in my life, for at least 2 weeks straight, where I felt like everything was an effort; 6. I get mad easily and feel a need to blow off some steam | Self, electronic | Pregnant women (Ondersma, 2012^58^)
Indirect^¶^ | 4P’s Plus | Parents Partner Past Pregnancy | 5 | Alcohol, tobacco^#^ | 1. Did either of your parents ever have a problem with alcohol or drugs?; 2. Does your partner have a problem with alcohol or drugs?; 3. Have you ever drunk beer, wine, or liquor?; 4. In the month before you knew you were pregnant, how many cigarettes did you smoke?; 5. In the month before you knew you were pregnant, how many beers/how much wine/how much liquor did you drink? | Interviewer, face-to-face | Pregnant women (Chasnoff, 2007^47^)

* Specific modifications not reported by study

† Tobacco and alcohol were included in the screening test, but those questions were not used to determine who screened

‡ Questions 1–7 of the ASSIST each contain specific questions regarding up to 10 substance classes. The number of items delivered depends on the responses given to Question 1 and Question 2

§ Five initial questions for specific substance groups followed by 3–4 optional questions for each substance that are asked only if one of the first 5 questions is answered affirmatively

ǁ Order of questions varied depending on age

¶ Targets only substances other than drugs (like alcohol or tobacco) and/or other social factors associated with drug use

# Parents’ and partners’ alcohol and drug use were assessed in addition to participant’s use of alcohol and tobacco

Abbreviations: Admin = administration; ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; AUDIT = Alcohol Use Disorders Identification Test; BSTAD = Brief Screener for Tobacco, Alcohol, and Other Drugs; CAST = Cannabis Abuse Screening Test; CPQ-A-S = Cannabis Problems Questionnaire for Adolescents Shortened; CRAFFT = Car Relax Alone Forget Family/Friends Trouble; DAST-10 = 10-Item Drug-Abuse Screening Test; DAST-28 = 28-Item Drug-Abuse Screening Test; HED = heavy episodic drinking; No. = number; PESQ-PS = Personal Experience Screening Questionnaire; PRO = Prenatal Risk Overview; PSQ = Parent Screening Questionnaire; SDS = Severity of Dependence Scale; SoDU = Screen of Drug Use; SUBS = Substance Use Brief Screen; TAPS = Tobacco, Alcohol, Prescription Medication, and Other Substance Use; TICS = Two-Item Conjoint Screen; WIDUS = Wayne Indirect Drug Use Screener

Most of the studies used a structured diagnostic interview to determine the substance use condition, although various versions were used (e.g., ADI, CIDI, DISC-IV, MINI) and sometimes the interview was used in combination with other screening instruments (e.g., ASSIST), the TLFB, or biologic confirmation. For pregnant or postpartum women, three of the five studies^15,^ ^47,^ ^58^ relied solely on hair or urine analysis to determine substance use during pregnancy. The majority of the studies were fair quality (17 of 28); among these, risk of bias resulted from a variety of reasons, including: not reporting enough information regarding the order and timing of the reference standard and screening tool; not clearly reporting whether the researchers had knowledge of the index tool results during the administration and interpretation of the reference standard; not presenting a range of cutoff values and selecting only the optimal or an a priori threshold; and/or unclear reporting of whether participant recruitment was random or consecutive.

Thirty screening tools were evaluated in the included studies. The screening tools varied in the number of questions (range 1–31 questions) and subsequent administration time, administration method (interviewer-administered in person or via phone or self-administered electronically or via paper-pencil), and the substances addressed. Most of the screening tools addressed the use of any drug (with or without addressing alcohol and tobacco use). Among these, the majority included an assessment of nonmedical use of prescription drugs either through a specific question or prior to administering the screening participants were told that drug use included nonmedical use of prescription medications. Four screening tools asked only about cannabis use; three only asked about alcohol use; and one only asked about cigarette use and other social factors. A list of all the included screening tools and their full names is provided in Table 4.

We organized the results within population subgroups by the type of screening instrument: 1) frequency-based screening instruments (addressing any use and/or frequency of use), 2) risk assessment instruments (addressing the potential consequences of drug use, typically those that are indicators of a use disorder and often in combination with drug use frequency), and 3) indirect screening instruments (did not screen for drug use directly but assessed other correlates of drug use, such as alcohol use, tobacco use, partner substance use, and other social factors).

For adolescents, most of the studies focused on detecting cannabis use conditions. All studies validated responses solely against structured clinical interviews. Sensitivity of the frequency-based (Figure 2) and risk assessment tools (Figure 3 and Figure 4) for detecting any cannabis use or unhealthy cannabis use ranged from 0.68 to 0.98 (95% CI range, 0.64 to 0.99) and specificity ranged from 0.82 to 1.00 (95% CI range, 0.80 to 1.00). Sensitivity and specificity for identifying a cannabis use disorder for frequency-based and risk assessment tools ranged from 0.71 to 0.98 (95% CI range, 0.41 to 0.99) and 0.79 to 0.95 (95% CI range, 0.77 to 0.98), respectively; the low prevalence of cannabis use disorder and small sample size in one study resulted in less overall precision in the estimates of sensitivity when compared to other cannabis use conditions.

Figure 2 Accuracy of Frequency-Based Screening Tools in Detecting Specific Drug Use Among Adolescents

Abbreviations: BSTAD = Brief Screener for Tobacco, Alcohol, and Other Drugs; cann = cannabis; CI = confidence interval; I = interviewer-administered; mo = months; n = number of participants screened; S = self-administered

This figure shows the test accuracy frequency-based screening tools in detecting specific drug use among adolescents.

Figure 3 Accuracy of Risk Assessment Screening Tools in Detecting Any Drug Use or Unhealthy Drug Use Among Adolescents Screening

Abbreviations: ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; CAST = Cannabis Abuse Screening Test; CI = confidence interval; CRAFFT = Car Relax Alone Forget Family/Friends Trouble; n = number of participants screened; PESQ-PS = Personal Experience Screening Questionnaire

This figure shows the test accuracy risk assessment screening tools in detecting any drug use or unhealthy drug use among adolescents.

Figure 4 Accuracy of Risk Assessment Screening Tools in Detecting Drug Use Disorder Among Adolescents

Abbreviations: ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; CAST = Cannabis Abuse Screening Test; CI = confidence interval; CPQ-A-S = Cannabis Problems Questionnaire for Adolescents Shortened; CRAFFT = Car Relax Alone Forget Family/Friends Trouble; I = interviewer-administered; n = number of participants screened; PESQ-PS = Personal Experience Screening Questionnaire; POSIT = Problem Oriented Screening Instrument for Teenagers; S = self-administered; SDS = Severity of Dependence Scale

This figure shows the test accuracy of risk assessment screening tools in detecting drug use disorder among adolescents.

Among adults, frequency-based tools (Figure 5 and Figure 6) and risk assessment screening tools (Figure 7 and Figure 8) showed sensitivity for detecting unhealthy use of any drug (not including alcohol) ranging from 0.71 to 0.94 (95% CI range, 0.62 to 0.97) and specificity ranging from 0.87 to 0.97 (95% CI range, 0.83 to 0.98). For identifying drug use disorders among adults, sensitivity for frequency-based and risk assessment tools ranged from 0.85 to 1.00 (95% CI range, 0.67 to 1.00) and specificity ranged from 0.67 to 0.93 (95% CI, 0.58 to 0.95) when using the same tool cutoffs. In studies that examined unhealthy use of specific drugs, the ranges of sensitivity were lower and less precise for detecting unhealthy use or use disorders for prescription opioids and prescription sedatives (sensitivity ranged from 0.38 to 0.89 [95% CI range, 0.29 to 0.94] as compared with other classes of drugs, although confidence intervals generally overlapped. Specificity was comparable and ranged from 0.79 to 1.00 [95% CI range, 0.71 to 1.00])

Figure 5 Accuracy of Frequency-Based Screening Tools in Detecting Any Drug Use Among Adults

Abbreviations: B = reference standard included biologic confirmation; CI = confidence interval; n = number of participants screened; SUBS = Substance Use Brief Screen

This figure shows the test accuracy of frequency-based screening tools in detecting any drug use among adults.

Figure 6 Accuracy of Frequency-Based Screening Tools in Detecting Specific Drug Use Among Adults

Abbreviations: CI = confidence interval; n = number of participants screened; Rx = prescription; SUBS = Substance Use Brief Screen; TAPS-1 = Tobacco, Alcohol, Prescription Medication, and Other Substance Use first-stage screening component

This figure shows test accuracy of frequency-based screening tools in detecting specific drug use among adults.

Figure 7 Accuracy of Risk Assessment Screening Tools in Detecting Any Drug Use Among Adults

Abbreviations: ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; B = reference standard included biologic confirmation; CI = confidence interval; DAST-2 = 2-Item Drug-Abuse Screening Test; DAST-10 = 10-Item Drug-Abuse Screening Test; DAST-28 = 28-Item Drug-Abuse Screening Test; PSQ = Parent Screening Questionnaire; n = number of participants screened; S = self-administered; SoDU = Screen of Drug Use

This figure shows the test accuracy of risk assessment screening tools in detecting any drug use among adults.

Figure 8 Accuracy of Risk Assessment Screening Tools in Detecting Specific Drug Use Among Adults

Abbreviations: ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; CAST = Cannabis Abuse Screening Test; CI = confidence interval; I = interviewer-administered; n = number of participants screened; PDUQp = Prescription Drug Use Questionnaire Patient Version; Rx = prescription; S = self-administered; TAPS = Tobacco, Alcohol, Prescription Medication, and Other Substance Use

This figure shows the test accuracy of risk assessment screening tools in detecting specific drug use among adults.

Sensitivity and specificity for detecting any prenatal drug use (based on validation against hair or urine analysis) was generally lower than the estimates found for any drug use in non-pregnant adults (only rarely based on validation against biologic sample analyses) and ranged from 0.37 to 0.76 (95% CI range, 0.24 to 0.86) and 0.68 to 0.83 (95% CI range, 0.55 to 0.91). The 4P’s Plus, which indirectly screens for drug use, had a sensitivity of 0.87 (95% CI, 0.71 to 0.95) and specificity of 0.76 (95% CI, 0.70 to 0.82) for detecting any prenatal alcohol or drug use when compared with a diagnostic interview.

Across all studies, there was no clear pattern of better accuracy when looking at interviewer-administration versus self-administration of the screening tools. In studies that included biologic confirmation of drug use in addition to a structured clinical interview, sensitivity was lower when compared with the structured clinical interview alone. Indirect screeners (i.e., those that did not ask directly about drug use) generally had similar specificity, but lower sensitivity in detecting unhealthy drug use or use disorders among adolescents (range, 0.20 to 0.54 [95% CI range, 0.17 to 0.60]) and adults (0.59 to 0.72 [95% CI range, 0.48 to 0.82]) as compared with the frequency-based and risk assessment tools. Among pregnant women, indirect screeners had comparable accuracy with the direct screeners.

### Key Question 1a Does Primary Care Screening for Drug Use in Adolescents and Adults, Including Pregnant Women, Reduce Drug Use or Improve Other Risky Behaviors?

### Key Question 1b Does Primary Care Screening for Drug Use in Adolescents and Adults, Including Pregnant Women, Reduce Morbidity or Mortality or Improve Other Health, Social, or Legal Outcomes?

We identified no trials that addressed the effects of screening for drug use on drug use outcomes, risky behaviors (such as alcohol or tobacco use or risky sexual behaviors) or health, social, or legal outcomes.

### Key Question 2 What Is the Accuracy of Drug Use Screening Instruments?

#### Adolescents

##### Study and Population Characteristics

Eleven studies (n=13,330), four rated as good quality and seven as fair quality, evaluated the accuracy of screening instruments among adolescents (Table 3).^42,^ ^46,^ ^52,^ ^54,^ ^56,^ ^57,^ ^59,^ ^60,^ ^64^ Seven of the studies recruited participants from primary care^42,^ ^46,^ ^52,^ ^54,^ ^56,^ ^60,^ ^64^ or the emergency department^66^ in the United States; the remaining four studies recruited youth from schools or the broader community within European countries.^57,^ ^59,^ ^60,^ ^67^ Sample sizes ranged from 136 to 5787. Most participants in the U.S.-based studies were nonwhite. Race and ethnicity were not reported for the studies conducted in Europe. In all but one of the nine studies, in which 71.5 percent of participants were male,^59^ sex was evenly distributed. Three of the four studies conducted in Europe restricted inclusion to adolescents who had used cannabis in the previous year^57^ or month^59^ or were current cannabis users.^55^

Two studies reported the prevalence of unhealthy use of alcohol or any drugs at 18.5 percent^56^ and 26.8 percent,^46^ whereas two other studies reported unhealthy use of cannabis at 15.3 percent^54^ and 19.7 percent.^64^ Any use of drugs was only reported for cannabis in two studies; in these studies, prevalence of previous-year cannabis use among adolescents was 18.4 percent^52^ and 36.6 percent.^64^ All eleven studies reported the prevalence of a use disorder (alcohol, any drug, or cannabis) or dependence. The prevalence of cannabis use disorders (the most commonly reported condition) ranged from 5.9 percent to 35.7 percent among adolescents.

We included tool accuracy measures for four target conditions across the nine studies, including unhealthy drug use (variably defined as any drug use, heavy use, problem use, and/or drug use disorders) 4 studies^46,^ ^52,^ ^54,^ ^56,^ ^64^); any drug use (cannabis specifically, 2 studies^52,^ ^64^); drug use disorders (8 studies^42,^ ^46,^ ^52,^ ^54,^ ^56,^ ^64^), and dependence alone (6 studies^46,^ ^54,^ ^56,^ ^57,^ ^59,^ ^60^). Two studies^57,^ ^59^ reported only the accuracy of screening instruments to detect dependence. All eleven studies used a structured diagnostic interview to diagnose a drug use disorder or dependence based on DSM-IV or DSM-5 standard criteria. None of the studies among adolescents included biological confirmation of self-reported use.

Fourteen different screening tools were evaluated. Five instruments—the CRAFFT, CAST, AUDIT, POSIT, and the single-item cannabis frequency question—were evaluated in more than one study among adolescents (Table 4). While the target conditions for this review were required to focus on drug use, many of the screening tools queried participants about their use of all substances, including alcohol and tobacco. Six tools asked about general substance use including drugs and alcohol with or without tobacco (ASSIST, BSTAD, CRAFFT, PESQ-PS, POSIT, POSIT-revised); five instruments asked about cannabis use only (ASSIST-LITE for cannabis, CAST, CPQ-A-S, single-item cannabis-frequency question, SDS); and three instruments that assessed alcohol only were used as indirect instruments for detecting drug use (AUDIT, AUDIT-C, NIAAA Youth Screen). Two screeners addressed only the frequency of use; most assessed risks associated with use in addition to frequency. The number of questions included in each screening tool ranged from 1 to 18, with 10 questions or less for all but four screening tools (CPQ-A-S, PESQ-PS, POSIT, and POSIT revised). Six studies had an interviewer administer the screening tool (s) in person,^46,^ ^52,^ ^54,^ ^56,^ ^66,^ ^67^ three studies had participants self-administer the screening tool (s) electronically,^52,^ ^59,^ ^64^ three studies had the participants self-administer the tool on paper,^57,^ ^60,^ ^64^ and one study had an interviewer administer the screening tool over the phone.^55^ One study split its sample and had half the participants self-administer the screening tool electronically, while the other half were administered the tool in person by an interviewer.^42^

##### Detailed Results: Tool Accuracy

Results related to the sensitivity and specificity and corresponding 95% confidence intervals for all screening tools and target conditions among adolescents are presented in Table 5.

Table 5 Results of Screening Accuracy Studies Among Adolescents (KQ 2), by Tool Type and Specific Tool

Tool type | Tool name | Tool cutoff^*^ | Author, year | Reference standard | Condition | Condition, % | Total n | Sensitivity (95% CI) | Specificity (95% CI) | AUC (95% CI)
Frequency-based | BSTAD | 2+^†^ | Kelly, 2014^42^ | CIDI-2 | Cannabis use disorder | 10.7 | 525 | 0.80 (0.69, 0.89) | 0.93 (0.91, 0.95) | 0.87 (NR)
Frequency-based | Single-item frequency, cannabis | 2+/year | Chung, 2003^66^ | DISC | Cannabis abuse or dependence | 15.4 | 442 | 0.96 (0.88, 0.98) | 0.86 (0.82, 0.89) | NR
Frequency-based | Single-item frequency, cannabis (self-administered) | 12-month use | Harris, 2016^52^ | TLFB | Cannabis use in past year | 18.4 | 136 | 0.72 (0.52, 0.86) | 1.00 (0.97, 1.00) | NR
Frequency-based | Single-item frequency, cannabis (interviewer-administered) | 12-month use | Harris, 2016^52^ | TLFB | Cannabis past year use | 18.4 | 136 | 0.79 (0.58, 0.91) | 0.99 (0.94, 1.00) | NR
Frequency-based | Single-item frequency, cannabis (self-administered) | 3-month use | Harris, 2016^52^ | ADI | Cannabis abuse or dependence | 5.9 | 136 | 0.88 (0.46, 0.98) | 0.93 (0.86, 0.96) | NR
Frequency-based | Single-item frequency, cannabis (interviewer-administered) | 3-month use | Harris, 2016^52^ | ADI | Cannabis abuse or dependence | 5.9 | 136 | 0.86 (0.41, 0.98) | 0.91 (0.85, 0.95) | NR
Risk assessment | ASSIST | 2+ | Gryczynski, 2015^54^ | CIDI-2 | Cannabis unhealthy use^‡^ | 15.2 | 525 | 0.975 (0.91, 0.98) | 0.912 (0.88, 0.94) | 0.94 (NR)
Risk assessment | ASSIST | 2+ | Gryczynski, 2015^54^ | CIDI-2 | Cannabis use disorder | 10.7 | 525 | 0.982 (0.91, 1.0) | 0.868 (0.83, 0.90) | 0.93 (NR)
Risk assessment | ASSIST | 7+ | Gryczynski, 2015^54^ | CIDI-2 | Cannabis moderate-severe use disorder | NR | 525 | 1.0 (NR^§^) | 0.92 (NR^§^) | 0.96 (NR)
Risk assessment | ASSIST-Lite | 1+ | Gryczynski, 2015^54^ | CIDI-2 | Cannabis use disorder | 10.7 | 525 | 0.96 (0.88, 0.99) | 0.88 (0.85, 0.91) | 0.92 (NR)
Risk assessment | CAST | 3+ | Legleye, 2011^60^ | M-CIDI | Cannabis abuse or dependence^ǁ^ | 35.7 | 2566 | 0.795 (0.77, 0.82) | 0.809 (0.79, 0.83) | 0.877 (NR)
Risk assessment | CAST | 6+ | Bastiani, 2013^57^ | M-CIDI | Cannabis dependence^¶^ | 15.5 | 5787 | 0.803 (0.78, 0.83) | 0.801 (0.79, 0.81) | 0.875 (0.861, 0.888)
Risk assessment | CAST | 5+ | Fernandez-Artamendi, 2012^59^ | NSDUH | Cannabis dependence | 31.9 | 144 | 0.83 (0.589, 0.857) | 0.87 (0.858, 0.971) | 0.929 (NR)
Risk assessment | CAST | 3+ | Legleye, 2011^60^ | M-CIDI | Cannabis dependence^ǁ^ | 22.1 | 2566 | 0.841 (0.81, 0.87) | 0.717 (0.70, 0.74) | 0.854 (NR)
Risk assessment | CAST (binary) | 2+ | Legleye, 2011^60^ | M-CIDI | Cannabis abuse or dependence^ǁ^ | 35.7 | 2566 | 0.706 (0.68, 0.73) | 0.873 (0.86, 0.89) | 0.859 (NR)
Risk assessment | CAST (binary) | 3+ | Bastiani, 2013^57^ | M-CIDI | Cannabis dependence^¶^ | 15.5 | 5787 | 0.783 (0.75, 0.81) | 0.823 (0.81, 0.83) | 0.869 (0.855, 0.883)
Risk assessment | CAST (binary) | 2+ | Legleye, 2011^60^ | M-CIDI | Cannabis dependence | 22.1 | 2566 | 0.776 (0.74, 0.81) | 0.792 (0.77, 0.81) | 0.849 (NR)
Risk assessment | CPQ-A-S | 3+ | Fernandez-Artamendi, 2012^59^ | NSDUH | Cannabis dependence | 31.9 | 144 | 0.83 (0.686, 0.922) | 0.775 (0.680, 0.854) | 0.881 (NR)
Risk assessment | CRAFFT | 2+ | Knight, 2002^46^ | ADI + POSIT | Alcohol or drug unhealthy use^#^ | 26.8 | 538 | 0.76 (0.68, 0.83) | 0.94 (0.92, 0.96) | 0.92 (NR)
Risk assessment | CRAFFT | 2+ | Mitchell, 2014^56^ | CIDI-2 | Alcohol or drug unhealthy use^**^ | 18.5 | 525 | 0.79 (0.71, 0.87) | 0.97 (0.95, 0.98) | 0.93 (NR)
Risk assessment | CRAFFT | 2+ | Knight, 2002^46^ | ADI | Alcohol or drug abuse or dependence | 16.2 | 538 | 0.80 (0.72, 0.89) | 0.86 (0.83, 0.89) | 0.90 (NR)
Risk assessment | CRAFFT | 2+ | Mitchell, 2014^56^ | CIDI-2 | Alcohol or drug abuse or dependence | 12.4 | 525 | 0.91 (0.83, 0.97) | 0.93 (0.90, 0.95) | 0.97 (NR)
Risk assessment | CRAFFT | 2+ | Rial, 2018^67,^ ^77^ | ADI | All substances use disorder | 26.8 | 312 | 0.744 (0.64, 0.82) | 0.964 (0.93, 0.98) | 0.946 (NR)
Risk assessment | CRAFFT | 2+ | Mitchell, 2014^56^ | CIDI-2 | Alcohol or drug moderate-severe use disorder | NR | 525 | 0.88 (0.75, 0.97) | 0.87 (0.84, 0.90) | 0.95 (NR)
Risk assessment | CRAFFT | 2+ | Knight, 2002^46^ | ADI | Alcohol or drug dependence | 6.7 | 538 | 0.92 (0.82, 1.00) | 0.80 (0.77, 0.83) | 0.93 (NR)
Risk assessment | CRAFFT | 2+ | D’Amico, 2016^64^ | DISC-IV | Cannabis past year use | 36.6 | 1567 | 0.68 (0.64, 0.72) | 0.92 (0.90, 0.94) | NR
Risk assessment | CRAFFT | 2+ | D’Amico, 2016^64^ | DISC-IV | Cannabis unhealthy use^††^ | 19.3 | 1567 | 0.84 (0.79, 0.88) | 0.83 (0.81, 0.85) | NR
Risk assessment | CRAFFT (self-administered) | 2+ | D’Amico, 2016^64^ | DISC-IV | Cannabis use disorder | 13.6 | 1567 | 0.88 (0.83, 0.92) | 0.80 (0.78, 0.82) | NR
Risk assessment | CRAFFT (self-administered) | 2+ | Harris, 2016^52^ | ADI | Cannabis abuse or dependence | 5.9 | 136 | 0.88 (0.46, 0.98) | 0.94 (0.88, 0.97) | NR
Risk assessment | CRAFFT (interviewer-administered) | 2+ | Harris, 2016^52^ | ADI | Cannabis abuse or dependence | 5.9 | 136 | 0.88 (0.46, 0.98) | 0.95 (0.90, 0.98) | NR
Risk assessment | PESQ-PS | Yellow or Red Flag | D’Amico, 2016^64^ | DISC-IV | Cannabis use in past year | 36.6 | 1541 | 0.72 (0.68, 0.75) | 0.93 (0.91, 0.94) | NR
Risk assessment | PESQ-PS | Yellow or Red Flag | D’Amico, 2016^64^ | DISC-IV | Cannabis unhealthy use^††^ | 19.3 | 1541 | 0.86 (0.81, 0.90) | 0.82 (0.80, 0.84) | NR
Risk assessment | PESQ-PS | Yellow or Red Flag | D’Amico, 2016^64^ | DISC-IV | Cannabis use disorder | 13.6 | 1541 | 0.91 (0.86, 0.94) | 0.79 (0.77, 0.81) | NR
Risk assessment | POSIT | 2+ | Rial, 2018^67,^ ^77^ | ADI | All substances use disorder | 21.4 | 569 | 0.943 (0.89, 0.97) | 0.839 (0.80, 0.87) | 0.953 (NR)
Risk assessment | POSIT | 2+ | Kelly, 2014^42,^ ^76^ | CIDI | Alcohol or cannabis use disorder | 12.4 | 525 | 0.85 (0.75, 0.92) | 0.95 (0.93, 0.97) | 0.90 (0.85, 0.95)
Risk assessment | POSIT | 2+ | Kelly, 2014^42,^ ^76^ | CIDI | Cannabis use disorder | 10.7 | 525 | 0.86 (0.77, 0.94) | 0.94 (0.92, 0.96) | 0.91 (0.86, 0.96)
Risk assessment | POSIT, revised | 2+ | Kelly, 2014^42,^ ^76^ | CIDI | Alcohol or cannabis use disorder | 12.4 | 525 | 0.83 (0.73, 0.91) | 0.96 (0.94, 0.97) | 0.90 (0.84, 0.95)
Risk assessment | POSIT, revised | 2+ | Kelly, 2014^42,^ ^76^ | CIDI | Cannabis use disorder | 10.7 | 525 | 0.86 (0.75, 0.93) | 0.95 (0.92, 0.97) | 0.90 (0.85, 0.95)
Risk assessment | SDS | 3+ | Bastiani, 2013^57^ | M-CIDI | Cannabis dependence^¶^ | 15.5 | 5787 | 0.747 (0.72, 0.77) | 0.754 (0.74, 0.77) | 0.828 (0.813, 0.844)
Indirect | AUDIT | 3 | Chung, 2003^66^ | DISC | Cannabis abuse or dependence | 15.4 | 442 | 0.70 (0.59, 0.80) | 0.82 (0.78, 0.86) | NR
Indirect | AUDIT | 8+ | D’Amico, 2016^64^ | DISC-IV | Cannabis use in past year | 36.6 | 1569 | 0.20 (0.17, 0.24) | 0.99 (0.98, 0.99) | NR
Indirect | AUDIT | 8+ | D’Amico, 2016^64^ | DISC-IV | Cannabis unhealthy use^††^ | 19.3 | 1569 | 0.29 (0.24, 0.34) | 0.97 (0.96, 0.98) | NR
Indirect | AUDIT | 8+ | D’Amico, 2016^64^ | DISC-IV | Cannabis use disorder | 13.6 | 1569 | 0.32 (0.26, 0.39) | 0.96 (0.94, 0.97) | NR
Indirect | AUDIT-C | 2 | Chung, 2003^66^ | DISC | Cannabis abuse or dependence | 15.4 | 442 | 0.62 (0.50, 0.72) | 0.85 (0.81, 0.88) | NR
Indirect | NIAAA Youth Screen | Moderate or high risk | D’Amico, 2016^64^ | DISC-IV | Cannabis use in past year | 36.6 | 1573 | 0.39 (0.35, 0.44) | 0.93 (0.92, 0.95) | NR
Indirect | NIAAA Youth Screen | Moderate or high risk | D’Amico, 2016^64^ | DISC-IV | Cannabis unhealthy use^††^ | 19.3 | 1573 | 0.48 (0.42, 0.54) | 0.88 (0.87, 0.90) | NR
Indirect | NIAAA Youth Screen | Moderate or high risk | D’Amico, 2016^64^ | DISC-IV | Cannabis use disorder | 13.6 | 1573 | 0.54 (0.47, 0.60) | 0.87 (0.85, 0.89) | NR

* Study-reported or reviewer-determined optimal cut-off

† 2 days in past 12 months

‡ Past year cannabis use and ≥1 DSM-5 criteria for cannabis

§ Could not be calculated

ǁ Included withdrawal as criterion for dependence

¶ Dependence was based on 4/7 criteria and included withdrawal as criterion

# POSIT score ≥2 or DSM-IV abuse or dependence for alcohol and drugs

** ≥1 DSM-5 criterion for alcohol and drugs

†† ≥2 instances of cannabis use/days used

Abbreviations: ADI = Adolescent Diagnostic Interview; ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; AUC = area under the curve; AUDIT = Alcohol Use Disorders Identification Test; BSTAD = Brief Screener for Tobacco, Alcohol, and Other Drugs; CAST = Cannabis Abuse Screening Test; CI = confidence interval; CPQ-A-S = Cannabis Problems Questionnaire for Adolescents Shortened; CRAFFT = Car Relax Alone Forget Family/Friends Trouble; DISC-IV = Diagnostic Interview for Children Version IV; M-CIDI = Munich-Composite International Diagnostic Interview; n = number; NIAAA = National Institute on Alcohol Abuse and Alcoholism; NSDUH = National Survey on Drug Use and Health; PESQ-PS = Personal Experience Screening Questionnaire; SDS = Severity of Dependence Scale

Frequency-based screening tools. Two studies evaluated a single-item cannabis-frequency question,^52,^ ^66^ and one study^42^ examined the BSTAD to detect any cannabis use or a cannabis use disorder (Figure 2). The single item about cannabis-use frequency in the previous 12 months was found to have a sensitivity of 0.72 and 0.79 (95% CI range, 0.52 to 0.91) and specificity of 1.00 and 0.99 (95% CI range, 0.94 to 1.00) in detecting any cannabis use for self-administered and interviewer-administered versions, respectively. To detect cannabis use disorder, sensitivity ranged from 0.86 to 0.96 (95% CI range, 0.41 to 0.98) and specificity ranged from 0.86 to 0.93 (95% CI range, 0.82 to 0.96). Similarly, the BSTAD at a cutoff of 2 or more had a sensitivity of 0.80 (95% CI, 0.69 to 0.89) and specificity of 0.93 (95% CI, 0.91 to 0.95) for detecting a cannabis use disorder.

Risk assessment screening tools. Ten studies evaluated nine different risk-assessment screening tools among adolescents (Figure 3 and Figure 4).^46,^ ^52,^ ^54,^ ^56,^ ^57,^ ^59,^ ^60,^ ^64^ All of the studies evaluated the screening tool accuracy in detecting cannabis use or alcohol or drug use. The sensitivity and specificity for detecting any cannabis use of the CRAFFT (0.68 [95% CI, 0.64 to 0.72] and 0.92 [95% CI, 0.90 to 0.94] and PESQ-PS (0.72 [95% CI, 0.68 to 0.75] and 0.93 [95% CI, 0.91 to 0.94] were similar to estimates for the single-item cannabis frequency question. For detecting unhealthy cannabis use, sensitivity ranged from 0.84 to 0.98 [95% CI range, 0.79 to 0.99] and specificity ranged from 0.82 to 0.91 [95% CI range, 0.80 to 0.94] among three different instruments (ASSIST, CRAFFT, and PESQ-PS) (Figure 3). Sensitivity and specificity was similar for the CRAFFT in detecting unhealthy use of drugs or alcohol. More studies evaluated the ability of these tools, using the same cut-points, to detect a cannabis use disorder or dependence. Across nine different screening instruments, the ASSIST, ASSIST-Lite, and PESQ-PS had the best sensitivity in detecting a cannabis use disorder (≥0.90) whereas the CRAFFT, POSIT, and POSIT revised had the highest specificity (≥0.90).

Indirect screening tools. Two studies^64,^ ^66^ evaluated the accuracy of three different alcohol screening instruments—the AUDIT, AUDIT-C, and NIAAA Youth Screen—to identify cannabis use and unhealthy cannabis use. Sensitivity was much lower for these instruments than in the frequency-based and risk assessment screeners, ranging from 0.20 to 0.70 (95% CI range, 0.17 to 0.80); specificity was comparable, ranging from 0.82 to 0.99 (95% CI, 0.78 to 0.99).

Differences by subpopulations. Three studies examined differences in the accuracy of the CRAFFT^46,^ ^56,^ ^67^ and one study in the accuracy of the POSIT between males and females.^67^ For the detection of alcohol or drug dependence, use disorder, and unhealthy use, the CRAFFT and POSIT both generally performed better for males than females with an increased or equivalent sensitivity. However, the confidence intervals for both groups overlapped, indicating there could be no difference between the groups.

One study^67,^ ^77^ examined differences by age (12–14, 15–16, and 17–18 years) in the accuracy of the CRAFFT and POSIT to detect substance use disorder. Accuracy for both the CRAFFT and POSIT were similar across adolescent age groups.

#### Adults

##### Study and Population Characteristics

We included 12 studies (n=49,961), six of them good quality and the others fair quality, that evaluated the accuracy of 15 different screening tools to detect drug use or drug use problems in non-pregnant adults (Table 3).^43,^ ^45,^ ^48–51,^ ^55,^ ^61,^ ^62,^ ^65,^ ^68^ There were considerable differences among the studies in terms of the populations, screening tools, and target conditions. All but two of the studies took place in the United States; the remaining studies^55,^ ^68^ recruited previous-year cannabis users in France. Among the studies in the United States, most recruited participants directly within primary care; however, one study recruited participants from an emergency department,^65^ one study used data from a representative sample of U.S. adults (n=42,923),^61^ and another recruited adults (n=139) who were seeking evaluation for attention-deficit/hyperactivity disorder (ADHD) at a specialty clinic.^49^ One study^44^ recruited participants from primary care clinics within a U.S. Department of Veterans Affairs health care system; the majority of participants in this study were male (95.3%), with a mean age of 63 years. Another study^62^ focused specifically on caregivers of children <6 years and included mostly females (94%). For the remaining studies, the proportion of female participants ranged from 30.9 to 67.9 percent. Excluding the large U.S.-based national sample (n=42,923), sample sizes ranged from 139 to 2057. Within the eight studies that reported the race and ethnicity of participants, the percent of nonwhite participants ranged from 4.3 percent to 82.9 percent; the majority of nonwhite participants was black. Most participants in the studies had a high school education or higher.

Three studies^43–45^ reported the prevalence of unhealthy drug use ranging from 14.2 percent to 37.9 percent; three studies^43,^ ^50,^ ^65^ reported the prevalence of unhealthy drug use for specific drugs ranging from 2 percent (for unhealthy use of prescription sedatives) to 38.4 percent (for unhealthy prescription opioid use). Any previous-year drug use, as reported in three studies,^43,^ ^45,^ ^61^ ranged from 5.7 percent (in the large, nationally representative sample^61^) to 40.4 percent (in primarily black primary care patients^45^). In six studies,^43–45,^ ^49,^ ^61,^ ^62^ any drug use disorder ranged from 1.8 to 16.7 percent (dependence ranged from 0.6 percent^61^ for dependence of any drug to 12.6^55^ percent for cannabis specifically in three studies). Two studies^55,^ ^68^ including adolescents and adults aged 15–64 years who had used cannabis in the previous year had a much higher prevalence of cannabis use disorder at 28.9 percent and 34.1 percent. One study,^65^ including adults 50 years or older recruited from an emergency department and using prescription drugs, reported a prevalence of prescription drug use disorder of 58.9 percent (16.1 percent with moderate-severe use disorder).

We included tool accuracy measures for four target conditions across the 12 studies—any drug use (4 studies),^45,^ ^51,^ ^61,^ ^70^ unhealthy drug use (variably defined as any drug use, heavy use, problem use, and/or drug use disorders) 5 studies),^43–45,^ ^50,^ ^65,^ ^70^ drug use disorders (all 12 studies), and dependence alone (6 studies).^45,^ ^51,^ ^55,^ ^61,^ ^65,^ ^68^ To determine the target conditions of drug use disorder or dependence, all 12 studies used a structured diagnostic interview such as the CIDI or MINI-Plus. Reference standards for the target conditions of unhealthy use or any use often included oral fluid tests or the Timeline Followback method (to identify current use) as well as the structured interview. Three studies also used other questionnaires, usually combined with the structured interview, as reference standards—the Short Inventory of Problems-Alcohol and Drugs, the ASSIST, and the Inventory of Drug Use Consequences.

Consistent with the included evidence for adolescents, screening tools addressed only the frequency of drug use (single-item drug frequency, SUBS, TAPS-1), frequency of drug use along with further risk assessment (ASSIST, ASSIST-Drug, CAST, DAST-2, DAST-10, DAST-28, PDUQp, PSQ, SoDU, TAPS, TICS), or indirect questions (single-item HED frequency) (Table 4). Most of the drug-specific screeners addressed any drug use with or without questions related to alcohol or tobacco use, but four screeners only asked about cannabis use (single-item cannabis frequency, CAST, ASSIST-Lite Cannabis, CPQ-A-S), one screener asked only about prescription drug use (PDUQp), and five screeners queried participants on their use of specific types of drugs (ASSIST-2, BSTAD, ASSIST, SUBS, TAPS). Five studies had an interviewer administer the screening tool (s) in person,^44,^ ^45,^ ^48,^ ^49,^ ^61^ four studies had participants self-administer the screening tool (s) electronically,^43,^ ^51,^ ^62,^ ^65^ and two studies had an interviewer administer the screening tool over the phone.^55,^ ^68^ One study^50^ evaluated both interviewer- and self-administered versions of the same screening tool.

##### Detailed Results: Tool Accuracy

Results related to the sensitivity and specificity and corresponding 95% confidence intervals for all screening tools and target conditions among adults are presented in Table 6.

Table 6 Results of Screening Accuracy Studies Among Adults (KQ 2), by Tool Type and Specific Tool

Tool type | Tool name | Tool cutoff^*^ | Author, year | Reference standard | Condition | Condition, % | Total n | Sensitivity (95% CI) | Specificity (95% CI) | AUC (95% CI)
Frequency-based | Single-item drug frequency | 1+ | McNeely, 2015^43^ | TLFB, Oral fluid | Drug use in past month | 14.2 | 459 | 0.726 (0.609, 0.824) | 0.860 (0.821, 0.893) | 0.79 (0.74, 0.85)
Frequency-based | Single-item drug frequency | 1+ | Smith, 2010^45^ | CIDI | Drug use in past year | 34.6 | 286 | 0.929 (0.861, 0.965) | 0.941 (0.898, 0.967) | 0.93 (NR)
Frequency-based | Single-item drug frequency | 1+ | Smith, 2010^45^ | CIDI, Oral Fluid | Drug use in past year | 40.4 | 217 | 0.847 (0.756, 0.908) | 0.962 (0.914, 0.984) | 0.92 (NR)
Frequency-based | Single-item drug frequency | 1+ | McNeely, 2015^43,^ ^70^ | MINI Plus, SIP | Drug unhealthy use^†^ | 14.2 | 459 | 0.846 (0.735, 0.924) | 0.870 (0.833, 0.902) | 0.86 (0.81, 0.91)
Frequency-based | Single-item drug frequency | 1+ | McNeely, 2015^43,^ ^70^ | MINI Plus, SIP, TLFB, Oral Fluid^§^ | Drug unhealthy use^‡^ | 26.7 | 459 | 0.713 (0.624, 0.791) | 0.943 (0.913, 0.966) | 0.83 (0.79, 0.87)
Frequency-based | Single-item drug frequency | 1+ | Smith, 2010^45^ | CIDI, SIP-DU | Drug unhealthy use^ǁ^ | 32.2 | 286 | 0.935 (0.865, 0.970) | 0.912 (0.864, 0.945) | 0.90 (NR)
Frequency-based | Single-item drug frequency | 1+ | Smith, 2010^45^ | CIDI, Oral Fluid, SIP-DU | Drug unhealthy use^¶^ | 37.9 | 217 | 0.85 (0.75, 0.91) | 0.93 (0.87, 0.96) | 0.89 (NR)
Frequency-based | Single-item drug frequency | 1+ | McNeely, 2015^43,^ ^70^ | MINI Plus | Drug abuse or dependence | 16.1 | 459 | 0.851 (0.750, 0.923) | 0.886 (0.850, 0.916) | 0.87 (0.83, 0.91)
Frequency-based | Single-item drug frequency | 1+ | Smith, 2010^45^ | CIDI | Drug abuse or dependence | 12.9 | 286 | 1.00 (0.906, 1.00) | 0.735 (0.677, 0.786) | NR
Frequency-based | Single-item drug frequency | 1+ | Smith, 2010^45^ | CIDI | Drug dependence | 12 | 286 | 0.97 (0.85, 0.999) | 0.79 (0.73, 0.84) | 0.93 (NR)
Frequency-based | SUBS | 1+ | McNeely, 2015^43^ | MINI-Plus, ASSIST, TLFB, Oral Fluid^§^ | Drug unhealthy use^#^ | 27.3 | 586 | 0.825 (0.757, 0.880) | 0.911 (0.879, 0.936) | 0.87 (0.84, 0.90)
Frequency-based | SUBS | 1+ | McNeely, 2015^43^ | MINI-Plus, ASSIST, TLFB, Oral Fluid^§^ | Illicit drug unhealthy use^**^ | 25.3 | 586 | 0.811 (0.738, 0.870) | 0.970 (0.949, 0.984) | 0.89 (0.86, 0.92)
Frequency-based | SUBS | 1+ | McNeely, 2015^43^ | MINI Plus, ASSIST, TLFB, Oral Fluid^§^ | Prescription drug unhealthy use^**^ | 9.2 | 586 | 0.556 (0.414, 0.691) | 0.916 (0.889, 0.938) | 0.74 (0.67, 0.80)
Frequency-based | SUBS | 1+ | McNeely, 2015^43^ | MINI Plus | Drug abuse or dependence | 16.7 | 586 | 0.857 (0.772, 0.920) | 0.820 (0.782, 0.853) | 0.84 (0.80, 0.88)
Frequency-based | SUBS | 1+ | McNeely, 2015^43^ | MINI Plus | Illicit drug abuse or dependence | 16.2 | 586 | 0.821 (0.729, 0.892) | 0.888 (0.856, 0.914) | 0.85 (0.81, 0.90)
Frequency-based | SUBS | 1+ | McNeely, 2015^43^ | MINI Plus | Prescription drug abuse or dependence | 4.6 | 586 | 0.593 (0.388, 0.776) | 0.892 (0.863, 0.916) | 0.74 (0.65, 0.84)
Frequency-based | TAPS-1 | 1+/year | McNeely, 2016^50,^ ^74^ | CIDI | Illicit drug problem use or higher^††^ | 17.0 | 1997 | 0.91 (0.87, 0.94) | 0.89 (0.87, 0.90) | 0.90 (NR)
Frequency-based | TAPS-1 | 1+/year | McNeely, 2016^50,^ ^74^ | CIDI | Illicit drug use disorder | 13.0 | 1997 | 0.93 (0.89, 0.96) | 0.85 (0.83, 0.87) | 0.89 (NR)
Frequency-based | TAPS-1 | 1+/year | McNeely, 2016^50,^ ^74^ | CIDI | Illicit drug moderate-severe use disorder | 9.0 | 1997 | 0.95 (0.91, 0.97) | 0.83 (0.81, 0.85) | 0.89 (NR)
Frequency-based | TAPS-1 | 1+/year | McNeely, 2016^50,^ ^74^ | CIDI | Prescription drug use problem use or higher^††^ | 5.0 | 1995 | 0.85 (0.76, 0.91) | 0.91 (0.90, 0.92) | 0.88 (NR)
Frequency-based | TAPS-1 | 1+/year | McNeely, 2016^50,^ ^74^ | CIDI | Prescription drug use disorder | 4.0 | 1995 | 0.89 (0.79, 0.94) | 0.91 (0.90, 0.92) | 0.90 (NR)
Frequency-based | TAPS-1 | 1+/year | McNeely, 2016^50,^ ^74^ | CIDI | Prescription drug use moderate-severe disorder | 2.0 | 1995 | 0.96 (0.85, 0.99) | 0.90 (0.89, 0.91) | 0.93 (NR)
Risk assessment | ASSIST | 2+ | Kumar, 2016^51^ | MINI Plus | Cannabis use in past yea | 14.0 | 399 | 0.946 (0.851, 0.989) | 0.816 (0.771, 0.856) | 0.83 (NR)
Risk assessment | ASSIST | 2+ | Kumar, 2016^51^ | MINI Plus | Cocaine use in past year | 9.0 | 399 | 0.861 (0.705, 0.953) | 0.840 (0.798, 0.876) | 0.85 (NR)
Risk assessment | ASSIST | 4+ | Kumar, 2016^51^ | MINI Plus | Cannabis abuse or dependence | 7.3 | 399 | 0.828 (0.642, 0.942) | 0.832 (0.790, 0.874) | 0.83 (NR)
Risk assessment | ASSIST | 4+ | Kumar, 2016^51^ | MINI Plus | Cocaine abuse or dependence | 7.3 | 399 | 0.897 (0.726, 0.978) | 0.868 (0.829, 0.900) | 0.88 (NR)
Risk assessment | ASSIST-Drug | 2+ days (Q1) and/or 5+ days (Q2) | Tiet, 2015^44,^ ^72^ | InDUC | Drug unhealthy use^‡‡^ | 15.8 | 640 | 0.901 (0.827, 0.945) | 0.924 (0.898, 0.943) | 0.91 (NR)
Risk assessment | ASSIST-Drug | 2+ days (Q1) and/or 5+ days (Q2) | Tiet, 2015^44,^ ^72^ | MINI | Drug abuse or dependence | 10.2 | 640 | 0.954 (0.873, 0.984) | 0.878 (0.849, 0.903) | 0.92 (NR)
Risk assessment | CAST | 3+ | Legleye, 2015^55^ | M-CIDI | Cannabis abuse or dependence | 28.9 | 550 | 0.805 (0.737, 0.859) | 0.749 (0.704, 0.790) | 0.851 (0.814, 0.887)
Risk assessment | CAST | 5+ | Legleye, 2018^68^ | M-CIDI | Cannabis moderate-severe use disorder | 16.0 | 1351 | 0.866 (0.81, 0.90) | 0.782 (0.76, 0.81) | 0.91 (0.89, 0.93)
Risk assessment | CAST | 5+ | Legleye, 2015^55,**^ | M-CIDI | Cannabis dependence | 12.6 | 550 | 0.812 (0.704, 0.886 | 0.790 (0.73, 0.84) | 0.868 (0.823, 0.913)
Risk assessment | CAST | 8+ | Legleye, 2018^68^ | M-CIDI | Cannabis severe use disorder | 5.5 | 1351 | 0.86 (0.77, 0.92) | 0.867 (0.85, 0.88) | 0.94 (0.92, 0.96)
Risk assessment | DAST-2 | 1+ day/year | Tiet, 2015^44,^ ^72,^ ^75^ | InDUC | Drug unhealthy use^‡‡^ | 15.8 | 640 | 0.921 (0.851, 0.959) | 0.934 (0.911, 0.953) | 0.93 (NR)
Risk assessment | DAST-2 | 1+ day/year | Tiet, 2015^44,^ ^72,^ ^75^ | MINI | Drug abuse or dependence | 10.2 | 640 | 0.954 (0.873, 0.984) | 0.885 (0.857, 0.909) | 0.92 (NR)
Risk assessment | DAST-10 | 3+ | Smith, 2010^45^ | CIDI | Drug use in past year | 34.6 | 286 | 0.828 (0.742, 0.890) | 0.936 (0.891, 0.963) | 0.89 (NR)
Risk assessment | DAST-10 | 3+ | Smith, 2010^45^ | CIDI, Oral Fluid | Drug use in past year | 40.4 | 217 | 0.800 (0.703, 0.871) | 0.939 (0.885, 0.969) | 0.89 (NR)
Risk assessment | DAST-10 | 3+ | Smith, 2010^45^ | CIDI, SIP-DU | Drug unhealthy use^§§^ | 32.2 | 286 | 0.870 (0.786, 0.924) | 0.928 (0.885, 0.969) | 0.88 (NR)
Risk assessment | DAST-10 | 3+ | Smith, 2010^45^ | CIDI, Oral Fluid, SIP-DU | Drug unhealthy use^¶^ | 37.9 | 217 | 0.835 (0.738, 0.901) | 0.928 (0.872, 0.960) | NR
Risk assessment | DAST-10 | 3+ | Smith, 2010^45^ | CIDI | Drug abuse or dependence | 12.9 | 286 | 1.0 (0.906, 1.0) | 0.771 (0.715, 0.819) | NR
Risk assessment | DAST-10 | 4+ | Smith, 2010^45^ | CIDI | Drug dependence | 12 | 286 | 1.0 (0.90, 1.0) | 0.84 (0.79, 0.88) | 0.96 (NR)
Risk assessment | DAST-28 | 5+ | McCann, 2000^49^ | Structured clinical interview | Drug abuse or dependence | 9.4 | 139 | 0.92 (0.667, 0.986) | 0.67 (0.58, 0.74) | NR
Risk assessment | PDUQp | 10 | Beaudoin, 2016^65^ | NESARC | Prescription opioid unhealthy use^ǁǁ^ | 38.4 | 112 | 0.442 (0.350, 0.533) | 0.786 (0.710, 0.861) | 0.61 (0.49, 0.72)
Risk assessment | PDUQp | 10 | Beaudoin, 2016^65^ | AUDADIS | Prescription opioid use disorder | 58.9 | 112 | 0.379 (0.289, 0.468) | 0.809 (0.736, 0.881) | 0.64 (0.53, 0.74)
Risk assessment | PDUQp | 10 | Beaudoin, 2016^65^ | AUDADIS | Prescription opioid moderate-severe use disorder | 16.1 | 112 | 0.556 (0.464, 0.647) | 0.747 (0.667, 0.828) | 0.71 (0.56, 0.86)
Risk assessment | PSQ | NA^¶¶^ | Lane, 2007^62^ | CIDI | Drug abuse | 3.2 | 216 | 0.29 (0.082, 0.641) | 0.95 (0.91, 0.97) | NR
Risk assessment | PSQ | NA^¶¶^ | Lane, 2007^62^ | CIDI | Alcohol or drug abuse | 15.7 | 216 | 0.15 (0.064, 0.301) | 0.96 (0.92, 0.98) | NR
Risk assessment | SoDU | 7+ (Q1), 2+ (Q2) | Tiet, 2015^44,^ ^72^ | MINI | Drug abuse or dependence | 10.2 | 640 | 0.9231 (0.8322, 0.9667) | 0.9287 (0.9047, 0.9470) | 0.93 (NR)
Risk assessment | SoDU | 7+ (Q1), 2+ (Q2) | Tiet, 2015^44,^ ^72^ | InDUC | Drug unhealthy use^‡‡^ | 15.8 | 640 | 0.8317 (0.7569, 0.8922) | 0.9685 (0.9501, 0.9802) | 0.90 (NR)
Risk assessment | TAPS (self-administered) | 1+ | McNeely, 2016^50^ | CIDI | Cannabis unhealthy use^##^ | 11.6 | 1997 | 0.79 (0.73, 0.84) | 0.93 (0.91, 0.94) | NR
Risk assessment | TAPS (interviewer-administered) | 1+ | McNeely, 2016^50^ | CIDI | Cannabis unhealthy use^##^ | 11.6 | 1996 | 0.82 (0.76, 0.87) | 0.93 (0.91, 0.94) | NR
Risk assessment | TAPS (self-administered) | 1+ | McNeely, 2016^50^ | CIDI | Cocaine or methamphetamine unhealthy use^##^ | 6.0 | 1996 | 0.73 (0.64, 0.80) | 0.99 (0.98, 0.99) | NR
Risk assessment | TAPS (interviewer-administered) | 1+ | McNeely, 2016^50^ | CIDI | Cocaine or methamphetamine unhealthy use^##^ | 6.0 | 1995 | 0.68 (0.59, 0.77) | 0.99 (0.98, 0.99) | NR
Risk assessment | TAPS (self-administered) | 1+ | McNeely, 2016^50^ | CIDI | Heroin unhealthy use^##^ | 3.4 | 1995 | 0.77 (0.65, 0.86) | 1.00 (0.99, 1.00) | NR
Risk assessment | TAPS (interviewer-administered) | 1+ | McNeely, 2016^50^ | CIDI | Heroin unhealthy use^##^ | 3.4 | 1994 | 0.78 (0.67, 0.87) | 1.00 (0.99, 1.00) | NR
Risk assessment | TAPS (self-administered) | 1+ | McNeely, 2016^50^ | CIDI | Prescription opioid unhealthy use^##^ | 3.0 | 1995 | 0.61 (0.47, 0.73) | 0.98 (0.97, 0.98) | NR
Risk assessment | TAPS (interviewer-administered) | 1+ | McNeely, 2016^50^ | CIDI | Prescription opioid unhealthy use^##^ | 3.0 | 1995 | 0.71 (0.58, 0.82) | 0.99 (0.98, 0.99) | NR
Risk assessment | TAPS (self-administered) | 1+ | McNeely, 2016^50^ | CIDI | Prescription sedative unhealthy use^##^ | 2.0 | 1995 | 0.66 (0.49, 0.80) | 0.97 (0.96, 0.98) | NR
Risk assessment | TAPS (interviewer-administered) | 1+ | McNeely, 2016^50^ | CIDI | Prescription sedative unhealthy use^##^ | 2.0 | 1995 | 0.63 (0.47, 0.78) | 0.99 (0.98, 0.99) | NR
Risk assessment | TAPS (self-administered) | 2+ | McNeely, 2016^50^ | CIDI | Cannabis use disorder | 7.4 | 1997 | 0.70 (0.62, 0.77) | 0.95 (0.94, 0.96) | NR
Risk assessment | TAPS (interviewer-administered) | 2+ | McNeely, 2016^50^ | CIDI | Cannabis use disorder | 7.4 | 1997 | 0.71 (0.63, 0.79) | 0.95 (0.94, 0.96) | NR
Risk assessment | TAPS (self-administered) | 2+ | McNeely, 2016^50^ | CIDI | Cocaine or methamphetamine use disorder | 5.4 | 1996 | 0.60 (0.50, 0.69) | 0.99 (0.99, 0.99) | NR
Risk assessment | TAPS (interviewer-administered) | 2+ | McNeely, 2016^50^ | CIDI | Cocaine or methamphetamine use disorder | 5.4 | 1996 | 0.57 (0.47, 0.67) | 0.99 (0.99, 1.00) | NR
Risk assessment | TAPS (self-administered) | 2+ | McNeely, 2016^50^ | CIDI | Heroin use disorder | 3.2 | 1995 | 0.66 (0.53, 0.77) | 1.00 (0.99, 1.00) | NR
Risk assessment | TAPS (interviewer-administered) | 2+ | McNeely, 2016^50^ | CIDI | Heroin use disorder | 3.2 | 1995 | 0.66 (0.53, 0.77) | 1.00 (1.00, 1.00) | NR
Risk assessment | TAPS (self-administered) | 2+ | McNeely, 2016^50^ | CIDI | Prescription opioid use disorder | 2.4 | 1995 | 0.48 (0.33, 0.63) | 0.99 (0.98, 0.99) | NR
Risk assessment | TAPS(interviewer-administered) | 2+ | McNeely, 2016^50^ | CIDI | Prescription opioid use disorder | 2.4 | 1995 | 0.48 (0.33, 0.63) | 1.00 (0.99, 1.00) | NR
Risk assessment | TAPS (self-administered) | 2+ | McNeely, 2016^50^ | CIDI | Prescription sedative use disorder | 1.4 | 1995 | 0.54 (0.34, 0.72) | 0.98 (0.97, 0.99) | NR
Risk assessment | TAPS (interviewer-administered) | 2+ | McNeely, 2016^50^ | CIDI | Prescription sedative use disorder | 1.4 | 1995 | 0.54 (0.34, 0.72) | 0.99 (0.98, 0.99) | NR
Risk assessment | TICS | NA^***^ | Brown, 2001^48^ | CIDI | Alcohol or drug abuse or dependence^†††^ | 21.4 | 702 | 0.780 (0.707, 0.839) | 0.763 (0.73, 0.80) | NR
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Drug use in past year | 5.7 | 42923 | 0.633 (0.614, 0.652) | 0.789 (0.785, 0.793) | 0.799 (NR)
Indirect | Single-item alcohol HED | 1+ | Smith, 2010^45,^ ^69,^ ^73^ | CIDI, Oral Fluid | Drug use in past year | 40.4 | 217 | 0.588 (0.476, 0.694) | 0.803 (0.725, 0.867) | 0.70 (NR)
Indirect | Single-item alcohol HED | 1+ | Smith, 2010^45,^ ^69,^ ^73^ | CIDI | Drug use in past year | 34.6 | 286 | 0.626 (0.523, 0.722) | 0.727 (0.658, 0.790) | 0.67 (NR)
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Cannabis use in past year | 3.8 | 42923 | 0.727 (0.704, 0.748) | 0.784 (0.780, 0.788) | 0.839 (NR)
Indirect | Single-item alcohol HED | 7+ | Dawson, 2010^61^ | NESARC | Cocaine use in past year | 0.5 | 42923 | 0.776 (0.714, 0.825) | 0.845 (0.842, 0.848) | 0.893 (NR)
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Prescription drug use in past year | 2.9 | 42923 | 0.565 (0.537, 0.593) | 0.774 (0.77, 0.778) | 0.748 (NR)
Indirect | Single-item alcohol HED | 1+ | Smith, 2010^45,^ ^69^ | CIDI, SIP-DU | Drug unhealthy use^ǁ^ | 32.2 | 286 | 0.602 (0.501, 0.697) | 0.721 (0.650, 0.785) | 0.66 (NR)
Indirect | Single-item alcohol HED | 1+ | Smith, 2010^45,^ ^69^ | CIDI, Oral Fluid, SIP-DU | Drug unhealthy use^¶^ | 37.9 | 217 | 0.608 (0.491, 0.716) | 0.797 (0.720, 0.861) | NR
Indirect | Single-item alcohol HED | 1+ | Smith, 2010^45^ | CIDI | Drug abuse or dependence | 12.9 | 286 | 0.676 (0.502, 0.820) | 0.647 (0.584, 0.706) | 0.58 (NR)
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Drug abuse or dependence | 1.8 | 42923 | 0.719 (0.686, 0.749) | 0.773 (0.769, 0.777) | 0.833 (NR)
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Cannabis abuse or dependence | 1.3 | 42923 | 0.770 (0.734, 0.804) | 0.771 (0.767, 0.775) | 0.854 (NR)
Indirect | Single-item alcohol HED | 7+ | Dawson, 2010^61^ | NESARC | Cocaine abuse or dependence | 0.2 | 42923 | 0.760 (0.669, 0.836) | 0.843 (0.84, 0.846) | 0.897 (NR)
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Prescription drug abuse or dependence | 0.5 | 42923 | 0.601 (0.539, 0.663) | 0.765 (0.761, 0.769) | 0.766 (NR)
Indirect | Single-item alcohol HED | 1+ | Smith, 2010^45,^ ^69,^ ^73^ | CIDI | Drug dependence | 12 | 286 | 0.676 (0.495, 0.826) | 0.643 (0.580, 0.702) | 0.57 (NR)
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Drug dependence | 0.6 | 42923 | 0.724 (0.667, 0.778) | 0.766 (0.762, 0.77) | 0.826 (NR)
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Cannabis dependence | 0.3 | 42923 | 0.783 (0.702, 0.842) | 0.765 (0.76, 0.77) | 0.851 (NR)
Indirect | Single-item alcohol HED | 12+ | Dawson, 2010^61^ | NESARC | Cocaine dependence | 0.1 | 42923 | 0.760 (0.619, 0.854) | 0.860 (0.857, 0.863) | 0.887 (NR)
Indirect | Single-item alcohol HED | 1+ | Dawson, 2010^61^ | NESARC | Prescription drug dependence | 0.2 | 42923 | 0.603 (0.498, 0.698) | 0.764 (0.760, 0.768) | 0.764 (NR)

* Study-reported or systematic reviewer-determined optimal cutoff

† Any drug use in past 30 days with self-reported consequence of use

‡ Any drug use in past 30 days with or without self-reported consequence of use, or DSM-IV abuse or dependence

§ Oral fluid testing only for participants at New York site

ǁ Past 12-month use and ≥1 positive response on the SIP-DU or DSM-IV drug abuse or dependence

¶ Past 12-month use confirmed through oral fluid testing and ≥1 positive response on the SIP-DU or DSM-IV drug abuse or dependence

# Any use of an illicit drug or nonmedical use of a prescription drug (TLFB, oral fluid), moderate- or high-risk use (ASSIST), or a positive response on unhealthy drug use (MINI question J1)

** Any illicit or nonmedical use of a prescription drug (TLFB, oral fluid), moderate- or high-risk use (ASSIST), or a positive response on unhealthy drug use (MINI question J1)

†† 1+ DSM-5 criterion

‡‡ Negative consequences of drug use in past 12 months

§§ Past 12-month use and ≥1 positive response on the SIP-DU or DSM-IV drug abuse or dependence

ǁǁ Defined as the use of prescription opioids outside of their prescribed indications (i.e., pain), self-escalating doses of these medications, or giving to or receiving prescription opioid medications from others within the past 30 days.

¶¶ Positive response to either question

## Any DSM-5 criterion

*** Positive response to either question

††† DSM-III-R abuse or dependence

Abbreviations: ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; AUC = area under the curve; CAST = Cannabis Abuse Screening Test; CI = confidence interval; CIDI = Composite International Diagnostic Interview; DAST-10 = 10-Item Drug-Abuse Screening Test; DAST-28 = 28-Item Drug-Abuse Screening Test; DSM = Diagnostic and Statistical Manual of Mental Disorders; HED = heavy episodic drinking; InDUC = Inventory of Drug Use Consequences; MINI = Multi International Neuropsychiatric Interview-plus; n = number; NESARC = National Epidemiologic Survey on Alcohol and Related Conditions; PDUQp = Prescription Drug Use Questionnaire, patient version; PSQ = Parent Screening Questionnaire; SIP-DU = The Short Inventory of Problems—Modified for Drug Use; SoDU = Screen of Drug Use; SUBS = Substance Use Brief Screen; TAPS = Tobacco, Alcohol, Prescription Medication, and Other Substance Use; TICS = Two-Item Conjoint Screen; TLFB = Timeline Followback

Frequency-based screening tools. Three studies^43,^ ^45,^ ^50,^ ^70,^ ^74^ examined the accuracy of a single-item drug-frequency question, one study^43^ examined the SUBS, and one study examined the TAPS-1.^50,^ ^74^ (Figure 5 and Figure 6). Two studies^43,^ ^45,^ ^70^ reported tool accuracy for any drug use and unhealthy drug use with sensitivity ranging from 0.71 to 0.94 (95% CI range, 0.61 to 0.97) and specificity ranging from 0.86 to 0.96 (95% CI range, 0.82 to 0.98). These two studies examined the accuracy of the single-item frequency question when using a structured clinical interview only and the interview plus biologic confirmation as the reference standard to identify any drug use and unhealthy use of any drugs. Both studies found that sensitivity was lower and specificity higher when compared with the reference standard including biologic confirmation of use versus the diagnostic interview alone, although confidence intervals overlapped. For any drug use disorder and any drug dependence, sensitivity ranged from 0.85 to 1.0 (95% CI range, 0.75 to 1.0) and specificity ranged from 0.74 to 0.89 (95% CI range, 0.68 to 0.92).

Two studies^43,^ ^50,^ ^74^ also reported the accuracy of the SUBS and the TAPS-1 in identifying unhealthy use and use disorder of prescription drugs and illicit drugs. To identify unhealthy use of prescription drugs, sensitivity ranged from 0.56 to 0.85 (95% CI range, 0.41 to 0.99) and specificity ranged from 0.91 to 0.92 (95% CI range, 0.89 to 0.94). Tools that aimed to identify prescription drug use disorder had similar performance, with sensitivity ranging from 0.59 to 0.89 (95 % CI range, 0.39 to 0.94) and specificity ranging from 0.89 to 0.91 (95% CI range, 0.86 to 0.92). The sensitivity for the SUBS and TAPS-1 in identifying unhealthy use and use disorder of illicit drugs was higher than prescription drugs, but the specificity was similar.

Risk assessment screening tools. Nine studies^44,^ ^45,^ ^49–51,^ ^55,^ ^62,^ ^65,^ ^68,^ ^75^ evaluated 11 screening tools that included risk assessment: ASSIST, ASSIST-Drug, CAST, DAST-2, DAST-10, DAST-28, PDUQp, PSQ, SoDU, TAPS, and TICS (Figure 7). For any drug use and unhealthy use of any drugs, sensitivity ranged from 0.80 to 0.92 (95% CI range, 0.70 to 0.96) and specificity ranged from 0.92 to 0.97 (95% CI range, 0.87 to 0.98). For any drug use disorder and dependence, sensitivity ranged from 0.92 to 1.0 (95% CI range, 0.67 to 1.0) and specificity ranged from 0.67 to 0.93 (95% CI range, 0.58 to 0.96). One notable exception was the PSQ that includes two questions to assess drug and alcohol use for both the respondent and their partner, which had a sensitivity of 0.29 (95% CI, 0.08 to 0.64) (specificity of 0.95 [95% CI, 0.91 to 0.97]) to identify any drug use disorder.^62^

The accuracy for detecting use, unhealthy use, or use disorders of specific drugs (cannabis, cocaine, cocaine or methamphetamine, heroin, prescription opioid, prescription sedative) was reported for four screening tools—the ASSIST, CAST, PDUQp, and TAPS (Figure 8). Sensitivity to detect any use or unhealthy use ranged from 0.44 to 0.95 (95% CI range, 0.35 to 0.99) and specificity ranged from 0.79 to 1.0 (95% CI range, 0.71 to 1.0). Sensitivity and specificity was generally higher for detecting unhealthy use of cannabis than in detecting unhealthy use of cocaine, heroin, or prescription medications, although 95% confidence intervals overlapped for all estimates. Sensitivity was the lowest for the detection of unhealthy prescription opioids (0.44 to 0.71) and prescription sedatives (0.63 to 0.66); specificity was comparable with other substances (0.79 to 0.99). For use disorder and dependence, sensitivity ranged from 0.38 to 0.90 (95% CI range, 0.29 to 0.94) and specificity ranged from 0.75 to 1.00 (95% CI range, 0.70 to 1.00). Again, the lower sensitivity values were from the PDUQp and TAPS screening tools for prescription opioid and prescription sedative-use disorders.

Indirect screening tools. Two studies^45,^ ^61,^ ^73^ evaluated a single-item question assessing heavy episodic drinking to identify unhealthy drug use or use disorders. For detecting any drug use and unhealthy drug use, sensitivity ranged from 0.59 to 0.63 (95% CI range, 0.48 to 0.72) and specificity ranged from 0.72 to 0.80 (95% CI range, 0.65 to 0.87. For detecting any drug use disorder and dependence, sensitivity ranged from 0.68 to 0.72 (95% CI range, 0.50 to 0.82) and specificity ranged from 0.65 to 0.77 (95% CI range, 0.58 to 0.78). Sensitivity was highest for cannabis use (sensitivity ranging from 0.73 to 0.78 [95% CI range, 0.70 to 0.84] and specificity ranging from 0.77 to 0.78 [95% CI range, 0.76 to 0.79]) and cocaine use (sensitivity ranging from 0.76 to 0.78 [95% CI range, 0.62 to 0.85] and specificity ranging from 0.84 to 0.86 [95% CI range, 0.84 to 0.86]), but lowest for prescription drugs (sensitivity ranging from 0.57 to 0.60 [95% CI range, 0.50 to .70], specificity ranging from 0.76 to 0.77 [95% CI range, 0.76 to 0.78).

Differences by subpopulations. One study examined prespecified differences by sex, education, age, and ethnicity in the accuracy of self-administered versions of the SUBS and a single-item drug-frequency question to detect unhealthy drug use.^43,^ ^70^ For both the SUBS and the single-item drug-frequency question, sensitivity was lower for females versus males, Hispanic versus non-Hispanic, those with less than a high school education versus those with a high school education or higher, and those age 21 to 50 years versus those age 51 to 65 years. However, the only statistically significant difference for SUBS was for sensitivity and specificity for males versus females.^43^ For the single-item drug-frequency question, sensitivity was statistically significantly lower among those with less than a high school education (0.63) versus those with a high school education or higher (0.79) (p<0.01); there was not a statistically significant difference in specificity between the two groups.^70^

One study^65^ examined differences in the accuracy of the PDUQp to detect unhealthy use and use disorders of prescription opioids for adults aged 50–64 and those aged 65 years or older. Sensitivity was much lower, and specificity was higher for adults 65 years or older versus those aged 50–64 years, with most of the confidence intervals not overlapping. However, the authors noted that adjusting the cutoff to 5 or 7 for adults 65 years or older could improve tool performance for screening purposes.

#### Pregnant and Postpartum Women

##### Study and Population Characteristics

We identified five studies (n=2429), one of them good quality^58^ and four of them fair quality,^15,^ ^47,^ ^53,^ ^63^ that evaluated the accuracy of drug screening instruments to detect any drug use or drug use disorders during pregnancy (Table 3). Three studies recruited women during pregnancy^47,^ ^53,^ ^63^ whereas the other two^15,^ ^58^ recruited women directly following delivery. These latter two studies^15,^ ^58^ were conducted by the same author group and had partially overlapping samples. Grekin et al.^15^ evaluated the accuracy of the DAST-10 in identifying last-trimester drug use among the full sample, whereas Ondersma et al.^58^ included these same women as their developmental sample for a new instrument (the WIDUS) and a separate sample of 100 women to cross-validate the accuracy of both the DAST-10 and WIDUS. We only included data from the cross-validation sample (n=100). Across the five studies, four took place in the United States and one was conducted in Hong Kong. Three of the studies targeted women with low SES, with either a Medicaid or Medicaid-managed plan for all women in the study^47^ or public assistance for the majority of women.^15,^ ^58^ In the U.S.-based samples, the majority of women were black.

The prevalence of any prenatal drug use was highly variable across the four studies that reported it, ranging from 1.2 percent (in the sample of women from Hong Kong^53^) to 41 percent using drugs in the last trimester of pregnancy (among a sample of low-income, majority black women).^58^ One study reported that 7 percent of pregnant women met diagnostic criteria for drug abuse, drug dependence, or both, primarily for cannabis use.^63^

The five studies evaluated the accuracy of five different instruments including the 4P’s Plus,^47^ a modified version of the first two questions of the ASSIST (hereafter called ASSIST-2),^58^ DAST-10,^15,^ ^53,^ ^58^ PRO,^63^ and WIDUS^58^ (Table 4). Only three of the instruments (the ASSIST-2, DAST-10, and PRO) directly screen for drug use and drug-related problems prior to pregnancy and/or during pregnancy. The 4P’s plus focuses on use of cigarettes and alcohol prior to knowing pregnancy status as well as whether their parents or partner ever had problems with alcohol or drugs and the WIDUS was designed as an indirect screener and asks about social issues (marital status), stress, depression, and cigarette use. Three studies^15,^ ^53,^ ^58^ relied on hair and/or urine analyses to confirm drug use (detection windows of 24–48 hours for urine analysis and 90 days for hair analysis) whereas the other two used structured clinical interviews.^47,^ ^63^

##### Detailed Results: Tool Accuracy

Results related to the sensitivity and specificity and corresponding 95% confidence intervals for all screening tools and target conditions among adults are presented in Table 7. In general, the sensitivity and specificity for detecting prenatal drug use or use disorders was much lower than what was seen in non-pregnant adults. The tools with the highest sensitivity—the PRO (0.89) and 4P’s Plus (0.87)—were the only tools that were not evaluated against a reference standard that included biologic confirmation, but rather were based on clinical interviews.

Table 7 Results of Screening Accuracy Studies Among Pregnant and Postpartum Women (KQ 2), by Tool Type and Specific Test

Tool type | Tool name | Tool cutoff^*^ | Author, year | Reference standard | Condition | Condition, % | Total n | Sensitivity (95% CI) | Specificity (95% CI)
Frequency-based | ASSIST-2 (modified)^‡^ | Any use | Ondersma, 2012^58^,^†^ | Hair and urine analyses | Any drug use during prenatal period | 41 | 100 | 0.41 (0.28, 0.57) | 0.83 (0.72, 0.91)
Risk assessment | DAST-10 | 1+ | Grekin, 2010^15^,^†^ | Hair and urine analyses | Any cannabis use during prenatal period | NR | 274 | 0.53 (NR^‡^) | 0.82 (NR^‡^)
Risk assessment | DAST-10 | 1+ | Grekin, 2010^15^,^†^ | Hair and urine analyses | Any drug use in the last trimester | 24 | 274 | 0.47 (0.35, 0.59) | 0.82 (0.76, 0.87)
Risk assessment | DAST-10 | 1+ | Ondersma, 2012^58^,^†^ | Hair and urine analyses | Any drug use during prenatal period | 41 | 100 | 0.37 (0.24, 0.52) | 0.83 (0.72, 0.91)
Risk assessment | DAST-10 | 1+ | Lam, 2015^53^,^§^ | Urinalysis | Any drug use in the last trimester | 1.2 | 1082 | 0.692 (0.424, 0.873) | 0.700 (0.672, 0.726)
Risk assessment | DAST-10 | 1+ | Grekin, 2010^15^,^†^ | Hair and urine analyses | Any noncannabis use during prenatal period | NR | 274 | 0.32 (NR^‡^) | 0.77 (NR^‡^)
Risk assessment | PRO | Mod+ | Harrison, 2012^63^,^§^ | SCID | Drug abuse or dependence | 7.0 | 745 | 0.885 (0.77, 0.946) | 0.743 (0.709, 0.774)
Risk assessment | WIDUS/ASSIST-2 (modified)^ǁ^ | 3+/Any use | Ondersma, 2012^58^,^†^ | Hair and urine analyses | Any drug use during prenatal period | 41 | 100 | 0.76 (0.61, 0.86) | 0.68 (0.55, 0.78)
Indirect | 4P’s Plus | Any cigarette or alcohol use | Chasnoff, 2007^47^,^§^ | Structured clinical interview | Any alcohol or drug use in the month prior to knowledge of pregnancy or after | 13.6 | 228 | 0.87 (0.71, 0.95) | 0.76 (0.70, 0.82)
Indirect | WIDUS | 3+ | Ondersma, 2012^58^,^†^ | Hair and urine analyses | Any drug use during prenatal period | 41 | 100 | 0.68 (0.53, 0.80) | 0.69 (0.57, 0.80)

* Study-reported or reviewer-determined optimal cut-off

† Postpartum

‡ Could not be calculated

§ Pregnant

ǁ Specific modifications not reported by the study

Abbreviations: ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; CI = confidence interval; DAST-10 = 10-Item Drug-Abuse Screening Test; n = number; N = no; NR = not reported; PRO = Prenatal Risk Overview; SCID = Structured Clinical Interview for the DSM; WIDUS = Wayne Indirect Drug Use Screener; Y = yes

Frequency-based screening tools. One study evaluated the use of a modified two-question ASSIST to detect any prenatal drug use. Sensitivity was 0.41 (95% CI, 0.28 to 0.57) and specificity was 0.83 (95% CI, 0.72 to 0.91) when drug use was confirmed with hair and urine analyses.^58^

Risk assessment screening tools. Three studies evaluated the accuracy of the DAST-10 at a cutoff of 1 or more to detect any prenatal drug use,^15,^ ^53,^ ^58^ one study evaluated the PRO in identifying drug abuse or dependence (in pregnant women),^63^ and one^58^ took results from both the ASSIST-2 and WIDUS to detect any prenatal drug use. Sensitivity for detecting any prenatal drug use ranged from 0.37 to 0.76 (95% CI range, 0.24 to 0.86) and specificity ranged from 0.68 to 0.83 (95% CI range, 0.55 to 0.91). The PRO resulted in a sensitivity of 0.89 (95% CI, 0.77 to 0.95) and specificity of 0.74 (95% CI, 0.71 to 0.77) for identifying drug abuse or dependence based on a clinical interview as the reference standard.

Indirect screening tools. A confirmation of any cigarette or alcohol use on the 4P’s plus had a sensitivity and specificity of 0.87 (95% CI, 0.71 to 0.95) and 0.76 (95% CI, 0.70 to 0.82), respectively, to identify any alcohol or drug use in the month prior to knowledge of pregnancy or after as reported in a structured clinical interview.^47^ The WIDUS, designed as an indirect screener, had a sensitivity of 0.68 (95% CI, 0.53 to 0.80) and specificity of 0.69 (95% CI, 0.57 to 0.80) for correctly identifying any prenatal drug use.

### Key Question 3 What Are the Harms of Primary Care Screening for Drug Use in Adolescents and Adults, Including Pregnant Women?

We identified no trials that addressed the harms of screening for drug use.

## Key Questions 4–5 Overall Summary of Results for Interventions to Reduce Drug Use

We included 27 trials (reported in 37 publications) that addressed the effectiveness of a counseling intervention on changes in drug use or improved health, social, or legal outcomes among a screen-detected population (Table 8).^78–110^ All but two trials were conducted in the United States; one trial took place in Chile^102^ and another took place in Germany.^111^ Three trials specifically targeted adolescents,^78,^ ^96,^ ^107^ five trials targeted young adults,^80,^ ^93,^ ^94,^ ^101,^ ^105^ 14 targeted adults,^81–83,^ ^87–89,^ ^102–104,^ ^108,^ ^109,^ ^112^ and five targeted pregnant^106,^ ^110^ and postpartum^98–100^ women. We rated four of the trials among adults^82,^ ^95,^ ^103,^ ^104^ as good quality and the remaining 23 trials as fair quality. Only one trial among adults^81^ was included in the previous USPSTF review.

Table 8 Trial and Population Characteristics, by Subpopulation (KQ 4 and KQ 5)

Target pop | Author, year Study name | QR | Country | Target subs | n rand | Brief population description | Mean age, yrs | Female, % | Race/ethnicity, % | SES variables | Outcomes reported
Adolescents | D’Amico, 2018^78^ | Fair | US | Cannabis, Alcohol | 294 | Adolescents aged 12–18 yrs | 16.0 | 56.8 | White: 11.6; Black: 16.7; Hisp: 66.3; Other: 5.4 | | Health, Beh
Adolescents | Mason, 2015^96^ | Fair | US | Alcohol, All drugs | 119 | Adolescents aged 14–18 yrs | 16.4 | 71.0 | Black: 84.0; Other: 16.0 | | Beh
Adolescents | Walton, 2013^107^ Project Chill | Fair | US | Cannabis | 328 | Adolescents aged 12–18 yrs | 16.3 | 66.5 | Black: 60.7; Hisp: 11.0 | Dropped out of school: 5.8% | Health, Beh
Young adults | Bernstein, 2009^80^ | Fair | US | Cannabis | 139^†^ | Adolescents and young adults aged 14–21 yrs | NR^‡^ | 66.2 | White: 5.7; Black: 80.6; Hisp: 12.9; Other: 0.7 | | Health, Beh
Young adults | Lee, 2010^93^ | Fair | US | Cannabis | 341 | Incoming college students aged 17–19 yrs | 18.0 | 54.6 | White: 68.3; Black: 1.5; Hisp: 6.2; Asian: 16.2; AI/NA: 0.9; Other: 7.0 | | Health, Beh, Harms
Young adults | Lee, 2013^94^ | Fair | US | Cannabis | 212 | College students aged 18–25 yrs | 20.0 | 45.3 | White: 74.8; Hisp: 5.7; Asian: 10.5; Other: 14.7 | | Health, Beh, Harms
Young adults | Palfai, 2014^101^; eCHECKUP TO GO | Fair | US | Cannabis | 123 | Undergraduate students | 19.7 | 57.7 | White: 87.0; Black: 2.4; Hisp: 17.0; Asian: 5.7; AI/NA: 1.6 | | Health, Beh
Young adults | Stein, 2011^105^ | Fair | US | Cannabis | 332 | Women aged 18–24 yrs | 20.5 | 100 | White: 67.8; Black: 10.5; Hisp: 11.5; Other: 10.2 | Some college or degree: 69.9% | Health, Beh
Adults | Bernstein, 2005^81^,^§^ | Fair | US | Cocaine, Heroin | 1175 | Adults aged ≥18 yrs | 37.9 | 29.4 | White: 14.2; Black: 62.0; Hisp: 23.2; Other: 0.06 | Educ <HS: 37.8%; Working: 42.9 %; Homeless: 45.8% | Beh
Adults | Blow, 2017^82^; HealthiER You | Good | US | All drugs | 387 | Adults aged 18–60 yrs | 31.2 | 55.5 | White: 39.2; Black: 52.2; Hisp: 6.0; Other: 8.6 | Educ <HS: 64%; Unemployed: 74% | Beh
Adults | Bogenschutz, 2014^83^; SMART-ED (Screening, Motivational Assessment, Referral, and Treatment in Emergency Departments) | Fair | US | All drugs | 854^ǁ^ | Adults aged ≥18 yrs | 36.0 | 31.0 | White: 48.8; Black: 34.9; Asian: 1.0; AI/AN: 2.3; Other: 9.5 | Educ <HS: 30.6%; Unemployed in past 30 days: 41.7%; Household income ≤$15,000: 62.2% | Beh
Adults | Gelberg, 2015^87^; Project QUIT (Quit Using Drugs Intervention Trial) | Fair | US | All drugs | 334 | Adults aged ≥18 yrs | 41.7 | 37.1 | White: 37.7; Black: 22.8; Hisp: 33.8; Other: 5.7 | Educ ≥12 yrs: 83.8%; U.S. born: 87.2%; Homelessness: 61.0%; Income ≤ $500/month: 58.0% | Health, Beh
Adults | Gelberg, 2017^88^; Project QUIT pilot replication | Fair | US | All drugs | 65 | Adults aged ≥18 yrs | 30.8 | 41.5 | Hispanic: 93.9 | Education ≥12 yrs: 83.1%; U.S. born: 87.5%; Homelessness: 34.4%; Income ≤$500/month: 75.0% | Beh
Adults | Gryczynski, 2016^112^ | Fair | US | All drugs | 80 | Adults aged ≥18 yrs | 35.2 | 52.5 | White: 86.2; Hisp: 42.5 | NR | Beh
Adults | Humeniuk, 2012^89^ | Fair | Australia, Brazil, India, US^¶^ | All drugs | 389 | Adolescents and adults aged 16–62 yrs | 31.4^#^ | 44.2 | NR | Employed: 59.8% | Beh
Adults | Martino, 2018^95^ | Good | US | Alcohol, All drugs | 439 | Pregnant and nonpregnant women aged ≥18 yrs | 34.2 | 100 | White: 13.2; Black: 66.7; Hisp: 14.8; Other: 5.2 | Educ <HS: 33.4%; Employed: 33.7% | Health, Beh
Adults | Poblete, 2017^102^ | Fair | Chile | Alcohol, All drugs | 806 | Adults aged 19–55 yrs | 29.2 | 21.8 | NR | Employed: 67.4% | Beh
Adults | Roy-Byrne, 2014^103^ | Good | US | All drugs | 868 | Adults aged ≥18 yrs | 47.8 | 30.0 | White: 45.0; Black: 37.0; Hisp: 9.0; Other: 18.0 | Educ <HS: 19%; Working: 9%; Homeless: 30% | Health, Beh
Adults | Saitz, 2014^104^; ASPIRE | Good | US | All drugs | 528 | Adults aged ≥18 yrs | 41.3 | 30.1 | White: 20.2; Black: 68.8; Hisp: 9.6; Other: 1.4 | HS grad: 69.9%; Medicaid/Medicare: 81.3%; No insurance: 5.7% | Health, Beh
Adults | Watkins, 2017^108^; SUMMIT (Substance Use Motivation and Medication) | Fair | US | Alcohol, Opioids | 397 | Adults aged ≥18 yrs | 42.0 | 20.4 | White: 43.8; Black: 13.3; Asian: 0.8; AI/AN: 1.3; Hisp: 31.0; Other: 40.3 | <HS: 27.9%; HS grad: 31.0%; >HS: 41.1%; Homeless: 49.3% | Health, Beh
Adults | Woolard, 2013^109^; Project Reduce | Fair | US | Alcohol, Cannabis | 515 | Adults aged ≥18 yrs | 28.4 | 16.5 | White: 68.0; Hisp: 17.0 | Mean educ, yrs: 12.4 | Health, Beh
Adults | Zahradnik, 2009^111^ | Fair | DEU | Prescription drugs | 126 | Adults aged 18–69 yrs | 55.1 | 61.9 | NR | Educ >10 yrs: 13.5%; Employed: 12.7% | Beh
Postpartum women | Ondersma, 2007^99^ | Fair | US | All drugs | 107 | Postpartum women in post-delivery recovery aged ≥18 yrs | 25.1 | 100 | Black: 97.2 | <HS: 41.1%; Employed full-time: 29.0%; Public assistance: 88.8% | Beh
Postpartum women | Ondersma, 2014^98^ | Fair | US | All drugs | 143 | Postpartum women in post-delivery recovery aged ≥18 yrs | 26.6 | 100 | White: 5.8; Black: 90.6; Hisp: 1.5; Other: 3.6 | Food assistance: 90.0%; HS grad or higher: 58.7%; Currently married: 7.1%; Work for pay: 44.8% | Beh, Harms
Postpartum women | Ondersma, 2018^100^ | Fair | US | All drugs | 502 | Postpartum women in post-delivery recovery aged 18–45 yrs | 24.6 | 100 | White: 2.6; Black: 73.2; Hisp: 3.6; Other: 24.2 | Employed: 35.2%; Food assistance: 83.4% | Beh, Harms
Pregnant women | Tzilos Wernette, 2017^106^ | Fair | US | Alcohol, Cannabis | 50 | Pregnant women (<5 months gestation) | 24.4 | 100 | White: 30.0; Black: 26.0; Asian: 0; AI/AN: 4.0; Hisp: 32.0; Other: 40.0 | HS grad: 28.0%; ≥ Some college: 34%; Unemployed: 44.0%; Single: 48.0%; Public assistance: 62.0% | Beh
Pregnant women | Yonkers, 2012^110^ | Fair | US | Alcohol, All drugs | 183 | Pregnant women (<28 wks gestation), aged ≥16 yrs | NR^**^ | 100 | White: 22.0; Black: 53.0; Hisp: 23.0; Other: 2.0 | Mean educ (yrs):; <12: 34.0; 12: 40.0; 13–15: 22.0; 16+: 4.0 | Health, Beh

* As available or reported by study

† Full study randomized N = 210. The nonassessed control group was not included in this report.

‡ ≤ 17 years: 29.5%; ≥ 18 years: 70.5%

§ In previous review

ǁ Full study randomized N = 1285. Minimal screening only group was not included in this report given no baseline measures for outcome variables.

¶ Country-specific data for only Australia and the US reported where available. Full N randomized=731; Australia N=171; US N=218

# Mean age of full sample (N= 731)

** <20: 17%; 20–34: 75%; 35+: 8%

Abbreviations: Beh = behavioral; educ = education; Hisp = Hispanic; HS = high school; n = number; NR = not reported; QR = quality rating; pop = population; n rand = number of participants randomized; SES = socioeconomic status; subs = substance; target subs = specific substance(s) targeted by the intervention; wks = weeks; yrs = years

Fifteen trials addressed any type of drug use (and in some cases also addressed alcohol use),^82,^ ^83,^ ^87–89,^ ^95,^ ^96,^ ^98–100,^ ^102–104,^ ^110,^ ^112^ nine trials focused specifically on marijuana use (with or without targeting alcohol use),^78,^ ^80,^ ^93,^ ^94,^ ^101,^ ^105–107,^ ^109^ one targeted opioid or alcohol use,^108^ one targeted cocaine and heroin use only,^81^ and one focused on misuse of prescription drugs.^111^ Within all of the trials, all participants were systematically screened for substance use prior to entry (using frequency-based or risk assessment instruments or 1–2 questions about current drug use) to determine their study eligibility and baseline substance use. The thresholds of drug use for inclusion varied across the trials ranging from any previous-year use to weekly use in the previous 3 months (Table 9). In four studies, drug use screening and intervention took place in an emergency or urgent care setting;^80,^ ^82,^ ^83,^ ^109^ the one trial in Chile screened adults presenting in primary care, emergency rooms, or police stations.^102^ The trial that took place in Germany screened adults being admitted to internal, surgical, or gynecological wards of a hospital.^111^ The remaining 22 trials screened participants presenting for a primary care office visit or those responding to direct mailing or generic advertising. The interventions were very similar across the trials, generally consisting of one brief in-person or computer-based personalized feedback session with up to two booster telephone calls (Table 10). Most of the interventions were based on principles of motivational interviewing and were administered by trained mental or behavioral health specialists or were self-directed. One intervention focused on a system-level intervention of collaborative care to facilitate behavioral or medication-assisted therapy for those at risk of an opioid or alcohol use disorder.^108^ Only two of the interventions included interaction with the participants’ primary care team,^87,^ ^88^ although several of the other interventions took place in the participants’ primary care clinics.

Table 9 Trial Recruitment Methods and Baseline Substance-Related Variables, by Subpopulation (KQ 4 and KQ 5)

Target pop | Author, year Study name | Recruitment method | Screener | Substance use eligibility criteria | Screen pos, % | n rand | FU, mos | FU, %^*^ | Baseline substance use-related characteristics (mean, sd)
Adolescents | D’Amico, 2018^78^ | Primary care visit | NIAAA SG | Any past-year drinking ≥1 day (for 12–15 yrs), ≥6 days (for 16–17 yrs), or ≥12 days (for 18 yrs) | 18.7 | 294 | 3, 6, 12 | 80.3 | Cannabis use in past 12 months: 77%; Cannabis use disorder: 38.4%
Adolescents | Mason, 2015^96^ | Primary care visit | CRAFFT | CRAFFT score of 2 or 3 (at risk for substance use disorder)^†^ | 15.8 | 119 | 1, 3, 6 | 98.3 | Cannabis use in past 30 days^‡^: 1.4 (1.3); Intentions to use cannabis in next 90 days^§^: 1.9 (1.3)
Adolescents | Walton, 2013^107^ Project Chill | Primary care visit | Add Health | Any cannabis use in past year | 25.8 | 328 | 3, 6, 12 | 83.8 | Cannabis use in past 90 days^ǁ^: 3.2 (1.9)
Young adults | Bernstein, 2009^80^ | Pediatric ED visit | Youth and Young Adult Health and Safety Needs Survey | Smoked marijuana ≥3 times in the past 30 days or risky behavior related to marijuana use | NR | 139 | 3, 12 | 73.4 | Days used cannabis in past 30 days: 17.1 (10.5)
Young adults | Lee, 2010^93^ | Direct mailing | GAIN-I | Any cannabis use in the past 3 months | 17.4 | 341 | 3, 6 | 94.4 | Days used cannabis in past 90 days: 9.9 (16.0)
Young adults | Lee, 2013^94^ | Direct mailing | NR | Cannabis use ≥5 days in the past month | 14.1 | 212 | 3, 6 | 82.5 | Days used cannabis in past 30 days: 16.1 (10); Number of joints smoked in typical week: 8.9 (9.7)
Young adults | Palfai, 2014^101^; eCHECKUP TO GO | Primary care visit | ASSIST | At least monthly cannabis use in past 3 months^¶^ | 19.4 | 123 | 3, 6 | 83.7 | Days used cannabis in past 90 days: 35.0 (28.4); ASSIST score: 11.9 (6.5); Readiness to change^#^: 1.34 (2.3)
Young adults | Stein, 2011^105^ | Generic advertising for health study | NR | Cannabis use ≥3 times in past 3 months^**^ | 29.8 | 332 | 1, 3, 6 | 78.9 | Proportion of days used cannabis, in past 90 days: 0.57 (0.34); Years of regular cannabis use: 3.9 (2.6); Cannabis dependence: 39.5%; Desire to quit using cannabis: 60.2%
Adults | Bernstein, 2005^81^,^††^ | Primary care visit | DAST-10 | Cocaine and/or heroin use in last 30 days and DAST-10 score ≥ 3 (moderate-to-severe problems related to drug use) | 5.2 | 1175 | 6 | 66.2 | Cocaine use: 92.5%; Heroin use: 44.9%; Readiness to change^‡‡^: 7.0; ≥1 prior admission for detox or substance abuse treatment: 46.4%
Adults | Blow, 2017^82^ | ED visit | ASSIST | ASSIST score ≥4 (past 3-month use of illicit drugs or misuse or prescription drugs) | 22.0 | 387 | 3, 6, 12 | 85.3 | Cannabis use: 91.0%; Cannabis use problem (ASSIST≥4): 88.0%; Prescription drug misuse: 20.0%
Adults | Bogenschutz, 2014^83^ | ED visit | DAST-10 | At least one day of drug use in past 30 days and DAST-10 score ≥ 3 (moderate-to-severe problems related to drug use) | 15.3 | 854 | 3,6, 12 | 80.3 | Drug use days in past 30 days: 16.2 (11.6); Prevalence of drug use^§§^:; Cannabis: 44%; Cocaine: 27%; Street opioids: 17%; Prescription opioids: 5%; Methamphetamine: 4%
Adults | Gelberg, 2015^87^ | Primary care visit | ASSIST | ASSIST score 4 to 26 (Moderate risk for drug use) | 10.5 | 334 | 3 | 79.0 | ASSIST score^§§^: 14.5 (range 4–26); Duration of drug use, yrs^‡‡^: 20.4 (13.4); Prevalence of drug use^‡‡^: Cannabis: 51.8%; Cocaine/crack: 20.1%; Amphetamines: 12.3%; Sedatives: 8.7%; Opiates: 6.6%; Other (inhalants, hallucinogens): 0.6%
Adults | Gelberg, 2017^88^ | Primary care visit | ASSIST | ASSIST score 4 to 26 (Moderate risk for drug use) | 7.6 | 65 | 3 | 78.5 | ASSIST score^§§^: 14.4 (6.2); Duration of drug use, yrs^§§^: 12.9 (12.9); Prevalence of drug use^§§^: Cannabis: 67.7%; Cocaine/crack: 9.2%; Amphetamines: 7.7%; Sedatives: 3.1%; Opiates: 12.3%; Other (inhalants, hallucinogens): 0.0%
Adults | Gryczynski, 2016^112^ | Community health center | ASSIST | ASSIST score 4 to 26 (Moderate risk for drug use) | 14.4 | 80 | 3 | 88.8 | Moderate risk (ASSIST score 4–26): Cannabis: 90.0%; Cocaine: 5.0%; Amphetamines16.2%; Opioids: 23.8%
Adults | Humeniuk, 2012^89^ | University-affiliated community clinic, walk-in health clinic, walk-in sexually transmitted disease clinic visit | ASSIST | ASSIST score 4 to 26 (Moderate risk for cannabis, cocaine, amphetamine-type stimulant, or opioid use^†††^) | NR | 389 | 3 | 85.1 | Moderate risk (ASSIST score 4–26)^§§ǁǁ^:; Cannabis: 54.0%; Cocaine: 12.9%; Amphetamines: 21.2%; Opioids: 12.7%
Adults | Martino, 2018^95^ | Reproductive health clinic visit | ASSIST | ASSIST score 4 to 26 (Moderate risk for drug use) or ≥11 for nonpregnant women and ≥6 for pregnant women for alcohol | NR | 439 | 1, 3, 6 | 87.9 | ASSIST score^§§^: 22.5 (8.1); Cannabis use disorder: 33.7%; Other illicit drug use disorder: 20.2%
Adults | Poblete, 2017^102^ | Primary care, ED, or police station visit | ASSIST, Chilean version | ASSIST score 11 to 20 for alcohol or ASSIST score 4 to 20 for drug use (moderate risk) | 15.8 | 806 | 3 | 61.7 | ASSIST (Chilean) score: 26.8 (9.5); Moderate risk (ASSIST score 4–20): Cannabis: 49%; Cocaine: 19%; Sedatives: 5%; Other drug: 5%
Adults | Roy-Byrne, 2014^103^ | Primary care visit | NR | Any illegal drug or nonprescribed medication use at least once in the past 3 months | 15.7 | 868 | 3, 6, 9, 12 | 89.5 | Days used most frequently used drug in past 30 days: 13.8 (11.0); Past 30 day use:; Cannabis: 76%; Stimulants: 42%; Cocaine: 37%; Amphetamines: 7%; Opiates: 26%; Heroin: 7%; Methadone and other opiates/analgesics nonprescribed: 24%; Sedatives/hypnotics/tranquilizers: 8%
Adults | Saitz, 2014 ^104^; ASPIRE | Primary care visit | ASSIST | ASSIST score ≥4 (drug use weekly or more in past 3 months or less frequent use but with consequences) | 68.1 | 528 | 6 | 97.9 | Days used most frequently used drug past 30 days: 14.4 (11.5); Main drug:; Opioid (including prescription): 17.1%; Prescription opioid only: 5.7%; Cocaine: 18.6%; Cannabis: 62.7%
Adults | Watkins, 2017^108^; SUMMIT | Primary care visit | NIDA Quick Screen | Probable opioid or alcohol use disorder | 61.2 | 397 | 6 | 69.2 | Alcohol abuse or dependence only: 54%; Heroin abuse or dependence with or without cooccurring alcohol or prescription opioid abuse or dependence: 31%; Prescription opioid abuse or dependence with or without cooccurring alcohol abuse or dependence: 16%
Adults | Woolard, 2013^109^ | ED visit | 10-item wellness questionnaire | Any past month alcohol use and past year marijuana use | 14.0 | 515 | 12 | 82.7 | AUDIT score: 10.9 (1.4); Cannabis use days in past 30 days: 12.6
Adults | Zahradnik, 2009^111^ | Admission to internal, surgical, or gynecological ward of hospital | QPM, SDS | Prescription drug use^¶¶^ >60 days in past 3 months or PD abuse or dependence | 18.0 | 126 | 3, 12 | 88.9 | PD misuse: 17.5%; PD dependence: 43.6%
Postpartum women | Ondersma, 2007^99^ | Inpatient hospitalization for childbirth | Single question | Any illicit drug use in the month before becoming pregnant | NR | 107 | 4 | 71.0 | Daily or weekly cannabis use in 3 months prior to pregnancy: 62.6%; Drug use other than cannabis in 3 months prior to pregnancy: 12.1%
Postpartum women | Ondersma, 2014^98^ | Inpatient hospitalization for childbirth | Single question | Any illicit drug use in the month before becoming pregnant | 25.7 | 143 | 3, 6 | 65.9 | ≥ ASSIST scores for moderate risk^##^:; Cannabis: 76.9%; Cocaine: 11%; Opiates: 9.1%; Daily/near daily cannabis use^##^: 86.5%
Postpartum women | Ondersma, 2018^100^ | Inpatient hospitalization for childbirth | WIDUS | WIDUS score ≥3 | NR | 502 | 3, 6 | 65.3 | Pre-pregnancy opioid misuse: 12.0%^***^
Pregnant women | Tzilos Wernette, 2017^106^ | Obstetrics visit | T-ACE or SURP-P | Current alcohol or drug use or at -risk for prenatal alcohol/drug use (positive score on T-ACE or SURP-P) | NR | 50 | 4 | 98.0 | Reported alcohol or marijuana use: 70%
Pregnant women | Yonkers, 2012^110^ | Obstetrics visit | TWEAK | Any use of alcohol or illicit drug use (excluding opiates) in last 30 days or TWEAK score ≥3 | NR | 183 | 1, 3 | 91.8 | Past month use:; Alcohol: 52%; Heroin: 2%; Methadone: 8%; Opiates (excl methadone): 6%; Barbiturates: 0; Sedatives: 4%; Cocaine: 11%; Amphetamines: 1%; Cannabis: 44%; Hallucinogens: 2%; Inhalants: 0

* At longest followup time point

† Those endorsing ≥4 were excluded and were encouraged to talk with a social worker or doctor

‡ Scale 0–7 where 0 = 0 days, 1 = 1–2 days, 2 = NR, 3 = 3–5 days, 4 = 6–9 days, 5 = 10–19 days, 6 = 20–29 days, and 7 = all 30 days

§ Scale 0–4 where 0 = definitely no, 1 = probably no, 2 = unsure, 3 = probably yes, and 4 = definitely yes

ǁ Scale 0–6 where 0 = never, 1= 1–2 days, 2 = once a month or less, 3= 2–3 days per month, 4 = 1–2 days per week, 5 = 3–5 days per week, and 6 = every day or almost every day

¶ Persons with ASSIST score >27 for cannabis at baseline (indicating a high likelihood of substance dependence) were excluded

# Computed by subtracting the mean precontemplation score from the sum of the contemplation and action scores, range not reported

** Those meeting criteria for drug dependence, other than cannabis dependence, were excluded

†† In previous review

‡‡ Range 1–10 where 0–3 = not ready, 4–6 = unsure, 7–10 = ready to change

§§ For primary drug

ǁǁ For full sample. Proportion of participants at moderate risk for each drug class not reported by country.

¶¶ Includes opioids, anxiolytics, hypnotics, sedative, and caffeine with addiction potential

## Baseline measures referred to use in the three months prior to pregnancy

*** Use of other drugs not reported at baseline

††† Those scoring >27 or who had frequently injected drugs in the last 3 months were referred to specialist drug and alcohol treatment services.

Abbreviations: Add Health = National Longitudinal Study of Adolescent Health; ASPIRE = The Assessing Screening Plus Brief Intervention’s Resulting Efficacy to Stop Drug Use; ASSIST = Alcohol, Smoking, and Substance Involvement Screening Test; BL = baseline; CRAFFT = Car, Relax, Alone, Forget, Friends, Trouble; DAST-10 = The Drug Abuse Screening Test-10 item; ED = emergency department; excl = excluding; FU = followup; GAIN-I = The Global Appraisal of Individual Needs-Initial; n rand = number of participants randomized to the trial; NIAAA SG = National Institute of Alcohol Abuse and Alcoholism Screening Guide; NR = not reported; PD = prescription drugs; pop = population; pos = positive; QPM = questionnaire for prescription drug misuse; sd = standard deviation; SDS = Severity of dependence scale; SURP-P = Substance Use Risk Profile-Pregnancy scale; TWEAK = Tolerance, Worried, Eye-opener; Amnesia; K/Cut Down; WIDUS = Wayne Indirect Drug Use Screener

Table 10 Intervention Characteristics of All Trials, by Subpopulation (KQ 4 and KQ 5)

Target pop | Author, year | Target subs | Int arm | Intervention | Intensity category^*^ | Brief description | Setting | CBT | ME | MI | PNF | Refer | Provider | CG
Adolescents | D’Amico, 2018^78^ | Cannabis, Alcohol | IG1 | In-person brief intervention | Extended single | One 15–20-min individual counseling session | Primary care | | | X | X | | Trained facilitator | UC
Adolescents | Mason, 2015^96^ | Alcohol, all drugs | IG1 | Peer network counseling | Extended single | One 20-min individual counseling session | Primary care | | X | X | X | | Mental or behavioral health specialists | AC
Adolescents | Walton, 2013^107^ | Cannabis | IG1 | In-person personalized feedback | Very brief^†^ | One personalized feedback session (min NR) | Primary care | | | X | X | | Mental or behavioral health specialists | UC
Adolescents | Walton, 2013^107^ | Cannabis | IG2 | Computer-based personalized feedback | Very brief^†^ | One computerized feedback session (min NR) | Primary care | | | X | X | | Self-directed | UC
Young adults | Bernstein, 2009^80^ | Cannabis | IG1 | In-person brief intervention | Extended multi-contact | One 20–30-min brief individual counseling session and one 5–10-min booster phone call | ED | | | X | | | Lay counselors | UC
Young adults | Lee, 2010^93^ | Cannabis | IG1 | Computer-based personalized feedback | Very brief | One computerized, personalized feedback session with access to feedback for 3 months | Home | | | | X | | Self-directed | None
Young adults | Lee, 2013^94^ | Cannabis | IG1 | In-person personalized feedback | Extended single | One 60-min in-person personalized feedback session | NR | | X | X | X | | NR | None
Young adults | Palfai, 2014^101^ | Cannabis | IG1 | Computer-based personalized feedback (eCHECKUP TO GO) | Brief single | One web-based personalized feedback session (min NR) | College health clinic | | | | X | | Self-directed | AC
Young adults | Stein, 2011^105^ | Cannabis | IG1 | Motivational interviewing | Extended multi-contact | Two 45-min motivational interviewing sessions | Research clinic | | | X | X | | Mental or behavioral health specialists | None
Adults | Bernstein, 2005^81^ | Cocaine, heroin | IG1 | Motivational interviewing + telephone booster session | Extended multi-contact | One 10–45 min motivational interview interviewing session followed by one 5–10 min phone call | Primary care | | | X | | | Peers | Minimal
Adults | Blow, 2017^82^ | All drugs | IG1 | Therapist delivered brief intervention | Extended single | One 30-min in-person brief intervention session | ED | | | X | | | Behavioral health specialist | UC
Adults | Blow, 2017^82^ | All drugs | IG2 | Computer-delivered brief intervention | Extended | One 30-min computerized brief intervention session | ED | | | X | | | Self-directed | UC
Adults | Bogenschutz, 2014^83^ | All drugs | IG1 | Brief intervention + telephone booster sessions | Brief multi-contact | One brief intervention and two telephone booster calls | ED | | X | X | | X | Research staff | Minimal
Adults | Gelberg, 2015^87^ | All drugs | IG1 | Brief intervention + telephone coaching sessions | Extended multi-contact | One 3–4-min brief intervention followed by two 20–30 min phone calls | Primary care | X | | X | | | PCP, lay counselors | AC
Adults | Gelberg, 2017^88^ | All drugs | IG1 | Brief intervention + telephone coaching sessions | Extended multi-contact | One 3–4 min brief intervention followed by two 20–30 min phone calls | Primary care | X | | X | | | PCP, lay counselors | AC
Adults | Gryczynski, 2016^112^ | All drugs | IG1 | Computer-based brief intervention | Brief single | One 10 min computerized brief session | Community health center | | | X | X | | Self-directed | WL
Adults | Humenuik, 2011^89^ | All drugs | IG1 | Brief intervention | Brief single | One 15 min brief intervention session | Primary care | | | X | | | Research staff | WL
Adults | Martino, 2018^95^ | Alcohol, All drugs | IG1 | In-person brief intervention | Extended single | One 20 min brief intervention session | Primary care | | | X | | X | Research nurse, social workers, PCP | UC
Adults | Martino, 2018^95^ | Alcohol, All drugs | IG2 | Computer-based brief intervention | Extended single | One 20 min brief intervention session | Primary care | | | X | | X | Self-directed | UC
Adults | Poblete, 2017^102^ | Alcohol, All drugs^‡^ | IG1 | Brief intervention based on FRAMES | Extended single | One 18 min brief individual counseling session | Primary care, ED, police station | | | | | | Social workers, psychologists | UC
Adults | Roy-Byrne, 2014^103^ | All drugs | IG1 | In-person personalized feedback + telephone booster session | Extended multi-contact | One 30 min personalized feedback session and one 10-min booster call | Primary care | | | X | X | X | Social workers | UC
Adults | Saitz, 2014^104^ | All drugs | IG1 | Brief negotiated interview | Brief single | One 10–15 min brief negotiated interviewing session | Primary care | | | X | X | | Health educators | Minimal
Adults | Saitz, 2014^104^ | All drugs | IG2 | Motivational interviewing + telephone booster session | Extended multi-contact | One 30–45 min motivational interviewing session and one optional 20–30 min booster followup session | Primary care | | | X | X | | Mental or behavioral health specialists | Minimal
Adults | Watkins, 2017^108^ | Alcohol, Opioids | IG1 | Collaborative care | Extended multi-contact | Collaborative care (registry, regular assessment, adherence support) plus training for behavioral therapists and doctors for medication-assisted treatment | Primary care | X | | X | | | PCP, mental or behavioral health specialists, social workers | UC
Adults | Woolard, 2013^109^ | Alcohol, Cannabis | IG1 | Motivational interviewing | Extended multi-contact | Two 15–60 min individual counseling sessions | ED, behavioral/mental health clinic | | X | X | | | Research staff | UC
Adults | Zahradnik, 2009^111^ | Prescription drugs | IG1 | Motivational interviewing | Extended multi-contact | One 35-min in-person MI session, one phone MI session, and one individualized feedback letter | Hospital | | | X | X | | Psychologist | UC
Postpartum women | Ondersma, 2007^99^ | All drugs | IG1 | Computer-based brief intervention | Extended single | One 20 min computer-delivered brief intervention session and two non-tailored mailings | Hospital | | | X | X | X | Self-directed | None
Postpartum women | Ondersma, 2014^98^ | All drugs | IG1 | Computer-based personalized feedback (eCHECKUP TO GO) | Extended single | One 20 min interactive computer-based personalized feedback session | Hospital | | | X | | | Self-directed | AC
Postpartum women | Ondersma, 2018^100^ | All drugs | IG1 | Computer-based brief intervention focused on parenting | Brief single | One brief computer-based session and personalized feedback report | Hospital | | | X | | | Self-directed | AC
Pregnant women | Tzilos Wernette, 2017^106^ | Alcohol, Cannabis | IG1 | Health Checkup for Expectant Moms computerized program^§^ | Extended multi-contact | One 60-min computer-delivered MI session and one 15-min computer-delivered booster session | Ob/Gyn clinic | | | X | | | Self-directed | AC
Pregnant women | Yonkers, 2012^110^ | Alcohol, all drugs (except opioids) | IG1 | MET-CBT | Extended multi-contact | Six 30 min MET + CBT sessions | Ob/Gyn clinic | | X | | | | Research nurses | UC

* Intensity categories defined as: Very brief = single contact, ≤5 min; Brief = singe contact, ≤15 min; Extended = single contact, ≥15 min; Brief multi-contact = multiple contacts, ≤15 min each; Extended multi-contact = multiple contacts, ≥15 min each

‡ 48% received alcohol-related brief intervention, 36% received a cannabis-related brief intervention, 12% received a cocaine-related brief intervention, and 4% received a brief intervention for other substances.

§ Intervention addressed both STI/HIV and alcohol/drug risk

Abbreviations: AC = attention control; CBT = cognitive behavioral therapy; CG = control group; ED = emergency department; FRAMES = Feedback, Responsibility, Advice, Menu Options, Empathy and Self-Efficacy; IG = intervention group; Int = intervention; MET = motivational enhancement therapy; MI = motivational interviewing; min = minute; None = assessment only; NR = not reported; PCP = primary care provider; PNF = personalized normative feedback; self-admin = self-administered; subs = substance; target subs = substance(s) targeted by the intervention; UC = usual care; WL = waitlist

Across all 27 trials (n analyzed=8705), there was no consistent effect of the interventions on rates of self-reported or biologically confirmed drug use at 3- to 12-month followup (KQ 4a). Within each study, the frequency and quantity of drug use generally decreased, and rates of abstinence increased in both intervention and control groups, with no statistically significant between-group differences detected. Among young adults and adults, a meta-analysis of 10 out of the 19 studies that reported days of drug use resulted in a nonsignificant difference in the mean change in drug use in the past 7 days between intervention and control groups at both 3 months (mean difference [MD], −0.08 [95% CI, −0.27 to 0.10]; k=9; n=3183; I^2^=18.6%) (Figure 9) and 6 to 12 months (MD, −0.00 [95% CI, −0.26 to 0.20]; k=10; n=3632; I^2^=32.3%) (Figure 10). Likewise, across 14 trials reporting the effects of the interventions on health, social, or legal outcomes (KQ 4b) (n=4590), none of the trials found a statistically significant difference between intervention and control groups on any of these measures at 3- to 12-month followup. Four of the 27 trials (n=1161)—two targeting marijuana use among college students and two targeting any drug use among postpartum women—reported no harms or unintended effects from participation in the trials among intervention or control group participants.

Figure 9 Pooled Analysis of Days Used Drugs in the Past 7 Days (KQ 4a), Mean Difference in Change Between Brief Interventions and Control Groups at 3 Months Followup

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number of participants analyzed; SD = standard deviation

This figure is a forest plot of days of drug use in the past 7 days (KQ4a), mean difference in change between brief interventions and control groups, at 3 months of followup.

Figure 10 Pooled Analysis of Days Used Drugs in the Past 7 Days (KQ 4a), Mean Difference in Change Between Brief Interventions and Control Groups at 6 to 12 Months Followup

Abbreviations: CG = control group; CI = confidence interval; FU = followup; IG = intervention group; N = number of participants analyzed; SD = standard deviation

This figure is a forest plot of days of drug use in the past 7 days (KQ4a), mean difference in change between brief interventions and control groups, at 6 to 12 months of followup.

### Key Question 4a Do Counseling Interventions to Reduce Drug Use, With or Without Referral, Reduce Drug Use or Improve Other Risky Behaviors in Screen-Detected Persons?

### Key Question 4b Do Counseling Interventions to Reduce Drug Use, With or Without Referral, Reduce Morbidity or Mortality or Improve Other Health, Social, or Legal Outcomes in Screen-Detected Persons?

### Key Question 5 What Are the Harms of Interventions to Reduce Drug Use in Screen-Detected Persons?

#### Adolescents

##### Study, Population, and Intervention Characteristics

We included three fair-quality trials (n=741) that addressed interventions to reduce drug use among screen-detected “at-risk” adolescents, all with a mean age of 16 years (Table 8).^78,^ ^96,^ ^107^ Participants in all three trials were recruited in U.S.-based primary care settings, and were mostly black (61%^107^ and 84%^96^) or Hispanic (66%^78^) and female (57 to 71%). Limited data on participants’ education or socioeconomic status were reported, with the exception of one trial, which reported that 5.8 percent of adolescents had dropped out of school.^107^ One trial targeted both alcohol and drug use,^96^ one targeted both cannabis and alcohol,^78^ while the remaining one specifically targeted cannabis use.^107^ In the former two trials, adolescents were eligible if they were considered at risk for a substance use disorder (CRAFFT score of 2 or 3) or alcohol use disorder, whereas the latter only enrolled adolescents who reported any previous-year cannabis use. Baseline cannabis use in all trials indicated that on average, adolescents were using cannabis 1 to 3 days per month (Table 9). All three trials included one personalized counseling session either in person with trained mental or behavioral health specialist or via a computerized session using principles of motivational interviewing and personalized and normative feedback (Table 10 and Table 11). Retention rates were high all trials, with more than 80 percent of participants completing 6-month followup.

Table 11 Detailed Intervention Characteristics, by Subpopulation (KQ 4 and KQ 5)

Target pop | Author, year | Target subs | Int arm | Intervention | IG detailed description | Intervention adherence | CG description
Adolescents | D’Amico, 2018^78^ | Cannabis, Alcohol | IG1 | In-person brief intervention | Participants received a 15–20 minute in-person brief motivational interviewing intervention that focused on assessing motivation for change. Participants discussed their personal pros and cons of alcohol or drug (AOD) use and determined what their friends thought about AOD use, and how that might affect their own use. The facilitator provided normative information on AOD use and participants were asked to discuss what they thought might happen if they continued to use AOD in the same way. Depending on participants’ motivation to change their behavior, a discussion that addresses their willingness and confidence to cut back and/or stop their use followed. Finally, if participants were willing, they discussed a plan to prepare for high-risk situations where AOD might be present and how they could make a healthy choice in those situations. | 92.8% received intervention as assigned | UC: During their primary care appointment, participants received a brochure developed by the project team with information on the effects of AOD use, how to prepare for risky situations, and online and telephone resources to obtain additional information.
Adolescents | Mason, 2015^96^ | Alcohol, all drugs | IG1 | Peer network counseling | Participants received a 20-min Peer Network Counseling intervention guided by five key motivational interviewing (MI) clinical issues: rapport, acceptance, collaboration, reflections, and nonconfrontation. Therapists used baseline data from participants’ screening surveys to show graphic displays of substance use and peer network characteristics during the counseling session. The intervention followed Motivational Enhancement procedures with age-matched substance use normative data presented as feedback. The intervention was structured into four component parts each lasting for 5 minutes: (a) rapport building and laptop presentation of substance use feedback in simple graphic form, (b) discussion of substance use likes/dislikes and discrepancies, (c) introduction of peer network information and graphical feedback, and (d) summary, change talk, and plans. The rapport building and feedback component was used to establish a nonjudgmental relationship and to present the participant with a graphical display of their substance use compared to national normative data. During the likes/dislikes discussion, participants’ baseline responses were then reflected back to the teen, highlighting goals and values in order to have the participant identify and articulate discrepancies between current use and future goals and values. The peer network component began by introducing the concept of peer network and its influence on health using the laptop to illustrate the concept. The participants’ peer network is reviewed for risks, protection, support, prosocial activities, and encouragement for healthful behavior as well as for substance use, influence/offers to use substance, and risky/dangerous activities. Participants were encouraged to reflect on their network and to consider making small modifications, such as adjusting the amount of time spent with particular peers as well as time spent at particular locations in order to support participants’ willingness for peer network adjustment. The summary, change, talk and plans component summarized the session with appreciation of the client’s honesty, and pays particular attention to underscoring discrepancies and reflecting on client-generated change talk. If the adolescent has articulated a change plan, this is reviewed, encouraged, and supported. If the teen has not made a specific change plan, the counselor encourages personal reflection on what was discussed. | 100% received intervention | AC: Participants reviewed an informational handout with the therapist which covered several topics related to health behaviors such as exercise, nutrition/weight management, and life skills. These sessions lasted 20 minutes, matching the experimental condition in length.
Adolescents | Walton, 2013^107^ | Cannabis | IG1 | In-person personalized feedback | The intervention, delivered by a therapist and facilitated by a computer, incorporated motivational interviewing, including tailored, parallel content: (1) goals/values; (2) feedback for cannabis, alcohol and other drug use, including consequences and DUI; (3) decisional balance exercise about cannabis; (4) tricky situations (e.g., role plays) including refusal skills for cannabis and other drug use, safe ways to get home/prevent driving high/drunk, dealing with peer pressure for delinquency (e.g., stealing a car/joy riding), coping with negative affect such as boredom, anger or sadness, and consequences (i.e., problem identification, getting help); and 5) the control brochure. The therapist used an elicit-provide-elicit framework when reviewing tailored feedback, using summaries and open-ended questions to evoke change talk. During role plays, therapists elicited tools to reduce use and avoid consequences. | NR | UC: Participants handed a brochure containing warning signs of cannabis problems, resources (substance use treatment, suicide hotlines, employment services, leisure activities), and cannabis information websites.
Adolescents | Walton, 2013^107^ | Cannabis | IG2 | Computer-based personalized feedback | The CBI was a stand-alone interactive animated program administered with a touch screen tablet and incorporated motivational interviewing, including tailored, parallel content: (1) goals/values; (2) feedback for cannabis, alcohol and other drug use, including consequences and DUI; (3) decisional balance exercise about cannabis; (4) tricky situations (e.g., role plays) including refusal skills for cannabis and other drug use, safe ways to get home/prevent driving high/drunk, dealing with peer pressure for delinquency (e.g., stealing a car/joy riding), coping with negative affect such as boredom, anger or sadness, and consequences (i.e., problem identification, getting help); and 5) the control brochure. Research staff handed a tablet to participants, and showed them how to adjust the audio. A virtual buddy guided participants through the program and provided audio feedback (via headphones). During the roleplays, participants watched animated situations and then were asked to make a behavioral choice. If a participant chose a negative option (e.g., smoking cannabis), they were asked to consider the consequences in relation to their goals. Once a positive choice was made, the animation resumed, modeling this selection. The tailored role-plays included six characters and showed the progression in medical, social, and legal consequences for characters that did and did not use cannabis over time. At the end, the computer instructed participants to return the tablet to staff. | NR
Young adults | Bernstein, 2009^80^ | Cannabis | IG1 | Computer-based personalized feedback | After completion of their baseline surveys, participants could immediately view feedback online and could choose to print feedback to their own printer. Participants could return to view feedback on the web for 3 months. Feedback was based on a motivational interviewing approach and normative feedback and was primarily text-based, but incorporated pictures to enhance interest and appeal as well as figures and graphs representing normative information and comparisons. Participants were presented with feedback about their cannabis use (e.g., frequency and quantity of use), perceived and actual descriptive norms for cannabis use (e.g., how frequently they believe the typical student uses cannabis), and perceived pros and cons of using cannabis. Self-reported negative consequences were included in the feedback, as well as ways in which reducing or eliminating cannabis use might be associated with reduced social and academic harm and participants’ own cost-benefit scale for use. Skills training tips for avoiding cannabis and making changes in one’s use were provided, as well as feedback about limiting alcohol intake. Perceived high-risk contexts and alternative activities around campus and in the community, were provided. | 92.5% reported receiving emails about feedback, 75.2% reported linking to and viewing feedback, and 5.6% reported printing the feedback. | None
Young adults | Lee, 2010^93^ | Cannabis | IG1 | In-person brief intervention | In addition to brief written materials about risks associated with marijuana use and a list of community resources and adolescent treatment facilities, participants received a 20- to 30-minute structured intervention delivered by a peer educator. The intervention consisted of the following components: 1) obtaining engagement and permission to raise the subject; 2) establishing context (‘‘What’s a typical day in your life like?’’); 3) offering brief feedback, information, and norms, specific to age and sex, and exploring pros and cons of use: eliciting ‘‘change talk’’ and using the CRAFFT questions and a Readiness to Change ruler to reinforce movement toward behavior change); 4) generating a menu of options; 5) calling up assets ⁄ instilling hope; 6) discussing the challenges of change; and ending in a 7) prescription for change, generated by the subject, and referrals to community resources and specialty drug treatment services. Participants with CRAFFT scores of >2 were advised that the score may indicate high risk and a possible need for further evaluation and treatment. Participants also received a 5- to 10-minute booster phone call during which the interventionist reviewed the elements of the change plan, inquired about any progress toward change, and offered further referrals if those originally provided had not been possible to accomplish. | NR | UC: Participants received brief written materials about risks associated with marijuana use and a list of community resources and adolescent treatment facilities.
Young adults | Lee, 2013^94^ | Cannabis | IG1 | In-person personalized feedback | Participants received a 1-hour intervention designed to provide the opportunity to discuss their cannabis use and review personalized graphic feedback. Facilitators used motivational interviewing principles. The personalized graphic feedback illustrated the impact of cannabis use in multiple domains to facilitate conversations about patterns of use and related consequences, including information regarding participants’ typical pattern of cannabis use (i.e., frequency, quantity, peak occasion, timing of use during the day, and perceived time spent high) and comparison to peers. Information was provided on participants’ estimated spending on cannabis compared with items that could be purchased instead, followed by feedback about self-reported confidence to avoid smoking in certain situations. Participants received feedback on family history risk, alcohol use, frequency of other drug use, and instances of combining other substances with cannabis such that interaction risks could be described. The final two sections of the feedback were dedicated to exploring students’ social networks and goals for the next year. Related to social networks students listed up to 6 people whom they could count on for support, considered if the person knew about their cannabis use, and considered how the person felt about their cannabis use (or would feel about it). Finally, their five most important goals were listed and students were asked to rate how cannabis use affects goal attainment and how reducing cannabis use may positively or negatively affect attainment. At the end of the feedback session, students could ask questions and discuss goals. Participants who did not attend an in-person session were offered a mailed copy of the personalized feedback with a facilitated guide to reading the feedback. | 54.7% participants attended the in-person intervention. Overall, 90 (84.9%) of participants received either the in-person or mailed feedback. | None
Young adults | Palfai, 2014^101^ | Cannabis | IG1 | Computer-based personalized feedback (eCHECKUP TO GO) | Following assessment, participants were provided with detailed personalized feedback about their cannabis use, including costs, norms, risks, consequences, and alternative activities. | NR | AC: Participants were provided minimal general health feedback regarding recommended guidelines for sleep, exercise, and nutrition.
Young adults | Stein, 2011^105^ | Cannabis | IG1 | Motivational interviewing | Participants received two 45-min motivational interviewing sessions spaced 1 month apart. During the initial session, participants were informed that the goals of the session (raising awareness of the pros and cons of cannabis use, exploring any conflicting motivation governing the decision to change, and organizing strategies to deal with internal or external obstacles to achieving change goals) and assured there was no “hidden agenda” about having to quit. Interventionists engaged participants in a discussion of values and goals, thoughts about cutting back/quitting, and state of readiness to make changes and provided feedback from the research assessment materials. This discussion led to the option of generating a change plan, which could be used for any goal, such as a health behavior goal or a general life goal, in addition to or instead of a cannabis-related goal. If participants were unable to generate an idea for a goal and did not explicitly state they did not want to set a goal, common goals were offered as examples, such as increased exercise, change in diet, or change in money or time management. At the end of the session, change plan sheets and an assessment feedback report were given to participants and the next appointment date was set. The followup session occurred 1 month later and was based on the participants’ goals and change plans from the initial session. MI techniques were used to review the information from the first session to reevaluate the interest in setting a cannabis-related goal. Participants were also offered suggestions about interim steps that they might consider prior to setting an abstinence goal, such as gaining knowledge about trigger situations and/or beginning to increase quality of life activities such as exercising or using stress management techniques. For participants who did not set any goals in the first session, MI techniques were used to review the information from the first session to reevaluate the interest for setting a health-related, cannabis-related risk behavior and/or cannabis-related risk behavior goal. | 80.3% received both MI sessions, 9.8% received one MI session, and 9.8% received none of the MI sessions. | None
Adults | Bernstein, 2005^81^ | Cocaine, Heroin | IG1 | Motivational interviewing | Participants received a semi scripted, brief (10–45 min) motivational interview delivered by a peer, a substance abuse outreach worker in recovery. The motivational interview involved the following steps: establishing rapport, asking permission to discuss drugs, exploring the pros and cons of drug use, eliciting the gap between real and desired quality of life, and assessing readiness to change on a ruler scaled from 1 (not ready) to 10 (ready). The peer interventionist negotiated an action plan based on examples of the enrollee’s past successes in making behavior change. Participants also received a handout from the interventionist stating that “based on your screening responses, you would benefit from help with your drug use.” This form included a list of treatment options including detox, AA/NA, acupuncture, residential treatment facilities, and harm reduction information about safe sex and needle exchange. In addition to this interview, semi-scripted and tailored to individual behavior, risks, culture, and language, participants in the intervention group received referrals if desired, and a 5–10 min telephone booster call after 10 days, during which the interventionist asked what had transpired and if any new referrals were needed. | 31% could be reached for phone booster session. | MI: Participants received only a handout stating that “based on your screening responses, you would benefit from help with your drug use.” This form included a list of treatment options including detox, AA/NA, acupuncture, residential treatment facilities, and harm reduction information about safe sex and needle exchange, but there was no discussion about this information.
Adults | Blow, 2017^82^ | All drugs | IG1 | Therapist-delivered brief intervention | Received 30-min therapist-delivered intervention based on principles of motivational interviewing, transtheoretical model, and FRAMES during their ED visit. Therapists used a touchscreen tablet to guide the session. Throughout the intervention, therapists handed the participant the computer so that they could view and collaboratively select goals, concerns, benefits, readiness to change statements for each drug, tools to manage challenging situations, and strengths. During the feedback portion of the intervention, participants viewed a graphic depicting the local prevalence of each substance the patient reported using during screening. The final screen displayed a tailored summary which therapists used to provide a final verbal summary and which was printed and provided to the participants. At the end of the intervention, participants received a 4-page “change plan” booklet containing goals, plan related to their use, benefits, tools, and strengths. | NR | UC: Printed materials with information about community treatment resources and 3-min review of information
Adults | Blow, 2017^82^ | All drugs | IG2 | Computer-based brief intervention | Received 30-min computer-delivered intervention based on principles of motivational interviewing, transtheoretical model, and FRAMES during their ED visit. The intervention was delivered via touchscreen tablet computers with audio headphones. The intervention included still images of actors streamed together and interactive questions and exercises. Participants had a choice of selecting a culturally-specific virtual health counselor who introduced choices and activities on the computer. Participants watched short video vignettes featuring a recorded voice of a character telling a story of drug use. Interactive exercises during the intervention including selecting goals, concerns, benefits, change statement, challenges, tools/strategies and strengths. | NR | UC: Printed materials with information about community treatment resources and 3-min review of information
Adults | Bogenschutz, 2014^83^ | All drugs | IG1 | Brief intervention + telephone booster sessions | In addition to an informational pamphlet about drug use and misuse, its potential consequences, and treatment options and optional referral to addiction treatment, participants received a manual-guided brief intervention with telephone boosters (BI-B) based on motivational interviewing principles. The BI-B had content patterned based on motivational enhancement therapy, including use of feedback based on screening information and development of a change plan if indicated. Consistent with the spirit of motivational interviewing, the BI focused initially on the primary problem drug identified by the participant, but also addressed concerns about other substance use if these came up in the session. In addition, participants received up to 2 telephone “booster” sessions to check whether they had entered treatment, review change plans, and reinforce motivation. The booster calls occurred within 7 days of the ED visit if possible, but up to 1 month was allowed to complete the calls if necessary. | 421 (99%) participants received the initial brief intervention, 243 (57%) received the first booster call, and 166 (39%) received the second booster call. 250 (58.5%) of participants were referred to addiction treatment | MI: Participants received an informational pamphlet about drug use and misuse, its potential consequences, and treatment options and optional referral to addiction treatment, consisting of a recommendation to seek treatment and a standardized list of available options.
Adults | Gelberg, 2015^87^ | All drugs | IG1 | Brief intervention + telephone coaching sessions | Participants received a face-to-face brief intervention during their clinician visit. Clinicians followed a paper scripted protocol “Summary to Clinician” provided by research staff based on the patients’ highest-scoring drug in risky range (HSD). The message covered drug addiction as a chronic brain disease, the need to quit or reduce using drugs to prevent this disease, the physical and mental consequences of drug use, and the potential accelerated progression towards severe substance use disorders caused by poly-substance use. If a participant scored in the risky range on multiple drugs, clinicians focused on the HSD, but also recommended reduction of the other drugs. If a participant scored in the risky range for a stimulant (methamphetamine, amphetamines, cocaine), clinicians focused on that stimulant even if it was not the HSD, since prior investigation found that stimulants were the most common serious drugs used illicitly by the patient population. Clinicians also told participants that they would receive telephone calls 2 and 6 weeks later from a health educator. Participants subsequently received a Drug Health Education Booklet with a Report Card for their HSD and viewed a video doctor (2 minutes) reinforcing the clinician message. The 2-week and 6-week telephone drug-use coaching sessions (20–30 minutes each) reinforced the clinicians’ message, and followed a patient-centered protocol, focusing on HSD use reduction. | All 171 intervention participants received clinician brief advice, and 134 (78%) had at least 1 telephone session (93 [54%] two sessions, 41 [24%] one session). | AC: Received a video doctor and information booklet on cancer screening. At study exit, participants were given all intervention materials and, if they scored 4 or higher for nay drugs on the 3-month ASSIST, with their permission the results were given to their doctor (although brief intervention for drug use was not provided to CG participants).
Adults | Gelberg, 2017^88^ | All drugs | IG1 | Brief intervention + telephone coaching sessions | Replication of Gelberg, 2015 intervention with minor modifications. | All 32 intervention participants received clinician brief advice (as reported on the clinician Intervention Plan), and 22 (69%) had at least 1 telephone session and 15 (47%) had both sessions. | AC: Participants received a video doctor and information booklet on cancer screening.
Adults | Gryczynski, 2016^112^ | All drugs | IG1 | Brief computer-based session | Computerized brief intervention consisting of a short, single-session interactive program led by an animated talking avatar. Participants’ choice was emphasized throughout, and participants were free to choose which substances to focus on (up to two) and what kinds of behavioral changes they were willing to make. The computer BI included questions about substance use problems, gender-specific normative feedback messaging, rating importance to change, and rating confidence (self-efficacy) to change. Participants received tailored messages and options based on their responses. | NR | WL
Adults | Humenuik, 2011^89^ | All drugs | IG1 | Brief intervention | Participants received a brief intervention (BI) linked to the results of the ASSIST screening questionnaire via the use of the ASSIST Feedback Report card. The BI focused on the drug receiving the highest moderate-risk specific substance involvement score on the ASSIST (for cannabis, cocaine, amphetamine-type stimulants, or opioids). If participants scored within the moderate-risk range for two or more of the target drugs, the intervention focused on the highest scoring substance or the substance that was of most concern to the participant. Discussion of the scores and their meaning comprised a major part of the BI, and participants took the card home with them. The BI incorporated motivational interviewing (MI) techniques, and each country developed their own culturally appropriate BI based on the principles of MI. The BI also comprised a take-home guide called Self-Help Strategies for Cutting Down or Stopping Substance Use. On average, sessions lasted 13.8 minutes. | Assume 100% of participants received brief intervention | WL: Participants were invited to contact the clinical interviewer if they had concerns about their substance use and were administered the brief intervention following the intervention period.
Adults | Martino, 2018^95^ | Alcohol, All drugs | IG1 | In-person brief intervention | Following screening, one 20-min intervention based on motivational interviewing to support the importance of, and a woman’s confidence in, cutting down or quitting substances and obtaining treatment. | 99% received the intervention | UC: Received 2-min interaction based on their ASSIST score and told about local treatments.
Adults | Martino, 2018^95^ | Alcohol, All drugs | IG2 | Computer-based brief intervention | Following screening, one 20-min computer-based, self-directed intervention based on motivational interviewing to support the importance of, and a woman’s confidence in, cutting down or quitting substances and obtaining treatment. The electronic sessions featured an interactive, 3-dimensional, mobile narrator that delivered the intervention. | 99% received the intervention | UC: Received 2-min interaction based on their ASSIST score and told about local treatments.
Adults | Poblete, 2017^102^ | Alcohol, All drugs | IG1 | Brief intervention based on FRAMES | Participants received an ASSIST-linked brief intervention for the substance with the highest score, and the ASSIST self-help guide, with additional information regarding substances and high-risk situation management. When two substances had the same score, the participant had the choice to decide which substance to receive counseling for. The intervention was based on the FRAME (Feedback, Responsibility, Advice, Menu Options, Empathy, and Self-Efficacy) model, which provides specific feedback, offers a menu of options, and enhances motivation to change. The average intervention time, including the initial screening was 17.6 minutes. | Assume 100% of participants received brief intervention | UC: Participants received a pamphlet of their own choosing containing broad information on substance use risk and harm.
Adults | Roy-Byrne, 2014^103^ | All drugs | IG1 | In-person personalized feedback + telephone booster session | Participants received a single brief (30-min) intervention in which interventionists provided feedback about their drug use screening results, explored pros and cons of drug use, increased participant confidence in their ability to change, and discussed opportunities to change. When appropriate, interventionists used an illustrated handout depicting the participant’s DAST-10 score and its associated problem severity (low, intermediate, substantial/severe) to aid the discussion and provided a list of substance abuse treatment resources. Interventionists used a motivational interviewing approach and tailored the intervention to allow for flexibility as to which or how many drugs to target, as well as in how to guide the participant (e.g., specialty treatment, abstinence, harm reduction). The same interventionist attempted a follow-up telephone booster session within 2 weeks of the intervention. | 97% received a brief intervention and 47% received a booster call. Brief intervention averaged 27 min. | UC: Participants received an illustrated handout depicting their DAST-10 drug problem severity score and list of substance abuse resources. Resembled the “notification and referral” strategy that might be implemented in high-quality usual care.
Adults | Saitz, 2014^104^ | All drugs | IG1 | Brief negotiated interview | Participants received a single 10- to 15-minute structured interview that used some features of motivational interviewing and included feedback, review of the “pros and cons” of use, and development of a plan for change. The interview focused on the participant’s main drug, but addressed alcohol and other drugs if they emerged as relevant. | All participants received intervention. | MI: Participants were given information on how to contact AA, NA, the hospital behavioral health clinic and emergency team, a state hotline, a city triage line, and websites for alcohol and drug screening.
Adults | Saitz, 2014^104^ | All drugs | IG2 | Motivational interviewing | Participants received 30 to 45 minutes of motivational interviewing with an offered 20- to 30-minute booster followup session. The interview elicited possible links between drug use and health concerns, heightening discrepancies between negative drug use outcomes and valued goals, enhancing self-efficacy about behavior change, and providing options for change. The interview focused on the participant’s main drug, but addressed alcohol and other drugs if they emerged as relevant. | All participants received 30–45 min motivational interviewing session, and 31% received the optional 20–30 min booster session.
Adults | Watkins, 2017^108^ | Alcohol, All drugs | IG1 | Collaborative care | The intervention included a population-based management approach, measurement-based care, and integration of addiction expertise through a RAND-based clinical psychologist affiliated with the Motivational Interviewing Network of Trainers. Along with therapy, participants had the option to use medication-assisted treatment (MAT) with sublingual buprenorphine/naloxone for opioid use or long-acting injectable naltrexone for alcohol use disorders. Care coordinators met with participants and encouraged them to meet with a therapist for evaluation and treatment planning. All participants were entered in a registry that tracked treatment progress and prompted care coordinators to reach out to patients with missed visits. Care coordinators conducted regular assessments of substance use; results were entered in the registry and reviewed during team meetings. | 98% were entered into the registry, 93% met with the care coordinator, 76% scheduled an appointment with a therapist, 45% kept the appointment, and 20% had at least 1 additional psychotherapy session. Sixteen of the 24 clinicians who were trained prescribed XR-NTX and 11 of the 12 waivered prescribers prescribed BUP/NX; overall 61% prescribed MAT. | UC: Participants were told by the research team that the clinic provided opioid, alcohol, and other drug treatment and given a number for appointment scheduling and list of community referrals. They did not receive any additional outreach or contact.
Adults | Woolard, 2013^109^ | Alcohol, Cannabis | IG1 | Brief motivational interviewing | Participants received two brief interventions guided by the principles of motivational interviewing. The goal of the first brief intervention was to engage the participant in reflection upon the pros and cons of alcohol and marijuana use. The intervention incorporated the following elements of motivational interviewing: 1) feedback; 2) emphasis on personal responsibility for change; 3) advice with permission; 4) a menu of alternative change options; 5) an empathic interventionist style; and 6) fostering patient self-efficacy. The interventionist provided direct feedback concerning the participant’s alcohol and marijuana use compared to community norms. The participant and interventionist developed a change plan that addressed the changes the participant wanted to make, usually focused on reduction of substance use. If the participant was not ready to change substance use, the interventionist worked with the participant to increase motivation for change. The interventionists discussed with participants the pros and cons of alcohol and marijuana use and explored their conjoint use, and the effect that conjoint use had on the pros and cons. The focus of the second brief intervention session was to review and reinforce the change and create a change plan with those who had not made a change plan in the first session. In addition to the brief intervention sessions, participants received routine emergency care for their presenting medical complaint and were offered information on local treatment resources for substance misuse. | 51% returned to second intervention session | UC: Participants received routine emergency care for their presenting medical complaint and were offered information on local treatment resources for substance misuse.
Adults | Zahradnik, 2009^111^ | Prescrip-tion drugs | IG1 | Motivational interviewing | Participants received two motivational interviewing sessions. The first 30–45 minute session took place in the hospital; the second session, 4 weeks later, was conducted by phone. The intervention was based on the Transtheoretical Model of behavior change. Participants received an individualized feedback letter eight weeks after the first intervention. which was sent to study participants 8 weeks after the first intervention. When appropriate, strategies for improving self-efficacy and maintaining changes were included in the feedback letter. In each step of the intervention, it was pointed out that it was necessary to discontinue or reduce the medication only with help from professionals, e.g. the general practitioner or a medical specialist. | NR | UC: Informational booklet about prescription drugs.
Postpartum women | Ondersma, 2007^99^ | All drugs | IG1 | Computer-based brief intervention | Participants received a 20-minute single-session computer-delivered brief intervention. The intervention consisted of three components based on motivational interviewing and brief intervention principles: (1) feedback regarding the negative consequences of drug use that the participant reported, as well as self-reported readiness to change, and drug use as compared to that of all adult women; (2) pros and cons of drug use and related change, in which the participant chose from lists of positive and negative aspects of drug use from their perspective; and (3) a summary and query regarding the participant’s interest in change, followed by optional goal-setting regarding drug use. Throughout the intervention section, the animated narrator reflected back the participant’s answers, emphasized that whether or not to change was up to the participant, and expressed optimism regarding the possibility of success. In addition, participants received two non-tailored mailings 4 and 9 weeks after the intervention and were offered free taxi transportation for electing to attend a treatment intake/substance abuse evaluation at a local agency. | NR | None: CG received no intervention.
Postpartum women | Ondersma, 2014^98^ | All drugs | IG1 | Computer-based personalized feedback (eCHECKUP TO GO) | Participants received six 30-min individual behavioral therapy sessions that involved a combination of motivational enhancement therapy (MET) and cognitive behavioral therapy (CBT). The content included motivational enhancement, functional analysis, safe sexual behavior, communication skills, relapse prevention and problem-solving skills. Research nurse therapists had the flexibility to offer additional sessions or repeat topics if there was time and need. An unlimited number of sessions was available in pregnancy and up to 2 booster sessions after delivery although the manual included 6 total sessions. | 4.3% did not receive the intervention, 23.9% received 1–2 sessions, and 60.9% received ≥3 sessions. Women in CG attended an average of 7 treatment visits while IG subjects attended an average of 5 visits. Average time in treatment was 7.12 (SD 3.57) minutes for CG and 148.17 (SD 97.34) minutes for IG participants. An average of 5.88 sessions and 3.89 sessions were received in pregnancy by the CG and IG, respectively. | UC: Participants received one minute of brief advice based on a manualized version of standard interventions offered by obstetrical doctors and nurses. The manual, used by the participant’s obstetrical provider, provided guidance on the risks of substance use, the importance of abstinence, and the benefit of seeking drug and alcohol treatment outside of the prenatal setting.
Postpartum women | Ondersma, 2018^100^ | All drugs | IG1 | Computer-based brief intervention focused on parenting | Participants received an indirect computerized, interactive intervention with an animated talking narrator and natural-language reflections. The intervention was patterned after motivational interviewing principles and used tailoring on multiple elements to present each participant with unique content. Participants began the intervention by completing a brief assessment of substance use, mental health, relationship safety, exposure to violence, risky sexual behaviors, ethnic identity, and religiosity. Upon completing the assessment, participants received a video-based orientation to the intervention, described as “The Parent Check-up (PCU)”, which was tailored to their ethnic identity and religiosity. After the video, the intervention focused on key parenting strengths, first focusing a strength identified by participants provided during the assessment process, and then discussing the four key strengths that facilitate infant growth and development (emotional health, safety, physical health, and a healthy home). The video touched on substance use but did not focus on it exclusively. After the video, participants received a feedback report indicating which of the four strengths were already strengths, and which might be considered a growth area. Participants were asked for their thoughts regarding that feedback and were offered the option of changing in one of the four areas or ending the PCU. | 100% received intervention | AC: Participants watched educational videos about infant nutrition from birth to age one (i.e., breastfeeding, formula feeding, when to introduce solids) with no mention of safety, emotional health, or substance use.
Pregnant women | Tzilos Wernette, 2017^106^ | Alcohol, Cannabis | IG1 | Health Checkup for Expectant Moms computerized program | Participants interacted with a computer and were guided by an animated narrator, which engages in a motivational interviewing-consistent style, can use emotionally expressive statements and empathic reflection. Health Checkup for Expectant Moms (HCEM), a 60-minute computer-delivered session, was self-administered with the assistance of a research assistant (RA) and included a behavioral skills component, in which the RA facilitated the setup of models for male and female condom use application. This portion of HCEM included video instruction that was guided by a computer. HCEM presented information and education regarding health risks and included testimonial videos of women who were HIV positive and pictures of STIs. All participants had the option to create a personalized safety plan that was tailored and designed to increase awareness of the interconnected risk factors for STI/HIV and alcohol/drug use in the woman’s life. At the 15-minute booster session, the narrator reviewed the components of the intervention session (e.g., goal-setting), and participants reviewed their personalized plan and identified any barriers to increasing safety behaviors. Participants also received brochures specifically designed to reduce risky behaviors during pregnancy | 100% completed HCEM program; 97% completed booster session | AC: Participants interacted with the computer and were guided by the same narrator used for intervention group participants. Participants watched brief segments of popular television shows with subsequent questions for ratings of their subjective preference. Participants also received brochures specifically designed to reduce risky behaviors during pregnancy.
Pregnant women | Yonkers, 2012^110^ | Alcohol, all drugs | IG1 | MET-CBT | Participants completed a 20-min screening and brief intervention on tablets. The intervention comprised a mobile, 3-dimensional cartoon character capable of ≥50 animated actions that read each item for the participant, acted as narrator and guide throughout the process, and actively sought a nonjudgmental, empathic, and nonthreatening demeanor using reflections and self-deprecating humor. The experience of working with the software was intended to be highly interactive, with immediate responses to most input, occasional summaries, branching based on participant characteristics, responses, or preferences, and empathic reflection branches/approaches based on participant reports of current drug use and type of drug use, as well as on participants’ stated plans regarding drug use after going home. The intervention was broken down into components focusing on (a) eliciting the participant’s thoughts about change and their perceived advantages of doing so, if any; (b) reviewing feedback regarding how the participant’s drug use compares to that of others, and of possible benefits of changing; and (c) optional goal-setting, including a menu of change options. The intervention allowed participant input (e.g., whether or not to see more information on a certain topic), and used different branches/approaches based on participant reports of current drug use and type of drug use, as well as on participants’ stated plans regarding drug use after going home. Participants listened to the narrator via headphones to ensure privacy. | NR | AC: Participants were asked a number of questions about their preferences in music and television, were shown brief video clips consistent with their preferences, and were asked to provide feedback regarding their opinion of the various video clips.

Abbreviations: AA = Alcoholics Anonymous; AC = attention control; CBT = cognitive behavioral therapy; CG = control group; FRAMES = Feedback, Responsibility, Advice, Menu Options, Empathy and Self-Efficacy; IG = intervention group; MET = motivational enhancement therapy; MI = motivational interviewing; NA = Narcotics Anonymous; NR = not reported; target subs = substance(s) targeted by the intervention; UC = usual care; WL = waitlist

##### Detailed Results: Drug Use and Other Risky Behaviors (KQ 4a)

All three trials reported the effects of the interventions on self-reported frequency of drug and alcohol use at 3- to 12-month followup (Table 12).^96,^ ^107^ In general, there was no difference between change in drug use at 3, 6 and 12 months among adolescents taking part in one individual counseling session versus those taking part in usual care or attention control conditions. One trial reported small effects of the intervention on the frequency of cannabis use over 6 months among males, but not among females or the full sample.^96^ A secondary, exploratory analysis of 46 participants reporting heavy cannabis use at baseline (10 or more days of use in the past month), found a greater probability of heavy cannabis use at 6 months in the control group (38.1%) versus those in the intervention (16.6%).^97^ Despite one trial’s intervention targeting cannabis use only, the only statistically significant benefit was limited to the frequency of non-cannabis drug use at 6 months among adolescents randomized to the computer-based, but not therapist-led, brief intervention.^107^ This same trial also observed no statistically significant changes in the frequency of driving under the influence of cannabis within or between any of the groups over time.^107^ The remaining trial found no differences in self-reported frequency or quantity of cannabis use at 3-, 6-, or 12-months followup.^78^ No differences in the frequency of alcohol use were reported within these trials. Effects of the interventions on other behavioral measures such as risky sexual behaviors were not reported by these two trials.

Table 12 Results for Drug Use (KQ 4a) for Trials Among Adolescents

Author, year | Outcome | Scale range^*^ | Recall (mo.) | Arm (subgrp) | FU | IG n | IG BL mean (sd) | IG FU mean (sd) | IG % mean change (sd) | CG n | CG BL mean (sd) | CG FU mean (sd) | CG mean change (sd) | Study-reported between group difference^†^ | Study-reported p-value
D’Amico, 2018^78^ | Cannabis use frequency | NA | 3^‡^ | IG1 | 3 | 153 | 10.02; (8.51) | 6.38; (8.05) | NR | 141 | 9.51; (8.31) | 5.95; (7.58) | NR | 0.00 | 0.99
D’Amico, 2018^78^ | Cannabis use frequency | NA | 3^‡^ | IG1 | 6 | 153 | 10.02; (8.51) | 6.13; (7.9) | NR | 141 | 9.51; (8.31) | 5.07; (6.83) | NR | 0.11 | 0.35
D’Amico, 2018^78^ | Cannabis use frequency | NA | 3^‡^ | IG1 | 12 | 153 | 10.02; (8.51) | 6.76; (8.37) | NR | 141 | 9.51; (8.31) | 5.21; (7.35) | NR | 0.14 | 0.23
D’Amico, 2018^78^ | Number of times used cannabis on days used | NA | 3^‡^ | IG1 | 3 | 153 | 1.54; (1.15) | 1.34; (1.16) | NR | 141 | 1.51; (1.15) | 1.22; (1.1) | NR | 0.09 | 0.41
D’Amico, 2018^78^ | Number of times used cannabis on days used | NA | 3^‡^ | IG1 | 6 | 153 | 1.54; (1.15) | 1.14; (1.16) | NR | 141 | 1.51; (1.15) | 1.18; (1.16) | NR | -0.04 | 0.73
D’Amico, 2018^78^ | Number of times used cannabis on days used | NA | 3^‡^ | IG1 | 12 | 153 | 1.54; (1.15) | 1.18; (1.2) | NR | 141 | 1.51; (1.15) | 1.06; (1.16) | NR | 0.05 | 0.64
Mason, 2015^96^ | Cannabis use days | 0–7^§^ | 1 | IG1 (Males) | 3 | 15 | 1.59; (NR) | 1.43; (NR) | NR | 20 | 1.11; (NR) | 1.26; (NR) | NR | NR | NR
Mason, 2015^96^ | Cannabis use days | 0–7^§^ | 1 | IG1 (Females) | 3 | 44 | 1.06; (NR) | 1.10; (NR) | NR | 40 | 1.78; (NR) | 1.40; (NR) | NR | NR | NR
Mason, 2015^96^ | Cannabis use days | 0–7^§^ | 1 | IG1 (Males) | 6 | 15 | 1.59; (NR) | 1.28; (NR) | NR | 20 | 1.11; (NR) | 1.44; (NR) | NR | 0.37 | NR
Mason, 2015^96^ | Cannabis use days | 0–7^§^ | 1 | IG1 (Females) | 6 | 44 | 1.06; (NR) | 1.13; (NR) | NR | 40 | 1.78; (NR) | 1.28; (NR) | NR | NR, NS | NR
Walton, 2013^107^ | Cannabis use frequency | 0–6^ǁ^ | 3 | IG1 | 3 | 118 | 3.14; (1.86) | 2.37; (2.13) | -24.5; (≤0.01) | 110 | 3.25; (1.87) | 2.09; (2.06) | -35.7 (≤0.01) | -0.18 (0.13) | 0.16
Walton, 2013^107^ | Cannabis use frequency | 0–6^ǁ^ | 3 | IG2 | 3 | 100 | 3.06; (1.90) | 2.05; (2.25) | -33.0; (≤0.01) | 110 | 3.25; (1.87) | 2.09; (2.06) | -35.7 (≤0.01) | -0.08 (0.15) | 0.57
Walton, 2013^107^ | Cannabis use frequency | 0–6^ǁ^ | 3 | IG1 | 6 | 118 | 3.14; (1.86) | 2.40; (2.11) | -23.6; (NR) | 110 | 3.25; (1.87) | 2.04; (2.10) | -37.2 (NR) | 0.25 (0.14) | 0.08
Walton, 2013^107^ | Cannabis use frequency | 0–6^ǁ^ | 3 | IG2 | 6 | 100 | 3.06; (1.90) | 1.96; (2.05) | -35.9; (NR) | 110 | 3.25; (1.87) | 2.04; (2.10) | -37.2 (NR) | 0.08 (0.16) | 0.62
Walton, 2013^107^ | Cannabis use frequency | 0–6^ǁ^ | 3 | IG1 | 12 | 118 | 3.14; (1.86) | 2.63; (2.20) | -19.1; (NR) | 110 | 3.25; (1.87) | 2.14; (2.21) | -31.1 (NR) | 0.15 (0.14) | 0.28
Walton, 2013^107^ | Cannabis use frequency | 0–6^ǁ^ | 3 | IG2 | 12 | 100 | 3.06; (1.90) | 2.04; (2.20) | -32.7; (NR) | 110 | 3.25; (1.87) | 2.14; (2.21) | -31.1 (NR) | -0.03 (0.16) | 0.85
Walton, 2013^107^ | Other drug use frequency | 0–6^ǁ^ | 3 | IG1 | 3 | 118 | 0.47; (1.29) | 0.26; (0.92) | -44.7; (≤0.05) | 110 | 1.16; (2.71) | 1.18; (4.13) | 1.7 (NR) | 0.61 (0.39) | 0.12
Walton, 2013^107^ | Other drug use frequency | 0–6^ǁ^ | 3 | IG2 | 3 | 100 | 0.86; (3.01) | 0.16; (0.62) | -81.4; (≤0.05) | 110 | 1.16; (2.71) | 1.18; (4.13) | 1.7 (NR) | 1.82 (0.68) | <0.01
Walton, 2013^107^ | Other drug use frequency | 0–6^ǁ^ | 3 | IG1 | 6 | 118 | 0.47; (1.29) | 0.26; (0.93) | -44.7; (NR) | 110 | 1.16; (2.71) | 1.19; (4.64) | 2.6 (NR) | -0.48 (0.42) | 0.255
Walton, 2013^107^ | Other drug use frequency | 0–6^ǁ^ | 3 | IG2 | 6 | 100 | 0.86; (3.01) | 0.11; (0.45) | -87.2; (NR) | 110 | 1.16; (2.71) | 1.19; (4.64) | 2.6 (NR) | -1.41 (0.52) | <0.01
Walton, 2013^107^ | Other drug use frequency | 0–6^ǁ^ | 3 | IG1 | 12 | 118 | 0.47; (1.29) | 0.38; (1.70) | -19.1; (NR) | 110 | 1.16; (2.71) | 0.64; (2.12) | -39.7 (NR) | 0.33 (0.51) | 0.52
Walton, 2013^107^ | Other drug use frequency | 0–6^ǁ^ | 3 | IG2 | 12 | 100 | 0.86; (3.01) | 0.48; (2.13) | -44.2; (NR) | 110 | 1.16; (2.71) | 0.64; (2.12) | -39.7 (NR) | 0.21 (0.48) | 0.66
Walton, 2013^107^ | Frequency of cannabis DUI | 0–5^¶^ | 3 | IG1 | 3 | 118 | 0.40; (0.93) | 0.20; (0.65) | -50.0; (≤0.05) | 110 | 0.26; (0.66) | 0.32; (0.83) | 23.1 (NR) | 0.87 (0.33) | <0.01
Walton, 2013^107^ | Frequency of cannabis DUI | 0–5^¶^ | 3 | IG2 | 3 | 100 | 0.48; (1.06) | 0.37; (0.94) | -22.9; (NR) | 110 | 0.26; (0.66) | 0.32; (0.83) | 23.1 (NR) | 0.55 (0.35) | 0.11
Walton, 2013^107^ | Frequency of cannabis DUI | 0–5^¶^ | 3 | IG1 | 6 | 118 | 0.40; (0.93) | 0.26; (0.79) | -35.0 | 110 | 0.26; (0.66) | 0.37; (0.90) | 42.3 | -0.68 (0.41) | 0.10
Walton, 2013^107^ | Frequency of cannabis DUI | 0–5^¶^ | 3 | IG2 | 6 | 100 | 0.48; (1.06) | 0.46; (1.05) | -4.2 | 110 | 0.26; (0.66) | 0.37; (0.90) | 42.3 | -0.34 (0.37) | 0.36
Walton, 2013^107^ | Frequency of cannabis DUI | 0–5^¶^ | 3 | IG1 | 12 | 118 | 0.40; (0.93) | 0.33; (0.90) | -17.5 | 110 | 0.26; (0.66) | 0.25; (0.85) | -3.8 | -0.32 (0.41) | 0.44
Walton, 2013^107^ | Frequency of cannabis DUI | 0–5^¶^ | 3 | IG2 | 12 | 100 | 0.48; (1.06) | 0.45; (0.99) | -6.2 | 110 | 0.26; (0.66) | 0.25; (0.85) | -3.8 | -0.17 (0.44) | 0.70

* Low value indicates better outcome for all scales

† D’Amico, 2018 and Mason, 2015 reported Cohen’s d effect size. Walton, 2013 reported mean difference and standard error

‡ Baseline measurement reflects number of times used cannabis in the past year whereas measures at 3-, 6-, and 12-months reflect number of times used cannabis in the past 3 months

§ Categorical responses where 0 = 0 days, 1 = 1–2 days, 2 = NR, 3 = 3–5 days, 4 = 6–9 days, 5 = 10–19 days, 6 = 20–29 days, and 7 = all 30 days

ǁ Categorical responses where 0 = never, 1= 1–2 days, 2 = once a month or less, 3= 2–3 days per month, 4 = 1–2 days per week, 5 = 3–5 days per week, and 6 = every day or almost every day

¶ Categorical responses (assumed) where 0 = never, 1 = 1–2 times, 2 = 3–5 times, 3 = 6–9 times, 5 = 10 or more times

Abbreviations: BL = baseline; CG = control group; DUI = driving under the influence; FU = followup; IG = intervention group; mo. = months; n = number; NR = not reported; NS = not statistically significant; recall = period of time respondents are asked to recall their substance use; sd = standard deviation; subgrp = subgroup

##### Detailed Results: Health, Social, and Legal Outcomes (KQ 4b)

Two of the three trials among adolescents reported effects on health, social, or legal outcomes, specifically cannabis-related consequences (n=622) (Table 13).^107^ In one trial, the mean number of cannabis-related consequences (e.g., had a fight, argument, bad feelings with a friend; missed out on other things because you spent too much money on cannabis; kept smoking when you promised yourself not to) significantly decreased among adolescents in the therapist-led brief intervention over time (baseline, 14.2; 3 months, 12.5; 6 months, 11.3; 12 months, 11.1) and among adolescents in the computer-based brief intervention from baseline (14.3) to 3 months (11.5) and 6 months (10.5), while no significant change was seen in the control group (baseline, 14.0; 3 months, 13.6; 6 months, 11.0; 12 months, 11.5). Differences in these changes were not statistically difference between groups at 6 or 12 months; only the change in the number of cannabis-related consequences at 3 months for the computer-based intervention participants was significantly improved compared with the control group (mean difference in change, −0.24 [standard error, 0.12], p<0.05). In the other trial, the number of cannabis-related consequences decreased among intervention participants while they increased among control group participants and a statistically significant effect was found at 12 months (p=0.04); this difference was not apparent, however, at 3- or 6-months followup.^78^

Table 13 Results for Health, Social, and Legal Outcomes (KQ 4b) for Trials Among Adolescents

Author, year | Outcome | Scale range | Recall (mo.) | Arm | FU | IG n | IG BL mean (sd) | IG FU mean (sd) | IG % mean change (sd) | CG n | CG BL mean (sd) | CG FU mean (sd) | CG % mean change (sd) | Study-reported between group mean difference(se)^*^ | Study-reported p-value
D’Amico, 2018^78^ | Cannabis-related consequences | 0–20^†^ | 3^‡^ | IG1 | 3 | 153 | 3.58; (10.46) | 1.67; (5.19) | NR | 141 | 4.63; (12.54) | 1.89; (7.19) | NR | 0.01 | 0.93
D’Amico, 2018^78^ | Cannabis-related consequences | 0–20^†^ | 3^‡^ | IG1 | 6 | 153 | 3.58; (10.46) | 0.70; (1.54) | NR | 141 | 4.63; (12.54) | 1.46; (5.67) | NR | -0.20 | 0.16
D’Amico, 2018^78^ | Cannabis-related consequences | 0–20^†^ | 3^‡^ | IG1 | 12 | 153 | 3.58; (10.46) | 0.92; (3.26) | NR | 141 | 4.63; (12.54) | 2.36; (9.29) | NR | -0.28 | 0.04
Walton, 2013^107^ | Cannabis-related consequences | 0–28^§^ | 3 | IG1 | 3 | 118 | 14.2; (15.3) | 12.5; (12.5) | -11.7; (NR) | 110 | 14.0; (15.0) | 13.6; (15.1) | -2.6 (NR) | -0.18 (0.12) | 0.15
Walton, 2013^107^ | Cannabis-related consequences | 0–28^§^ | 3 | IG2 | 3 | 100 | 14.3; (15.5) | 11.5; (15.0) | -19.7; (≤0.01) | 110 | 14.0; (15.0) | 13.6; (15.1) | -2.6 (NR) | -0.24 (0.12) | <0.05
Walton, 2013^107^ | Cannabis-related consequences | 0–28^§^ | 3 | IG1 | 6 | 118 | 14.2; (15.3) | 11.3; (12.9) | -20.4 | 110 | 14.0; (15.0) | 11.0; (13.6) | -20.9 | -0.08 (0.15) | 0.60
Walton, 2013^107^ | Cannabis-related consequences | 0–28^§^ | 3 | IG2 | 6 | 100 | 14.3; (15.5) | 10.5; (13.6) | -26.6 | 110 | 14.0; (15.0) | 11.0; (13.6) | -20.9 | -0.15 (0.16) | 0.37
Walton, 2013^107^ | Cannabis-related consequences | 0–28^§^ | 3 | IG1 | 12 | 118 | 14.2; (15.3) | 11.1; (13.0) | -21.8 | 110 | 14.0; (15.0) | 11.5; (14.4) | -17.9 | -0.07 (0.15) | 0.62
Walton, 2013^107^ | Cannabis-related consequences | 0–28^§^ | 3 | IG2 | 12 | 100 | 14.3; (15.5) | 12.7; (13.8) | -6.7 | 110 | 14.0; (15.0) | 11.5; (14.4) | -17.9 | 0.08 (0.17) | 0.62

* D’Amico, 2018 reported Cohen’s d effect size.

† Adolescents rated how often they experienced a particular negative consequence in the past year or past 3 months on a scale from 0 (never) to 7 (20 or more times). Items were rescaled to a pseudo-continuous variable ranging from 0 to 20 using the midpoint of any range as the new value (e.g., 3–5 times was recoded as 4 times) and then summed to create a total score indicating the number of negative consequences experienced

‡ Baseline measurement reflects number of times used cannabis in the past year whereas measures at 3-, 6-, and 12-months reflect number of times used cannabis in the past 3 months

§ Included 23 items from the adapted version of the Rutgers Alcohol Problems Index (Marijuana Problem Inventory) and 5 items from the Severity of Dependence Scale where endorsement of an item = 1 and no endorsement = 0. Low value indicates better outcome.

Abbreviations: BL = baseline; CG = control group; FU = followup; IG = intervention group; mo. = months; n = number; recall = period of time respondents are asked to recall their substance use; sd = standard deviation; se = standard error

##### Detailed Results: Harms (KQ 5)

None of the three trials among adolescents reported on harms related to the intervention.

#### Adults

##### Study, Population, and Intervention Characteristics

Nineteen (n=8110) (sample size range 65 to 1175) evaluated the effectiveness of interventions to reduce drug use among young adults or adults (Table 8).^80–83,^ ^87–89,^ ^93–95,^ ^101–105,^ ^108,^ ^109,^ ^111,^ ^112^ All but two trials^89,^ ^102^ took place in the United States. Five trials recruited primarily white young adults with a mean age of ranging from 18 to 20.5 years whereas the remaining 14 trials targeted adults 18 and older. The latter trials among adults generally represented both younger adults and middle-aged adults (mean age ranged from 28.4 to 55.1 years), mostly male (74%), non-white (14% to 86%), and lower socioeconomic adults. When reported, a history of or current homelessness was common (30 to 61%) as were rates of medical comorbidities (e.g., 56% with at least one mental health illness, 46% with a mood disorder, 85% with a comorbidity such as hypertension, HIV, or depression). In most trials, participants were recruited and universally screened for drug use upon presenting to primary care clinics, including walk-in and reproductive health clinics (e.g., student health, urgent care, women’s, and homeless clinics),^81,^ ^89,^ ^95,^ ^101,^ ^112^ safety-net primary care clinics,^103^ Federally Qualified Health Centers,^87,^ ^88,^ ^108^ and urban primary care clinics.^104^ Five trials recruited, screened, and intervened within an emergency department^80,^ ^82,^ ^83,^ ^102,^ ^109^ and one^111^ recruited patients being admitted to an internal, surgical, or gynecologic ward of a hospital. The remaining trials directly recruited incoming college students via mail^93,^ ^94^ or through generic advertising.^105^

The methods of screen detection, drugs targeted, and eligibility criteria varied across the trials (Table 9). All five trials among young adults focused on reducing cannabis use whereas most of the trials among general adults targeted adults at moderate risk of drug use or a drug use disorder for any drug type. Four focused on specific drugs including one trial that targeted use of cocaine and/or heroin^81^, one that targeted alcohol and opioid use,^108^ one that targeted alcohol and cannabis use,^109^ and one that targeted prescription drug misuse.^111^ Few studies^87–89,^ ^95,^ ^102,^ ^105,^ ^112^ excluded adults who screened at high risk for a drug use disorder (e.g., ASSIST score ≥27, meeting criteria for drug dependence); in those that did, only one^89^ had a formal referral process in place for substance use treatment. As a result, rates of current drug use at baseline were high in most trials; however, within notable variability within trials. For instance, the prevalence of cannabis use in the past 30 days ranged from 44 to 76 percent, the prevalence of cocaine use ranged from 9 to 93, and the prevalence of opioid use (illicit and prescribed) ranged from 4 to 45 percent (in trials reporting these measures). In studies that reported it, participants were averaging drug use on about half of the days of the month. Only four trials reported the proportion of participants with a drug use disorder or drug dependence at baseline; in all four trials approximately one-third to one-half of the sample had cannabis dependence,^105^ a cannabis use disorder,^95^ heroin or prescription opioid abuse or dependence,^108^ or prescription drug dependence.^111^

Despite the range in drug use and risk for a drug use disorder within and between trials, the included interventions (22 interventions in 19 trials) were generally similar in content and intensity (Table 10 and Table 11). All but one intervention^108^ was a brief intervention provided during one to two sessions ranging in length from 3 minutes to 60 minutes per session. In most of the interventions, counseling was provided in-person by trained peers, social workers, health educators, or mental or behavioral health specialists. Only four trials included interaction with a primary care provider.^87,^ ^88,^ ^95,^ ^108^ Four trials tested a computer-based, self-directed brief intervention.^82,^ ^93,^ ^101,^ ^112^ About one-third of the interventions also provided booster telephone counseling sessions occurring approximately 2 weeks following the in-person counseling session, although completion of these telephone calls was generally low. The content of the sessions was generally the same, comprising personalized normative feedback and using features of motivational interviewing to establish rapport and discuss the links between drug use and health concerns, heighten discrepancies between negative drug use outcomes and valued goals, enhance self-efficacy about behavior change, and provide options for change. Only two trials^81,^ ^83^ specifically offered referrals for further drug use treatment following brief intervention; several others provided general information on drug treatment options in their communities. The one remaining trial consisted of a system-level collaborative care intervention designed to facilitate treatment for a probable opioid or alcohol use disorder.^108^ Patients in the intervention group met with a care coordinator to assess motivation and encourage patients to meet with a therapist for evaluation and treatment planning and all patients were tracked and re-contacted to evaluate treatment progress. Treatment within the clinic included a 6-session brief psychotherapy treatment and/or medication-assisted therapy (MAT) with either sublingual buprenorphine/naloxone for opioid use disorders or long-acting injectable naltrexone for alcohol use disorders. All therapists and clinicians were offered training (and waivered in the case of MAT) to provide treatment. The comparators in these trials included usual primary care or minimal interventions such as generic information for drug use treatment options in their local community.

##### Detailed Results: Drug Use and Other Risky Behaviors (KQ 4a)

There was no consistent evidence of a benefit of brief interventions on self-reported drug use compared with controls at 3-, 6-, or 12-months followup within the trials among screen-detected adults (n analyzed=7090) (Table 14). The measured outcomes were variable, including days of drug use (for cannabis specifically, the “primary” or most frequently used drug, or any drug), number of joints smoked, drug use abstinence/discontinuation (for specific drugs or any drugs), and drug use severity as measured by the Addiction Severity Index or ASSIST. Only one study^108^ reported the proportion of participants meeting the criteria for drug abuse or dependence and few studies confirmed self-reported drug use with biologic confirmation.

Table 14 Results for Drug Use (KQ 4a) for Trials Among Young Adults and Adults

Target pop | Author, year | Outcome | Recall (mo) | Arm | FU (mo) | IG n | IG BL mean (sd)^*^ | IG FU mean (sd)^†^ | CG n | CG BL mean (sd)^*^ | CG FU mean (sd)^†^ | Study-reported between group difference | Study-reported p-value
Young Adults | Bernstein, 2009^80^ | Cannabis use days | 1 | IG1 | 3 | 41 | 19.0 (10.9) | 14.2 (10.8) | 54 | 15.3 (10.1) | 13.7 (11.2) | -4.2 (-8.1 to -0.3) | 0.039
Young Adults | Bernstein, 2009^80^ | Cannabis use days | 1 | IG1 | 12 | 47 | 19.0 (10.9) | 11.0 (10.7) | 55 | 15.3 (10.1) | 13.2 (11.7) | -5.3 (-10.0 to -0.6) | 0.024
Young Adults | Bernstein, 2009^80^ | Cannabis abstinence^‡^ | 1 | IG1 | 3 | 42 | 0 | 6 (14.3) | 54 | 0 | 7 (12.7) | OR=1.15 (0.36 to 3.73) | 0.814
Young Adults | Bernstein, 2009^80^ | Cannabis abstinence^‡^ | 1 | IG1 | 12 | 47 | 0 | 21 (44.7) | 55 | 0 | 12 (21.8) | OR=2.89 (1.22 to 6.84) | 0.014
Young Adults | Lee, 2010^93^ | Cannabis use days | 3 | IG1 | 3 | 171 | 9.9 (15.8) | 9.1 (14.1) | 170 | 9.8 (16.2) | 9.1 (15.8) | NR | NR, NS
Young Adults | Lee, 2010^93^ | Cannabis use days | 3 | IG1 | 6 | 171 | 9.9 (15.8) | 11.1 (18.7) | 170 | 9.8 (16.2) | 11.9 (19.3) | NR | NR, NS
Young Adults | Lee, 2013^94^ | Cannabis use days | 1 | IG1 | 3 | 86 | 16.5 (8.2) | 14.1 (10.1) | 93 | 15.6 (8.8) | 14.9 (10.8) | RR=0.96 (0.80 to 1.15)^§^ | NR, NS
Young Adults | Lee, 2013^94^ | Cannabis use days | 1 | IG1 | 6 | 89 | 16.5 (8.2) | 13.2 (10.6) | 84 | 15.6 (8.8) | 11.7 (11.1) | RR=1.11 (0.85 to 1.43)^§^ | NR, NS
Young Adults | Lee, 2013^94^ | Joints smoked^ǁ^ | 2 | IG1 | 3 | 89 | 9.4 (9.8) | 6.9 (8.2) | 95 | 8.3 (8.8) | 8.5 (9.8) | RR=0.76 (0.0.60 to 0.96)^§^ | <0.05
Young Adults | Lee, 2013^94^ | Joints smoked^ǁ^ | 2 | IG1 | 6 | 90 | 9.4 (9.8) | 7.3 (8.4) | 87 | 8.3 (8.8) | 7.5 (10.7) | RR=1.46 (0.73 to 1.46)^§^ | NR, NS
Young Adults | Palfai, 2014^101^ | Cannabis use days | 3 | IG1 | 3 | 54 | 30.3 (28.4) | 30.3 (30.3) | 49 | 39.6 (28.4) | 38.3 (32.0) | NR | NR, NS
Young Adults | Palfai, 2014^101^ | Cannabis use days | 3 | IG1 | 6 | 54 | 30.3 (28.4) | 29.3 (29.7) | 49 | 39.6 (28.4) | 37.1 (32.4) | NR | NR, NS
Young Adults | Stein, 2011^105^ | Any cannabis use^‡^ | 3 | IG1 | 3 | 163 | 163 (100.0) | NR | 169 | 169 (100.0) | NR | OR=0.53 (0.33 to 0.86) | <0.01
Young Adults | Stein, 2011^105^ | Any cannabis use^‡^ | 3 | IG1 | 6 | 163 | 163 (100.0) | NR | 169 | 169 (100.0) | NR | OR=0.74 (0.47 to 1.17) | 0.202
Adults | Bernstein, 2005^81^,^¶^ | Cocaine and opiates abstinence^‡^,^#^ | 1 | IG1 | 6 | 403^**^ | 0 (0.0) | 70 (17.4) | 375^**^ | 0 (0.0) | 48 (12.8) | OR=1.51 (0.98 to 2.26) | 0.052
Adults | Bernstein, 2005^81^,^¶^ | Cocaine abstinence^‡^,^#^ | 1 | IG1 | 6 | 376 | 0 (0.0) | 84 (22.3) | 344 | 0 (0.0) | 58 (16.9) | OR=1.51 (1.01 to 2.24) | 0.045
Adults | Bernstein, 2005^81^,^¶^ | Opiates abstinence^‡^,^#^ | 1 | IG1 | 6 | 189 | 0 (0.0) | 76 (40.2) | 160 | 0 (0.0) | 49 (30.6) | OR=1.57 (1.00 to 2.47) | 0.05
Adults | Bernstein, 2005^81^,^¶^ | Cocaine levels^††^ | 1 | IG1 | 6 | 376 | 616 (NR) | 436 (NR) | 344 | 485 (NR) | 464 (NR) | NR | 0.058
Adults | Bernstein, 2005^81^,^¶^ | Opiate levels^††^ | 1 | IG1 | 6 | 189 | 26.4 (NR) | 18.8 (NR) | 160 | 30.7 (NR) | 22.9 (NR) | NR | 0.186
Adults | Bernstein, 2005^81^,^¶^ | Severity of disorder (ASI - Drug)^‡‡^ | 1 | IG1 | 6 | 490 | 0.3 (0.1) | NR | 472 | 0.2 (0.1) | NR | NR | 0.06
Adults | Bernstein, 2005^81^,^¶^ | Severity of disorder (ASI - Medical)^‡‡^ | 1 | IG1 | 6 | 490 | 0.6 (0.3) | NR | 472 | 0.5 (0.4) | NR | NR | 0.055
Adults | Blow, 2017^82^ | Drug use days | 3 | IG1 | 3 | 104 | 41.9 (33.5) | 39.7 (35.8) | 106 | 56.0 (34.6) | 51.1 (37.1) | NR | NR
Adults | Blow, 2017^82^ | Drug use days | 3 | IG2 | 3 | 95 | 47.9 (34.8) | 46.8 (35.7) | 106 | 56.0 (34.6) | 51.1 (37.1) | NR | NR
Adults | Blow, 2017^82^ | Drug use days | 3 | IG1 | 6 | 110 | 41.9 (33.5) | 34.5 (35.8) | 114 | 56.0 (34.6) | 48.2 (39.0) | NR | NR
Adults | Blow, 2017^82^ | Drug use days | 3 | IG2 | 6 | 105 | 47.9 (34.8) | 43.5 (37.7) | 114 | 56.0 (34.6) | 48.2 (39.0) | NR | NR
Adults | Blow, 2017^82^ | Drug use days | 3 | IG1 | 12 | 112 | 41.9 (33.5) | 30.7 (34.7) | 110 | 56.0 (34.6) | 44.3 (38.1) | ES=-0.24 (-0.41 to -0.07) | <0.05
Adults | Blow, 2017^82^ | Drug use days | 3 | IG2 | 12 | 108 | 47.9 (34.8) | 42.7 (37.0) | 110 | 56.0 (34.6) | 44.3 (38.1) | ES=-0.13 (-0.28 to 0.03) | NR, NS
Adults | Blow, 2017^82^ | Cannabis use days | 3 | IG1 | 3 | 104 | 35.6 (34.6) | 34.5 (35.7) | 130 | 50.3 (36.3) | 45.1 (38.2) | NR | NR
Adults | Blow, 2017^82^ | Cannabis use days | 3 | IG2 | 3 | 95 | 43.3 (36.2) | 43.4 (36.2) | 130 | 50.3 (36.3) | 45.1 (38.2) | NR | NR
Adults | Blow, 2017^82^ | Cannabis use days | 3 | IG1 | 6 | 110 | 35.6 (34.6) | 31.0 (35.1) | 130 | 50.3 (36.3) | 43.2 (39.5) | NR | NR
Adults | Blow, 2017^82^ | Cannabis use days | 3 | IG2 | 6 | 105 | 43.3 (36.2) | 40.2 (37.6) | 130 | 50.3 (36.3) | 43.2 (39.5) | NR | NR
Adults | Blow, 2017^82^ | Cannabis use days | 3 | IG1 | 12 | 112 | 35.6 (34.6) | 28.3 (35.0) | 130 | 50.3 (36.3) | 41.4 (38.3) | ES=-0.24 (-0.42 to -0.06) | <0.05
Adults | Blow, 2017^82^ | Cannabis use days | 3 | IG2 | 12 | 108 | 43.3 (36.2) | 41.5 (37.8) | 130 | 50.3 (36.3) | 41.4 (38.3) | ES=-0.17 (-0.34 to -0.01) | <0.05
Adults | Bogenschutz, 2014^83^ | Drug use days^§§^ | 1 | IG1 | 3 | 375 | 14.8 (11.2) | 9.4 (11.7) | 382 | 16.3 (11.4) | 10.9 (12.1) | MD=0.70 (-0.83 to 2.23) | 0.57
Adults | Bogenschutz, 2014^83^ | Drug use days^§§^ | 1 | IG1 | 6 | 375 | 14.8 (11.2) | 8.2 (11.2) | 382 | 16.3 (11.4) | 9.7 (11.6) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use days^§§^ | 1 | IG1 | 12 | 375 | 14.8 (11.2) | 8.6 (11.2) | 382 | 16.3 (11.4) | 7.9 (11.1) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use days | 1 | IG1 | 3 | 375 | 16.4 (11.0) | 11.9 (12.0) | 382 | 18.5 (10.9) | 13.7 (12.4) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use days | 1 | IG1 | 6 | 375 | 16.4 (11.0) | 10.8 (12.1) | 382 | 18.5 (10.9) | 12.5 (12.2) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use days | 1 | IG1 | 12 | 375 | 16.4 (11.0) | 10.7 (11.8) | 382 | 18.5 (10.9) | 10.9 (12.1) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use abstinence^‡^,^††^,^§§^ | 3 | IG1 | 3 | 275 | 20 (5.7) | 31 (11.3) | 280 | 25 (7.4) | 15 (5.4) | NR | 0.02
Adults | Bogenschutz, 2014^83^ | Drug use abstinence^‡^,^††^,^§§^ | 3 | IG1 | 6 | 282 | 20 (5.7) | 38 (13.5) | 282 | 25 (7.4) | 27 (9.6) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use abstinence^‡^,^††^,^§§^ | 3 | IG1 | 12 | 265 | 20 (5.7) | 45 (17.0) | 268 | 25 (7.4) | 46 (17.2) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use abstinence^‡^,^††^ | 3 | IG1 | 3 | 274 | 9 (2.4) | 11 (4.0) | 285 | 9 (2.6) | 7 (2.4) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use abstinence^‡^,^††^ | 3 | IG1 | 6 | 275 | 9 (2.4) | 8 (2.9) | 282 | 9 (2.6) | 6 (2.1) | NR | NR, NS
Adults | Bogenschutz, 2014^83^ | Drug use abstinence^‡^,^††^ | 3 | IG1 | 12 | 260 | 9 (2.4) | 19 (7.3) | 264 | 9 (2.6) | 13 (4.9) | NR | NR, NS
Adults | Gelberg, 2015^87^ | Drug use days^§§^ | 1 | IG1 | 3 | 129 | 10.6 (NR) | 7.1 (5.8 to 8.5) | 132 | 10.7 (NR) | 9.9 (8.5 to 11.2) | MD=2.68 (0.76 to 4.60) | <0.01
Adults | Gelberg, 2017^88^ | Drug use days^§§^ | 1 | IG1 | 3 | 23 | 11.4 (11.2) | 6.6 (NR) | 28 | 12.4 (10.6) | 12.9 (NR) | MD=5.28 (-0.06 to 10.6) | 0.053
Adults | Gelberg, 2017^88^ | Any drug use^‡ǁǁǁ^ | 1 | IG1 | 3 | 21 | 21 (100) | 5 (25) | 26 | 26 (100) | 15 (56) | OR=0.10 (0.01 to 0.99) | <0.05
Adults | Gryczynski, 2016^112^ | ASSIST, total score | 3 | IG1 | 3 | 36 | 26.4 (9.5) | 24.4 (4.2)^¶¶¶^ | 35 | 34.2 (13.8) | 27.8 (4.3)^¶¶¶^ | β=-2.0 (2.7) | 0.46
Adults | Humenuik, 2011^89^ | ASSIST, total score | 3 | IG1^§§§^ | 3 | 103 | 34.9 (22.3) | 31.1 (19.7) | 115 | 39.0 (24.6) | 31.3 (18.7) | NR | 0.11
Adults | Humenuik, 2011^89^ | ASSIST, cannabis score | 3 | IG1^§§§^ | 3 | 74 | 16.8 (7.7) | 15.1 (9.5) | 72 | 16.2 (6.7) | 12.3 (7.0) | NR | 0.08
Adults | Humenuik, 2011^89^ | ASSIST, stimulant score^ǁǁ^ | 3 | IG1^§§§^ | 3 | 23 | 20.9 (7.9) | 16.2 (11.8) | 33 | 18.5 (7.6) | 13.2 (10.5) | NR | 0.8
Adults | Martino, 2018^95^ | Substance use days^###^ | 1 | IG1 | 3 | 145 | 22.8 (21.4 to 24.3) | 16.6 (14.8 to 18.6) | 151 | 23.5 (22.2 to 24.9) | 19.5 (18.1 to 21.1) | NR | NR
Adults | Martino, 2018^95^ | Substance use days^###^ | 1 | IG2 | 3 | 143 | 23.9 (22.4 to 25.5) | 16.9 (15.0 to 19.0) | 151 | 23.5 (22.2 to 24.9) | 19.5 (18.1 to 21.1) | NR | NR
Adults | Martino, 2018^95^ | Substance use days^###^ | 1 | IG1 | 6 | 145 | 22.8 (21.4 to 24.3) | 16.3 (14.4 to 18.5) | 151 | 23.5 (22.2 to 24.9) | 17.9 (16.1 to 19.9) | β=-0.032 (-0.115 to 0.052) | 0.461
Adults | Martino, 2018^95^ | Substance use days^###^ | 1 | IG2 | 6 | 143 | 23.9 (22.4 to 25.5) | 16.3 (14.3 to 18.7) | 151 | 23.5 (22.2 to 24.9) | 17.9 (16.1 to 19.9) | β=-0.016 (-0.068 to 0.100) | 0.706
Adults | Poblete, 2017^102^ | ASSIST, total score | 3 | IG1 | 3 | 400 | 27.1 (9.2) | 28.1 (14.4) | 406 | 26.6 (9.7) | 27.9 (15.0) | MD=-0.13 (-1.47 to 1.74) | NR, NS
Adults | Poblete, 2017^102^ | ASSIST, cannabis score | 3 | IG1 | 3 | 143 | 9.6 (4.6) | 10.4 (6.4) | 144 | 10.0 (4.3) | 9.8 (6.7) | MD=-.021 (-1.25 to 1.66) | NR, NS
Adults | Poblete, 2017^102^ | ASSIST, cocaine score | 3 | IG1 | 3 | 41 | 11.1 (5.1) | 11.1 (9.2) | 53 | 10.4 (5.1) | 10.3 (8.5) | MD=-0.11 (-3.69 to 3.48) | NR, NS
Adults | Roy-Byrne, 2014^103^ | Drug use days^§§^ | 1 | IG1 | 3 | 378 | 14.4 (11.3) | 12.0 (12.1) | 389 | 13.3 (10.7) | 9.8 (10.6) | β=0.89 (-0.49 to 2.26) | NR, NS
Adults | Roy-Byrne, 2014^103^ | Drug use days^§§^ | 1 | IG1 | 6 | 381 | 14.4 (11.3) | 11.8 (10.6 to 13.0) | 389 | 13.3 (10.7) | 10.5 (9.5 to 11.7) | NR | NR, NS
Adults | Roy-Byrne, 2014^103^ | Drug use days^§§^ | 1 | IG1 | 9 | 377 | 14.4 (11.3) | 11.4 (10.3 to 12.7) | 384 | 13.3 (10.7) | 10.4 (9.4 to 11.6) | NR | NR, NS
Adults | Roy-Byrne, 2014^103^ | Drug use days^§§^ | 1 | IG1 | 12 | 435 | 14.4 (11.3) | 11.5 (10.3 to 12.7) | 433 | 13.3 (10.7) | 10.0 (9.0 to 11.3) | OR=1.20 (0.96 to 1.50)^¶¶^ | NR, NS
Adults | Roy-Byrne, 2014^103^ | Severity of disorder (ASI - Drug)^§§^ | 1 | IG1 | 3 | 370 | 0.11 (0.1) | 0.1 (0.09) | 379 | 0.1 (0.1) | 0.09 (0.09) | β=0.008 (-0.006 to 0.021) | NR, NS
Adults | Roy-Byrne, 2014^103^ | Severity of disorder (ASI - Drug)^§§^ | 1 | IG1 | 6 | 374 | 0.11 (0.1) | 0.1 (0.1 to 0.1) | 373 | 0.1 (0.1) | 0.1 (0.1 to 0.1) | NR | NR, NS
Adults | Roy-Byrne, 2014^103^ | Severity of disorder (ASI - Drug)^§§^ | 1 | IG1 | 9 | 372 | 0.11 (0.1) | 0.1 (0.1 to 0.1) | 375 | 0.1 (0.1) | 0.1 (0.1 to 0.1) | NR | NR, NS
Adults | Roy-Byrne, 2014^103^ | Severity of disorder (ASI - Drug)^§§^ | 1 | IG1 | 12 | 435 | 0.11 (0.1) | 0.1 (0.1 to 0.1) | 433 | 0.1 (0.1) | 0.1 (0.1 to 0.1) | β=0.005 (-0.005 to 0.016) | NR, NS
Adults | Saitz, 2014^104^ | Drug use days | 1 | IG1 | 6 | 169 | 15.1 (11.7) | 14.2 (12.5) | 175 | 14.3 (11.4) | 13.8 (12.1) | IRR=0.97 (0.77 to 1.22)^##^ | 0.81
Adults | Saitz, 2014^104^ | Drug use days | 1 | IG2 | 6 | 173 | 13.8 (11.2) | 14.1 (12.1) | 175 | 14.3 (11.4) | 13.8 (12.1) | IRR=1.05 (0.84 to 1.32)^##^ | 0.81
Adults | Saitz, 2014^104^ | Drug use days >1 time | 1 | IG1 | 6 | 169 | 10.5 (11.1) | 10.8 (12.0) | 175 | 9.6 (11.1) | 9.1 (11.3) | IRR=1.20 (0.86 to 1.66)^##^ | 0.31
Adults | Saitz, 2014^104^ | Drug use days >1 time | 1 | IG2 | 6 | 173 | 9.4 (11.1) | 11.1 (12.2) | 175 | 9.6 (11.1) | 9.1 (11.3) | IRR=1.19 (0.86 to 1.65)^##^ | 0.31
Adults | Saitz, 2014^104^ | Any drug use^‡,**^ | 3 | IG1 | 6 | 169 | 160 (97.0) | 150 (94.9) | 175 | 157 (95.7) | 150 (91.5) | OR=1.65 (0.65 to 4.21) | 0.57
Adults | Saitz, 2014^104^ | Any drug use^‡,**^ | 3 | IG2 | 6 | 173 | 157 (95.7) | 152 (93.2) | 175 | 157 (95.7) | 150 (91.5) | OR=1.29 (0.54 to 3.06) | 0.57
Adults | Saitz, 2014^104^ | Severity of disorder (ASSIST score)^***^ | 3 | IG1 | 6 | 169 | 21.8 (18.4) | 24.8 (17.1) | 175 | 22.9 (19.5) | 25.8 (19.4) | β=-1.00 (-3.62 to 1.62) | 0.50
Adults | Saitz, 2014^104^ | Severity of disorder (ASSIST score)^***^ | 3 | IG2 | 6 | 173 | 22.0 (18.6) | 25.9 (19.9) | 175 | 22.9 (19.5) | 25.8 (19.4) | β=0.73 (-1.41 to 2.87) | 0.50
Adults | Watkins, 2017^108^ | Opioid or any alcohol abstinence^‡^ | 1 | IG1 | 6 | 138 | NA | 45 (32.8) | 123 | NA | 27 (22.3) | ES=0.10 (0.01 to 0.23) | 0.03
Adults | Watkins, 2017^108^ | Opioid, any alcohol, cocaine, methamphetamine, and marijuana abstinence^‡^ | 1 | IG1 | 6 | 138 | NA | 36 (26.3) | 123 | NA | 19 (15.6) | ES=0.13 (0.03 to 0.23) | 0.01
Adults | Watkins, 2017^108^ | Opioid abstinence^‡^ | 1 | IG1 | 6 | 138 | 135 (72.0) | 122 (8.7) | 123 | 129 (67.9) | 98 (79.9) | ES=0.07 (-0.07 to 0.22) | 0.33
Adults | Watkins, 2017^108^ | Heroin abstinence^‡^ | 1 | IG1 | 6 | 138 | 156 (83.4) | 129 (93.5) | 123 | 152 (80.0) | 110 (89.4) | NR | NR
Adults | Watkins, 2017^108^ | Prescription opioid abstinence^‡^ | 1 | IG1 | 6 | 138 | 145 (77.5) | 124 (89.9) | 123 | 144 (75.8) | 115 (93.5) | NR | NR
Adults | Watkins, 2017^108^ | Cocaine abstinence^‡^ | 1 | IG1 | 6 | 138 | 152 (81.3) | 120 (87.0) | 123 | 163 (85.8) | 109 (88.6) | NR | NR
Adults | Watkins, 2017^108^ | Methamphetamine abstinence^‡^ | 1 | IG1 | 6 | 138 | 141 (75.4) | 125 (90.6) | 123 | 140 (73.7) | 100 (81.3) | NR | NR
Adults | Watkins, 2017^108^ | Heroin abuse or depend^‡^,^†††^ | 1 | IG1 | 6 | 138 | 51 (27.0) | 34 (24.6) | 123 | 64 (34.0) | 36 (29.3) | NR | NR
Adults | Watkins, 2017^108^ | Prescription opioid abuse or depend^‡^,^†††^ | 1 | IG1 | 6 | 138 | 32 (17.1) | 25 (18.1) | 123 | 27 (14.2) | 17 (13.8) | NR | NR
Adults | Woolard, 2013^109^ | Alcohol and cannabis conjoint use days | 1 | IG1 | 3 | 211 | 6.5 (5.7 to 7.3) | 2.0 (1.3 to 3.0) | 224 | 6.2 (5.4 to 7.0) | 2.7 (1.9 to 3.6) | NR | NR
Adults | Woolard, 2013^109^ | Alcohol and cannabis conjoint use days | 1 | IG1 | 12 | 206 | 6.5 (5.7 to 7.3) | 1.3 (0.8 to 1.5) | 220 | 6.2 (5.4 to 7.0) | 2.2 (1.6 to 2.9) | NR | 0.02
Adults | Woolard, 2013^109^ | Cannabis use days | 1 | IG1 | 3 | 211 | 12.8 (11.4 to 14.3) | 10.7 (9.1 to 12.3) | 224 | 12.4 (11.0 to 13.8) | 10.6 (9.0 to 12.2) | NR | NR
Adults | Woolard, 2013^109^ | Cannabis use days | 1 | IG1 | 12 | 206 | 12.8 (11.4 to 14.3) | 9.4 (7.8 to 11.0) | 220 | 12.4 (11.0 to 13.8) | 10.0 (8.4 to 11.6) | NR | 0.83
Adults | Woolard, 2013^109^ | Heavy cannabis use days^‡‡‡^ | 1 | IG1 | 3 | 211 | 5.3 (4.5 to 6.2) | 4.8 (3.4 to 6.3) | 224 | 4.9 (4.2 to 5.6) | 3.5 (2.3 to 4.8) | NR | NR
Adults | Woolard, 2013^109^ | Heavy cannabis use days^‡‡‡^ | 1 | IG1 | 12 | 206 | 5.3 (4.5 to 6.2) | 3.2 (2.2 to 4.5) | 220 | 4.9 (4.2 to 5.6) | 3.6 (2.5 to 5.0) | NR | 0.30
Adults | Zahradnik, 2009^111^ | Prescription drug abstinence^‡^ | 1 day | IG1 | 3 | 56 | NA | 10 (17.9) | 70 | NA | 6 (8.6) | ES: 0.28 | 0.17
Adults | Zahradnik, 2009^111^ | Prescription drug abstinence^‡^ | 1 day | IG1 | 12 | 56 | NA | 14 (25.0) | 70 | NA | 14 (20.0) | OR=1.42 (0.57 to 3.52) | 0.45

* Baseline n may differ from n analyzed

† Or 95% CI as reported

‡ n (%)

§ Rate ratio calculated using negative binomial regression models

ǁ Number of joints smoked during a typical week

¶ Analysis of outcomes was limited to 778/1175 participants who had biologically confirmed cocaine or heroin use at baseline

# n analyzed = n positive at baseline

** Cocaine or opiates

†† Based on hair sample (units = ng/10 mg)

‡‡ Scale range 0–1, where lower scores indicate better outcomes

§§ For the most frequently used drug

ǁǁ Among those eligible for a cocaine or amphetamine-type stimulant brief intervention

¶¶ Odds ratio calculated using negative binomial regression models

## Incidence rate ratio calculated using negative binomial regression models

*** Scale range 0–273, where lower scores indicate better outcomes

††† With or without cooccurring alcohol or prescription opioid/heroin abuse or dependence

‡‡‡ Defined as being “somewhat high” or “very high” on days used cannabis

§§§ Results for US sample only

ǁǁǁ Based on urine samples

¶¶¶ Standard error

### Any substance use (including nicotine, cannabis, alcohol, and other drugs)

Abbreviations: ASI = Addiction Severity Index; ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; BL = baseline; CG = control group; CI = confidence interval; ES = effect size; FU = followup; IG = intervention group; IRR = incidence rate ratio; MD = mean difference; mo. = months; NR = not reported; NS = not statistically significant; OR = odds ratio; pop = population; recall = period of time respondents are asked to recall their substance use; RR = rate ratio; sd = standard deviation

The most commonly reported outcome was the number of days using drugs in the past 30 or 90 days (Table 14). In general, self-reported drug use days decreased in both the intervention and control groups over time, with no statistically significant differences between groups. The absolute change in drug use days in intervention and controls groups ranged considerably. Across studies, changes in drug use days ranged from an increase of 1.2 days/90 days (0.1/7 days) to a decrease of 8 days/30 days (-1.9/7 days) among intervention participants. Among control participants, the range was an increase of 2.1 days/90 days (0.2/7 days) to a decrease of 8.4 days/30 days (-2.0/7 days). In a pooled analysis of nine trials that reported mean changes in drug use days at 3 months followup, the mean difference in change in past 7-day use of drugs between intervention and control groups was not statistically significant (mean difference [MD], −0.08 [95% CI, −0.27 to 0.10]; k=9; n=3183; I^2^=18.6%) (Figure 9). Likewise, no association was found between brief interventions and drug use days in the last 7-days in trials reporting longer term followup at 6- to 12-months (MD, −0.00 [95% CI, −0.26 to 0.20]; k=10; n=3632; I^2^=32.3%) (Figure 10).

Of the eight trials that reported a binary outcome of use vs. no use or drug use abstinence, four fair-quality trials found a statistically significant reduction in the proportion of participants using drugs at followup although the effects were generally small and inconsistent across drug types and different followup time points within studies (Table 14).^80,^ ^81,^ ^88,^ ^105^ For instance, in the two trials among young adults that reported the odds of cannabis use at followup, one found an effect of the intervention at 12 but not 3 months^80^ and the other found an effect at 3, but not 6 months.^105^ In the small pilot replication study of Project QUIT, 5 of 21 patients in the intervention group (25%) versus 15 out of 26 patients in the control group (56%) self-reported using their “highest scoring drug” (aka, primary drug) at 3 months following a brief intervention and up to 2 phone calls over 6 weeks (OR, 0.10 [95% CI, 0.10 to 0.99], p<0.05).^88^ Outcomes at longer term followup were not measured in this study. Finally, one trial among 778 adults with moderate-to-severe cocaine and heroin use reported a borderline statistically significant benefit of one motivational interviewing session on biologically confirmed use of cocaine and/or opiates at 6 months (intervention group: 17.4% vs. control group: 12.8%; adjusted OR, 1.51 [95% CI, 0.98 to 2.26], p=0.052).^81^ However, the same study found no statistically significant effect for levels of cocaine and heroin use as measured by hair samples at 6 months (p=0.058 for cocaine and p=0.186 for heroin). There were no differences between groups in the rates of abstinence or use in the remaining four trials.

The effects of the interventions on other behavioral outcomes such as alcohol use or risky sexual behaviors were consistent with the drug use outcomes, finding no benefit.

##### Detailed Results: Health, Social, and Legal Outcomes (KQ 4b)

Eleven of the 19 trials among adults (n analyzed=3833) reported the effects of the interventions on health, social, or legal outcomes with none finding a statistically significant effect after 3 to 12-months of followup (Table 15). Among young adults, all five studies^80,^ ^93,^ ^94,^ ^101,^ ^105^ reported the effects of the interventions on cannabis-related consequences as measured by the Rutgers Marijuana Problem Index or Marijuana Problem Scale, although modifications were evident and the number of items and scales differed across all five trials. Example items included: “driving after cannabis use,” “not able to do your homework or study for a test,” “missed out on other things because you spent too much money on marijuana,” and “had intense anxiety or panic attacks.” Where reported, scores decreased^94,^ ^101^ or slightly increased^80,^ ^93^ within both intervention and control groups from baseline to 3–12 months, and no statistically significant differences were seen between groups. Among adults, no differences were seen in changes in quality of life,^87,^ ^104,^ ^108^ drug use consequences,^103,^ ^104,^ ^108,^ ^109^ mental health symptoms,^104^ or healthcare utilization,^95,^ ^103,^ ^104,^ ^108^ including entering substance use treatment. In the ASPIRE trial,^91,^ ^104^ despite the brief interventions including formal referral to treatment when indicated, no differences were found between intervention and control groups in the receipt of additional treatment within the 6 months following study entry. Among persons taking part in the brief intervention (one 10- to 15-minute structured interview), 18 percent received any additional treatment versus 17 percent of those in the control group (adjusted odds ratio, 1.11 [95% CI, 0.57, 2.15], p=0.76). In contrast, persons taking part in the 2-session motivational interviewing arm had lower odds of receiving treatment (10%) versus those in the control group (17%) (adjusted OR, 0.36 [95% CI, 0.17, 0.78], p=0.02).^91^

Table 15 Results for Health, Social, and Legal Outcomes (KQ 4b) for Trials Among Young Adults and Adults

Target pop | Author, year | Outcome | Scale range | Recall (mo) | Arm | FU | IG n | IG BL mean (sd) | IG FU mean (sd) | CG n | CG BL mean (sd) | CG FU mean (sd) | Study-reported between group difference | Study-reported p-value
Young adults | Bernstein, 2009^80^ | Drove after cannabis use^ǁ^ | NA | 1 | IG1 | 3 | 42 | 8 (14.5) | 6 (14.3) | 55 | 9 (14.1) | 10 (18.2) | OR=0.82 (0.24 to 2.76) | 0.745
Young adults | Bernstein, 2009^80^ | Drove after cannabis use^ǁ^ | NA | 1 | IG1 | 12 | 47 | 8 (14.5) | 8 (17.0) | 55 | 9 (14.1) | 13 (23.6) | OR=0.60 (0.12 to 1.75) | 0.352
Young adults | Bernstein, 2009^80^ | Rode in car with person high after cannabis use^ǁ^ | NA | 1 | IG1 | 3 | 42 | 12 (21.8) | 11 (26.2) | 55 | 11 (17.2) | 13 (23.6) | OR=1.01 (0.39 to 2.62) | 0.985
Young adults | Bernstein, 2009^80^ | Rode in car with person high after cannabis use^ǁ^ | NA | 1 | IG1 | 12 | 47 | 12 (21.8) | 10 (21.3) | 55 | 11 (17.2) | 13 (23.6) | OR=0.81 (0.31 to 2.10) | 0.668
Young adults | Lee, 2010^93^ | Cannabis-related consequences | 0–90^*^ | 2 | IG1 | 3 | 171 | 2.11 (2.69) | 2.47 (3.77) | 170 | 1.86 (2.23) | 1.99 (2.76) | NR | NR, NS
Young adults | Lee, 2010^93^ | Cannabis-related consequences | 0–90^*^ | 2 | IG1 | 6 | 171 | 2.11 (2.69) | 2.59 (3.96) | 170 | 1.86 (2.23) | 2.19 (2.95) | NR | NR, NS
Young adults | Lee, 2013^94^ | Cannabis-related consequences | 0–100^†^ | 2 | IG1 | 3 | 87 | 10.45 (4.9) | 7.84 (4.9) | 90 | 10.38 (5.9) | 8.67 (6.0) | RR=0.90 (0.76 to 1.07) | <0.10
Young adults | Lee, 2013^94^ | Cannabis-related consequences | 0–100^†^ | 2 | IG1 | 6 | 82 | 10.45 (4.9) | 6.54 (5.3) | 83 | 10.38 (5.9) | 6.75 (6.5) | RR=1.15 (0.9 to 1.47) | NR, NS
Young adults | Palfai, 2014^101^ | Cannabis-related consequences | 0–19^‡^ | 3 | IG1 | 3 | 54 | 3.74 (3.89) | 2.19 (3.00) | 49 | 4.51 (3.72) | 3.43 (3.74) | NR | NR
Young adults | Palfai, 2014^101^ | Cannabis-related consequences | 0–19^‡^ | 3 | IG1 | 6 | 54 | 3.74 (3.89) | 2.12 (2.51) | 49 | 4.51 (3.72) | 2.97 (1.72) | β=0.66 (0.53) | >0.05
Young adults | Stein, 2011^105^ | Cannabis-related consequences | 0–38^§^ | 3 | IG1 | 3 | 163 | 4.82 (4.66) | NR | 169 | 4.99 (4.71) | NR | β=-0.40 | 0.353
Young adults | Stein, 2011^105^ | Cannabis-related consequences | 0–38^§^ | 3 | IG1 | 6 | 163 | 4.82 (4.66) | NR | 169 | 4.99 (4.71) | NR | β=-0.10 | 0.89
Adults | Gelberg, 2015^87^ | QOL, mental health component^§§^ | 0–100 | NA | IG1 | 3 | 129 | 42.69 (12.57) | 43.71 (11.78) | 132 | 42.94 (12.28) | 44.39 (12.21) | MD=0.25 (NR) | 0.848
Adults | Gelberg, 2015^87^ | QOL, physical health component^§§^ | 0–100 | NA | IG1 | 3 | 129 | 42.97 (12.11) | 45.07 (12.18) | 132 | 43.1 (12.01) | 44.47 (12.21) | MD=1.59 (NR) | 0.115
Adults | Martino, 2018^95^ | Entered substance use treatment or self-help program | NA | 6 | IG1 | 6 | 145 | NA | NR | 151 | NA | NR | OR=0.391 (0.559 to 1.551) | 0.810
Adults | Martino, 2018^95^ | Entered substance use treatment or self-help program | NA | 6 | IG2 | 6 | 143 | NA | NR | 151 | NA | NR | OR=0.968 (0.579 to 1.617) | 0.990
Adults | Roy-Byrne, 2014^103^ | All-cause mortality^ǁ^ | NA | NA | IG1 | 12 | 426 | NA | 10 (2.0) | 422 | NA | 7 (2.0) | OR=1.42 (0.54 to 3.78) | 0.48
Adults | Roy-Byrne, 2014^103^ | Consequences - Employment | 0–1 | 1 | IG1 | 12 | 426 | 0.79 (0.23) | 0.78 (0.24) | 422 | 0.79 (0.23) | 0.78 (0.24) | β=0.006 (-0.016 to 0.028) | 0.58
Adults | Roy-Byrne, 2014^103^ | Consequences - Family/social | 0–1 | 1 | IG1 | 12 | 426 | 0.17 (0.22) | 0.11 (0.18) | 422 | 0.17 (0.22) | 0.13 (0.20) | β=-0.020 (-0.046 to 0.006) | 0.14
Adults | Roy-Byrne, 2014^103^ | Consequences - Legal | 0–1 | 1 | IG1 | 12 | 426 | 0.06 (0.12) | 0.04 (0.10) | 422 | 0.07 (0.15) | 0.04 (0.12) | β=0.000 (-0.014 to 0.014) | 0.95
Adults | Roy-Byrne, 2014^103^ | Consequences - Medical | 0–1 | 1 | IG1 | 12 | 426 | 0.65 (0.32) | 0.54 (0.35) | 422 | 0.66 (0.35) | 0.56 (0.36) | β=-0.004 (-0.050 to 0.042) | 0.86
Adults | Roy-Byrne, 2014^103^ | Consequences - Psychiatric | 0–1 | 1 | IG1 | 12 | 426 | 0.37 (0.24) | 0.31 (0.26) | 422 | 0.39 (0.24) | 0.32 (0.26) | β=0.004 (-0.026 to 0.034) | 0.79
Adults | Roy-Byrne, 2014^103^ | Drug treatment admissions^ǁ¶^ | NA | 12 | IG1 | 12 | 426 | 37 (8.7) | 60 (14.1) | 422 | 53 (12.6) | 57 (13.5) | OR=1.16 (0.77 to 1.73) | 0.48
Adults | Roy-Byrne, 2014^103^ | Inpatient hospitalizations^ǁ^ | NA | 12 | IG1 | 12 | 426 | 113 (26.5) | 106 (24.9) | 422 | 108 (25.6) | 98 (23.2) | OR=1.09 (0.78 to 1.51) | 0.62
Adults | Roy-Byrne, 2014^103^ | Emergency department visits^ǁ^ | NA | 12 | IG1 | 12 | 426 | 215 (50.5) | 204 (47.8) | 422 | 213 (50.5) | 198 (46.9) | OR=1.04 (0.76 to 2.06) | 0.77
Adults | Roy-Byrne, 2014^103^ | Outpatient visits^ǁ^ | NA | 12 | IG1 | 12 | 426 | 381 (89.4) | 402 (94.4) | 422 | 380 (90.0) | 399 (94.5) | OR=1.00 (0.53 to 1.88) | 0.99
Adults | Roy-Byrne, 2014^103^ | Felony or gross misdemeanor arrests^ǁ^ | NA | 12 | IG1 | 12 | 426 | 36 (8.5) | 41 (9.6) | 426 | 43 (10.2) | 37 (8.8) | OR=1.21 (0.74 to 1.98) | 0.45
Adults | Saitz, 2014^91,^ ^104^ | Consequences | 0–45^#^ | 1 | IG1 | 6 | 169 | 9.3 (11.8) | 12.1 (13.8) | 175 | 11.3 (13.3) | 9.4 (12.1) | IRR=0.95 (0.71 to 1.26) | 0.71
Adults | Saitz, 2014^91,^ ^104^ | Consequences | 0–45^#^ | 1 | IG2 | 6 | 173 | 9.2 (11.3) | 12.7 (13.7) | 175 | 11.3 (13.3) | 9.4 (12.1) | IRR=1.11 (0.83 to 1.47) | 0.71
Adults | Saitz, 2014^91,^ ^104^ | Anxiety^ǁ^** | NA | NA | IG1 | 6 | 169 | 59 (33.9) | 49 (29.0) | 175 | 57 (32.2) | 59 (33.7) | NR | NR
Adults | Saitz, 2014^91,^ ^104^ | Anxiety^ǁ^** | NA | NA | IG2 | 6 | 173 | 60 (33.9) | 55 (31.8) | 175 | 57 (32.2) | 59 (33.7) | NR | NR
Adults | Saitz, 2014^91,^ ^104^ | Depression^ǁ††^ | NA | NA | IG1 | 6 | 169 | 63 (36.2) | 43 (25.4) | 175 | 60 (33.9) | 57 (32.6) | NR | NR
Adults | Saitz, 2014^91,^ ^104^ | Depression^ǁ††^ | NA | NA | IG2 | 6 | 173 | 66 (37.3) | 53 (30.8) | 175 | 60 (33.9) | 57 (32.6) | NR | NR
Adults | Saitz, 2014^91,^ ^104^ | Health-related QOL | 0–100^‡‡^ | NA | IG1 | 6 | 169 | 70.8 (18.8) | 71.5 (19.4) | 175 | 71.5 (19.6) | 72.1 (20.6) | NR | NR
Adults | Saitz, 2014^91,^ ^104^ | Health-related QOL | 0–100^‡‡^ | NA | IG2 | 6 | 173 | 68.5 (22.4) | 68.5 (20.7) | 175 | 71.5 (19.6) | 72.1 (20.6) | NR | NR
Adults | Saitz, 2014^91,^ ^104^ | ED visit^ǁ^ for addiction or mental health | NA | 3 | IG1 | 6 | 169 | 12 (6.9) | 13 (7.7) | 175 | 18 (10.2) | 17 (9.7) | OR=0.79 (0.36 to 1.76) | 0.57
Adults | Saitz, 2014^91,^ ^104^ | ED visit^ǁ^ for addiction or mental health | NA | 3 | IG2 | 6 | 173 | 17 (9.6) | 11 (6.4) | 175 | 18 (10.2) | 17 (9.7) | OR=0.63 (0.27 to 1.44) | 0.54
Adults | Saitz, 2014^91,^ ^104^ | Hospitalization for addiction or mental health^ǁ^ | NA | 3 | IG1 | 6 | 169 | 12 (6.9) | 10 (5.9) | 175 | 7 (4.0) | 8 (4.6) | OR=0.95 (0.29 to 3.09) | 1.00
Adults | Saitz, 2014^91,^ ^104^ | Hospitalization for addiction or mental health^ǁ^ | NA | 3 | IG2 | 6 | 173 | 10 (5.7) | 12 (7.0) | 175 | 7 (4.0) | 8 (4.6) | OR=1.44 (0.49 to 4.42) | 1.00
Adults | Saitz, 2014^91,^ ^104^ | Specialty treatment for addiction or mental health^ǁ^ | NA | 3 | IG1 | 6 | 169 | NR | 53 (31.4) | 175 | NR | 44 (25.1) | OR=1.41 (0.83 to 2.39) | 0.41
Adults | Saitz, 2014^91,^ ^104^ | Specialty treatment for addiction or mental health^ǁ^ | NA | 3 | IG2 | 6 | 173 | NR | 51 (29.5) | 175 | NR | 44 (25.1) | OR=0.98 (0.57 to 1.68) | 0.93
Adults | Saitz, 2014^91,^ ^104^ | Receipt of any addiction treatment^ǁ^ | NA | 6 | IG1 | 6 | 174 | NR | 31 (17.8) | 177 | NR | 30 (16.9) | OR=1.11 (0.57 to 2.15) | 0.76
Adults | Saitz, 2014^91,^ ^104^ | Receipt of any addiction treatment^ǁ^ | NA | 6 | IG2 | 6 | 177 | NR | 17 (9.6) | 177 | NR | 30 (16.9) | OR=0.36 (0.17 to 0.78) | 0.02
Adults | Watkins, 2017^108^ | Consequences | 0–15^#^ | 1 | IG1 | 6 | 138 | 9.1 (4.9) | 7.0 (5.9) | 123 | 9.6 (4.8) | 6.2 (5.5) | ES=1.55 (-0.21 to 3.31) | 0.08
Adults | Watkins, 2017^108^ | ED visit or hospital stay^ǁ^ | NA | 3 | IG1 | 6 | 138 | 72 (38.5) | 27 (19.6) | 123 | 67 (35.3) | 28 (22.8) | NR | NR
Adults | Watkins, 2017^108^ | QOL, mental health component^§§^ | 0–100 | NA | IG1 | 6 | 138 | 40.1 (10.8) | 41.0 (12.4) | 123 | 39.5 (10.9) | 40.8 (12.2) | ES=-1.61 (-5.61 to 2.39) | 0.43
Adults | Watkins, 2017^108^ | QOL, physical health component^§§^ | 0–100 | NA | IG1 | 6 | 138 | 47.6 (9.9) | 48.1 (11.5) | 123 | 47.2 (10.2) | 46.7 (10.8) | ES=1.49 (-2.05 to 5.03) | 0.41
Adults | Woolard, 2013^109^ | Cannabis-related injuries | NA | 12 | IG1 | 12 | 206 | 2.8 | 1.7 | 220 | 2.5 | 1.5 | NR | NR, NS

* 18 items from Rutger’s Marijuana Problem Index with categorical responses from 0 (never) to 4 (more than 10 times)

† 18 items from Rutger’s Marijuana Problem Index with categorical responses from 1 (never) to 5 (more than 10 times) plus 10 study-developed items unique to the physical and motivational effects of marijuana use with binary coding of 0 (not experienced) and 1 (experienced)

‡ 19 items from Marijuana Problem Scale with binary coding of 0 (not experienced) and 1 (experienced)

§ 19 items from Marijuana Problem Scale with categorical responses of 0 (experiencing none), 1 (minor), or 2 (major)

ǁ n (%)

¶ Excluded detoxification services

# As measured with the Short Inventory of Problems; higher score indicates worse outcome.

** Number with anxiety symptoms where OASIS score ≥8

†† Number with depression symptoms where PHQ-9 score ≥10

‡‡ High value indicates better outcome

§§ As measured by SF-12 Health Survey

Abbreviations: BL = baseline; CG = control group; ES = effect size; FU = followup; IG = intervention group; IRR = incidence rate ratio; mo = months; NA = not applicable; NR = not reported; NS = not statistically significant; OR = odds ratio; pop = population; recall = period of time respondents are asked to recall their substance use; RR = rate ratio; sd = standard deviation

##### Detailed Results: Harms (KQ 5)

Only two of the 19 trials among adults reported on harms related to the intervention (n=518). In those two trials, no adverse events were reported by college students taking part in a one-hour in-person^94^ or web-based^93^ personalized feedback session addressing marijuana use.

#### Pregnant and Postpartum Women

##### Study, Population, and Intervention Characteristics

We identified five fair-quality trials among postpartum^98–100^ and pregnant women (Table 8).^106,^ ^110^ In the trials by Ondersma et al.,^98–100^ primarily low-income African American women (n=107 to 502) were recruited during their inpatient hospitalization for childbirth. In the first two trials,^98,^ ^99^ women reporting any illicit drug use in the month before becoming pregnant were eligible to participate (Table 9). Just over a quarter (25.7%) of the women screened positive and agreed to participate. Marijuana was the most prevalent drug used, with 62.6 percent^99^ and 86.5 percent^98^ reporting daily or near daily marijuana use in the 3 months prior to pregnancy. In the 2018 trial,^100^ women were indirectly screened for drug use risk using the WIDUS; rates of drug use at baseline (pre-pregnancy or during pregnancy) were not reported in this study. In all three trials, baseline assessments were self-administered anonymously on a computer tablet, then randomization and the intervention or the attention control were administered immediately after on the same computer tablet. All three interventions were a single 20-minute session following motivational interviewing principles; control participants spent the same amount of time on the computer tablet watching and providing feedback on video clips unrelated to drug use (Table 10 and Table 11).

In both trials among pregnant women, women in the first two trimesters of pregnancy were recruited from reproductive health clinics (n=183^110^ and n=50^106^). Women were eligible to participate if they reported using alcohol or illicit drugs in the previous month or scored positively for risk of alcohol or drug use (Table 9). In one trial,^110^ opiate users were given a referral to a local methadone maintenance facility. At baseline, 44 and 70 percent of women reported marijuana use during pregnancy. One intervention was a 60-minute computerized motivational interviewing session^106^ whereas the other intervention was the most intense of the interventions included in this review (Table 10 and Table 11) and consisted of six 30-minute individual counseling sessions combining motivational enhancement therapy and cognitive behavioral therapy, delivered by research nurses during routine prenatal and immediate postnatal care visits.^110^

##### Detailed Results: Drug Use and Other Risky Behaviors (KQ 4a)

Results on drug use outcomes were mixed and inconsistent in the trials among postpartum women (Table 16). In the first Ondersma trial (n=107), there was a statistically significant effect of the intervention on any drug use and non-cannabis use frequency in the 4 months following birth; but, no effect was found on total abstinence.^99^ In contrast, in the 2014 trial, at 3 months following delivery, 26.4 percent versus 9.9 percent of intervention versus control participants were abstinent from drugs as assessed by self-report and biological verification (OR, 3.28 [95% CI, 1.3 to 8.39], p-value=0.010). This difference, however, did not remain statistically significant at 6 months followup (OR, 1.47 [95% CI, 0.53–4.12], p-value=0.456). Likewise, women in the intervention group reported fewer days of drug use in the previous 3 months (median 31.6 days) than women in the control group (median, 77.2 days) at 6 months (p=0.207), but this difference was not statistically significant.^98^ In the 2018 trial, there was no effect of the intervention at 3 or 6 months on drug use days or self-reported or biologically-confirmed drug use.^100^

Table 16 Results for Drug Use (KQ 4a) for Trials Among Pregnant and Postpartum Women

Target pop | Author, year | Outcome | Recall (mo) | FU (mo) | IG n | IG BL | IG FU | CG n | CG BL | CG FU | Study-reported between group difference | Study-reported p-value
Postpartum women | Ondersma, 2007^99^ | Any drug use, n (%) | 3 | 4 | 39 | NR | 26 (67.6) | 37 | NR | 31 (83.7) | OR=2.48 (0.59 to 10.42) | NR, NS
Postpartum women | Ondersma, 2007^99^ | Any cannabis use, n (%) | 3 | 4 | 39 | NR | 26 (66.1) | 37 | NR | 29 (78.0) | OR=2.13 (0.58 to 7.78) | NR, NS
Postpartum women | Ondersma, 2007^99^ | Any other (non-cannabis) drug use, n (%) | 3 | 4 | 39 | NR | 4 (9.9) | 37 | NR | 8 (21.3) | OR=2.41 (0.66 to 8.83) | NR, NS
Postpartum women | Ondersma, 2007^99^ | Any drug use frequency^*^ | 3 | 4 | 55 | NR | NR | 52 | NR | NR | ES=0.46 (0.15 to 1.53) | 0.042
Postpartum women | Ondersma, 2007^99^ | Cannabis use frequency^*^ | 3 | 4 | 55 | 2.81 (NR) | 1.91 (NR) | 52 | 2.47 (NR) | 2.08 (NR) | ES=0.39 (0.01 to 0.97) | 0.202
Postpartum women | Ondersma, 2007^99^ | Other (non-cannabis) drug use frequency^*^ | 3 | 4 | 55 | 0.28 (NR) | 0.11 (NR) | 52 | 0.11 (NR) | 0.34 (NR) | ES= 0.40 (0.02 to 0.78) | 0.032
Postpartum women | Ondersma, 2014^98^ | Abstinence from drugs (self-report and urine), n (%) | 7 days | 3 | 72 | 0 (0.0) | 19 (26.4) | 71 | 0 (0.0) | 7 (9.9) | OR=3.28 (1.3 to 8.39) | 0.010
Postpartum women | Ondersma, 2014^98^ | Abstinence from drugs (self-report and urine), n (%) | 7 days | 6 | 72 | 0 (0.0) | 10 (13.9) | 71 | 0 (0.0) | 7 (9.9) | OR=1.47 (0.53 to 4.12) | 0.456
Postpartum women | Ondersma, 2014^98^ | Drug use days, median | 3 | 3 | 53 | NR | 25.6 | 52 | NR | 51.4 | Effect size=0.60 | 0.058
Postpartum women | Ondersma, 2014^98^ | Drug use days, median | 3 | 6 | 53 | NR | 31.6 | 52 | NR | 77.2 | Effect size=0.57 | 0.207
Postpartum women | Ondersma, 2018^100^ | Any drug use (self-report), n (%) | 3 | 3 | 252 | NR | 134 (53) | 248 | NR | 129 (52) | RR=1.02 (0.84 to 1.23) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Any drug use (self-report), n (%) | 3 | 6 | 252 | NR | 121 (48) | 248 | NR | 122 (49) | RR=0.97 (0.79 to 1.20) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Any drug use (urine), n (%) | 3 | 3 | 252 | NR | 131 (52) | 248 | NR | 129 (52) | RR=1.01 (0.84 to 1.22) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Any drug use (urine), n (%) | 3 | 6 | 252 | NR | 118 (47) | 248 | NR | 117 (47) | RR=0.99 (0.79 to 1.24) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Any cannabis use (self-report), n (%) | 3 | 3 | 252 | NR | 113 (45) | 248 | NR | 117 (47) | RR=0.95 (0.74 to 1.20) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Any cannabis use (self-report), n (%) | 3 | 6 | 252 | NR | 113 (45) | 248 | NR | 117 (47) | RR=0.97 (0.77 to 1.21) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Any cannabis use (urine), n (%) | 3 | 3 | 252 | NR | 103 (41) | 248 | NR | 109 (44) | RR=0.93 (0.73 to 1.18) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Any cannabis use (urine), n (%) | 3 | 6 | 252 | NR | 103 (103) | 248 | NR | 107 (43) | RR=0.95 (0.75 to 1.21) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Drug use days, median (IQR) | 3 | 3 | 252 | NR | 1.0 (0 to 14.9) | 248 | NR | 1.0 (0 to 13.7) | OR=0.98 (0.68 to 1.4) | NR, NS
Postpartum women | Ondersma, 2018^100^ | Drug use days, median (IQR) | 3 | 6 | 252 | NR | 0.8 (0 to 22.7) | 248 | NR | 1.4 (0 to 23.1) | OR=0.97 (0.71 to 1.34) | NR, NS
Pregnant women | Tzilos Wernette, 2017^106^ | Any alcohol or cannabis use, n (%) | 3 | 4 | 31 | 24 (77) | 7 (23) | 19 | 11 (58) | 8 (42) | OR=0.16 (0.04 to 0.74) | 0.02
Pregnant women | Yonkers, 2012^110^ | % of days using drugs, mean (sd) | 1 | Delivery | 80 | 21 (34) | 7 (22) | 83 | 18 (27) | 6 (17) | β=0.08 (-0.76 to 0.92) | NR, NS
Pregnant women | Yonkers, 2012^110^ | % of days using drugs, mean (sd) | 1 | 3 mo. post-delivery | 71 | 21 (34) | 13 (24) | 72 | 18 (27) | 14 (25) | β=-0.21 (-1.11 to 0.69)^†^ | NR, NS
Pregnant women | Yonkers, 2012^110^ | Abstinence from alcohol and drugs (self-report and urine), n (%) | 1 | Delivery | 55 | 35 (43.2)^‡^ | 41 (74.5) | 51 | 26 (32.5)^§^ | 39 (76.5) | OR=0.77 (0.32 to 1.84) | 0.5
Pregnant women | Yonkers, 2012^110^ | Abstinence from alcohol and drugs (self-report and urine), n (%) | 1 | 3 mo. post-delivery | 64 | 35 (43.2)^‡^ | 21 (32.8) | 64 | 26 (32.5)^§^ | 22 (34.4) | OR=0.76 (0.27 to 2.11)^†^ | NR, NS
Pregnant women | Yonkers, 2012^110^ | Abstinence from drugs (urine), n (%) | 1 | Delivery | 55 | 45 (55.6)^ǁ^ | 46 (83.6) | 51 | 43 (53.8)^¶^ | 43 (84.3) | OR=0.96 (0.34 to 2.72) | NR, NS
Pregnant women | Yonkers, 2012^110^ | Abstinence from drugs (urine), n (%) | 1 | 3 mo. post-delivery | 64 | 45 (55.6)^ǁ^ | 38 (59.4) | 64 | 43 (53.8)^¶^ | 33 (51.6) | OR=1.21 (0.57 to 2.57)^†^ | NR, NS
Pregnant women | Yonkers, 2012^110^ | Abstinence from alcohol and drugs (self-report), n (%) | 1 | Delivery | 80 | 40 (48.8)^#^ | 61 (76.3) | 83 | 35 (40.7)^**^ | 62 (74.6) | OR=0.77 (0.36 to 1.67) | 0.79
Pregnant women | Yonkers, 2012^110^ | Abstinence from alcohol and drugs (self-report), n (%) | 1 | 3 mo. post-delivery | 71 | 40 (48.8)^#^ | 29 (40.8) | 72 | 35 (40.7)^**^ | 27 (37.5) | OR=1.05 (0.42 to 2.62)^†^ | NR, NS

* Categorical responses where 0 = never, 1 = once or twice, 2 = monthly, 3 = weekly, and 4 = daily or almost daily

† From delivery to 3 months post-delivery

‡ 35/81=43.2% at baseline

§ 26/80=32.5% at baseline

ǁ 45/81=55.6%

¶ 43/80=53.8%

# 40/82=48.8%

** 35/86=40.7% at baseline

Abbreviations: BL = baseline; CG = control group; FU = followup; IG = intervention group; IQR = interquartile range; mo = months; NA = not applicable; NR = not reported; NS = not statistically significant; OR = odds ratio; pop = population; recall = period of time respondents are asked to recall their substance use; RR = relative risk; sd = standard deviation

Findings were also mixed in the two trials among pregnant women (n=213). One small trial (n=50) reported that 23 percent versus 42 percent of intervention versus control women were using any alcohol or cannabis use at 4 months followup (OR=0.16 [95% CI, 0.04 to 0.74], p=0.02).^106^ In the trial by Yonkers (n=104), substance use decreased among women in both the intervention and control groups between baseline (prenatally) and delivery, but increased again after 3 months postdelivery, and no statistically significant differences were found between groups at any time point, based on both self-report and urine samples.^110^ No studies evaluated effects of interventions on risky behaviors related to sexual activity or alcohol or tobacco use.

##### Detailed Results: Health, Social, and Legal Outcomes (KQ 4b)

Only one trial reported results related to health outcomes. Within one trial among pregnant women (n=163), 10.1 percent versus 20.2 percent of intervention and control women gave birth preterm (i.e., <37 weeks gestation) (p=0.08) and 14.5 percent versus 20.2 percent of intervention and control participants delivered a low-birthweight infant (i.e., <2500 grams) (p=0.41).^110^

##### Detailed Results: Harms (KQ 5)

In both studies among postpartum women, no women experienced any harms or unintended effects based on their participation in an electronic screening and brief intervention (n=643).^98,^ ^100^