# Chapter 2 Methods

## Scope and Purpose

This review is an update of the 2008 review^2^ that supported the USPSTF recommendation for screening for drug misuse among adolescents and adults, including pregnant women.^1^ The USPSTF will use this report to update its 2008 recommendation. Our update includes all studies from the previous review that met our updated inclusion criteria, as well as studies published since the previous review.

## Key Questions and Analytic Framework

With input from the USPSTF, we developed an Analytic Framework (Figure 1) and five Key Questions (KQs) to guide the search and selection of studies, data abstraction, and data synthesis.

Figure 1 Analytic Framework

Figure 1 is the analytic framework that depicts the five Key Questions to be addressed in the systematic review. The figure illustrates how primary care screening for drug use in adolescents and adults, including pregnant women, may reduce morbidity or mortality to improve other health, social, or legal outcomes (KQ1a), and how primary care screening for drug use in adolescents and adults, including pregnant women, may reduce morbidity or mortality to improve other health, social, or legal outcomes (KQ1b). Additionally, the figure illustrates what the accuracy of commonly used instruments to screen for drug use may be (KQ2), and what adverse events may be associated with screening for drug use in adolescents and adults, including pregnant women (KQ3). Further, this figure illustrates how counseling interventions to reduce drug use, with or without referral, may reduce drug use or improve other risky behaviors in screen-detected persons (KQ4a), and how counseling interventions to reduce drug use, with or without referral, may reduce morbidity or mortality to improve other health, social, or legal outcomes in screen-detected persons (KQ4b). Finally, this figure illustrates what adverse events may be associated with interventions to reduce drug use in screen-detected persons.

1. a. Does primary care screening^*^ for drug use^†^ in adolescents and adults, including pregnant women, reduce drug use or improve other risky behaviors?
  b. Does primary care screening^*^ for drug use^†^ in adolescents and adults, including pregnant women, reduce morbidity or mortality or improve other health, social, or legal outcomes?
2. What is the accuracy of drug use screening instruments?
3. What are the harms of primary care screening^*^ for drug use in adolescents and adults, including pregnant women?
4. a. Do counseling interventions to reduce drug use, with or without referral, reduce drug use or improve other risky behaviors in screen-detected persons?^‡^
  b. Do counseling interventions to reduce drug use, with or without referral, reduce morbidity or mortality or improve other health, social, or legal outcomes in screen-detected persons?^‡^
5. What are the harms of interventions to reduce drug use in screen-detected persons?^‡^

* “Screening” refers to screening methods that pose questions about drug use or drug-related risks, not laboratory testing of biologic samples for the presence of drugs.

† Includes illicit drug use and nonmedical pharmaceutical drug use.

‡ A separate report refers to these “counseling interventions” as “interventions” under Key Questions 4 and 5 and as “psychosocial interventions” in the body of the report.^35^

## Data Sources and Searches

We conducted dual, independent reviews to re-evaluate 48 studies included in three related USPSTF reviews, using the inclusion/exclusion criteria as a guide.^2,^ ^3,^ ^5^ We then searched the following databases for relevant English-language literature published between January 1, 2006 (for KQs 1, 3, 4, and 5), January 1, 1998 (KQ2), and June 7, 2018: MEDLINE, PubMed (for publisher-supplied records only), PsycINFO, and the Cochrane Central Register of Controlled Trials. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix C, Literature Search Strategies). We also examined the reference lists of other previously published reviews and primary studies. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) and the WHO International Clinical Trials Registry Platform (www.who.int/ictrp) for ongoing trials. We imported the literature from these sources directly into EndNote® X7 (Thomson Reuters, New York, NY).

Since June 7, 2018, we conducted ongoing surveillance through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that may affect conclusions. The last surveillance was conducted on November 22, 2019. Four studies that addressed the accuracy of screening instruments to detect cannabis{Tiet, 2019 #35318} and opioid use disorders{Tiet, 2019 #35317} among adults and drug use during pregnancy {Ondersma, 2019 #35315;Coleman-Cowger, 2019 #35316} were identified. Additionally, one new trial of a computer-based substance use screening and counseling intervention among adolescents was identified.{Knight, 2019 #35314} These five studies were evaluated and did not change our conclusions and therefore, are not included in this review.

## Study Selection

We developed criteria for including or excluding studies based on the original review^2^ and expert consultation (Appendix C Table 1). For all KQs, we included studies among adolescents and adults aged 12 years and older, including pregnant women. We included studies that enrolled patients attending primary care clinical settings, emergency departments, or behavioral health assessment clinics as well as persons recruited from schools or the general community (a few of which specifically recruited persons based on their current drug use). Studies targeting illicit psychoactive drug use or nonmedical pharmaceutical drug use were included; those targeting nonpsychoactive drugs (e.g., laxatives, anabolic steroids) were excluded. For KQs 1 and 3, we included studies that compared individuals who received screening with those who received no screening or who received usual care, including randomized trials or nonrandomized controlled trials. For KQ 2, we included studies of screening accuracy reporting sensitivity and specificity (or data to calculate) compared with a structured or semi-structured clinical interviews or biological samples to detect any drug use, unhealthy drug use, or drug use disorders and excluded case-control studies. We included studies of brief standardized screening instruments or a set of questions that screened directly for drug use or drug use risk or those that indirectly screened for drug use with questions regarding alcohol use or other risky behaviors. We did not include studies that examined the accuracy of laboratory testing as a screening tool. Included screening instruments could be conducted in person or via telephone, mail, or electronically. For all screening questions (KQs 1–3), screening had to be population based and take place in a setting that was applicable to primary care; screening taking place in settings such as behavioral or mental health clinics or substance abuse treatment facilities were excluded. Development studies that recruited participants for the sole purpose of creating a screening tool were excluded. If a study recruited a separate validation sample, only the validation sample was used.

For questions related to intervention effectiveness and harms (KQ 4 and KQ 5), only studies in which at least 50 percent of the enrolled sample was recruited via population-based screening (i.e., individual outreach to members of a defined population [or random or consecutive sample] who have been identified as potentially eligible) were eligible. Studies who screened all potential participants by asking 1–2 questions regarding current drug use to determine eligibility were also included. Interventions could include any counseling approach designed to reduce drug use, with or without referral, including brief interventions delivered in-person or through virtual delivery. Studies of medication-assisted therapy (i.e., the use of methadone, buprenorphine, or naltrexone plus counseling) to treat opioid use disorders were excluded given that these treatments are limited to adults with a diagnosed opioid use disorder (typically severe and non-screen detected). Additionally, trials of interventions aimed at preventing drug use initiation or those using contingency management or vocational rehabilitation were excluded. We also excluded comparative effectiveness trials that compared two active interventions with no true control group.

This review addressed drug use outcomes (either as self-reported or through biologic verification) and other related behavioral outcomes, and health, social, and legal outcomes such as morbidity, mortality, obstetrical, perinatal, and neonatal outcomes, quality of life, and drug-related problems, such as legal problems and social and family relations. We only included these outcomes if reported at least 3 months after baseline measurement (except for studies among pregnant women for which any followup was accepted). Harms included any serious harm at any time point after the screening or intervention began, including reports of stigma, labeling or discrimination, privacy issues, or demoralization due to failed quit attempts. For all KQs, studies limited to persons seeking or referred for treatment for illicit drug use or nonmedical pharmaceutical use, persons with psychotic disorders, persons receiving chronic opioid therapy, and other groups not generalizable to primary care (e.g., persons court-mandated to receive substance use treatment, persons who are incarcerated) were not included. We required that studies take place in developed countries as defined as “very high” on the 2014 Human Development Index of the United Nations^36^ to ensure that the evidence was applicable to a U.S. setting.

Using the inclusion and exclusion criteria as a guide, two reviewers independently screened all records based on their titles and abstracts. Subsequently, at least two reviewers assessed the full text of potentially relevant studies, including all the previously included studies, using a standard form that outlined the eligibility criteria. Disagreements were resolved through discussion and consensus. Title and abstract and full-text review was conducted in DistillerSR (Evidence Partners, Ottawa, Canada). We kept detailed records of all included and excluded studies, including the reason for their exclusion.

## Quality Assessment and Data Abstraction

Two reviewers independently used USPSTF criteria to assess the methodological quality of all eligible studies in DistillerSR. Disagreements were resolved by consensus and, if needed, consultation with a third independent reviewer. We assigned each study a quality rating of “good,” “fair,” or “poor” according to the USPSTF’s study design-specific criteria (Appendix C Table 2).^37^ Good-quality studies were those that met nearly all specified quality criteria. For studies of accuracy, we rated studies as good quality if they recruited patients consecutively or randomly, administered the index tool blinded to, or at least prior to, the reference standard, used a reference standard that could accurately classify the target condition, interpreted the reference standard independently from the screening tool, and administered the screening tool and reference standard on the same day to all participants. For studies of psychosocial interventions, we rated trials as good quality if comparable groups were assembled initially and maintained throughout the study, reliable and valid measurement instruments were used and applied equally to the groups, procedures for maintaining fidelity to the intervention were in place, followup was adequate (i.e., ≥85%), data were complete, and there was no evidence of selective reporting. Fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study. Studies rated as poor quality had several important limitations and were excluded from this review.

We abstracted descriptive and outcome data from each included study into detailed abstraction forms using DistillerSR. One reviewer completed primary data abstraction, and a secondary reviewer checked all data for accuracy and completeness. Data collection for all KQs included general characteristics of the study (e.g., author, year, study design) and characteristics of the sample (e.g., age and clinical characteristics of the population and setting, country). For studies of accuracy, data collection also included characteristics of the screening tool, reference standard, and target conditions as well as accuracy results. We abstracted the optimal cutoff for each screening tool, either as defined by the author or selected by the reviewer as the best balance of sensitivity and specificity reported. For intervention studies, data collection also included description of the intervention (e.g., type, provider, frequency, duration), outcome measurement details (e.g., followup, instruments), and results. We contacted authors when data reporting was incomplete, or data points required clarification. In cases where data was only presented in graphical format, we used WebPlotDigitizer© Version 3.10 to extract data and provide estimates of the within-group means and variance at followup.

## Data Synthesis and Analysis

We synthesized data separately for each KQ and subpopulation (i.e., adolescents, young adults and adults, and pregnant and postpartum women). The data for KQ 2 did not allow for quantitative pooling due to the limited number of contributing studies and the variability in screening instruments and target conditions, so we synthesized the data qualitatively through tables and narrative synthesis and created forest plots (without pooling) to illustrate each trial’s results. We grouped the data by the type of screening instrument, the specific target condition, and substance or substances the screening instrument addressed (e.g., drugs and alcohol, drugs only, or specific drugs such as cannabis, prescription drugs, or cocaine). Types of screening instruments were grouped as 1) frequency-based screening instruments (addressing any use and/or frequency of use), 2) risk assessment instruments (addressing the potential consequences of drug use, typically those that are indicators of a use disorder and often in combination with drug use frequency), and 3) indirect screening instruments (did not screen for drug use directly but assessed other correlates of drug use, such as alcohol use, tobacco use, partner substance use, and other social factors).

If a study reported results for more than one substance that would fit into one group, we selected the more inclusive option (e.g., if a study reported results for “all drugs” and “illicit drugs,” we report the result for “all drugs” only). Given the variability in target conditions presented across the trials, we collapsed the conditions into four groups: any use, unhealthy use (variably defined in the studies), use disorder (DSM-IV abuse or dependence, DSM-5 use disorder), or dependence (DSM-IV dependence or DSM-5 moderate-severe use disorder). (Appendix A describes relation between DSM-IV and DMS-5 criteria.) The target condition of “unhealthy use” included conditions such as the full spectrum of unhealthy use (e.g., problem use or a use disorder), meeting any DSM criterion for a use disorder, heavy use (e.g., using a substance twice or more per day) or negative consequences or problems related to drug use.

For studies on the accuracy of screening instruments (KQ 2), we calculated confidence intervals (CIs)^38,^ ^39^ in Stata 13.1 (StataCorp LLC, College Station, TX) using data from 2x2 tables that included true positives, false positives, false negatives, and true negatives. If these data were not reported directly, we created 2x2 tables based on the total sample size, number of persons with the diagnosis according to the reference standard, sensitivity, and specificity. We report a range of sensitivity and specificity across eligible studies to provide an overall description of findings.

For studies measuring the effectiveness of counseling interventions (KQ 4), we computed a random-effects models on drug use days, the most commonly reported outcome across studies. We standardized drug use days to be the number of days of drug use in the past 7 days dividing means and standard deviations by 4.3 for recall in the last 30 days and 12.9 for recall in the last 90 days. The tables of results present the original data for the precise recall period for each study. We computed two separate models at 3 and 6–12 months of followup to assess short- and long-term effects and incorporated cannabis use days into the models when drug use days was not a reported outcome. We used the Profile Likelihood (PL) model for pooling.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^40^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation Working Group.^41^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, none suspected, or not applicable (e.g., when there is insufficient evidence for an outcome). Study quality reflects the quality ratings of the individual studies and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body-of-evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. We developed our overall strength of evidence grade based on consensus discussion involving at least two reviewers.

## Expert Review and Public Comment

A draft of the Analytic Framework, KQs, and inclusion and exclusion criteria were posted on the USPSTF Web site for public comment from August 4, 2016, through August 31, 2016. In response, the USPSTF revised the exclusion of studies limited to persons with concomitant mental health disorders to indicate that only studies limited to persons with psychotic disorders (e.g., schizophrenia) were excluded. Studies limited to persons with other mental health conditions, such as depression, anxiety, attention deficit hyperactivity disorder, and post-traumatic stress disorder are included. Other minor modifications and clarifications were made as appropriate, including updating some of the conditions (e.g., bath salts) and settings (e.g., school health clinics) that would be included in the review. Public comments on the Draft Research Plan for Screening and Behavioral Counseling Interventions for Unhealthy Alcohol Use in Adolescents and Adults, Including Pregnant Women were also reviewed given the similar scope of the two reviews. Based on those comments, the USPSTF modified the criteria to clarify that interventions that target persons with dependent drug use are out of scope for these reviews. Therefore, pharmacotherapy interventions (including medication-assisted therapy) were excluded from the review. A final research plan was posted on the USPSTF Web site on October 20, 2016. Two subsequent scope changes were made during the review to include a broader evidence base: 1) including results reported at 3-month or longer followup (as opposed to 6-months or longer) and 2) including studies that screened for and/or provided drug use interventions in emergency departments.

The draft report was posted on the USPSTF Web site for public comment from August 13, 2019, through September 10, 2019. No substantive changes to the report were made as a result of public comments. We added further clarifying language throughout the document to reiterate the focus on screening instruments or tools with the exclusion of drug testing via biologic samples.

## USPSTF Involvement

We worked with three USPSTF members at key points throughout this review, particularly when determining the scope and methods and developing the Analytic Framework and KQs. The USPSTF members approved the final Analytic Framework, KQs, and inclusion and exclusion criteria after revisions reflecting the public comment period. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.