# Chapter 1 Introduction

## Scope and Purpose

In 2008, the U.S. Preventive Services Task Force (USPSTF) concluded that there was insufficient evidence to recommend for or against screening adolescents and adults, including pregnant women, for illicit drug use.^1^ This recommendation was based on a staged evidence review of the literature published between 1994 and April 2006^2^ and a supplemental assessment of screening instruments.^3^ The staged review included research related to screening or treatment (including behavioral interventions) for marijuana, cocaine, opioids, or combined drug use and included evidence for adolescents and adults, including pregnant women. Subsequently, in 2014, the USPSTF issued another insufficient evidence recommendation specifically for children and adolescents, focused on interventions to prevent and reduce illicit drug or nonmedical pharmaceutical use among children and adolescents who had not already been diagnosed with a substance use disorder.^4^ The 2014 review focused on children and adolescents did not include a screening framework.^5^

The objective of this review is to systematically review the evidence on the benefits and harms of screening for drug use among adolescents and adults, including pregnant women, as well as the benefits and harms of subsequent interventions for drug use among a screen-detected population. This review also synthesizes the evidence on the diagnostic accuracy of screening instruments to detect unhealthy drug use.

## Condition Definition

Substance use typically refers to substances that affect mental processes (e.g., cognition, affect) when they are ingested, inhaled, injected, or taken through other administration routes. These substances have psychoactive properties and can include licit (legal) and illicit (illegal) substances, such as alcohol, tobacco, marijuana, and prescription drugs such as opioids and morphine derivatives, depressants, and stimulants. In this review, we focus on illicit drug use and the nonmedical use of prescription and over-the-counter drugs. Nonmedical use (also known as “extramedical use”) refers to use of a prescription or over-the-counter drug in ways other than prescribed (i.e., more frequently or for a longer duration) or by people other than the prescribed individual. Use of marijuana/cannabis, regardless of its legal status for medical or recreational use, is included in this review given its psychoactive properties and the evidence (and lack of evidence) regarding the health effects of its use.^6^

Individuals generally use these substances to “get high” or for other unapproved indications. There are no widely agreed-upon standards for “unhealthy” use of drugs given that any amount of some drugs can cause negative health consequences. As examples, a single use of cocaine can lead to a myocardial infarction, any drug injection can lead to HIV infection, and drug-impaired driving can lead to serious injury or death. Therefore, in this report, we include screening for and treating the full spectrum of drug use that can result in health consequences, hereafter called “unhealthy drug use.” This includes any use (of any amount, frequency or duration regardless of health consequences), heavy use, use that has already resulted in consequences but not yet as a diagnosable disorder (often referred to as problem use, misuse, or hazardous use), or use that meets criteria for a drug use disorder (i.e., DSM-IV abuse or dependence or DSM-5 use disorder) (Appendix A). A complete list of illicit, prescription, and over-the-counter drugs including their common and “street” names, the Drug Enforcement Administration controlled substance schedule, the common route of administration, and possible health effects is provided in Appendix B.

## Burden and Prevalence of Drug Use

Drug use is among the most common causes of preventable death in the United States^7,^ ^8^ and a leading cause of years lived in disability.^8^ Although the proportion of deaths attributable to unintentional injuries (e.g., drug poisonings, motor vehicle crashes) has remained relatively stable at around 5 percent, intentional and nonintentional drug poisonings (including “overdoses”) have increased each year to become the leading cause of injury death, with over 11,000 more deaths in 2011 than in 2005.^9^ The age-adjusted rate of death from drug poisonings (including all intents) increased from 10.1 per 100,000 in 2005 to 12.3 per 100,000 in 2011.^9^ The National Vital Statistics System reported over 70,000 drug overdose deaths in 2017.^10^ The National Drug Intelligence Center reported in 2011 that the cost of illicit drug use exceeded $193 billion, including direct and indirect costs in the three main areas of crime, health, and productivity.^11^

The National Survey on Drug Use and Health (NSDUH), administered by the Substance Abuse and Mental Health Services Administration (SAMHSA), is the primary source of epidemiologic data on the use of illicit and misuse of prescription drugs, alcohol, and tobacco by the U.S. civilian, noninstitutionalized population aged 12 or older.^12^ In 2017, an estimated 30.5 million Americans aged 12 or older (11.2% of the population aged 12 or older) were current illicit drug users, meaning they had used an illicit drug (marijuana/hashish, cocaine [including crack], heroin, hallucinogens, inhalants, or prescription-type psychotherapeutics used nonmedically) during the month prior to the survey interview (Table 1).^12^ The estimate for illicit drug use in Americans is largely driven by marijuana use (9.6%; 26.0 million current users) and nonmedical use of prescription psychotherapeutic drugs (2.2%; 6.0 million current users), in particular, pain relievers (1.2%; 3.2 million current users). Marijuana was used by 85.3 percent of current illicit drug users, while an estimated 19.5 percent of illicit drug users used psychotherapeutic drugs nonmedically, including opioids (11.6%), pain relievers (10.6%), tranquilizers (5.7%), stimulants including methamphetamine (2.5%), and sedatives (1.2%). Other illicit drugs were used by a smaller percentage of current illicit drug users aged 12 years and older: cocaine (7.1%), hallucinogens (4.7%), and inhalants (1.8%).^12^

Table 1 Current (Previous Month) Illicit Drug Use,^*^ 2017 National Survey on Drug Use and Health^12^

Substance | All (12 years or older) | Adolescents (12–17 years) | Young adults (18–25 years) | Adults (26 years or older)
Any illicit drug | 11.2 (0.19) | 7.9 (0.26) | 24.2 (0.47) | 9.5 (0.22)
Marijuana | 9.6 (0.18) | 6.5 (0.24) | 22.1 (0.46) | 7.9 (0.20)
Use/misuse of prescription psychotherapeutics^†^ | 2.2 (0.08) | 1.5 (0.11) | 4.5 (0.22) | 1.9 (0.09)
Cocaine | 0.8 (0.05) | 0.1 (0.03) | 1.9 (0.14) | 0.7 (0.06)
Hallucinogens | 0.5 (0.03) | 0.6 (0.08) | 1.7 (0.14) | 0.3 (0.03)
Inhalants | 0.2 (0.02) | 0.6 (0.07) | 0.5 (0.06) | 0.1 (0.02)
Heroin | 0.2 (0.02) | 0.0 (0.01) | 0.3 (0.06) | 0.2 (0.03)
Binge alcohol use | 24.5 (0.27) | 5.3 (0.22) | 36.9 (0.57) | 24.7 (0.32)
Tobacco | 22.4 (0.26) | 4.9 (0.21) | 29.1 (0.48) | 23.4 (0.31)

* All values in table are percent (standard error)

† Includes pain relievers, tranquilizers, stimulants (methamphetamine), sedatives

To put the rates of drug use in context with the use of other substances, in 2017 the rate of previous-month binge alcohol use (5 or more drinks on the same occasion on at least 1 day in the past 30 days) in persons ages 12 years or older was 24.5 percent and current tobacco use was 22.4 percent.^12^ Illicit drug use was approximately 10 times higher in persons who smoked cigarettes and drank alcohol during the previous month (34.4%) than in those who neither smoked cigarettes nor drank alcohol during the previous month (3.5%).^12^

In 2017, an estimated 7.2 percent of the population aged 12 or older (19.7 million people) was classified with substance dependence or abuse in the previous year based on responses to NSDUH questions. Of these, 2.3 million (0.9%) people were classified with dependence on or abuse of alcohol and illicit drugs, 5.2 million (1.9%) had dependence or abuse of illicit drugs but not alcohol, and 12.2 million (4.5%) had dependence or abuse of alcohol but not illicit drugs.^12^

The prevalence of drug use is not equally distributed across the U.S. population. Subpopulations that experience a higher prevalence of drug use include young adults, males, certain racial and ethnic minority groups, and individuals living with mental health conditions.^12^

- [underlined: Age]. Young adults, aged 18 to 25 years, have the highest rate of current illicit drug use (24.2%), followed by adolescents aged 12 to 17 years old (7.9%) (Table 1).^12^
- [underlined: Sex]. In general, current illicit drug use among individuals aged 12 years or older was higher for males (13.7%) than females (8.8%). Males were more likely than females to use marijuana (11.9 vs. 7.3%), cocaine (1.1 vs. 0.5%), and hallucinogens (0.7 vs. 0.4%).^12^
- [underlined: Racial/ethnic groups]. Rates of current illicit drug use among those aged 12 years or older in 2017 varied by race and ethnicity, with the highest rates among those reporting two or more races (17.1%) and American Indians or Alaska Natives (17.6%), followed by blacks (13.1%), whites (11.6%), Native Hawaiians or Pacific Islanders (10.4%), Hispanics or Latinos (9.8%), and Asians (4.5%).^12^
- [underlined: Persons with mental health conditions]. An estimated 3.4 percent of adults had any type of mental illness and met the criteria for dependence or abuse for alcohol or illicit drugs in the previous 12 months, while 1.3 percent had a serious mental illness and met criteria for a substance use disorder. Among adolescents aged 12 to 17 years in 2017, 0.8 percent had a substance use disorder and experienced a major depressive episode in the previous year.^12^
- [underlined: Pregnant women.] Pregnant women are approximately half as likely as nonpregnant women of the same age to use drugs. Based on 2017 data, 8.5 percent of pregnant women aged 15 to 44 were current illicit drug users, while 14.0 percent of nonpregnant women in this age group were drug users.^12^ Rates of use among pregnant women also differ by age groups. The rate of current illicit drug use was 11.0 percent among pregnant women aged 18 to 25 and 7.2 percent among pregnant women aged 26 to 44. These rates are likely conservative estimates since they only reflect previous-month use, not use during the entire pregnancy. They are also limited to women who knew they were pregnant at the time of the survey. At least one study has shown that women tend to have higher rates of illicit drug use (not including prescription drug misuse) during the first trimester than the second or third; thus, pregnant women who do not yet know they are pregnant may have rates of drug use closer to the nonpregnant female population.^13^ Likewise, there is a rich literature base documenting under-reporting of drug use among pregnant and postpartum women, likely due to social stigma as well as fear of socio-legal consequences such as losing custody of one’s infant.^14–17^

## Other Risk Factors for Drug Use

Risk factors for drug use in U.S. adults include a history of childhood adversity (i.e., physical abuse, witnessed fights at home, neglect by parent or guardian, sexual assault), family history of addiction (i.e., drug or alcohol problems in first-degree relatives), a pre-existing personality or mood disorder, previous nicotine dependence, and alcohol dependence.^18^ Additional risk factors related to drug use during pregnancy include lack of prenatal care and cigarette smoking.^19,^ ^20^ Among adolescents, risk factors are aggressive behavior in childhood, lack of parental supervision, poor social skills, drug experimentation, availability of or access to drugs at school, and community poverty.^21^ Factors associated with increased risk for misuse of prescribed drugs vary by type of prescription drug, but include a history of other substance use or misuse, history of mental illness, acute and chronic pain, physical health problems (i.e., fatigue or headaches), heightened physiological reactions to drugs (i.e., having a greater subjective euphoric reaction), and greater prescription access (e.g., excessive exposure to prescription opioids or benzodiazepines, having a larger prescribed dosage of opioids).^22^ It is generally argued that many of these factors play a role in the onset or continuation of drug use although it is unclear whether many of these risks are causes, consequences, or correlates of drug use.

## Screening for Drug Use

Screening for drug use in primary care can help to manage the quality and safety of health care as well as to identify unhealthy drug use that requires intervention. Knowledge of a patient’s use of prescription and non-prescription drugs, including nonmedical use of prescription drugs and illicit drug use, is often part of a comprehensive medication history. Drug use information has implications for the diagnosis and management of medical and psychiatric conditions, screening for other health risk behaviors, selection of medications, and for monitoring medication interactions, effectiveness and side effects. Since primary care practitioners have a limited amount of time to address multiple health concerns, the ideal instrument to screen for drug use would be brief, validated for a primary care population, and able to identify the full spectrum of drug use. Drug screening tools are generally very brief and are intended to identify any use (“yes/no”). Some screening tools may also provide additional risk-based assessment that estimates current risk related to use. However, screening tools are not intended as tools for diagnosing substance use disorders or as assessments to determine characteristics that may influence treatment decisions and contribute to the success of treatment including the patient’s substance use behavior, readiness to change, related problems, and other areas of psychological and social functioning.^23^ Screening for drug use is more difficult than screening for unhealthy alcohol use since screening tools need to target a range of drugs, including prescription drugs, not simply one substance. Further, the amount of each drug that constitutes a health risk is not well defined and differs across each substance.^24^ Laboratory testing, including hair or urine samples, can also be used to identify current use of some drugs, but is generally not considered useful for population-based screening given the limitations of typically only detecting recent use, requiring testing for a wide variety of drugs, the costs of the tests, and providing no information about the severity of use.^24^ Additionally, specific concerns related to routine laboratory drug testing among pregnant and postpartum women exist given reporting mandates and legal requirements that vary from state to state.^25^

## Interventions to Reduce Drug Use

Treatment to reduce drug use may include psychosocial interventions and/or medications. Screening for substance use, brief intervention, and referral to treatment (the SBIRT model) has been promoted to reduce the health burden related to substance use.^26^ Brief interventions are typically administered by primary care clinicians and are used as an early intervention approach to reduce current drug use and risks related to drug use. These interventions target individuals with any use, heavy use, or use that has already resulted in consequences but not yet as a diagnosable disorder (often referred to as problem use, misuse, or hazardous use),.^27^ Brief interventions are generally conducted in person in a primary care setting, and range from 5 minutes of brief advice to 15 to 30 minutes of brief counseling, typically over the course of one to four sessions.^26^ The two most common counseling interventions used in SBIRT programs are brief versions of motivational interviewing (MI) and cognitive behavioral therapy (CBT), which may be used in adults, pregnant women, and adolescent populations.^26,^ ^28^ These types of treatments are often collectively called psychosocial treatments. MI is a person-centered counseling style designed to strengthen personal motivation for and commitment to a specific goal by eliciting and exploring the person’s own reasons for change.^29^ CBT interventions help individuals identify and correct unhealthy behaviors by applying a range of skills (e.g., coping strategies, exploration of positive and negative consequences of continued drug use) that can be used to stop unhealthy substance use.^30^ Other counseling strategies include counseling on mindfulness-based approaches (including meditation) and general counseling such as fact-based education regarding drug use and health risks along with suggestions for minimizing harm (with or without components of MI or CBT). All of these counseling approaches can be delivered in an individual or group format and can include family and friends for social support. For adults with drug use disorders, referral to more extensive treatment that includes more intensive psychosocial interventions and medical treatment may be indicated. Three U.S. Food and Drug Administration (FDA)-approved medications are available for treating opioid use disorders: methadone, buprenorphine and naltrexone.^31,^ ^32^ Additionally, naloxone is approved to treat a known or suspected opioid overdose.

## Current Clinical Practice in the United States

Available data on current clinical practice regarding screening for drug use is more than a decade old. National survey data from 2000 indicate that less than one-third of primary care physicians screen for substance use, and less than 20 percent describe themselves as “very prepared” to identify alcohol abuse (19.9%) or illicit drug use (16.9%).^33^ In this survey, clinicians did not screen, missed, or misdiagnosed patients’ substance use for reasons including lack of training, skepticism about treatment effectiveness, time constraints, perceived patient resistance, and discomfort discussing substance use.^33^ A 2001 study of 604 American College of Gynecology (ACOG) members found that 87 percent of respondents reported asking their pregnant patients about drug use at their first prenatal visit, while 98 percent reported screening for tobacco use.^34^ Among pregnant women reporting drug use, 97 percent of their clinicians discussed adverse effects of drug use and 95 percent advised abstinence.^34^ Almost half of clinicians reported referring their patients for treatment, and one-third reported administering periodic drug screens.^34^

## Recommendations of Others

Recommendations and statements from other organizations about screening and treatment for drug use reflect differences by subpopulations among existing guidelines (Table 2). The American Academy of Family Physicians (AAFP) (2014) and the Department of Veterans Affairs (VA) (2015) agree with the 2008 USPSTF recommendation that there is insufficient evidence to assess the balance of benefits and harms of screening for drug use among adults. The American Academy of Pediatrics (AAP) recommends that pediatricians increase their capacity in substance use (including alcohol use) detection, assessment and intervention and become familiar with adolescent SBIRT practices and their potential to be incorporated into universal screening and comprehensive care of adolescents in the medical home. ACOG (2014) released three Committee Opinions that advocated for providers to be educated about established techniques for screening and intervention and that all women should be routinely asked about their use of drugs, including the nonmedical use of prescription drugs, both prior to and early in pregnancy.

Table 2 Recommendations on Screening for Drug Use

Organization | Year | Recommendation
American Academy of Family Physicians (AAFP) | 2014 | Adopts the 2008 and 2014 USPSTF recommendation on screening adolescents, adults, and pregnant women for illicit drug use^138^ and primary care-based behavioral interventions to prevent or reduce illicit drug use in children and adolescents.^139^
Department of Veterans Affairs (VA) | 2015 | Adopts the 2008 USPSTF recommendation on screening adolescents, adults, and pregnant women for illicit drug use.^140^; For patients with substance use disorders, there is insufficient evidence to recommend for or against using a standardized assessment that would determine initial intensity and setting of substance use disorder care rather than the clinical judgment of trained providers.
American Academy of Pediatrics (AAP) | 2016 | Recommends that pediatricians should increase their capacity in substance use detection, assessment, and intervention; and become familiar with adolescent SBIRT practices and their potential to be incorporated into universal screening and comprehensive care of adolescents in the medical home.^141^
American College of Obstetricians and Gynecologists (ACOG) | 2012 (Reaffirmed 2014) | Recommends that all women should be routinely asked about their use of drugs, including prescription drugs used nonmedically, both before pregnancy and early in pregnancy, provided counseling when substance use is suspected or identified, and referred to treatment when drug dependence is apparent.^142,^ ^143^ (committee opinion)

Abbreviations: SBIRT = Screening, brief intervention, and/or referral to treatment

## Previous USPSTF Recommendation

In 2008, the USPSTF concluded that the current evidence was insufficient to assess the balance of benefits and harms of screening adolescents, adults, and pregnant women for illicit drug use (I statement).^1^