# Appendix H List of Ongoing Studies (as of November 2018) Screening

Study Reference Trial Identifier | Principal Investigator/Study Contact (if different) | Study name | Location | N | Description | 2019 Status
NCT01501318 | Matthew G Hile, PhD; matthew.hile@mimh.edu | Impact of Personalized Feedback Alone on Substance Use Behaviors | US | 40 | The investigators seek to develop a more efficient and effective approach to providing brief behavioral health interventions for risky substance use behaviors by comparing a brief coach directed intervention to a tailored report only group. | Completed Nov 2012. No published records.
NCT02191605 | Steven J Ondersma, PhD; s.ondersma@wayne.edu | Computer-delivered Screening & Brief Intervention for Marijuana Use in Pregnancy | US | 80 | The investigators will test two technology-based, highly practical interventions that could reduce the number of children who are prenatally exposed to marijuana. | Completed Oct 2017. No published records.
NCT03165175 | Suzanne L Hurtado, MPH; NR | Mobile Application for Prescription Drug-Abuse Education (MAPDE) | US | 60 | The aims of this pilot study are: (1) to assess the feasibility and acceptability of a mobile application to educate military members about the risks of prescription drug misuse; (2) to determine if there is evidence that the mobile application plus treatment as usual reduces the risk of prescription drug misuse and shows differences in related measures compared to treatment as usual among military medical clinic patients currently taking prescription medication; and (3) if evidence of reduced risk is found, to estimate effect sizes for a future effectiveness trial. | Ongoing: Est. Completion Date Sep 2018
NCT03037476 | Irene M Geisner, PhD; geisner@uw.edu | Personalized Health Assessment Related to Medications (Project PHARM) | US | 1050 | This project proposes to evaluate the efficacy of Screening and Brief Interventions (SBIs) for reducing college students’ PSM misuse through two different routes of screening and intervention across 9 colleges and universities spanning the United States. | Ongoing: Est. Completion Date Jun 2019
NCT02408952 | Stacy A Sterling, DrPH; stacy.a.sterling@kp.org | Screening for Youth Alcohol and Drug Use: A Study of Primary Care Providers | US | 9084 | This study evaluates the implementation and effectiveness of two modalities of Screening, Brief Intervention and Referral to Treatment (SBIRT) to reduce adolescent alcohol and other drug (AOD) use in a large pediatrics clinic. | Ongoing: Est. Completion Date Jun 2018. No published records.
NCT02744118 | V. Fan Tait, MD/Kristen Kaseeska, MPH; kkaseeska@aap.org | Helping Eliminate Marijuana Use Through Pediatric Practice (HEMPP) | US | 1020 | This study adapts the Public Health Service (PHS) 5As model for use with adolescent marijuana users and pilot the intervention to test feasibility and acceptability in pediatric primary care settings. | Ongoing: Est. Completion Date Mar 2019
NCT03074877 | Ty Ridenour, PhD; tridenour@rti.org | Substance Use Screening and Prevention for Adolescents in Pediatric Primary Care (SKY) | US | 1000 | This study is to test the effectiveness of integrating and adapting two National Institute on Drug Abuse (NIDA)-funded procedures for use in primary care pediatric clinics serving low-income youth. | Ongoing: Est. Completion Date May 2019
NCT02893514 | Donna Shelley, MD; shelld01@nyumc.org | Leveraging Technology to Address Unhealthy Drug Use in Primary Care Settings | US | 250 | This study will develop a clinical decision support tool that assists primary care providers in carrying out substance use interventions, and then compare (in Phase 2) two clinical scenarios, screening only (SO) vs. SUSIT, (on dose of substance use brief intervention received) and changes in drug use at 3 and 6 months, among primary care patients. | Ongoing: Est. Completion Date June 2019
NCT03069118 | Meghan Moynihan, PhD; meghan@workithealth.com | 90-Day Online Substance Use Program | US | 200 | To test the effectiveness of a remote behavioral intervention and coaching support for risky substance users in a randomized control trial. | Ongoing: Est. Completion Date Dec 2017. No published records.
5R01DA041328 (NIH RePORTER) | Victoria H. Coleman-Cowger, PhD; colemancowger@battelle.org | Comparison of Substance Use Screeners in Assessing Prescription Drug Abuse and Other Illicit Drug Use Among Pregnant Women | US | 500 | To compare and validate three existing substance use screeners – 4 P’s, NIDA Quick Screen/ASSIST, and the Substance Use Risk Profile-Pregnancy scale | Ongoing: Est. Completion Date Aug 2019
5R21DP006082-02 (NIH RePORTER) | Kimberly Yonkers, MD; kimberly.yonkers@yale.edu | Prenatal Substance Use Screening: Validation and Comparison of Promising Measures | US | NR | To validate and compare screening tools for maternal substance use. | Ongoing: Est. Completion Date Aug 2018. No published records.