# Appendix G List of Abbreviations for Screening Tools and Reference Standards

Abbreviation: Instrument
4P’s Plus: Parents Partner Past Pregnancy
ADI: Adolescent Diagnostic Interview
ASSIST: Alcohol, Smoking and Substance Involvement Screening Test
AUDIT: Alcohol Use Disorders Identification Test
AUDIT-C: Alcohol Use Disorders Identification Test - Consumption
BSTAD: Brief Screener for Tobacco, Alcohol, and Other Drugs
CAST: Cannabis Abuse Screening Test
CIDI: Composite International Diagnostic Interview
CPQ-A-S: Cannabis Problems Questionnaire for Adolescents Shortened
CRAFFT: Car Relax Alone Forget Family/Friends Trouble
DAST-2: 2-Item Drug-Abuse Screening Test
DAST-10: 10-Item Drug-Abuse Screening Test
DAST-28: 28-Item Drug-Abuse Screening Test
DISC-IV: Diagnostic Interview for Children Version IV
DSM: Diagnostic and Statistical Manual of Mental Disorders
InDUC: Inventory of Drug Use Con-sequences
M-CIDI: Munich-Composite International Diagnostic Interview
MINI: Multi International Neuropsychiatric Interview
NESARC: National Epidemiologic Survey on Alcohol and Related Conditions
NIAAA: National Institute on Alcohol Abuse and Alcoholism
NSDUH: National Survey on Drug Use and Health
PDUQp: Prescription Drug Use Questionnaire Patient Version
PESQ-PS: Personal Experience Screening Questionnaire
POSIT: Problem Oriented Screening Instrument for Teenagers
PRO: Prenatal Risk Overview
PSQ: Parent Screening Questionnaire
SCID: Structured Clinical Interview for the DSM
SDS: Severity of Dependence Scale
SIP: The Short Inventory of Problems
SIP-DU: The Short Inventory of Problems—Modified for Drug Use
SoDU: Screen of Drug Use
SUBS: Substance Use Brief Screen
TAPS: Tobacco, Alcohol, Prescription Medication, and Other Substance Use
TICS: Two-Item Conjoint Screen
TLFB: Timeline Follow Back
WIDUS: Wayne Indirect Drug Use Screener