# Appendix F List of Excluded Studies

Reason for Exclusion^*^
E1 | Study Aim: Not applicable/relevant to key question
E2a | Setting: Not in very high human development index country*
E2b | Setting: Screening and/or intervention is not conducted in, recruited from, or feasible for primary care
E2c | Setting: Conducted in emergency department or urgent care setting
E3a | Population:; - For screening, participants selected on the basis of alcohol or drug use or a related behavior or condition; - For interventions: Not among a screen-detected population (i.e., <50% of enrolled sample is recruited via population-based screening) or among those with addiction or dependence
E3b | Population: Otherwise out-of-scope (e.g., psychotic disorder, persons on chronic opioid therapy, court-mandated, incarcerated)
E3c | Population: Children <12 years
E4 | Outcome: No measure of drug use (only a composite substance use index) or no measure related to sensitivity and specificity for screening accuracy
E5a | Screening tool (KQ1, 2, 3): Assessment for drug or alcohol use does NOT include a brief standardized instrument or set of questions that is conducted in person or via telephone, mail, or electronically
E5b | Screening tool accuracy (KQ2): Not an included instrument (NIAAA one- or two-item screener or comparable, BSTAD, AUDIT and AUDIT-C, ASSIST, CARET, TWEAK, and T-ACE).
E5c | Intervention: Not an included intervention (e.g., medication, only contingency management, vocational rehabilitation, financial incentive)
E5e | Intervention: Prevention
E6 | Comparator: Not an included comparator (e.g., screening results given to control providers [KQ1,3], no reference standard [KQ2], active intervention [KQ4,5])
E7 | Condition: Nonpsychoactive drug (e.g., laxative, anabolic steroid)
E8 | Follow-up: KQ1, 4: Less than 3 months postbaseline (except among pregnant women)
E9 | Study design: KQ1, 3, 4, 5=RCTs and CCTs, KQ2=screening accuracy, KQ5=large cohort or case control studies for medication trials
E10 | Study Quality: Poor

* Assigned at full-text phase.

Abbreviation: E = exclude.

1 Aalborg A, Miller B, Husson G, . Implementation of adolescent family-based substance use prevention programmes in health care settings: Comparisons across conditions and programmes. Health education journal. 2012;71(1):53–61. PMID: 22984294. KQ4E5e, KQ5E5e.22984294
2 Abrams TE. Capsule commentary on McNeely ., Validation of self-administered single item screening questions (SISQs) for unhealthy alcohol and drug use in primary care patients. J Gen Intern Med. 2015;30(12):1845. KQ2E9.26307385
3 Adamson SJ, Kay-Lambkin FJ, Baker AL, . An improved brief measure of cannabis misuse: The Cannabis Use Disorders Identification Test-Revised (CUDIT-R). Drug Alcohol Depend. 2010;110(1–2):137–43. KQ2E3a.20347232
4 Alexander TL. Substance abuse screening with deaf clients: Development of a culturally sensitive scale. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2005;66(2-A):756. KQ2E4.
5 Ali R, Meena S, Eastwood B, . Ultra-rapid screening for substance-use disorders: the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST-Lite). Drug Alcohol Depend. 2013;132(1–2):352–61. PMID: 23561823. KQ2E2a.23561823
6 Altieri KM. Validating the Alcohol and Drug Use Survey and determining the relationships of familial and age-related variables with substance abuse of adolescents in a correctional facility. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2002;63(2-A):506. KQ2E2b.
7 Araujo M, Golpe S, Brana T, . Psychometric validation of the POSIT for screening alcohol and other drugs risk consumption among adolescents. Adicciones. 2017;0(0):958. PMID: 28492958. KQ2E10.28492958
8 Ashman TA, Schwartz ME, Cantor JB, . Screening for substance abuse in individuals with traumatic brain injury. Brain Inj. 2004;18(2):191–202. PMID: 14660230. KQ2E3b.14660230
9 Assadi SM, Radgoodarzi R, Ahmadi-Abhari SA. Baclofen for maintenance treatment of opioid dependence: a randomized double-blind placebo-controlled clinical trial [ISRCTN32121581]. BMC psychiatry. 2003;3:16. PMID: 14624703. KQ4E5c, KQ5E5c.14624703
10 Baer JS, Garrett SB, Beadnell B, . Brief motivational intervention with homeless adolescents: evaluating effects on substance use and service utilization. Psychol Addict Behav. 2007;21(4):582–6. PMID: 18072842. KQ4E10, KQ5E10.18072842
11 Bagley SM, Anderson BJ, Stein MD. Usefulness of the CRAFFT to diagnose alcohol or cannabis use disorders in a sample of emerging adults with past-month alcohol or cannabis use. Journal of child & adolescent substance abuse. 2017;26(1):18–23. KQ2E3a.28553066
12 Baldus C, Miranda A, Weymann N, . “CAN Stop”-implementation and evaluation of a secondary group prevention for adolescent and young adult cannabis users in various contexts-study protocol. BMC Health Serv Res. 2011;11:80. PMID: 21501479. KQ4E3a, KQ5E3a.21501479
13 Bannink R, Broeren S, Joosten-van Zwanenburg E, . Effectiveness of a Web-based tailored intervention (E-health4Uth) and consultation to promote adolescents’ health: randomized controlled trial. J Med Internet Res. 2014;16(5):e143. PMID: 24878521. KQ4E5e, KQ5E5e.24878521
14 Bashford J, Flett R, Copeland J. The Cannabis Use Problems Identification Test (CUPIT): development, reliability, concurrent and predictive validity among adolescents and adults. Addiction. 2010;105(4):615–25. PMID: 20403014. KQ2E2b.20403014
15 Batki SL, Washburn AM, Delucchi K, . A controlled trial of fluoxetine in crack cocaine dependence. Drug Alcohol Depend. 1996;41(2):137–42. PMID: 8809502. KQ4E5c, KQ5E5c.8809502
16 Becker J, Haug S, Kraemer T, . Feasibility of a group cessation program for co-smokers of cannabis and tobacco. Drug & Alcohol Review. 2015;34(4):418–26. PMID: 25676414. KQ4E9, KQ5E9.25676414
17 Bedregal LE, Sobell LC, Sobell MB, . Psychometric characteristics of a Spanish version of the DAST-10 and the RAGS.[Erratum appears in Addict Behav. 2006 Sep;31(9):1730]. Addict Behav. 2006;31(2):309–19. PMID: 15979248. KQ2E3a.15979248
18 Berman AH, Palmstierna T, Kallmen H, . The self-report Drug Use Disorders Identification Test: Extended (DUDIT-E): reliability, validity, and motivational index. J Subst Abuse Treat. 2007;32(4):357–69. PMID: 17481459. KQ2E3a.17481459
19 Berman AH, Wennberg P, Sinadinovic K. Changes in mental and physical well-being among problematic alcohol and drug users in 12-month Internet-based intervention trials. Psychol Addict Behav. 2015;29(1):97–105. PMID: 25664387. KQ4E3a, KQ5E3a.25664387
20 Blevins CE, Banes KE, Stephens RS, . Change in motives among frequent cannabis-using adolescents: Predicting treatment outcomes. Drug Alcohol Depend. 2016;167:175–81. PMID: 27577862. KQ4E3a, KQ5E3a.27577862
21 Blow F, Bohnert A, Ignacio R, . Efficacy of computer and therapist brief interventions for drug users. Drug Alcohol Depend. 2015;156:e21. KQ4E11, KQ5E11.
22 Boden MT, Kimerling R, Jacobs-Lentz J, . Seeking Safety treatment for male veterans with a substance use disorder and post-traumatic stress disorder symptomatology. Addiction. 2012;107(3):578–86. PMID: 21923756. KQ4E3a, KQ5E3a.21923756
23 Bonevski B, Sanson-Fisher RW, Campbell E, . Randomized controlled trial of a computer strategy to increase general practitioner preventive care. Preventive medicine. 1999;29(6 Pt 1):478–86. PMID: 10600428. KQ4E4, KQ5E4.10600428
24 Bonn-Miller MO, Heinz AJ, Smith EV, . Preliminary Development of a Brief Cannabis Use Disorder Screening Tool: The Cannabis Use Disorder Identification Test Short-Form. Cannabis Cannabinoid Res. 2016;1(1):252–61. PMID: 28861497. KQ2E10.28861497
25 Boothroyd RA, Peters RH, Armstrong MI, . The Psychometric Properties of the Simple Screening Instrument for Substance Abuse. Evaluation & the health professions. 2015;38(4):538–62. PMID: 23754847. KQ2E6.23754847
26 Boudreaux ED, Abar B, Baumann BM, . A randomized clinical trial of the health evaluation and referral assistant (HERA): research methods. Contemp Clin Trials. 2013;35(2):87–96. PMID: 23665335. KQ4E4, KQ5E4.23665335
27 Bouhnik A, Carrieri M, Rey D, . Drug injection cessation among HIV-infected injecting drug users. Addict Behav. 2004;29(6):1189–97. KQ4E3b, KQ5E3b.15236822
28 Braaten K, Briegleb C, Hauke S, . Screening pregnant young adults for alcohol and drug use: a pilot study. J Addict Med. 2008;2(2):74–8. PMID: 21768975. KQ1E9, KQ2E9, KQ3E9.21768975
29 Broderick KB, Richmond MK, Fagan J, . Pilot Validation of a Brief Screen Tool for Substance Use Detection in Emergency Care. J Emerg Med. 2015;49(3):369–74. PMID: 26054313. KQ2E6.26054313
30 Brody GH, Chen YF, Kogan SM, . Family-centered program deters substance use, conduct problems, and depressive symptoms in black adolescents. Pediatrics. 2012;129(1):108–15. PMID: 22157131. KQ4E5e, KQ5E5e.22157131
31 Broning S, Sack PM, Thomsen M, . Implementing and evaluating the German adaptation of the “Strengthening Families Program 10 - 14”- a randomized-controlled multicentre study. BMC Public Health. 2014;14:83. PMID: 24467917. KQ4E5e, KQ5E5e.24467917
32 Cantillano V, Del Villar P, Contreras L, . Psychometric properties of the Spanish version of the Cannabis Use Problems Identification Test among Chilean university students: A validation study. Drug Alcohol Depend. 2017;170:32–6. PMID: 27866060. KQ2E10.27866060
33 Chambers JE, Brooks AC, Medvin R, . Examining multi-session brief intervention for substance use in primary care: research methods of a randomized controlled trial. Addict Sci Clin Pract. 2016;11(1):8. PMID: 27090097. KQ4E4, KQ5E4.27090097
34 Chasnoff I, Griffith D, MacGregor S, . Temporal patterns of cocaine use in pregnancy. Perinatal outcome. JAMA. 1989;261(12):1741–4. KQ4E1, KQ5E1.2918671
35 Chen WJ, Fang CC, Shyu RS, . Underreporting of illicit drug use by patients at emergency departments as revealed by two-tiered urinalysis. Addict Behav. 2006;31(12):2304–8. PMID: 16564643. KQ2E5a.16564643
36 Cherpitel CJ, Borges G. Screening for drug use disorders in the emergency department: performance of the rapid drug problems screen (RDPS). Drug Alcohol Depend. 2004;74(2):171–5. PMID: 15099660. KQ2E2a.15099660
37 Cherry AL, Dillon ME. The AC-OK Cooccurring Screen: Reliability, Convergent Validity, Sensitivity, and Specificity. J Addict. 2013;2013:573906. PMID: 24826362. KQ2E3a.24826362
38 Colon HM, Perez CM, Melendez M, . The validity of drug use responses in a household survey in Puerto Rico: comparison of survey responses with urinalysis. Addict Behav. 2010;35(7):667–72. PMID: 20223601. KQ2E5a.20223601
39 Copeland J, Swift W, Roffman R, . A randomized controlled trial of brief cognitive-behavioral interventions for cannabis use disorder. J Subst Abuse Treat. 2001;21(2):55–64. KQ4E3a, KQ5E3a.11551733
40 Corrigan MJ. Predictive validity test of the Adolescent Domain Screening Inventory. Journal of child & adolescent substance abuse. 2014;23(2):130–6. KQ2E6.
41 Cuenca-Royo AM, Sanchez-Niubo A, Forero CG, . Psychometric properties of the CAST and SDS scales in young adult cannabis users. Addict Behav. 2012;37(6):709–15. PMID: 22386300. KQ2E10.22386300
42 Cummins LH, Chan KK, Burns KM, . Validity of the CRAFFT in American-Indian and Alaska-Native adolescents: screening for drug and alcohol risk. J Stud Alcohol. 2003;64(5):727–32. PMID: 14572196. KQ2E10.14572196
43 Dagmar MH, Anne M, Daniele L, . Prism-Ado: Cluster Randomised Trial of a Brief Primary Care Intervention Addressing Excessive Substance Use in Young People. Turkish Archives of Pediatrics. 2013;48:34. KQ4E2a, KQ5E2a.
44 D’Amico EJ, Miles JN, Stern SA, . Brief motivational interviewing for teens at risk of substance use consequences: a randomized pilot study in a primary care clinic. J Subst Abuse Treat. 2008;35(1):53–61. PMID: 18037603. KQ4E10, KQ5E10.18037603
45 Dembo R, Briones-Robinson R, Schmeidler J, . Brief intervention impact on truant youths’ marijuana use: Eighteen-month follow-up. Journal of child & adolescent substance abuse. 2016;25(1):18–32. KQ4E3a, KQ5E3a.
46 Dennis ML, Chan YF, Funk RR. Development and validation of the GAIN Short Screener (GSS) for internalizing, externalizing and substance use disorders and crime/violence problems among adolescents and adults. Am J Addict. 2006;15: Suppl 1:80–91. PMID: 17182423. KQ2E3a.17182423
47 Donovan DM, Bogenschutz MP, Perl H, . Study design to examine the potential role of assessment reactivity in the Screening, Motivational Assessment, Referral, and Treatment in Emergency Departments (SMART-ED) protocol. Addict Sci Clin Pract. 2012;7:16. PMID: 23186329. KQ4E4, KQ5E4.23186329
48 Dupont HB, Candel M, Lemmens P, . Stages of Change Model has Limited Value in Explaining the Change in Use of Cannabis among Adolescent Participants in an Efficacious Motivational Interviewing Intervention. J Psychoactive Drugs. 2017:1–10. PMID: 28548619. KQ4E3a, KQ5E3a.27918874
49 Dupont HB, Candel MJ, Kaplan CD, . Assessing the Efficacy of MOTI-4 for Reducing the Use of Cannabis Among Youth in the Netherlands: A Randomized Controlled Trial. J Subst Abuse Treat. 2016;65:6–12. PMID: 26780988. KQ4E3a, KQ5E3a.26780988
50 Durbeej N, Berman AH, Gumpert CH, . Validation of the Alcohol Use Disorders Identification Test and the Drug Use Disorders Identification Test in a Swedish sample of suspected offenders with signs of mental health problems: results from the Mental Disorder, Substance Abuse and Crime study. J Subst Abuse Treat. 2010;39(4):364–77. PMID: 20822878. KQ2E3b.20822878
51 Dyer P. Brief substance dependence screening for women. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2006;67(6-B):3447. KQ2E3a.
52 Eisenberg K, Woodruff SI. Randomized controlled trial to evaluate screening and brief intervention for drug-using multiethnic emergency and trauma department patients. Addict Sci Clin Pract. 2013;8(1):8. PMID: 23566363. KQ4E12, KQ5E12.23566363
53 Estrada Y, Rosen A, Huang S, . Efficacy of a Brief Intervention to Reduce Substance Use and Human Immunodeficiency Virus Infection Risk Among Latino Youth. J Adolesc Health. 2015. PMID: 26549551. KQ4E5e, KQ5E5e.26549551
54 Fang L, Schinke SP. Two-year outcomes of a randomized, family-based substance use prevention trial for Asian American adolescent girls. Psychol Addict Behav. 2013;27(3):788–98. PMID: 23276322. KQ4E5e, KQ5E5e.23276322
55 Fang L, Schinke SP, Cole KC. Preventing substance use among early Asian-American adolescent girls: initial evaluation of a web-based, mother-daughter program. J Adolesc Health. 2010;47(5):529–32. PMID: 20970090. KQ4E5e, KQ5E5e.20970090
56 Feinn R, Gelernter J, Cubells JF, . Sources of unreliability in the diagnosis of substance dependence. J Stud Alcohol Drugs. 2009;70(3):475–81. KQ2E5a.19371499
57 Fischer B, Jones W, Shuper P, . 12-month follow-up of an exploratory ‘brief intervention’ for high-frequency cannabis users among Canadian university students. Subst Abuse Treat Prev Policy. 2012;7:15. PMID: 22538183. KQ4E3a, KQ5E3a.22538183
58 Fridell M, Hesse M. Psychiatric severity and mortality in substance abusers: a 15-year follow-up of drug users. Addict Behav. 2006;31(4):559–65. PMID: 15967584. KQ4E1, KQ5E1.15967584
59 Gillespie W, Holt JL, Blackwell RL. Measuring outcomes of alcohol, marijuana, and cocaine use among college students: A preliminary test of the Shortened Inventory of Problems-Alcohol and Drugs (SIP-AD). J Drug Issues. 2007;37(3):549–68. KQ2E4.
60 Group WAW. The Alcohol, Smoking and Substance Involvement Screening Test (ASSIST): development, reliability and feasibility. Addiction. 2002;97(9):1183–94. KQ2E4.12199834
61 Gryczynski J, Mitchell S, Peterson T, . The relationship between services delivered and substance use outcomes in New Mexico’s Screening, Brief Intervention, Referral and Treatment (SBIRT) Initiative. Drug Alcohol Depend. 2011;118(2–3):152–7. PMID: 21482039. KQ4E9, KQ5E9.21482039
62 Gryczynski J, Mitchell SG, Ondersma SJ, . Potential radiating effects of misusing substances among medical patients receiving brief intervention. J Subst Abuse Treat. 2015;55:39–44. PMID: 25812927. KQ4E6, KQ5E6.25812927
63 Guan W, Liu T, Baird J, . Evaluation of a brief intervention to reduce the negative consequences of drug misuse among adult emergency department patients. Drug Alcohol Depend. 2015;157:44–53. PMID: 26482090. KQ4E12, KQ5E12.26482090
64 Guthmann D, Lazowski LE, Moore D, . Validation of the substance abuse screener in American Sign Language (SAS-ASL). Rehabil Psychol. 2012;57(2):140–8. PMID: 22686552. KQ2E5a.22686552
65 Gyepesi A, Urban R, Farkas J, . Psychometric properties of the Cannabis Abuse Screening Test in Hungarian samples of adolescents and young adults. Eur Addict Res. 2014;20(3):119–28. PMID: 24217457. KQ2E10.24217457
66 Haller DM, Meynard A, Lefebvre D, . Effectiveness of training family physicians to deliver a brief intervention to address excessive substance use among young patients: a cluster randomized controlled trial. CMAJ : Canadian Medical Association journal = journal de l’Association medicale canadienne. 2014;186(8):E263–72. PMID: 24616136. KQ1E5a, KQ3E5a.24616136
67 Harris SK, Csemy L, Sherritt L, . Computer-facilitated substance use screening and brief advice for teens in primary care: an international trial. Pediatrics. 2012;129(6):1072–82. PMID: 22566420. KQ4E5e, KQ5E5e.22566420
68 Heinemann AW, Lazowski LE, Moore D, . Validation of a substance use disorder screening instrument for use in vocational rehabilitation settings. Rehabil Psychol. 2008;53(1):63–72. KQ2E5a.
69 Helmer SM, Muellmann S, Zeeb H, . Development and evaluation of the efficacy of a web-based ‘social norms’-intervention for the prevention and reduction of substance use in a cluster-controlled trial conducted at eight German universities. BMC Public Health. 2016;16:252. PMID: 26969585. KQ4E3a, KQ5E3a.26969585
70 Hides L, Carroll S, Scott R, . Quik Fix: a randomized controlled trial of an enhanced brief motivational interviewing intervention for alcohol/cannabis and psychological distress in young people. Psychother Psychosom. 2013;82(2):122–4. PMID: 23295899. KQ4E2b, KQ5E2b.23295899
71 Holliday J, Segrott J, Rothwell H, . Pragmatic trials of non-NHS interventions: Experiences from a Randomised Controlled Trial of the Strengthening Families 10–14 UK Programme (SFP10–14 UK). Trials. 2011;12. KQ4E5e, KQ5E5e.
72 Hotham E, Ali R, White J, . Investigation of the Alcohol, Smoking, and Substance Involvement Screening Test (the ASSIST) Version 3.0 in pregnancy. Addict Disord Their Treat. 2013;12(3):123–35. KQ2E10.
73 Hser YI, Hoffman V, Grella CE, . A 33-year follow-up of narcotics addicts. Arch Gen Psychiatry. 2001;58(5):503–8. PMID: 11343531. KQ4E1, KQ5E1.11343531
74 Huang S, Cordova D, Estrada Y, . An application of the Complier Average Causal Effect analysis to examine the effects of a family intervention in reducing illicit drug use among high-risk Hispanic adolescents. Family process. 2014;53(2):336–47. PMID: 24611528. KQ4E5e, KQ5E5e.24611528
75 Humeniuk R, Ali R, Babor TF, . Validation of the Alcohol, Smoking And Substance Involvement Screening Test (ASSIST). Addiction. 2008;103(6):1039–47. PMID: 18373724. KQ2E2b.18373724
76 J M, J S. Deterioration over time in effect of Motivational Interviewing in reducing drug consumption and related risk among young people. Addiction. 2005;100(4):470–8. KQ4E3a, KQ5E3a.15784061
77 Jalling C, Bodin M, Romelsjo A, . Parent Programs for Reducing Adolescent’s Antisocial Behavior and Substance Use: A Randomized Controlled Trial. J Child Fam Stud. 2016;25:811–26. PMID: 26900316. KQ4E3a, KQ5E3a.26900316
78 Jensen MR, Wong JJ, Gonzales NA, . Long-term effects of a universal family intervention: mediation through parent-adolescent conflict. Journal of Clinical Child & Adolescent Psychology. 2014;43(3):415–27. PMID: 24730357. KQ4E5e, KQ5E5e.24730357
79 JF K, E G, T P, . Reliabilities of short substance abuse screening tests among adolescent medical patients. Pediatrics. 2000;105:948–53. KQ2E4.10742352
80 Kandemir H, Aydemir O, Ekinci S, . Validity and reliability of the Turkish version of CRAFFT Substance Abuse Screening Test among adolescents. Neuropsychiatr. 2015;11:1505–9. PMID: 26150721. KQ2E2a.26150721
81 Kay-Lambkin FJ, Baker AL, Lewin TJ, . Computer-based psychological treatment for comorbid depression and problematic alcohol and/or cannabis use: a randomized controlled trial of clinical efficacy. Addiction. 2009;104(3):378–88. KQ4E3a, KQ5E3a.19207345
82 Kedzior KK, Martin-Iverson MT. Concurrent validity of cannabis misuse diagnoses on CIDI-Auto 2.1 in low-level cannabis users from the general population. Australian Journal of Psychology. 2007;59(3):169–75. KQ2E6.
83 Kellogg SH, McHugh PF, Bell K, . The Kreek-McHugh-Schluger-Kellogg scale: a new, rapid method for quantifying substance abuse and its possible applications. Drug Alcohol Depend. 2003;69(2):137–50. PMID: 12609695. KQ2E2b.12609695
84 Khan R, Chatton A, Nallet A, . Validation of the French version of the alcohol, smoking and substance involvement screening test (ASSIST). Eur Addict Res. 2011;17(4):190–7. PMID: 21494047. KQ2E2b.21494047
85 Kills Small NJ, Simons JS, Stricherz M. Assessing criterion validity of the Simple Screening Instrument for Alcohol and Other Drug Abuse (SSI-AOD) in a college population. Addict Behav. 2007;32(10):2425–31. PMID: 17481826. KQ2E3a.17481826
86 Kirisci L, Reynolds M, Carver D, . Quick screen to detect current substance use disorder in adolescents and the likelihood of future disorder. Drug Alcohol Depend. 2013;128(1–2):116–22. PMID: 22999041. KQ2E2b.22999041
87 Kirisci L, Reynolds M, Tarter R. Quick Screen to Detect Current and Future Substance Use Disorder in Female Adolescents. International Journal of Person Centered Medicine. 2013;3(4):280–5. PMID: 25089182. KQ2E1.25089182
88 Knight JR, Shrier LA, Bravender TD, . A new brief screen for adolescent substance abuse. Arch Pediatr Adolesc Med. 1999;153(6):591–6. PMID: 10357299. KQ2E6.10357299
89 Knowlton A, Latkin C, Schroeder J, . Longitudinal predictors of depressive symptoms among low income injection drug users. AIDS Care. 2001;13(5):549–59. KQ4E1, KQ5E1.11571003
90 Kumpfer KL, Whiteside HO, Greene JA, . Effectiveness outcomes of four age versions of the Strengthening Families Program in statewide field sites. Group Dynamics: Theory, Research, and Practice. 2010;14(3):211–29. KQ4E5e, KQ5E5e.
91 Kurtz SP, Buttram ME, Pagano ME, . A randomized trial of brief assessment interventions for young adults who use drugs in the club scene. J Subst Abuse Treat. 2017;78:64–73. PMID: 28554606. KQ4E3a, KQ5E3a.28554606
92 L B, Francis G, K L. The RAFFT as a screening tool for adolescent substance use disorders. Am J Addict. 2000;9:10–6. KQ2E3a.10914289
93 L B, K R, D S. The RAFFT as a screening tool for adult substance use disorders. Am J Drug Alc Abuse. 2002;28:681–91. KQ2E3a.
94 Laporte C, Vaillant-Roussel H, Pereira B, . Cannabis and Young Users-A Brief Intervention to Reduce Their Consumption (CANABIC): A Cluster Randomized Controlled Trial in Primary Care. Ann Fam Med. 2017;15(2):131–9. PMID: 28289112. KQ4E10, KQ5E10.28289112
95 Laporte C, Vaillant-Roussel H, Pereira B, . CANABIC: CANnabis and Adolescents: effect of a Brief Intervention on their Consumption-study protocol for a randomized controlled trial. Trials [Electronic Resource]. 2014;15:40. PMID: 24479702. KQ4E4, KQ5E4.24479702
96 Lee JD, Delbanco B, Wu E, . Substance use prevalence and screening instrument comparisons in urban primary care. Subst Abus. 2011;32(3):128–34. PMID: 21660872. KQ2E6.21660872
97 Legleye S, Karila L, Beck F, . Validation of the CAST, a general population Cannabis Abuse Screening Test. Journal of Substance Use. 2007;12(4):233–42. KQ2E10.
98 Legleye S, Piontek D, Kraus L, . A validation of the Cannabis Abuse Screening Test (CAST) using a latent class analysis of the DSM-IV among adolescents. Int J Methods Psychiatr Res. 2013;22(1):16–26. PMID: 23519957. KQ2E6.23519957
99 Leonardson GR, Kemper E, Ness FK, . Validity and reliability of the audit and CAGE-AID in Northern Plains American Indians. Psychological reports. 2005;97(1):161–6. PMID: 16279320. KQ2E6.16279320
100 Levy S, Weiss R, Sherritt L, . An electronic screen for triaging adolescent substance use by risk levels. JAMA Pediatr. 2014;168(9):822–8. PMID: 25070067. KQ2E2b.25070067
101 Louis M, Ricketson J, Wishart I. What is the accuracy of screening instruments for alcohol and cannabis misuse disorders among adolescents and young adults in the emergency department? Ann Emerg Med. 2013;61(4):404–6. PMID: 23102852. KQ2E9.23102852
102 Lucas G, Cheever L, Chaisson R, . Detrimental effects of continued illicit drug use on the treatment of HIV-1 infection. J Acquir Immune Defic Syndr. 2001;27(3):251–9. KQ4E1, KQ5E1.11464144
103 Lucas G, Griswold M, Gebo K, . Illicit drug use and HIV-1 disease progression: a longitudinal study in the era of highly active antiretroviral therapy. Am J Epidemiol. 2006;163(5):412–20. KQ4E1, KQ5E1.16394200
104 Marijuana Treatment Project Research Group. Brief treatments for cannabis dependence: findings from a randomized multisite trial. J Consult Clin Psychol. 2004;72(3):455–66. PMID: 15279529. KQ4E3a, KQ5E3a.15279529
105 Marsden J, Stillwell G, Barlow H, . An evaluation of a brief motivational intervention among young ecstasy and cocaine users: no effect on substance and alcohol use outcomes. Addiction. 2006;101(7):1014–26. PMID: 16771893. KQ4E3a, KQ5E3a.16771893
106 Marsden J, Stillwell G, Barlow H, . An evaluation of a brief intervention model for use with young non-injecting stimulant users. DRUGS-EDUCATION PREVENTION AND POLICY. 2005;12:90–3. PMID: None. KQ4E3a, KQ5E3a.
107 Marsiglia FF, Ayers SL, Baldwin-White A, . Changing Latino Adolescents’ Substance Use Norms and Behaviors: the Effects of Synchronized Youth and Parent Drug Use Prevention Interventions. Prev Sci. 2016;17(1):1–12. PMID: 26103920. KQ4E5e, KQ5E5e.26103920
108 Martin G, Copeland J. The adolescent cannabis check-up: randomized trial of a brief intervention for young cannabis users. J Subst Abuse Treat. 2008;34(4):407–14. PMID: 17869051. KQ4E3a, KQ5E3a.17869051
109 Martin G, Copeland J, Gates P, . The Severity of Dependence Scale (SDS) in an adolescent population of cannabis users: reliability, validity and diagnostic cut-off. Drug Alcohol Depend. 2006;83(1):90–3. PMID: 16310973. KQ2E10.16310973
110 Mason WA, Haggerty K, Fleming A, . Family intervention to prevent depression and substance use among adolescents of depressed parents. J Child Fam Stud. 2012;21(6):891–905. PMID: None. KQ4E5e, KQ5E5e.23798891
111 McCambridge J, Day M, Thomas BA, . Fidelity to Motivational Interviewing and subsequent cannabis cessation among adolescents. Addict Behav. 2011;36(7):749–54. PMID: 21440994. KQ4E4, KQ5E4.21440994
112 McCambridge J, Slym RL, Strang J. Randomized controlled trial of motivational interviewing compared with drug information and advice for early intervention among young cannabis users. Addiction. 2008;103(11):1809–18. PMID: 18778385. KQ4E3a, KQ5E3a.18778385
113 Merchant R, Baird J, Liu T. Short-term Efficacy of a Brief Intervention to Reduce Drug Misuse and Increase Drug Treatment Utilization Among Adult Emergency Department Patients. Acad Emerg Med. 2015;22(10):1172–80. PMID: 26375468. KQ4E10, KQ5E10.26375468
114 Milburn NG, Iribarren FJ, Rice E, . A family intervention to reduce sexual risk behavior, substance use, and delinquency among newly homeless youth. Journal of Adolescent Health. 2012;50(4):358–64. PMID: 22443839. KQ4E3a, KQ5E3a.22443839
115 Miller WR, Toscova RT, Miller JH, . A theory-based motivational approach for reducing alcohol/drug problems in college. Health education & behavior : the official publication of the Society for Public Health Education. 2000;27(6):744–59. PMID: 11104373. KQ4E5e, KQ5E5e.11104373
116 Moon K. Targeted interventions for adolescents to prevent drug use. Am Fam Physician. 2010;81(11):1369–74. KQ4E9, KQ5E9.
117 Morley KC, Sitharthan G, Haber PS, . The efficacy of an opportunistic cognitive behavioral intervention package (OCB) on substance use and comorbid suicide risk: a multisite randomized controlled trial. Journal of Consulting & Clinical Psychology. 2014;82(1):130–40. PMID: 24364795. KQ4E3a, KQ5E3a.24364795
118 N E-B, RF S, S S, . Assessing the utility of the Drug Abuse Screening Test in the workplace. Research on Social Work Practice. 1997;7:99–114. KQ2E2b.
119 Nct. Substance-use Focused Screening and Brief Intervention as a Complement to Internet-based Psychiatric Treatment for Depression, Panic Disorder or Social Phobia: A Randomized Controlled Trial (eScreeniPsy). Http://clinicaltrialsgov/show/NCT01885026. 2013. KQ4E4, KQ5E4.
120 Newcombe D, Tanielu-Stowers H, McDermott R, . The validation of the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) amongst Pacific people in New Zealand. New Zealand Journal of Psychology. 2016;45(1):30–9. KQ2E4.
121 Newcombe DA, Humeniuk RE, Ali R. Validation of the World Health Organization Alcohol, Smoking and Substance Involvement Screening Test (ASSIST): report of results from the Australian site. Drug Alcohol Rev. 2005;24(3):217–26. PMID: 16096125. KQ2E2b.16096125
122 Norberg M, Hides L, Olivier J, . Brief interventions to reduce Ecstasy use: a multi-site randomized controlled trial. Behav Ther. 2014;45(6):745–59. PMID: 25311285. KQ4E3a, KQ5E3a.25311285
123 Nyamathi A, Branson C, Kennedy B, . Impact of nursing intervention on decreasing substances among homeless youth. Am J Addict. 2012;21(6):558–65. PMID: 23082836. KQ4E6, KQ5E6.23082836
124 O’Connor PG. Managing substance dependence as a chronic disease is the glass half full or half empty? JAMA: Journal of the American Medical Association. 2013;310(11):1132–4. KQ4E9, KQ5E9.24045739
125 O’Farrell TJ, Fals-Stewart W, Murphy M. Concurrent validity of a brief self-report drug use frequency measure. Addict Behav. 2003;28(2):327–37. KQ2E4.12573682
126 Okulicz-Kozaryn K, Sieroslawski J. Validation of the “problematic use of narcotics” (PUN) screening test for drug using adolescents. Addict Behav. 2007;32(3):640–6. PMID: 16870350. KQ2E9.16870350
127 Palfai T, Saitz R, Winter M. Moderators of electronic screening and brief intervention for marijuana among students in a health center: eCHECKUP TO GO bolsters efforts of those who are already trying to change. Drug Alcohol Depend. 2015;156:e170. KQ4E11, KQ5E11.
128 Pantin H, Prado G, Lopez B, . A randomized controlled trial of Familias Unidas for Hispanic adolescents with behavior problems. Psychosomatic medicine. 2009;71(9):987–95. KQ4E5e, KQ5E5e.19834053
129 Passos SR, Camacho LA, Lopes CS, . Nefazodone in out-patient treatment of inhaled cocaine dependence: a randomized double-blind placebo-controlled trial. Addiction. 2005;100(4):489–94. PMID: 15784063. KQ4E5c, KQ5E5c.15784063
130 Peterson PL, Baer JS, Wells EA, . Short-term effects of a brief motivational intervention to reduce alcohol and drug risk among homeless adolescents. Psychol Addict Behav. 2006;20(3):254–64. PMID: 16938063. KQ4E10, KQ5E10.16938063
131 Piehler TF, Winters KC. Parental involvement in brief interventions for adolescent marijuana use. Psychol Addict Behav. 2015;29(3):512–21. PMID: 26415058. KQ4E3a, KQ5E3a.26415058
132 Rapp RC, Otto AL, Lane DT, . Improving linkage with substance abuse treatment using brief case management and motivational interviewing. Drug Alcohol Depend. 2008;94(1–3):172–82. PMID: 18242883. KQ4E3a, KQ5E3a.18242883
133 Rhee H, Hollen PJ, Belyea MJ, . Decision-making program for rural adolescents with asthma: a pilot study. Journal of pediatric nursing. 2008;23(6):439–50. PMID: 19026912. KQ4E5e, KQ5E5e.19026912
134 Robbins MS, Feaster DJ, Horigian VE, . Brief strategic family therapy versus treatment as usual: results of a multisite randomized trial for substance using adolescents. Journal of Consulting & Clinical Psychology. 2011;79(6):713–27. PMID: 21967492. KQ4E3a, KQ5E3a.21967492
135 Rubio Valldolid G, Martinez-Raga J, Martinez-Gras I, . Validation of the Spanish version of the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST). Psicothema. 2014;26(2):180–5. PMID: 24755018. KQ2E2b.24755018
136 S L, L S, SK H, . Test-retest reliability of adolescents’ self-report of substance use. Alcohol Clin Exp Res. 2004;28:1236–41. KQ2E4.15318123
137 Salvalaggio G, Dong K, Vandenberghe C, . Enhancing screening, brief intervention, and referral to treatment among socioeconomically disadvantaged patients: study protocol for a knowledge exchange intervention involving patients and physicians. BMC Health Serv Res. 2013;13:108. PMID: 23517813. KQ4E3a, KQ5E3a.23517813
138 Sanci L, Chondros P, Sawyer S, . Responding to Young People’s Health Risks in Primary Care: A Cluster Randomised Trial of Training Clinicians in Screening and Motivational Interviewing. PloS one. 2015;10(9):e0137581. PMID: 26422235. KQ1E10, KQ3E10.26422235
139 Satre DD, Delucchi K, Lichtmacher J, . Motivational interviewing to reduce hazardous drinking and drug use among depression patients. J Subst Abuse Treat. 2013;44(3):323–9. PMID: 22999815. KQ4E3a, KQ5E3a.22999815
140 Satre DD, Leibowitz A, Sterling SA, . A randomized clinical trial of Motivational Interviewing to reduce alcohol and drug use among patients with depression. Journal of Consulting & Clinical Psychology. 2016;84(7):571–9. PMID: 26985728. KQ4E3a, KQ5E3a.26985728
141 Schaub M, Sullivan R, Haug S, . Web-based cognitive behavioral self-help intervention to reduce cocaine consumption in problematic cocaine users: randomized controlled trial. J Med Internet Res. 2012;14(6):e166. PMID: 23192752. KQ4E6, KQ5E6.23192752
142 Schaub M, Sullivan R, Stark L. Snow control - an RCT protocol for a web-based self-help therapy to reduce cocaine consumption in problematic cocaine users. BMC psychiatry. 2011;11:153. PMID: 21943294. KQ4E6, KQ5E6.21943294
143 Schaub MP, Haug S, Wenger A, . Can reduce-the effects of chat-counseling and web-based self-help, web-based self-help alone and a waiting list control program on cannabis use in problematic cannabis users: a randomized controlled trial. BMC psychiatry. 2013;13:305. PMID: 24228630. KQ4E4, KQ5E4.24228630
144 Schaub MP, Maier LJ, Wenger A, . Evaluating the efficacy of a web-based self-help intervention with and without chat counseling in reducing the cocaine use of problematic cocaine users: the study protocol of a pragmatic three-arm randomized controlled trial.[Erratum appears in BMC Psychiatry. 2015;15:218; PMID: 26376748]. BMC psychiatry. 2015;15:156. PMID: 26159624. KQ4E3a, KQ5E3a.26159624
145 Schinke SP, Fang L, Cole KC. Preventing substance use among adolescent girls: 1-year outcomes of a computerized, mother-daughter program. Addict Behav. 2009;34(12):1060–4. PMID: 19632053. KQ4E5e, KQ5E5e.19632053
146 Schinke SP, Fang L, Cole KC. Computer-delivered, parent-involvement intervention to prevent substance use among adolescent girls. Preventive medicine. 2009;49(5):429–35. PMID: 19682490. KQ4E5e, KQ5E5e.19682490
147 Schonfeld L, King-Kallimanis B, Duchene D, . Screening and brief intervention for substance misuse among older adults: the Florida BRITE project. Am J Public Health. 2010;100(1):108–14. PMID: 19443821. KQ4E9, KQ5E9.19443821
148 Schwartz RP, McNeely J, Wu LT, . Identifying substance misuse in primary care: TAPS Tool compared to the WHO ASSIST. J Subst Abuse Treat. 2017;76:69–76. PMID: 28159441. KQ2E6.28159441
149 Segrott J, Gillespie D, Holliday J, . Preventing substance misuse: study protocol for a randomised controlled trial of the Strengthening Families Programme 10–14 UK (SFP 10–14 UK). BMC Public Health. 2014;14:49. PMID: 24438460. KQ4E5e, KQ5E5e.24438460
150 Seib CA, Daglish M, Heath R, . Screening for alcohol and drug use in pregnancy. Midwifery. 2012;28(6):760–4. PMID: 21940079. KQ2E6.21940079
151 Shankaran S, Das A, Bauer C, . Association between patterns of maternal substance use and infant birth weight, length, and head circumference. Pediatrics. 2004;114(2):e226–e34. KQ4E1, KQ5E1.15286261
152 Sinadinovic K, Berman AH, Hasson D, . Internet-based assessment and self-monitoring of problematic alcohol and drug use. Addict Behav. 2010;35(5):464–70. KQ2E4.20092953
153 Sinadinovic K, Wennberg P, Berman AH. Targeting problematic users of illicit drugs with Internet-based screening and brief intervention: a randomized controlled trial. Drug Alcohol Depend. 2012;126(1–2):42–50. PMID: 22613182. KQ4E3a, KQ5E3a.22613182
154 Skarstrand E, Sundell K, Andreasson S. Evaluation of a Swedish version of the Strengthening Families Programme. European journal of public health. 2014;24(4):578–84. PMID: 24078373. KQ4E5e, KQ5E5e.24078373
155 Skinner HA. The drug abuse screening test. Addict Behav. 1982;7(4):363–71. PMID: 7183189. KQ2E4.7183189
156 Skogen JC, Boe T, Knudsen AK, . Psychometric properties and concurrent validity of the CRAFFT among Norwegian adolescents. Ung@hordaland, a population-based study. Addict Behav. 2013;38(10):2500–5. PMID: 23770648. KQ2E6.23770648
157 Slesnick N, Tonigan J. Assessment of Alcohol and Other Drug Use by Runaway Youths: A Test-Retest Study of the Form 90. Alcoholism Treatment Quarterly. 2004;22(2):21–34. KQ2E4.18563208
158 Smith DC, Bennett KM, Dennis ML, . Sensitivity and specificity of the gain short-screener for predicting substance use disorders in a large national sample of emerging adults. Addict Behav. 2017;68:14–7. PMID: 28088053. KQ2E3a.28088053
159 Sorensen HJ, Jepsen PW, Haastrup S, . Drug-use pattern, comorbid psychosis and mortality in people with a history of opioid addiction. Acta psychiatrica Scandinavica. 2005;111(3):244–9. PMID: 15701109. KQ4E1, KQ5E1.15701109
160 Spoth R, Redmond C, Shin C, . PROSPER community-university partnership delivery system effects on substance misuse through 6 1/2 years past baseline from a cluster randomized controlled intervention trial.[Erratum appears in Prev Med. 2014 Dec;69:36]. Preventive medicine. 2013;56(3–4):190–6. PMID: 23276777. KQ4E2b, KQ5E2b.23276777
161 Spoth R, Trudeau L, Redmond C, . Replication RCT of early universal prevention effects on young adult substance misuse. Journal of Consulting & Clinical Psychology. 2014;82(6):949–63. PMID: 24821095. KQ4E5e, KQ5E5e.24821095
162 Staley D, el-Guebaly N. Psychometric properties of the Drug Abuse Screening Test in a psychiatric patient population. Addict Behav. 1990;15(3):257–64. PMID: 2378285. KQ2E3a.2378285
163 Stanger C, Budney AJ, Kamon JL, . A randomized trial of contingency management for adolescent marijuana abuse and dependence. Drug Alcohol Depend. 2009;105(3):240–7. PMID: 19717250. KQ4E3a, KQ5E3a.19717250
164 Stein M, Herman D, Anderson B. A motivational intervention trial to reduce cocaine use. J Subst Abuse Treat. 2009;36(1):118–25. PMID: 18657938. KQ4E3a, KQ5E3a.18657938
165 Stein MD, Caviness CM, Morse EF, . A Developmental-based Motivational Intervention to Reduce Alcohol and Marijuana Use Among Non-Treatment-Seeking Young Adults: A Randomized Controlled Trial. Addiction. 2017. PMID: 28865169. KQ4E3a, KQ5E3a.28865169
166 Stephens R, Roffman R, Curtin L. Comparison of extended versus brief treatments for marijuana use. J Consult Clin Psychol. 2000;68(5):898–908. KQ4E3a, KQ5E3a.11068976
167 Sterling S, Kline-Simon AH, Weisner C, . Pediatrician and Behavioral Clinician-Delivered Screening, Brief Intervention and Referral to Treatment: Substance Use and Depression Outcomes. Journal of Adolescent Health. 2018;62(4):390–6. PMID: 29396080. KQ4E10, KQ5E10.29396080
168 Stoutenberg M, Rethorst CD, Fuzat G, . STimulant Reduction Intervention using Dosed Exercise (STRIDE)-Description of the exercise intervention and behavioral program to ensure adherence. Mental health and physical activity. 2012;5(2):175–82. KQ4E3a, KQ5E3a.23667387
169 Subramaniam M, Cheok C, Verma S, . Validity of a brief screening instrument-CRAFFT in a multiethnic Asian population. Addict Behav. 2010;35(12):1102–4. PMID: 20805016. KQ2E10.20805016
170 Tait RJ, Hulse GK, Robertson SI. Effectiveness of a brief-intervention and continuity of care in enhancing attendance for treatment by adolescent substance users. Drug Alcohol Depend. 2004;74(3):289–96. PMID: 15194207. KQ4E4, KQ5E4.15194207
171 Tait RJ, Hulse GK, Robertson SI, . Emergency department-based intervention with adolescent substance users: 12-month outcomes. Drug Alcohol Depend. 2005;79(3):359–63. PMID: 16102378. KQ4E3a, KQ5E3a.16102378
172 Tait RJ, McKetin R, Kay-Lambkin F, . Breakingtheice: a protocol for a randomised controlled trial of an internet-based intervention addressing amphetamine-type stimulant use. BMC psychiatry. 2012;12:67. PMID: 22731926. KQ4E4, KQ5E4.22731926
173 Tait RJ, McKetin R, Kay-Lambkin F, . Six-month outcomes of a Web-based intervention for users of amphetamine-type stimulants: randomized controlled trial. J Med Internet Res. 2015;17(4):e105. PMID: 25925801. KQ4E3a, KQ5E3a.25925801
174 Tait RJ, Teoh L, Kelty E, . Emergency department based intervention with adolescent substance users: 10year economic and health outcomes. Drug Alcohol Depend. 2016;165:168–74. PMID: 27317044. KQ4E4, KQ5E4.27317044
175 Tirrell CA. Concurrent validity of the MMPI-A substance abuse scales: MAC-R, ACK, and PRO. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;65(9-B):4893. KQ2E5a.
176 Tucker JA. Commentary on Gates et al. (2012): Telehealth services to extend the reach of care involve more than using a telephone for intervention delivery. Addiction. 2012;107(12):2159–60. KQ4E9, KQ5E9.23167648
177 Voluse AC, Gioia CJ, Sobell LC, . Psychometric properties of the Drug Use Disorders Identification Test (DUDIT) with substance abusers in outpatient and residential treatment. Addict Behav. 2012;37(1):36–41. PMID: 21937169. KQ2E3a.21937169
178 Wagner EF, Hospital MM, Graziano JN, . A randomized controlled trial of guided self-change with minority adolescents. Journal of Consulting & Clinical Psychology. 2015;82(6):1128–39. PMID: 24841864. KQ4E3a, KQ5E3a.24841864
179 Walker DD, Stephens RS, Blevins CE, . Augmenting brief interventions for adolescent marijuana users: The impact of motivational check-ins. Journal of Consulting & Clinical Psychology. 2016;84(11):983–92. PMID: 27762569. KQ4E3a, KQ5E3a.27762569
180 Watson J, Toner P, Day E, . Youth social behaviour and network therapy (Y-SBNT): adaptation of a family and social network intervention for young people who misuse alcohol and drugs - a randomised controlled feasibility trial. Health Technol Assess. 2017;21(15):1–260. PMID: 28399988. KQ4E3a, KQ5E3a.28399988
181 Werch CE, Moore MJ, Bian H, . Efficacy of a brief image-based multiple-behavior intervention for college students. Ann Behav Med. 2008;36(2):149–57. PMID: 18800217. KQ4E1, KQ5E1.18800217
182 Westermeyer J, Yargic I, Thuras P. Michigan assessment-screening test for alcohol and drugs (MAST/AD): evaluation in a clinical sample. Am J Addict. 2004;13(2):151–62. PMID: 15204666. KQ2E3a.15204666
183 Whetten K, Reif S, Swartz M, . A brief mental health and substance abuse screener for persons with HIV. AIDS Patient Care STDS. 2005;19(2):89–99. PMID: 15716640. KQ2E9.15716640
184 Wickersham JA, Azar MM, Cannon CM, . Validation of a Brief Measure of Opioid Dependence: The Rapid Opioid Dependence Screen (RODS). Journal of Correctional Health Care. 2015;21(1):12–26. PMID: 25559628. KQ2E3b.25559628
185 Wiggins M, Bonell C, Sawtell M, . Health outcomes of youth development programme in England: Prospective matched comparison study. BMJ. 2009;339(7713):148–51. KQ4E6, KQ5E6.
186 Wilson CR, Sherritt L, Gates E, . Are clinical impressions of adolescent substance use accurate? Pediatrics. 2004;114(5):e536–40. PMID: 15520086. KQ2E1.15520086
187 Winters KC, Kaminer Y. Screening and assessing adolescent substance use disorders in clinical populations. Journal of the American Academy of Child & Adolescent Psychiatry. 2008;47(7):740–4. PMID: 18574399. KQ2E9.18574399
188 Winters KC, Latimer WW, Stinchfield RD, . Measuring adolescent drug abuse and psychosocial factors in four ethnic groups of drug-abusing boys. Experimental and clinical psychopharmacology. 2004;12(4):227–36. PMID: 15571439. KQ2E5a.15571439
189 Winters KC, Lee S, Botzet A, . One-year outcomes and mediators of a brief intervention for drug abusing adolescents. Psychol Addict Behav. 2014;28(2):464–74. PMID: 24955669. KQ4E3a, KQ5E3a.24955669
190 Woodruff S, Clapp J, Eisenberg K, . Randomized clinical trial of the effects of screening and brief intervention for illicit drug use: the Life Shift/Shift Gears study. Addict Sci Clin Pract. 2014;9:8. PMID: 24886786. KQ4E10, KQ5E10.24886786
191 Wusthoff LE, Waal H, Grawe RW. The effectiveness of integrated treatment in patients with substance use disorders co-occurring with anxiety and/or depression-a group randomized trial. BMC psychiatry. 2014;14:67. PMID: 24597469. KQ4E2b, KQ5E2b.24597469
192 Yonkers K, Gotman N, Kershaw T, . Screening for prenatal substance use: development of the Substance Use Risk Profile-Pregnancy scale. Obstet Gynecol. 2010;116(4):827–33. PMID: 20859145. KQ2E6.20859145
193 Yurasek AM. A randomized controlled trial of a behavioral economic intervention for substance abuse in a diverse college sample. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2015;76(6-B(E)):No Pagination Specified. KQ4E6, KQ5E6.
194 Yurasek AM, Dennhardt AA, Murphy JG. A randomized controlled trial of a behavioral economic intervention for alcohol and marijuana use. Experimental & Clinical Psychopharmacology. 2015;23(5):332–8. PMID: 26191947. KQ4E6, KQ5E6.26191947
195 Zatzick D, Russo J, Lord SP, . Collaborative care intervention targeting violence risk behaviors, substance use, and posttraumatic stress and depressive symptoms in injured adolescents: a randomized clinical trial. JAMA Pediatr. 2014;168(6):532–9. PMID: 24733515. KQ4E3b, KQ5E3b.24733515
196 Zgierska A, Amaza IP, Brown RL, . Unhealthy drug use: how to screen, when to intervene. Journal of Family Practice. 2014;63(9):524–30. PMID: 25353031. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9.25353031