# Appendix E List of Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

## KQ1 and KQ3

No included studies

## KQ2

- Bastiani L, Siciliano V, Curzio O, . Optimal scaling of the CAST and of SDS Scale in a national sample of adolescents. Addict Behav. 2013;38(4):2060–7. PMID: 23396173. 10.1016/j.addbeh.2012.12.016 23396173
- Beaudoin FL, Merchant RC, Clark MA. Prevalence and Detection of Prescription Opioid Misuse and Prescription Opioid Use Disorder Among Emergency Department Patients 50 Years of Age and Older: Performance of the Prescription Drug Use Questionnaire, Patient Version. Am J Geriatr Psychiatry. 2016;24(8):627–36. PMID: 27426210. 10.1016/j.jagp.2016.03.010 27426210
- Brown RL, Leonard T, Saunders LA, . A two-item conjoint screen for alcohol and other drug problems. J Am Board Fam Pract. 2001;14(2):95–106. PMID: 11314930.11314930
- Chasnoff I, Wells A, McGourty R, . Validation of the 4P’s Plus screen for substance use in pregnancy validation of the 4P’s Plus. J Perinatol. 2007;27(12):744–8. PMID: 17805340. 10.1038/sj.jp.7211823 17805340
- Chung T, Colby SM, O’Leary TA, . Screening for cannabis use disorders in an adolescent emergency department sample. Drug Alcohol Depend. 2003;70(2):177–86. 10.1016/S0376-8716(02)00346-0 12732411
- D’Amico EJ, Parast L, Meredith LS, . Screening in Primary Care: What Is the Best Way to Identify At-Risk Youth for Substance Use? Pediatrics. 2016;138(6). PMID: 27940696. 10.1542/peds.2016-1717 27940696
- Dawson DA, Compton WM, Grant BF. Frequency of 5+/4+ drinks as a screener for drug use and drug-use disorders. J Stud Alcohol Drugs. 2010;71(5):751–60. PMID: 20731982. 10.15288/jsad.2010.71.751 20731982
- Fernandez-Artamendi S, Fernandez-Hermida JR, Muniz-Fernandez J, . Screening of cannabis-related problems among youth: the CPQ-A-S and CAST questionnaires. Subst Abuse Treat Prev Policy. 2012;7:13. PMID: 22471908. 10.1186/1747-597X-7-13 22471908
- Grekin ER, Svikis DS, Lam P, . Drug use during pregnancy: validating the Drug Abuse Screening Test against physiological measures. Psychol Addict Behav. 2010;24(4):719–23. PMID: 21198230. 10.1037/a0021741 21198230
- Gryczynski J, Kelly SM, Mitchell SG, . Validation and performance of the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) among adolescent primary care patients. Addiction. 2015;110(2):240–7. PMID: 25311148. 10.1111/add.12767 25311148
- Harris SK, Knight JR, Jr., Van Hook S, . Adolescent substance use screening in primary care: Validity of computer self-administered versus clinician-administered screening. Subst Abus. 2016;37(1):197–203. PMID: 25774878. 10.1080/08897077.2015.1014615 25774878
- Harrison PA, Godecker A, Sidebottom A. Validity of the Prenatal Risk Overview for detecting drug use disorders in pregnancy. Public Health Nurs. 2012;29(6):563–73. PMID: 23078427. 10.1111/j.1525-1446.2012.01030.x 23078427
- Kelly SM, Gryczynski J, Mitchell SG, . Validity of brief screening instrument for adolescent tobacco, alcohol, and drug use. Pediatrics. 2014;133(5):819–26. PMID: 24753528. 10.1542/peds.2013-2346 24753528
  - Kelly SM, O’Grady KE, Gryczynski J, . The concurrent validity of the Problem Oriented Screening Instrument for Teenagers (POSIT) substance use/abuse subscale in adolescent patients in an urban federally qualified health center. Subst Abus. 2017:1–7. PMID: 28686545. 10.1080/08897077.2017.1351413 28080324
- Knight J, Sherritt L, Shirier L, . Validity of the CRAFFT substance abuse screening test among adolescent clinic patients. Arch Pediatr Adolesc Med. 2002;156(6):607–14. PMID: 12038895. 10.1001/archpedi.156.6.607 12038895
- Kumar PC, Cleland CM, Gourevitch MN, . Accuracy of the Audio Computer Assisted Self Interview version of the Alcohol, Smoking and Substance Involvement Screening Test (ACASI ASSIST) for identifying unhealthy substance use and substance use disorders in primary care patients. Drug Alcohol Depend. 2016;165:38–44. PMID: 27344194. 10.1016/j.drugalcdep.2016.05.030 27344194
- Lam LP, Leung WC, Ip P, . Validation of the Drug Abuse Screening Test (DAST-10): A study on illicit drug use among Chinese pregnant women. Sci. 2015;5:11420. PMID: 26091290. 10.1038/srep11420 26091290
- Lane WG, Dubowitz H, Feigelman S, . Screening for parental substance abuse in pediatric primary care. Ambul Pediatr. 2007;7(6):458–62. PMID: 17996841. 10.1016/j.ambp.2007.07.007 17996841
- Legleye S. The Cannabis Abuse Screening Test and the DSM-5 in the general population: Optimal thresholds and underlying common structure using multiple factor analysis. Int J Methods Psychiatr Res. 2018;27(2):e1597. PMID: 29124816. 10.1002/mpr.1597 29124816
- Legleye S, Guignard R, Richard JB, . Properties of the Cannabis Abuse Screening Test (CAST) in the general population. Int J Methods Psychiatr Res. 2015;24(2):170–83. PMID: 26077195. 10.1002/mpr.1465 26077195
- Legleye S, Piontek D, Kraus L. Psychometric properties of the Cannabis Abuse Screening Test (CAST) in a French sample of adolescents. Drug Alcohol Depend. 2011;113(2–3):229–35. PMID: 20869178. 10.1016/j.drugalcdep.2010.08.011 20869178
- McCann BS, Simpson TL, Ries R, . Reliability and validity of screening instruments for drug and alcohol abuse in adults seeking evaluation for attention-deficit/hyperactivity disorder. Am J Addict. 2000;9(1):1–9. PMID: 10914288. 10.1080/10550490050172173 10914288
- McNeely J, Strauss SM, Saitz R, . A Brief Patient Self-administered Substance Use Screening Tool for Primary Care: Two-site Validation Study of the Substance Use Brief Screen (SUBS). Am J Med. 2015;128(7):784.e9–19. PMID: 25770031. 10.1016/j.amjmed.2015.02.007 25770031
  - McNeely J, Cleland CM, Strauss SM, . Validation of Self-Administered Single-Item Screening Questions (SISQs) for Unhealthy Alcohol and Drug Use in Primary Care Patients. J Gen Intern Med. 2015;30(12):1757–64. PMID: 25986138 10.1007/s11606-015-3391-6 25986138
- McNeely J, Wu LT, Subramaniam G, . Performance of the Tobacco, Alcohol, Prescription Medication, and Other Substance Use (TAPS) Tool for Substance Use Screening in Primary Care Patients. Ann Intern Med. 2016. PMID: 27595276. 10.7326/m16-0317 27595276
  - Gryczynski J, McNeely J, Wu LT, . Validation of the TAPS-1: A Four-Item Screening Tool to Identify Unhealthy Substance Use in Primary Care. J Gen Intern Med. 2017. PMID: 28550609. 10.1007/s11606-017-4079-x 28550609
  - Wu LT, McNeely J, Subramaniam GA, . Design of the NIDA clinical trials network validation study of tobacco, alcohol, prescription medications, and substance use/misuse (TAPS) tool. Contemp Clin Trials. 2016;50:90–7. PMID: 27444426. 10.1016/j.cct.2016.07.013 27444426
- Mitchell SG, Kelly SM, Gryczynski J, . The CRAFFT cut-points and DSM-5 criteria for alcohol and other drugs: a reevaluation and reexamination. Subst Abus. 2014;35(4):376–80. PMID: 25036144. 10.1080/08897077.2014.936992 25036144
- Ondersma SJ, Svikis DS, LeBreton JM, . Development and preliminary validation of an indirect screener for drug use in the perinatal period. Addiction. 2012;107(12):2099–106. PMID: 22882721. 10.1111/j.1360-0443.2012.03982.x 22882721
- Rial A, Kim-Harris S, Knight JR, . Empirical validation of the CRAFFT Abuse Screening Test in a Spanish sample. Adicciones. 2018;0(0):1105. PMID: 29353300. 10.20882/adicciones.1105 29353300
  - Araujo M, Golpe S, Brana T, . Psychometric validation of the POSIT for screening alcohol and other drugs risk consumption among adolescents. Adicciones. 2018;30(2):130–9. PMID: 28492958. 10.20882/adicciones.958 28492958
- Smith P, Schmidt S, Allensworth-Davies D, . A single-question screening test for drug use in primary care. Arch Intern Med. 2010;170(13):1155–60. PMID: 20625025. 10.1001/archinternmed.2010.140 20625025
  - Saitz R, Cheng DM, Allensworth-Davies D, . The ability of single screening questions for unhealthy alcohol and other drug use to identify substance dependence in primary care. J Stud Alcohol Drugs. 2014;75(1):153–7. PMID: 24411807. 10.15288/jsad.2014.75.153 24411807
  - Smith PC, Cheng DM, Allensworth-Davies D, . Use of a single alcohol screening question to identify other drug use. Drug Alcohol Depend. 2014;139:178–80. PMID: 24768061. 10.1016/j.drugalcdep.2014.03.027 24768061
- Tiet Q, Leyva Y, Moos R, . Screen of Drug Use: Diagnostic Accuracy of a New Brief Tool for Primary Care. JAMA Intern Med. 2015;175(8):1371–7. PMID: 26075352. 10.1001/jamainternmed.2015.2438 26075352
  - Tiet QQ, Leyva Y, Moos RH, . Diagnostic accuracy of a two-item screen for drug use developed from the alcohol, smoking and substance involvement screening test (ASSIST). Drug Alcohol Depend. 2016;164:22–7. PMID: 27234660. 10.1016/j.drugalcdep.2016.03.029 27234660
  - Tiet QQ, Leyva YE, Moos RH, . Diagnostic accuracy of a two-item Drug Abuse Screening Test (DAST-2). Addict Behav. 2017;74:112–7. PMID: 28609724. 10.1016/j.addbeh.2017.06.008 28609724

## KQ4 and KQ5

- Bernstein J, Bernstein E, Tassiopoulos K, . Brief motivational intervention at a clinic visit reduces cocaine and heroin use. Drug Alcohol Depend. 2005;77(1):49–59. PMID: 15607841. 10.1016/j.drugalcdep.2004.07.006 15607841
- Bernstein E, Edwards E, Dorfman D, . Screening and brief intervention to reduce marijuana use among youth and young adults in a pediatric emergency department. Acad Emerg Med. 2009;16(11):1174–85. PMID: 20053238. 10.1111/j.1553-2712.2009.00490.x 20053238
- Blow FC, Walton MA, Bohnert ASB, . A randomized controlled trial of brief interventions to reduce drug use among adults in a low-income urban emergency department: the HealthiER You study. Addiction. 2017;112(8):1395–405. PMID: 28127808. 10.1111/add.13773 28127808
  - Bonar EE, Walton MA, Cunningham RM, . Computer-enhanced interventions for drug use and HIV risk in the emergency room: preliminary results on psychological precursors of behavior change. J Subst Abuse Treat. 2014;46(1):5–14. PMID: 24035142. 10.1016/j.jsat.2013.08.005 24035142
  - Bonar EE, Walton MA, Barry KL, . Sexual HIV risk behavior outcomes of brief interventions for drug use in an inner-city emergency department: Secondary outcomes from a randomized controlled trial. Drug Alcohol Depend. 2018;183:217–24. PMID: 29291549. 10.1016/j.drugalcdep.2017.10.036 29291549
- Bogenschutz M, Donovan D, Mandler R, . Brief intervention for patients with problematic drug use presenting in emergency departments: a randomized clinical trial. JAMA Intern Med. 2014;174(11):1736–45. PMID: 25179753. 10.1001/jamainternmed.2014.4052 25179753
  - Bogenschutz MP, Donovan DM, Adinoff B, . Design of NIDA CTN Protocol 0047: screening, motivational assessment, referral, and treatment in emergency departments (SMART-ED). American Journal of Drug & Alcohol Abuse. 2011;37(5):417–25. PMID: 21854285. 10.3109/00952990.2011.596971 21854285
- D’Amico EJ, Parast L, Shadel WG, . Brief motivational interviewing intervention to reduce alcohol and marijuana use for at-risk adolescents in primary care. J Consult Clin Psychol. 2018;86(9):775–86. PMID: 30138016. 10.1037/ccp0000332 30138016
- Gelberg L, Andersen RM, Afifi AA, . Project QUIT (Quit Using Drugs Intervention Trial): a randomized controlled trial of a primary care-based multi-component brief intervention to reduce risky drug use. Addiction. 2015;110(11):1777–90. PMID: 26471159. 10.1111/add.12993 26471159
- Gelberg L, Andersen RM, Rico MW, . A pilot replication of QUIT, a randomized controlled trial of a brief intervention for reducing risky drug use, among Latino primary care patients. Drug Alcohol Depend. 2017;179:433–40. PMID: 28844733. 10.1016/j.drugalcdep.2017.04.022 28844733
- Gryczynski J, O’Grady KE, Mitchell SG, . Immediate Versus Delayed Computerized Brief Intervention for Illicit Drug Misuse. J Addict Med. 2016;10(5):344–51. PMID: 27504925. 10.1097/adm.0000000000000248 27504925
- Humeniuk R, Ali R, Babor T, . A randomized controlled trial of a brief intervention for illicit drugs linked to the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) in clients recruited from primary health-care settings in four countries. Addiction. 2012;107(5):957–66. PMID: 22126102. 10.1111/j.1360-0443.2011.03740.x 22126102
- Lee C, Neighbors C, Kilmer J, . A brief, web-based personalized feedback selective intervention for college student marijuana use: a randomized clinical trial. Psychol Addict Behav. 2010;24(2):265–73. PMID: 20565152. 10.1037/a0018859 20565152
- Lee CM, Kilmer JR, Neighbors C, . Indicated prevention for college student marijuana use: a randomized controlled trial. J Consult Clin Psychol. 2013;81(4):702–9. PMID: 23750464. 10.1037/a0033285 23750464
- Martino S, Ondersma SJ, Forray A, . A randomized controlled trial of screening and brief interventions for substance misuse in reproductive health. Am J Obstet Gynecol. 2018;218(3):322.e1–.e12. PMID: 29247636. 10.1016/j.ajog.2017.12.005 29247636
- Mason M, Light J, Campbell L, . Peer Network Counseling with Urban Adolescents: A Randomized Controlled Trial with Moderate Substance Users. J Subst Abuse Treat. 2015;58:16–24. PMID: 26234955. 10.1016/j.jsat.2015.06.013 26234955
  - Mason MJ, Sabo R, Zaharakis NM. Peer Network Counseling as Brief Treatment for Urban Adolescent Heavy Cannabis Users. Journal of Studies on Alcohol & Drugs. 2017;78(1):152–7. PMID: 27936376.27936376
- Ondersma S, Svikis D, Thacker L, . Computer-delivered screening and brief intervention (e-SBI) for postpartum drug use: a randomized trial. J Subst Abuse Treat. 2014;46(1):52–9. PMID: 24051077. 10.1016/j.jsat.2013.07.013 24051077
- Ondersma SJ, Svikis DS, Thacker C, . Computer-delivered indirect screening and brief intervention for drug use in the perinatal period: A randomized trial. Drug Alcohol Depend. 2018;185:271–7. PMID: 29482051. 10.1016/j.drugalcdep.2017.12.022 29482051
- Ondersma SJ, Svikis DS, Schuster CR. Computer-based brief intervention a randomized trial with postpartum women.[Erratum appears in Am J Prev Med. 2007 Jun;32(6):549]. Am J Prev Med. 2007;32(3):231–8. PMID: 17236741.17236741
- Palfai T, Saitz R, Winter M, . Web-based screening and brief intervention for student marijuana use in a university health center: pilot study to examine the implementation of eCHECKUP TO GO in different contexts. Addict Behav. 2014;39(9):1346–52. PMID: 24845164. 10.1016/j.addbeh.2014.04.025 24845164
- Poblete F, Barticevic NA, Zuzulich MS, . A randomized controlled trial of a brief intervention for alcohol and drugs linked to the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) in primary health care in Chile. Addiction. 2017;112(8):1462–9. PMID: 28239995. 10.1111/add.13808 28239995
- Roy-Byrne P, Bumgardner K, Krupski A, . Brief intervention for problem drug use in safety-net primary care settings: a randomized clinical trial. JAMA. 2014;312(5):492–501. PMID: 25096689. 10.1001/jama.2014.7860 25096689
  - Krupski A, Joesch J, Dunn C, . Testing the effects of brief intervention in primary care for problem drug use in a randomized controlled trial: rationale, design, and methods. Addict Sci Clin Pract. 2012(7):27. PMID: 23237456. 10.1186/1940-0640-7-27 23237456
- Saitz R, Palfai T, Cheng D, . Screening and brief intervention for drug use in primary care: the ASPIRE randomized clinical trial. JAMA. 2014;312(5):502–13. PMID: 25096690. 10.1001/jama.2014.7862 25096690
  - Fuster D, Cheng DM, Wang N, . Brief intervention for daily marijuana users identified by screening in primary care: A subgroup analysis of the ASPIRE randomized clinical trial. Subst Abus. 2016;37(2):336–42. PMID: 26453188. 10.1080/08897077.2015.1075932 26453188
  - Kim TW, Bernstein J, Cheng DM, . Receipt of addiction treatment as a consequence of a brief intervention for drug use in primary care: a randomized trial. Addiction. 2017;112(5):818–27. PMID: 27886657. 10.1111/add.13701 27886657
- Stein M, Hagerty C, Herman D, . A brief marijuana intervention for non-treatment-seeking young adult women. J Subst Abuse Treat. 2011;40(2):189–98. PMID: 21185685. 10.1016/j.jsat.2010.11.001 21185685
- Tzilos Wernette G, Plegue M, Kahler CW, . A Pilot Randomized Controlled Trial of a Computer-Delivered Brief Intervention for Substance Use and Risky Sex During Pregnancy. J Womens Health (Larchmt). 2017. PMID: 28981379. 10.1089/jwh.2017.6408 28981379
- Walton MA, Bohnert K, Resko S, . Computer and therapist based brief interventions among cannabis-using adolescents presenting to primary care: one year outcomes. Drug Alcohol Depend. 2013;132(3):646–53. PMID: 23711998. 10.1016/j.drugalcdep.2013.04.020 23711998
- Watkins KE, Ober AJ, Lamp K, . Collaborative Care for Opioid and Alcohol Use Disorders in Primary Care: The SUMMIT Randomized Clinical Trial. JAMA Internal Medicine. 2017;177(10):1480–8. PMID: 28846769. 10.1001/jamainternmed.2017.3947 28846769
- Woolard R, Baird J, Longabaugh R, . Project reduce: reducing alcohol and marijuana misuse: effects of a brief intervention in the emergency department. Addict Behav. 2013;38(3):1732–9. PMID: 23261491. 10.1016/j.addbeh.2012.09.006 23261491
- Yonkers K, Forray A, Howell H, . Motivational enhancement therapy coupled with cognitive behavioral therapy versus brief advice: a randomized trial for treatment of hazardous substance use in pregnancy and after delivery. Gen Hosp Psychiatry. 2012;34(5):439–49. PMID: 22795046. 10.1016/j.genhosppsych.2012.06.002 22795046
- Zahradnik A, Otto C, Crackau B, . Randomized controlled trial of a brief intervention for problematic prescription drug use in non-treatment-seeking patients. Addiction. 2009;401(1):109–17. PMID: 19133895. 10.1111/j.1360-0443.2008.02421.x 19133895
  - Otto C, Crackau B, Lohrmann I, . Brief intervention in general hospital for problematic prescription drug use: 12-month outcome. Drug Alcohol Depend. 2009;105(3):221–6. PMID: 19726140. 10.1016/j.drugalcdep.2009.07.010 19726140