# Appendix D Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 34,037 citations identified through literature databases. An additional 32 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, and 74 citations were from previous related USPSTF reviews focusing on drug use (Lanier, 2008; Patnode, 2014; and Polen, 2008). After duplicates were removed, 17,921 unique citations were screened at the title/abstract stage. The full-text of 273 citations were examined for inclusion for one or more of the Key Questions. No studies were identified for Key Question 1, 28 studies reported in 37 publications were included for Key Question 2, no studies were identified for Key Question 3, 27 studies reported in 37 publications were included for Key Question 4, and 4 studies reported in 4 publications were included for Key Question 5. Reasons for excluding the other articles are available in Appendix F.