# Appendix C Literature Search Strategies

Key:

- / = subject heading
- $ = truncation
- *=truncation
- ab = word in abstract
- adj# = adjacent within x number of words
- hw = subject heading word
- id = key phrase identifier
- kw = keyword
- md = methodology
- pt = publication type
- ti = word in title

## Cochrane Central Register of Controlled Trials (CENTRAL)

#1 (drug or drugs or substance* or opioid* or opiate* or amphetamine* or amfetamine* or benzodiazepine* or morphine* or methadone* or prescription* or phencyclidine* or solvent* or inhalant* or barbiturate* or depressant* or sedative* or stimulant* or psychotherapeutic or psycho-therapeutic or ritalin or adderall or methylphenidate or oxycodone or hydrocodone or pain relief or pain reliever* or pain medication*):ti,ab,kw near/3 (addict* or abuse* or abusing or abusive or misuse* or mis-use* or misusing or mis-using or non medical or extramedical or extra medical or illicit* or illegal* or unlawful* or unsanction* or habit* or dependen* or disorder or disorders or consumption or diversion*):ti,ab,kw
#2 (“drug use” or “substance use”):ti
#3 marijuana:ti,ab,kw
#4 Cannabinoid*:ti,ab,kw
#5 cocaine:ti,ab,kw
#6 methamphetamine:ti,ab,kw
#7 (mdma or ecstasy):ti,ab,kw
#8 (hallucinogen$ or lsd):ti,ab,kw
#9 [or #1-#8]
#10 screen*:ti,ab,kw
#11 assessment:ti,ab,kw next (tool* or instrument*):ti,ab,kw
#12 ((drug or substance) next (use or misuse or mis-use or abuse)):ti,ab,kw near/5 (scale* or inventor* or questionnaire* or survey* or index* or checklist* or interview*):ti,ab,kw
#13 “Addiction Severity Index”:ti,ab,kw
#14 “Antenatal Psychosocial Health Assessment”:ti,ab,kw
#15 “NIDA-Modified ASSIST”:ti,ab,kw
#16 “Cut down Annoyed Guilty Eye-opener”:ti,ab,kw
#17 “Chemical Use Abuse and Dependence Scale”:ti,ab,kw
#18 “Drug Abuse Problem Assessment for Primary Care”:ti,ab,kw
#19 DUDIT:ti,ab,kw
#20 “Relax Alone Forget Friends Trouble”:ti,ab,kw
#21 “Reduce Annoyed Guilty Start”:ti,ab,kw
#22 SMAST-AID:ti,ab,kw
#23 “4Ps Plus”:ti,ab,kw
#24 “Substance Use Risk Profile-Pregnancy”:ti,ab,kw
#25 [#10-‘#24]
#26 #9 and #25
#27 (advice or advise*):ti,ab,kw
#28 counsel*:ti,ab,kw
#29 behavio*:ti,ab,kw and chang*:ti,ab,kw
#30 behavio*:ti,ab,kw and intervention*:ti,ab,kw
#31 behavio*:ti,ab,kw and modification*:ti,ab,kw
#32 (motivational next interview*):ti,ab,kw
#33 (cognitive next behavio*):ti,ab,kw or cbt:ti,ab,kw
#34 behavio*:ti,ab,kw and therapy:ti,ab,kw
#35 (brief next intervention*):ti,ab,kw
#36 “self help”:ti,ab,kw
#37 computer:ti,ab,kw next (based or mediated or assisted):ti,ab,kw
#38 email*:ti,ab,kw or internet:ti,ab,kw or (text next messag*):ti,ab,kw or web:ti,ab,kw or website:ti,ab,kw
#39 “patient education”:ti,ab,kw or “health education”:ti,ab,kw or “health promotion”:ti,ab,kw
#40 “12 step”:ti,ab,kw or “twelve step”:ti,ab,kw or “narcotics anonymous”:ti,ab,kw
#41 intervention*:ti or psychosocial:ti
#42 [or #27-#41]
#43 #9 and #42
#44 #26 or #43 Publication Year from 2006 to 2016, in Trials

## Ovid Medline, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

1. substance-related disorders/
2. amphetamine-related disorders/
3. cocaine-related disorders/
4. inhalant abuse/
5. marijuana abuse/
6. opioid-related disorders/
7. heroin dependence/
8. morphine dependence/
9. phencyclidine abuse/
10. substance abuse, intravenous/
11. street drugs/
12. hallucinogens/
13. ((drug or drugs or substance$ or opioid$ or opiate$ or amphetamine$ or amfetamine$ or benzodiazepine$ or morphine$ or methadone$ or prescription$ or phencyclidine$ or solvent$ or inhalant$ or barbiturate$ or depressant$ or sedative$ or stimulant$ or psychotherap$ or psycho-therap$ or ritalin or adderall or methylphenidate or oxycodone or hydrocodone or pain relief or pain reliever$ or pain medication$) adj3 (addict$ or abuse$ or abusing or abusive or misuse$ or mis-use$ or misusing or mis-using or non medical or extramedical or extra medical or illicit$ or illegal$ or unlawful$ or unsanction$ or habit$ or dependen$ or disorder or disorders or consumption or diversion$)).ti,ab.
14. (drug use$ or substance use$).ti.
15. marijuana.ti,ab.
16. (cannabis or cannabinoid$).ti,ab.
17. cocaine.ti,ab.
18. methamphetamine$.ti,ab.
19. (mdma or ecstasy).ti,ab.
20. (hallucinogen$ or lsd).ti,ab.
21. or/1-20
22. Mass screening/
23. screen$.ti,ab.
24. (assessment adj (tool$ or instrument$)).ti,ab.
25. ((drug use$ or drug misuse$ or drug abuse$ or substance use$ or substance misuse$ or substance abuse$) adj5 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$)).ti,ab.
26. Substance Abuse Detection/
27. or/22-26
28. Addiction Severity Index.ti,ab.
29. Antenatal Psychosocial Health Assessment.ti,ab.
30. “Alcohol Smoking and Substance Involvement Screening Test”.ti,ab.
31. NIDA Quick Screen.ti,ab.
32. NIDA-Modified ASSIST.ti,ab.
33. Cut down Annoyed Guilty Eye-opener.ti,ab.
34. “Chemical Use Abuse and Dependence Scale”.ti,ab.
35. Drug Abuse Problem Assessment for Primary Care.ti,ab.
36. “Drug and Alcohol Problem Screen”.ti,ab.
37. DUDIT.ti,ab.
38. drug abuse screening test$.ti,ab.
39. Relax Alone Forget Friends Trouble.ti,ab.
40. Reduce Annoyed Guilty Start.ti,ab.
41. Rapid Drug Problems Screen$.ti,ab.
42. Substance Abuse Subtle Screening Inventory.ti,ab.
43. (“Short Michigan Alcoholism Screening Test” and drugs).ti,ab.
44. SMAST-AID.ti,ab.
45. Simple Screening Instrument for Substance Abuse.ti,ab.
46. Single-Question screening test$.ti,ab.
47. Texas Christian University Drug Screen.ti,ab.
48. 4Ps Plus.ti,ab.
49. “Substance Use Risk Profile-Pregnancy”.ti,ab.
50. Cannabis Abuse Screening Test.ti,ab.
51. Substance Abuse Detection/is
52. or/28-51
53. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
54. (clinical trial or controlled clinical trial or randomized controlled trial).pt.
55. Random$.ti,ab.
56. control groups/ or double-blind method/ or single-blind method/
57. clinical trial$.ti,ab.
58. controlled trial$.ti,ab.
59. or/53-58
60. 21 and (27 or 52) and 59
61. “Sensitivity and Specificity”/
62. “Predictive Value of Tests”/
63. ROC Curve/
64. False Negative Reactions/
65. False Positive Reactions/
66. Diagnostic Errors/
67. “Reproducibility of Results”/
68. Reference Values/
69. Reference Standards/
70. Observer Variation/
71. Receiver operat$.ti,ab.
72. ROC curve$.ti,ab.
73. sensitivit$.ti,ab.
74. specificit$.ti,ab.
75. predictive value.ti,ab.
76. accuracy.ti,ab.
77. false positive$.ti,ab.
78. false negative$.ti,ab.
79. miss rate$.ti,ab.
80. error rate$.ti,ab.
81. or/61-80
82. (21 and 27) or 52
83. 81 and 82
84. 60 or 83
85. limit 84 to (english language and yr=“2006 -Current”)
86. remove duplicates from 85
87. Behavior Therapy/
88. Cognitive Therapy/
89. Counseling/
90. Directive Counseling/
91. Patient Education as Topic/
92. Risk Reduction Behavior/
93. Feedback, psychological/
94. Health education/
95. Health promotion/
96. Motivation/
97. Internet/
98. Motivational interviewing/
99. Persuasive communication/
100. Self-help groups/
101. Text messaging/
102. Therapy, computer-assisted/
103. (advice or advise$).ti,ab.
104. counsel$.ti,ab.
105. behavio?r$ chang$.ti,ab.
106. behavio?r$ intervention$.ti,ab.
107. behavio?r$ modification$.ti,ab.
108. motivational interview$.ti,ab.
109. (cognitive behavio$ or behavio$ therapy or cbt).ti,ab.
110. brief intervention$.ti,ab.
111. self help.ti,ab.
112. text messag$.ti,ab.
113. (web or website).ti,ab.
114. (computer adj (based or mediated or assisted)).ti,ab.
115. 12 step.ti,ab.
116. twelve step.ti,ab.
117. Narcotics anonymous.ti,ab.
118. (intervention$ or psychosocial).ti.
119. or/87-118
120. 21 and 119
121. *Substance-Related Disorders/dt, pc, rh, th [Drug Therapy, Prevention & Control, Rehabilitation, Therapy]
122. *Amphetamine-Related Disorders/dt, pc, rh, th
123. *Cocaine-Related Disorders/dt, pc, rh, th
124. *Inhalant Abuse/dt, pc, rh, th
125. *Marijuana Abuse/dt, pc, rh, th
126. *Opioid-Related Disorders/dt, pc, rh, th
127. *Heroin Dependence/dt, pc, rh, th
128. *Phencyclidine Abuse/dt, pc, rh, th
129. *Substance Abuse, Intravenous/dt, pc, rh, th
130. 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129
131. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
132. (clinical trial or controlled clinical trial or randomized controlled trial).pt.
133. Random$.ti,ab.
134. control groups/ or double-blind method/ or single-blind method/
135. clinical trial$.ti,ab.
136. controlled trial$.ti,ab.
137. 131 or 132 or 133 or 134 or 135 or 136
138. 130 and 137
139. limit 138 to (english language and yr=“2006 -Current”)
140. remove duplicates from 139
141. 86 or 140
142. Animals/ not (Humans/ and Animals/)
143. 141 not 142

## PsycInfo

1. Drug Abuse/
2. Drug Usage/
3. Drug Dependency/
4. Drug Addiction/
5. Inhalant Abuse/
6. Glue Sniffing/
7. Polydrug Abuse/
8. Drug Abstinence/
9. Intravenous Drug Usage/
10. Marijuana Usage/
11. Cocaine/
12. Opiates/
13. Hallucinogenic Drugs/
14. Phencyclidine/
15. Methamphetamine/
16. Methylenedioxymethamphetamine/
17. Lysergic Acid Diethylamide/
18. ((drug or drugs or substance$ or opioid$ or opiate$ or amphetamine$ or amfetamine$ or benzodiazepine$ or morphine$ or methadone$ or prescription$ or phencyclidine$ or solvent$ or inhalant$ or barbiturate$ or depressant$ or sedative$ or stimulant$ or psychotherap$ or psycho-therap$ or ritalin or adderall or methylphenidate or oxycodone or hydrocodone or pain relief or pain reliever$ or pain medication$) adj3 (addict$ or abuse$ or abusing or abusive or misuse$ or mis-use$ or misusing or mis-using or non medical or extramedical or extra medical or illicit$ or illegal$ or unlawful$ or unsanction$ or habit$ or dependen$ or disorder or disorders or consumption or diversion$)).ti,ab,id.
19. (drug use$ or substance use$).ti.
20. marijuana.ti,ab,id.
21. (cannabis or cannabinoid$).ti,ab,id.
22. cocaine.ti,ab,id.
23. methamphetamine$.ti,ab,id.
24. (mdma or ecstasy).ti,ab,id.
25. (hallucinogen$ or lsd).ti,ab,id.
26. or/1-25
27. Screening/
28. Health Screening/
29. Screening Tests/
30. Intake Interview/
31. Symptom Checklists/
32. Interviews/
33. Questionnaires/
34. Rating Scales/
35. Self Report/
36. General Health Questionnaire/
37. Computer Assisted Diagnosis/
38. screen$.ti,ab,id.
39. (assessment adj (tool$ or instrument$)).ti,ab,id.
40. ((drug use$ or drug misuse$ or substance use$ or substance misuse$) adj5 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$)).ti,ab,id.
41. self report$.ti,ab,id.
42. identif$.ti.
43. or/27-42
44. Addiction Severity Index.ti,ab,tm.
45. Antenatal Psychosocial Health Assessment.ti,ab,tm.
46. “Alcohol Smoking and Substance Involvement Screening Test”.ti,ab,tm.
47. NIDA Quick Screen.ti,ab,tm.
48. NIDA-Modified ASSIST.ti,ab,tm.
49. Cut down Annoyed Guilty Eye-opener.ti,ab,tm.
50. “Chemical Use Abuse and Dependence Scale”.ti,ab,tm.
51. Drug Abuse Problem Assessment for Primary Care.ti,ab,tm.
52. “Drug and Alcohol Problem Screen”.ti,ab,tm.
53. DUDIT.ti,ab,tm.
54. drug abuse screening test$.ti,ab,tm.
55. Relax Alone Forget Friends Trouble.ti,ab,tm.
56. Reduce Annoyed Guilty Start.ti,ab,tm.
57. Rapid Drug Problems Screen$.ti,ab,tm.
58. Substance Abuse Subtle Screening Inventory.ti,ab,tm.
59. (“Short Michigan Alcoholism Screening Test” and drugs).ti,ab,tm.
60. SMAST-AID.ti,ab,tm.
61. Simple Screening Instrument for Substance Abuse.ti,ab,tm.
62. Single-Question screening test$.ti,ab,tm.
63. Texas Christian University Drug Screen.ti,ab,tm.
64. 4Ps Plus.ti,ab,tm.
65. “Substance Use Risk Profile-Pregnancy”.ti,ab,tm.
66. Cannabis Abuse Screening Test.ti,ab,tm.
67. or/44-66
68. random$.ti,ab,id,hw.
69. placebo$.ti,ab,id,hw.
70. controlled trial$.ti,ab,id,hw.
71. clinical trial$.ti,ab,id,hw.
72. Clinical Trial.md.
73. Experiment Controls/
74. or/68-73
75. 26 and (43 or 67) and 74
76. Test Validity/
77. Test Reliability/
78. Interrater Reliability/
79. validity.ti,ab,id.
80. reliability.ti,ab,id.
81. Receiver operat$.ti,ab,id.
82. ROC curve$.ti,ab,id.
83. sensitivit$.ti,ab,id.
84. specificit$.ti,ab,id.
85. predictive value.ti,ab,id.
86. accuracy.ti,ab,id.
87. false positive$.ti,ab,id.
88. false negative$.ti,ab,id.
89. miss rate$.ti,ab,id.
90. error rate$.ti,ab,id.
91. or/76-90
92. (26 and 43) or 67
93. 91 and 92
94. 75 or 93
95. limit 94 to (english language and yr=“2006 -Current”)
96. Health Promotion/
97. Motivation/
98. Behavior Modification/
99. Behavior Change/
100. behavio?r$ chang$.ti,ab,id.
101. behavio?r$ intervention$.ti,ab,id.
102. behavio?r$ modification$.ti,ab,id.
103. behavior therapy/
104. cognitive behavior therapy/
105. cognitive therapy/
106. Cognitive Techniques/
107. (cognitive behavio$ or behavio$ therapy or cbt).ti,ab,id.
108. brief intervention$.ti,ab,id.
109. Persuasive Communication/
110. Motivational Interviewing/
111. motivational interview$.ti,ab,id.
112. Health Knowledge/
113. Health Behavior/
114. Health Education/
115. Client Education/
116. Feedback/
117. Online Therapy/
118. Computer Assisted Therapy/
119. Computer Mediated Communication/
120. Computer Assisted Testing/
121. Internet/
122. (computer adj (based or mediated or assisted)).ti,ab,id.
123. text messag$.ti,ab,id.
124. email$.ti,ab,id.
125. internet.ti,ab,id.
126. (web or website).ti,ab,id.
127. Self Help Techniques/
128. self help.ti,ab,id.
129. counseling/
130. Group Counseling/
131. counseling.ti,ab,id.
132. counselling.ti,ab,id.
133. advice.ti,ab,id.
134. advise$.ti,ab,id.
135. (intervention$ or psychosocial).ti.
136. or/96-135
137. 26 and 136
138. 68 or 69 or 70 or 71 or 72 or 73
139. 137 and 138
140. limit 139 to (english language and yr=“2006 -Current”)
141. 95 or 140

## PubMed, publisher-supplied records

#27 Search #26 AND publisher[sb] AND (“2006/01/01”[Date - Publication] : “3000”[Date - Publication]) AND English[Language]
#26 Search (#11 OR #24) AND #25
#25 Search random*[tiab] OR clinical trial*[tiab] OR controlled trial*[tiab]
#24 Search #6 AND #23
#23 Search #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22
#22 Search intervention*[ti] OR psychosocial[ti]
#21 Search “12 step”[tiab] OR “twelve step”[tiab] OR “narcotics anonymous”[tiab]
#20 Search “patient education”[tiab] OR “health education”[tiab] OR “health promotion”[tiab]
#19 Search email*[tiab] OR internet[tiab] OR text messag*[tiab] OR web[tiab] OR website[tiab]
#18 Search cbt[tiab] OR brief intervention*[tiab] OR computer based[tiab] OR computer mediated[tiab] OR computer assisted[tiab] OR self help[tiab]
#17 Search behavio*[tiab] AND therapy[tiab]
#16 Search motivational interview*[tiab] OR cognitive behavio*[tiab]
#15 Search behavio*[tiab] AND modification*[tiab]
#14 Search behavio*[tiab] AND intervention*[tiab]
#13 Search behavio*[tiab] AND chang*[tiab]
#12 Search counsel*[tiab] OR advice[tiab] OR advise*[tiab]
#11 Search #6 AND #10
#10 Search #7 OR #8 OR #9
#9 Search (drug use*[tiab] OR drug misuse*[tiab] OR drug abuse*[tiab] OR substance use*[tiab] OR substance misuse*[tiab] OR substance abuse*[tiab]) AND (scale*[tiab] OR inventor*[tiab] OR questionnaire*[tiab] OR survey*[tiab] OR index*[tiab] OR checklist*[tiab] OR interview*[tiab])
#8 Search (assessment tool*[tiab] OR assessment instrument*[tiab])
#7 Search screen*[tiab]
#6 Search #3 OR #4 OR #5
#5 Search marijuana[tiab] OR cannabis[tiab] OR cannabinoid*[tiab] OR cocaine[tiab] OR methamphetamine[tiab] OR mdma[tiab] OR ecstasy[tiab] OR hallucinogen*[tiab] OR lsd[tiab]
#4 Search drug use*[tiab] OR substance use*[tiab]
#3 Search #1 AND #2
#2 Search addict*[tiab] OR abuse*[tiab] OR abusing[tiab] OR misus*[tiab] OR mis us*[tiab] nonmedical[tiab] OR “non medical”[tiab] OR extramedical[tiab] OR “extra medical”[tiab] OR illicit*[tiab] OR illegal*[tiab] OR unlawful*[tiab] OR unsanction*[tiab]
#1 Search drug[tiab] OR drugs[tiab] OR substance*[tiab] OR opioid*[tiab] OR opiate*[tiab] OR amphetamine*[tiab] OR amfetamine*[tiab] OR benzodiazepine*[tiab] OR morphine*[tiab] OR methadone*[tiab] OR prescription*[tiab] OR phencyclidine*[tiab] OR solvent*[tiab] OR inhalant*[tiab] OR barbiturate*[tiab] OR depressant*[tiab] OR sedative*[tiab] OR stimulant*[tiab] OR psychotherapeutic*[tiab] OR Ritalin[tiab] OR Adderall[tiab] OR methylphenidate[tiab] OR oxycodone[tiab] OR hydrocodone[tiab] OR pain relief[tiab] OR pain reliever*[tiab] OR pain medication*[tiab]

Appendix C Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Aim | Screening for illicit drug use and/or nonmedical pharmaceutical drug use and interventions for nondependent drug use, with or without addressing other substances or behaviors | Studies in which the only aim is targeting another behavior (e.g., unhealthy alcohol use, tobacco use) (i.e., change in drug use is not a stated aim but is a reported outcome)
Condition | Use of the following drugs, defined as any drug use that can result in poor health consequences, including meeting criteria for a drug use disorder:; - Cannabinoids (marijuana, hashish, synthetic cannabinoids); - Club drugs (3,4-methylenedioxymethamphetamine [MDMA or ecstasy], flunitrazepam [Rohypnol], gamma-hydroxybutyrate [GHB], synthetic cathinones [bath salts]); - Dissociative drugs (ketamine, phencyclidine [PCP] and analogs, Salvia divinorum [salvia], dextromethorphan [DXM]); - Hallucinogens (lysergic acid diethylamide [LSD or acid], N,N-dimethyltryptamine [DMT], mescaline, psilocybin); - Inhalants (also known as volatile substances); - Illicit opioids (heroin, opium, Mitragyna speciosa [kratom], illicitly manufactured fentanyl [IMF]); - Stimulants (cocaine, amphetamine, Catha edulis [khat], methamphetamine); - Prescription opioid pain relievers; - Prescription sedatives (barbiturates, benzodiazepines, sleep medications); - Prescription stimulants; - Over-the-counter drugs (e.g., DXM); - Combination of any of the above | - Medical use of drugs as prescribed; - Nonpsychoactive drugs (e.g., anabolic steroids, laxatives, aspirin)
Population | All KQs: Adolescents and adults age 12 years and older; KQs 1–3: Studies whose participants are not selected on the basis of drug use or a related behavior or condition; KQs 4, 5: Studies in which at least 50% of the enrolled sample is recruited via population-based screening; A priori subpopulations at greater risk for drug use or its consequences will be examined based on the following factors: age (particularly young adults ages 18 to 25 years and adolescents ages 12 to 17 years), sex, race/ethnicity, socioeconomic status, pregnancy status, concurrent substance use (tobacco or alcohol), severity of the disorder, and presence of comorbid mental health conditions | Studies limited to:; - Treatment-seeking individuals (including those responding to recruitment advertising); - Persons with psychotic disorders (e.g., schizophrenia); - Persons presenting in an emergency setting for drug-related issues (e.g., motor vehicle injury); - Persons receiving chronic opioid therapy; - Other groups not generalizable to primary care (e.g., psychiatric inpatients, persons who are court-mandated to receive treatment, persons who are incarcerated); - KQs 4, 5: Persons with dependent drug use (or studies in which >50% of the enrolled sample is persons with dependent drug use)
Screening | KQs 1, 3: Screening for drug use using a briefstandardized instrument or set of questions that is conducted in person or via telephone, mail, or electronically; KQ 2: Accuracy of screening instruments, such as the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST); Cut down, Annoyed, Guilty, Eye-opener–Adapted to Include Drug Use (CAGE-AID); Car, Relax, Alone, Forget, Friends, Trouble (CRAFFT); Drug Abuse Screening Test (DAST), including the DAST-10; Global Appraisal of Individual Needs-Short Screener (GAIN-SS); 4P’s Plus (Past use, Pregnancy, use by Parents and Partners); National Institute on Drug Abuse Quick Screen; and single screening questions (SSQs) | - Studies without any screening instruments or questions; - Laboratory tests; - Newborn screening tests for drug exposure (e.g., testing of meconium, infant hair, or umbilical cord specimens)
Interventions | - Counseling designed to reduce drug use, with or without referral; - Counseling interventions can vary in their approach (e.g., 12-step, cognitive behavioral therapy, motivational enhancement therapy), specific strategies (e.g., action plans, diaries), delivery method (e.g., face-to-face, electronic, individual, group-based), length of contact (e.g., brief, extended), and the number of contacts (e.g., single, multiple) | - Interventions to prevent drug use initiation; - Contingency management; - Vocational rehabilitation; - Community-based media or policy interventions; - Interventions to prevent initiation of use among nonusers; - Pharmacotherapy
Comparisons | KQs 1, 3:; - No screening; - Usual care; KQ 2: Reference standard (i.e., structured or semistructured clinical interview); KQs 4, 5:; - No intervention; - Usual care; - Waitlist; - Attention control (e.g., intervention is similar in format and intensity but on a different content area); - Minimal intervention (e.g., no more than one single brief contact per year, brief written materials such as pamphlets) | Active intervention
Settings | KQs 1–3: Population-based screening that takes place in a setting that is applicable to primary care, including: primary care clinics; prenatal clinics; obstetrics/gynecology clinics; emergency departments; specialty medical treatment settings (e.g., diabetes management); school health clinics; and research clinic/office, home, or other community settings, including electronic or computer-based screening; KQs 4, 5: Interventions in a screen-detected population that take place in a traditional primary care setting or one that is applicable to or referable from primary care, including: primary care clinics; prenatal clinics; obstetrics/gynecology clinics; behavioral/mental health clinics; emergency departments; substance abuse treatment centers; school health clinics; and research clinic/office, home, or other community settings, including electronic or computer-based interventions. Screening to identify eligible participants must take place in broad-based, general setting comparable to primary care with a defined population (e.g., primary care clinic, WIC program, orientation for incoming college freshman). | Screening that takes place in:; - Behavioral/mental health clinic; - Substance abuse treatment center; - Worksites, including occupational screening; - Inpatient/residential facility; - Other institutions (e.g., correctional facility)
Outcomes | KQs 1a, 4a:; - Drug use (required)(self-report and/or biologic measures):; ○ Abstinence (use/no use); ○ Frequency and/or quantity of drug use; ○ Severity of drug use disorder (reported as an index measured by a standardized questionnaire, such as the Short Inventory of Problems, Addiction Severity Index, or Severity of Dependence Scale); - Composite substance use; - Other risky behaviors (e.g., alcohol, tobacco, or other drug use; risky sexual behaviors); KQs 1b, 4b:; - All-cause mortality; - Drug-related mortality (intentional and unintentional); - Drug-related morbidity (e.g., mental health symptoms/disorders, STI/HIV transmission, hepatitis B or C virus transmission, respiratory infection, cardiovascular complications, stroke, seizure, nonfatal overdose, injuries and accidents, cognitive impairment, visit to emergency department, hospital inpatient stay); - Obstetrical/perinatal/neonatal outcomes (e.g., perinatal mortality, preterm labor/delivery, low birth weight, placental abruption, intrauterine growth restriction, preeclampsia, antepartum or postpartum hemorrhage, gestational hypertension, decreased neonate length/head circumference, neonate neurobehavioral effects, congenital anomalies, neonatal abstinence syndrome, neonatal intensive care unit admission, decreased length of neonate hospitalization); - Quality of life; - Drug-related problems, such as legal problems, social and family relations, employment, and school/educational outcomes; KQ 2: Sensitivity and specificity or data to calculate one or both; KQs 3, 5:; - Serious harms at any time point after the screening or intervention began (e.g., death, seizure, cardiovascular event, other medical issue requiring urgent medical treatment, serious obstetrical/perinatal/neonatal complication attributable to included medications); - Demoralization due to failed quit attempt; - Stigma, labeling, and/or discrimination; - Privacy issues (e.g., insurability status); - Job loss; - Interference with the doctor-patient relationship | - Attitudes, knowledge, and beliefs related to drug use; - Intention to change behavior; - Intervention participation/compliance
Outcome assessment timing | At least 3 months after baseline measurement (except for studies in pregnant women, for which shorter lengths of followup will be included)
Study design | KQs 1, 3: Studies that compare individuals who receive screening with those receiving no screening or usual care, including randomized controlled trials and nonrandomized controlled trials; KQ 2: Studies of screening accuracy reporting sensitivity and specificity compared with a structured or semistructured clinical interview; KQ 4, 5: Randomized, controlled trials and nonrandomized controlled trials | Prospective and retrospective cohort studies, case control studies, time series studies, before-after studies with no comparison group, cross-sectional studies, case studies, case series, editorials/commentaries
Country | Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries that are not categorized as “Very High” on the 2014 Human Development Index
Publication date | Studies whose primary results were published from 1992 to present | Studies whose primary results were published prior to 1992
Language | English | Non-English
Quality | Fair or good quality | Poor quality (according to design-specific USPSTF criteria)

Appendix C Table 2 Study Design-Specific Quality Rating Criteria^*^

Study Design | Adapted Quality Criteria
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) I^144^ and II^145^ instrument | Patient Selection; - Was a consecutive or random sample of patients enrolled?; - Did the study avoid inappropriate exclusions?; Index Test; - Were the index test results interpreted without knowledge of the reference standard results?; - If a threshold was used, was it prespecified or was a range of values presented?; Reference Standard; - Is the reference standard likely to correctly classify the target condition?; - Were the reference standard results interpreted without knowledge of the index test?; - Were staff trained in the use of the reference standard?; - Was fidelity of the reference standard monitored or reported?; Flow and Timing; - Was there an appropriate interval between the index test and reference standard?; - Did all patients receive a reference standard?; - Did all patients receive the same reference standard?; ○ Were all patients included in the analysis?
RCT^37^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* All studies were classified as good, fair, or poor according to the USPSTF Procedure Manual.^37^

Abbreviation: RCT = randomized controlled trial.