# Appendix B Commonly Abused Illicit, Prescription, and Over-the-Counter Drugs

Substance category | Substance name | Street name(s) | Commercial name(s) | Common form(s) | Common ways taken | DEA schedule^*^ | Possible health effects
Cannabinoids | Marijuana^†^ (Cannabis) | Blunt, Bud, Dope, Ganja, Grass, Green, Herb, Joint, Mary Jane, Pot, Reefer, Sinsemilla, Skunk, Smoke, Trees, Weed; Hashish: Boom, Gangster, Hash, Hemp | Various brand names in states where the sale of marijuana is legal^‡^ | Greenish-gray mixture of dried, shredded leaves, stems, seeds, and/or flowers; resin (hashish) or sticky, black liquid (hash oil) | Smoked, eaten (mixed in food or brewed as tea) | I | Short-term: Enhanced sensory perception and euphoria followed by drowsiness/relaxation; slowed reaction time; problems with balance and coordination; increased heart rate and appetite; problems with learning and memory; hallucinations; anxiety; panic attacks; psychosis.; Long-term: Mental health problems, chronic cough, frequent respiratory infections.; Youth: possible loss of IQ points when repeated use begins in adolescence.; Pregnancy: babies born with problems with attention, memory, and problem solving.
Club drugs | MDMA (3,4-methylenedioxy-methamphetamine) | Ecstasy, Molly, Adam, clarity, Eve, lover’s speed, peace, uppers | No commercial uses | Colorful tablets with imprinted logos, capsules, powder, liquid | Swallowed, snorted | I | Short-term: Lowered inhibition; enhanced sensory perception; confusion; depression; sleep problems; anxiety; increased heart rate and blood pressure; muscle tension; teeth clenching; nausea; blurred vision; faintness; chills or sweating; sharp rise in body temperature leading to liver, kidney, or heart failure and death.; Long-term: Long-lasting confusion, depression, problems with attention, memory, and sleep; increased anxiety, impulsiveness, aggression; loss of appetite; less interest in sex.; Youth: Unknown; Pregnancy: Unknown
Club drugs | Rohypnol (Flunitrazapam) | Circles, Date Rape Drug, Forget Pill, Forget-Me Pill, La Rocha, Lunch Money, Mexican Valium, Mind Eraser, Pingus, R2, Reynolds, Rib, Roach, Roach 2, Roaches, Roachies, Roapies, Rochas Dos, Roofies, Rope, Rophies, Row-Shay, Ruffies, Trip-and-Fall, Wolfies | Flunitrazepam, Rohypnol® | Tablet | Swallowed (as a pill or as dissolved in a drink), snorted | IV^§^ | Short-term: Drowsiness, sedation, sleep; amnesia, blackout; decreased anxiety; muscle relaxation, impaired reaction time and motor coordination; impaired mental functioning and judgment; confusion; aggression; excitability; slurred speech; headache; slowed breathing and heart rate.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown
Club drugs | GHB (gamma-hydroxybutyrate) | G, Georgia home boy, grievous bodily harm, liquid ecstasy, soap, scoop, good, liquid X | Gamma-hydroxybutyrate or sodium oxybate (Xyrem®) | Colorless liquid, white powder | Swallowed | I | Short-term: Euphoria, drowsiness, decreased anxiety, confusion, memory loss, hallucinations, excited and aggressive behavior, nausea, vomiting, unconsciousness, seizures, slowed heart rate and breathing, lower body temperature, coma, death.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: Sometimes used as a date-rape drug
Dissociative drugs | Ketamine | Cat Valium, K, Special K, vitamin K | Ketalar® | Liquid, white powder | Injected, snorted, or smoked (powder added to tobacco or marijuana cigarettes), swallowed | III | Short-term: Problems with attention, learning, and memory; dreamlike states, hallucinations; sedation; confusion and problems speaking; loss of memory; problems moving, to the point of being immobile; raised blood pressure; unconsciousness; slowed breathing that can lead to death.; Long-term: Ulcers and pain in the bladder; kidney problems; stomach pain; depression; poor memory.; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: Sometimes used as a date-rape drug; Risk of HIV, hepatitis, and other infectious diseases from shared needles
Dissociative drugs | PCP (phencyclidine) | Angel dust, boat, hog, love boat, peace pill | No commercial uses | White or colored powder, tablet, or capsule; clear liquid | Injected, snorted, swallowed, smoked (powder added to mint, parsley, oregano, or marijuana) | I/II | Short-term: Delusions, hallucinations, paranoia, problems thinking, a sense of distance from one’s environment, anxiety.; Low doses: slight increase in breathing rate; increased blood pressure and heart rate; shallow breathing; face redness and sweating; numbness of the hands or feet; problems with movement.; High doses: lowered blood pressure, pulse rate, breathing rate; nausea; vomiting; blurred vision; flicking up and down of the eyes; drooling; loss of balance; dizziness; violence; suicidal thoughts; seizures, coma, and death.; Long-term: Memory loss, problems with speech and thinking, depression, weight loss, anxiety.; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: PCP has been linked to self-injury; Risk of HIV, hepatitis, and other infectious diseases from shared needles.
Dissociative drugs | Salvia^†^ (salvia divinorum) | Magic mint, Maria Pastora, Sally-D, Shepherdess’s Herb, Diviner’s Sage | Sold legally in most states as Salvia divinorum | Smoked, chewed, or brewed as tea | Smoked, chewed, or brewed as tea | Not scheduled^ǁ^ | Short-term: Short-lived but intense hallucinations; altered visual perception, mood, body sensations; mood swings, feelings of detachment from one’s body; sweating.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown
Hallucinogens | Ayahuasca^†^ | Aya, Yagé, Hoasca | No commercial uses | Brewed as tea | Swallowed as tea | I^¶^ | Short-term: Strong hallucinations including perceptions of otherworldly imagery, altered visual and auditory perceptions; increased blood pressure; vomiting.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown
Hallucinogens | DMT^†^ | DMT, Dimitri | No commercial uses | White or yellow crystalline powder | Smoked, injected | I | Short-term: Intense visual hallucinations, depersonalization, auditory distortions, and an altered perception of time and body image, usually resolving in 30–45 minutes or less. Physical effects include hypertension, increased heart rate, agitation, seizures, dilated pupils, involuntary rapid eye movements, dizziness, and incoordination.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: At high doses, coma and respiratory arrest have occurred.
Hallucinogens | LSD (lysergic acid diethylamide) | Acid, blotter, cubes, microdot, yellow sunshine, blue heaven | No commercial uses | Tablet; capsule; clear liquid; small, decorated squares of absorbent paper that liquid has been added to | Swallowed or absorbed through mouth tissues | I | Short-term: Rapid emotional swings; distortion of a person’s ability to recognize reality, think rationally, or communicate with others; raised blood pressure, heart rate, body temperature; dizziness and insomnia; loss of appetite; dry mouth; sweating; numbness; weakness; tremors; enlarged pupils.; Long-term: Frightening flashbacks (called Hallucinogen Persisting Perception Disorder [HPPD]); ongoing visual disturbances, disorganized thinking, paranoia, and mood swings.; Youth: Unknown; Pregnancy: Unknown
Hallucinogens | Mescaline (Peyote) | Buttons, cactus, mesc | No commercial uses | Fresh or dried buttons, capsule | Swallowed (chewed or soaked in water and drunk) | I | Short-term: Enhanced perception and feeling; hallucinations; euphoria; anxiety; increased body temperature, heart rate, blood pressure; sweating; problems with movement.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown
Hallucinogens | Psilocybin^†^ | Little Smoke, Magic Mushrooms, Purple Passion, Shrooms | No commercial uses | Fresh or dried mushrooms with long, slender stems topped by caps with dark gills | Swallowed (eaten, brewed as tea, or added to other foods) | I | Short-term: Hallucinations, altered perception of time, inability to tell fantasy from reality, panic, muscle relaxation or weakness, problems with movement, enlarged pupils, nausea, vomiting, drowsiness.; Long-term: Risk of flashbacks and memory problems.; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: Risk of poisoning if a poisonous mushroom is accidentally used.
Opioids | Heroin | Smack, horse, brown sugar, dope, H, junk, skag, skunk, white horse, China white, cheese (with OTC cold medicine and antihistamine) | No commercial uses | White or brownish powder, or black sticky substance known as “black tar heroin” | Injected, smoked, or snorted | I | Short-term: Euphoria; warm flushing of skin; dry mouth; heavy feeling in the hands and feet; clouded thinking; alternate wakeful and drowsy states; itching; nausea; vomiting; slowed breathing and heart rate.; Long-term: Collapsed veins; abscesses (swollen tissue with pus); infection of the lining and valves in the heart; constipation and stomach cramps; liver or kidney disease; pneumonia.; Youth: Unknown; Pregnancy: miscarriage, low birth weight, neonatal abstinence syndrome.; Other health-related issues: Risk of HIV, hepatitis, and other infectious diseases from shared needles.
Opioids | Kratom (Mitragyna speciosa) | Herbal Speedball, Biak-biak, Ketum, Kahuam, Ithang, Thom | None | Fresh or dried leaves, powder, liquid, gum | Chewed (whole leaves); eaten (mixed in food or brewed as tea); occasionally smoked | Not scheduled | Short-term: Sensitivity to sunburn, nausea, itching, sweating, dry mouth, constipation, increased urination, loss of appetite. Low doses: increased energy, sociability, alertness. High doses: sedation, euphoria, decreased pain.; Long-term: Anorexia, weight loss, insomnia, skin darkening, dry mouth, frequent urination, constipation. Hallucination and paranoia with long-term use at high doses.; Youth: Unknown; Pregnancy: Unknown
Other Compounds | Inhalants | Solvents (paint thinners, gasoline, glues); gases (butane, propane, aerosol propellants, nitrous oxide); nitrates (isoamyl, isobutyl, cyclohexyl): laughing gas, poppers, snappers, whippets | Various | Various forms^#^ | Inhaled through nose or mouth | Not scheduled | Short-term: Confusion; nausea; slurred speech; lack of coordination; euphoria; dizziness; drowsiness; disinhibition, lightheadedness, hallucinations/delusions; headaches; sudden sniffing death due to heart failure (from butane, propane, and other chemicals in aerosols); death from asphyxiation, suffocation, convulsions or seizures, coma, or choking.; Nitrites: enlarged blood vessels, enhanced sexual pleasure, increased heart rate, brief sensation of heat and excitement, dizziness, headache.; Long-term: Liver and kidney damage; bone marrow damage; limb spasms due to nerve damage; brain damage from lack of oxygen that can cause problems with thinking, movement, vision, and hearing.; Nitrites: increased risk of pneumonia.; Youth: Unknown; Pregnancy: low birth weight, bone problems, delayed behavioral development due to brain problems, altered metabolism and body composition.
Over-the-counter Cough/Cold medicines | Dextromethorphan or DXM | Robotripping, Robo, Triple C | Various (many brand names include “DM”) | Syrup, capsule | Swallowed | Not scheduled | Short-term: Euphoria; slurred speech; increased heart rate, blood pressure, temperature; numbness; dizziness; nausea; vomiting; confusion; paranoia; altered visual perceptions; problems with movement; buildup of excess acid in body fluids.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: Breathing problems, seizures, and increased heart rate may occur from other ingredients in cough/cold medicines.
Prescription Opioids | Codeine | Captain Cody, Cody, Lean, Schoolboy, Sizzurp, Purple Drank With glutethimide: Doors & Fours, Loads, Pancakes and Syrup | Codeine (various brand names) | Tablet, capsule, liquid | Injected, swallowed (often mixed with soda and flavorings) | II/III/V | Short-term: Pain relief, drowsiness, nausea, constipation, euphoria, confusion, slowed breathing, death.; Long-term: Unknown; Youth: Unknown; Pregnancy: Miscarriage, low birth weight, neonatal abstinence syndrome.; Older adults: higher risk of accidental misuse or abuse because many older adults have multiple prescriptions, increasing the risk of drug-drug interactions, and breakdown of drugs slows with age; also, many older adults are treated with prescription medications for pain.; Other health-related issues: Risk of HIV, hepatitis, and other infectious diseases from shared needles.
Prescription Opioids | Fentanyl | Apache, China Girl, China White, Dance Fever, Friend, Goodfella, Jackpot, Murder 8, Tango and Cash, TNT | Fentanyl (Actiq®, Duragesic®, Sublimaze®) | Lozenge, sublingual tablet, film, buccal tablet | Injected, smoked, or snorted | II
Prescription Opioids | Hydrocodone or Dihydrocodeine | Vike, Watson-387 | Hydrocodone or dihydrocodeinone (Vicodin®, Lortab®, Lorcet®, and others) | Capsule, liquid, tablet | Swallowed, snorted, injected | II
Prescription Opioids | Hydromorphone | D, Dillies, Footballs, Juice, Smack | Hydromorphone (Dilaudid®) | Liquid, suppository | Injected, rectal | II
Prescription Opioids | Meperidine | Demmies, Pain Killer | Meperidine (Demerol®) | Tablet, liquid | Swallowed, snorted, injected | II
Prescription Opioids | Methadone | Amidone, Fizzies With MDMA: chocolate chip cookies | Methadone (Dolophine®, Methadose®) | Tablet, dispersible tablet, liquid | Swallowed, injected | II
Prescription Opioids | Morphine | M, Miss Emma, monkey, white stuff | Morphine (Duramorph®, Roxanol®) | Tablet, liquid, capsule, suppository | Injected, swallowed, or smoked | II/III
Prescription Opioids | Oxycodone | O.C., Oxycet, Oxycotton, Oxy, Hillbilly Heroin, Percs | Oxycodone (OxyContin®, Percodan®, Percocet®, and others) | Capsule, liquid, tablet | Swallowed, snorted, injected | II
Prescription Opioids | Oxymorphone | Biscuits, Blue Heaven, Blues, Mrs. O, O Bomb, Octagons, Stop Signs | Oxymorphone (Opana®) | Tablet | Swallowed, snorted, injected | II
Prescription Sedatives (Tranquilizers, Depressants) | Barbiturates | Barbs, Phennies, Red Birds, Reds, Tooies, Yellow Jackets, Yellows | pentobarbital (Nembutal®), phenobarbital (Luminal®) | Pill, capsule, liquid | Swallowed, injected | II/III/IV | Short-term: Drowsiness, slurred speech, poor concentration, confusion, dizziness, problems with movement and memory, lowered blood pressure, slowed breathing.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: Sleep medications are sometimes used as date rape drugs.; Risk of HIV, hepatitis, and other infectious diseases from shared needles.
Prescription Sedatives (Tranquilizers, Depressants) | Benzodiazepines | Candy, Downers, Sleeping Pills, Tranks | alprazolam (Xanax®), chlorodiazepoxide (Limbitrol®), diazepam (Valium®), lorazepam (Ativan®), triazolam (Halicon®) | Pill, capsule, liquid | Swallowed, injected | IV
Prescription Sedatives (Tranquilizers, Depressants) | Sleep Medications | Forget-me Pill, Mexican Valium, R2, Roche, Roofies, Roofinol, Rope, Rophies | eszopiclone (Lunesta®), zaleplon (Sonata®), zolpidem (Ambien®) | Pill, capsule, liquid | Swallowed, injected | IV
Prescription Stimulants | Amphetamines | Bennies, Black Beauties, Crosses, Hearts, LA Turnaround, Speed, Truck Drivers, Uppers | Amphetamine (Adderall®, Benzedrine®) | Tablet, capsule | Swallowed, snorted, smoked, injected | II | Short-term: Increased alertness, attention, energy; increased blood pressure and heart rate; narrowed blood vessels; increased blood sugar; opened-up breathing passages.; High doses: dangerously high body temperature and irregular heartbeat; heart failure; seizures.; Long-term: Heart problems, psychosis, anger, paranoia.; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: Risk of HIV, hepatitis, and other infectious diseases from shared needles.
Prescription Stimulants | Methylphenidate | JIF, MPH, R-ball, Skippy, The Smart Drug, Vitamin R | Methylphenidate (Concerta®, Ritalin®) | Liquid, tablet, chewable tablet, capsule | Swallowed, snorted, smoked, injected, chewed | II
Steroids | Steroids (Anabolic) | Juice, Gym Candy, Pumpers, Roids | Nandrolone (Oxandrin®), oxandrolone (Anadrol®), oxymetholone (Winstrol®), stanozolol (Durabolin®), testosterone cypionate (Depo-testosterone®) | Tablet, capsule, liquid drops, gel, cream, patch, injectable solution | Injected, swallowed, applied to skin | III | Short-term: Headache, acne, fluid retention (especially in the hands and feet), oily skin, yellowing of the skin and whites of the eyes, infection at the injection site.; Long-term: Kidney damage or failure; liver damage; high blood pressure, enlarged heart, or changes in cholesterol leading to increased risk of stroke or heart attack, even in young people; aggression; extreme mood swings; anger (“roid rage”); paranoid jealousy; extreme irritability; delusions; impaired judgment.; Youth: Unknown; Adolescents: stunted growth; Pregnancy: Unknown; Males: Shrunken testicles, lowered sperm count, infertility, baldness, development of breasts, increased risk for prostate cancer.; Females: Facial hair, male-pattern baldness, menstrual cycle changes, enlargement of the clitoris, deepened voice.; Other health-related issues: Risk of HIV, hepatitis, and other infectious diseases from shared needles.
Stimulants | Cocaine | Blow, bump, C, candy, Charlie, coke, crack, flake, rock, snow, toot | Cocaine hydrochloride topical solution (anesthetic rarely used in medical procedures) | White powder, whitish rock crystal | Snorted, smoked, or injected | II | Short-term: Narrowed blood vessels; enlarged pupils; increased body temperature, heart rate, and blood pressure; headache; abdominal pain and nausea; euphoria; increased energy, alertness; insomnia, restlessness; anxiety; erratic and violent behavior, panic attacks, paranoia, psychosis; heart rhythm problems, heart attack; stroke, seizure, coma.; Long-term: Loss of sense of smell, nosebleeds, nasal damage and trouble swallowing from snorting; infection and death of bowel tissue from decreased blood flow; poor nutrition and weight loss from decreased appetite.; Youth: Unknown; Pregnancy: Premature delivery, low birth weight, neonatal abstinence syndrome.; Other health-related issues: Risk of HIV, hepatitis, and other infectious diseases from shared needles.
Stimulants | Khat^†^ (Catha edulis) | Abyssinian Tea, African Salad, Catha, Chat, Kat, Oat | No commercial uses | Fresh or dried leaves | Chewed brewed as tea | I^**^ | Short-term: Euphoria, increased alertness and arousal, increased blood pressure and heart rate, depression, inability to concentrate, irritability, loss of appetite, insomnia.; Long-term: Tooth decay and gum disease; gastrointestinal disorders such as constipation, ulcers, stomach inflammation, and increased risk of upper gastrointestinal tumors; cardiovascular disorders such as irregular heartbeat, decreased blood flow, and heart attack.; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: In rare cases associated with heavy use: psychotic reactions such as fear, anxiety, grandiose delusions (fantastical beliefs that one has superior qualities such as fame, power, and wealth), hallucinations, and paranoia.
Stimulants | Methamphetamine | Crank, Chalk, Crystal, Fire, Glass, Go Fast, Ice, Meth, Speed | Desoxyn® | White powder or pill; crystal meth looks like pieces of glass or shiny blue-white “rocks” of different sizes | Swallowed, snorted, smoked, or injected | II | Short-term: Increased wakefulness and physical activity; decreased appetite; increased breathing, heart rate, blood pressure, temperature; irregular heartbeat.; Long-term: Anxiety, confusion, insomnia, mood problems, violent behavior, paranoia, hallucinations, delusions, weight loss, severe dental problems (“meth mouth”), intense itching leading to skin sores from scratching.; Youth: Unknown; Pregnancy: Premature delivery; separation of the placenta from the uterus; low birth weight; lethargy; heart and brain problems.; Other health-related issues: Risk of HIV, hepatitis, and other infectious diseases from shared needles.
Synthetics (Other) | Synthetic Cannabinoids | K2, Spice, Black Mamba, Bliss, Bombay Blue, Fake Weed, Fire, Genie, Moon Rocks, Skunk, Smacked, Yucatan, Zohai | No commercial uses | Dried, shredded plant material that looks like potpourri and is sometimes sold as “incense” | Smoked, swallowed (brewed as tea) | I | Short-term: Increased heart rate; vomiting; agitation; confusion; hallucinations, anxiety, paranoia; increased blood pressure and reduced blood supply to the heart; heart attack.; Long-term: Unknown; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: Use of synthetic cannabinoids has led to an increase in emergency room visits in certain areas.
Synthetics (Other) | Synthetic Cathinones (Bath salts) | Bloom, Cloud Nine, Cosmic Blast, Flakka, Ivory Wave, Lunar Wave, Scarface, Vanilla Sky, White Lightning | No commercial uses for ingested “bath salts” | White or brown crystalline powder sold in small plastic or foil packages labeled “not for human consumption” and sometimes sold as jewelry cleaner; tablet, capsule, liquid | Swallowed, snorted, injected | I^††^ | Short-term: Increased heart rate and blood pressure; euphoria; increased sociability and sex drive; paranoia, agitation, and hallucinations; psychotic and violent behavior; nosebleeds; sweating; nausea, vomiting; insomnia; irritability; dizziness; depression; suicidal thoughts; panic attacks; reduced motor control; cloudy thinking.; Long-term: Breakdown of skeletal muscle tissue; kidney failure; death.; Youth: Unknown; Pregnancy: Unknown; Other health-related issues: Risk of HIV, hepatitis, and other infectious diseases from shared needles.

* DEA Drug Schedules: Drugs, substances, and certain chemicals used to make drugs are classified into five (5) distinct categories or schedules depending upon the drug’s acceptable medical use and the drug’s abuse or dependency potential. The abuse rate is a determinate factor in the scheduling of the drug.

Schedule I: defined as drugs with no currently accepted medical use and a high potential for abuse. These are considered the most dangerous drugs of all the drug schedules with potentially severe psychological and/or physical dependence.

Schedule II: defined as drugs with a high potential for abuse, with use potentially leading to severe psychological or physical dependence. These drugs are also considered dangerous.

Schedule III: defined as drugs with a moderate to low potential for physical and psychological dependence.

Schedule IV: defined as drugs with a low potential for abuse and low risk of dependence.

Schedule V: defined as drugs with lower potential for abuse than Schedule IV and consist of preparations containing limited quantities of certain narcotics. Schedule V drugs are generally used for antidiarrheal, antitussive, and analgesic purposes.

† It is not known whether substance is addictive.

‡ Marijuana for recreational use is legal in Alaska, California, Colorado, Maine, Massachusetts, Michigan, Nevada, Oregon, Vermont, Washington and the District of Columbia. Marijuana for medical use is legal in Arizona, Arkansas, Connecticut, Delaware, Florida, Hawaii, Illinois, Louisiana, Maryland, Minnesota, Missouri, Montana, Nevada, New Hampshire, New Jersey, New Mexico, New York, North Dakota, Ohio, Oklahoma, Pennsylvania, Rhode Island, Utah, and West Virginia.

§ Rohypnol® is not approved for medical use in the United States; it is available as a prescription sleep aid in other countries

ǁ Labeled drug of concern by DEA and illegal in some states

¶ DMT is Schedule I, but plants containing it are not controlled.

# Various forms may include: Paint thinners or removers, degreasers, dry-cleaning fluids, gasoline, lighter fluids, correction fluids, permanent markers, electronics cleaners and freeze sprays, glue, spray paint, hair or deodorant sprays, fabric protector sprays, aerosol computer cleaning products, vegetable oil sprays, butane lighters, propane tanks, whipped cream aerosol containers, refrigerant gases, ether, chloroform, halothane, nitrous oxide.

** Cathinone is Schedule I, making khat use illegal, but the khat plant is not controlled.

†† Some formulations have been banned by the DEA.

Abbreviations: DEA = Drug Enforcement Agency; HIV = human immunodeficiency virus; IQ = intelligence quotient; Motivational Enhancement Therapy (MET); OCT = over the counter