# Appendix A Comparison of DSM-IV and DSM-5 Substance Use Disorders

DSM-IV | DSM-5
Substance abuse: One or more symptoms | Substance Use Disorder: Two out of 11 criteria clustering in a 12-month period are needed to meet disorder threshold
Recurrent substance-related legal problems | DROPPED
Recurrent substance use in situations where it is physically hazardous | SAME
Recurrent substance use resulting in a failure to fulfill major role obligations at work, school, or home | SAME
Continued substance use despite having persistent or recurrent social or interpersonal problems caused or exacerbated by the effects of the substance | SAME
| ADDED Craving or a strong desire or urge to use the substance
Substance dependence: Three or more symptoms in the same 12-month period (or one symptom if dependence criteria have been met previously in the lifetime)
Substance is taken in larger amounts or over a longer period than was intended | SAME
There is a persistent desire or unsuccessful efforts to cut down or control substance use | SAME
A great deal of time is spent in activities necessary to obtain the substance, use the substance, or recover from its effects | SAME
Important social, occupational, or recreational activities are given up or reduced because of substance use | SAME
Substance use is continued despite knowledge of having a persistent or recurrent physical or psychological problem that is likely to have been caused or exacerbated by substance use | SAME
Tolerance, as defined by either: (1) a need for markedly increased amounts of substance to achieve intoxication or desired effect or (2) a markedly diminished effect with continued use of the same amount of the substance | SAME
Withdrawal, as manifested by either: (1) the characteristic withdrawal syndrome for the substance (excludes Cannabis, Hallucinogens, and Inhalants) (2) the substance (or a similar substance) is taken to relieve or avoid withdrawal symptoms | Withdrawal, as manifested by either: (1) the characteristic withdrawal syndrome for the substance (excludes Phencyclidine, Other Hallucinogens, and Inhalants (2) the substance (or a closely related substance) is taken to relieve or avoid withdrawal symptoms