# References

1 Moyer VA. Primary care interventions to prevent tobacco use in children and adolescents: U.S. preventive services task force recommendation statement. Pediatrics. 2013;132(3):560–5. doi: 10.1542/peds.2013-2079. PMID: 23979083.23979083
2 Patnode CD, O’Connor E, Whitlock EP, . Primary Care Relevant Interventions for Tobacco Use Prevention and Cessation in Children and Adolescents: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 97. AHRQ Publication No. 12-05175-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2012.
3 Patnode CD, O’Connor E, Whitlock EP, . Primary care-relevant interventions for tobacco use prevention and cessation in children and adolescents: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 Feb 19;158(4):253–60. doi: 10.7326/0003-4819-158-4-201302190-00580. PMID: 23229625.23229625
4 Patnode CD, Henderson JT, Thompson JH, . Behavioral Counseling and Pharmacotherapy Interventions for Tobacco Cessation in Adults, Including Interventions for Tobacco Cessation in Adults, Including Pregnant Women: A Review of Reviews for the U.S. Preventive Services Task Force. Evidence Synthesis No. 134. AHRQ Publication No. 14-05200-EF-1. Rockville (MD): Agency for Healthcare Research and Quality; 2015.
5 U.S. Department of Health and Human Services. Food and Drug Administration. Deeming Tobacco Products To Be Subject to the Federal Food, Drug, and Cosmetic Act, as Amended by the Family Smoking Prevention and Tobacco Control Act; Restrictions on the Sale and Distribution of Tobacco Products and Required Warning Statements for Tobacco Products. Fed Regist. 2016 May 10;81(90):28974–9106.
6 Smoking Cessation: A Report of the Surgeon General. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health; 2020.
7 U.S. Food and Drug Administration. FDA finalizes enforcement policy on unauthorized flavored cartridge-based e-cigarettes that appeal to children, including fruit and mint. 2020. https://www.fda.gov/news-events/press-announcements/fda-finalizes-enforcement-policy-unauthorized-flavored-cartridge-based-e-cigarettes-appeal-children. Accessed February 14, 2020.
8 The Health Consequences of Smoking: 50 years of Progress. A Report of the Surgeon General. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health; 2014.
9 Wang TW, Gentzke AS, Creamer MR, . Tobacco product use and associated factors among middle and high school students - United States, 2019. MMWR Surveill Summ. 2019;68(12):1–22. doi: 10.15585/mmwr.ss6812a1. PMID: 31805035.31805035
10 National Academies of Sciences, Engineering Medicine, Health, Medicine, Division; Board on Population, Health Public Health, Practice; Committee on the Review of the Health Effects of Electronic Nicotine Delivery, Systems. Public Health Consequences of E-Cigarettes. Washington (DC): National Academies Press (US); 2018.
11 Goriounova NA, Mansvelder HD. Short- and long-term consequences of nicotine exposure during adolescence for prefrontal cortex neuronal network function. Cold Spring Harb Perspect Med. 2012 Dec 1;2(12):a012120. doi: 10.1101/cshperspect.a012120. PMID: 22983224.22983224
12 Musso F, Bettermann F, Vucurevic G, . Smoking impacts on prefrontal attentional network function in young adult brains. Psychopharmacology (Berl). 2007 Mar;191(1):159–69. doi: 10.1007/s00213-006-0499-8. PMID: 16937098.16937098
13 Alzahrani T, Pena I, Temesgen N, . Association between electronic cigarette use and myocardial infarction. Am J Prev Med. 2018 Oct;55(4):455–61. doi: 10.1016/j.amepre.2018.05.004. PMID: 30166079.30166079
14 Substance Abuse and Mental Health Services Administration. Key Substance Use and Mental Health Indicators in the United States: Results from the 2018 National Survey on Drug Use and Health. HHS Publication No. PEP19-5068, NSDUH Series H-54. Rockville (MD): Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration; 2019. Retrieved from https://www.samhsa.gov/data/.
15 Singh T, Arrazola RA, Corey CG, . Tobacco use among middle and high school students-United States, 2011-2015. MMWR Morb Mortal Wkly Rep. 2016 Apr 15;65(14):361–7. doi: 10.15585/mmwr.mm6514a1. PMID: 27077789.27077789
16 U.S. Food and Drug Administration. Selling Tobacco Products in Retail Stores. 2019. https://www.fda.gov/tobacco-products/retail-sales-tobacco-products/selling-tobacco-products-retail-stores. Accessed February 18, 2020.
17 Gentzke AS, Creamer M, Cullen KA, . Vital signs: tobacco product use among middle and high school students - United States, 2011-2018. MMWR Morb Mortal Wkly Rep. 2019 Feb 15;68(6):157–64. doi: 10.15585/mmwr.mm6806e1. PMID: 30763302.30763302
18 Wang TW, Gentzke A, Sharapova S, . Tobacco product use among middle and high school students - United States, 2011-2017. MMWR Morb Mortal Wkly Rep. 2018 Jun 8;67(22):629–33. doi: 10.15585/mmwr.mm6722a3. PMID: 29879097.29879097
19 Apelberg BJ, Corey CG, Hoffman AC, . Symptoms of tobacco dependence among middle and high school tobacco users: results from the 2012 National Youth Tobacco Survey. Am J Prev Med. 2014 Aug;47(2 Suppl 1):S4–14. doi: 10.1016/j.amepre.2014.04.013. PMID: 25044195.25044195
20 Kann L, McManus T, Harris WA, . Youth risk behavior surveillance - United States, 2017. MMWR Surveill Summ. 2018 Jun 15;67(8):1–114. doi: 10.15585/mmwr.ss6708a1. PMID: 29902162.29902162
21 Vickers KS, Thomas JL, Patten CA, . Prevention of tobacco use in adolescents: review of current findings and implications for healthcare providers. Curr Opin Pediatr. 2002;14(6):708–12. PMID: 12436041.12436041
22 Mowery PD, Farrelly MC, Haviland ML, . Progression to established smoking among U.S. youths. Am J Public Health. 2004;94(2):331–7. doi: 10.2105/AJPH.94.2.331. PMID: 14759951.14759951
23 E-Cigarette Use Among Youth and Young Adults. A Report of the Surgeon General. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health; 2016.
24 Johnston LD, Miech RA, O’Malley PM, . Monitoring the future national survey results on drug use: 1975-2017: overview, key findings on adolescent drug use. Ann Arbor: Institute for Social Research, The University of Michigan; 2018.
25 Fanshawe TR, Halliwell W, Lindson N, . Tobacco cessation interventions for young people. Cochrane Database Syst Rev. 2017 Nov 17;11:CD003289. doi: 10.1002/14651858.CD003289.pub6. PMID: 29148565.29148565
26 Kann L, McManus T, Harris WA, . Youth risk behavior surveillance - United States, 2015. MMWR Surveill Summ. 2016 Jun 10;65(6):1–174. doi: 10.15585/mmwr.ss6506a1. PMID: 27280474.27280474
27 Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health; 2012.
28 Morean ME, Krishnan-Sarin S, S O’Malley S. Assessing nicotine dependence in adolescent E-cigarette users: the 4-item Patient-Reported Outcomes Measurement Information System (PROMIS) Nicotine Dependence Item Bank for electronic cigarettes. Drug Alcohol Depend. 2018 Jul 1;188:60–3. doi: 10.1016/j.drugalcdep.2018.03.029. PMID: 29753155.29753155
29 Centers for Disease Control and Prevention. Outbreak of Lung Injury Associated with the Use of E-Cigarette, or Vaping, Products. 2020. https://www.cdc.gov/tobacco/basic_information/e-cigarettes/severe-lung-disease.html. Accessed February 26, 2020.
30 Johnston LD, Miech RA, O’Malley PM, . Monitoring the future national survey results on drug use 1975-2018: overview, key findings on adolescent drug use. Ann Arbor: Institute for Social Research, University of Michigan; 2019.
31 Staff J, Maggs JL, Ploubidis GB, . Risk factors associated with early smoking onset in two large birth cohorts. Addict Behav. 2018 Dec;87:283–9. doi: 10.1016/j.addbeh.2018.06.008. PMID: 29935736.29935736
32 U.S. Department of Health and Human Services. Office of Adolescent Health. Adolescents and Tobacco: Risk and Protective Factors. https://www.hhs.gov/ash/oah/adolescent-development/substance-use/drugs/tobacco/risk-and-protective-factors/index.html. Accessed Sep 8, 2018.
33 Hu MC, Griesler P, Schaffran C, . Risk and protective factors for nicotine dependence in adolescence. J Child Psychol Psychiatry. 2011 Oct;52(10):1063–72. doi: 10.1111/j.1469-7610.2010.02362.x. PMID: 21250992.21250992
34 Hartmann-Boyce J, Chepkin SC, Ye W, . Nicotine replacement therapy versus control for smoking cessation. Cochrane Database Syst Rev. 2018 May 31;5:CD000146. doi: 10.1002/14651858.CD000146.pub5. PMID: 29852054.29852054
35 Hughes JR, Stead LF, Hartmann-Boyce J, . Antidepressants for smoking cessation. The Cochrane database of systematic reviews. 2014 Jan 8(1):CD000031. doi: 10.1002/14651858.CD000031.pub4. PMID: 24402784.24402784
36 Tobacco Use and Dependence Guideline Panel. Treating Tobacco Use and Dependence: 2008 Update: Clinical Practice Guideline. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service; 2008.
37 U.S. Food and Drug Administration. Want to Quit Smoking? FDA-Approved Products Can Help. 2017. https://www.fda.gov/ForConsumers/ConsumerUpdates/ucm198176.htm. Accessed September 8, 2018.
38 Collins L, Smiley SL, Moore RA, . Physician tobacco screening and advice to quit among U.S. adolescents - National Survey on Drug Use and Health, 2013. Tob Induc Dis. 2017;15:2. doi: 10.1186/s12971-016-0107-6. PMID: 28077940.28077940
39 Dai H, Clements M. Trends in healthcare provider advice on youth tobacco use, 2011-2015. Am J Prev Med. 2018 Aug;55(2):222–30. doi: 10.1016/j.amepre.2018.04.015. PMID: 29934017.29934017
40 Farber HJ, Walley SC, Groner JA, . Clinical practice policy to protect children from tobacco, nicotine, and tobacco smoke. Pediatrics. 2015 Nov;136(5):1008–17. doi: 10.1542/peds.2015-3108 PMID: 26504137.26504137
41 Walley SC, Jenssen BP, Section on Tobacco Control. Electronic nicotine delivery systems. Pediatrics. 2015 Nov;136(5):1018–26. doi: 10.1542/peds.2015-3222. PMID: 26504128.26504128
42 American Academy of Family Physicians. Tobacco: Preventing and Treating Nicotine Dependence and Tobacco Use (Position Paper). https://www.aafp.org/about/policies/all/nicotine-tobacco-prevention.html. Accessed September 8, 2018.
43 U.S. Preventive Services Task Force. Procedure Manual. 2017. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed September 8, 2018.
44 Higgins JPT, Green S (editors). Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0 [updated March 2011]: The Cochrane Collaboration; 2011. Available from http://handbook.cochrane.org.
45 Ausems M, Mesters I, van Breukelen G, . Short-term effects of a randomized computer-based out-of-school smoking prevention trial aimed at elementary schoolchildren. Prev Med. 2002;34(6):581–9. doi: 10.1006/pmed.2002.1021. PMID: 12052017.12052017
46 Bauman KE, Ennett ST, Foshee VA, . Influence of a family-directed program on adolescent cigarette and alcohol cessation. Prev Sci. 2000;1(4):227–37. PMID: 11523750.11523750
47 Bauman KE, Ennett ST, Foshee VA, . Influence of a family program on adolescent smoking and drinking prevalence. Prev Sci. 2002;3(1):35–42. PMID: 12002557.12002557
48 Bauman KE, Foshee VA, Ennett ST, . The influence of a family program on adolescent tobacco and alcohol use. Am J Public Health. 2001;91(4):604–10. PMID: 11291373.11291373
49 Colby SM, Monti PM, O’Leary Tevyaw T, . Brief motivational intervention for adolescent smokers in medical settings. Addict Behav. 2005;30(5):865–74. doi: 10.1016/j.addbeh.2004.10.001. PMID: 15893085.15893085
50 Colby SM, Nargiso J, Tevyaw TO, . Enhanced motivational interviewing versus brief advice for adolescent smoking cessation: results from a randomized clinical trial. Addict Behav. 2012;37(7):817–23. doi: 10.1016/j.addbeh.2012.03.011. PMID: 22472523.22472523
51 Cremers HP, Mercken L, Candel M, . A Web-based, computer-tailored smoking prevention program to prevent children from starting to smoke after transferring to secondary school: randomized controlled trial. J Med Internet Res. 2015 Mar 09;17(3):e59. doi: 10.2196/jmir.3794. PMID: 25759248.25759248
52 Curry SJ, Hollis J, Bush T, . A randomized trial of a family-based smoking prevention intervention in managed care. Prev Med. 2003;37(6 Pt 1):617–26. PMID: 14636795.14636795
53 Fidler W, Lambert TW. A prescription for health: a primary care based intervention to maintain the non-smoking status of young people. Tob Control. 2001;10(1):23–6. PMID: 11226356.11226356
54 Gray KM, Carpenter MJ, Baker NL, . Bupropion SR and contingency management for adolescent smoking cessation. J Subst Abuse Treat. 2011;40(1):77–86. doi: 10.1016/j.jsat.2010.08.010. PMID: 20934835.20934835
55 Haggerty KP, Skinner ML, MacKenzie EP, . A randomized trial of Parents Who Care: effects on key outcomes at 24-month follow-up. Prev Sci. 2007;8(4):249–60. doi: 10.1007/s11121-007-0077-2. PMID: 17987388.17987388
56 Haug S, Schaub MP, Venzin V, . Efficacy of a text message-based smoking cessation intervention for young people: a cluster randomized controlled trial. J Med Internet Res. 2013 Aug 16;15(8):e171. doi: 10.2196/jmir.2636. PMID: 23956024.23956024
57 Hiemstra M, Ringlever L, Otten R, . Long-term effects of a home-based smoking prevention program on smoking initiation: a cluster randomized controlled trial. Prev Med. 2014 Mar;60:65–70. doi: 10.1016/j.ypmed.2013.12.012. PMID: 24355576.24355576
58 Hollis JF, Polen MR, Whitlock EP, . Teen reach: outcomes from a randomized, controlled trial of a tobacco reduction program for teens seen in primary medical care. Pediatrics. 2005;115(4):981–9. doi: 10.1542/peds.2004-0981. PMID: 15805374.15805374
59 Hovell MF, Slymen DJ, Jones JA, . An adolescent tobacco-use prevention trial in orthodontic offices. Am J Public Health. 1996;86(12):1760–6. PMID: 9003134.9003134
60 Huang M, Hollis J, Polen M, . Stages of smoking acquisition versus susceptibility as predictors of smoking initiation in adolescents in primary care. Addict Behav. 2005;30(6):1183–94. doi: 10.1016/j.addbeh.2004.12.009. PMID: 15925127.15925127
61 Jackson C, Dickinson D. Can parents who smoke socialise their children against smoking? Results from the Smoke-free Kids intervention trial. Tob Control. 2003;12(1):52–9. PMID: 12612363.12612363
62 Jackson C, Dickinson D. Enabling parents who smoke to prevent their children from initiating smoking: results from a 3-year intervention evaluation. Arch Pediatr Adolesc Med. 2006;160(1):56–62. doi: 10.1001/archpedi.160.1.56. PMID: 16389212.16389212
63 Jaszyna-Gasior M, Schroeder JR, Moolchan ET. Alcohol use and tobacco abstinence among adolescents in cessation treatment: preliminary findings. Addict Behav. 2007;32(3):617–21. doi: 10.1016/j.addbeh.2006.05.009. PMID: 16814935.16814935
64 Kentala J, Utriainen P, Pahkala K, . Can brief intervention through community dental care have an effect on adolescent smoking? Prev Med. 1999;29(2):107–11. doi: 10.1006/pmed.1999.0512. PMID: 10446036.10446036
65 Killen JD, Robinson TN, Ammerman S, . Randomized clinical trial of the efficacy of bupropion combined with nicotine patch in the treatment of adolescent smokers. J Consult Clin Psychol. 2004;72(4):729–35. doi: 10.1037/0022-006x.72.4.729. PMID: 15301658.15301658
66 Lando HA, Hennrikus D, Boyle R, . Promoting tobacco abstinence among older adolescents in dental clinics. J Smok Cessat. 2007;2(1):23–30. doi: 10.1375/jsc.2.1.23. PMID: 27958471.27958471
67 Muramoto ML, Leischow SJ, Sherrill D, . Randomized, double-blind, placebo-controlled trial of 2 dosages of sustained-release bupropion for adolescent smoking cessation. Arch Pediatr Adolesc Med. 2007;161(11):1068–74. doi: 10.1001/archpedi.161.11.1068. PMID: 17984409.17984409
68 Pbert L, Druker S, DiFranza JR, . Effectiveness of a school nurse-delivered smoking-cessation intervention for adolescents. Pediatrics. 2011;128(5):926–36. doi: 10.1542/peds.2011-0520. PMID: 22007015.22007015
69 Pbert L, Flint AJ, Fletcher KE, . Effect of a pediatric practice-based smoking prevention and cessation intervention for adolescents: a randomized, controlled trial. Pediatrics. 2008;121(4):e738–47. doi: 10.1542/peds.2007-1029. PMID: 18381502.18381502
70 Prado G, Pantin H, Briones E, . A randomized controlled trial of a parent-centered intervention in preventing substance use and HIV risk behaviors in Hispanic adolescents. J Consult Clin Psychol. 2007;75(6):914–26. doi: 10.1037/0022-006x.75.6.914. PMID: 18085908.18085908
71 Redding CA, Prochaska JO, Armstrong K, . Randomized trial outcomes of a TTM-tailored condom use and smoking intervention in urban adolescent females. Health Educ Res. 2015 Feb;30(1):162–78. doi: 10.1093/her/cyu015. PMID: 24794584.24794584
72 Robling M, Bekkers MJ, Bell K, . Effectiveness of a nurse-led intensive home-visitation programme for first-time teenage mothers (Building Blocks): a pragmatic randomised controlled trial. Lancet. 2016 Jan 09;387(10014):146–55. doi: 10.1016/S0140-6736(15)00392-X. PMID: 26474809.26474809
73 Saari AJ, Kentala J, Mattila KJ. Long-term effectiveness of adolescent brief tobacco intervention: a follow-up study. BMC Res Notes. 2012 Feb 16;5:101. doi: 10.1186/1756-0500-5-101. PMID: 22339943.22339943
74 Scherphof CS, van den Eijnden RJ, Engels RC, . Long-term efficacy of nicotine replacement therapy for smoking cessation in adolescents: a randomized controlled trial. Drug Alcohol Depend. 2014 Jul 01;140:217–20. doi: 10.1016/j.drugalcdep.2014.04.007. PMID: 24811201.24811201
75 Schuck K, Otten R, Kleinjan M, . Promoting smoking cessation among parents: effects on smoking-related cognitions and smoking initiation in children. Addict Behav. 2015 Jan;40:66–72. doi: 10.1016/j.addbeh.2014.09.002. PMID: 25222850.25222850
76 Stevens MM, Olson AL, Gaffney CA, . A pediatric, practice-based, randomized trial of drinking and smoking prevention and bicycle helmet, gun, and seatbelt safety promotion. Pediatrics. 2002;109(3):490–7. PMID: 11875146.11875146
77 Scherphof CS, van den Eijnden RJ, Engels RC, . Short-term efficacy of nicotine replacement therapy for smoking cessation in adolescents: a randomized controlled trial. J Subst Abuse Treat. 2014 Feb;46(2):120–7. doi: 10.1016/j.jsat.2013.08.008. PMID: 24029624.24029624
78 Gray KM, Riggs PD, Min SJ, . Cigarette and cannabis use trajectories among adolescents in treatment for attention-deficit/hyperactivity disorder and substance use disorders. Drug Alcohol Depend. 2011;117(2-3):242–7. PMID: CN-00812326.21411243
79 Wang Z. Converting odds ratio to relative risk in cohort studies with partial data information. Journal of Statistical Software. 2013;55(5) doi: 10.18637/jss.v055.i05.
80 Floden L, Taren DL, Muramoto ML, . BMI changes in adolescents treated with bupropion SR for smoking cessation. Obesity. 2016 Jan;24(1):26–9. doi: 10.1002/oby.21360. PMID: 26692579.26692579
81 Soneji S, Barrington-Trimis JL, Wills TA, . Association between initial use of e-cigarettes and subsequent cigarette smoking among adolescents and young adults: a systematic review and meta-analysis. JAMA Pediatrics. 2017 Aug 01;171(8):788–97. doi: 10.1001/jamapediatrics.2017.1488. PMID: 28654986.28654986
82 Loukas A, Marti CN, Cooper M, . Exclusive e-cigarette use predicts cigarette initiation among college students. Addict Behav. 2018 Jan;76:343–7. doi: 10.1016/j.addbeh.2017.08.023. PMID: 28892771.28892771
83 Best C, Haseen F, Currie D, . Relationship between trying an electronic cigarette and subsequent cigarette experimentation in Scottish adolescents: a cohort study. Tob Control. 2017 Jul 22 doi: 10.1136/tobaccocontrol-2017-053691. PMID: 28735273.28735273
84 Conner M, Grogan S, Simms-Ellis R, . Do electronic cigarettes increase cigarette smoking in UK adolescents? Evidence from a 12-month prospective study. Tob Control. 2017 Aug 17 doi: 10.1136/tobaccocontrol-2016-053539. PMID: 28818839.28818839
85 East K, Hitchman SC, Bakolis I, . The association between smoking and electronic cigarette use in a cohort of young people. J Adolesc Health. 2018 May;62(5):539–47. doi: 10.1016/j.jadohealth.2017.11.301. PMID: 29499983.29499983
86 Morgenstern M, Nies A, Goecke M, . E-cigarettes and the use of conventional cigarettes—a cohort study in 10th grade students in Germany. Dtsch Arztebl Int. 2018 Apr 06;115(14):243–8. doi: 10.3238/arztebl.2018.0243. PMID: 29716689.29716689
87 Wills TA, Knight R, Sargent JD, . Longitudinal study of e-cigarette use and onset of cigarette smoking among high school students in Hawaii. Tob Control. 2017 Jan;26(1):34–9. doi: 10.1136/tobaccocontrol-2015-052705. PMID: 26811353.26811353
88 Leventhal AM, Stone MD, Andrabi N, . Association of e-cigarette vaping and progression to heavier patterns of cigarette smoking. JAMA. 2016 Nov 8;316(18):1918–20. doi: 10.1001/jama.2016.14649. PMID: 27825000.27825000
89 Doran N, Brikmanis K, Petersen A, . Does e-cigarette use predict cigarette escalation? A longitudinal study of young adult non-daily smokers. Prev Med. 2017 Jul;100:279–84. doi: 10.1016/j.ypmed.2017.03.023. PMID: 28583658.28583658
90 U.S. Food and Drug Administration. WELLBUTRIN (bupropion hydrochloride) tablets. 2017. https://www.accessdata.fda.gov/drugsatfda_docs/label/2017/018644s053lbl.pdf. Accessed September 17, 2018.
91 Yale University. Effects of e-cigarette flavors on youth. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2018 Sep 8]. https://clinicaltrials.gov/ct2/show/NCT03634839. NLM Identifier: NCT03634839.
92 Truth Initiative. Inspiring tobacco-free lives. 2020. https://truthinitiative.org/. Accessed Feb 14 2020.
93 U.S. Food and Drug Administration. CHANTIX FDA Prescripton Label. 2019. https://www.accessdata.fda.gov/drugsatfda_docs/label/2019/021928s048lbl.pdf. Accessed April 24, 2019.
94 University of California, Los Angeles; Philip Morris USA, Inc. Effects of contingency management and nicotine replacement therapy on youth smoking. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2018 Sep 8]. https://clinicaltrials.gov/ct2/show/NCT01359709. NLM Identifier: NCT01359709.
95 Yale University; National Institutes of Health (NIH); National Institute on Drug Abuse (NIDA). Enhancing a high school based smoking cessation program. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2018 Sep 8]. https://clinicaltrials.gov/ct2/show/NCT01145001. NLM Identifier: NCT01145001.
96 Pfizer Inc. Smoking cessation study in healthy adolescent smokers. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2018 Sep 8]. https://clinicaltrials.gov/ct2/show/NCT01312909. NLM Identifier: NCT01312909.
97 Gray KM, Baker NL, McClure EA, . Efficacy and safety of varenicline for adolescent smoking cessation: a randomized clinical trial. JAMA pediatrics. 2019;173(2):1146–53. doi: 10.1001/jamapediatrics.2019.3553. PMID: 31609433.31609433
98 Dai H. Self-reported marijuana use in electronic cigarettes among US youth, 2017 to 2018. JAMA. 2020;323(5):473–4. doi: 10.1001/jama.2019.19571. PMID: 31848567.31848567