# Acknowledgments

The authors thank Tracy Dana, MLS at Oregon Health and Science University for conducting the searches, and AHRQ Medical Officer Tina Fan, MD, MPH; as well as the U.S. Preventive Services Task Force.