# Chapter 4 Discussion

## Summary of Review Findings

This report updates a 2012 USPSTF review on primary care relevant interventions for tobacco use prevention and cessation in children and adolescents.^2,3^ New to this update is the inclusion of e-cigarettes as a tobacco product and an expansion of the age for prevention trials to participants up to the age of 25. Table 11 summarizes the evidence reviewed for this update. Most of the trial interventions in this review were of (or included, in the case of pharmaceutical trials) a behavioral intervention that often consisted of information to increase communication and positive parenting in trials that targeted parents and/or focused on educating the adolescent and assessing his or her readiness to act/change while providing strategies and processes to facilitate action or behavior change in trials that targeted the youth. While the prior review found no trials that reported health outcomes or intervention effects on subsequent adult smoking (Key Question 1), we identified one study for each. A trial conducted in the United Kingdom examined health outcomes in pregnant teenagers who received an average of 39 nurse home visits and were followed for up to 2 years postpartum. There were no differences between nurse visits and usual care on self-reported psychological distress, depression, and problems with alcohol or drug use. However, the details of the intervention were not described and extensive resources were available to those who received usual care, which may have diluted any effect of the nurse visits. A second trial of brief counseling by dentists on the effects of smoking on oral health found no difference in smoking prevalence after long-term followup (when participants were approximately 29 years old).

Table 11 Summary of Evidence

Key question | Populations or interventions | Studies (k); observations (n); study designs | Summary of findings | Consistency and precision | Other limitations | Strength of evidence | Applicability
Key Question 1 Efficacy of Interventions | Reduce tobacco product use in adulthood | 1 trial (n=2,178) | Enrolled 12 year olds and evaluated smoking at age 29; prevalence of smoking 15.3% vs. 18.5% (OR 0.78, 95% CI, 0.56 to 1.09) | Unknown consistency; imprecise estimate | Only 39% responded to followup survey; | Insufficient | Finnish trial—U.S. applicable
Key Question 1 Efficacy of interventions | Improve adolescent health outcomes | 1 trials (n=1,092) | Enrolled pregnant adolescents, maternal ED/hospital admission (OR 1.32, 95% CI, 0.99 to 1.76), psychological distress scores, depressive symptom scores, and problems with alcohol and drug use scores not different with nurse home visits vs. control | Unknown consistency; imprecise estimate | Description of intervention not provided; details of usual care services accessed not provided | Insufficient | UK trial; services in control group exceed U.S.; intensive nurse visits less applicable to primary care practice
Key Question 2 Efficacy of behavioral interventions | Prevent smoking initiation in nonsmokers | 14 trials (n=25,049) | Pooled analysis of 13 trials (n=21,700, 7.4% vs. 9.2%, RR 0.82, 95% CI, 0.73 to 0.92); I^2^=15% | Consistent; precise | Most trials have moderate risk of bias | Moderate for benefit | Most trials U.S.
Key Question 2 Efficacy of behavioral interventions | Smoking cessation in baseline smokers | 9 trials (n=2,516) | Pooled analysis of 9 trials (80.7% vs. 84.1%, RR 0.97, 95% CI, 0.93 to 1.01); I^2^=29% | Consistent; precise | Most trials have moderate risk of bias | Low for no effect | Most trials U.S.
Key Question 2 Efficacy of behavioral interventions | Smoking prevalence in baseline smokers and nonsmokers | 9 trials (n=11,471) | Pooled analysis of 7 trials (n=10,533, 16.8% vs. 20.1%, RR 0.91, 95% CI, 0.83 to 0.995); I^2^=19% | Consistent; precise | Most trials have moderate risk of bias | Low for benefit | Most trials U.S.
Key Question 2 Efficacy of bupropion | Smoking cessation in baseline smokers | 2 trials in (n=523) | 2 trials of bupropion demonstrated no benefit over placebo | Consistent; estimates imprecise | Low retention (<70%) | Low for no effect | Trials conducted in US
Key Question 2 Efficacy of NRT | Smoking cessation in baseline smokers | 1 trial (n=265) | 6 months: 8.1% vs. 5.7%, AOR 2.09, 95% CI, 0.20 to 22; 12 months: 8.1% vs. 8.2%, AOR 1.13, 95% CI, 0.17 to 7.44 | Unknown consistency, imprecise estimate | None | Insufficient | Netherlands trial—US applicable
Key Question 3 Harms of behavioral interventions | Baseline smokers and nonsmokers | No studies | No studies | No studies | No studies | No studies | No studies
Key Question 3 Harms of bupropion | Baseline smokers | 3 trials (n=657) | No difference between bupropion and control in experiencing a serious or severe adverse event (2 trials), 4% withdrew with bupropion due to adverse events (2 trials); bupropion associated with more headache (2 trials), cough (1 trial), dream disturbance (1 trial), insomnia (1 trial), irritability (1 trial) than control | Consistent, imprecise | Trials rated moderate risk of bias | Low for harms | All trials conducted in U.S.
Key Question 3 Harms of NRT | Baseline smokers | 1 trial (n=257) | NRT associated with more headache, cough, abnormal dreams, muscle pain, and patch-related adverse events than placebo | Consistency unknown; estimate imprecise | None | Insufficient | Dutch study—U.S. applicable

Abbreviations: CI=confidence interval; NRT=nicotine replacement therapy; OR=odds ratio; RR=relative risk; U.S.=United States.

Pooled analysis of 13 prevention trials of behavioral interventions (Key Question 2) demonstrated significantly less smoking initiation among adolescents in the intervention groups than control groups (RR 7.3% vs. 9.2%, RR 0.82, 95% CI, 0.73 to 0.92, I^2^=15%). As in the prior review, proportions of participants who continued to smoke after the behavioral cessation interventions was similar between intervention and control groups in nine trials (80.7% continued smoking with the intervention vs. 84.1% in control groups, RR 0.97, 95% CI, 0.93 to 1.01, I^2^=29%). One new trial of NRT, in addition to two previous trials of bupropion, also found no differences with pharmacotherapy compared with placebo pills or patches. NRT was found to increase abstinence among highly compliant adolescents at the end of treatment, but the effect was lost after 6 months. One trial also found treatment with bupropion 300 mg successful during short-term followup, but not by the 26-week followup. In the other bupropion trial, all participants also received NRT and self-reported smoking cessation rates were fairly high in both arms of the study at 26 weeks (24% in the bupropion arm and 28% in the placebo arm). In a pooled analysis of the nine behavioral intervention trials that combined smokers and nonsmokers, fewer participants smoked after the intervention but the result was not statistically significant (20.3% vs. 23.5%, RR 0.93, 95% CI, 0.86 to 1.01, I^2^=24%). However, two trials included very intense interventions that were unlike other interventions and less likely to be referable from primary care due to availability. Sensitivity analysis removing these two trials did find a statistically significant treatment effect (16.8% vs. 20.1%, RR 0.91, 95% CI, 0.83 to 0.995, I^2^=19%) indicating less smoking at followup in adolescents who received more primary care applicable behavioral intervention compared with controls. Due to the heterogeneity of trial study design and differences between trials in populations enrolled, it is likely this finding is multifactorial and not necessarily only a function of the intervention’s intensity.

There were no harms reported in trials of behavioral interventions (Key Question 3). Bupropion carries a boxed warning for increased risk of suicidality in children, adolescents, and young adults, with other concerns for increased risk for seizure, hypertension, mania, visual problems, and unusual thoughts and behaviors.^90^ Trials of bupropion in children and adolescents for attention-deficit/hyperactivity disorder and/or depression are few and small; and few studies report significant adverse events with bupropion. In the bupropion and NRT trials, there were no serious adverse events reported that were related to the study medication, although a few non-serious adverse events were more common with pharmacotherapy compared with controls (e.g., headache, cough) in some trials.

Exploratory meta-regressions of study level characteristics were conducted and results consistently demonstrated no ability of any variable or group of variables to predict the magnitude of the intervention effect for prevention, cessation, or combined trials. This is likely due to the small numbers of trials included in the meta-regressions and the extensive heterogeneity in multiple study design variables (e.g., target of the intervention, methods of intervention delivery, duration of the intervention, location of the intervention) and the populations enrolled (e.g., both sexes, all female, mostly white, mostly black, all Hispanic, younger adolescents, older adolescents) in the included prevention, cessation, and combined trials. The only exceptions were the unexpected findings that in prevention studies trials that used a single mode of delivering the intervention or fewer number of contacts as part of the intervention (in-person visits, telephone calls, mailings to the adolescent’s home) were more likely to report less smoking initiation than trials that employed multiple methods or had more participant contacts. However, the significance of these findings is unclear.

## Contextual Issues

Child, adolescent, and young adult use of e-cigarettes is not safe.^23^ Concerns regarding e-cigarette use by youth include nicotine addiction, harm to the developing brain, progression to combustible tobacco use, nicotine toxicity, inhalation of toxins or carcinogens, and explosions and fires caused by the e-cigarette device. Although we identified no trials in children and adolescents that examine the prevention or cessation of e-cigarette use, there is strong evidence linking e-cigarette use in nonsmoking adolescents and young adults to subsequent cigarette smoking. According to a 2018 report by the NASEM ever having used e-cigarettes is associated with a statistically significant increased risk of ever using combustible tobacco products.^10^ Additionally, increased degree of e-cigarette use is associated with increased frequency and intensity of smoking cigarettes.

## Limitations

Although our searches were not limited to cigarette smoking, most studies were published more than 10 years ago and only examined cigarette smoking with few enquiries regarding other forms of tobacco products. Many of the studies reviewed were rated fair-quality due to risks of bias associated with unclear randomization and allocation concealment, lack of blinding, and high attrition; we did not include trials that were rated poor-quality. Additionally, the behavioral interventions included were quite heterogeneous and not always well described. We conducted exploratory meta-regression and stratified analyses to help understand study design characteristics related to decreased smoking but could not explain why some trials demonstrated significant effects of the behavioral interventions and others did not. However, meta-regression was limited by the few number of studies and there were numerous statistical tests conducted, which increases the risk for a Type I error. The small number of trials also limited our ability to conduct statistical and graphical tests for publication bias, but most published trials did not demonstrate a significant intervention effect. There were also inconsistent definitions of baseline smoking status, initiation, and abstinence. When possible we pooled self-reported smoking rather than chemically verified smoking, which may be unreliable in children who smoke irregularly. In the three studies that included both self-reported smoking abstinence and biochemically-verified smoking abstinence, biochemically-verified abstinence was lower than self-report (e.g., 15.3% self-report vs. 5.3% verified) but did not change study conclusions or meta-analysis results in the one trial included in the meta-analysis. Only one trial each assessed health outcomes and adult smoking. There were few trials that assessed pharmacotherapy for smoking cessation and they were small. There were no cessation trials of e-cigarette use identified; there were also no prevention trials in young adults found, even though we conducted a separate search to identify trials in this population. Other limitations include the lack of reporting on adherence in most trials, both in the delivery of the intervention and in the participation of the adolescent, or low adherence (in delivery and/or participation) reported in a few trials that may cause an intervention to appear less effective than it otherwise might be. Most cessation studies also did not report results by baseline motivation to quit tobacco or by baseline degree of nicotine addiction so it is not clear whether an intervention’s relative success is dependent on the degree of motivation to stop smoking or the degree of addiction to nicotine. Additional limitations are that we excluded results found only in abstracts due to insufficient information to rate study quality and we also excluded trials published in languages other than English.

## Emerging Issues/Next Steps

As the technology of e-cigarette use evolves (e.g., smaller vape clouds, devices that look like thumb drives), it becomes easier for youth to use e-cigarettes without detection by parents, school officials, or primary care physicians, increasing the likelihood of potential harms with e-cigarette use. There is one trial (NCT03634839),^91^ with an estimated completion date August 2021, that is studying the effect of different flavorings and different nicotine concentrations on 60 youth (aged 16 to 20 years) and has a primary outcome of change score in liking/wanting e-cigarettes. One cluster trial (NCT04054765) is recruiting 12 to 15 year olds for a virtual reality video game intervention on the prevention of e-cigarette use (December 2020 estimated completion date). One trial in young adults aged 18 years to 24 years that is currently recruiting will compare the effect of a text messaging intervention on e-cigarette cessation (NCT04251273). This trial is sponsored by the Truth Initiative^92^ and has an estimated completion date of January 2021. Additionally, the Adolescent Brain Development Study is a longitudinal study of brain development and child health in the United States. The behavioral and biological development of almost 12,000 9 to 10 year-olds at 21 research sites will be tracked into young adulthood. Substance use, including tobacco products, is being tracked as a part of this study and may provide additional insight into the effects of nicotine exposure on the developing adolescent brain.

Other emerging issues concern the use of pharmacotherapy for smoking cessation in this age group. The FDA has not approved any smoking cessation drug (e.g., bupropion, NRT, varenicline) for use in children and there are few published trials of these drugs. In addition, in 2019 the FDA noted that it is changing the label for varenicline to specifically note that it is not recommended for persons 16 years and younger, as it has not been proven effective.^93^ Two recently completed studies of NRT (NCT01359709,^94^ NCT01145001^95^) and one additional trial of varenicline (NCT01312909^96^) in adolescents were identified, that have not yet been published. These studies should shed additional light on the efficacy and safety of these medications in the pediatric population.

One varenicline randomized trial (n=157) included adolescents and young adults 14 to 21 years of age, but was excluded because the mean age was 19.1 years and results were not reported separately for those less than 18 years of age.^97^ It found no difference between varenicline versus placebo in self-reported 7-day smoking abstinence at the end of 12-weeks of treatment (n=90, 31% vs. 27%). At 6-month followup, the difference between varenicline and placebo on 7-day abstinence had widened (n=83, 36% vs. 17%). Attrition was high (47%); in addition, it is unclear why varenicline would show a delayed effect. Results of this trial were similar to an unpublished varenicline trial in adolescents (NCT01312909^96^). There was no difference between varenicline and placebo on 4-week continuous abstinence rate (week 9 through week 12) but in participants who received low-dose varenicline (0.5 mg), continuous abstinence rates from weeks nine through weeks 24 and 52 weeks were improved with varenicline. Attrition in this trial was 40%.

Another emerging issue is the relationship between e-cigarette use and marijuana use. Prevalence of self-reported marijuana use has been increasing in adolescents and young adults. In 2018, 42.7 percent of youth who had ever used an e-cigarette, 53.5 percent of youth who were current e-cigarette users, and 71.6 percent of youth who used multiple tobacco products reported ever using marijuana in e-cigarettes, with the largest increase observed in youth who were current users of tobacco products (33.2% to 40.6% from 2017 to 2018).^98^

## Relevance for Priority Populations

Children and adolescents are a vulnerable population with developing bodies, developing brains, and developing personalities. Most smokers initiate smoking in adolescence. Methods to reduce exposure to nicotine and known and unknown toxins and carcinogens found in cigarettes, cigars, e-cigarettes, and other tobacco products have tremendous consequences for short-term (e.g., nicotine addiction, harm to the developing brain, nicotine toxicity, burns from vaping device explosions) and long-term (e.g., lung cancer, mouth and throat cancer, myocardial infarction, stroke, chronic obstructive pulmonary disease) mental and physical health. Access to primary care relevant behavioral intervention may decrease the likelihood that a child will pursue cigarette smoking or use of other tobacco products, thereby extending the child’s life and health.

## Applicability

Most studies were conducted in the United States and the remainder were conducted in Western Europe and are highly applicable to U.S. settings. We required trials to be conducted in primary care settings or to be referable from primary care.. Because trials enrolled mostly white adolescents, it is unclear if there are differences based on race or ethnic background in the effects of various interventions. Additionally, since most studies did not report the proportion of youth smoking by baseline characteristics, it is not known, for example, if behavioral interventions are more successful among youth highly motivated to quit versus those less motivated.

## Future Research

There is no trial evidence on the prevention or cessation of e-cigarette use, of cigar use, or of other forms of tobacco use in children and adolescents with the exception of cigarette use. Such trials, particularly trials of e-cigarette use, are desperately needed, given the high and rapidly increasing prevalence of e-cigarette use among middle and high school aged youth. Additional well-conducted randomized trials are also needed to ascertain the best methods to encourage and achieve smoking cessation. Trials of most behavioral interventions for smoking cessation favor the intervention with a pooled estimate that is very close to statistical significance. Larger trials, especially trials conducted in youth wanting to quit tobacco products, may show a clear indication for the benefit of behavioral interventions. Additionally, trials should examine health outcomes such as respiratory and cardiovascular disease and should follow adolescents into adulthood to determine the interventions effects on long-term outcomes. None of the medication trials were very large (n≤312) and no published trial of varenicline met inclusion criteria.

## Conclusions

Behavioral interventions can reduce the likelihood of smoking initiation in nonsmoking youth and young adults. Research is needed to identify effective behavioral interventions for youth who smoke or who use other tobacco products and to understand the effectiveness of pharmacotherapy for cessation of tobacco use. Due to the rapid escalation of e-cigarette use among youth, both prevention and cessation trials that target and/or include e-cigarette use are imminently needed.