# Chapter 3 Results

We identified 26 trials, reported in 33 publications,^45–77^ examining the effects and harms of interventions designed to prevent the initiation of tobacco use and/or promote cessation among children and adolescents (Table 3). Twenty-five of the 26 included trials reported smoking prevalence at 6 months or longer followup; one additional trial did not report health outcomes or tobacco prevalence at 6 months or longer followup and thus, was only included for harms (Key Question 3).^78^ Seven trials were newly identified as part of this update and 19 were carried forward from the previous review. Overall, five trials were rated good-quality^58,59,68,74,76^ and the remainder were rated fair-quality largely due to unspecified methods of allocation concealment, lack of reporting of baseline participant characteristics by randomized group, and high attrition (Appendix B1). We did not include three studies rated poor-quality. Tables 4, 5, and 6 present study, population, and intervention characteristics for all included trials. Appendix B2 presents detailed descriptions of the behavioral interventions.

Table 3 Included Studies by Intervention Type

Trial | Prevent initiation | Behavioral cessation | Pharmacotherapy cessation | Combined prevalence
Ausems, 2002^45^ | X
Bauman, 2000^46^; Bauman, 2001^48^; Bauman, 2002^47^ | X | X | | X
Colby, 2005^49^ | | X
Colby, 2012^50^ | | X
Cremers, 2015^51^ | X
Curry, 2003^52^ | X
Fidler, 2001^53^ | X
Gray, 2011^54^ | | | X (Bupropion)
Haggerty, 2007^55^ | X
Haug, 2013^56^ | | X
Hiemstra, 2014^57^ | X
Hollis, 2005^58^ | X | X | | X
Hovell, 1996^59^ | X
Jackson, 2006^62^ | X
Kentala, 1999^64^; Saari, 2012^73^ | | | | X
Killen, 2004^65^ | | | X (Bupropion)
Lando, 2007^66^ | X | X | | X
Muramoto, 2007^67^ | | | X (Bupropion)
Pbert, 2008^69^ | X | X | | X
Pbert, 2011^68^ | | X
Prado, 2007^70^ | | | | X
Redding, 2015^71^ | X | X | | X
Robling, 2016^72^ | | | | X
Scherphof, 2014^74^ | | | X (NRT)
Schuck, 2015^75^ | X
Stevens, 2002^76^ | | | | X
Total Number of Studies (New) | 14 (4) | 9 (2) | 4 (1) | 9 (2)

Abbreviations: NRT=nicotine replacement therapy

Table 4 Characteristics of Behavioral Intervention Prevention Trials

Trial; quality; location; setting; N^*^ | Target of intervention | Components included in intervention | Interventionist; mode of Intervention; role of PC | Duration of intervention (hours of contact);^†^ followup | Control group | Mean age (range), years; female; nonwhite
Ausems 2002^‡,45^; Fair; The Netherlands, home; IG: 871; CG: 793 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: NA; Mode of intervention: Print; Role of PC: None | Duration: 9 weeks (0); Months to followup: 6; Followup: 91.5% | Not described | Age: 11.7 (NR); Female: 50.6%; Nonwhite: NR
Bauman, 2001^§,48^; Fair; U.S., home; IG: 658; CG: 658 | Person: Parent; Based on smoking status: No | Multiple behaviors: Yes; Group sessions: No; MI: No | Interventionist: Health educators; Mode of intervention: Phone, print; Role of PC: None | Duration: 15 weeks (0.96); Months to followup: 7,^ǁ^ 16; Followup: 81.2% | Not described | Age: 13.9 (12–14); Female: 50.7%; Nonwhite: 26.6%
Cremers, 2015^51^; Fair; The Netherlands, school and home; IG1: 1207; IG2: 1003;^¶^ CG: 1003 | Person: Youth; Based on smoking status: No | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: Self-directed; Mode of intervention: Computer; Role of PC: None | Duration: 25 months (0); Months to followup: 12,^ǁ^ 25; Followup: 66.8% | Usual care | Age: 10.4 (10-11); Female: 50.6%; Nonwhite: 11.7%
Curry, 2003^52^; Fair; U.S., home (optional primary care); IG: 2020; CG: 2006 | Person: Both; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: Study-trained telephone counselor, PC; Mode of intervention: Print, phone; Role of PC: Recruitment only, optional PC | Duration: 6 weeks + 1 booster call within 14 months (NR); Months to followup: 20; Followup: 88.5% | Usual care | Age: 11. 0 (10–12); Female: 52.0%; Nonwhite: NR
Fidler, 2001^53^; Fair; U.K., home; IG: 1456; CG: 1486 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: NA; Mode of intervention: Print; Role of PC: Recruitment only | Duration: 12 months (0); Months to followup: 12; Followup: 75.3% | No interaction | Age: NR (10–15); Female: 55.3%; Nonwhite: NR
Haggerty, 2007^55^; Fair; U.S., home (IG1) or after school (IG2)^**^; IG1: 107; IG2: 118; CG: 83 | Person: Both; Based on smoking status: Yes | Multiple behaviors: Yes; Group sessions: Yes; MI: No | Interventionist: Study-trained workshop leaders; Mode of intervention: Face; Role of PC: None | Duration: 7 weeks (15.5); Months to followup: 12,^ǁ^ 24; Followup: 92.5% | Low intensity | Age: 13. 7 (NR); Female: 48.6%; Nonwhite: 50.8%
Hiemstra, 2014^57^; Fair; The Netherlands, home; IG: 728; CG: 750 | Person: Both; Based on smoking status: No | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: NA; Mode of intervention: Print; Role of PC: Recruitment only | Duration: 20 weeks + 1 booster module at 12 months (0); Months to followup: 6, 12,^ǁ^ 24, 36; Followup: 92.6% | Not described | Age: 10.1 (9-11); Female: 52.6%; Nonwhite: 1.7%
Hollis, 2005^§,58^; Good; U.S., medical office; IG: 1254; CG: 1272 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: PCP, health counselor,^*^ self-directed; Mode of intervention: Face, computer, print, phone; Role of PC: Conducted in PC, provider delivered part | Duration: 1 visit + 2 booster sessions within 12 months (0.25); Months to followup: 12,^ǁ^ 24; Followup: 93.7% | Attention control | Age: 15.4 (14–17); Female: 59.2%; Nonwhite: 21.8%
Hovell, 1996^59^; Good; U.S., orthodontic office; IG: 7149; CG: 7626 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: Orthodontic staff; Mode of intervention: Face, print; Role of PC: Conducted in dental, provider delivered most | Duration: 2 years (NR); Months to followup: 24; Followup: 92.5% | Usual care | Age: 14.4 (11–19); Female: 54.0%; Nonwhite: 27.0%
Jackson, 2006^62^; Fair; U.S., home; IG: 426; CG: 447 | Person: Both; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: NA; Mode of intervention: Print; Role of PC: None | Duration: 10 weeks + 1 booster guide within 12 months (NR); Months to followup: 36; Followup: 87.5% | Low intensity | Age: NR (7–8); Female: 52.6%; Nonwhite: 23.7%
Lando, 2007^§,66^; Fair; U.S., dental clinic; IG: 175; CG: 169 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Dental staff; Mode of intervention: Face, phone; Role of PC: Conducted in dental, provider delivered part | Duration: 1 visit + 3 to 6 booster calls within 6 months (1.2); Months to followup: 12; Followup: 65.4% | Low intensity | Age: 15.4 (14–17); Female: 52.0%; Nonwhite: 19.0%
Pbert, 2008^§,69^; Fair; U.S., pediatric clinic; IG: 1346; CG: 1365 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Peer counselors; Mode of intervention: Face, phone; Role of PC: Conducted in PC, provider delivered part | Duration: 1 visit + 4 booster calls over 21 weeks (1.1); Months to followup: 6, 12^ǁ^; Followup: 99.2% | Usual care | Age: 16.9 (13–17); Female: 54.1%; Nonwhite: 8.6%
Redding, 2015^§,71^; Fair; U.S., medical office; IG: 424; CG: 404 | Person: Youth (female only); Based on smoking status: Yes | Multiple behaviors: Yes; Group sessions: No; MI: Yes | Interventionist: BA- or MA-level counselors, Self-directed; Mode of intervention: Face, computer; Role of PC: None | Duration: 9 months (NR, up to 4 counseling sessions); Months to followup: 12,^ǁ^ 18; Followup: 63.6% | Low intensity | Age: 16.4 (14-17); Female: 100%; Nonwhite: 92.1%
Schuck, 2015^75^; Fair; The Netherlands, home; IG: 256; CG: 256 | Person: Parent; Based on smoking status: Yes (parents), No (youth) | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Dutch national quit line counselors; Mode of intervention: Phone, print; Role of PC: None | Duration: 3 months (NR, up to 7 telephone counseling sessions); Months to followup: 3, 12,^ǁ^ 30; Followup: 77.9% | Low intensity | Age: 10.5 (9-12); Female: 50.4%; Nonwhite: NR

* Randomized.

† With interventionist

‡ Study not included in meta-analysis.

§ Study also included in combined prevention and cessation table and cessation only table (Tables 5 and 6).

ǁ Data from this followup point used.

¶ Interventions were combined in the meta-analysis.

** Intervention group utilized in the meta-analysis.

Abbreviations: BA=bachelor degree; CG=control group; IG=intervention group; MA=master degree; MI=motivational interviewing; N=number; NA=not applicable; NR=not reported; PC=primary care; U.K.=United Kingdom; U.S.=United States.

Table 5 Characteristics of Cessation Trials

Trial; quality; location; setting; N^*^ | Target of intervention | Components included in intervention | Interventionist; mode of intervention; role of PC | Duration of intervention (hours of contact);^†^ followup | Control group | Mean age (range), years; female; nonwhite
Bauman, 2000^‡,46^; Fair; U.S., home; IG: 658; CG: 658 | Person: Parent; Based on smoking status: No | Multiple behaviors: Yes; Group sessions: No; MI: No | Interventionist: Health educators; Mode of intervention: Phone, print; Role of PC: None | Duration: 15 weeks (0.96); Months to followup: 7,^§^ 16; Followup: 81.2% | Not described | Age: 13.9 (12–14); Female: 50.7%; Nonwhite: 26.6%
Colby, 2005^49^; Fair; U.S., NR; IG: 43; CG: 42 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Study-trained interventionists; Mode of intervention: Face, phone, print; Role of PC: Recruitment only | Duration: 1 visit + 1 booster call within 1 week (0.875); Months to followup: 6; Followup: 80.0% | Low intensity | Age: 16. 3 (12–19); Female: 61.0%; Nonwhite: 45.0%
Colby, 2012^50^; Fair; U.S., NR; IG: 79; CG: 83 | Person: Both; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Study-trained interventionists; Mode of intervention: Face, phone, print; Role of PC: Recruitment only | Duration: 1 visit + 1 booster call within 1 week + 1 parent discussion (1.25); Months to followup: 6; Followup: 81.5% | Low intensity | Age: 16.2 (14-18); Female: 47.5%; Nonwhite: 27.8%
Haug, 2013^56^; Fair; Switzerland, home; IG: 372; CG: 383 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: NA; Mode of intervention: Text messaging; Role of PC: None | Duration: 3 months (0); Months to followup: 6; Followup: 74% | Assessment only | Age: 18.2 (NR); Female: 51.9%; Nonwhite: NR
Hollis, 2005^‡,58^; Good; U.S., medical office; IG: 1254; CG: 1272 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: PC, health counselor,^*^ self-directed; Mode of intervention: Face, computer, print, phone; Role of PC: Provider delivered part | Duration: 1 visit + 2 booster sessions within 12 months (0.25); Months to followup: 12,^§^ 24; Followup: 93.7% | Attention control | Age: 15.4 (14–17); Female: 59.2%; Nonwhite: 21.8%
Lando, 2007^†,66^; Fair; U.S., dental clinic; IG: 175; CG: 169 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Dental staff; Mode of intervention: Face, phone; Role of PC: Provider delivered part | Duration: 1 visit + 3 to 6 booster calls within 6 months (1.2); Months to followup: 12; Followup: 65.4% | Low intensity | Age: 15.4 (14–17); Female: 52.0%; Nonwhite: 19.0%
Pbert, 2008^†,69^; Fair; U.S., pediatric clinic; IG: 1346; CG: 1365 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Peer counselors; Mode of intervention: Face, phone; Role of PC: Provider delivered part | Duration: 1 visit + 4 booster calls over 21 weeks (1.1); Months to followup: 6, 12^§^; Followup: 99.2% | Usual care | Age: 16.9 (13–17); Female: 54.1%; Nonwhite: 8.6%
Pbert, 2011^68^; Good; U.S., school health clinic; IG: 486; CG: 582 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: School nurse; Mode of intervention: Face; Role of PC: None | Duration: 4 weeks (1.5); Months to followup: 12; Followup: 88.4% | Low intensity | Age: 16.9 (NR); Female: 47.7%; Nonwhite: 7.4%
Redding, 2015^‡,71^; Fair; U.S., medical office; IG: 424; CG: 404 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: Yes; Group sessions: No; MI: Yes | Interventionist: BA- or MA-level counselors, Self-directed; Mode of intervention: Face, computer; Role of PC: None | Duration: 9 months (NR, up to 4 counseling sessions); Months to followup: 12,^§^ 18; Followup: 63.6% | Low intensity | Age: 16.4 (14-17); Female: 100%; Nonwhite: 92.1%
Killen, 2004^ǁ,65^; Fair; U.S., NR; IG:103; CG: 108 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: Yes; MI: No | Interventionist: Study-trained counselors; Mode of intervention: Face; Role of PC: None | Duration: 10 weeks (7.5); Months to followup: 6; Followup: 63.5% | Placebo | Age: 17.3 (15–18); Female: 31.3%; Nonwhite: 49.8%
Muramoto, 2007^ǁ,67^; Fair; U.S., research clinic; IG1: 105;^¶^ IG2: 104 CG: 103 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: NR; Mode of intervention: Face; Role of PC: None | Duration: 7 weeks (2.25); Months to followup: 6; Followup: 61.9% | Placebo | Age: 16.0 (14–17); Female: 45.8%; Nonwhite: 26.0%
Scherphof, 2014^ǁ,74^; Good; The Netherlands, School; IG: 135; CG: 122 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: NR; Mode of intervention: Face; Role of PC: None | Duration: 6 or 9 weeks depending on # cigarettes smoked per day (1.25); Months to followup: 6, 12^§^; Followup: 89.9% | Placebo | Age: 16.7 (NR); Female: 52.9%^**^; Nonwhite: NR

* Randomized.

† With interventionist

‡ Study also included on combined prevention and cessation table and prevention only table (Tables 4 and 6).

§ Data from this followup point used.

ǁ Pharmacotherapy utilized in intervention group.

¶ Intervention group utilized in the meta-analysis.

** Calculated based on presented data.

Abbreviations: BA=bachelor degree; CG=control group; IG=intervention group; MA=master degree; MI=motivational interviewing; N=number; NA=not applicable; NR=not reported; PC=primary care; U.K.=United Kingdom; U.S.=United States.

Table 6 Characteristics of Combined Prevention and Cessation Behavioral Intervention Trials

Trial; quality; location; setting; N^*^ | Target of intervention | Components included in intervention | Interventionist; mode of intervention; role of PC | Duration of intervention (hours of contact);^†^ followup | Control group | Mean age (range), years; female; nonwhite
Bauman, 2002^‡,47^; Fair; U.S., home; IG: 658; CG: 658 | Person: Parent; Based on smoking status: No | Multiple behaviors: Yes; Group sessions: No; MI: No | Interventionist: Health educators; Mode of intervention: Phone, print; Role of PC: None | Duration: 15 weeks (0.96); Months to followup: 7,^§^ 16; Followup: 81.2% | Not described | Age: 13.9 (12–14); Female: 50.7%; Nonwhite: 26.6%
Hollis, 2005^‡,58^; Good; U.S., medical office; IG: 1254; CG: 1272 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: PC, health counselor,^*^ self-directed; Mode of intervention: Face, computer, print, phone; Role of PC: Conducted in PC, provider delivered part | Duration: 1 visit + 2 booster sessions within 12 months (0.25); Months to followup: 12,^§^ 24; Followup: 93.7% | Attention control | Age: 15.4 (14–17); Female: 59.2%; Nonwhite: 21.8%
Kentala, 1999^64^; Saari, 2012^73^; Fair; Finland, dental clinic; IG: 1348; CG: 1238 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: No | Interventionist: Dental staff; Mode of intervention: Face; Role of PC: Conducted in dental, provider delivered most | Duration: 1-4 visits (0.17); Months to followup: 12,^§^ 24; Followup: 84.2% | Usual care | Age: 13.1 (NR); Female: 49.0%; Nonwhite: NR
Lando, 2007^‡,66^; Fair; U.S., dental clinic; IG: 175;CG: 169 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Dental staff; Mode of intervention: Face, phone; Role of PC: Conducted in dental, provider delivered part | Duration: 1 visit + 3 to 6 booster calls within 6 months (1.2); Months to followup: 12; Followup: 65.4% | Low intensity | Age: 15.4 (14–17); Female: 52.0%; Nonwhite: 19.0%
Pbert, 2008^‡,69^; Fair; U.S., pediatric clinic; IG: 1346; CG: 1365 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: No; Group sessions: No; MI: Yes | Interventionist: Peer counselors; Mode of intervention: Face, phone; Role of PC: Conducted in PC, provider delivered part | Duration: 1 visit + 4 booster calls over 21 weeks (1.1); Months to followup: 6, 12^§^; Followup: 99.2% | Usual care | Age: 16.9 (13–17); Female: 54.1%; Nonwhite: 8.6%
Prado, 2007^70^; Fair; U.S., home, community; IG: 91; CG: 84 | Person: Parent; Based on smoking status: No | Multiple behaviors: Yes; Group sessions: Yes; MI: No | Interventionist: Study-trained facilitators; Mode of intervention: Face; Role of PC: None | Duration: 12 months (49); Months to followup: 12,^§^ 24, 36; Followup: 88.0% | Attention control | Age: 13.4 (NR); Female: 53.7%; Nonwhite: 100%
Redding, 2015^‡,71^; Fair; U.S., medical office; IG: 424; CG: 404 | Person: Youth; Based on smoking status: Yes | Multiple behaviors: Yes; Group sessions: No; MI: Yes | Interventionist: BA- or MA-level counselors, Self-directed; Mode of intervention: Face, computer; Role of PC: None | Duration: 9 months (NR, up to 4 counseling sessions); Months to followup: 12,^§^ 18; Followup: 63.6% | Low intensity | Age: 16.4 (14-17); Female: 100%; Nonwhite: 92.1%
Robling, 2016^72^; Fair; U.K., home; IG: 823; CG: 822 | Person: Youth (pregnant); Based on smoking status: No | Multiple behaviors: Yes; Group sessions: No; MI: Yes | Interventionist: Family nurses; Mode of intervention: Face; Role of PC: Home visits by nurse | Duration: 24 months (mean nurse visits 39); Months to followup: 24; Followup: 66.4% | Usual care | Age: 17.9 (16.9-18.8); Female: 100%; Nonwhite: 11.9%
Stevens, 2002^ǁ,76^; Good; U.S., pediatric office; IG: 1780; CG: 1331 | Person: Parent and youth; Based on smoking status: No | Multiple behaviors: Yes; Group sessions: No; MI: No | Interventionist: PCP; Mode of intervention: Face, phone, print; Role of PC: Provider delivered part | Duration: 36 months (NR); Months to followup: 12,^§^ 24, 36; Followup: 95.5% | Attention control | Age: 11. 0 (NR); Female: 48.3%; Nonwhite: NR

* Randomized.

† With interventionist

‡ Study also included on prevention only and cessation only tables (Tables 4 and 5).

§ Data from this followup point used in meta-analysis.

ǁ Study not included in meta-analysis.

Abbreviations: BA=bachelor degree; CG = control group; IG = intervention group; MA=master degree; N = number; NR = not reported; PC=primary care; U.S. = United States.

## Key Question 1 Do Primary Care Interventions to Prevent Tobacco and Nicotine Use or Improve Tobacco and Nicotine Cessation Rates in Children and Adolescents Improve Health Outcomes (i.e., Respiratory, Dental, Cardiovascular, and Oral Health) and Reduce the Likelihood of Tobacco and Nicotine Use in Adulthood?

### Summary

The previous USPSTF review^2,3^ found no eligible evidence on the effects of primary care interventions on smoking status as adults or on health outcomes. One long-term followup paper of a previously included trial^64^ found no long-term effect of counseling by a dentist on the likelihood of adult smoking at 16 years of followup (odds ratio [OR] 0.78, 95% confidence interval [CI] 0.56 to 1.09), although the effect estimate favored the intervention.^73^ One new trial found no effect of a nurse visitation program on smoking during late pregnancy (56% in both intervention and control groups) or on mental health outcomes at 2 years postpartum.^72^ However, the intervention was not well-defined. Both trials were rated fair-quality due to unclear allocation concealment,^64^ unclear if randomized groups were similar at baseline,^64^ and high attrition.^64,72^ We identified no trials of e-cigarette use.

### Evidence

The prior review found no evidence for this key. One trial^64^ included previously enrolled 12 year olds (n=2,586) at their routine dental exam in Finland and assigned them to brief counseling by a dentist or usual care. Adolescents who did not smoke (94.3%) were counseled against smoking. Both adolescents who smoked and those who did not smoke were shown photos of teeth discolored by smoking and invited to check their own teeth with a hand mirror for discolorations. The brief counseling was provided to participants up to four times during routine dental visits over approximately 2.5 years. The prevalence of smoking at the 2-year followup was 18.1 percent in the group that received counseling by the dentist and 20.8 percent among those assigned to usual care and was not statistically significantly different. A companion publication reported long-term followup when the study participants were 29 years old and found that in the 1,020 participants who returned the survey (39.4% of the original sample), 15.3 percent in the intervention group and 18.5 percent in the usual care group were smokers (OR 0.78, 95% CI, 0.56 to 1.09).^73^ Most started smoking at 15 years old (median), which was not different between the groups.

One non-blinded, randomized trial of a combined intervention enrolled 1,645 pregnant women 19 years or younger and less than 25 weeks gestation to an intensive program of home visits by nurses in the United Kingdom (Family Nurse Partnership [FNP]) plus usual care or to usual care alone (publically funded health care and social care).^72^ This study was based on a U.S. model of home visitation that covered parent education on fetal and infant development, informal support, and referrals to other services as needed. However, details of the intervention in the U.K. trial were not provided and it is unknown how closely the U.K. trial followed the U.S. model. In the U.K. trial, primary outcomes included self-reported tobacco use in late pregnancy. Secondary outcomes included maternal depression, problems with alcohol and drug use, and emergency department visits and hospital admissions not related to the birth of the child through 24 months postpartum. Both smokers (57%) and nonsmokers (43%) were enrolled and assigned to treatment groups through minimization. Self-reported smoking or cotinine levels were missing from 486 participants (30%). Of the 1,092 women analyzed for smoking, there were no differences in self-reported smoking during late pregnancy (56% both groups) or in the number of cigarettes smoked per day. While there were no differences between groups on maternal non-delivery related emergency department visits and hospital admissions, maternal psychological distress scores, depressive symptoms score, or problems with alcohol and drug use scores at 24 months postpartum, it is uncertain if these outcomes would be substantially affected by the smoking intervention and may not be the best benchmark for evaluating the value of the intervention.

## Key Question 2 Do Primary Care Interventions Prevent Tobacco and Nicotine Use or Improve Tobacco and Nicotine Cessation Rates in Children and Adolescents?

### Summary

The prior review^2,3^ included 18 trials and seven new trials were identified for this update.^51,56,57,71,72,74,75^ Across all 25 trials, 14 provided evidence on preventing tobacco initiation among nonusers, 12 provided evidence on tobacco cessation among users, and nine provided evidence on the overall tobacco prevalence. Similar to the prior review,^2,3^ behavioral interventions were associated with reduced smoking initiation compared with controls (k=13, n=21,700, 7.4% vs. 9.2%, RR 0.82, 95% CI, 0.73 to 0.92, I^2^=15%).^45,48,51–53,55,57–59,62,66,69,71,75^ However, as in the prior review,^2,3^ there was no effect of behavioral intervention trials on smokers (n=2,516) quitting smoking and most continued to smoke after the intervention (80.7% vs. 84.1%, RR 0.97, 95% CI, 0.93 to 1.01, I^2^=29%).^46,49,50,56,58,66,68,69,71^ One new medication trial (n=257) found no effect of NRT on smoking cessation.^74^ Behavioral interventions had a significant effect on decreasing smoking prevalence in trials that included both smokers and nonsmokers at baseline (n=10,533, 16.8% vs. 20.1%, RR 0.91, 95% CI, 0.83 to 0.995, p=0.04, I^2^=19%). However, these results were sensitive to inclusion of two trials with behavioral interventions that were less applicable to primary care. We identified no prevention, cessation, or combined prevention and cessation trials of e-cigarette use, either as a target of the intervention or as a means to smoking cessation.

Most trials were rated fair-quality, including six of the seven new trials, due to unclear allocation concealment, uncertainty about whether important baseline characteristics were similar between randomized groups, lack of blinding or not reporting blinding, and high loss to followup (Appendix B1). One new trial was rated good-quality.^74^

### Evidence

#### Prevention Interventions

The prior review^2,3^ found less smoking initiation with behavioral interventions (k=9, n=17,721, 8.8% vs. 10.4%, RR 0.81, 95% CI, 0.70 to 0.93, I^2^=38%) based on two good-quality^58,59^ and seven fair-quality trials.^48,51–53,55,66,69^ Four new, fair-quality studies of behavioral interventions were identified that reported smoking initiation.^51,57,71,75^ Table 7 provides characteristics of behavioral interventions by the four methods of delivering the intervention (i.e., face-to-face counseling, telephone counseling, print materials, and through the use of a computer).

Table 7 Behavioral Intervention Implementation Table

Mode of prevention intervention delivery | Print | Face-to-face | Telephone | Computer
Study Findings | k=8, n=18,733; RR 0.81 (95% CI, 0.70 to 0.94) | k=6, n=10,751; RR 0.91 (95% CI, 0.81 to 1.01) | k=6, n=7,501; RR 0.82 (95% CI, 0.69 to 0.96) | k=3, n=4,076; RR 0.76 (95% CI, 0.60 to 0.97)
Example Interventions^*^ | Fidler, 2001;^51^ Jackson, 2006;^60^ Hovell,1996^57^ | Hollis, 2005;^56^ Pbert, 2008^67^ | Pbert, 2008;^67^ Hollis, 2005^56^ | Redding, 2015;^69^ Hollis, 2005^56^
Intensity of Delivery | Handouts may be reinforcement of information given or sole intervention; from newsletters and stickers to children to booklets and activity guides for parents | Face-to-face may be primary means of intervention delivery or one part of intervention; ranged from 1 visit to 8 visits | Telephone counseling was never used alone but always accompanied print material or face-to-face counseling; often took the form of 1 to 4 booster calls | Computer programs were interactive or web-based as in Fun Without Smokes; use of the computer ranged from 1 use to 6 uses
Materials provided for practice^*^ | Prescriptions with preprinted anti-tobacco messages were given to the adolescents covering: tobacco-free office, tobacco advertising, tobacco and sports, smokeless tobacco, nicotine and tobacco addiction, passive smoking, tobacco and the adolescent’s teeth, and negative consequences of tobacco use.^57^ | Use of 5A model: Provider asked about smoking, advised continued abstinence and referred to peer counselor who continued the model (assess, assist, arrange followup) using motivational interviewing and behavior change counseling.^67^ | Use of 5A model: Provider asked about smoking, advised continued abstinence and referred to peer counselor who continued the model (assess, assist, arrange followup) using motivational interviewing and behavior change counseling.^67^ | Computer screenshots: Redding, 2015^69^
Primary Population | The age range for studies targeting youth only was 10 to 19 years: 10 to 19 years for print materials, 11 to 19 years for face-to-face and telephone counseling, and 10 to 17 years for computer assessment and counseling. The age range of the child in studies that targeted the parent only was 9 to 14 years for print materials and telephone counseling. There were no studies of face-to-face or computer counseling that targeted the parents only. The age range of the child in studies that targeted both the child and the parent was 7 to 12 years: 7 to 12 years for print materials, 10 to 12 years for telephone counseling; one study of face-to-face counseling did not report age range. The weighted mean ages of youth exposed to print materials was 12.9 years, to face-face-counseling was 14.8 years, to telephone counseling was 12.9 years, and to computer assessment/counseling was 13.3 years. The weight mean ages of studies targeting only the youth was 13.6 years, targeting only the parent was 12.6 years, and targeting both the youth and the parent was 10.9 years. Three studies did not report mean age of participants.
Primary Outcome | Initiation of smoking in baseline nonsmokers
Behavior change goals & techniques | Designed to prevent youth from smoking; there was no difference between trials that targeted smoking behavior only (10 trials, n=20,330, RR 0.80, 95% CI, 0.69 to 0.93) and trials that targeted other behaviors such as alcohol consumption (3 trials, n=1,370, RR 0.83, 95% CI, 0.65 to 1.07)
Duration of Interventions | Duration ranged from very brief (1 week) to 25 months; there was no difference between trials that were shorter than 12 months (6 trials, n=2,545, RR 0.82, 95% CI, 0.66 to 1.02) and trials of longer interventions (7 trials, n=19,155, RR 0.79, 95% CI, 0.66 to 0.95)
Settings of Studies | Trials occurred in primary (medical) care (2 trials, n=2,442), primary (dental) care (2 trials, n=7,738), family planning clinic (1 trials, n=379), and not in a medical setting (9 trials, n=14,490)
Target of Intervention | Interventions targeted the child, the parent or caregiver, or both; there were no differences based on whether the intervention targeted the child (7 trials, n=14,532, RR 0.82, 95% CI, 0.71 to 0.95), the parent (2 trials, n=1,340, RR 0.84, 95% CI, 0.64 to 1.09), or both (4 trials, Ns=5,828)
Evidence of effect modification | Single mode of intervention delivery (5 trials, n=6,239, RR 0.66, 95% CI, 0.53 to 0.82) vs. multiple modes (8 trials, n=15,461, RR 0.90, 95% CI, 0.82 to 0.99); ≤6 contacts (8 trials, n=11,210, RR 0.74, 95% CI, 0.64 to 0.86) vs. >6 contacts (5 trials, n=10,490, RR 0.92, 95% CI, 0.83 to 1.03); p-values in meta-regression controlling for responses in control groups are p=0.044 and p=0.032, respectively
Comparison group | Usual care, attention control, low intensity intervention, no intervention, not described
Interventionist and training required | Prevention trials used physicians or other medical providers, dentists, dental hygienists, health educators, health counselors, peer counselors, study-trained counselor, study-trained workshop leader
Reported adherence to intervention | From the 6 individual studies that reported child, parent, or counselor/educator’s adherence: 70% of students read their letters; 62% of families completed all 4 booklets; 51% to 83% of parents completed tasks, 47% of parents reported speaking with a counselor for a booster counseling call, 60% of kids read the comic book, 48% of kids watched the video; 81% of family activities completed; 67% of adolescents actually received the counseling and < 50% completed both interviews; 72% of protocol given to nonsmokers and former smokers, 84% of protocol given to nonsmokers

* We included the only 3 studies that had significant findings (Fidler, 2001;^51^, Hollis, 2005;^56^ and Jackson, 2006^60^) and the only 3 studies that provided practice materials (Hovell et al., 1996;^57^ Pbert, 2008;^67^ Redding, 2015^69^); although other studies referenced practice materials, websites were no longer active or referenced outdated modes of communication (VHS tape) or referenced material in a foreign language

Abbreviations: CI=confidence interval; RR=relative risk.

##### Characteristics of Prevention Studies

Included trials were heterogeneous in type, target, and intensity of the interventions (Table 4). All trials were conducted in the United States^48,52,55,58,59,62,66,69,71^ or in Europe (i.e., The Netherlands,^45,51,57,75^ the United Kingdom^53^). Nine trials enrolled only nonsmokers^45,51–53,55,57,59,62,75^ and five enrolled baseline smokers and nonsmokers but reported results by smoking status.^46,58,66,69,71^ Being a nonsmoker was defined as never smoking, not even one puff,^45,48,62^ never smoked or smoked one to two puffs but not in the past year,^69^ no smoking in the past 30 days,^58^ never smoked but susceptible to smoking or smoked previously but not in the past 30 days,^66^ no tobacco use in past 30 days and never used tobacco more than 100 times,^59^ smokes less than one cigarette per week,^53^ never smoked weekly or more,^71^ never smoked not even one puff or tried smoking but do not smoke anymore or stopped smoking after smoked at least once a week (or less),^51^ or was not reported.^52,55,57^

Interventions took place in primary care clinics,^58,69,71^ dental clinics,^59,66^ homes,^45,48,51–53,55,57,62,75^ and a school.^55^ The intervention that took place in a school was conducted after school hours and was not a school-based intervention. Eight trials targeted the youth to receive the intervention,^45,51,53,58,59,66,69,71^ two targeted the parent^48,75^ and four targeted both child and parent.^52,55,57,62^ Three trials targeted behaviors in addition to smoking—alcohol use,^48,55^ marijuana and other illegal drug use,^55^ sexual activity,^55^ and condom use.^71^ One trial also assessed the intervention’s effect on the proportion who initiated the use of chewing tobacco.^48^

Trials used a single mode of intervention delivery^45,51,53,55,57,62,75^ or used multiple means of delivery^48,52,58,59,66,69,71^ Print materials were used most commonly to deliver part or all of the intervention^45,48,52,53,57–59,62,75^ followed by face-to-face encounters with a counselor, health educator, or primary care medical or dental provider.^55,58,59,66,69,71^ Several trials also employed telephone support or booster calls^52,58,66,69,75^ and three trials were internet-based or used an interactive computer program.^51,58,71^ The control groups consisted of usual care,^51,52,59,69^ an attention control,^58^ a low intensity smoking intervention,^55,62,66,71,75^ no interaction,^53^ or was not described.^45,48,57^

The content of the interventions, like the methods for intervention delivery, were heterogeneous. Studies focused on: 1) increasing parental communication, support, and guidance for the adolescent (antismoking socialization);^48,52,55,57,62^ 2) providing health education on the harms of smoking;^52,53,59,66^ 3) providing messages that smoking makes one’s teeth less attractive;^59,66^ 4) describing the advantages of remaining a nonsmoker;^45,53^ 5) exposing the adolescent to nonsmoking information, animated videos, and computer games;^51^ and 6) assessing a participants readiness to act or change and providing strategies and processes to facilitate action or behavior change.^45,58,66,69,71^ One trial targeted smoking parents who received up to seven telephone calls by Dutch national quit line counselors who provided information on nicotine dependence and utilized cognitive behavioral therapy (CBT) techniques to assist parents in quitting smoking.^75^ The outcome of interest in this trial was the effect of the parent receiving the intervention and possibly quitting smoking on the child’s smoking initiation.

The duration of the interventions ranged from 7 weeks^55^ to 25 months^51^ with a mean number of six contacts, ranging from three contacts (1 visit and 2 telephone calls^58^ ^6^ or 3 mailings^45,53^) to 15 contacts (3 computer-tailored feedback messages and 6 prompt messages per year for 2 years).^51^ The duration of the prevention trials ranged from 6^45^ to 36 months.^57^ The primary smoking outcomes reported were 30-day point prevalence of smoking,^45,52,58,66^ 30-day point prevalence of any tobacco use,^59^ taken even one puff of a cigarette,^48,57,62,75^ and smoking or starting to smoke or smoking initiation.^51,53,55,69,71^

##### Characteristics of Participants in Prevention Studies

The weighted mean age of study participants was 12.8 years (the age range is unknown since not all of the trials reported the age range of those actually enrolled). Calculation of the mean age did not include one trial that enrolled 10 to 15 year olds but did not report a mean age^53^ and assumes a mean age of 7.5 years in one trial that enrolled 7 to 8 year olds.^62^ Only one study enrolled more males than females (51.4% vs. 48.6%);^55^ the weighted mean percent females was 53.9 percent (range: 48.6% to 100%). Studies enrolled primarily whites (weighted mean proportion white 77.6%, range: 7.9% to 98.3%). Three studies did not report the racial breakdown (Table 4).^52,53,75^

##### Results From Prevention Studies

Meta-analysis of the nine trials from the prior review^2,3^ and the four new trials found that behavioral interventions were associated with reduced smoking initiation at 6 months or longer compared with controls (k=13, n=21,700, 7.4% vs. 9.2%, RR 0.82, 95% CI, 0.73 to 0.92, I^2^=15%, Figure 2 and Table 8).^45,48,51–53,55,57–59,62,66,69,71,75^ Outcomes reported at 12 months were pooled when available. Eight trials provided outcomes at 12 months, and one trial each provided outcomes at 7 months,^48^ 18 months,^71^ 20 months,^52^ 24 months,^59^ and 36 months.^62^ One prevention trial (n=3,349) that could not be pooled found an out-of-school intervention (3 letters mailed to participants homes that contained smoking prevention messages) associated with a decreased likelihood of initiating smoking compared with a control group at 6 months (10.4% vs. 18.1%, p<0.05).^45^ However, this comparison included 1,068 adolescents in the intervention group who also received the school-based social influence program entitled “Don’t play with Fire.”

Figure 2 Meta-Analysis of Smoking Prevention Interventions to Reduce Smoking Initiation

NOTE: Weights are from random effects analysis

*This study reports on any tobacco use at followup, not just smoking.

Abbreviations: CI=confidence interval.

Figure 2 is a forest plot of studies reporting the relative risk of smoking at followup for prevention interventions to reduce smoking initiation compared with control groups. Data for Figure 2 are presented in Table 8. In 13 studies, the overall relative risk of smoking at followup is 0.82 (95 percent confidence interval 0.73 to 0.92). A footnote indicates that one of the thirteen studies (Hovell, 1996) reports on any tobacco use at followup, not just smoking.

Table 8 Results of Behavioral Intervention Prevention Trials

Trial, quality | Person targeted | Role of PC | Mode of intervention | Time point analyzed | % Initiating smoking at followup (IG vs. CG) | Relative risk (95% CI)
Ausems, 2002^45^; Fair | Youth | None | Print | 6 months | 10.4^*^ vs. 18.0 | NR^*^
Bauman, 2001^48^; Fair | Parent | None | Phone, print | 7 months | 17.0 vs. 21.0 | 0.81 (0.61 to 1.07)
Cremers, 2015^51^; Fair | Youth | None | Computer | 12 months | 0.59 (IG1) and 1.06 (IG2) vs. 1.02 | NR^†^
Curry, 2003^52^; Fair | Both | Recruitment only | Phone, print | 20 months | 2.4^‡^ vs. 2.3^‡^ | 1.04 (0.68 to 1.58)
Fidler, 2001^53^; Fair | Youth | Recruitment only | Print | 12 months | 5.1 vs. 7.8 | 0.65 (0.47 to 0.90)
Haggerty, 2007^55^; Fair | Both | None | Face | 12 months | 11.8^§^ vs.9.0^§^ | 1.31 (0.52 to 3.28)
Hiemstra, 2014^57^; Fair | Both | Recruitment only | Print | 12 months | 10.8 vs. 12.0 | NR^ǁ^
Hollis, 2005^58^; Good | Youth | Conducted in PC, provider delivered part | Face, computer | 12 months | 9.3 vs. 12.1 | 0.76 (0.59 to 0.99)
Hovell, 1996^59^; Good | Youth | Conducted in dental, provider delivered most | Face, print | 24 months | 12.0^¶^ vs. 12.6^¶^ | 0.95 (0.84 to 1.07)
Jackson, 2006^62^; Fair | Both | None | Print | 36 months | 11.9 vs. 19.3 | 0.62 (0.44 to 0.87)
Lando, 2007^66^; Fair | Youth | Conducted in dental, provider delivered part | Face, phone | 12 months | 9.7 vs. 16.7 | 0.58 (0.25 to 1.37)
Pbert, 2008^69^; Fair | Youth | Conducted in PC, provider delivered part | Face, phone | 12 months | 3.2 vs. 4.5 | 0.69 (0.30 to 1.58)
Redding, 2015^71^; Fair | Youth | Conducted in family planning clinics, PC not involved | Face, computer | 18 months | 8.5 vs. 7.3 | NR^**^
Schuck, 2015^75^; Fair | Parent | None | Phone, print | 12 months | 20.1 vs. 14.7 | NR^††^

* The number of baseline nonsmokers and the number of children initiating smoking at followup were not reported. The percentage of children initiating smoking at followup (as reported in the article) were 10.4% (95% CI, 6.9% to 14.0%) in the intervention group and 18.1% (95% CI, 12.5% to 23.7%) in the control group.

† Adjusted OR (age, gender, ethnicity, SES, among others for Prompt-reinforced intervention: 0.53 (95% CI, 0.12 to 2.47); No prompt-reinforced intervention: OR 1.01 (95% CI, 0.24 to 4.21).

‡ Among the assessment cohort (n=492), 2.5% of the IG and 0% of the CG reported smoking in the past 30 days at baseline. Author does not report whether baseline smokers were included in the followup.

§ At baseline, 22.0% of the IG and 21.7% of the CG reported smoking; these individuals were excluded from the analysis at followup.

ǁ ITT Adjusted OR (adjusted for parental smoking): 1.01 (95% CI, 0.82 to 1.24); adjusted for asthma: OR 0.91 (95% CI, 0.32 to 2.60); adjusted for SES: OR 1.06 (95% CI, 0.71 to 1.59).

¶ Baseline smokers were excluded from the analysis (specific numbers not reported).

** GEE analysis indicated no significant differences between groups.

†† OR 0.70 (95% CI, 0.41 to 1.20).

Abbreviations: CG=control group; CI=confidence interval; Face=face-to-face; GEE=generalized estimating equation; IG=intervention group; ITT=intention to treat; NR=not reported; PC=primary care; OR=odds ratio; SES=socioeconomic status.

Six trials not only reported outcomes at 12 months, but also reported outcomes beyond 12 months.^48^ ^26,51,55,57,58,75^ Results beyond 12 months were consistent with the 12-month findings for each trial with the exception of one trial where outcomes at 24 months were no longer statistically significant (OR 0.80, 95% CI, 0.62 to 1.03).^58^ One trial, that found no difference between the intervention and control groups at 12 months, reported significant findings at 6 months (1.8% initiated smoking vs. 3.5%, p<0.05).^69^ Additionally, one trial reported the effect of the intervention on initiation of chewing tobacco and found no differences between intervention and control groups, but very few adolescents began chewing tobacco (approximately 3% in both groups).^48^

Three of the four new prevention trials were conducted in Europe, did not take place in a medical setting, and targeted smoking behaviors only.^51,57,75^ The fourth trial was conducted in the United States in a family planning clinic, enrolled only females, and focused on condom use in addition to smoking behaviors.^71^ The duration of the interventions ranged from 3^75^ to 25 months,^51^ and involved no contact time with an interventionist^51,57^ to up to seven telephone counseling sessions.^75^ Two trials targeted the youth,^51,71^ one targeted the parent,^75^ and one targeted both child and parent.^57^ None of these trials individually demonstrated a treatment effect (RRs 0.61 to 1.08).

Three individual trials (total n=4,923) from the prior review^2,3^ demonstrated significant effects of the intervention in the pooled analysis (RRs 0.62 to 0.76).^53,58,62^ The trials focused solely on smoking behavior and all interventions were 12 months in duration. One trial was conducted in pediatric and family medicine clinics and involved approximately 15 minutes of contact with a health counselor in addition to the use of an interactive computer program, print materials, and two telephone booster calls.^58^ The other two trials limited the intervention to print materials.^53,62^

Exploratory meta-regression of multiple study-level characteristics were conducted (Appendix C1) and results consistently demonstrated that no variable or group of variables predicted the magnitude of the intervention effect for prevention trials. Results were similar with stratified analyses (Appendix C2). That is, results from trials conducted in the United States were similar to those conducted in Europe; trials employing face-to-face counseling had similar findings as those that did not; and prevention only trials had similar results as trials that combined prevention and cessation interventions. The only exceptions were the unexpected findings that trials that used a single mode of delivering the intervention were more likely to report less smoking initiation than trials that employed multiple methods and that trials with fewer contacts with the participant (e.g., visits, telephone calls, mailings) were more likely to demonstrate an intervention effect than did trials with more contacts. However, the meta-regression was limited by few studies and the significance of these findings are unclear.

#### Cessation Interventions

##### Behavioral Intervention Trials

The prior review^2,3^ included seven trials that enrolled smokers.^46,49,50,58,66,68,69^ Pooled analysis of the seven trials found no effect of the behavioral intervention (n=1,882, RR 0.96, 95 percent CI, 0.90 to 1.02) based on two good-quality^46,49,50,58,66,68,69^ and five fair-quality studies.^46,49,50,58,66,68,69^ Two new, fair-quality cessation trials were identified for this update review (n=634).^56,71^

##### Characteristics of Cessation Interventions in Behavioral Trials

Similar to the prevention studies, cessation trials were also heterogeneous in study design (Table 5). All trials were conducted in the United States,^46,49,50,58,66,68,69,71^ except for one trial that was conducted in Switzerland.^56^ Four behavioral trials enrolled only smokers^49,50,56,68^ and the remainder enrolled both smokers and nonsmokers but reported results by smoking status.^46,58,66,69,71^ Being a smoker was generally defined as smoking at least one cigarette in the past 30 days.^46,58,66,68^ Other definitions included daily smoking in the past 30 days,^49^ weekly smoking in the past 30 days,^50^ or smoked at least weekly and still smoking.^71^ One study did not define what being a “smoker” constituted.^56^

The trials were conducted in primary care clinics,^58,69,71^ a school health clinic,^68^ a dental clinic,^66^ and homes.^46,56^ The location was not specified in two trials.^49,50^ Seven trials targeted the youth,^49,56,58,66,68,69,71^ one targeted the parent, ^46^ and one targeted both child and parent.^50^ Two trials targeted behaviors in addition to smoking: alcohol use^46^ and condom use.^71^

Two trials employed one method of delivering the intervention^56,68^ while the other utilized multiple means of intervention delivery.^46,49,50,58,66,69,71^ Face-to-face counseling was used the most often,^49,50,58,66,68,69,71^ followed by telephone counseling.^49,50,58,66,69^ One trial sent text messages to participants,^56^ four trials made use of print materials,^46,49,50,58^ and two trials used a computer to deliver part of the intervention.^58,71^ The control groups consisted of usual care,^69^ an attention control,^58^ a low intensity smoking intervention,^49,50,66,68,71^ an assessment only group,^56^ or was not described.^46^ Most trials assessed the adolescent’s readiness to stop smoking and provided strategies and processes to facilitate behavior change.^49,50,56,58,66,68,69,71^ Other behavioral intervention strategies included focusing on increasing parental communication, support, and guidance for the adolescent (antismoking socialization);^46^ providing health education on the harms of smoking;^49,50,66,68^ and providing messages that smoking makes one’s teeth less attractive.^66^

The duration of the intervention ranged from 1 week^49^ to 12 months^58^ with a median of four contacts and a range of two contacts (1 visit and 1 booster call)^49^ to 66 contacts (all text messages, including 11 assessment messages).^56^ The duration of the cessation trials with behavioral interventions ranged from 6^49,50,56^ to 24 months.^58^ Smoking outcomes included 30-day point prevalence of smoking,^46,49,58,66,68^ 7-day point prevalence of smoking,^49,50,56^ or was not reported.^69,71^

##### Characteristics of Participants in Cessation Trials of Behavioral Interventions

Whereas the weighted mean age in prevention trials was 12.8 years, the average age of participants in cessation trials was much older at 16.6 years. All but two studies enrolled more females than males^49,68^ and one trial enrolled only females.^71^ The weighted mean proportion of females was 54 percent (range: 47.5% to 100%). Similar to the prevention trials, more whites than nonwhites were enrolled (weighted mean proportion of whites 84.4%, range 7.9% to 92.6%). One trial, conducted in Switzerland, did not report racial breakdown (Table 5).^56^

##### Results for Cessation Studies of Behavioral Interventions

Similar to the prior review^2,3^ meta-analysis of the nine cessation trials found that behavioral interventions to quit smoking were not associated with less smoking post intervention when compared with controls (n=2,516, 80.6% vs. 84.1%, RR 0.97, 95% CI, 0.93 to 1.01, I^2^=29%, Figure 3 and Table 9).^46,49,50,56,58,66,68,69,71^ Four trials reported outcomes at 12 months,^58,66,68,69^ three at 6 months,^49,50,56^ and one trial each at 7 months^48^ and 18 months.^71^ Two trials provided data beyond 12 months,^46,58^ and had similar findings as those reporting at 12 months. One trial that found no intervention effect at 12 months reported significantly less smoking at 6 months compared with usual care (63.6% still smoking vs. 75.4%, p<0.05).^69^

Figure 3 Meta-Analysis of Smoking Cessation Behavioral Interventions Effect on Quitting

NOTE: Weights are from random effects analysis

Abbreviations: CI=confidence interval.

Figure 3 is a forest plot of studies reporting the relative risk of smoking at followup for cessation behavioral interventions effect on quitting compared with control groups. Data for Figure 3 are presented in Table 9. In 9 studies, the overall relative risk of smoking at followup is 0.97 (95 percent confidence interval 0.93 to 1.01).

Table 9 Results of Cessation Trials

Trial, quality | Role of PC | Mode of intervention | Time point analyzed | Definition of smoker at baseline | % Smoking at followup (IG vs. CG) | % Quitting at followup (IG vs. CG) | Relative risk (95% CI)
Bauman, 2000^46^; Fair | None | Phone, print | 7 months | Smoked [underlined: ≥]1 days in past 30 days | 59.5 vs. 62.5 | 40.5 vs. 37.5 | 0.95 (0.67 to 1.34)
Colby, 2005^49^; Fair | Recruitment only | Face, phone, print | 6 months | Daily smoking for the past 30 days | 76.5 vs. 97.1 | 23.5 vs. 2.9 | 0.79 (0.65 to 0.96)
Colby, 2012^50^; Fair | Recruitment only | Face, phone, print | 6 months | Smoked [underlined: ≥]1 time a week for past 30 days | 95.1 vs. 97.2 | 4.9 vs. 2.8 | 0.98 (0.91 to 1.05)
Haug, 2013^56^; Fair | None | Text messaging | 6 months | Daily or occasional cigarette smoking (≥4 cigarettes in preceding month and ≥1 cigarette in preceding week) | 87.5 vs. 90.4 | 12.5 vs. 9.6 | NR^*^
Hollis, 2005^58^; Good | Conducted in PC, provider delivered part | Face, computer | 12 months | Smoked [underlined: ≥]1 cigarettes in past 30 days | 67.5^†^ vs. 76.8^†^ | 32.5^†^ vs. 23.2^†^ | 0.88 (0.79 to 0.97)
Lando, 2007^66^; Fair | Conducted in dental, provider delivered part | Face, phone | 12 months | Smoked in past 30 days | 93.4 vs. 88.9 | 6.6 vs. 11.1 | 1.05 (0.94 to 1.17)
Pbert, 2008^69^; Fair | Conducted in PC, provider delivered part | Face, phone | 12 months | Smoked occasionally or regularly | 74.4 vs. 72.4 | 25.6 vs. 27.6 | 1.02 (0.75 to 1.38)
Pbert, 2011^68^; Good | None | Face | 12 months | Smoked in past 30 days and interested in quitting in next 2 weeks | 84.8 vs. 85.7 | 15.2 vs. 14.3 | 0.99 (0.93 to 1.05)
Redding, 2014^71^; Fair | Conducted in family planning clinics, PC not involved | Face, Computer | 18 months | Ever smoked more than weekly | 71.1 vs. 76.7 | 28.9 vs. 23.3 | NR^‡^
Killen, 2004^65^; (medication); Fair | None | Face | 6 months | Smoked [underlined: ≥]10 cigarettes per day, smoked [underlined: ≥]6 months, had made one or more failed quit attempts, and scored [underlined: ≥]10 on mFTQ | 87.5 vs. 90.0 | 12.5 vs. 10.0 | 0.97 (0.86 to 1.10)
Muramoto, 2007^67^; (medication); Fair | None | Face | 6 months | Smoked ≥6 cigarettes per day, had an exhaled CO level [underlined: ≥]10 ppm, and had at least 2 previous quit attempts and motivated to quit; excluded those using other tobacco products | 93.8 vs. 89.7 | 6.3 vs. 10.3 | 1.05 (0.94 to 1.16)
Scherphof, 2014^74^; (medication); Good | None | Face | 12 months | Smoked ≥7 cigarettes per day, parent aware of smoking behavior, and motivated to quit smoking | 95.6 vs. 93.4 | 4.4 vs. 6.6 | NR^§^

* OR 1.03 (95%CI, 0.59 to 1.79); 4-week abstinence: 6.3% vs. 5.5%; OR 0.97 (95%CI, 0.50 to 1.90).

† Includes self-described experimenters and smokers.

‡ GEE analysis indicated no difference between groups.

§ Adjusted OR (gender, compliance, interaction of compliance and group, and other variables significantly correlated with smoking cessation in the study: 1.13 (95% CI, 0.17 to 7.44).

Abbreviations: CG=control group; CI=confidence interval; CO=carbon monoxide; Face=face-to-face; IG=intervention group; ITT=intention to treat; Med=medication; mFTQ=modified Fagerström Tolerance Questionnaire; NR=not reported; OR=odds ratio; PC=primary care.

Of the two new trials, one trial was conducted in a U.S. family planning clinic and was also a prevention trial,^71^ while the other was conducted in Switzerland and consisted of text messages sent to vocational students at least three times a week over 3 months.^56^ Text messages included a review of outcome expectations, social support, and tips for coping with cravings. Having an intention to quit smoking was not an inclusion criterion for this trial. Neither of the new trials demonstrated a significant treatment effect (RR1.06, 95% CI, 0.84 to 1.33^71^; RR 0.97, 95% CI, 0.91 to 1.03^56^).

The two trials from the prior review that did demonstrate a treatment effect (RR 0.79, 95% CI, 0.65 to 0.96;^49^ RR 0.88, 95% CI, 0.79 to 0.97^58^) were conducted in the United States and targeted the youth or young adult.^49,58^ One trial was also a prevention trial,^58^ conducted in primary care, and involved 15 minutes of motivational interviewing with a health counselor supplemented with handouts, a session with an interactive computer program, and two booster calls.^58^ The other trial limited the role of primary care to recruitment only and consisted of one visit plus one booster call within 1 week.^49^ Most patients in this trial (81%) had no immediate plans to quit smoking.

Exploratory meta-regression of multiple study-level characteristics in cessation trials were conducted (Appendix C1) and results consistently demonstrated no ability of any variable or group of variables to predict the magnitude of the intervention effect for cessation trials. Results were similar with stratified analyses (Appendix C3).

In one trial, post hoc analysis of baseline smokers found that the intervention effect was greater among nonwhite adolescents (OR 4.10, 95% CI, 1.01 to 16.71) compared with white adolescents (OR 2.16, 95% CI, 1.14 to 4.08), although this difference was not statistically significant.^58^ Also, in one study of a school nurse-delivered, patient-centered counseling program, the school nurse met with adolescent smokers for four individual sessions (2 to 20 minute sessions before the quit smoking date and 2 to 15 minute sessions after the quit date) over 1 month.^68^ Although there was a significant effect of the intervention at 3 months among males (no effect was seen among females), this was not seen at 12 months. The lack of intervention effect could be due to the intensity of the attention control condition. Adolescents assigned to the attention control group also met with the school nurse for four weekly visits. In addition, control adolescents were asked about smoking status and given an anti-smoking informational pamphlet each visit.

##### Medication Intervention Trials

Two fair-quality medication trials^65,67^ from the prior review^2,3^ evaluated the use of bupropion slow release (SR) in addition to behavioral counseling to encourage smokers to quit smoking (Table 5). No new trials of bupropion for smoking cessation in adolescents were identified for the update. One new, good-quality trial of NRT, in addition to a short behavioral intervention, on quitting smoking in children aged 12 to 18 years was identified.^74^ The three medication trials were relatively small (n range: 211 to 312), recruited from schools, used placebo as a control, included a 6-month followup assessment, and enrolled adolescents who were motivated to quit smoking^74^ or who had at least one ^65^ or two previous quit attempts.^67^ One trial recruited through the media and various community venues (e.g., shopping malls, doctors’ offices), as well as from schools.^67^ One trial included outcomes at 12 months, as well as at 6 months.^74^

The new NRT trial was conducted in the Netherlands and enrolled 265 adolescents, who smoked at least seven cigarettes per day and were randomized to receive NRT or a placebo patch.^74^ Those who smoked less than 20 cigarettes per day at baseline received the patch for 6 weeks (3 weeks at 14 mg/day followed by 3 weeks at 7 mg/day) and those who smoked more than 20 cigarettes per day at baseline received the patch for 9 weeks (3 weeks at 21 mg/day then 3 weeks at 14 mg/day then 3 weeks at 7 mg/day). All participants also received a behavioral intervention that consisted of a 75-minute information meeting covering preparation and expectations of quitting smoking and instructions on using NRT. Smoking cessation was defined as 30-day point prevalence abstinence at 6 and 12 months. Although NRT was associated with increased smoking cessation at the end of treatment among highly compliant adolescents (adjusted OR [AOR] 1.09, 95% CI, 1.01 to 1.17),^74^ there was no effect after 6 months or 12 months among all participants (6 months: 8.1% vs. 5.7%, AOR 2.09, 95% CI, 0.20 to 22; 12 months: 8.1% vs. 8.2%, AOR 1.13, 95% CI, 0.17 to 7.44) or among only the more compliant youth (AOR 0.99, 95% CI, 0.91 to 1.07; AOR 0.99, 95% CI, 0.92 to 1.07, respectively, Table 9).^74^

Both trials of bupropion SR were conducted in the United States. One trial compared bupropion SR 150 mg and placebo,^65^ while the other compared bupropion SR 150 mg, 300 mg, and placebo.^67^ The three armed trial included 14 to 17 year olds who smoked six or more cigarettes per day, and in addition to bupropion SR 150 mg, 300 mg, or placebo, participants received 10 to 20 minutes of standardized individual cessation counseling. There were several time points when self-reported smoking abstinence with bupropion 300 mg was greater than with placebo (i.e., at weeks 1, 3, 5, and 6 after the target quit date). However, at the 26-week followup, quit rates in the 300 mg, 150 mg, and placebo groups were not significantly different from each other at 17 percent, 6 percent, and 10 percent, respectively (Table 9).

The other bupropion trial^65^ included 15 to 18 year olds who smoked at least 10 cigarettes per day and in addition to bupropion 150 mg or placebo, participants also received NRT (dose based on number of cigarettes smoked per day) for 8 weeks and weekly group skills training designed to facilitate not smoking in high-risk situations. At week 26, self-reported abstinence rates were 24 percent with bupropion plus NRT versus 28 percent in the group that received placebo plus NRT and provided no evidence for a treatment effect. However, compliance in this trial was not high. At week 5, only 39 out of 103 participants had evidence of bupropion in their urine (38%) and only 22 percent reported taking all of their bupropion pills (Table 9).

#### Combined Prevention and Cessation Interventions

Two good-quality trials^58,76^ and five fair-quality behavioral trials^47,64,66,69,70^ from the prior review^2,3^ and two new fair-quality behavioral trials^71,72^ included both smokers and nonsmokers. Four combined trials reported only prevalence of smoking at postintervention.^64,70,72,76^ The remaining five trials reported results by smoking status and are also included as prevention and cessation trials.^47,58,66,69,71^

##### Characteristics of Combined Studies

Most trials were conducted in the United States,^47,58,66,69–71,76^ one trial was conducted in the United Kingdom,^72^ and one trial was conducted in Finland (Table 6).^64^ The intervention took place in primary care medical clinics,^58,69,71,76^ dental clinics,^64,66^ and at homes.^47,70,72^ Six trials targeted the youth to receive the intervention,^58,64,66,69,71,72^ two targeted the parent ^47,70^ and one targeted both the child and parent.^76^

Trials used a single mode of intervention delivery^64,70,72^ or used multiple means of delivery.^47,58,66,69,71,76^ Face-to-face counseling was used most frequently to deliver part or all of the intervention^58,64,66,69–72^ followed by telephone counseling or booster calls.^58,66,69,76^ Print materials were used to deliver the intervention in three trials^47,58,76^ and two trials used a computer to deliver part of the intervention.^58,71^ The control groups consisted of usual care,^64,69,72^ an attention control,^58,70,76^ a low intensity smoking intervention,^66,71^ or was not described.^48^ The content of the interventions included a focus on assessing a participant’s readiness to act or change and providing strategies and processes to facilitate action or behavior change;^58,66,69,71,72^ increasing parental communication, support, and guidance for the adolescent;^47,70,76^ providing health education on the harms of smoking;^66,76^ and providing messages that smoking makes one’s teeth less attractive.^64,66^

The duration of the intervention ranged from 15 weeks^47^ to 36 months^76^ with a median of 10 contacts, ranging from two contacts (2 dental visits)^64^ to a mean of 39 nurse home visits.^72^ The duration of the combined trials ranged from 6 ^66^ to 36 months.^70,76^ The primary smoking outcomes were 30-day point prevalence of smoking,^58,66^ ever smoked at posttest,^76^ taken even one puff of a cigarette,^48^ smoked in the past 90 days,^70^ smoking at late pregnancy,^72^ and smoking or starting to smoke/smoking initiation.^64,69,71^

##### Characteristics of Participants in Combined Studies

The weighted mean age of study participants was 14.0 years. Only one study enrolled more males than females (51.4% vs. 48.6%);^55^ the weighted mean percent females was 58.6 percent (range: 48.3% to 100%). Two studies enrolled only female adolescents or young adults.^71,72^ Studies enrolled primarily whites (weighted mean proportion white 73.2%, range: 0 to 91.4%). One trial enrolled only Hispanic adolescents^70^ and one trial enrolled over 84 percent black adolescents.^71^ Two studies did not report the racial breakdown (Table 6).^64,76^

##### Results From Combined Studies

The prior review^2,3^ found no difference in smoking prevalence at followup between adolescents in the intervention groups compared with the control groups in a pooled analysis of six trials (n=6,838, RR 0.91, 95% CI, 0.81 to 1.01). One combined trial did not provide adequate data for inclusion in the prior meta-analysis.^76^ New statistical techniques now enable an estimate of the effect size to be calculated.^79^ Findings from pooled analysis including all nine trials were similar to those from the prior review (n=11,471, 20.3% vs. 23.5%, RR 0.93, 95% CI, 0.86 to 1.01, I^2^=24%, Figure 4 and Table 10). Sensitivity analysis removing the study with estimated results^76^ yielded similar, nonsignificant intervention effects (n=7,501, RR 0.92, 95% CI, 0.85 to 1.01). Two trials, that combined smokers and nonsmokers, employed extremely intensive interventions that were quite different from the remaining trials and may not be available for referral from primary care.^70,72^ A sensitivity analysis removing these two trials that provided 49 contact hours over 12 months,^70^ and 64 nurse visits over more than 24 months,^72^ resulted in a borderline significant estimate of effect (n=10,533, 16.8% vs. 20.1%, RR 0.91, 95% CI, 0.83 to 0.995, p=0.04, I^2^=19%, Figure 5). This change in the effect estimate is likely multifactorial due to the sizable heterogeneity in study design and populations enrolled.

Figure 4 Meta-Analysis of Combined Interventions Effect on Tobacco Use

NOTE: Weights are from random effects analysis

Abbreviations: CI=confidence interval.

Figure 4 is a forest plot of studies reporting the relative risk of smoking at followup for combined prevention and cessation interventions effect on tobacco use compared with control groups. Data for Figure 4 are presented in Table 10. In 9 studies, the overall relative risk of smoking at followup is 0.93 (95 percent confidence interval 0.86 to 1.01).

Figure 5 Sensitivity Analysis of Combined Interventions Effect on Tobacco Use^*^ * Removed 2 trials of intensive interventions^68,70^

NOTE: Weights are from random effects analysis

^†^ Effect significance: p=0.04

Abbreviations: CI=confidence interval.

Figure 5 is a forest plot of studies reporting the relative risk of smoking at followup for combined prevention and cessation interventions effect on tobacco use compared with control groups. Data for Figure 4 are presented in Table 10. In 7 studies, the pooled relative risk of smoking at followup is 0.91 (95 percent confidence interval 0.83 to 1.00). A footnote indicates that 2 trials of intensive interventions (references 68 and 70) were removed from the analysis. Another footnote indicates that the effect significance is a p-value equal to 0.04.

Table 10 Results of Combined Primary Prevention and Cessation Behavioral Intervention Trials

Trial, quality | Targeted multiple behaviors | Person targeted | Role of PC | Mode of intervention | Time point analyzed | % Smoking at baseline (IG^*^ vs. CG^*^) | % Smoking at followup (IG^†^ vs. CG^†^) | Relative risk (95% CI)
Bauman, 2002^47^; Fair | Yes | Parent | None | Phone, print | 7 months | 19.3^‡^ vs. 24.8^‡^ | 36.0 vs. 43.0 | 0.84 (0.72 to 0.97)
Hollis, 2005^58^; Good | No | Youth | Conducted in PC, provider delivered part | Face, computer | 12 months | 23.3^§^ vs. 23.4^§^ | 22.8 vs. 27.2 | 0.84 (0.73 to 0.96)
Kentala, 1999^64^; Fair | No | Youth | Conducted in dental, provider delivered most | Face | 12 months | 5.5 vs. 6.0 | 13.3 vs. 12.2 | 1.09 (0.87 to 1.36)
Lando, 2007^66^; Fair | No | Youth | Conducted in dental, provider delivered part | Face, phone | 12 months | 34.9^‡^ vs. 37.3^‡^ | 48.1 vs. 47.6 | 1.01 (0.79 to 1.29)
Pbert, 2008^69^; Fair | No | Youth | Conducted in PC, provider delivered part | Face, phone | 12 months | 8.7 vs. 10.6 | 9.4 vs. 11.7 | 0.80 (0.50 to 1.26)
Prado, 2007^70^; Fair | Yes | Parent | None | Face | 12 months | 3.3 vs. 1.2 | 7.6 vs. 4.0 | 1.90 (0.49 to 7.32)
Redding, 2015^71^; Fair | Yes | Youth | Conducted in family planning clinics, PC not involved | Face, computer | 18 months | 18.4^‡^ vs. 22.3^‡^ | 20.6^‡^ vs. 22.4^‡^ | NR^ǁ^
Robling, 2016^72^; Fair | No | Youth | Home visits by nurse | Face | 24 months (postpartum) | 56 vs. 58 | 56 vs. 56 | 0.90 (0.64 to 1.28)
Stevens, 2002^¶,76^; Good | Yes | Both | Conducted in PC, provider delivered part | Face, phone, print | 12 months | 5.3^‡^ vs. 4.5^‡^ | NR | NR^**^

* Among those randomized.

† Among those analyzed at followup.

‡ Calculated based on presented data.

§ Calculated based on data requested from the author.

ǁ GEE analysis indicated no difference between groups.

¶ Not included in meta-analysis.

** The adjusted OR for having ever smoked for the intervention group compared with the control group was 1.05 (95% CI, 0.80 to 1.39).

Abbreviations: CG=control group; CI=confidence interval; Face=face-to-face; GEE=generalized estimating equation; IG=intervention group; ITT=intention to treat; NR=not reported; OR=odds ratio; PC=primary care.

The new intensive, combined trial, enrolled 1,645 nulliparous women in early pregnancy in the United Kingdom who were 19 years or younger (mean age: 17.9 years, range: 16.9 to 18.8 years).^72^ This trial was also discussed in Key Question 1. The intensive intervention (FNP) consisted of up to 64 structured nurse visits to participants’ homes beginning in pregnancy until the child turned 2 years old in addition to usual care. The control intervention was usual care, which consisted of publically funded health care and social care. Self-reported tobacco use in late pregnancy was a primary outcome and occurred with similar frequency in both groups (304/547 with the intervention, 306/545 with usual care; 56% in both groups). Smoking status was verified by urine cotinine level. Trial authors suggest that the level of care routinely available to teenage mothers in the United Kingdom is higher than that in the United States and that this extra support may have diluted any effect of the FNP Program.

The other new trial was included in the previous sections on prevention and cessation; it also enrolled only female adolescents, was conducted in a family planning clinic, and the intervention consisted of completing a smoking module on a computer and up to four counseling sessions with a bachelors or masters level counselor.^71^ Neither of these trials demonstrated an individual treatment effect (RR 0.86 and RR 0.99).

Two individual trials from the prior review^2,3^ enrolled both smokers and nonsmokers and demonstrated a significant treatment effect on reducing smoking at followup (RR 0.84 both trials).^47,58^ One trial discussed previously, was conducted in primary care, targeted the adolescent with a brief clinician message along with a computer assessment, a motivational interview conducted by health counselors, and two booster phone calls.^58^ The only other combined trial with significant findings, targeted parents and included four activity books followed by four phone calls by health educators over 15 weeks.^47^

Meta-regression analyses identified the duration of the intervention, in weeks, as the only variable that predicted intervention response in the combined trials, with greater intervention effects seen with shorter intervention durations (p=0.047). However, after adjusting for the response in the control groups, statistical significance was lost (p=0.053, Appendix C1). Stratified analyses of intervention duration (using a 12-month cutoff) also did not demonstrate a significant effect (Appendix C4).

## Key Question 3 What Adverse Effects Are Associated With Primary Care Interventions to Prevent Tobacco and Nicotine Use or Improve Tobacco and Nicotine Cessation Rates in Children and Adolescents?

### Summary

We included all 26 trials for this key question (22 behavioral-based intervention trials, and 4 trials of medications for smoking cessation). Five trials were rated good-quality^58,59,68,74,76^ and the remainder were rated fair-quality. As in the prior review^2,3^ new trials of behavioral interventions did not report any specific harms. The prior review reported harms of the three bupropion trials.^54,65,67^ One new trial of NRT also reported harms.^74^ Of the four medication trials, no serious adverse events occurred that were attributed to the study medication. We identified no trials of e-cigarette use in children and/or adolescents.

### Evidence

None of the 22 behavioral intervention trials reported adverse events or harms associated with the intervention. Nine trials reported greater percentages of smoking in the intervention group than control group after the intervention (RRs 1.01 to 1.90).^52,55,64,66,69–71,75,76^ However, this difference between the intervention and control groups was generally small (RRs less than 1.10). In the trial with the greatest RR (1.90, 95% CI, 0.49 to 7.32), the effect estimate was imprecise due to the small sample size and few total adolescents smoking at 12 months (n=9 out of 154 participants). In no prevention, cessation, or combined trial was the proportion smoking in the intervention group significantly greater than that in the control group.

Four medication trials reported harms; three bupropion trials^54,65,67^ from the prior review^2,3^ and one new NRT trial.^75^ All medication trials were small (n range: 134 to 257). The new trial of NRT reported that participants in the NRT group reported more headaches, cough, abnormal dreams, muscle pain, and patch related adverse events (p<0.05) compared with participants in the placebo patch group who reported more sleeplessness (p<0.01).^74^ Itchiness was a common complaint in patients regardless of treatment group. No serious adverse events were reported.

In one of the bupropion trials, eight patients discontinued the study drug due to adverse events: feeling depressed, irritable, angry, having sleep disturbances, headaches, urticarial, anxiety, palpitations, attempted suicide, anticholinergic crisis attributed to recreational drug use, and pregnancy.^67^ The number who left due to adverse events in the placebo group was not reported. Two serious adverse events were reported (one due to an ingestion of Jimson weed for recreational purposes and the other an attempted suicide with an intentional overdose of bupropion along with other drugs and alcohol) but neither were attributed to the study medication.^67^ In a separate publication of this trial, body mass index (BMI) changes associated with bupropion treatment were examined to see if quitting smoking with this medication led to weight increases sometimes associated with quitting smoking. There was no increase in BMI, either among those who achieved smoking abstinence or those who did not.^80^ Although participants randomized to 300 mg of bupropion experienced a decrease of 0.16 BMI z-score at 6 weeks compared with placebo (p=0.01), this effect was not maintained at 26 weeks (BMI z-score increase 0.05, p=0.50).

In the second trial of bupropion, where all participants also received NRT by patch, the total number of participants who experienced an adverse event, serious adverse event, or left the study due to an adverse event was not reported.^65^ None of the adverse events that were reported (e.g., nausea, rash, weakness) were judged to be serious and there were no significant elevations in blood pressure.

In the third trial of bupropion, adverse events were reported after only 12 weeks, so this trial did not meet inclusion criteria for efficacy but is included here for harms.^54^ In this study 76 of the 134 participants (57%) experienced at least one adverse event, with no significant differences between intervention and control groups. Headaches and dream disturbances were common with bupropion, with all of the nine instances of dream disturbances being associated with bupropion. Three participants (4.1%) in the bupropion groups (with and without contingency management) and three participants (4.9%) in the placebo groups (with and without contingency management) withdrew from the study due to adverse events.

## Contextual Question 1 What Is the Relationship Between Use of E-Cigarettes and Use of Other Tobacco Products?

As mentioned in the introduction, the most commonly cited reasons for use of e-cigarettes among youth (and young adults) were curiosity, flavoring, and low perceived harm relative to regular tobacco products.^23^ A 2018 report on Public Health Consequences of E-cigarettes, by the National Academies of Science, Engineering, and Medicine (NASEM) contained a section on smoking among youth and young adults (up to 29 years), focused on whether there were differences in patterns of cigarette use between those who were e-cigarette users versus those who were not.^10^ The report included one systematic review of nine studies (n=16,621) evaluated the association of having ever used e-cigarettes among those who had never smoked a cigarette at baseline with those who had ever smoked a cigarette at followup.^81^ Pooled analysis of the seven studies examining smoking initiation demonstrated increased initiation of cigarette smoking associated with e-cigarette use (23.2% for those who had ever used an e-cigarette vs. 7.2% for those who had never used an e-cigarette, AOR 3.5; 95% CI, 2.38 to 5.16). Findings were similar among adolescents and young adults in a study of 2,588 18 to 25 year olds published since the systematic review.^82^ The use of e-cigarettes was associated with increased initiation of cigarette smoking compared with never having used e-cigarettes (AOR 1.36, 95% CI, 1.01 to 1.83). Past 30-day use of e-cigarettes was also associated with increased past 30-day use of cigarettes based on a pooled analysis of two studies (n=2,084, AOR 4.28, 95% CI, 2.52 to 7.27). Four additional studies (n=5,976), not included in the systematic review’s meta-analysis,^81^ examined cigarette initiation at 4 months to 1 year followup.^83–86^ All studies found a significantly increased risk in initiation of cigarette smoking in adolescents who had used e-cigarettes, consistent with the systematic review.^83–86^ One study found that having ever smoked a cigarette was associated with an increased risk of initiation of e-cigarettes (OR 3.69, 95% CI, 1.88 to 7.23).^85^

There is also evidence that the frequency of e-cigarette use is associated with the frequency of cigarette smoking based on findings from one study (n=1,070).^87^ The AOR for one or two instances of e-cigarette use was 2.88 (95% CI, 1.96 to 4.22) compared with AOR 4.17 (95% CI, 2.03 to 8.57) for monthly or yearly use. Another study (n=3,084) published after the systematic review^81^ examined the frequency and intensity of e-cigarette use in the past 30 days and its association with the frequency and intensity of combustible tobacco products during the same time period in adolescents and young adults.^88^ The odds of smoking frequency and intensity were both increased with increased vaping levels (OR 1.37, 95% CI, 1.16 to 1.61; OR 1.26, 95% CI, 1.07 to 1.48), suggesting a dose response relationship. Another study also found a similar positive association between initial e-cigarette use frequency and smoking use frequency and intensity at 12 months followup.^89^ The findings with regard to frequency were not significant but the analysis of intensity found a 13 percent increase in total cigarettes smoked for each category increase in initial e-cigarette use (e.g., going from 1 to 3 uses in 6 months to monthly use), (incidence rate ratio [IRR] 1.13%, 95% CI, 1.06 to 1.11). An additional study found an increase in initiation of conventional smoking among adolescents who escalated their e-cigarette use compared with those who maintained their e-cigarette use, over 4 to 6 months (AOR 7.89, 95% CI, 3.06 to 20.38).^85^ The same study also found the risk of initiation of e-cigarettes was increased among adolescents who smoked conventional cigarettes and who escalated their smoking compared with those who maintained their smoking usage, over 4 to 6 months (AOR 5.79, 95% CI, 2.55 to 13.15).

Overall, these additional studies suggest that not only is the use of e-cigarettes in adolescents and young adults associated with increased risk for using combustible tobacco, the degree of e-cigarette use is likely also associated with increased frequency of smoking and number of cigarettes smoked. These risks are in addition to the youth-specific harms of e-cigarette use, namely nicotine addiction and harm to the developing brain.

One study also suggests that the risk of initiating e-cigarette use is increased among conventional cigarette smoking adolescents. It should be noted that, although studies of e-cigarette use in adolescents for smoking cessation were excluded from this review, the searches would have captured these studies, but none were identified.