# Chapter 2 Methods

## Key Questions and Analytic Framework

The Pacific Northwest Evidence-based Practice Center (EPC) and the USPSTF worked together to determine the scope, key questions, and analytic framework for this review using established methods.^43^ Figure 1 outlines the analytic framework.

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts the pathway children and adolescents may go through to prevent and/or stop tobacco and/or nicotine use. Children and adolescents are assessed for tobacco and/or nicotine use, may undergo prevention and/or cessation interventions that may lead to prevention and/or cessation of tobacco or nicotine use and secondary health outcomes (respiratory health, dental/oral health, and cardiovascular health) and adult tobacco or nicotine use. Interventions may also lead to harms.

### Key Questions

1. Do primary care interventions to prevent tobacco and nicotine use or improve tobacco and nicotine cessation rates in children and adolescents improve health outcomes (i.e., respiratory, dental, cardiovascular, and oral health) and reduce the likelihood of tobacco or nicotine use in adulthood?
2. Do primary care interventions prevent tobacco and nicotine use or improve tobacco and nicotine cessation rates in children and adolescents?
3. What adverse effects are associated with primary care interventions to prevent tobacco and nicotine use or improve tobacco and nicotine cessation rates in children and adolescents?

### Contextual Questions

One Contextual Question was also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. What is the relationship between use of e-cigarette and use of other tobacco products?

## Search Strategies

A research librarian searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews, Ovid MEDLINE, PsycINFO, and EMBASE (through June 25, 2019) for relevant English-language studies, systematic reviews, and meta-analyses. Searches included studies published in September 2012 to the present to update tobacco use, however searches were not limited by date for e-cigarette use, or for prevention of tobacco use in the young adult population (19 to 25-year olds). Surveillance was conducted through February 7, 2020. Search strategies are available in Appendix A1. Search terms included “tobacco, smoking, cigarettes, electronic cigarettes, e-cigarettes, nicotine, and electronic nicotine delivery system,” among other terms. Investigators also reviewed reference lists of relevant articles to identify studies.

## Study Selection

We selected studies based on the inclusion and exclusion criteria developed for each key question (Appendix A2). After an initial dual review of citations and abstracts, investigators retrieved full-text articles of potentially relevant material. Two reviewers conducted full-text review of articles and discrepancies were resolved through consensus or with input from a third reviewer. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

For Key Questions 1 and 2, we included randomized and nonrandomized controlled trials of children and adolescents with a minimum of 6 months (or 24 weeks) of followup postbaseline. We included comparative observational studies along with randomized and nonrandomized controlled trials to describe potential harms of interventions (Key Question 3).

Intervention trials designed to prevent tobacco use in children or adolescents, or trials that promoted the cessation of tobacco use published since the search of the last review (September 2012) were eligible for inclusion. Included interventions were primary care-relevant behavioral counseling interventions (e.g., face-to-face individual and/or group counseling, telephone or technology-based counseling; text-messages; interactive websites), pharmacotherapy (i.e., NRT, bupropion, or varenicline tartrate), and complementary and alternative medicine interventions (e.g., acupuncture and hypnosis). We included trials that targeted parents or caregivers as a means to prevent or reduce tobacco or nicotine use in children and adolescents, the child/adolescent directly, or both parent and child/adolescent. We also included studies of interventions aimed at preventing multiple risky behaviors (e.g., smoking, drinking, drug use, sex) or increasing safe or healthy behaviors (e.g., condom use, use of additional services as needed) if the trials reported outcomes of interest separately from other outcomes.

Prevention or cessation studies of all types of tobacco products (e.g., cigarettes, smokeless tobacco, cigars, pipes, e-cigarettes) were eligible for inclusion provided they reported health outcomes (e.g., respiratory, cardiovascular, oral health outcomes), tobacco or nicotine use, or frequency or quantity of alcohol use or use of other psychotropic substances. We included trials of baseline nonsmokers that reported initiation of smoking, trials of baseline smokers that reported cessation of smoking, and trials of combined smokers and nonsmokers that reported smoking prevalence as study outcomes. Outcomes were typically 7-day point prevalence, 30-day point prevalence, or continuous abstinence. See Table 2 for common tobacco use measures. Eligible intervention studies that followed children and adolescents to adulthood and reported adult tobacco and/or e-cigarette use were also included. We excluded trials that reported only perceptions or attitudes about tobacco use or intentions to quit. We also excluded head-to-head studies of one smoking intervention compared with another smoking intervention and required control groups to include no smoking intervention or a minimal smoking intervention (e.g., usual care, attention control, wait list control, no intervention).

Table 2 Common Tobacco Use Measures

Tobacco use term | Common measures and definitions
Susceptible | Defined as the absence of a firm resolve to not smoke in the future. Operationally determined with 3 questions: 1) Do you think you will try a cigarette soon [yes/no]? 2) If one of your best friends were to offer you a cigarette, would you smoke it [definitely yes/probably yes/probably not/definitely not]? 3) Do you think you will be smoking 1 year from now [definitely yes/probably yes/probably not/definitely not]? Youths are susceptible if they answer “yes” to the first question or if they fail to answer “definitely not” to the second or third question, or if they had smoked a cigarette in the past 30 days.
Experimentation | Often measured as ever smoking, even 1 or 2 puffs, or inferred from age at first smoking or youth’s self-description of being an experimenter.
Lifetime (“ever”) use | Ever smoked, even 1 or 2 puffs.
Former use | Ever smoked, but not in the past 30 days (some studies also use ever smoked, but not in the past year).
Current use | Any tobacco/cigarette use (even a puff) during the previous 30 days or ≥1 days in the past 30 days; this is also referred to as “monthly smoking” in some studies. Some studies consider current use to be in the past 7 or 90 days.
Daily smoking | Average of ≥1 cigarettes per day during the previous 30-day period.
Frequent smoking | ≥20 cigarettes in the past 30 days.
Point prevalence abstinence | Not smoking at the point of followup; often measured as the past 7 or 30 days.
Continuous abstinence | No smoking through the followup period, also referred to as “sustained” abstinence.

We excluded most trials conducted in schools because of the interaction of students with each other, the influence of peer relationships, and the inability to replicate these conditions within clinical practice, but included trials that were conducted in school buildings after hours or trials where the school nurse counseled individual students. We also excluded any studies that used e-cigarettes as a cessation or prevention intervention for children and adolescents due to concerns over the harms of using e-cigarettes in this population (e.g., nicotine addiction, harm to the developing brain, nicotine toxicity). We included studies of adolescents up to 18 years of age for cessation interventions and up to 25 years of age for prevention interventions.

## Data Abstraction and Quality Rating

For the included trials, investigators abstracted the following data: study design, setting, population characteristics, intervention characteristics, and results for each outcome. Two investigators independently applied criteria developed by the USPSTF^43^ to rate the quality of each study as good, fair, or poor (Appendix A5). Studies that were rated poor-quality were excluded because results are likely to be biased and highly unreliable.^43^ Discrepancies were resolved through a consensus process.

## Data Synthesis

Self-reported smoking status was the primary outcome. We analyzed trials by whether they targeted smokers, nonsmokers, or both. When able, we calculated relative risks (RRs) using raw data counts and pooled trials using random effects meta-analyses on the natural log scale and back transformed the results; we assessed statistical heterogeneity with the I^2^ statistic. The meta-analyses were adjusted for cluster randomization for six trials using the sample sizes, number of clusters, and an estimated intraclass correlation coefficient (ICC), in accordance with the Cochrane Handbook.^44^ As in the prior USPSTF review,^2,3^ we used an ICC of 0.01. Sample sizes in the text of the report included these adjusted numbers. We pooled studies in meta-analysis and meta-regression using Stata 14.2 (StataCorp, College Station, Texas). In instances where trials had more than one intervention group, we included in meta-analyses the group with the most intensive intervention. We conducted meta-regression to evaluate effects of study-level characteristics on estimates, used backward stepwise meta-regression with a p-value less than or equal to 0.20 for entry into the model, and controlled for the response in the control group. We also conducted stratified analyses of dichotomous variables (e.g., study conducted in the United States vs. Europe) and categorized continuous variables (i.e., duration of trial in weeks, age of participants in years, percent female, percent nonwhite, number of contacts) to explore their role on effect size. Additionally, we performed sensitivity analyses based on intensity of intervention (excluding highly intensive interventions). Analyses were based on data at 12 months postbaseline. When 12-month data were not available, we used end-of-trial data or data nearest to 12 months.

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (“insufficient”, “low”, “moderate”, and “high”) using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and precision of effects.^43^

## Expert Review and Public Comment

The draft Research Plan was posted on the USPSTF Website from June 22 to July 19, 2017. In response to comments, the USPSTF made the following changes to the Research Plan. The USPSTF added pregnant adolescents as an included population, as well as studies in subgroups of adolescents with health problems common to primary care, such as depression and asthma. The USPSTF increased the upper age limit to 25 years for tobacco and nicotine use prevention and changed pharmacotherapy use for tobacco and nicotine cessation in children and adolescents from a contextual question to an included intervention. The USPSTF also included cardiovascular outcomes in addition to respiratory and oral/dental health outcomes.

A draft version of this report was reviewed by content experts (Appendix A6), representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. In addition, the draft report was posted for public comment from June 25, 2019 to July 22, 2019. In response to public comments received, we made minor editorial clarifications to the report that did not include changes to the evidence or to conclusions drawn.