# Chapter 1 Introduction and Background

## Purpose

In 2013, the U.S. Preventive Services Task Force (USPSTF) issued a recommendation that primary care clinicians provide interventions, including education or brief counseling, to prevent initiation of tobacco use among school-aged children and adolescents.^1^ This recommendation was based on a systematic review published in 2012 on the efficacy and harms of primary care interventions to prevent tobacco initiation and encourage tobacco cessation among children and adolescents.^2,3^

The current systematic review will be used by the USPSTF to update its 2013 recommendation. It includes studies conducted since the last review, including literature on preventing and reducing use of newer tobacco products, such as e-cigarettes. In addition, this review extends the inclusion criteria for prevention studies to young adults (defined as ages 19 to 25 years old). Trials of smoking cessation in young adults are covered in a separate USPSTF review on tobacco smoking cessation in adults.^4^

## Condition Background

Tobacco can be consumed in many forms including cigarettes, pipes, cigars, cigarillos, little cigars, bidis (tobacco wrapped in tendu or temburni leaves), smokeless tobacco (including chew, snuff including snus, and dissolvable tobacco in the form of strips, sticks, or lozenges), and through a hookah or waterpipe. Electronic nicotine delivery systems (ENDS) are battery-operated devices that heat a solution usually containing nicotine (usually derived from tobacco) that the user inhales. Effective August 8, 2016 the U.S Food and Drug Administration (FDA) extended its regulatory authority to include ENDS (e.g., e-cigarettes, e-hookah, e-cigars, vape pens, advanced refillable personal vaporizers, and electronic pipes).^5^ However, there is inadequate evidence to conclude that ENDS use increases smoking cessation.^6^

There are multiple types of ENDS: electronic cigarettes (i.e., e-cigarettes or e-cigs) that look like cigarettes and are disposable or partly disposable, vape pens that are rechargeable (most have a universal serial bus [USB] charger) and have customizable looks and tips, Modified Vape Devices (Mods) or box-style mods that allow even greater customization (e.g., wattage, temperature control) and are generally larger and more powerful than the previous two ENDS types, and lastly, small and discreet devices, such as JUULS or Suorin, that look like USB sticks or highlighters and deliver the e-fluid through an insertable pod that is not intended to be refillable. Combustible cigarette cartridges or pods sold in the United States can only contain tobacco or menthol flavors. However, little cigars, or cigarillos, like e-fluid, also come in flavors such as cherry, grape, watermelon, rum, mango, and guava, and are appealing to youth. Although the FDA now is prioritizing enforcement against companies that continue to sell unauthorized e-cigarette cartridges in flavors that appeal to children, other e-fluid flavors that are not cartridge-based including fruit, candy, dessert, and cereal remain available.^7^

In this review, the term “tobacco and nicotine use” indicates the use of any tobacco product including e-cigarettes and the term “smoking” refers to the use of combustible tobacco products (primarily cigarettes in this review). The term e-cigarette refers to all ENDS.

### Prevalence and Burden of Disease/Illness

Tobacco use, not including exposure to second-hand smoke, is the leading cause of preventable death in the United States. An estimated 437,000 premature deaths occur annually among current or former smokers that are attributable to tobacco use, including 82 percent of 158,530 lung cancer deaths and 24 percent of 412,590 heart disease deaths in the United States from 2005 to 2009.^8^ Tobacco’s toll is not only physical, but also economic, as smoking costs the United States approximately $132.5 to 175.9 billion each year in direct medical costs and $156 billion from productivity losses.^8^ While cigarette smoking is still the predominant form of tobacco use in the United States among adults, e-cigarette use has seen a huge increase among adolescents and is now more common among youth than cigarette smoking.^9^ Although the short-term health risks of e-cigarette use may be less than those of cigarettes, the long-term effects of these products on morbidity and mortality are not yet clear.^10^ The 2014 Surgeon General’s Report on smoking concluded that exposure to nicotine during adolescence may have lasting adverse consequences for the still-developing adolescent brain.^8^ These consequences may include long-lasting effects on brain function including cognition.^11,12^ Additionally, one observational study found an adjusted odds ratio (AOR) for myocardial infarction of 1.79 (95% CI, 1.20 to 2.66) in adults who used e-cigarettes daily and 2.72 (95% CI, 2.29 to 3.24) in those who used cigarettes daily.^13^

It is estimated that approximately 1,600 children smoke their first cigarette every day,^14^ and that about 5.6 million adolescents alive today will die prematurely due to a smoking-related illness.^15^ Even though the legal age to purchase tobacco products is now 21 years of age,^16^ over 85 percent of adults who have ever smoked daily smoked their first cigarette by the age of 18; and 98 percent initiated tobacco use by the age of 26.^8^ The Centers for Disease Control and Prevention’s (CDC’s) National Youth Tobacco Survey (NYTS) of middle and high school students found that prevalence of current tobacco and cigarette use, defined as use in the past 30 days, declined between 2011 and 2017. Use of any tobacco product decreased from 24.2 percent to 19.6 percent among high school students^9^ during that time period but increased to 27.1 percent in 2018^17^ and to 31.2% in 2019.^9^ Use of any tobacco product declined from 7.5 percent in 2011 to 5.6 percent among middle school students but increased to 7.2 percent in 2018 and to 12.5 percent in 2019.^9^ This reversal in prevalence of tobacco product use among both middle and high schooler students is alarming. Since 2014, e-cigarettes have been the most commonly used tobacco product among both middle and high school students.^9,17^ Not only is the proportion of students using e-cigarettes increasing, but cigar use is also increasing among high schoolers (7.6% smoking cigars, cigarillos, or little cigars vs. 5.8% smoking cigarettes) and is now as frequent as cigarette use among those in middle school (2.3%).^9,17^ The proportion of students using more than one type of tobacco product is also increasing. In 2017, 9.2 percent of high school and 2.4 percent of middle school students reported using two or more tobacco products in the past 30 days.^18^ In 2019, those percentages were 10.8 and 4.0, respectively.^9^ Use of more than one tobacco product is associated with increased reporting of dependence symptoms.^19^ The prevalence of current use of all tobacco products by school level (i.e., middle school vs. high school) is presented in Table 1.

Table 1 Percentage of Middle and High School Students Who Currently Use^*^ Tobacco, by Product and School Level—National Youth Tobacco Survey, United States, 2019

School level | Any tobacco^†^ % (95% CI) | E-cigarettes % (95% CI) | Cigarettes % (95% CI) | Cigars % (95% CI) | Smokeless tobacco % (95% CI) | Hookah % (95% CI) | Pipe tobacco % (95% CI) | ≥2 Tobacco products % (95% CI)
Middle school | 12.5; (11.2 to 13.9) | 10.5; (9.4 to 11.8) | 2.3; (1.8 to 2.9) | 2.3; (1.9 to 2.9) | 1.8; (1.4 to 2.2) | 1.6; (1.2 to 2.1) | -- | 4.0; (3.3- to 4.7)
High school | 31.2; (29.1 to 33.5) | 27.5; (25.3 to 29.7) | 5.8; (4.6 to 7.3) | 7.6; (6.6 to 8.8) | 4.8; (3.7 to 6.3) | 3.4; (2.7 to 4.2) | 1.1; (0.8 to 1.5) | 10.8; (9.4 to 12.4)

* Current use = use on ≥1 day in the past 30 days. Past 30-day use of e-cigarettes was determined by asking, “During the past 30 days, on how many days did you use e-cigarettes?” Past 30-day use of cigarettes was determined by asking, “During the past 30 days, on how many days did you smoke cigarettes?” Past 30-day use of cigars was determined by asking, “During the past 30 days, on how many days did you smoke cigars, cigarillos, or little cigars?” Past 30-day use of hookah was determined by asking, “During the past 30 days, on how many days did you smoke tobacco in a hookah or waterpipe?” Smokeless tobacco was defined as use of chewing tobacco, snuff, dip, snus, and/or dissolvable tobacco products. Past 30-day use of smokeless tobacco was determined by asking the following question for use of chewing tobacco, snuff, and dip: “During the past 30-days, on how many days did you use chewing tobacco, snuff, or dip?,” and the following question for use of snus and dissolvable tobacco products: “In the past 30 days, which of the following products did you use on at least one day?” Responses from these questions were combined to derive overall smokeless tobacco use. Past 30-day use of pipe tobacco (not hookah) and bidis were determined by asking, “In the past 30 days, which of the following products have you used on at least one day?”"

† Any tobacco use = use of any tobacco product (e-cigarettes, cigarettes, cigars, smokeless tobacco, hookah, pipe tobacco, and/or bidis) on ≥1 day in the past 30 days.

Abbreviations: CI=confidence interval.

These findings are consistent with those of the National Youth Risk Behavior Survey.^20^ Overall, the prevalence of current tobacco use was higher among male (23.4%) than female (15.6%) students, and among those identifying as gay, lesbian, or bisexual (27.2%) than those identifying as heterosexual (19.2%). The prevalence of tobacco use was higher among white high school students (22.4%) compared with Hispanic (16.6%) and black high school students (14.9%). Current use of an e-cigarette was 13.2 percent among high school students, with higher proportions of males reporting use (15.9%) than females (10.5%). Frequent use was reported by 3.3 percent of high school students and 2.4 percent reported daily use.

### Etiology and Natural History

There are five stages for the process of smoking onset and established daily smoking: 1) not susceptible to smoking; 2) susceptible or preparing to smoke; 3) initiation or experimentation (trying the first cigarette); 4) becoming a smoker or irregular smoking; and 5) established or regular smoking (e.g., smoking every day or almost every day).^21,22^ More research is needed on the natural history of e-cigarette use; however, the most commonly cited reasons for use of e-cigarettes among youth (and young adults) were curiosity, flavoring, and low perceived harm relative to regular tobacco products.^23^

Although children as young as age 10 years may be susceptible to smoking, it can take up to 2 years to progress from early experimentation to addiction.^20,24^ While this is the path for most adolescent smokers, some children and adolescents progress rapidly to nicotine dependence, underscoring the need to prevent initial smoking uptake.^25^ Of all high school students who smoke, 45.5 percent have tried to stop smoking in the past year.^26^ However, most will fail and 75 percent will go on to smoke into adulthood.^27^ In fact, of adolescents aged 15 to 18 years who are daily smokers, only 12 percent were former smokers by ages 22 to 25 years.^27^ There is evidence that adolescent e-cigarette users also experience nicotine dependence^28^ and that e-cigarette use increases risk of ever using combustible tobacco cigarettes among youth and young adults.^10^ While the most serious health outcomes associated with adolescent tobacco use typically appear during adulthood, there are immediate adverse health effects among child and adolescent smokers, including increased negative respiratory effects such as impaired lung growth, early onset of lung function decline, respiratory and asthma-related symptoms (e.g., coughing and wheezing), and early abdominal aortic atherosclerosis.^8,27^ Concerns regarding adolescent and young adult use of e-cigarettes include nicotine addiction, harm to the developing brain, progression to combustible tobacco use, nicotine toxicity, inhalation of toxins or carcinogens, and explosions and fires caused by the device.^23^ Use of e-cigarettes can also cause serious harm such as lung injury and death, depending on the substances comprising the e-fluid.^29^

The relationship between e-cigarettes use in children and adolescents and the use of other tobacco products is discussed further in this report as a contextual question.

### Risk Factors

Risk factors for combustible cigarette smoking identified in the 2018 Monitoring the Future cohort of about 44,500 students in the 8^th^, 10^th^, and 12^th^ grade in 392 schools in the United States were being male, white, not college-bound, from a rural area, and having parents with lower levels of education.^30^ Prospective data from two studies conducted in the United Kingdom were compared, the British Cohort Study, which enrolled children in 1970 and the Millenium Cohort Study, which enrolled children in 2001. When the children were 10 to 11 years of age 14.3 percent had smoked in the British cohort, while in the Millenium cohort conducted 31 years later only 2.4 percent of children had smoked.^31^ The decline in children smoking was attributed to increases in maternal education, fewer parents smoking, and fewer childhood friends smoking in the Millenium sample. The children most likely to have smoked by 11 years old in both cohorts were those whose mothers had less education, both parents smoked heavily, and the child had at least one friend who smoked. According to the Department of Health and Human Services, other risk factors associated with tobacco use include being an older adolescent, being male, being white, lacking college plans, having parents who did not attend college, and experiencing highly stressful events (e.g., incarcerated parent, victim of abuse).^32^ Adolescent perceptions of risk of cigarette smoking has increased while the perception of risk associated with e-cigarette use remains very low (only 20% see regular e-cigarette use as a “great risk”).^32^

Evidence also suggests that multiple factors influence a child’s or adolescent’s continuation of smoking and the probability they will become nicotine dependent. Among smokers, pleasant initial sensitivity to tobacco use, parental nicotine dependence, adolescent nicotine dependence, and extensiveness of smoking at the initial interview were the strongest predictors of adolescent nicotine dependence 2 years later.^33^ Other risk factors for continued smoking include behavioral factors such as alcohol use and being with friends who smoke, smoking in early adolescence, and concerns about weight gain with quitting.^32^ Genetics may also play a role.^32^

### Prevention and Cessation Interventions

Interventions to address tobacco use in youth and young adults include behavioral interventions that discourage use of tobacco products, either to prevent initiation of use in those not using (prevention), to encourage quitting the use of tobacco products in those who currently use (cessation), or discourage use of tobacco products in both users and nonusers (combined prevention and cessation). Primary care relevant interventions are those that could be conducted by health care personnel in a primary care setting or that could be referred from primary care (e.g., behavioral counseling). In addition to directly targeting the child or young adult, interventions could target the parent or caregiver (e.g., to stop smoking, to increase communication and support for the child).

The use of pharmacologic adjuncts as an aid in cessation for adolescent smokers is also of interest, given the positive effects of these therapies in adults.^6,34–36^ However, there are currently no medications approved for tobacco cessation in adolescents and children. The FDA instructs adolescents to see their doctors if they are interested in nicotine replacement therapy (NRT).^37^ However, there is currently no data on physician prescribing practices of any pharmacotherapy in children and adolescents for decreasing or stopping the use of tobacco products. Because the safety and effectiveness of these drugs in pediatric patients have not been established, bupropion hydrochloride (known as Zyban^®^), an aminoketone antidepressant, and varenicline tartrate (known as Chantix^®^) are not FDA approved for smoking cessation for people younger than age 18 years.

### Current Clinical Practice

Many children and adolescents are not asked about the use of tobacco products when they visit their doctor. In a study based on data from the 2013 National Survey on Drug Use and Health, less than half of adolescents who visited a health care provider in the past 12 months reported being asked about tobacco use.^38^ Of those that reported past 30-day use, only 26.3 percent were screened and advised to quit. Adolescents who were screened by their physician were predominantly female (56.6%), white (60.1%), older (83.0%), and covered by private health insurance (63.8%). Hispanic adolescents were significantly less likely to receive advice to quit from their physician compared with non-Hispanic white adolescents.

In a study using NYTS data, the overall prevalence of tobacco screening was 32.2 percent in 2011, 37.9 percent in 2013, and 36.6 percent in 2015 among children and adolescents in grades 6 through 12 who visited a physician within the past year.^39^ The largest relative change from 2011 to 2015 was among females and blacks, with no significant increase among males, younger students aged 9 to 14 years, and e-cigarette users. Older students were more likely than younger students to be asked about tobacco use and students identifying as a racial or ethnic minority were less likely than non-Hispanic whites to be asked. Current cigarette only users, e-cigarette only users, and dual users were more likely to be asked about tobacco use than noncurrent users. Despite increased screening for tobacco use, the study found low and declining rates of advice to avoid or quit tobacco use among this population. The overall prevalence of being advised not to use tobacco decreased from 31.4 percent in 2011 to 30.1 percent in 2013 and 26.9 percent in 2015 with a relative decrease of 14.3 percent. Males and older students were more likely to be advised not to use tobacco, whereas Hispanics were less likely than whites to be so advised. Current cigarette-only users and dual users of cigarettes and e-cigarettes had higher odds of being encouraged not to use tobacco than noncurrent users. No significant difference was found between e-cigarette only users and those who reported no current tobacco use.

### Recommendations of Other Groups

In 2015, the American Academy of Pediatrics (AAP) published a policy statement on clinical practice policy to protect children from tobacco, nicotine, and tobacco smoke.^40^ The AAP recommends that pediatricians counsel parents and caregivers who use tobacco about the importance of and strategies for stopping tobacco product use, provide referral for additional tobacco dependence treatment resources and consider recommending or prescribing tobacco dependence treatment medication for parents and caregivers who smoke (Recommendation strength: Strong). Further, it was recommended that pediatricians provide brief counseling to all children and adolescents to prevent tobacco use initiation, and that all teenagers be screened for tobacco and nicotine use (Recommendation strength: Strong). For adolescents who want to stop using tobacco, it was recommended that tobacco dependence treatment and/or referral be offered (Recommendation strength: Strong), and that tobacco dependence pharmacotherapy can be considered for moderate to severely tobacco-dependent adolescents (Recommendation strength: Option). E-cigarettes were not recommended as a treatment for tobacco dependence (Recommendation strength: Strong).

A separate AAP policy statement was also published on e-cigarette use.^41^ The policy statement included recommendations that pediatricians screen children and adolescents, parents, and caregivers for e-cigarette use, and provide prevention counseling for children and adolescents. Further, AAP recommended that parents, caregivers, and adolescents who use e-cigarette should be offered or referred for tobacco cessation counseling and FDA-approved tobacco dependence pharmacotherapies appropriate to their level of addiction and readiness to change and, again, that e-cigarette was not recommended as a treatment for tobacco dependence.

In a 2014 position paper, the American Academy of Family Physicians encouraged screening of children and adolescents for tobacco and nicotine use.^42^ For all patients, family physicians are encouraged to use the five A’s: Ask, Assess, Advise, Assist, and Arrange. Recommended interventions included referral; provision of self-help materials; provision of brief, intermediate, or intensive counseling (motivational interviewing); pharmacotherapy; NRT; group visits; or combinations of interventions.^42^

## Previous USPSTF Recommendation

In 2013, the USPSTF updated its 2003 recommendation from an I (insufficient evidence) statement to a B recommendation that primary care clinicians provide interventions, including education or brief counseling, to prevent initiation of tobacco use among school-aged children and adolescents.^1^ This was based on moderate certainty that primary care-relevant behavioral interventions can prevent tobacco use in children and adolescents with moderate net benefit.