# Appendix C Supplemental Analysis Tables

## Appendix C1 Meta-Regression Analysis

Study-level characteristico | Prevention; P-value | Cessation; P-value | Combination; P-value
Univariate analysis
Trial conducted in United States vs. Europe | 0.542 | 0.936 | *
Trial targets smoking vs. multiple behaviors | 0.752 | 0.663 | 0.951
Trial targets parent | 0.883 | 0.845 | 0.739
Trial targets youth | 0.703 | 0.929 | 0.301
Role of primary care | 0.094^†^ | 0.886 | 0.239
Use of single vs. multimodal intervention | 0.046 ^†^ | 0.656 | 0.061^†^
Use of print materials in intervention | 0.887 | 0.118^†^ | 0.644
Use of face-to-face counseling | 0.290 | 0.961 | 0.241
Use of telephone counseling | 0.750 | 0.452 | 0.081^†^
Use of computer counseling | 0.535 | 0.206 | 0.180^†^
Use of motivational interviewing | 0.684 | 0.672 | 0.672
Duration of intervention | 0.198^†^ | 0.417 | 0.047^†^
Year of trial publication | 0.140^†^ | 0.204 | 0.829
Prevention or cessation-only vs. combined trial | 0.535 | 0.868 | NA
Outcome 30-day point prevalence vs. NR or one puff | 0.200^†^ | 0.694 | 0.892
NonWhite race | 0.598 | 0.887 | 0.746
Number of contacts (visits, telephone calls, mailings) | 0.232 | 0.849 | 0.436
Includes adjustment for proportion smoking in control group
Trial conducted in United States vs. Europe | 0.312 | 0.903 | 0.059^†^
Trial targets smoking vs. multiple behaviors | 0.478 | 0.547 | 0.881
Trial targets parent | 0.734 | 0.816 | 0.799
Trial targets youth | 0.439 | 0.955 | 0.399
Role of primary care | 0.186^†^ | 0.950 | 0.306
Use of single vs. multimodal intervention | 0.044 ^†^ | 0.684 | *
Use of print materials in intervention | 0.793 | 0.120 | 0.058^†^
Use of face-to-face counseling | 0.375 | 0.955 | 0.311
Use of telephone counseling | 0.712 | 0.471 | 0.075^†^
Use of computer counseling | 0.739 | 0.186^†^ | 0.182
Use of motivational interviewing | 0.621 | 0.716 | 0.684
Duration of intervention | 0.415 | 0.536 | 0.053^†^
Year of trial publication | 0.070^†^ | 0.176^†^ | 0.722
Prevention-only vs. combined trial | 0.733 | 0.774 | NA
Outcome 30-day point prevalence vs. NR or one puff | 0.486 | 0.431 | 0.715
NonWhite race | 0.603 | 0.919 | 0.831
Number of contacts (visits, telephone calls, mailings) | 0.032 ^†^ | 0.818 | 0.126^†^

* Model failed to converge

† Entered into backwards stepwise regression model

Abbreviations: NA=not applicable; NR=not reported.

## Appendix C2 Stratified Effect Estimates for Smoking Prevention Interventions

Group 1 vs. group 2 | k=# Studies; n=# Youth; RR (95% CI) for Group 1 | k=# Studies; n=# Youth; RR (95% CI) for Group 2 | Group 1 vs. group 2; p value
Prevention-only study vs. Combined study | k=8, n=17,895; 0.83 (0.68 to 1.00) | k=5, n=3,805; 0.77 (0.64 to 0.91) | p>0.05
U.S. studies vs. European studies | k=10; n=17,214; 0.83 (0.74 to 0.95) | k=3; n=4,486; 0.71 (0.53 to 0.96) | p>0.05
Intervention focused on smoking alone vs. Intervention included other behaviors (e.g., alcohol, sex) | k=10; n=20,330; 0.80 (0.69 to 0.93) | k=3; n=1,370; 0.83 (0.65 to 1.07) | p>0.05
Targeted parent vs. Did not target parent | k=6; n=7,168; 0.81 (0.66 to 0.99) | k=7; n=14,532; 0.82 (0.71 to 0.92) | p>0.05
Targeted youth vs. Did not target youth | k=11; n=20,360; 0.80 (0.69 to 0.92) | k=2; n=1,340; 0.84 (0.64 to 1.09) | p>0.05
Primary care had active role vs. Primary care had no role or recruitment only | k=4; n=10,179; 0.87 (0.74 to 1.02) | k=8; n=7,958; 0.73 (0.62 to 0.86) | p>0.05
Single mode of intervention delivery vs. Intervention delivered by multiple methods | k=5; n=6,239; 0.66 (0.53 to 0.82) | k=8; n=15,461; 0.90 (0.82 to 0.99) | p<0.05
Intervention included print materials vs. Intervention included no print materials | k=8; n=18,733; 0.81 (0.70 to 0.94) | k=5, n=2,967; 0.78 (0.53 to 1.15) | p>0.05
Intervention included face-to-face contact vs. Intervention included no face-to-face contact | k=6; n=10,751; 0.91 (0.81 to 1.01) | k=7; n=10,979; 0.75 (0.64 to 0.88) | p>0.05
Intervention included telephone contact vs. Intervention included no telephone contact | k=6; n=7,501; 0.82 (0.69 to 0.96) | k=7; n=14,199; 0.77 (0.62 to 0.97) | p>0.05
Intervention included use of computer vs. Intervention did not use a computer | k=3, n=4,076; 0.76 (0.60 to 0.97) | k=10, n=17,624; 0.81 (0.70 to 0.95) | p>0.05
Intervention included motivational interviewing vs. Intervention included no motivational interviewing | k=5; n=3,489; 0.77 (0.62 to 0.95) | k=8; n=18,211; 0.82 (0.69 to 0.97) | p>0.05
Duration of intervention at least 12 months vs. Duration of intervention shorter than 12 months | k=7; n=19,155; 0.79 (0.66 to 0.95) | k=6; n=2,545; 0.82 (0.66 to 1.02) | p>0.05
Proportion of females <53% vs. Proportion of females ≥53% | k=6; n=6,984; 0.89 (0.72 to 1.09) | k=7; n=14,716; 0.76 (0.63 to 0.91) | p>0.05
Age of participants < 14 years vs. Age of participants ≥ 14 years | k=7; n=8,930; 0.80 (0.67 to 0.96) | k=5; n=10,558; 0.90 (0.80 to 1.00) | p>0.05
Outcome 30-day point prevalence vs. Outcome even one puff | k=4; n=13,235; 0.90 (0.78 to 1.04) | k=4; n=3,442; 0.74 (0.60 to 0.90) | p>0.05
Nonwhite enrollment > 20% vs. Nonwhite enrollment ≤ 20% | k=6; n=11,662; 0.82 (0.70 to 0.97) | k=4; n=3,751; 0.65 (0.41 to 1.01) | p>0.05
Number of contacts (e.g., visits, phone calls, mailings) ≤ 6 vs. Number of contacts > 6 | k=8, n=11,210; 0.74 (0.64 to 0.86) | k=5; n=10,490; 0.92 (0.83 to 1.03) | p>0.05

Abbreviations: CI=confidence interval; k=number of studies; n=number of participants; RR=relative risk.

## Appendix C3 Stratified Effect Estimates for Smoking Cessation Interventions

Group 1 vs. group 2 | k=# Studies; n=# Youth; RR (95% CI) for Group 1 | k=# Studies; n=# Youth; RR (95% CI) for Group 2 | Group 1 vs. group 2; p value
Cessation-only study vs. Combined study | k=4, n=1,566; 0.97 (0.93 to 1.01) | k=5, n=950; 0.98 (0.89 to 1.08) | p>0.05
U.S. studies vs. European studies | k=8; n=1,974; 0.97 (0.91 to 1.02) | k=1; n=542; 0.97 (0.91 to 1.02) | p>0.05
Intervention focused on smoking alone vs. Intervention included other behaviors (e.g., alcohol, sex) | k=7; n=2,339; 0.96 (0.92 to 1.01) | k=2; n=177; 1.02 (0.85 to 1.24 | p>0.05
Targeted parent vs. Did not target parent | k=2; n=217; 0.98 (0.91 to 1.05) | k=7; n=2,299; 0.96 (0.91 to 1.02) | p>0.05
Targeted youth vs. Did not target parent | k=8; n=2,431; 0.97 (0.93 to 1.01) | k=1, n=85; 0.95 (0.67 to 1.34) | p>0.05
Primary care had active role vs. Primary care had no role or recruitment only | k=3; n=773; 0.97 (0.84 to 1.11) | k=6; n=1,743; 0.97 (0.94 to 1.01) | p>0.05
Single mode of intervention delivery vs. Intervention delivered by multiple methods | k=2; n=1,366; 0.98 (0.94 to 1.02) | k=7; n=1,150; 0.96 (0.89 to 1.03) | p>0.05
Intervention included print materials vs. Intervention included no print materials | k=4; n=874; 0.91 (0.83 to 1.00) | k=5, n=1,642; 0.99 (0.95 to 1.03) | p>0.05
Intervention included face-to-face contact vs. Intervention included no face-to-face contact | k=7; n=1,889; 0.96 (0.91 to 1.02) | k=2; n=627; 0.97 (0.91 to 1.03) | p>0.05
Intervention included telephone contact vs. Intervention included no telephone contact | k=7; n=1,600; 0.96 (0.90 to 1.01) | k=2; n=916; 0.99 (0.94 to 1.05) | p>0.05
Intervention included use of computer vs. Intervention did not use a computer | k=2; n=681; 0.94 (0.79 to 1.11) | k=7; n=1,835; 0.98 (0.94 to 1.02) | p>0.05
Intervention included motivational interviewing vs. Intervention included no motivational interviewing | k=6; n=1,065; 0.95 (0.88 to 1.04) | k=3; n=1,451; 0.98 (0.94 to 1.02) | p>0.05
Duration of intervention at least 20 weeks vs. Duration of intervention shorter than 20 weeks | k=4; n=1,315; 0.98 (0.87 to 1.10) | k=5; n=1,201; 0.97 (0.93 to 1.01) | p>0.05
Proportion of females <53% vs. Proportion of females ≥53% | k=5; n=1,707; 0.99 (0.95 to 1.02) | k=4; n=809; 0.90 (0.80 to 1.01) | p>0.05
Age of participants < 16 years vs. Age of participants ≥ 16 years | k=3; n=798; 0.96 (0.83 to 1.10) | k=6; n=1,718; 0.97 (0.94 to 1.01) | p>0.05
Outcome 30-day point prevalence vs. Outcome 7-day point prevalence | k=4; n=1,622; 0.97 (0.90 to 1.05) | k=3, n=742; 0.95 (0.88 to 1.02) | p>0.05
Nonwhite enrollment > 20% vs. Nonwhite enrollment ≤ 20% | k=5; n=966; 0.93 (0.85 to 1.01) | k=3; n=1,008; 1.00 (0.95 to 1.05) | p>0.05
Number of contacts (e.g., visits, phone calls, mailings) <5 vs. Number of contacts ≥ 5 | k=6, n=1,790; 0.95 (0.89 to 1.01) | k=3, n=726; 0.99 (0.94 to 1.04) | p>0.05

Abbreviations: CI=confidence interval; k=number of studies; n=number of participants; RR=relative risk.

## Appendix C4 Stratified Effect Estimates for Primary Smoking Prevention and Cessation Interventions

Group 1 vs. Group 2 | k=# Studies; n=# Youth; RR (95% CI) for Group 1 | k=# Studies; n=# Youth; RR (95% CI) for Group 2 | Group 1 vs. Group 2; p value
U.S. studies vs. European studies | k=7; n=8,201; 0.88 (0.81 to 0.95) | k=2; n=3,270; 1.01 (0.92 to 1.11) | p>0.05
Intervention focused on smoking alone vs. Intervention included other behaviors (e.g., alcohol, sex) | k=4; n=5,451; 0.93 (0.81 to 1.08) | k=5; n=-6,020; 0.94 (0.84 to 1.04) | p>0.05
Targeted parent vs. Did not target parent | k=3; n=4,359; 0.93 (0.75 to 1.16) | k=6; n=7,112; 0.94 (0.86 to 1.03) | p>0.05
Targeted youth vs. Did not target youth | K=7; n=10,182; 0.95 (0.88 to 1.03) | k=2; n=1,289; 0.95 (0.53 to 1.69) | p>0.05
Primary care had active role vs. Primary care had no role or recruitment only | k=7; n=10,182; 0.95 (0.88 to 1.03) | k=2; n=1,289; 0.95 (0.53 to 1.69) | p>0.05
Single mode of intervention delivery vs. Intervention delivered by multiple methods | k=2; n=1,246; 0.99 (0.89 to 1.10) | k=7; n=10,225; 0.91 (0.83 to 1.00) | p>0.05
Intervention included print materials vs. Intervention included no print materials | k=3; n=6,729; 0.87 (0.78 to 0.97) | k=6, n=4,742; 0.99 (0.91 to 1.08) | p>0.05
Intervention included face-to-face contact vs. Intervention included no face-to-face contact | k=8; n=11,222; 0.96 (0.88 to 1.03) | k=1; n=1,135; 0.84 (0.72 to 0.97) | p>0.05
Intervention included telephone contact vs. Intervention included no telephone contact | k=5; n=8,619; 0.88 (0.80 to 0.96) | k=4; n=2,852; 1.00 (0.91 to 1.09) | p>0.05
Intervention included use of computer Intervention did not use a computer | k=2; n=2,995; 0.84 (0.74 to 0.96) | k=7; n=8,476; 0.96 (0.88 to 1.05) | p>0.05
Intervention included motivational interviewing vs. Intervention included no motivational interviewing | k=5; n=4,934; 0.93 (0.85 to 1.01) | k=4; n=6,537; 0.98 (0.81 to 1.17) | p>0.05
Duration of intervention longer than 12 months vs. Duration of intervention 12 months or less | k=3; n=6,340; 1.01 (0.93 to 1.11) | k=6; n=5,131; 0.86 (0.79 to 0.94) | p>0.05
Proportion of females <53% vs. Proportion of females ≥53% | k=4; n=6,663; 0.97 (0.84 to 1.11) | k=5; n=4,808; 0.91 (0.82 to 1.02) | p>0.05
Age of participants < 14 years Age of participants ≥ 14 years | k=4; n=6,537; 0.98 (0.81 to 1.17) | k=5; n=4,934; 0.93 (0.83 to 1.03) | p>0.05
Outcome 30-day point prevalence vs. Outcome even one puff or not reported | k=4; n=4,050; 0.94 (0.83 to 1.06) | k=5; n=7,421; 0.93 (0.82 to 1.06) | p>0.05
Nonwhite enrollment > 20% vs. Nonwhite enrollment ≤ 20% | k=4; n=4,284; 0.84 (0.77 to 0.93) | k=3; n=1,939; 0.98 (0.90 to 1.08) | p>0.05
Number of contacts (e.g., visits, phone calls, mailings) <6 vs. Number of contacts ≥ 6 | k=5; n=5,894; 0.91 (0.79 to 1.05) | k=4; n=5,577; 0.95 (0.90 to 1.05) | p>0.05

Abbreviations: CI=confidence interval; k=number of studies; n=number of participants; RR=relative risk.